# Appendix C

## Figure 1 Counseling to Promote Physical Activity Analytic Framework

[image]

Arrow 1: Does counseling children, adolescents, adults, and seniors in primary care settings to incorporate physical activity into their daily routines improve sedentary or maintain active physical levels?

Arrow 2: What are the adverse effects of counseling patients to increase physical activity?

Arrow 3: How can primary care clinicians identify patients who would benefit from physical activity counseling (in appendix)?

Table 1. Comparison of Surgeon General's report on PA with 2nd Guide to Clinical Prevemtive ServicesAppendix C

Disease | Claim | Evidence | Results | Dose response | 2nd Guide to Preventive Services
Cardiovascular Disease (CVD) | Low levels of physical activity increase risk of CVD death | 5/7 large population-based cohort studies with FU at 4-26 years. Reported between 1979 and 1996. Studies adjusted for other CVD risks. | Comparing sedentary or low activity to active. RR, 1.28-1.84. | 4 of 7 cohort studies reported inverse relationship | Not reported.
Cardiovascular Disease (CVD) | Low levels of fitness increase risk of CVD death | 5/5 large population-based cohort studies with FU at 5-16 years. Reported between 1988 and 1995 | Unfit compared with fit. RR, 2.5-9.2 for men and women. | 4 of 5 cohort studies reported inverse relationship | Not reported.
Coronary Heart Disease (CHD) | Physically active people have lower risk for coronary events. | 19/22 large population-based cohort studies with FU at 6-26 years. | Comparing sedentary or low activity to active. RR, 1.2 to 2.8. | 11/17 cohort studies reported inverse linear relationship; 3 studies reported "U" relationship. Protective effect reduced for vigorous exercise. | Agreement. 3 additional prospective cohort studies adjusted for other CHD risks not in the Surgeon General's report (1987-1993) reported increased risk for sedentary. 1990 metanalysis listed RR of death from CHD for sedentary adults at 1.9 (95% CI, 1.6-2.2).
Coronary Heart Disease (CHD) | Low levels of fitness increase the risk of coronary events. | 5/ 5 large population-based cohort studies adjusted for other CHD risks had FU at 4-20 years. Reported between 1983 and 1992. No studies of women. | Comparing low fit to high fit. RR, 1.2-1.6. | 4 of 4 cohort studies reported inverse relationship | Not reported.
Hypertension | Physical inactivity is associated with increased risk of later developing hypertension in men and women. | 5 of 5 large population-based cohort studies adjusted for other hypertension risk factors had FU at 2 to 14 years. Reported between 1968 and 1991. 1 of 1 RCT (n=201) that combined exercise with diet. | Comparing sedentary to active. RR, 1.3-2.4 | 3 of 3 cohort studies, 1 RCT reported inverse relationship | Agreement. One additional RCT that combined exercise with weight loss.
Colon Cancer | Physical inactivity is associated with increased risk of later developing colon cancer in men and women. | 6 of 9 case control studies and 3 of 3 large cohort studies adjusted for other colon risk factors. Reported between 1988 and 1995. | Comparing sedentary to active. RR, for men 1.4-1.9, significant in 6/9 case control and cohort studies. RR for women 2.0-2.5 in 3/4 case control studies. | 3 of 4 cohort studies reported inverse relationship | Not reported
Diabetes | Physical activity protects against development of NIDDM. | 3 of 3 large cohort studies with FU 5-8 years Reported in 1991 and 1992. | Comparing sedentary to patients active at least once per week. RR, .71-.94. | 2 of 3 cohort studies reported inverse relationship | Agreement. Same 3 cohort studies.
Diabetes | Physical activity may also protect against development of NIDDM in patients with impaired glucose tolerance. | 2 of 2 controlled trials with FU 5-6 years. Reported in 1991 and 1995. | Comparing sedentary to active. RR, 1.9-2.0. | | Not reported.
Osteoporosis | Physical activity enhances the effect of estrogen replacement therapy to decrease bone loss. It is not clear whether physical activity alone also decreases bone loss. | 4 cross-sectional reported in 1984-1994. 1 longitudinal RCT in 1987 and 1 longitudinal controlled trial in 1988. | The 4 cross-sectional studies demonstrated that bone mineral density in postmenopausal women is related to physical activity. The 2 longitudinal studies found that bone mineral density was increased in women who exercised. | | Agreement.
Osteoporosis | Physical activity, including resistance exercise appears to protect against falling and fractures in elderly. | 2 of 3 cohort studies reported 1989-1995. 1 of 2 case-control studies reported in 1993 - 1994. | Cohort studies reported that active women had lower risks of hip fractures than sedentary. 1 of 2 case-control studies demonstrated that moderately active women had lower risks of hip fractures than sedentary women.
Obesity | BMI is lower among active people than sedentary people. | 9 cross-sectional studies reported between 1983-1996. 3 of 4 cohort studies reported between 1992 and 1996. | All 9 cross-sectional studies reported a relationship between BMI and activity. The relationship was also found in 3 of 4 cohort studies, particularly for women. | | Agreement, 2 additional prospective cohort studies
Mental Health (Depression) | Physical activity may protect against development of depression although further research is needed. | 3 of 4 large population-based cohort studies with FU 5-27 years. Reported in 1988-1994. Baseline measures of the same cohort studies showed inverse relationship (3 of 3) | OR of sedentary compared to active: for non-depressed women: 1.7-1.9 and men: 1.76; for depressed men 12.9; RR comparing sedentary to very active (3+hours/week) men 1.4, nonsig for depressed women | 2 of 3 cohort studies reported an inverse relationship. | Agreement in claim but not strong enough for a recommendation. Contained same 1988 cohort study.

Note: CI indicates confidence interval; FU, follow-up; NIDDM, Non-Insulin Dependent Diabetes Mellitus; OR, odds ratio; RR, relative risk.

Table 2. Poor TrialsAppendix C

Study | Reasons for poor rating | Result
Bull, 1998^ 1 ^ | Maintenance of comparison groups questioned. Nonrandomized trial design (same providers for control and intervention patients based on days of the week during 3 week recruitment) had high potential for contamination. Fair to poor follow-up (70% at 1 month, 57% at 6 months, 56% at 12 months). | Increased proportion of active intervention patients (40%) at 1 month compared with 31% of control patients (a difference of 9%; CI, 7% to 11%). Increased proportion of active intervention patients (38%) at 6 months compared with 30% of control patients (a difference of 8%; CI, 6% to 10%). No difference in the active proportion at 1 year, 36% intervention patients compared with 31% control patients (a difference of 5%; CI, 3.5% to 6.5%).
Calfas, 1996^ 3 ^ | Establishment and maintenance of comparison groups questioned. Nonrandomized trial design with intervention physicians selected based on personal interest in physical activity. Suggests that control physicians had less interest in physical activity and may have had lower than expected usual care baseline counseling rates. Trial lost 17% of intervention physicians and 30% of control physicians during study. | Increased proportion of intervention patients (52%) achieved PACE active stage (meets HP) at 4-6 weeks compared with 12% of control patients (a difference of 40%; CI, 33% to 47%).
Elder, 1995^ 5 ^ | High loss to follow-up. 45% of intervention patients responded at 4 years compared with 44% of control patients. Nonresponders were excluded from the analysis. | Intervention patients reported an increased metabolic rate of 432 at 4 years, compared with 388 for control patients (P=.0006).
Graham-clarke, 1994^ 7 ^ | Unclear if randomization was adequate since a greater proportion of intervention patients (53%) were at "intended to change" stage compared with control patients (37%), a difference of 16%; CI, 13% to 19%. Achieved poor follow-up, 44% at 4 months and 50% at 12 months. Paper didn't give sufficient results to abstract needed results relative to randomization. | Not reported based on randomization.
Kreuter, 2000^ 9 ^ | Unclear if randomization was adequate since no baseline demographics were provided. The analysis made no mention of an intent-to-treat analysis. Used a new PA tool with no validity analysis reported. | Intervention patients who received physician advice to exercise prior to receiving education materials were more likely to change behavior (OR, 1.51; CI, .95 to 2.4) than patients who received no advice.

Note: CI indicates 95% confidence interval; HP, Healthy People 2010 recommendation: Moderate activity 30 min./5 times/week (or) vigorous activity 20 min./3 times/week; PA, physical activity; PACE, Physician-based Assessment and Counseling for Exercise.

Table 3. Linkage summaryAppendix C

Link | Critical Path | Question | Findings | Evidence
1 (Fair) | Yes | Does counseling children, adolescents, adults and seniors in primary care settings improve and/or maintain PA levels? | 1 of 3 trials reported increased PA short term (less than 6 months) in adults and seniors counseled to increase PA compared with usual care. 2 of 6 trials reported increased PA long term (6 months and longer). | 5 RCTS (1 good and 4 fair) and 1 fair nonrandomized controlled trial had usual care comparisons. Most fair trials had 1 or more of the following quality limitations: counseling interventions not defined; follow-up less than 80%; differing baseline activity levels between groups; or excluded nonresponders.
1 (Fair) | Yes | Does counseling children, adolescents, adults and seniors in primary care settings improve and/or maintain PA levels? | Information about counseling children and/or parents in primary care is very limited. One fair RCT employed the PACE methodology to adolescents and found an effect at 4 months for youth who set goals to increase either moderate or vigorous behavior. This trial had no usual care comparison. | No trials in primary care for adolescents or children had a usual care comparison.
2 | No | What are the adverse effects of counseling patients to increase PA? | In one good RCT, 30% of adults (ages 35-75) in stable health experienced musculoskeletal injuries annually. Patients with a finding during a submax test or with pre-existing heart disease were excluded. 1% to 4% of patients were hospitalized annually for a potential cardiac event. Since there was no usual care condition, it is difficult to know how much the interventions contributed to the adverse effects. | 1 good RCT with no usual care comparison.
3 | Yes | How can primary care clinicians identify patients who would benefit from PA counseling? | Several tools are reported in the counseling efficacy studies, PACE, PASE, CAQ, 7-day recall (PAR). This evidence was not systematically reviewed and is summarized in the appendix. | Several cross-sectional studies provide test-retest and validity testing for these self-report tools. However, most counseling efficacy studies provide no direct measure of PA.

Note: CAQ indicates College Alumni Questionnaire; PA, physical activity; PACE, Physician-based Assessment and Counseling for Exercise; PAR, 7-day Physical Activity Recall; PASE, Physical Activity Scale for the Elderly; RCT, randomized controlled trial.