# Appendix B: Assessment

## How can primary care clinicians identify patients who would benefit from PA counseling (Arrow 3)?

For PA assessment and counseling to be well accepted in primary care, clinicians need a feasible, valid, and reliable way to assess whether a patient is sedentary or physically active. In most practices, physicians have limited time and resources for assessment and counseling.

In most of the counseling efficacy studies, patients were assessed with a brief self-report tool that had previously been tested or that borrowed questions from larger validated health-assessment tools (1-7). In some studies, patients were assessed during a pre-visit phone call by trained interviewers or research staff, (2, 3, 8) were mailed the questionnaire prior to the visit, and were then evaluated by the physician (4) or during a home visit (5). In several studies, a nurse or research assistant conducted a baseline assessment at the office and placed it on the medical chart for the physician's visit (1, 3, 4, 6, 9-11). In trials that used the PACE (Physician-based Assessment and Counseling for Exercise) protocol (2, 6) a nurse or research assistant scored the PACE assessment, which led directly to a stage-based PA prescription. The physician and patient together then reviewed and refined the PA prescription during the visit.

The tools used for assessment in the counseling efficacy studies are described in Table 2. This table lists the tools and which studies used them, and then describes the PA questions and the scoring. For example, two trials (3, 6) used the Physical Activity Scale for the Elderly (PASE) tool, an 11-item tool specially designed for older adults. Respondents are asked to recall a variety of activities over the past seven days in a series of questions -- eg, "Over the past 7 days, how often did you walk outside your home or yard for any reason?" Respondents typically take 5 minutes to complete the questionnaire (12).

Another tool used with adults, PACE, begins with definitions of moderate and vigorous activities. From 11 graded statements, the participants select the one statement that best describes their current PA and their current interest in increasing PA (2, 12). The selected statement is used to categorize the participants into 1 of 3 stages: "precontemplative (not active and not intending to become active), contemplative (little or no activity, but intending to become active), and active (physically active on a regular basis)"(2).

To measure the accuracy of self-report assessment tools, some investigators have compared the results of self-report with other, more direct measures such as electronic pedometers (2, 12-15). In these studies the pedometer measure is considered the gold standard measure of PA. An electronic pedometer measures the vertical acceleration (up and down changes in the rate of movement) of the body. The pedometer counts these changes, which typically occur each time the foot contacts the ground. To measure the horizontal distance walked, the investigator measures several stride lengths to obtain an average (13). Accelerations due to nonwalking activity -- eg, climbing stairs -- are dropped. For example, when walking distance was measured using the College Alumni Questionnaire (CAQ) and with a pedometer, both men and women under-reported their walking (13). On average, the men reported walking 1.56 km per day even though the pedometer measured 4.02 km per day. Similarly, women reported 1.30 km per day and the pedometer measured 4.32 km per day. The correlation between the CAQ and the pedometer measure was stronger in women (correlation coefficient (r)=0.48, P=0.001) than in men (r=0.35, P=0.02). In another study that compared an activity counter with CAQ, the correlation coefficient was (r=0.23, P<.05) for 79 postmenopausal women (15). The correlation may improve as patients are more active. A previous study (14) reported a correlation coefficient of (r=0.33) when only the intervention women walking 7-9 miles per week were considered. When compared to daily logs of activities, the CAQ achieved a correlation coefficient of (r=0.81, P<0.01) (16).

A similar evaluation has been performed with the PASE tool (12). The PASE score correlated with a pedometer (r=0.79) for all types of activity. When compared to an activity diary, the PASE scores and the diary were correlated, r=0.85. Overall, these self-report tools appear to be only moderately valid in identifying sedentary patients.

An assessment tool should not only be valid but also reliable. The test-retest reliability or repeatability of the CAQ and 7-day recall are mixed, depending on the intensity of the activity (17). With 4 weeks between measures, the CAQ achieved correlation coefficients ranging from r=0.68 for moderate activity, r=0.60 for very hard activity, to r=0.72 for vigorous activity. With 2 weeks between measures, the 7-day recall achieved correlation coefficients of r=0.48-0.65 for light activity, r=0.08-0.46 for moderate activity, r=0.31 for hard activity, and r=0.61-0.94 for vigorous activity. It appears that the repeatability of these tools may be related to the type and intensity level of the activity being measured.

When 7-12 weeks separated the measures, the correlation coefficient fell to r=0.52 (17). However, this may reflect an inconsistent PA from week to week, not poor retest reliability. Use of correlation coefficients to test repeatability has a downside. If a relatively sedentary population is sampled, the respondents will reply with "no activity" on both the baseline and retest evaluation. This may inflate the overall repeatability of the measure (17).

A further precaution required when assessing physical activity is to screen for medical conditions that might limit safe PA. Investigators using the PACE assessment forms also use a form (the "Physical Activity Readiness Questionnaire," PAR-Q) (6, 18) to identify patients who should postpone starting a PA program until after consulting their physician (2) -- this on the assumption that physicians may have additional guidelines for their patients to ensure safe PA.

It is possible some patients may feel emotional harm (discouragement) if they receive negative feedback and no follow-up advice or assistance (19). Thus, assessment without intent (and resources) to intervene with all patients might cause harm. Also, some patients who receive favorable feedback might develop a false sense of safety (19). However, none of the efficacy studies examined these potential adverse effects of assessment.

Another possible adverse effect relates to time and money. Assessment takes patient and staff time. Most of the counseling efficacy studies had additional staffing to complete the assessments (2, 3, 5, 7, 20, 21). One RCT(3) documented that a research staff member spent 5.8 minutes assessing each patient using the PASE assessment tool. Another RCT had a financial incentive to increase the assessment compliance rate (21). The medical assistants were given a dollar for each baseline assessment form the patients completed. This strategy increased the completion rate of the forms (and enrollment in the intervention). Some studies described office support systems that assisted practices with assessing and tracking patients (2, 20, 22). Health care systems also provided training and materials for implementing the 5 A's (22).

In summary, self-report PA tools appear to be only moderately valid and reasonably reliable (15) in identifying sedentary patients. However, they are the best hope for feasibly identifying patients in need of PA intervention. More research is needed to avoid misclassifying patients (19).

## References

1 Bull FC, Jamrozik K Advice on exercise from a family physician can help sedentary patients to become active Am J Prev Med 1998 15(2):85 94 9713663
2 Calfas KJ, Long BJ, Sallis JF, Wooten WJ, Pratt M, Patrick K A controlled trial of physician counseling to promote the adoption of physical activity Prev Med 1996 25(3):225 233 8780999
3 Goldstein MG, Pinto BM, Marcus BH, et al Physician-based physical activity counseling for middle-aged and older adults: a randomized trial Ann Behav Med 1999 21(1):40 47 18425653
4 Graham-Clarke P, Oldenburg B The effectiveness of a general-practice-based physical activity intervention on patient physical activity status Behavioral Change 1994 11(3):132 144
5 Kerse NM, Flicker L, Jolley D, Arroll B, Young D Improving the health behaviours of elderly people: randomised controlled trial of a general practice education programme BMJ 1999 319(7211):683 687 10480825 28221
6 Norris SL, Grothaus MA, Buchner DM, Pratt M. Effectiveness of physician-based assessment and counseling for exercise in a staff model HMO. Prev Med. 2000;30:513-523. [pmid: 10901494].
7 Steptoe A, Doherty S, Rink E, Kerry S, Kendrick T, Hilton S Behavioural counseling in general practice for the promotion of healthy behaviour among adults at increased risk of coronary heart disease: randomised trial BMJ 1999 319(7215):943 947 discussion 947 948 10514155 28246
8 Burton LC, Paglia MJ, German PS, Shapiro S, Damiano AM The effect among older persons of a general preventive visit on three health behaviors: smoking, excessive alcohol drinking, and sedentary lifestyle. The Medicare Preventive Services Research Team Prev Med 1995 24(5):492 497 8524724
9 Eckstrom E, Hickam DH, Lessler DS, Buchner DM Changing physician practice of physical activity counseling Journal of General Internal Medicine 1999 14(6):376 378 10354259 1496586
10 Elder JP, Williams SJ, Drew JA, Wright BL, Boulan TE Longitudinal effects of preventive services on health behaviors among an elderly cohort Am J Prev Med 1995 11(6):354 359 8775655
11 Smith BJ, Bauman AE, Bull FC, Booth ML, Harris MF Promoting physical activity in general practice: a controlled trial of written advice and information materials Br J Sports Med 2000 34(4):262 267 10953898 1724212
12 Washburn RA, Smith KW, Jette AM, Janney CA The physical activity scale for elderly (PASE): Development and Evaluation J Clin Epidemiol 1993 46(2):153 162 8437031
13 Bassett DR, Cureton AL, Ainsworth BE Measurement of daily walking distance-questionaire versus pedometer Med Sci Sports Exerc 2000 32(5):1018 1023 10795795
14 LaPorte RE, Kuller LH, Kupfer DJ, McPartland RJ, Matthews G. An objective measure of physical activity for epdemiological research. Am J Epidemiol. 1979;109:158-168. [pmid: 425955].
15 LaPorte RE, Montoye HJ, Casperson CJ Assessment of physical activity in epidemiologic research: problems and prospects Public Health Rep 1985 100(2):131 146 3920712 1424723
16 Lamb KL, Brodie DA The assessment of physical activity by leisure-time physical activity questionnaires Sports Med 1990 10(3):159 180 2237033
17 Booth ML, Owen N, Bauman AE, Gore CJ Retest reliability of recall measures of leisure-time physical activity in Austrian Adults Int J Epidemiol 1996 25(1):153 159 8666485
18 Chisholm DM, et al. Physical activity readiness. Br Columbia Med J. 1975;17:375-378.
19 Dickey LL, Gemson DH, Carney P Office system interventions supporting primary-care based health behavior change counseling Am J Prev Med. 1999 17(4):299 308 10606199
20 Calfas KJ, Sallis JF, Zabinski BA, et al Preliminary evaluation of a multi-component program for nutrition and physical activity change in primary care: PACE+ for adults Preventive Medicine 2002 34(2):153 161 11817910
21 Kreuter MW, Chheda SG, Bull FC How does physician advice influence patient behavior? Evidence for a priming effect Arch Fam Med 2000 9(5):426 433 10810947
22 Marcus BH, Goldstein MG, Jette A, et al Training physicians to conduct physical activity counseling Prev Med 1997 26(3):382 388 9144763