# Appendix A: Search Strategy for Physical Activity

1. COUNSEL.$.mp. [mp=title, abstract, full text, keywords, caption text]
2. PATIENT EDUCATION.mp. [mp=title, abstract, full text, keywords, caption text]
3. 1 or 2
4. PHYSICAL ACTIVITY.mp. [mp=title, abstract, full text, keywords, caption text]
5. EXERCI$.mp. [mp=title, abstract, full text, keywords, caption text]
6. 4 or 5
7. 3 and 6