# References

1 National Heart, Lung, and Blood Institute. Clinical Guidelines on the Identification, Evaluation, and Treatment of Overweight and Obesity in Adults: the Evidence Report. Bethesda, MD. National Institutes of Health. 1998.
2 Flegal KM, Carroll MD, Ogden CL, Curtin LR. Prevalence and trends in obesity among US adults, 1999-2008. JAMA. 2010;303:235-41. [pmid: 20071471].
3 Stein CJ, Colditz GA. The epidemic of obesity. J Clin Endocrinol Metab. 2004;89:2522-5. [pmid: 15181019].
4 Vasan RS, Pencina MJ, Cobain M, et al. Estimated risks for developing obesity in the Framingham Heart Study. Ann Intern Med. 2005;143:473-80. [pmid: 16204159].
5 Adams KF, Schatzkin A, Harris TB, et al. Overweight, obesity, and mortality in a large prospective cohort of persons 50 to 71 years old. N Engl J Med. 2006;355:763-78. [pmid: 16926275].
6 Flegal KM, Graubard BI, Williamson DF, Gail MH. Excess deaths associated with underweight, overweight, and obesity. JAMA. 2005;293:1861-7. [pmid: 15840860].
7 Fontaine KR, Redden DT, Wang C, et al. Years of life lost due to obesity. JAMA. 2003;289:187-93. [pmid: 12517229].
8 Whitlock G, Lewington S, Sherliker P, et al. Body-mass index and cause-specific mortality in 900,000 adults: collaborative analyses of 57 prospective studies. Lancet. 2009;373:1083-96. [pmid: 19299006].
9 Danaei G, Ding EL, Mozaffarian D, et al. The preventable causes of death in the United States: comparative risk assessment of dietary, lifestyle, and metabolic risk factors. PLoS Med. 2009;6:e1000058. [pmid: 19399161].
10 Peeters A, Barendregt JJ, Willekens F, et al. Obesity in adulthood and its consequences for life expectancy: a life-table analysis. Ann Intern Med. 2003;138:24-32. [pmid: 12513041].
11 Berrington de Gonzalez A, Hartge P, Cerhan JR, et al. Body-mass index and mortality among 1.46 million white adults. N Engl J Med. 2010;363:2211-9. [pmid: 21121834].
12 Calle EE, Thun MJ, Petrelli JM, et al. Body-mass index and mortality in a prospective cohort of US adults. N Engl J Med. 1999;341:1097-105. [pmid: 10511607].
13 Lenz M, Richter T, Mühlhauser I. The morbidity and mortality associated with overweight and obesity in adulthood: a systematic review. Dtsch Arztebl Int. 2009;106:641-8. [pmid: 19890430].
14 Stevens J. Obesity and mortality in African-Americans. Nutr Rev. 2000;58:346-58. [pmid: 11140906].
15 Gu D, He J, Duan X, et al. Body weight and mortality among men and women in China. JAMA. 2006;295:776-83. [pmid: 16478900].
16 Jee SH, Sull JW, Park J, et al. Body-mass index and mortality in Korean men and women. N Engl J Med. 2006;355:779-87. [pmid: 16926276].
17 Matsuo T, Sairenchi T, Iso H, et al. Age- and gender-specific BMI in terms of the lowest mortality in Japanese general population. Obesity (Silver Spring). 2008;16:2348-55. [pmid: 18719651].
18 Tsugane S, Sasaki S, Tsubono Y. Under- and overweight impact on mortality among middle-aged Japanese men and women: a 10-y follow-up of JPHC study cohort I. Int J Obes Relat Metab Disord. 2002;26:529-37. [pmid: 12075580].
19 Janssen I, Mark AE. Elevated body mass index and mortality risk in the elderly. Obes Rev. 2007;8:41-59. [pmid: 17212795].
20 Oreopoulos A, Kalantar-Zadeh K, Sharma AM, et al. The obesity paradox in the elderly: potential mechanisms and clinical implications. Clin Geriatr Med. 2009;25:643-59. [pmid: 19944265].
21 Bogers RP, Bemelmans WJ, Hoogenveen RT, et al. Association of overweight with increased risk of coronary heart disease partly independent of blood pressure and cholesterol levels: a meta-analysis of 21 cohort studies including more than 300,000 persons. Arch Intern Med. 2007;167:1720-8. [pmid: 17846390].
22 Colditz GA, Willett WC, Rotnitzky A, Manson JE. Weight gain as a risk factor for clinical diabetes mellitus in women. Ann Intern Med. 1995;122:481-6. [pmid: 7872581].
23 Willett WC, Manson JE, Stampfer MJ, et al. Weight, weight change, and coronary heart disease in women: risk within the “normal” weight range. JAMA. 1995;273:461-5. [pmid: 7654270].
24 Kenchaiah S, Evans JC, Levy D, et al. Obesity and the risk of heart failure. N Engl J Med. 2002;347:305-13. [pmid: 12151467].
25 Stommel M, Schoenborn CA. Variations in BMI and prevalence in health risks in diverse racial and ethnic populations. Obesity (Silver Spring). 2010;18:1821-6. [pmid: 20075855].
26 Abell JE, Egan BM, Wilson PW, et al. Age and race impact the association between BMI and CVD mortality in women. Public Health Rep. 2007;122:507-12. [pmid: 17639654].
27 Abell JE, Egan BM, Wilson PW, et al. Differences in cardiovascular disease mortality associated with body mass between black and white persons. Am J Public Health. 2008;98:63-6. [pmid: 18048799].
28 Stevens J, Juhaeri, Cai J, Jones DW. The effect of decision rules on the choice of a body mass index cutoff for obesity: examples from African American and white women. Am J Clin Nutr. 2002;75:986-92. [pmid: 12036803].
29 Chen Y, Henson S, Jackson AB, Richards JS. Obesity intervention in persons with spinal cord injury. Spinal Cord. 2006;44:82-91. [pmid: 16103891].
30 Huxley R, Barxi F, Lee CM, et al. Waist circumference thresholds provide an accurate and widely applicable method for the discrimination of diabetes. Diabetes Care. 2007;30:3116-8. [pmid: 17804678].
31 Ni Mhurchu C, Rodgers A, Pan WH, et al. Body mass index and cardiovascular disease in the Asia-Pacific region: an overview of 33 cohorts involving 310,000 participants. Int J Epidemiol. 2004;33:751-8. [pmid: 15105409].
32 Guh DP, Zhang W, Bansback N, et al. The incidence of co-morbidities related to obesity and overweight: a systematic review and meta-analysis. BMC Public Health. 2009;9:88. [pmid: 19320986].
33 Maskarinec G, Grandinetti A, Matsuura G, et al. Diabetes prevalence and body mass index differ by ethnicity: the Multiethnic Cohort. Ethn Dis. 2009;19:49-55. [pmid: 19341163].
34 Razak F, Anand SS, Shannon H, et al. Defining obesity cut points in a multiethnic population. Circulation. 2007;115:2111-8. [pmid: 17420343].
35 Razak F, Anand S, Vuksan V, et al. Ethnic differences in the relationships between obesity and glucose-metabolic abnormalities: a cross-sectional population-based study. Int J Obes. 2005;29:656-67.
36 Sánchez-Castillo CP, Velázquez-Monroy O, Berber A, et al. Anthropometric cutoff points for predicting chronic diseases in the Mexican National Health Survey 2000. Obes Res. 2003;11:442-51. [pmid: 12634443].
37 Low S, Chin MC, Ma S, et al. Rationale for redefining obesity in Asians. Ann Acad Med Singapore. 2009;38:66-74. [pmid: 19221673].
38 WHO Expert Consultation. Appropriate body-mass index for Asian populations and its implications for policy and intervention strategies. Lancet. 2010;363:157-63.
39 Wen CP, David Cheng TY, Tsai SP, et al. Are Asians at greater mortality risks for being overweight than Caucasians? Redefining obesity for Asians. Public Health Nutr. 2008;12:497-506. [pmid: 18547457].
40 Dai Z, Xu YC, Niu L. Obesity and colorectal cancer risk: a meta-analysis of cohort studies. World J Gastroenterol. 2007;13:4199-206. [pmid: 17696248].
41 Harriss DJ, Atkinson G, George K, et al. Lifestyle factors and colorectal cancer risk (1): systematic review and meta-analysis of associations with body mass index. Colorectal Dis. 2009;11:547-63. [pmid: 19207714].
42 Renehan AG, Tyson M, Egger M, et al. Body-mass index and incidence of cancer: a systematic review and meta-analysis of prospective observational studies. Lancet. 2008;371:569-78. [pmid: 18280327].
43 Calle EE, Rodriguez C, Walker-Thurmond K, Thun MJ. Overweight, obesity, and mortality from cancer in a prospectively studied cohort of U.S. adults. N Engl J Med. 2003;348:1625-38. [pmid: 12711737].
44 Strazzullo P, D'Elia L, Cairella G, et al. Excess body weight and incidence of stroke: meta-analysis of prospective studies with 2 million participants. Stroke. 2010;41:e418-26. [pmid: 20299666].
45 Zhou M, Offer A, Yang G, et al. Body mass index, blood pressure, and mortality from stroke: a nationally representative prospective study of 212,000 Chinese men. Stroke. 2008;39:753-9. [pmid: 18239175].
46 Frost L, Hune LJ, Vestergaard P. Overweight and obesity as risk factors for atrial fibrillation or flutter: the Danish Diet, Cancer, and Health Study. Am J Med. 2005;118:489-95. [pmid: 15866251].
47 Wang TJ, Parise H, Levy D, et al. Obesity and the risk of new-onset atrial fibrillation. JAMA. 2004;292:2471-7. [pmid: 15562125].
48 Hassing LB, Dahl AK, Thorvaldsson V, et al. Overweight in midlife and risk of dementia: a 40-year follow-up study. Int J Obes (Lond). 2009;33:893-8. [pmid: 19506566].
49 Ageno W, Becattini C, Brighton T, et al. Cardiovascular risk factors and venous thromboembolism: a meta-analysis. Circulation. 2008;117:93-102. [pmid: 18086925].
50 Stampfer MJ, Maclure KM, Colditz GA, et al. Risk of symptomatic gallstones in women with severe obesity. Am J Clin Nutr. 1992;55:652-8. [pmid: 1550039].
51 Willett WC, Dietz WH, Colditz GA. Guidelines for healthy weight. N Engl J Med. 1999;341:427-34. [pmid: 10432328].
52 Pandolfino JE, El-Serag HB, Zhang Q, et al. Obesity: a challenge to esophagogastric junction integrity. Gastroenterology. 2006;130:639-49. [pmid: 16530504].
53 Ferris M, Hogan S, Chin H, et al. Obesity, albuminuria, and urinalysis findings in US young adults from the Add Health Wave III study. Clin J Am Soc Nephrol. 2007;2:1207-14. [pmid: 17942783].
54 Hsu CY, McCulloch CE, Iribarren C, et al. Body mass index and risk for end-stage renal disease. Ann Intern Med. 2006;144:21-8. [pmid: 16389251].
55 Young T, Skatrud J, Peppard PE. Risk factors for obstructive sleep apnea in adults. JAMA. 2004;291:2013-6. [pmid: 15113821].
56 Cicuttini FM, Baker JR, Spector TD. The association of obesity with osteoarthritis of the hand and knee in women: a twin study. J Rheumatol. 1996;23:1221-6. [pmid: 8823696].
57 Hart DJ, Spector TD. The relationship of obesity, fat distribution and osteoarthritis in women in the general population: the Chingford Study. J Rheumatol. 1993;20:331-5. [pmid: 8474072].
58 Chen H, Guo X. Obesity and functional disability in elderly Americans. J Am Geriatr Soc. 2008;56:689-94. [pmid: 18266843].
59 Morin KH. Perinatal outcomes of obese women: a review of the literature. J Obstet Gynecol Neonatal Nurs. 1998;27:431-40.
60 ACOG Committee on Practice Bulletins. ACOG Practice Bulletin: chronic hypertension in pregnancy. Obstet Gynecol. 2001;98(Suppl):177-85. [pmid: 11508256].
61 Sarwer DB, Allison KC, Gibbons LM, et al. Pregnancy and obesity: a review and agenda for future research. J Womens Health (Larchmt). 2006;15:720-33. [pmid: 16910904].
62 Tennant PW, Rankin J, Bell R. Maternal body mass index and the risk of fetal and infant death: a cohort study from the North of England. Hum Reprod. 2011;26:1501-11. [pmid: 21467206].
63 Jia H, Lubetkin EI. The impact of obesity on health-related quality-of-life in the general adult US population. J Public Health (Oxf). 2005;27:156-64. [pmid: 15820993].
64 Fine JT, Colditz GA, Coakley EH, et al. A prospective study of weight change and health-related quality of life in women. JAMA. 1999;282:2136-45. [pmid: 10591335].
65 Luppino FS, de Wit LM, Bouvy PF, et al. Overweight, obesity, and depression: a systematic review and meta-analysis of longitudinal studies. Arch Gen Psychiatry. 2010;67:220-9. [pmid: 20194822].
66 Bertakis KD, Azari R. Obesity and the use of health care services. Obes Res. 2005;13:372-9. [pmid: 15800296].
67 Quesenberry CP Jr, Caan B, Jacobson A. Obesity, health services use, and health care costs among members of a health maintenance organization. Arch Intern Med. 1998;158:466-72. [pmid: 9508224].
68 Qi L, Cho YA. Gene-environment interaction and obesity. Nutr Rev. 2008;66:684-94. [pmid: 19019037].
69 Bouchard C, Tremblay A, Després JP, et al. The response to long-term overfeeding in identical twins. N Engl J Med. 1990;322:1477-82. [pmid: 2336074].
70 Williamson DF, Madans J, Anda RF, et al. Recreational physical activity and ten-year weight change in a US national cohort. Int J Obes Relat Metab Disord. 1993;17:279-86. [pmid: 8389337].
71 Hu FB, Li TY, Colditz GA, et al. Television watching and other sedentary behaviors in relation to risk of obesity and type 2 diabetes mellitus in women. JAMA. 2003;289:1785-91. [pmid: 12684356].
72 Pereira MA, Kartashov AI, Ebbeling CB, et al. Fast-food habits, weight gain, and insulin resistance (the CARDIA study): 15 year prospective analysis. Lancet. 2005;365:36-42. [pmid: 15639678].
73 Vorona RD, Winn MP, Babineau TW, et al. Overweight and obese patients in a primary care population report less sleep than patients with a normal body mass index. Arch Intern Med. 2005;165:25-30. [pmid: 15642870].
74 Power C, Jefferis BJ. Fetal environment and subsequent obesity: a study of maternal smoking. Int J Epidemiol. 2002;31:413-9. [pmid: 11980805].
75 Dabelea D, Hanson RL, Lindsay RS, et al. Intrauterine exposure to diabetes conveys risks for type 2 diabetes and obesity: a study of discordant sibships. Diabetes. 2000;49:2208-11. [pmid: 11118027].
76 Harder T, Bergmann R, Kallischnigg G, Plagemann A. Duration of breastfeeding and risk of overweight: a meta-analysis. Am J Epidemiol. 2005;162:397-403. [pmid: 16076830].
77 Freedman DS, Khan LK, Serdula MK, et al. The relation of childhood BMI to adult adiposity: the Bogalusa Heart Study. Pedatrics. 2005;115:22-7.
78 Guo SS, Roche AF, Chumlea WC, et al. The predictive value of childhood body mass index values for overweight at age 35 y. Am J Clin Nutr. 1994;59:810-9. [pmid: 8147324].
79 Bray GA. Clinical classification and natural history of overweight. Bray GA, editor. Contemporary Diagnosis and Management of Obesity and the Metabolic Syndrome. 3. Newtown, PA. Handbooks in Health Care. 2003:111-43.
80 Howard BV, Manson JE, Stefanick ML, et al. Low-fat dietary pattern and weight change over 7 years: the Women's Health Initiative Dietary Modification Trial. JAMA. 2006;295:39-49. [pmid: 16391215].
81 National Heart, Lung, and Blood Institute. Obesity Education Initiative. Bethesda, MD. National Institutes of Health. 1998.
82 McTigue KM, Garrett JM, Popkin BM. The natural history of the development of obesity in a cohort of young U.S. adults between 1981 and 1998. Ann Intern Med. 2002;136:857-64. [pmid: 12069559].
83 U.S. Preventive Services Task Force. Screening for obesity in adults: recommendations and rationale. Ann Intern Med. 2003;139:930-2. [pmid: 14644896].
84 McTigue KM, Harris R, Hemphill MB, et al. Screening and Interventions for Overweight and Obesity in Adults. Systematic Evidence Review No. 21. Rockville, MD. Agency for Healthcare Research and Quality. 2003.
85 Bigaard J, Frederiksen K, Tjønneland A, et al. Waist and hip circumference and all-cause mortality usefulness of the waist-to-hip ratio?. Int J Obes Relat Metab Disord. 2004;28:741-7. [pmid: 15052280].
86 Koster A, Leitzmann MF, Schatzkin A, et al. Waist circumference and mortality. Am J Epidemiol. 2008;167:1465-75. [pmid: 18417494].
87 Pischon T, Boeing H, Hoffmann K, et al. General and abdominal adiposity and risk of death in Europe. N Engl J Med. 2008;359:2105-20. [pmid: 19005195].
88 Price GM, Uauy R, Breeze E, et al. Weight, shape, and mortality risk in older persons: elevated waist-hip ratio, not high body mass index, is associated with a greater risk of death. Am J Clin Nutr. 2006;84:449-60. [pmid: 16895897].
89 Reis JP, Macera CA, Araneta MR, et al. Comparison of overall obesity and body fat distribution in predicting risk of mortality. Obesity (Silver Spring). 2009;17:1232-9. [pmid: 19197258].
90 Schneider HJ, Friedrich N, Klotsche J, et al. The predictive value of different measures of obesity for incident cardiovascular events and mortality. J Clin Endocrinol Metab. 2010;95:1777-85. [pmid: 20130075].
91 Seidell JC. Waist circumference and waist/hip ratio in relation to all-cause mortality, cancer and sleep apnea. Eur J Clin Nutr. 2010;64:35-41. [pmid: 19639001].
92 Simpson JA, MacInnis RJ, Peeters A, et al. A comparison of adiposity measures as predictors of all-cause mortality: the Melbourne Collaborative Cohort Study. Obesity (Silver Spring). 2007;15:994-1003. [pmid: 17426335].
93 Zhang C, Rexrode KM, van Dam RM, et al. Abdominal obesity and the risk of all-cause, cardiovascular, and cancer mortality: sixteen years of follow-up in US women. Circulation. 2008;117:1658-67. [pmid: 18362231].
94 Yusuf S, Hawken S, Ounpuu S, et al. Obesity and the risk of myocardial infarction in 27,000 participants from 52 countries: a case-control study. Lancet. 2005;366:1640-9. [pmid: 16271645].
95 Herrera VM, Casas JP, Miranda JJ, et al. Interethnic differences in the accuracy of anthropometric indicators of obesity in screening for high risk of coronary heart disease. Int J Obes (Lond). 2009;33:568-76. [pmid: 19238159].
96 Canoy D. Distribution of body fat and risk of coronary heart disease in men and women. Curr Opin Cardiol. 2008;23:591-8. [pmid: 18830075].
97 Janssen I, Katzmarzyk PT, Ross R. Waist circumference and not body mass index explains obesity-related health risk. Am J Clin Nutr. 2004;79:379-84. [pmid: 14985210].
98 Lear SA, James PT, Ko GT, Kumanyika S. Appropriateness of waist circumference and waist-to-hip ratio cutoffs for different ethnic groups. Eur J Clin Nutr. 2010;64:42-61. [pmid: 19672278].
99 Qiao Q, Nyamdorj R. The optimal cutoff values and their performance of waist circumference and waist-to-hip ratio for diagnosing type II diabetes. Eur J Clin Nutr. 2010;64:23-9. [pmid: 19690576].
100 Ardern CI, Janssen I, Ross R, Katzmarzyk PT. Development of health-related waist circumference thresholds within BMI categories. Obes Res. 2004;12:1094-103. [pmid: 15292473].
101 Freemantle N, Holmes J, Hockey A, Kumar S. How strong is the association between abdominal obesity and the incidence of type 2 diabetes?. Int J Clin Pract. 2008;62:1391-6. [pmid: 18557792].
102 Lear SA, Kohli S, Bondy GP, et al. Ethnic variation in fat and lean body mass and the association with insulin resistance. J Clin Endocrinol Metab. 2009;94:4696-702. [pmid: 19820012].
103 Lee CM, Huxley RR, Wildman RP, Woodward M. Indices of abdominal obesity are better discriminators of cardiovascular risk factors than BMI: a meta-analysis. J Clin Epidemiol. 2008;61:646-53. [pmid: 18359190].
104 Patel MR, Donahue M, Wilson PW, Califf RM. Clinical trial issues in weight-loss therapy. Am Heart J. 2006;151:633-42. [pmid: 16504625].
105 Vazquez G, Duval S, Jacobs DR Jr, Silventoinen K. Comparison of body mass index, waist circumference, and waist/hip ratio in predicting incident diabetes: a meta-analysis. Epidemiol Rev. 2007;29:115-28. [pmid: 17494056].
106 National Heart, Lung, and Blood Institute. Guidelines on Overweight and Obesity: Electronic Textbook. Bethesda, MD. National Institutes of Health. 2011. Accessed at http://www.nhlbi.nih.gov/guidelines/obesity/e_txtbk/index.htm. 31 August 2011.
107 WHO Consultation on Obesity. Obesity: Preventing and Managing the Global Epidemic. WHO Technical Report Series No. 894. Geneva. World Health Organization. 1999.
108 International Diabetes Institute. The Asia-Pacific Perspective: Redefining Obesity and its Treatment. Sydney. Health Communications Australia. 2000.
109 Hermansen K, Mortensen LS. Bodyweight changes associated with antihyperglycaemic agents in type 2 diabetes mellitus. Drug Saf. 2007;30:1127-42. [pmid: 18035865].
110 Mannucci E, Ognibene A, Cremasco F, et al. Effect of metformin on glucagon-like peptide 1 (GLP-1) and leptin levels in obese nondiabetic subjects. Diabetes Care. 2001;24:489-94. [pmid: 11289473].
111 Yasuda N, Inoue T, Nagakura T, et al. Enhanced secretion of glucagon-like peptide 1 by biguanide compounds. Biochem Biophys Res Commun. 2002;298:779-84. [pmid: 12419322].
112 Nauck MA, Niedereichholz U, Ettler R, et al. Glucagon-like peptide 1 inhibition of gastric emptying outweighs its insulinotropic effects in health humans. Am J Physiol. 1997;273:e981-8. [pmid: 9374685].
113 Tang-Christensen M, Larsen PJ, Göke R, et al. Central administration of GLP-1-(7-36) amide inhibits food and water intake in rats. Am J Physiol. 1996;271:R848-56. [pmid: 8897973].
114 Vetter ML, Faulconbridge LF, Webb VL, Wadden TA. Behavioral and pharmacologic therapies for obesity. Nat Rev Endocrinol. 2010;6:578-88. [pmid: 20680034].
115 FDA Issues Complete Response to New Drug Application for Contrave for the Management of Obesity. La Jolla, CA. Orexigen Therapeutics, Inc. 2011. Accessed at http://ir.orexigen.com/phoenix.zhtml?c=207034&p=irol-newsArticle&ID=1522207&highlight=. 23 September 2011.
116 Simkin-Silverman LR, Gleason KA, King WC, et al. Predictors of weight control advice in primary care practices: patient health and psychosocial characteristics. Prev Med. 2005;40:71-82. [pmid: 15530583].
117 Stafford RS, Farhat JH, Misra B, Schoenfeld DA. National patterns of physician activities related to obesity management. Arch Fam Med. 2000;9:631-8. [pmid: 10910311].
118 Ma J, Xiao L, Stafford RS. Adult obesity and office-based quality of care in the United States. Obesity (Silver Spring). 2009;17:1077-85. [pmid: 19197264].
119 Shiffman S, Sweeney CT, Pillitteri JL, et al. Weight management advice: what do doctors recommend to their patients?. Prev Med. 2009;49:482-6. [pmid: 19786045].
120 Dahlin A, Beermann B. Incorrect use of orlistat and sibutramine in clinical practice. Eur J Clin Pharmacol. 2007;63:205-9. [pmid: 17205321].
121 Lau DC, Douketis JD, Morrison KM, et al. 2006 Canadian clinical practice guidelines on the management and prevention of obesity in adults and children. CMAJ. 2007;176:S1-13. [pmid: 17420481].
122 Lyznicki JM, Young DC, Riggs JA, et al. Obesity: assessment and management in primary care. Am Fam Physician. 2001;63:2185-96. [pmid: 11417771].
123 National Institute for Health and Clinical Excellence. Obesity: Guidance on the Prevention, Identification, Assessment and Management of Overweight and Obesity in Adults and Children Clinical Guideline No. 43. London. National Institute for Health and Clinical Excellence. 2006.
124 Desilets AR, Dhakal-Karki S, Dunican KC. Role of metformin for weight management in patients without type 2 diabetes. Ann Pharmacother. 2008;42:817-26. [pmid: 18477733].
125 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20:21-35. [pmid: 11306229].
126 Bakris G, Calhoun D, Egan B, et al. Orlistat improves blood pressure control in obese subjects with treated but inadequately controlled hypertension. J Hypertens. 2002;20:2257-67. [pmid: 12409965].
127 Kelley DE, Bray GA, Pi-Sunyer FX, et al. Clinical efficacy of orlistat therapy in overweight and obese patients with insulin-treated type 2 diabetes: a 1-year randomized controlled trial. Diabetes Care. 2002;25:1033-41. [pmid: 12032111].
128 Kirk EP, Jacobsen DJ, Gibson C, et al. Time course for changes in aerobic capacity and body composition in overweight men and women in response to long-term exercise: the Midwest Exercise Trial (MET). Int J Obes Relat Metab Disord. 2003;27:912-9. [pmid: 12861232].
129 Van Gaal LF, Broom JI, Enzi G, Toplak H. Efficacy and tolerability of orlistat in the treatment of obesity: a 6-month dose-ranging study. Eur J Clin Pharmacol. 1998;54:125-32. [pmid: 9626916].
130 Muls E, Kolanowski J, Scheen A, et al. The effects of orlistat on weight and on serum lipids in obese patients with hypercholesterolemia: a randomized, double-blind, placebo-controlled, multicentre study. Int J Obes Relat Metab Disord. 2001;25:1713-21. [pmid: 11753595].
131 Trolle B, Flyvbjerg A, Kesmodel U, Lauszus FF. Efficacy of metformin in obese and non-obese women with polycystic ovary syndrome: a randomized, double-blinded, placebo-controlled cross-over trial. Hum Reprod. 2007;22:2967-73. [pmid: 17766923].
132 Broom I, Hughes E, Dodson P, et al. The role of orlistat in the treatment of obese patients with mild to moderate hypercholesterolaemia: consequences for coronary risk. Br J Cardiol. 2002;9:460-8.
133 Acharya NV, Wilton LV, Shakir SA. Safety profile of orlistat: results of a prescription-event monitoring study. Int J Obes (Lond). 2006;30:1645-52. [pmid: 16552401].
134 Perrio MJ, Wilton LV, Shakir SA. The safety profiles of orlistat and sibutramine: results of prescription-event monitoring studies in England. Obesity (Silver Spring). 2007;15:2712-22. [pmid: 18070762].
135 Uusi-Rasi K, Rauhio A, Kannus P, et al. Three-month weight reduction does not compromise bone strength in obese premenopausal women. Bone. 2010;46:1286-93. [pmid: 19857618].
136 Gokcel A, Gumurdulu Y, Karakose H, et al. Evaluation of the safety and efficacy of sibutramine, orlistat and metformin in the treatment of obesity. Diabetes Obes Metab. 2002;4:49-55. [pmid: 11874442].
137 Williamson DA, Martin CK, Anton SD, et al. Is caloric restriction associated with development of eating-disorder symptoms? Results from the CALERIE trial. Health Psychol. 2008;27(1 Suppl):S32-42. [pmid: 18248104].
138 Warren M, Schmitz KH. Safety of strength training in premenopausal women: musculoskeletal injuries from a two-year randomized trial. Am J Health Promot. 2009;23:309-14. [pmid: 19445432].
139 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21:1539-58. [pmid: 12111919].
140 Egger M, Davey Smith G, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315:629-34. [pmid: 9310563].
141 Terrin N, Schmid CH, Lau J. In an empirical evaluation of the funnel plot, researchers could not visually identify publication bias. J Clin Epidemiol. 2005;58:894-901. [pmid: 16085192].
142 The Diabetes Prevention Program: design and methods for a clinical trial in the prevention of type 2 diabetes. Diabetes Care. 1999;22:623-34. [pmid: 10189543].
143 Hypertension Prevention Trial Research Group. The Hypertension Prevention Trial: three-year effects of dietary changes on blood pressure. Arch Intern Med. 1990;150:153-62. [pmid: 2404477].
144 Anderssen S, Holme I, Urdal P, Hjermann I. Diet and exercise intervention have favourable effects on blood pressure in mild hypertensives: the Oslo Diet and Exercise Study (ODES). Blood Press. 1995;4:343-9. [pmid: 8746601].
145 Burke V, Beilin LJ, Cutt HE, et al. Effects of a lifestyle programme on ambulatory blood pressure and drug dosage in treated hypertensive patients: a randomized controlled trial. J Hypertens. 2005;23:1241-9. [pmid: 15894901].
146 Christian JG, Bessesen DH, Byers TE, et al. Clinic-based support to help overweight patients with type 2 diabetes increase physical activity and lose weight. Arch Intern Med. 2008;168:141-6. [pmid: 18227359].
147 Cohen MD, D'Amico FJ, Merenstein JH. Weight reduction in obese hypertensive patients. Fam Med. 1991;23:25-8. [pmid: 2001777].
148 Cussler EC, Teixeira PJ, Going SB, et al. Maintenance of weight loss in overweight middle-aged women through the Internet. Obesity (Silver Spring). 2008;16:1052-60. [pmid: 18309301].
149 Davis BR, Oberman A, Blaufox MD, et al. Effect of antihypertensive therapy on weight loss. Hypertension. 1992;19:393-9. [pmid: 1555871].
150 Frey-Hewitt B, Vranizan KM, Dreon DM, Wood PD. The effect of weight loss by dieting or exercise on resting metabolic rate in overweight men. Int J Obes. 1990;14:327-34. [pmid: 2361810].
151 Haapala I, Barengo NC, Biggs S, et al. Weight loss by mobile phone: a 1-year effectiveness study. Public Health Nutr. 2009;12:2382-91. [pmid: 19323865].
152 Irwin ML, Yasui Y, Ulrich CM, et al. Effect of exercise on total and intra-abdominal body fat in postmenopausal women: a randomized controlled trial. JAMA. 2003;289:323-30. [pmid: 12525233].
153 Jeffery RW, Wing RR, Thorson C, et al. Strengthening behavioral interventions for weight loss: a randomized trial of food provision and monetary incentives. J Consult Clin Psychol. 1993;61:1038-45. [pmid: 8113481].
154 Jones DW, Miller ME, Wofford MR, et al. The effect of weight loss intervention on antihypertensive medication requirements in the Hypertension Optimal Treatment (HOT) study. Am J Hypertens. 1999;12:1175-80. [pmid: 10619579].
155 Kastarinen MJ, Puska PM, Korhonen MH, et al. Non-pharmacological treatment of hypertension in primary health care: a 2-year open randomized controlled trial of lifestyle intervention against hypertension in eastern Finland. J Hypertens. 2002;20:2505-12. [pmid: 12473876].
156 Kulzer B, Hermanns N, Gorges D, et al. Prevention of Diabetes Self-Management Program (PREDIAS): effects on weight, metabolic risk factors, and behavioral outcomes. Diabetes Care. 2009;32:1143-6. [pmid: 19509014].
157 Langford HG, Blaufox MD, Oberman A, et al. Dietary therapy slows the return of hypertension after stopping prolonged medication. JAMA. 1985;253:657-64. [pmid: 3881608].
158 Martin PD, Dutton GR, Rhode PC, et al. Weight loss maintenance following a primary care intervention for low-income minority women. Obesity (Silver Spring). 2008;16:2462-7. [pmid: 18787526].
159 Mayer-Davis EJ, D'Antonio AM, Smith SM, et al. Pounds Off With Empowerment (POWER): a clinical trial of weight management strategies for black and white adults with diabetes who live in medically underserved rural communities. Am J Public Health. 2004;94:1736-42. [pmid: 15451743].
160 Mensink M, Blaak EE, Corpeleijn E, et al. Lifestyle intervention according to general recommendations improves glucose tolerance. Obes Res. 2003;11:1588-96. [pmid: 14694225].
161 Mitsui T, Shimaoka K, Tsuzuku S, et al. Gentle exercise of 40 minutes with dietary counseling is effective in treating metabolic syndrome. Tohoku J Exp Med. 2008;215:355-61. [pmid: 18679010].
162 Moore H, Summerbell CD, Greenwood DC, et al. Improving management of obesity in primary care: cluster randomised trial. BMJ. 2003;327:1085. [pmid: 14604931].
163 Narayan KM, Hoskin M, Kozak D, et al. Randomized clinical trial of lifestyle interventions in Pima Indians: a pilot study. Diabet Med. 1998;15:66-72. [pmid: 9472866].
164 Perri MG, McAllister DA, Gange JJ, et al. Effects of four maintenance programs on the long-term management of obesity. J Consult Clin Psychol. 1988;56:529-34. [pmid: 2848874].
165 Pritchard DA, Hyndman J, Taba F. Nutritional counselling in general practice: a cost effective analysis. J Epidemiol Community Health. 1999;53:311-6. [pmid: 10396539].
166 Silva MN, Vieira PN, Coutinho SR, et al. Using self-determination theory to promote physical activity and weight control: a randomized controlled trial in women. J Behav Med. 2010;33:110-22. [pmid: 20012179].
167 Simkin-Silverman LR, Wing RR, Boraz MA, Kuller LH. Lifestyle intervention can prevent weight gain during menopause: results from a 5-year randomized clinical trial. Ann Behav Med. 2003;26:212-20. [pmid: 14644697].
168 Stevens VJ, Corrigan SA, Obarzanek E, et al. Weight loss intervention in phase 1 of the Trials of Hypertension Prevention. Arch Intern Med. 1993;153:849-58. [pmid: 8466377].
169 Stevens VJ, Obarzanek E, Cook NR, et al. Long-term weight loss and changes in blood pressure: results of the Trials of Hypertension Prevention, phase II. Ann Intern Med. 2001;134:1-11. [pmid: 11187414].
170 Svetkey LP, Stevens VJ, Brantley PJ, et al. Comparison of strategies for sustaining weight loss: the Weight Loss Maintenance randomized controlled trial. JAMA. 2008;299:1139-48. [pmid: 18334689].
171 ter Bogt NC, Bemelmans WJ, Beltman FW, et al. Preventing weight gain: one-year results of a randomized lifestyle intervention. Am J Prev Med. 2009;37:270-7. [pmid: 19765497].
172 Tuomilehto J, Lindström J, Eriksson JG, et al. Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. N Engl J Med. 2001;344:1343-50. [pmid: 11333990].
173 Villareal DT, Shah K, Banks MR, et al. Effect of weight loss and exercise therapy on bone metabolism and mass in obese older adults: a one-year randomized controlled trial. J Clin Endocrinol Metab. 2008;93:2181-7. [pmid: 18364384].
174 Werkman A, Hulshof PJ, Stafleu A, et al. Effect of an individually tailored one-year energy balance programme on body weight, body composition and lifestyle in recent retirees: a cluster randomised controlled trial. BMC Public Health. 2010;10:110. [pmid: 20205704].
175 Whelton PK, Appel LJ, Espeland MA, et al. Sodium reduction and weight loss in the treatment of hypertension in older persons: a randomized controlled Trial of Nonpharmacologic Interventions in the Elderly (TONE). JAMA. 1998;279:839-46. [pmid: 9515998].
176 Wood PD, Stefanick ML, Dreon DM, et al. Changes in plasma lipids and lipoproteins in overweight men during weight loss through dieting as compared with exercise. N Engl J Med. 1988;319:1173-9. [pmid: 3173455].
177 Wood PD, Stefanick ML, Williams PT, Haskell WL. The effects on plasma lipoproteins of a prudent weight-reducing diet, with or without exercise, in overweight men and women. N Engl J Med. 1991;325:461-6. [pmid: 1852180].
178 Woollard J, Burke V, Beilin LJ, et al. Effects of a general practice-based intervention on diet, body mass index and blood lipids in patients at cardiovascular risk. J Cardiovasc Risk. 2003;10:31-40. [pmid: 12569235].
179 Apfelbaum M, Vague P, Ziegler O, et al. Long-term maintenance of weight loss after a very-low-calorie diet: a randomized blinded trial of the efficacy and tolerability of sibutramine. Am J Med. 1999;106:179-84. [pmid: 10230747].
180 Berne C, Orlistat Swedish Type 2 Diabetes Study Group. A randomized study of orlistat in combination with a weight management programme in obese patients with type 2 diabetes treated with metformin. Diabet Med. 2005;22:612-8. [pmid: 15842517].
181 Broom I, Wilding J, Stott P, et al. Randomised trial of the effect of orlistat on body weight and cardiovascular disease risk profile in obese patients: UK Multimorbidity Study. Int J Clin Pract. 2002;56:494-9. [pmid: 12296610].
182 Davidson MH, Hauptman J, DiGirolamo M, et al. Weight control and risk factor reduction in obese subjects treated for 2 years with orlistat: a randomized controlled trial. JAMA. 1999;281:235-42. [pmid: 9918478].
183 Derosa G, Mugellini A, Ciccarelli L, Fogari R. Randomized, double-blind, placebo-controlled comparison of the action of orlistat, fluvastatin, or both an anthropometric measurements, blood pressure, and lipid profile in obese patients with hypercholesterolemia prescribed a standardized diet. Clin Ther. 2003;25:1107-22. [pmid: 12809960].
184 Finer N, James WP, Kopelman PG, et al. One-year treatment of obesity: a randomized, double-blind, placebo-controlled, multicentre study of orlistat, a gastrointestinal lipase inhibitor. Int J Obes Relat Metab Disord. 2000;24:306-13. [pmid: 10757623].
185 Fontbonne A, Charles MA, Juhan-Vague I, et al. The effect of metformin on the metabolic abnormalities associated with upper-body fat distribution. Diabetes Care. 1996;19:920-6. [pmid: 8875083].
186 Gambineri A, Patton L, Vaccina A, et al. Treatment with flutamide, metformin, and their combination added to a hypocaloric diet in overweight-obese women with polycystic ovary syndrome: a randomized, 12-month, placebo-controlled study. J Clin Endocrinol Metab. 2006;91:3970-80. [pmid: 16868063].
187 Hanefeld M, Sachse G. The effects of orlistat on body weight and glycaemic control in overweight patients with type 2 diabetes: a randomized, placebo-controlled trial. Diabetes Obes Metab. 2002;4:415-23. [pmid: 12406041].
188 Hauner H, Meier M, Wendland G, et al. Weight reduction by sibutramine in obese subjects in primary care medicine: the SAT Study. Exp Clin Endocrinol Diabetes. 2004;112:201-7. [pmid: 15127325].
189 Hauptman J, Lucas C, Boldrin MN, et al. Orlistat in the long-term treatment of obesity in primary care settings. Arch Fam Med. 2000;9:160-7. [pmid: 10693734].
190 Hill JO, Hauptman J, Anderson JW, et al. Orlistat, a lipase inhibitor, for weight maintenance after conventional dieting: a 1-y study. Am J Clin Nutr. 1999;69:1108-16. [pmid: 10357727].
191 Hollander PA, Elbein SC, Hirsch IB, et al. Role of orlistat in the treatment of obese patients with type 2 diabetes: a 1-year randomized double-blind study. Diabetes Care. 1998;21:1288-94. [pmid: 9702435].
192 Kaukua JK, Pekkarinen TA, Rissanen AM. Health-related quality of life in a randomised placebo-controlled trial of sibutramine in obese patients with type II diabetes. Int J Obes Relat Metab Disord. 2004;28:600-5. [pmid: 14770192].
193 Krempf M, Louvet JP, Allanic H, et al. Weight reduction and long-term maintenance after 18 months treatment with orlistat for obesity. Int J Obes Relat Metab Disord. 2003;27:591-7. [pmid: 12704403].
194 Lindgärde F. The effect of orlistat on body weight and coronary heart disease risk profile in obese patients: the Swedish Multimorbidity Study. J Intern Med. 2000;248:245-54. [pmid: 10971792].
195 Mathus-Vliegen EM, Balance Study Group. Long-term maintenance of weight loss with sibutramine in a GP setting following a specialist guided very-low-calorie diet: a double-blind, placebo-controlled, parallel group study. Eur J Clin Nutr. 2005;59(Suppl 1):S31-8. [pmid: 16052193].
196 McNulty SJ, Ur E, Williams G, Multicenter Sibutramine Study Group. A randomized trial of sibutramine in the management of obese type 2 diabetic patients treated with metformin. Diabetes Care. 2003;26:125-31. [pmid: 12502668].
197 Miles JM, Leiter L, Hollander P, et al. Effect of orlistat in overweight and obese patients with type 2 diabetes treated with metformin. Diabetes Care. 2002;25:1123-8. [pmid: 12087008].
198 Richelsen B, Tonstad S, Rössner S, et al. Effect of orlistat on weight regain and cardiovascular risk factors following a very-low-energy diet in abdominally obese patients: a 3-year randomized, placebo-controlled study. Diabetes Care. 2007;30:27-32. [pmid: 17192328].
199 Rössner S, Sjöström L, Noack R, et al. Weight loss, weight maintenance, and improved cardiovascular risk factors after 2 years treatment with orlistat for obesity. Obes Res. 2000;8:49-61. [pmid: 10678259].
200 Sjöström L, Rissanen A, Andersen T, et al. Randomised placebo-controlled trial of orlistat for weight loss and prevention of weight regain in obese patients. Lancet. 1998;352:167-72. [pmid: 9683204].
201 Swinburn BA, Carey D, Hills AP, et al. Effect of orlistat on cardiovascular disease risk in obese adults. Diabetes Obes Metab. 2005;7:254-62. [pmid: 15811142].
202 Torgerson JS, Hauptman J, Boldrin MN, Sjöström L. Xenical in the Prevention of Diabetes in Obese Subjects (XENDOS) study: a randomized study of orlistat as an adjunct to lifestyle changes for the prevention of type 2 diabetes in obese patients. Diabetes Care. 2004;27:155-61. [pmid: 14693982].
203 Wirth A, Krause J. Long-term weight loss with sibutramine: a randomized controlled trial. JAMA. 2001;286:1331-9. [pmid: 11560538].
204 Fitzgibbon ML, Stolley MR, Schiffer L, et al. Obesity Reduction Black Intervention Trial (ORBIT): 18-month results. Obesity (Silver Spring). 2010;18:2317-25. [pmid: 20300081].
205 Rubin RR, Knowler WC, Ma Y, et al. Depression symptoms and antidepressant medicine use in Diabetes Prevention Program participants. Diabetes Care. 2005;28:830-7. [pmid: 15793181].
206 Knowler WC, Barrett-Connor E, Fowler SE, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med. 2002;346:393-403. [pmid: 11832527].
207 Ratner R, Goldberg R, Haffner S, et al. Impact of intensive lifestyle and metformin therapy on cardiovascular disease risk factors in the Diabetes Prevention Program. Diabetes Care. 2005;28:888-94. [pmid: 15793191].
208 Parikh P, Simon EP, Fei K, et al. Results of a pilot diabetes prevention intervention in East Harlem, New York City: Project HEED. Am J Public Health. 2010;100(Suppl 1):S232-9. [pmid: 20147680].
209 Lindgärde F. Orlistat with diet was effective and safe for weight loss and coronary risk reduction in obesity. Evid Based Med. 2001;6:54.
210 Diabetes Prevention Program Research Group, Crandall J, Schade D, et al. The influence of age on the effects of lifestyle modification and metformin in prevention of diabetes. J Gerontol A Biol Sci Med Sci. 2006;61:1075-81. [pmid: 17077202].
211 Ackermann RT, Edelstein SL, Narayan KM, et al. Changes in health state utilities with changes in body mass in the Diabetes Prevention Program. Obesity (Silver Spring). 2009;17:2176-81. [pmid: 19390518].
212 Haffner S, Temprosa M, Crandall J, et al. Intensive lifestyle intervention or metformin on inflammation and coagulation in participants with impaired glucose tolerance. Diabetes. 2005;54:1566-72. [pmid: 15855347].
213 Diabetes Prevention Program Research Group, Knowler WC, Fowler SE, et al. 10-year follow-up of diabetes incidence and weight loss in the Diabetes Prevention Program Outcomes Study. Lancet. 2009;274:1677-86. [pmid: 19878986].
214 West DS, Prewitt TE, Bursac Z, Felix HC. Weight loss of black, white, and Hispanic men and women in the Diabetes Prevention Program. Obesity (Silver Spring). 2008;16:1413-20. [pmid: 18421273].
215 Derosa G, Maffioli P, Salvadeo SA, et al. Comparison of orlistat treatment and placebo in obese type 2 diabetic patients. Expert Opin Pharmacother. 2010;11:1971-82. [pmid: 20569086].
216 Gotfredsen A, Westergren Hendel H, Andersen T. Influence of orlistat on bone turnover and body composition. Int J Obes Relat Metab Disord. 2001;25:1154-60. [pmid: 11486790].
217 Giugliano D, Quatraro A, Consoli G, et al. Metformin for obese, insulin-treated diabetic patients: improvement in glycaemic control and reduction of metabolic risk factors. Eur J Clin Pharmacol. 1993;44:107-12. [pmid: 8453955].
218 U.S. Food and Drug Administration. Guidance for Industry: Developing Products for Weight Management. Rockville, MD. U.S. Food and Drug Administration. 2007. Accessed at http://www.fda.gov/downloads/Drugs/GuidanceComplianceRegulatoryInformation/Guidances/ucm071612.pdf. 6 September 2011.
219 Gregg EW, Gerzoff RB, Thompson TJ, Williamson DF. Trying to lose weight, losing weight, and 9-year mortality in overweight U.S. adults with diabetes. Diabetes Care. 2004;27:657-62. [pmid: 14988281].
220 Knudtson MD, Klein BE, Klein R, Shankar A. Associations with weight loss and subsequent mortality risk. Ann Epidemiol. 2005;15:483-91. [pmid: 16029840].
221 Williamson DF, Pamuk E, Thun M, et al. Prospective study of intentional weight loss and mortality in never-smoking overweight US white women aged 40-64 years. Am J Epidemiol. 1995;141:1128-41. [pmid: 7771451].
222 Yaari S, Goldbourt U. Voluntary and involuntary weight loss: associations with long term mortality in 9,228 middle-aged and elderly men. Am J Epidemiol. 1998;148:546-55. [pmid: 9753009].
223 Williamson DF, Thompson TJ, Thun M, et al. Intentional weight loss and mortality among overweight individuals with diabetes. Diabetes Care. 2000;23:1499-1504. [pmid: 11023143].
224 Christou NV, Sampalis JS, Liberman M, et al. Surgery decreases long-term mortality, morbidity, and health care use in morbidly obese patients. Ann Surg. 2004;240:416-23. [pmid: 15319713].
225 Peeters A, O'Brien PE, Laurie C, et al. Substantial intentional weight loss and mortality in the severely obese. Ann Surg. 2007;246:1028-33. [pmid: 18043106].
226 Law MR, Wald NJ, Rudnicka AR. Quantifying effect of statins on low density lipoprotein cholesterol, ischaemic heart disease, and stroke: systematic review and meta-analysis. BMJ. 2003;326:1423. [pmid: 12829554].
227 Sjöström CD, Lissner L, Sjöström L. Relationships between changes in body composition and changes in cardiovascular risk factors: the SOS Intervention Study. Obes Res. 1997;5:519-30. [pmid: 9449135].
228 Tonstad S, Pometta D, Erkelens DW, et al. The effect of the gastrointestinal lipase inhibitor, orlistat, on serum lipids and lipoproteins in patients with primary hyperlipidaemia. Eur J Clin Pharmacol. 1994;46:405-10. [pmid: 7957533].
229 Neter JE, Stam BE, Kok FJ, et al. Influence of weight reduction on blood pressure: a meta-analysis of randomized controlled trials. Hypertension. 2003;42:878-84. [pmid: 12975389].
230 Collins R, MacMahon S. Blood pressure, antihypertensive drug treatment and the risks of stroke and of coronary heart disease. Br Med Bull. 1994;50:272-98. [pmid: 8205459].
231 Tothill P. Dual-energy x-ray absorptiometry measurements of total-body bone mineral during weight change. J Clin Densitom. 2005;8:31-8. [pmid: 15722585].
232 Tothill P, Laskey MA, Orphanidou CI, van Wijk M. Anomalies in dual energy x-ray absorptiometry measurements of total-body bone mineral during weight change using Lunar, Hologic and Norland instruments. Br J Radiol. 1999;72:661-9. [pmid: 10624323].
233 Tothill P, Hannan WJ, Cowen S, Freeman CP. Anomalies in the measurement of changes in total-body bone mineral by dual-energy x-ray absorptiometry during weight change. J Bone Miner Res. 1997;12:1908-21. [pmid: 9383696].
234 Arnold AM, Newman AB, Cushman M, et al. Body weight dynamics and their association with physical function and mortality in older adults: the Cardiovascular Health Study. J Gerontol A Biol Sci Med Sci. 2010;65:63-70. [pmid: 19386574].
235 Field AE, Malspeis S, Willett WC. Weight cycling and mortality among middle-aged or older women. Arch Intern Med. 2009;169:881-6. [pmid: 19433700].
236 Rzehak P, Meisinger C, Woelke G, et al. Weight change, weight cycling and mortality in the ERFORT Male Cohort Study. Eur J Epidemiol. 2007;22:665-73. [pmid: 17676383].
237 Wannamethee SG, Shaper AG, Walker M. Weight change, weight fluctuation, and mortality. Arch Intern Med. 2002;162:2575-80. [pmid: 12456229].
238 U.S. Food and Drug Administration. Questions and Answers: Orlistat and Severe Liver Injury. Rockville, MD. U.S. Food and Drug Administration. 2010. Accessed at http://www.fda.gov/Drugs/DrugSafety/PostmarketDrugSafetyInformationforPatientsandProviders/ucm213040.htm. 6 September 2011.
239 Picot J, Jones J, Colquitt JL, et al. The clinical effectiveness and cost-effectiveness of bariatric (weight loss) surgery for obesity: a systematic review and economic evaluation. Health Technol Assess. 2009;13:1-190.
240 Gonzalez R, Murr MM. Anastomotic leaks following gastric bypass surgery. Rosenthal RJ, Jones DB, editors. Weight Loss Surgery: A Multidisciplinary Approach. Edgemont, PA. Matrix Medical Communications. 2008:365-72.
241 Shiffman ML, Sugerman HJ, Kellum JM, et al. Gallstone formation after rapid weight loss: a prospective study in patients undergoing gastric bypass surgery for treatment of morbid obesity. Am J Gastroenterol. 1991;86:1000-5. [pmid: 1858735].
242 Bloomberg RD, Fleishman A, Nalle JE, et al. Nutritional deficiencies following bariatric surgery: what have we learned?. Obes Surg. 2005;15:145-54. [pmid: 15802055].
243 Colquitt JL, Picot J, Loveman E, Clegg AJ. Surgery for obesity. Cochrane Database Syst Rev. 2009. CD003641.
244 Sjöström L. Bariatric surgery and reduction in morbidity and mortality: experiences from the SOS study. Int J Obes (Lond). 2008;32(Suppl 7):S93-7. [pmid: 19136998].
245 Dansinger ML, Gleason JA, Griffith JL, et al. Comparison of the Atkins, Ornish, Weight Watchers, and Zone diets for weight loss and heart disease risk reduction: a randomized trial. JAMA. 2005;293:43-53. [pmid: 15632335].
246 Avenell A, Brown TJ, McGee MA, et al. What are the long-term benefits of weight reducing diets in adults? A systematic review of randomized controlled trials. J Hum Nutr Diet. 2004;17:317-35. [pmid: 15250842].
247 Gardner CD, Kiazand A, Alhassan S, et al. Comparison of the Atkins, Zone, Ornish, and LEARN diets for change in weight and related risk factors among overweight premenopausal women—the A TO Z Weight Loss Study: a randomized trial. JAMA. 2007;297:969-77. [pmid: 17341711].
248 Hession M, Rolland C, Kulkarni U, et al. Systematic review of randomized controlled trials of low-carbohydrate vs. low-fat/low-calorie diets in the management of obesity and its comorbidities. Obes Rev. 2009;10:36-50. [pmid: 18700873].
249 Curioni CC, Lourenço PM. Long-term weight loss after diet and exercise: a systematic review. Int J Obes. 2005;29:1168-74.
250 Franz MJ, VanWormer JJ, Crain AL, et al. Weight-loss outcomes: a systematic review and meta-analysis of weight-loss clinical trials with a minimum 1-year follow-up. J Am Diet Assoc. 2007;107:1755-67. [pmid: 17904936].
251 Shaw K, Gennat H, O'Rourke P, Del Mar C. Exercise for overweight or obesity. Cochrane Database Syst Rev. 2006. CD003817.
252 Wu T, Gao X, Chen M, van Dam RM. Long-term effectiveness of diet-plus-exercise interventions vs. diet-only interventions for weight loss: a meta-analysis. Obes Rev. 2009;10:313-23. [pmid: 19175510].
253 Wing RR, Phelan S. Long-term weight loss maintenance. Am J Clin Nutr. 2005;82(1 Suppl):S222-5.
254 Hernan WH, Brandle M, Zhang P, et al. Costs associated with the primary prevention of type 2 diabetes mellitus in the Diabetes Prevention Program. Diabetes Care. 2003;26:36-47. [pmid: 12502656].
255 Roux L, Kuntz KM, Donaldson C, Goldie SJ. Economic evaluation of weight loss interventions in overweight and obese women. Obesity (Silver Spring). 2006;14:1093-106. [pmid: 16861615].
256 Neovius M, Narbro K. Cost-effectiveness of pharmacological anti-obesity treatments: a systematic review. Int J Obes. 2008;32:1752-63.
257 Simons-Morton DG, Obarzanek E, Cutler JA. Obesity research—limitations of methods, measurements, and medications. JAMA. 2006;295:826-8. [pmid: 16478906].
258 Look AHEAD Research Group, Wing RR. Long-term effects of a lifestyle intervention on weight and cardiovascular risk factors in individuals with type 2 diabetes mellitus: four-year results of the Look AHEAD trial. Arch Intern Med. 2010;170:1566-75. [pmid: 20876408].
259 Foster GD, Borradaile KE, Sanders MH, et al. A randomized study on the effect of weight loss on obstructive sleep apnea among obese patients with type 2 diabetes: the Sleep AHEAD study. Arch Intern Med. 2009;169:1619-26. [pmid: 19786682].
260 Langford HG, Davis BR, Blaufox D, et al. Effect of drug and diet treatment of mild hypertension on diastolic blood pressure. Hypertension. 1991;17:210-7. [pmid: 1671380].
261 Davis BR, Blaufox MD, Hawkins CM, et al. Trial of antihypertensive interventions and management: design, methods, and selected baseline results. Control Clin Trials. 1989;10:11-30. [pmid: 2649308].
262 Orchard TJ, Temprosa M, Goldberg R, et al. The effect of metformin and intensive lifestyle intervention on the metabolic syndrome: the Diabetes Prevention Program randomized trial. Ann Intern Med. 2005;142:611-9. [pmid: 15838067].
263 Frank LL, Sorensen BE, Yasui Y, et al. Effects of exercise on metabolic risk variables in overweight postmenopausal women: a randomized clinical trial. Obes Res. 2005;13:615-25. [pmid: 15833948].
264 Mohanka M, Irwin M, Heckbert SR, et al. Serum lipoproteins in overweight/obese postmenopausal women: a one-year exercise trial. Med Sci Sports Exerc. 2006;38:231-9. [pmid: 16531889].
265 Hansson L, Zanchetti A. The Hypertension Optimal Treatment (HOT) Study—patient characteristics: randomization, risk profiles, and early blood pressure results. Blood Press. 1994;3:322-7. [pmid: 7866597].
266 The Hypertension Optimal Treatment Study (the HOT Study). Blood Press. 1993;(2):62-8. [pmid: 8193735].
267 Wassertheil-Smoller S, Langford HG, Blaufox MD, et al. Effective dietary intervention in hypertensives: sodium restriction and weight reduction. J Am Diet Assoc. 1985;85:423-30. [pmid: 3884691].
268 Davis Martin P, Rhode PC, Dutton GR, et al. A primary care weight management intervention for low-income African-American women. Obesity (Silver Spring). 2006;14:1412-20. [pmid: 16988084].
269 Mensink M, Corpeleijn E, Feskens EJ, et al. Study on Lifestyle-Intervention and Impaired Glucose Tolerance Maastricht (SLIM): design and screening results. Diabetes Res Clin Pract. 2003;61:49-58. [pmid: 12849923].
270 Silva MN, Markland D, Minderico CS, et al. A randomized controlled trial to evaluate self-determination theory for exercise adherence and weight control: rationale and intervention description. BMC Public Health. 2008;8:234. [pmid: 18613959].
271 Teixeira PJ, Silva MN, Coutinho SR, et al. Mediators of weight loss and weight loss maintenance in middle-aged women. Obesity (Silver Spring). 2010;18:725-35. [pmid: 19696752].
272 Simkin-Silverman LR, Wing RR, Boraz MA, et al. Maintenance of cardiovascular risk factor changes among middle-aged women in a lifestyle intervention trial. Womens Health. 1998;4:255-71. [pmid: 9787651].
273 Kuller LH, Simkin-Silverman LR, Wing RR, et al. Women's Healthy Lifestyle Project: a randomized clinical trial—results at 54 months. Circulation. 2001;103:32-7. [pmid: 11136682].
274 Park HA, Lee JS, Kuller LH, Cauley JA. Effects of weight control during the menopausal transition on bone mineral density. J Clin Endocrinol Metab. 2007;92:3809-15. [pmid: 17635939].
275 Whelton PK, Hebert PR, Cutler J, et al. Baseline characteristics of participants in phase I of the Trials of Hypertension Prevention. Ann Epidemiol. 1992;2:295-310. [pmid: 1342280].
276 The effects of nonpharmacologic interventions on blood pressure of persons with high normal levels: results of the Trials of Hypertension Prevention, phase I. JAMA. 1992;267:1213-20. [pmid: 1586398].
277 Hollis JF, Satterfield S, Smith F, et al. Recruitment for phase II of the Trials of Hypertension Prevention: effective strategies and predictors of randomization. Ann Epidemiol. 1995;5:140-8. [pmid: 7795832].
278 Effects of weight loss and sodium reduction intervention on blood pressure and hypertension incidence in overweight people with high-normal blood pressure: the Trials of Hypertension Prevention, phase II. Arch Intern Med. 1997;157:657-67. [pmid: 9080920].
279 Weight Loss Maintenance Trial: Protocol. Portland, OR. Kaiser Permanente Center for Health Research. 2008. Accessed at http://www.kpchr.org/wlmpublic/public/common/getdoc.aspx?docid=817EC236-26D2-4C38-ABCC-741AA815E587. 6 September 2011.
280 Eriksson J, Lindström J, Valle T, et al. Prevention of type II diabetes in subjects with impaired glucose tolerance: the Diabetes Prevention Study (DPS) in Finland—study design and 1-year interim report on the feasibility of the lifestyle intervention programme. Diabetologia. 1999;42:793-801. [pmid: 10440120].
281 Lindström J, Louheranta A, Mannelin M, et al. The Finnish Diabetes Prevention Study (DPS): lifestyle intervention and 3-year results on diet and physical activity. Diabetes Care. 2003;26:3230-6. [pmid: 14633807].
282 Uusitupa M, Peltonen M, Lindström J, et al. Ten-year mortality and cardiovascular morbidity in the Finnish Diabetes Prevention Study—secondary analysis of the randomized trial. PLoS One. 2009;4:e5656. [pmid: 19479072].
283 Villareal DT, Banks M, Sinacore DR, et al. Effect of weight loss and exercise on frailty in obese older adults. Arch Intern Med. 2006;166:860-6. [pmid: 16636211].
284 Villareal DT, Miller BV 3rd, Banks M, et al. Effect of lifestyle intervention on metabolic coronary heart disease risk factors in obese older adults. Am J Clin Nutr. 2006;84:1317-23. [pmid: 17158411].
285 Appel LJ, Espeland M, Whelton PK, et al. Trial of Nonpharmacologic Interventions in the Elderly (TONE): design and rationale of a blood pressure control trial. Ann Epidemiol. 1995;5:119-29. [pmid: 7795830].
286 Chao D, Espeland MA, Farmer D, et al. Effect of voluntary weight loss on bone mineral density in older overweight women. J Am Geriatr Soc. 2000;48:753-9. [pmid: 10894313].
287 Kumanyika SK, Espeland MA, Bahnson JL, et al. Ethnic comparison of weight loss in the Trial of Nonpharmacologic Interventions in the Elderly. Obes Res. 2002;10:96-106. [pmid: 11836455].
288 Kiernan M, King AC, Stefanick ML, Killen JD. Men gain additional psychological benefits by adding exercise to a weight-loss program. Obes Res. 2001;9:770-7. [pmid: 11743061].
289 Jeffery RW, Wing RR. Long-term effects of interventions for weight loss using food provision and monetary incentives. J Consult Clin Psychol. 1995;63:793-6. [pmid: 7593872].
290 James WP, Avenell A, Broom J, Whitehead J. A one-year trial to assess the value of orlistat in the management of obesity. Int J Obes Relat Metab Disord. 1997;21(Suppl 3):S24-30. [pmid: 9225173].
291 Torgerson JS, Arlinger K, Käppi M, Sjöström L. Principles for enhanced recruitment of subjects in a large clinical trial: the XENDOS (Xenical in the Prevention of Diabetes in Obese Subjects) study experience. Control Clin Trials. 2001;22:515-25. [pmid: 11578785].
292 Higgins JP, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0. London. Cochrane Collaboration. 2011. Accessed at www.cochrane-handbook.org. 6 September 2011.
293 U.S. Preventive Services Task Force. Procedure Manual. Rockville, MD. U.S. Preventive Services Task Force. 2011. Accessed at http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm. 6 September 2011.
294 National Institute for Health and Clinical Excellence. The Guidelines Manual. London. National Institute for Health and Clinical Excellence. 2009. Accessed at http://www.nice.org.uk/media/5F2/44/The_guidelines_manual_2009_-_All_chapters.pdf. 6 September 2011.
295 Finer N, Bloom SR, Frost GS, et al. Sibutramine is effective for weight loss and diabetic control in obesity with type 2 diabetes: a randomised, double-blind, placebo-controlled study. Diabetes Obes Metab. 2000;2:105-12. [pmid: 11220522].
296 Blackburn GL, Hutter MM, Harvey AM, et al. Expert panel on weight loss surgery: executive report update. Obesity (Silver Spring). 2009;17:842-62. [pmid: 19396063].
297 Overby DW, Apelgren KN, Richardson W, et al. SAGES guidelines for the clinical application of laparoscopic biliary tract surgery. Surg Endosc. 2010;24:2368-86. [pmid: 20706739].
298 Centers for Disease Control and Prevention. Differences in prevalence of obesity among black, white, and Hispanic adults—United States, 2006–2008. MMWR Morb Mortal Wkly Rep. 2009;58:740-4. [pmid: 19609247].
299 Jacobs EJ, Newton CC, Wang Y, et al. Waist circumference and all-cause mortality in a large US cohort. Arch Intern Med. 2010;170:1293-301. [pmid: 20696950].
300 Buffington CK, Marema RT. Ethnic differences in obesity and surgical weight loss between African-American and Caucasian females. Obes Surg. 2006;16:159-65. [pmid: 16469217].
301 Ergina PL, Cook JA, Blazeby JM, et al. Challenges in evaluating surgical innovation. Lancet. 2009;374:1097-104. [pmid: 19782875].