# Discussion

## Benefits of Screening for Adult Obesity

We found no trials directly examining the benefit of screening for adult obesity. Six behavioral-based trials either screened consecutive patients in primary care practices158,162,165 or identified potentially eligible participants through medical records or disease registries and then invited them for further screening.146,159,178 All of these trials included fewer than 10 treatment sessions. Two of the five trials (both fair-quality) showed greater weight loss in intervention participants.159,165 No medication trials screened consecutive patients in primary care practices; however, three orlistat studies (one good- and two fair-quality) identified potentially eligible participants through medical records or disease registries and then invited them for screening.183, 200,215 These trials showed mixed but generally positive results. These trials suggest that weight loss programs can be effective in screen-detected patients, although it cannot be determined if screening affects the likelihood of success in weight loss (Table 18).

Table 18 Summary of Evidence

# of Studies | Design | Major limitations | Consistency | Applicability | Overall quality | Summary of findings
KQ1. Is there direct evidence that primary care screening programs for adult obesity improve health outcomes or result in short-term (12-18 months) or sustained (>18 months) weight loss or improved physiological measures?
0 screening trials | RCT | No data | N/A | N/A | N/A | N/A
KQ1a. How well is weight loss maintained after an intervention is completed?
0 screening trials | RCT | No data | N/A | N/A | N/A | N/A
KQ2. Do primary care–relevant interventions (behavioral-based interventions and/or pharmacotherapy) in obese or overweight adults lead to improved health outcomes?
Behavioral-based interventions
Death (M): 2 Cardiovascular disease (CVD): 4 Hospitalization (H): 1 Type 2 diabetes (DM): 3 HRQL/depression (Q): 3 | RCT | M: Very low event rate; sparsely reported CVD, H: Low event rates, sparsely reported DM: Sparsely reported Q: Sparsely reported | M: High CVD: High H: N/A DM: High Q: High | M: Low–Moderate; US, self-identified non-primary care samples CVD: Moderate; 2 conducted in US (not primary care) in self-identified samples. 2 conducted in study-identified samples in primary care outside US H: Low–Moderate; US, self-identified non-primary care samples DM: Moderate; conducted in US (not primary care) in self-identified samples. 2 conducted in study-identified samples outside US Q: Low–Moderate; 2 in US, self-identified samples; 1 nonUS recruitment sample NR | M: Good CVD: Fair– Good DM: Fair– Good Q: Fair | M: No differences in death rate, but small number of deaths limits conclusions. CVD: No differences in CVD events, deaths, or CVD-related deaths at 2.5, 3, and 10 years in 3 large, good-quality trials. Additional fair-quality trial showed no difference in % taking cardiovascular medication at 1 year. H: No differences in hospitalization, but low hospitalization rate limits conclusions. DM: In DPP, twice as many in control group than lifestyle intervention group developed diabetes at 3 years (28.9% vs. 14.4%; NNT=7); similar results in similar Finnish trial, but no DM reduction in small trial with very high base rates of elevated fasting glucose. Q: None of 3 trials found group differences in depression outcomes (% screening depressed, depressive symptomatology); small change in HRQL correlated with weight change in DPP.
Pharmacotherapy
[underlined: Orlistat] Death (M): 4 Type 2 diabetes (DM): 2 HRQL/depression (Q): 2 | RCT | M: Very low event rate; sparsely reported DM: Sparsely reported, high attrition Q: Sparsely reported; nonstandard quality of life measure in 1 study | M: High DM: High Q: N/A | M: Moderate; all conducted in primary care setting; 1 in US DM: Low; nonUS, not primary care; 1 trial required 5% weight loss during run-in phase Q: Low; nonUS setting with no connections to primary care | Fair | M: Each study only had 1 death; in all studies deaths were in orlistat group, but no clear relationship with treatment. DM: Both trials reported low incidence of diabetes, by 9-10 percentage points. Q: No difference in depression scores. Orlistat group had greater satisfaction with treatment and less overweight distress. 1 of 8 (vitality) subscales of SF-36 improved with orlistat.
[underlined: Metformin] Death (M): 2 Hospitalization (H): 1 Cardiovascular disease (CVD): 2 Type 2 diabetes (DM): 2 HRQL/depression (Q): 1 | RCT | M: Very low event rate; sparsely reported H: Sparsely reported CVD: Sparsely reported DM: Sparsely reported Q: Sparsely reported | M: High H: N/A CVD: High DM: High Q: N/A | M, CVD, DM: Low–Moderate; 1 conducted in self-identified samples, no connection to primary care; 1 study in Europe with no connection to primary care H, Q: Low–Moderate; US, self-identified sample, no connection to primary care | Fair–Good | M: No difference between groups, but small number of deaths limits conclusions. H: No difference in hospitalization. CVD: No difference in CVD events. DM: Incidence of diabetes was reduced in good-quality trial in prediabetics after 3 years (21.7% vs. 28.9%; NNT=14). Smaller trial with unclear adjudication also found decreased risk of diabetes in those randomized to metformin. Q: No difference in depression.
KQ2a. What are common elements of efficacious interventions?
Behavioral-based interventions
N/A | N/A | N/A | N/A | N/A | N/A | Insufficient data to examine.
KQ2b. Are there differences in efficacy between patient subgroups?
Behavioral-based interventions
Death, hospitalization (M, H): 1 Type 2 diabetes (DM): 1 HRQL/depression (Q): 2 | RCT | M, H: Sparsely reported; not powered to look for subgroup effects DM: Sparsely reported; not powered to look for subgroup effects Q: Sparsely reported | M, H, DM: N/A Q: High | All: Moderate; both conducted in US, not in primary care, in self-identified samples | M, H, DM: Good Q: Fair– Good | M, H: DPP found no treatment-by-age interactions in hospitalizations or deaths. DM: DPP found that diabetes incidence decreased in the older age groups in the behavioral intervention group; there was no difference in incidence in age groups in the placebo group. Intervention had greater effects among persons with lower baseline glucose concentrations after a 2-hour glucose load. Q: Neither trial found that treatment affected depression, nor did either report that men and women differed in their response to treatment.
Pharmacotherapy
[underlined: Orlistat]: 0 | N/A | N/A | N/A | N/A | N/A | No studies examined health outcomes by subgroups and subgroup analyses could not be conducted.
[underlined: Metformin] Death, hospitalization (M, H): 1 Type 2 diabetes (DM): 1 HRQL/depression (Q): 1 | RCT | M, H: Sparsely reported; not powered to look for subgroup effects DM: Sparsely reported; not powered to look for subgroup effects Q: Sparsely reported | All: N/A | All: Moderate; one in US, neither in primary care, both in self-identified samples | M, H, Q: Good DM: Good– Fair | M, H: DPP found no treatment-by-age interactions in hospitalizations or deaths. DM: DPP found that diabetes incidence was lower in younger age groups in metformin intervention group; there was no difference in incidence in age groups in placebo group. The effect of metformin was less in those with a lower BMI or lower fasting glucose. Treatment effects did not differ according to sex or ethnicity. Q: DPP did not find that treatment affected depression, nor did it report that men and women differed in their response to treatment.
KQ3. Do primary care–relevant interventions (behavioral-based interventions and/or pharmacotherapy) in obese or overweight adults lead to short-term or sustained weight loss, with or without improved physiological measures?
Behavioral-based interventions
Weight loss (W): 38 Adiposity (A): 14 Lipids (L): 16 Blood pressure (BP): 22 Glucose tolerance (GT): 12 (7 in populations selected for impaired glucose tolerance or diabetes) | RCT | All: High variability in design, setting population, and statistical heterogeneity in outcomes Lipids and glucose tolerance somewhat sparsely reported and subject to reporting bias. | All: Moderate | All: Moderate; two thirds conducted in US, but only 4 in US primary care, most in self-identified samples. | All: Fair– Good | W: Average of 3.0 kg more weight lost in intervention than control groups, ranging from no effect to 8.3 kg greater weight loss in intervention group. Group differences remain in long term, especially for higher-intensity interventions. A: Waist circumference reduced by average of 2.7 cm more in intervention than control groups. L: Little evidence that behavioral treatment improves lipids. Meta-analysis results likely overestimate lipid changes. BP: Average of 2.5/1.9 mmHg greater reduction in blood pressure in intervention than control groups. Reductions frequently maintained beyond 18 months with continued support. Risk of hypertension reduced with behavioral treatment in those with prehypertension; NNT for hypertension was 14 in large, good-quality trial. GT: Average of 5.3 mg/dL greater decline in fasting glucose in intervention than control groups in trials targeting patients with diabetes or impaired glucose tolerance. Little evidence that behavioral treatment improves glucose in other populations, where meta-analysis results likely overestimate glucose changes.
Pharmacotherapy
[underlined: Orlistat] Weight loss (W): 18 Adiposity (A): 12 Lipids (L): 18 Blood pressure (BP): 14 Glucose tolerance (GT): 14 | RCT | All: Most had high attrition; slightly over 60% of trials required successful run-in phase BP: Half could not be included in meta-analysis of SBP, and more than half (8 of 14) could not be included in meta-analysis of DBP | W: Moderate A: Moderate L: Moderate– High BP: Moderate GT: Low– Moderate | All: Low; only 5 conducted in US, only 1 in US primary care, almost all self-identified samples, most trials with run-in phase lost 10-20% of participants before randomization | All: Fair (17)–Good (1) | W: Average of 3.0 kg more weight lost in orlistat than placebo groups. Both groups also received behavioral interventions that were more intensive than would be typically found in primary care. Relative risk of losing 5% or more of initial weight was 1.57 (NNT=5). A: Waist circumference reduced by average of 2.3 cm more among those taking orlistat than those taking placebo. L: Orlistat was associated with greater average declines in total cholesterol (12.6 mg/dL) and LDL (11.4 mg/dL), but also with greater declines in HDL (0.9 mg/dL). BP: Small (2.0/1.3 mm Hg) or no greater reduction in blood pressure in those taking orlistat than those taking placebo. GT: Average of 5.7 mg/dL greater decrease in fasting glucose in those taking orlistat than those taking placebo, larger effects in studies of those with type 2 diabetes.
[underlined: Metformin] Weight loss (W): 3 Adiposity (A): 2 Lipids (L): 3 Blood pressure (BP): 2 Glucose tolerance (GT): 3 | RCT | Few trials total, with very different populations | All: Low–Moderate | All: Low (for general US primary care) Moderate (for patients at risk of diabetes); only 1 conducted in US, all involved selected samples, none conducted in primary care | All: Fair–Good | W: The good-quality trial of patients with prediabetes showed the largest effects (2.3 kg statistically greater weight loss with metformin), and included only a brief behavioral intervention. A trial of those with high WHR found that those on metformin lost a nonsignificant 1.2 kg more than those on placebo. A small trial of those with PCOS found no difference in weight loss between metformin and placebo. A: In DPP, waist circumference declined by an average of 1.5 cm more in those taking metformin than those taking placebo. A very small trial in women with PCOS did not find a significant difference. L: Metformin did not have favorable effects on total cholesterol, HDL, LDL, or triglycerides. Long-term metformin in DPP had favorable but small (<1mg/dL) effects on HDL. BP: Metformin did not improve blood pressure. GT: In DPP, metformin led to greater reductions in fasting glucose (4.2 mg/dL) compared with placebo (0.6 mg/dL). 2 smaller studies did not find effects of metformin on glucose measures.
KQ3a. How well is weight loss maintained after an intervention is completed?
Behavioral-based interventions
Maintenance trials (M): 3 Followup 4+ months after treatment ended (F): 6 | RCT | M: Few trials F: Few trials, very heterogeneous in terms of study design, outcomes reported, quality, and intensity of interventions. | M: Fair F: Low | M: Moderate; all 3 set in US, using self-identified samples, not connected to primary care F: Low; half conducted in US with self-identified participants and no connection to primary care; only 1 of nonUS trials in primary care | M: Fair–Good F: Fair–Good | M: Interventions involving 26 or more sessions over 18-24 months improved weight maintenance after weight loss, but no group differences were seen in less intensive programs. Only one of the more intensive trials had a period of at least 6 months of no contact at the end of the maintenance intervention; the others measured outcomes at the end of the maintenance intervention. F: 4 of 6 trials showed continued benefit 4-18 months after treatment ended; intensity of these programs ranged from 5 to 30 contacts.
Pharmacotherapy
[underlined: Orlistat] Maintenance trials (M): 1 Followup 4+ months after treatment ended (F): 0 | RCT | M: Few trials | M: N/A | M: Low; maintenance after a very low calorie diet | M: Fair | M: Those randomized to 120 mg tid of orlistat regained less weight than those randomized to placebo. 60 mg tid of orlistat was not as effective. F: No trials examined maintenance of weight loss after treatment with orlistat had ended.
[underlined: Metformin]: 0 | RCT | N/A | N/A | N/A | N/A | No trials examined maintenance of weight loss after treatment with metformin had ended.
KQ3b. What are common elements of efficacious interventions?
Behavioral-based interventions
38 | RCT | Variability in intervention details reported; most trials were efficacious; many sources of variability besides treatment components that may influence effect size | N/A | All: Moderate; two thirds conducted in US, but only 4 in US primary care; most in self-identified samples. | All: Fair–Good | Number of sessions in first year was the only element consistently related to effect size. No association was found for physical activity sessions, group sessions, individual sessions, technology-based intervention, specific weight loss goals, spouse or family involvement, addressing barriers to weight loss, motivational assessment (i.e., pros and cons of weight loss), self-monitoring, incentives for weight loss or participation, or support after active intervention phase.
KQ3c. Are there differences in efficacy between patient subgroups?
Behavioral-based interventions
Age (A): 5 Sex (S): 8 Race (R): 6 Baseline BMI (B): 4 CV risk status (CVRS): 38 | RCT | All: Sparsely reported, trials often not powered for subgroup effects CVRS: Individual trials did not perform subgroup analysis; results summarized here are comparisons of results from studies of participants with CVRS with studies of unselected or low-risk participants | A: Moderate S: Low–Moderate R: Low–Moderate B: Moderate CVRS: Moderate | All: Moderate | All except CVRS: Good (most trials reporting subgroup analyses rated good-quality) CVRS: Fair–Good | A: Good-quality trials found larger improvements in weight, waist circumference, and incident diabetes in older participants; 3 found no age effects on weight. S: Men lost more weight than women in 4 of 5 trials testing effect of sex, but other variables eliminated this effect in 2 trials. No to minimal differences in other intermediate outcomes of blood pressure and lipids. R: Black participants lost less weight than nonblacks in 3 of 4 trials testing effect of race; mixed results for incident hypertension in 2 trials. B: Baseline BMI predicted weight loss in only 1 of 4 trials at 12 months or beyond. CVRS: Weight loss did not vary by CV risk status; effect on glucose appears larger in trials of participants with diabetes or prediabetes; no apparent effect of CV risk status on other intermediate health outcomes.
Pharmacotherapy
[underlined: Orlistat] Age (A), Sex (S), Race (R), Baseline BMI (B): 0 CV risk status (CVRS): 18 | RCT | CVRS: Individual trials did not perform subgroup analysis; results summarized here are comparisons of results from studies of participants with CVRS with studies of unselected or low-risk participants | CVRS: Moderate–High | All: Low; only 5 conducted in US, only 1 in US primary care; almost all self-identified samples; most trials with run-in phase lost 10-20% of participants before randomization | CVRS: Fair (17)–Good (1) | A, S, R, B: No trials examined effects of age, sex, race, or baseline BMI. CVRS: Weight loss did not vary by CV risk status. Greater improvements in glucose seen in trials of patients with diabetes.
[underlined: Metformin] Age (A), Race (R), Sex (S): 1 | RCT | A, R, S: Not powered for subgroup effects. | A, R, S: N/A | All: Low–Moderate; US, self-identified sample, no connection to primary care | All: Good | A: Weight loss and waist circumference reductions greatest in oldest age group (ages 60-85 years). R, S: Treatment effects did not differ by sex or race.
KQ4. What are the adverse effects of primary care–relevant interventions in obese or overweight adults?
Behavioral-based interventions
Bone mineral density (BMD): 4 Serious adverse event (SAE): 2 Serious injury (SI): 2 Mild musculoskeletal injury (MI): 1 Eating disorder (ED): 1 | RCT | Fair studies: High attrition and/or small numbers of participants or followup of less than 1 year | BMD: Low–Moderate SAE: High SI: High MI: N/A Eating disorder: N/A | All: Moderate; most conducted in US | All: Good–Fair | BMD: 3 of 4 studies noted a decrease in total or hip bone density with weight loss. SAE: No serious adverse events reported in any treatment group. SI: No serious injuries reported in any treatment group. MI: Increase in mild musculoskeletal injuries with supervised exercise program, but did not affect daily activities or work attendance. ED: 1 study showed improvement, not worsening, of eating disorder symptoms with behavioral weight loss treatment.
Pharmacotherapy
[underlined: Orlistat] Withdrawals (W): 23 Any adverse event (AE): 8 Serious adverse event (SAE): 13 Bone mineral density (BMD): 1 Vitamin deficiency (V): 5 Liver injury (L): 1 | RCT (23) Event monitoring (1) | RCT: Most had high attrition; many had run-in phase with required compliance and/or weight loss requirement Event monitoring: Retrospective reporting and low response rate | W: Moderate AE: Moderate SAE: Moderate BMD: N/A V: Moderate L: N/A | All: Low; few conducted in US, even fewer in US primary care; almost all self-identified samples; most trials with run-in phase lost 10-20% of participants before randomization | All: Fair | W: More withdrawals in orlistat group than placebo; primarily due to gastrointestinal side effects of orlistat. AE: More adverse events in orlistat group than placebo; primarily due to gastrointestinal side effects of orlistat. SAE: No increase in serious adverse events in orlistat group. BMD: Data insufficient. V: Orlistat most closely associated with lower vitamin E and beta-carotene. Some evidence for lower vitamin A and K. Orlistat participants required more vitamin supplementation during the study. L: UK monitoring study reported elevated liver tests in 2 cases; no cases of serious hepatic adverse reactions.
[underlined: Metformin] Withdrawals (W): 2 Total adverse events (AE): 2 Serious adverse events (SAE): 0 Bone mineral density (BMD): 0 | RCT | High attrition or small number of participants | W: High AE: Moderate SAE: N/A BMD: N/A | All: Low (for general US primary care) Moderate (for patients at risk of diabetes); only 1 conducted in US, all involved selected samples, none conducted in primary care | All: Fair | W: More withdrawals in metformin group than placebo; primarily due to gastrointestinal side effects of metformin. AE: More adverse events in metformin group than placebo; primarily due to gastrointestinal side effects of metformin. SAE: No data. BMD: No data.
KQ4c. Are there differences in efficacy between patient subgroups?
Behavioral-based interventions
0 trials examined subgroups | RCT | No data | N/A | N/A | N/A
Pharmacotherapy
[underlined: Orlistat] CV risk status (CVRS): 23 | RCT | Individual trials did not perform subgroup analysis; results summarized here are comparisons of results from studies of participants with CVRS with studies of unselected or low-risk participants | Fair | Low; few conducted in US, even fewer in US primary care; almost all self-identified samples; most trials with run-in phase lost 10-20% of participants before randomization | Fair–Good | Those with CV risk factors were less likely to withdraw due to adverse events or to experience serious adverse events compared with those who were unselected for CV risk factor/at low risk.
[underlined: Metformin] Gastrointestinal adverse events (GI): 1 | RCT | Not powered to examine subgroup effects | N/A | Low–Moderate; US, self-identified nonprimary care samples | Good | GI: Did not differ by age.

Abbreviations: BMI=body mass index; CV=cardiovascular; DBP=diastolic blood pressure; DPP=Diabetes Prevention Program; HDL=high-density lipoprotein; HRQL=health-related quality of life; KQ=key question; LDL=low-density lipoprotein; N/A=not applicable; NNT=number needed to treat; NR=not reported; PCOS=polycystic ovary syndrome; RCT=randomized, controlled trial; SF-36=36-item Short-form Health Survey; SBP=systolic blood pressure; tid=three times a day; UK=United Kingdom; US=United States; WHR=waist-to-hip ratio.

## Benefits of Weight Loss Treatment

### Weight Loss

Participants of behavioral interventions lost an average of 3.0 kg more than control groups. Participants in control groups generally lost little or no weight, while the average weight loss in intervention groups ranged from 0 to 7 kg, with most falling in the 1.5 to 5 kg range, losing 4 percent of baseline weight on average (Table 19). These results are consistent with the previous review, despite the fact that only five of the trials in the current review were included in the 2002 review (Appendix B Table 3). Also consistent with the previous review, we found that intervention intensity influenced the amount of weight loss. Trials that provided 12 to 26 intervention sessions during the first year had a weighted average weight loss of 5.3 kg (generally 4 to 7 kg), or 6 percent of baseline weight, at 12 to 18 months compared with 0.3 kg weight loss (<1 percent of baseline weight) in control groups. The 2002 review reported an average weight loss of 2.7 to 5.5 kg in trials that involved more than monthly face-to-face contact for the first 3 months.

Table 19 Interquartile Range^*^ of Weight Change in Intervention and Control/Placebo Groups

Type of trial | No or minimal treatment (+ placebo for medication trials) | Behavioral treatment^**^ (+ placebo for medication trials) | No or minimal treatment + medication | Behavioral treatment^**^ + medication
Behavioral | +0.5 to -0.9 kg (27 trials) | 0-11 sessions: -1.5 to -4.2 kg (10 trials) 12-26 sessions: -3.8 to -6.8 kg (11 trials) | (--) | (--)
Orlistat | (--) | -3.3 to -6.4 kg (12 trials) | (--) | -5.6 to -9.5 kg (12 trials)
Metformin | -0.4 to -0.8 (2 trials) | -5 kg (1 trial) | -2.0 to -2.7 kg (2 trials) | -4 kg (1 trial)

* Full range provided if fewer than four trials.

** Behavioral treatment in medication trials rated as “intense” (i.e., more than could be expected in usual care).

Weight loss could be maintained for an additional year or more after completion of an active weight loss phase, particularly with additional support after completion. No other factors were clearly related to effect size in the included trials, but high variability in the intervention approaches, trial design, and populations may have obscured important relationships.

Taking a weight loss medication generally increased the amount of weight loss over and above that of the accompanying behavioral-based intervention (Table 19). These results are generally similar to the previous evidence review, despite the fact that only two of the 13 medication trials from the previous review were included in the current review (Appendix B Table 4). The absolute amount of weight loss varied substantially between trials, as did the extent of the treatment's behavioral component. Orlistat resulted in 5 to 10 kg of weight loss (8 percent of baseline weight). Metformin was associated with a smaller degree of weight loss (2 to 4 kg). The previous evidence review did not conclude that metformin led to significant weight loss, but it included only one study of metformin217 and that study was not included in our review.

Although the medication trials were conducted in more obese samples than the behavioral trials, the placebo groups that received an intensive behavioral intervention typically experienced 3 to 6 kg of weight loss, which is roughly comparable with that seen in behavioral weight loss trials with 12 or more intervention sessions (Table 19). Weight loss in placebo groups that received no or minimal behavioral treatment was minimal to nonexistent, consistent with the control groups of behavioral trials.

Weight loss of 5 and 10 percent of baseline weight was frequently reported in orlistat trials but not for metformin. This outcome was only rarely reported and varied substantially in the behavioral-based trials. Five percent weight loss is considered to be clinically meaningful by the FDA, where it is considered a primary weight loss outcome.218 Most orlistat trials reported that between one third and three fourths of intervention participants lost 5 percent or more of their initial weight after 1 year (compared with one tenth to one half in placebo participants). About half as many participants lost 10 percent of their initial weight as those who lost 5 percent.

Behavioral-based weight loss interventions consistently showed 2 to 5 cm greater reductions in waist circumference than placebo. The absolute reduction in waist circumference with orlistat was generally 5 to 9 cm compared with 2 to 7 cm in the placebo groups. Metformin led to a smaller, but still significant, reduction in waist circumference (2 to 5 cm).

### Weight Loss Results in Different Patient Subgroups

Data on the effects of weight loss or maintenance programs in subgroups were sparsely reported and somewhat mixed. Behavioral interventions appeared, on average, to lead to less weight loss in blacks and women than nonblacks and men.28,145,152,157,168,170,171,175,177,214 The only trial of medication examining subgroup effects was the metformin arm of DPP, which found that ethnicity and sex were not related to amount of weight lost.214 Older participants showed greater weight loss than younger participants in both the lifestyle and metformin arms of DPP.142 Although another good-quality behavioral trial169 also found increased weight loss with increasing age, three other behavioral trials showed no age-by-treatment interactions.152,170,171 Baseline BMI generally did not have an impact on treatment effect size at 12 months or beyond.

## Clinical Health Outcomes

The amount of weight loss apparent in the included trials did not demonstrate an effect on mortality, cardiovascular disease events, hospitalizations, or depression, although data were sparse for all outcomes. The two good-quality trials reporting one or more of these outcomes were not powered to detect group differences in these outcomes, other than depressive symptoms.142,172

Epidemiologic data about whether the degree of weight loss seen in the behavioral and medication trials is associated with reduced mortality were mixed. The relationship is likely confounded by a number of factors, particularly health status. Most,219-222 but not all,223 data suggest that intentional weight loss of less than 9 kg was not associated with reduced mortality. However, these studies generally assessed the intentionality of weight loss at only one time point and several relied on retrospective assessment of weight loss. Prospective cohort studies of obese adults undergoing bariatric surgery show substantial improvements in health; however, weight loss in these patients is generally on the order of 25 to 50 kg.224,225

### Lipids

The pooled estimates for lipid changes with behavioral interventions were at high risk of reporting bias because lipid outcomes were rarely reported. We concluded that there were either no or very small effects of weight loss interventions on lipid outcomes in the included trials. In the few studies that did report lipid changes with behavioral weight loss interventions, the reduction in LDL cholesterol (generally 2 to 11 mg/dL) was substantially smaller than that seen with statin medications, which can cause LDL reduction on the order of 70 mg/dL.226 These negative results for total cholesterol are not unexpected, based on data from the Swedish Obesity Subjects Study. This observational study of surgically and conventionally treated obese persons found that a weight loss of 20 to 30 kg was required to detect improvements in total cholesterol. Triglycerides and HDL cholesterol demonstrated marked improvements in response to large amounts of weight loss in this study.227

Orlistat had favorable effects on lipid outcomes compared with placebo. Reductions in LDL cholesterol ranged from 3 to 27 mg/dL. Patients with dyslipidemia, however, had LDL reduction of more than 37 mg/dL with orlistat.183 Orlistat may cause a decrease in lipid levels by a mechanism independent of weight loss;228 it may decrease lipids as a result of decreased absorption and increased fecal fat loss. Although still substantially smaller than statins' effects, an LDL reduction of 38 mg/dL has been associated with a 50 percent or more reduction in ischemic heart disease-related mortality in persons ages 45 to 59 years.9 In contrast, metformin did not improve lipid profiles compared with placebo.

### Blood Pressure

Behavioral weight loss interventions led to a greater reduction in blood pressure compared with placebo. SBP and DBP decreased by 2.5 and 1.9 mm Hg more, respectively, in behavioral intervention groups than in control conditions. Our findings are consistent with the findings of a previous meta-analysis of behavioral weight loss RCTs,229 which estimated that each kilogram of weight loss led to a 1.0 and 0.9 mm Hg decrease in SBP and DBP, respectively.229 Translated to our trials, we would expect a decrease of roughly 5 mm Hg in SBP and 4.8 mm Hg in DBP in the high-intensity intervention groups, which is what we observed.

Participants taking orlistat showed a 2.0 mm Hg greater reduction in SBP and a 1.3 mm Hg greater reduction in DBP than those taking placebo medications. However, the absolute reduction in blood pressure (SBP: 2 to 6 mm Hg; DBP: 2 to 5 mm Hg) with orlistat was about the same as in the behavioral trials, despite the greater weight loss achieved with orlistat. The reduction was highest in studies of participants with any cardiovascular risk factor, including hypertension. Metformin did not have favorable effects on blood pressure compared with placebo.

Reductions of 5 to 6 mm Hg in DBP over 5 to 10 years have been associated with 33 percent or more reduction in stroke incidence and 16 percent reduction in CHD events in persons with and without hypertension.230 Reductions of this magnitude were reported in some orlistat and behavioral-based trials in this review over 12 to 36 months, although none reported outcomes beyond 3 years.

### Diabetes

Diabetes outcomes were rarely reported in behavioral trials. We therefore focused on two large, good-quality behavioral trials of diabetes prevention.142,172 Behavioral interventions (7 to 23 sessions in first year) led to weight loss of 4 to 7 kg and decreased the incidence of diabetes by approximately half or more over 2 to 3 years. One of these trials, DPP, also examined metformin and noted a 31 percent reduction in diabetes incidence.213 The authors continued to follow participants after unblinding them and offering all participants the lifestyle treatment program, as well as additional booster sessions. Ten years after the original randomization, lifestyle and metformin participants still had a median delay of diabetes onset of 4 and 2 years, respectively, compared with controls.213 In two studies of persons with and without IGT, orlistat was associated with a reduced incidence of diabetes, although we had concerns about the reliability and generalizability of the data.

### Glucose Tolerance

Because trials of low-risk populations inconsistently reported fasting glucose outcomes, we focused on studies of individuals with prediabetes or diabetes, which more consistently reported fasting glucose changes. Behavioral-based interventions, orlistat, and metformin all led to a greater decline in fasting glucose than controls. Glucose reduction was greatest with orlistat (12 mg/dL greater reduction than placebo), possibly because those studies were all conducted in persons with diabetes. In behavioral and metformin studies of persons with prediabetes and diabetes, the decrease in fasting glucose was more modest (group differences of 5.3 and 4.8 mg/dL with behavioral intervention and metformin, respectively).

We did not find recent epidemiologic data that would allow us to gauge whether the effects of weight loss on diabetes risk or glucose tolerance in the included trials was consistent with the effects in real-world settings.

## Harms of Screening for Adult Obesity

No trials directly examined the harms of screening for adult obesity. The methods of measuring obesity in common practice (BMI, waist circumference, WHR) are low cost and have no direct physical harms. Possible secondary harms include labeling stigma, higher insurance premiums, or reinforcement of poor self-esteem. Misclassification is possible if BMI is used for screening because of differences in BMI's ability to predict future health risk, especially in different ethnic groups. Evidence is still being obtained on how we should adjust guidelines for more accurate identification of those at risk in order to better target management once screening positive.

## Harms of Weight Loss Treatment

Possible harms that could accrue from weight loss interventions include bone loss and increased fracture risk, injuries from increased physical activity, decreased self-esteem from being labeled as obese or failure to lose weight, use of extreme or unhealthy dietary approaches, and weight cycling. Limited data suggest that weight loss may be associated with decreased bone density at the hip. However, whether it is valid to measure bone density changes during weight changes is unclear; changes in fat distribution may alter bone measurements despite no real change in bone density.231-233 Also, the clinical significance of the bone loss is unclear, given the lack of data on changes in bone density after weight loss has stopped and subsequent fracture risk. Risk of minor, but not serious, injuries increased with a supervised exercise component. However, the mild injuries did not result in lost work time or a major change in daily activities. The included trials found no evidence that weight loss interventions are associated with an increased risk of eating disorders or depression, but these data were limited. No studies evaluated whether weight loss interventions increase the risk of weight cycling. However, whether weight cycling even leads to increased morbidity or mortality is unclear.234-237

Medications can lead to additional harms due to side effects. Orlistat and metformin caused mild to moderate gastrointestinal side effects that resulted in medication discontinuation.

Although orlistat did not cause more serious side effects than placebo in the included trials, the FDA recently (May 2010) approved a revised label for orlistat 120 mg (prescription strength) and 60 mg (over-the-counter strength). The revised label includes “new safety information about cases of severe liver injury that have been reported rarely with the use of this medication.”238 The FDA noted the possibility of severe liver injury during routine monitoring of submitted postmarketing adverse events. In the FDA's review, 13 cases of severe liver injury were identified. Two persons died and three required liver transplantation. Twelve of the identified persons had taken 120 mg tid and one had taken 60 mg tid. The FDA could not establish if there was a cause and effect relationship because other factors or drugs may have contributed in some of the cases.238

As described in Appendix G, surgery is another treatment option for obesity. There are short-term risks associated with surgery, including perioperative mortality, infection, bleeding, deep venous thrombosis, pulmonary embolism, and gastrointestinal leaks.239,240 Long-term harms include symptomatic ulcers, gastroesophageal reflux disease, diarrhea, cholelithiasis,241 and nutritional deficiencies.242 Surgical reoperations (excluding reoperation in the perioperative period for complications) range from 17–31 percent depending on the type of surgery.239,243,244

## Effectiveness of Specific Weight Loss Strategies

Greater treatment intensity was associated with greater weight loss. The association with treatment intensity was apparent despite the fact that our measure of treatment intensity (number of sessions in the first year) was imperfect, and particularly broke down at the extremes (e.g., one trial with “0” sessions involved extensive electronic contact, and one trial with 128 sessions was targeted toward physical activity and provided little counseling for dietary change). We also defined treatment intensity slightly differently in the behavioral and medication trials, but found similar weight loss in medication trials labeled as “intense” and behavioral trials involving 12 or more intervention sessions. Most of the higher-intensity behavioral-based interventions included coverage of behavioral management activities, such as self-monitoring, setting weight loss goals, addressing barriers to change, and strategizing how to maintain long-term behavioral changes. However, we found no association between effect size and any of these components or any other specific intervention characteristics.

We examined reviews and comparative effectiveness trials (which were excluded from this evidence review) to provide more information on the effectiveness of specific weight loss approaches. In two systematic reviews, all diets—if adhered to—resulted in weight loss, and the difference in weight loss between the various diets was negligible.123,245 Some reviews have found slight benefits to protein sparing modified fasts (e.g., Optifast and Modifast products),246 the Atkins diet (low carbohydrate),247 or a low carbohydrate/high protein diet.248

Weight loss may be sustained better over time when diet and exercise are combined.249-252 Higher-intensity exercise led to greater improvement in cardiovascular disease risk factors.251 In the National Weight Control Registry, a database of over 4,000 persons who successfully maintained their weight after a weight loss, those who successfully maintained weight loss had a high level of physical activity, consumed low-calorie, low-fat diets, consumed a regular breakfast, self-monitored weight and food intake (e.g., kept food diaries), maintained consistent eating patterns across weekdays and weekends, and recovered from small weight regains quickly. The most common weight loss trigger for this population was a medical event (23 percent), which included diagnosis of diabetes, a family member having a heart attack, or a doctor telling them they must lose weight.253

## Applicability to Primary Care

Only four trials of behavioral-based interventions were conducted in primary care settings in the United States.146,147,158,159 All reported small amounts of weight loss in the intervention groups (0.1 to 2.2 kg), and only one showed greater weight loss compared with the control group (by 1.7 kg) after 1 year.159 This trial had the most intensive intervention arm of all four trials, including 22 group sessions with a nutritionist in the first year. The same trial had a lower-intensity intervention arm (only four sessions over the course of the first year) that was not effective in helping participants lose weight. Aside from this trial, most of the successful behavioral-based interventions in the United States were not highly applicable to primary care. The participants had to be motivated to respond to advertisements or other media announcements. The interventions usually involved 12 or more sessions in 1 year, a high burden for a primary care clinic to undertake.

One fair-quality orlistat trial was conducted in a U.S. primary care setting.189 Only study physicians (not dietitians) were involved, along with video presentations. Weight loss was 3 kg greater in the intervention group (7 kg vs. 4 kg). None of the metformin studies recruited exclusively from primary care or were conducted in the primary care setting.

## Cost/Cost Effectiveness

The only included study that had accompanying cost effectiveness data was DPP.254 Compared with placebo, cost per quality-adjusted life year (QALY) gained was estimated at approximately $1,100 for the DPP lifestyle intervention and $31,300 for the metformin intervention in year 2000 dollars.254 (The standard threshold of cost effectiveness in the United States is $35,000 to $50,000 per QALY gained.) Because the weight loss effect was greater in DPP compared with other trials, this cost effectiveness evaluation may be a best care scenario. Over 3 years, implementing the lifestyle or metformin arms of DPP was estimated to cost a health care plan $2,250 per participant and reduce health care utilization and direct medical costs by $423 and $272 in the lifestyle and metformin intervention groups, respectively.254

Simulation studies are the main source of data on the cost effectiveness of behavioral interventions. For example, a recent Monte Carlo simulation study255 estimated that a weight loss intervention that included dietary counseling, physical activity, and behavioral modification training in otherwise healthy overweight or obese women ages 35 years would cost $12,600 per QALY gained over their lifetime.

A systematic review modeled the cost effectiveness or cost utility of orlistat treatment for obesity.256 The median incremental cost effectiveness ratio for orlistat was $36,400 per QALY, with a median modeled time horizon of 7.5 years.

## Limitations of the Review

Although we included 58 unique trials of weight loss efficacy, they were variable in the specific outcomes reported, and about one third of the trials could not be included in the meta-analysis of our primary outcome—weight loss. Intermediate physiologic outcomes (blood pressure, lipid levels, and fasting glucose) were sparsely reported, and also could not often be included in meta-analyses.

The applicability of our findings to primary care patients is unclear. Few of the studies were conducted in primary care settings and the interventions were often intensive and difficult to implement within a primary care setting (although overweight and obese patients could be referred into such programs by primary care providers). Participants in the behavioral-based weight loss trials generally fell into the overweight or class I obesity range, and the generalizability of these results to extremely obese persons is unknown. Most of the medication trials had run-in periods before randomization and usually required a certain degree of weight loss and/or compliance for inclusion in the main trial. Therefore, trial participants were likely more highly motivated, compliant, and responsive than primary care patient populations. The medication trials were almost exclusively financed by pharmaceutical companies; however, the one orlistat trial not financed by a pharmaceutical company had the largest effect size of all the trials.215

Our results, especially our medication findings, could also have been biased by high attrition. We chose to include studies with up to 40 percent attrition and/or 20 percent differential attrition. We made this decision because we believed it might be challenging for overweight and obese populations to continue participating in a trial for a full year or longer. We felt that early discontinuation might be common regardless of trial design and not necessarily due to a design flaw. The majority of medication trials included all randomized participants using the last-observation-carried-forward method of imputing intention-to-treat results. Epidemiological studies have shown that most weight loss occurs early in the intervention and that weight is often regained toward baseline or even higher levels.257 Therefore, using the last-observation-carried-forward approach to impute such large amounts of data (up to 40 percent) might have led to biased comparisons in unknown directions. We did examine the effect of attrition on effect size using meta-regression, but did not find that attrition had significant effects. The last-observation-carried-forward method was less common in the behavioral trials (in which attrition was generally lower than in medication trials). Behavioral trials were more likely to impute missing data through multilevel repeated measures modeling than carrying the last observation forward. However, behavioral trials were also more likely to drop participants from an analysis if they had missing data.

We reviewed several topics of high relevance to this topic as contextual questions only and not systematically. We did not include comparative effectiveness trials, as included studies had to have a control group with only a minimal intervention (Appendix A). Comparative effectiveness trials would shed more light on the components of an effective intervention. We also did not systematically examine the best screening approach. A growing body of evidence suggests that WHR or waist circumference may be better predictors of future health effects than BMI, especially for some subgroups. Finally, we only included one off-label medication, metformin. Other medications that are used off label for weight loss include zonisamide, an antiepileptic agent.114 We also did not include antiobesity drugs in development, including Lorcaserin, Qnexa (a combination of phentermine and topiramate), or Contrave (a combination of naltrexone and bupropion).

We excluded studies with control groups that had more than a minimal intervention. A total of 143 studies were excluded because the control intervention was considered too intensive. One such study, Look AHEAD (Action for Health in Diabetes), is an important study of a behavioral weight loss intervention in persons with diabetes. The controls in this study had three group sessions on diet, physical activity, and social support each year. Look AHEAD had similar, if not slightly more positive, findings than the findings of our systematic evidence report. In Look AHEAD, 4 years of an intensive lifestyle intervention (42 sessions in the first year) led to 6 percent weight loss (compared with <1 percent in controls), decreased SBP and DBP, and improvement in HDL cholesterol and triglycerides.258 The lifestyle intervention also led to significant and clinically relevant improvements in obstructive sleep apnea, especially in those participants who lost at least 10 kg.259

## Future Research

A study examining the effect of screening for adult obesity on long-term weight and health outcomes should be of high priority. We found little or no data on whether weight loss interventions (both behavioral and pharmacological) can lead to lasting weight loss and improvements in health outcomes. The benefits and harms of weight loss in the elderly are of particular interest given the potentially greater harms (e.g., decreased bone density and injuries from increased physical activity). There is also a need to examine patterns of how weight gain and loss across the lifetime might affect long-term health outcomes.

Future research should clarify the degree to which the benefits seen from weight loss are derived specifically from the weight loss itself or from the effects of behavioral factors, such as increased physical activity or changes in diet. We also believe that the next systematic review of the evidence on adult obesity should re-review the question of the best screening tool for adult obesity; BMI may not be the best screening tool in general, and particularly so in specific subgroups such as the elderly and some nonwhite populations. The cost effectiveness of behavioral and medication interventions also deserves more careful study.