# Results

We identified 58 trials of benefits of weight loss interventions, reported in 98 publications. Of these, 38 trials examined the benefits of behavioral-based interventions142-178 and 21 examined the benefits of medication (orlistat or metformin) for weight loss.142,179-203 One of the trials included both medication and behavioral-based intervention arms and was counted in both groups.142Table 1 lists all included trials assessing benefits of weight loss or weight maintenance interventions, grouped by the risk status of the population. We also identified an additional 12 studies (in 14 publications) on harms of weight loss interventions; four of these targeted behavioral weight loss methods and eight addressed harms of orlistat and/or metformin.

Table 1 Summary of Medication and Behavioral-Based Interventions

Medication Interventions | | | | | | Behavioral-based Interventions
Reference; Medication type; Quality rating | # Randomized | Average age (yrs) | % Female | % Nonwhite | Mean baseline BMI (kg/m^2^); Minimum BMI | Reference; # of sessions in 12 months; Quality rating | # Randomized | Average age (yrs) | % Female | % Nonwhite | Mean baseline BMI (kg/m^2^); Minimum BMI
With cardiovascular risk factors
Diabetes
Berne 2005^180^ Orlistat; Fair | 220 | 59.1 | 45.5 | 0 | 32.7 ≥ 28 | Christian 2008^146^ (US-PC) 4 sessions; Fair | 310 | 53.2 | 66.1 | 100 | 35.1 ≥25
Hanefeld 2002^187^ Orlistat; Fair | 383 | 56.2 | 50.9 | NR | 34.1 ≥28 | Mayer-Davis 2004^159^ (US-PC) (POWER) 30 sessions; Fair | 152 | 60.4 | 80.3 | 82.2 | 36.3 ≥25
Hollander 1998^191^ Orlistat; Fair | 322 | 55.1 | 48.9 | 12.5 | 34.3 ≥28
Miles 2002^197^ Orlistat; Fair | 516 | 53.1 | 48 | 18 | NR ≥28
Derosa 2010^215^ Orlistat; Good | 254 | 52.5 | 49.6 | NR | 32.8 ≥30
Hypertension
| | | | | | Burke 2005^145^ (ADAPT) 20 sessions; Fair | 241 | 56.2 | 55.6 | NR | 30.1 >25
| | | | | | Cohen 1991^147^ (US-PC) 12 sessions; Fair | 30 | 59.5 | NR | NR | 34.1 ≥27.8 (men) ≥27.3 (women)
| | | | | | Davis 1992^149^ (TAIM) 16 sessions; Fair | 200 | 47.7 | 50.0 | 34.0 | 194.2 lb (weight) NR
| | | | | | Jones 1999^154^ (HOT) 10 sessions; Fair | 111 | 58.0 | 52.0 | 40.2 | 34.0 ≥27
| | | | | | Kastarinen 2002^155^ (LIHEF) 5 sessions; Fair | 715 | 54.3 | 53.0 | NR | 28.7 NR
| | | | | | Langford 1985^157^ (DISH) 18 sessions; Fair | 176 | 56.7 | 65.9 | 65.9 | 87.9 kg (weight) NR
| | | | | | Whelton 1998^175^ (TONE) 26 sessions; Good | 585 | 66.0 | 52.6 | 28.2 | 86 kg (weight) NR
Dyslipidemia
Derosa 2003^183^ Orlistat; Fair | 50 | 52.0 | 52.0 | NR | 31.9 >30
Multiple risk factors
Broom 2002^181^ (UK Multimorbidity Study) Orlistat; Fair | 531 | 46.0 | 78.4 | NR | 37.0 ≥28 | Anderssen 1995^144^ (ODES) 159 sessions; Fair | 219 | 44.9 | 9.6 | NR | 28.4 >24
Lindgarde 2000^194^ (Swedish Multimorbidity Study); Orlistat; Fair | 376 | 53.5 | 63.6 | NR | 33.2 ≥28 | Svetkey 2008^170^ (WLM) 12 sessions; Good | 1032 | 55.6 | 63.4 | 37.6 | NR ≥25
Swinburn 2005^201^ Orlistat; Fair | 339 | 52.2 | 56.9 | NR | 37.8 ≥30 | ter Bogt 2009^171^ 5 sessions; Fair | 457 | 56.1 | 51.9 | NR | 29.6 ≥25
| | | | | | Woollard 2003^178^ 12 sessions; Fair | 212 | 60.2 | 50.7 | NR | 30.1 NR
Total trials (n) with cardiovascular risk factors
9 (2991) | | | | | | 13 (4440)
With subclinical increase in cardiovascular risk or risk factors
Prediabetes
Torgerson 2004^202^ (XENDOS); Orlistat; Fair | 3305 | 43.3 | 55.2 | NR | 37.4 ≥30 | DPP 2005^142^ 23 sessions; Good | 2161 | 50.6 | 67.7 | 45.3 | 34.1 ≥24 (≥22 in Asian Americans)
DPP 2005^142^ Metformin; Good | 2155 | 50.6 | 67.7 | 45.3 | 34.1 ≥24 (≥22 in Asian Americans) | Kulzer 2009^156^ (PREDIAS) 12 sessions; Fair | 182 | 56.3 | 43.0 | NR | 31.5 ≥26
| | | | | | Mensink 2003^160^ 4 sessions; Fair | 114 | 56.7 | 43.9 | 0 | 29.5 ≥25
| | | | | | Parikh 2010^204^ (Project HEED); 8 sessions; Fair | 99 | 48.0 | 85.0 | 98.0 | 31.5 ≥25
| | | | | | Tuomilehto 2001^172^ (FDPS) 7 sessions; Good | 522 | 55.0 | 67.0 | NR | 31.2 >25
Prehypertension
| | | | | | HPT 1990^143^ 16 sessions; Good | 251 | 38.8 | 32.7 | 19.9 | 28.5 NR
| | | | | | Stevens 1993^168^ (TOHP I) 23 sessions; Good | 564 | 43.0 | 29.9 | 17.8 | NR ≥115% of ideal weight
| | | | | | Stevens 2001^169^ (TOHP II) 32 sessions; Good | 1191 | 43.3 | 34.3 | 21.2 | NR 26.1 (men) 24.4 (women)
Multiple risk factors
Richelsen 2007^198^ Orlistat; Fair | 309 | 47.0 | 50.8 | NR | 37.5 ≥30
Total trials (n) with subclinical increase in cardiovascular risk or risk factors
3 (5769) | | | | | | 8 (5084)
Without increase in cardiovascular risk factors
Davidson 1999^182^ Orlistat; Fair | 892 | 43.5 | 84.2 | 19.2 | 36.3 ≥30 | Cussler 2008^148^ 2 sessions; Fair | 135 | 48.2 | 100 | NR | 30.3 ≥25
Finer 2000^184^ Orlistat; Fair | 228 | 41.5 | 88.5 | 5.1 | 36.8 ≥30 | Fitzgibbon 2010^200^ (ORBIT) 116 sessions; Fair | 213 | 46.0 | 100 | 100 | 39.3 ≥30
Hauptman 2000^189^ (US-PC); Orlistat; Fair | 635 | 42.5 | 78.3 | 9.1 | 36.1 ≥30 | Haapala 2009^151^ 0 sessions; Fair | 125 | 38.1 | 77.4 | NR | 30.5 ≥25
Hill 1999^190^ Orlistat; Fair | 729 | 46.3 | 84.0 | 11.7 | 32.8 ≥28 | Irwin 2003^152^ (PATH) 128 sessions; Good | 173 | 60.8 | 100 | 13.0 | 30.5 >25 (>24 if body fat >33%)
Krempf 2003^193^ Orlistat; Fair | 696 | 41.0 | 86.4 | NR | 36.1 ≥28 | Jeffery 1993^153^ (Trial of Food Provision and Monetary Incentives) 27 sessions; Fair | 202 | 37.5 | 50.0 | 7.9 | 31.1 NR
Rossner 2000^199^ Orlistat; Fair | 783 | 44.2 | 82.3 | NR | 35.0 ≥28 | Martin 2008^158^ (US-PC) 6 sessions; Fair | 137 | 41.8 | 100 | 100 | 39.1 ≥25
Sjostrom 1998^200^ Orlistat; Fair | 688 | 44.8 | 83.0 | NR | 36.0 ≥28 | Mitsui 2008^161^ 24 sessions, Fair | 46 | 63.3 | 54.3 | 100 | 25.2 NR
Fontbonne 1996^185^ (BIGPRO) Metformin; Fair | 457 | 49.5 | 66.7 | NR | 33.1 No min BMI (high WHR) | Moore 2003^162^ sessions NR; Fair | 843 | 48.6 | 73.9 | NR | 36.9 ≥30
Gambineri 2006^186^ Metformin; Fair | 40 | 27.0 | 100 | NR | 36.0 ≥28 | Narayan 1998^163^ 52 sessions; Fair | 95 | 33.5 | 75.8 | 100 | 34.9 ≥27 (men) ≥25 (women)
| | | | | | Perri 1988^164^ 26 sessions; Fair | 123 | NR | 78.9 | NR | NR NR
| | | | | | Pritchard 1999^165^ 8 sessions; Fair | 270 | NR | 72.5 | NR | 90.4 kg (weight) NR
Without increase in cardiovascular risk factors
| | | | | | Silva 2009^166^ 30 sessions; Fair | 239 | 37.6 | 100 | NR | 31.5 ≥25
| | | | | | Simkin-Silverman 2003^167^ (WHLP) 20 sessions; Good | 535 | 47.0 | 100 | NR | 25.0 ≥20
| | | | | | Villareal 2008^173^ 208 sessions; Fair | 27 | 70.0 | 66.7 | NR | NR ≥30
| | | | | | Werkman 2010^174^ 0 sessions; Good | 413 | 59.5 | 0 | NR | 27.0 NR
| | | | | | Wood 1988^176^ 23 sessions; Fair | 131 | 44.5 | 0 | NR | NR NR
| | | | | | Wood 1991^177^ 25 sessions; Fair | 264 | 39.7 | 48.5 | 11.3 | 30.7 ≥28 (men) ≥24 (women)
Total trials (n) with low cardiovascular risk or unselected samples
9 (5148) | | | | | | 17 (3971)
Total trials (n)
21 (13908) | | | | | | 38 (13495)

Abbreviations: ADAPT= Activity, Diet, and Blood Pressure Trial; BIGPRO=Biguanides and Prevention of Risks in Obesity; BMI=body mass index; DISH=Dietary Intervention to Study Hypertension; DPP=Diabetes Prevention Program; FDPS=Finnish Diabetes Prevention Study; HOT=Hypertension Optimal Treatment; HPT=Hypertension Prevention Trial; LIHEF=Lifestyle Intervention Against Hypertension in Eastern Finland; min=minimum; NR=not reported; ODES=Oslo Diet and Exercise Study; ORBIT=Obesity Reduction Black Intervention Trial; PATH=Physical Activity for Total Health; POWER=Pounds Off With Empowerment; HEED=Help Educate to Eliminate Diabetes; PREDIAS=Prevention of Diabetes Self-Management Program; TAIM=Trial of Antihypertensive Interventions and Management; TOHP=Trials of Hypertension Prevention; TONE=Trial of Nonpharmacologic Interventions in the Elderly; UK=United Kingdom; US-PC=participants recruited from primary care and/or intervention conducted in U.S. primary care; WHLP=Women's Healthy Lifestyle Project; WHR=waist-to-hip ratio; WLM=Weight Loss Maintenance; XENDOS=Xenical in the Prevention of Diabetes in Obese Subjects.

The participants in the behavioral interventions had mean BMI values that ranged from 25 to 39 kg/m^2^. Only three of the trials were limited to obese persons,162,173,204 and the remaining included overweight as well as obese persons, usually requiring a BMI of at least 25 kg/m^2^. Almost all of the medication trials required participants to have a BMI of at least 27 kg/m^2^. The mean BMI values in the medication trials were all in the obese range (32 to 38 kg/m^2^). For the purposes of this report, we use the term overweight and obese to refer to studies which had a minimum BMI criteria of 25 kg/m^2^, even if the mean BMI of the participants in these studies was in the obese range. For studies with a minimum BMI of 30 kg/m^2^, we refer to the subjects as obese.

## KQ 1 Is There Direct Evidence That Primary Care Screening Programs for Adult Obesity or Overweight Improve Health Outcomes or Result in Short-Term or Sustained Weight Loss or Improved Physiological Measures?

We identified no trials of adult obesity screening programs (i.e., randomizing participants to either be screened or not and then providing appropriate management for those screening positive for obesity).

## KQs 2–2b Do Primary Care–Relevant Interventions (Behavioral-Based Interventions and/or Pharmacotherapy) in Obese or Overweight Adults Lead to Improved Health Outcomes? What Are Common Elements of Efficacious Interventions? Are There Differences in Efficacy Between Patient Subgroups?

Health outcomes (see methods for a full list of outcomes eligible for systematic review) were minimally reported in the included trials, and almost all showed no effect on the health outcomes that were examined. The Diabetes Prevention Project (DPP) provided the most complete examination of health outcomes for behavioral treatment and metformin, covering cardiovascular disease events and deaths, deaths from any cause, hospitalizations, and depressive symptomatology.142,205-207 DPP was a large (n=3,234), good-quality randomized trial of persons with prediabetes (impaired fasting glucose [IFG] or impaired glucose tolerance [IGT]) with up to 3.2 years of followup. In addition to DPP, six behavioral-based trials (three fair-quality156,177,208 and three good-quality170,172,175) and eight fair-quality pharmacotherapy trials181,185,189,198,199,201,202,209 reported health outcomes.

### Death

DPP reported deaths, but there were too few deaths to be able to draw conclusions about the effect of the program in the approximately 3 years of followup.206 In the oldest age group (60 to 85 years), where deaths were most common, the death rates were 0.31 and 0.48 per 100 person-years in the lifestyle and metformin groups, respectively, compared with 0.86 per 100 person-years in the control group; neither active intervention group was statistically significantly different from the controls.210 All of the remaining behavioral,170 metformin,185 and orlistat181,189,202,209 trials that reported deaths had no more than one death in each treatment group.

### Cardiovascular Disease

DPP also reported that metformin and lifestyle participants showed no differences from control groups in nonfatal cardiovascular disease events or in cardiovascular disease-related deaths at 3 years postrandomization,207 and data were very similar in another large good-quality behavioral trial in persons with prediabetes.172 Another good-quality behavioral trial of weight loss in older adults with hypertension175 reported no differences in cardiovascular events (stroke, transient ischemic attack, myocardial infarction, angina, congestive heart failure, arrhythmia, and other) over 30 months of followup. The proportion with cardiovascular events was 14.3 percent in the weight loss group compared with 16.7 in the usual care group. Smaller trials also found no effect of behavioral treatment on use of medication for cardiovascular disease after 1 year,165 and no effect of metformin treatment on the development of ischemic cardiovascular disease.185

### Hospitalization

There were no differences in hospitalizations between the active treatment groups and control groups in DPP.206 Among adults ages 60 to 85 years, the rate of hospitalizations per 100 person-years was 12.3 in the lifestyle intervention group, 13.3 in the metformin group, and 10.6 in the control group.210

### Quality of Life and Depression

Of the few trials that examined depressive symptomatology or quality of life, almost none found positive effects of behavioral or medication treatment for weight loss. DPP,156 two additional behavioral trials,177,205 and two orlistat trials199,201 reported depression or quality of life outcomes using validated screening instruments, including one that was specifically designed for obese adults.199 None found group differences for depression, but DPP did report improvement in health-related quality of life (HRQL). The researchers characterized the HRQL effects as small and correlated with weight loss but not treatment assignment when weight loss was controlled for.211 One orlistat trial did find less overweight distress after 1 and 2 years in those taking orlistat.199 Another orlistat trial found greater improvement in the vitality subscale of the 36-item Short-form Health Survey (SF-36) in those taking orlistat compared with placebo (mean increase of 5.42 vs. decrease of 1.5 in placebo; p=0.006). However, there were no statistically significant differences on the seven other SF-36 subscales in this trial.201

### Common Elements of Efficacious Interventions

Too little data were provided to allow conclusions regarding components of efficacious interventions.

### Results in Different Subgroups

Only very minimal data were found to shed light on whether some subpopulations benefit more from treatment than others. DPP found no treatment-by-age interaction effects in hospitalizations or deaths for either treatment group, although it reported inadequate power to assess the significance of effects within the subgroups.206 Two behavioral trials that examined differential response to treatment on depression found no sex differences in response to treatment.177,205

## KQs 3–3c Do Primary Care–Relevant Interventions in Obese or Overweight Adults Lead to Short-Term or Sustained Weight Loss, With or Without Improved Physiological Measures? How Well is Weight Loss Maintained After an Intervention is Completed? What Are Common Elements of Efficacious Interventions? Are There Differences in Efficacy Between Patient Subgroups?

### Behavioral-Based Interventions

General characteristics of the trials. All 38 trials of behavioral-based interventions reported some measure of weight loss (n=13,495 randomized to behavioral-based or control treatment arms), although other intermediate outcomes were more sparsely reported.142-149,151-178,204,208 Three of these trials focused exclusively on maintenance of weight after weight loss had already been achieved.148,164,170 One trial did not report 12- to 18-month outcomes, but did report 36-month outcomes.143 The body of included behavioral treatment trials was a fairly high-quality, recent body of literature, overall. Twenty-six percent of the trials were rated as good quality,142,143,152,167-170,172,174,175 and 34 percent were published in 2008 or later. Among those rated as fair quality, randomization procedures (including generation of a random numbers table and blinding of allocation) were frequently not reported. In addition, a substantial number failed to report blinding of outcomes assessment. It was possible for a trial without evidence of outcomes blinding to be rated as good if assessment of anthropometric measures appeared to be highly standardized and involved training and/or quality assurance measures, although this was uncommon. Another common threat to internal validity in trials rated as fair was followup of less than 90 percent. Only approximately one fifth of the fair-quality trials had followup of 90 percent or more.144,147,156,161,163,171 Average followup for the entire group of trials, weighted by study sample size, was 88.2 percent.

Almost two thirds of the trials were conducted in the United States,142,143,146-149,152-154,157-159,163,164,167-170,173,175-177,204,208 but only four of the trials were conducted in primary care settings.146,147,158,159,204,208 Five more trials were conducted in primary care settings in other countries, primarily Europe155,162,171 and Australia.165,178 Just over one third of the trials identified potentially eligible patients prior to recruitment and used individual outreach and screening for study recruitment (referred to as “study-identified” in this review).144,146,147,157-160,162,163,165,171,172,174,178 The remaining trials either failed to report how they recruited patients (13 percent)154-156,168,208 or used broadbased media approaches that required potential participants to contact study staff in order to be screened for study eligibility (referred to as “self-identified” in this review).142,143,143,145,148,149,151-153,161,164,166,167,169,170,173,175-177,204

Thirteen of the trials were limited to overweight and obese persons with diabetes, hypertension, or dyslipidemia.144-147,149,154,155,157,159,170,171,175,178 Nine additional trials included only overweight and obese persons who had prediabetes,142,156,160,172,208 prehypertension,143,168,169 or increased waist circumference.161 One trial was limited to overweight or obese patients ages 60 years or older who also had some evidence of functional limitation or poor physical fitness.173 The remaining trials (n=15 [39 percent]) either had no limitations related to cardiovascular risk factors or accepted only those without cardiovascular risk factors.148,151-153,158,162-167,174,176,177,204

On average, the participants in the behavioral treatment trials were not extremely obese. The weighted average baseline BMI for participants across all trials was 31.9 kg/m^2^. Two trials, however, did have substantially higher average BMI values: one in black women in Chicago204 and one in frail obese older adults.173 All but two trials included both overweight and obese participants.162,173 Ethnicity was only reported in 18 of the 24 U.S.-based trials.142,143,146,149,152-154,157-159,163,168-170,175,177,204,208 Eight trials included more than 25 percent black participants,149,154,157-159,170,175,204 one reported 45 percent of participants were nonwhite,142 and there were additionally trials comprised of exclusively or predominantly Hispanic/Latino146,208 and exclusively Pima Indian participants.163 Overall, the weighted average percent of nonwhite participants was 41.5 percent among the trials reporting ethnicity.

Six trials included only women148,152,158,166,167,204 and two included only men.174,176 The overall weighted average percent of female participants in all trials was 59.3 percent. Age ranges varied substantially across the trials. Two were limited to younger adults (ages 25 to 44 or 45 years)151,153 and two to older adults.173,175 Five trials focused on middle-aged adults (ages 30–44 to 50–55 years).144,148,167-169 The remaining trials covered a broader range of ages. The overall weighted average age of the entire group was 51.4 years (range, 38 to 70 years).

Weight loss. Participants in behavioral-based interventions generally lost more weight than those in control groups. A meta-analysis combining the 21 weight loss trials reporting kilograms or pounds lost at 12 to 18 months estimated an average effect of 3.0 kg more lost in the intervention than control groups (95% CI, -4.0 to -2.0; I^2^ =94.9%; k=21; n=7,343) (Figure 2). Differences in the amount of weight change were highly variable, ranging from 1.7 kg greater weight gain163 to 8.3 kg greater weight loss177 in the intervention groups compared with placebo for all trials that reported these data (including those not included in the meta-analysis). The vast majority of weight loss trials did show a statistically significant effect on weight loss at 12 to 18 months (2 to 7 kg), including 16 of the 21 trials included in the meta-analysis and 10 of the 13 trials not included (Table 2). Three additional trials examining weight maintenance interventions148,164,170 and one that reported only long-term outcomes143 are discussed in the section titled “Weight maintenance and longer-term results.”

Figure 2 Difference Between Intervention and Control Groups in Weight Change (kg) at 12 to 18 Months

Abbreviations: ADAPT=Activity, Diet, and Blood Pressure Trial; CI=confidence interval CV=cardiovascular; DISH=Dietary Intervention to Study Hypertension; DPP=Diabetes Prevention Program; FDPS=Finnish Diabetes Prevention Study; HEED=Help Educate to Eliminate Diabetes; HI=intensive intervention; IV=intervention; LO=brief intervention; N=number; NR=not reported; ORBIT=Obesity Reduction Black Intervention Trial; PATH=Physical Activity for Total Health; PREDIAS=Prevention of Diabetes Self-Management Program; SD=standard deviation; Subclincl=subclinical; TOHP=Trials of Hypertension Prevention; WHLP=Women's Healthy Lifestyle Project; Unsel=unselected; WMD=weighted mean difference.

Figure 2 displays a forest plot of studies reporting the weighted mean difference in weight between intervention and control groups. Data from Figure 2 are presented in Appendix C, Tables 1 and 2. This figure is described further in the section “Results: Key Question 3: Behaviorally-based Interventions: Weight Loss” as follows: “A meta-analysis combining the 21 weight-loss trials reporting kilograms or pounds lost at 12 to 18 months estimated an average effect of 3.0 more kg lost in the intervention than control groups (95% CI -4.0, -2.0, I2=94.9%, k=21, n=7,343; Figure 2).” This figure is also described in the section “Results: Key Question 3: Pharmacotherapy: Orlistat: Weight Loss” as follows: “Overweight and obese participants randomized to orlistat lost an average of 3 kg more weight than those randomized to placebo after 12 months (WMD=-3.0 95% CI -3.9, -2.0, I2=84.9%, k=12; Figure 2).”

Table 2 Trials Not Included in Meta-Analysis: Weight Loss in Behavioral Trials, 12- to 18-Month Outcomes

Study | Population risk status (risk group) | # Sessions in first 12 months | N | Weight (kg) or BMI change (kg/m^2^)
Anderssen 1995^144^ | Multiple risk factors | 159 | IG: 67 CG: 43 | Mean (SD) change in BMI at 12 mo
Anderssen 1995^144^ | Multiple risk factors | 159 | IG: 67 CG: 43 | | 12 mo
Anderssen 1995^144^ | Multiple risk factors | 159 | IG: 67 CG: 43
Anderssen 1995^144^ | Multiple risk factors | 159 | IG: 67 CG: 43 | IG | -1.8 (1.4)
Anderssen 1995^144^ | Multiple risk factors | 159 | IG: 67 CG: 43 | CG | 0.3 (0.8)
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | Mean (SD) at baseline, mean change
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | | BL | 12 mo
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | IG | 81.1 (15.7) | -1.5
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | CG | 80.0 (14.8) | -0.2
Mayer-Davis 2004^159^ (POWER) | Diabetes | 22 | Total: 187 | Mean (SD) at baseline, mean change at 12 mo
Mayer-Davis 2004^159^ (POWER) | Diabetes | 22 | Total: 187 | | BL | 12 mo
Mayer-Davis 2004^159^ (POWER) | Diabetes | 22 | Total: 187
Mayer-Davis 2004^159^ (POWER) | Diabetes | 22 | Total: 187 | IG | 99.5 (17.1) | 2.2
Mayer-Davis 2004^159^ (POWER) | Diabetes | 22 | Total: 187 | CG | 93.0 (20.3) | -0.3
Davis 1992^149^ | Hypertension | 16 | IG: 100 CG: 100 | Figures show difference between weight loss and usual care groups through 2-2.5 years (p<0.05)
Jones 1999^154^ (HOT) | Hypertension | 10 | IG: 55 CG: 56 | Mean (SD) at baseline, mean change at 12 mo
Jones 1999^154^ (HOT) | Hypertension | 10 | IG: 55 CG: 56 | | BL | 12 mo (estimated from figures)
Jones 1999^154^ (HOT) | Hypertension | 10 | IG: 55 CG: 56
Jones 1999^154^ (HOT) | Hypertension | 10 | IG: 55 CG: 56 | IG | 97 (18) | -0.7
Jones 1999^154^ (HOT) | Hypertension | 10 | IG: 55 CG: 56 | CG | 92 (18) | -0.5
Whelton 1998^175^ (TONE) | Hypertension | 26 | IG: 147 CG: 147 | Mean at baseline, mean change at 12 +18 mo
Whelton 1998^175^ (TONE) | Hypertension | 26 | IG: 147 CG: 147 | | BL | 12 mo | 18 mo
Whelton 1998^175^ (TONE) | Hypertension | 26 | IG: 147 CG: 147
Whelton 1998^175^ (TONE) | Hypertension | 26 | IG: 147 CG: 147 | IG | 86.5 | -4.7 | -4.4
Whelton 1998^175^ (TONE) | Hypertension | 26 | IG: 147 CG: 147 | CG | 87 | -1.1 | -0.8
Jeffery 1993^153^ | Unselected/low risk | 27 | IG: 41 CG: 40 | Mean BMI at 12+ 18 mo
Jeffery 1993^153^ | Unselected/low risk | 27 | IG: 41 CG: 40 | | BL | 12 mo | 18 mo
Jeffery 1993^153^ | Unselected/low risk | 27 | IG: 41 CG: 40
Jeffery 1993^153^ | Unselected/low risk | 27 | IG: 41 CG: 40 | IG | 31.3 | 28.3 | 29.0
Jeffery 1993^153^ | Unselected/low risk | 27 | IG: 41 CG: 40 | CG | 30.9 | 30.4 | 30.7
Mitsui 2008^161^ | Unselected/low risk | 24 | IG: 24 CG: 22 | Mean (SD) BMI at 12 mo
Mitsui 2008^161^ | Unselected/low risk | 24 | IG: 24 CG: 22 | | BL | 12 mo
Mitsui 2008^161^ | Unselected/low risk | 24 | IG: 24 CG: 22
Mitsui 2008^161^ | Unselected/low risk | 24 | IG: 24 CG: 22 | IG | 24.8 (2.2) | 23.7 (2.4)
Mitsui 2008^161^ | Unselected/low risk | 24 | IG: 24 CG: 22 | CG | 25.6 (2.5) | 25.6 (2.6)
Moore 2003^162^ | Unselected/low risk | 12-24 (estimated) | IG: 415 CG: 428 | Mean (SD)
Moore 2003^162^ | Unselected/low risk | 12-24 (estimated) | IG: 415 CG: 428 | | BL | 12 mo | 18 mo
Moore 2003^162^ | Unselected/low risk | 12-24 (estimated) | IG: 415 CG: 428
Moore 2003^162^ | Unselected/low risk | 12-24 (estimated) | IG: 415 CG: 428 | IG | 100.8 (18.1) | 100.3 (--) | 100.8 (--)
Moore 2003^162^ | Unselected/low risk | 12-24 (estimated) | IG: 415 CG: 428 | CG | 100.2(17.4) | 99.3(--) | 99.5(--)
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | Median (range) at baseline, median change at 12 mo
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | | BL | 12 mo
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | IG | 96.4 (59.4-159.1) | 2.5
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | CG | 89.3 (59.2-184.8) | 0.8
Pritchard 1999^165^ | Unselected/low risk | 8 | IG: 92 CG: 90 | Mean at baseline, mean change at 12 mo
Pritchard 1999^165^ | Unselected/low risk | 8 | IG: 92 CG: 90 | | BL | 12 mo
Pritchard 1999^165^ | Unselected/low risk | 8 | IG: 92 CG: 90
Pritchard 1999^165^ | Unselected/low risk | 8 | IG: 92 CG: 90 | IG1 | 85.5 | -5.1
Pritchard 1999^165^ | Unselected/low risk | 8 | IG: 92 CG: 90 | IG2 | 91.7 | -6.2
Pritchard 1999^165^ | Unselected/low risk | 8 | IG: 92 CG: 90 | CG | 89.1 | 0.6
Silva 2009^166^ | Unselected/low risk | 30 | IG: 123 CG: 116 | Mean (SD) BMI at baseline, mean change at 12 mo
Silva 2009^166^ | Unselected/low risk | 30 | IG: 123 CG: 116 | | BL | 12 mo
Silva 2009^166^ | Unselected/low risk | 30 | IG: 123 CG: 116
Silva 2009^166^ | Unselected/low risk | 30 | IG: 123 CG: 116 | IG | 31.7 (4.24) | -2.3 (1.9)
Silva 2009^166^ | Unselected/low risk | 30 | IG: 123 CG: 116 | CG | 31.3 (4.00) | 0.7 (1.9)
Villareal 2008^173^ | Unselected/low risk | 208 | IG: 17 CG: 10 | Mean (SD) at baseline, %change(SD) in body weight at 12 mo
Villareal 2008^173^ | Unselected/low risk | 208 | IG: 17 CG: 10 | | BL | 12 mo
Villareal 2008^173^ | Unselected/low risk | 208 | IG: 17 CG: 10
Villareal 2008^173^ | Unselected/low risk | 208 | IG: 17 CG: 10 | IG | 99.7(13.6) | -10.1 (2.0)
Villareal 2008^173^ | Unselected/low risk | 208 | IG: 17 CG: 10 | CG | 103.2 (19.8) | 1.2 (1.3)

Bold=statistically significant difference between intervention and control groups.

Abbreviations: BL=baseline; BMI=body mass index; CG=control group; HOT=Hypertension Optimal Treatment; IG=intervention group; LIHEF=Lifestyle Intervention Against Hypertension in Eastern Finland; Mo=month; POWER=Pounds Off With Empowerment; SD=standard deviation; TONE=Trial of Nonpharmacologic Interventions in the Elderly.

In addition to reporting amount of weight loss, six trials also reported the proportion of participants losing at least 5 percent of their baseline weight (Figure 3).146,158,166,172,204,208 Intervention groups had an almost 2.5 times greater probability of losing 5 percent of their initial weight compared with control groups (relative risk [RR], 2.39 [95% CI, 1.72 to 3.31]; n=1,387). Absolute risk reduction was 19 percentage points, which translates into a NNT benefit of 5 (risk difference [RD], 0.19 [95% CI, 0.06 to 0.32]). Only one trial reported the proportion who lost 10 percent or more of their baseline weight, and found an almost fivefold increase in the intervention group compared with the control group (Figure 4).166 Taking all trials into account, participants in behavioral-based interventions lost an average of 4 percent of their baseline weight, based on average baseline and followup weights.

Figure 3 Relative Risk of Participants Losing at Least 5% of Baseline Weight in Intervention Group Compared With Control Group

Abbreviations: CI=confidence interval; CV=cardiovascular; FDPS=Finnish Diabetes Prevention Study; HEED=Help Educate to Eliminate Diabetes; HI=intensive intervention; IV=intervention; LO=brief intervention; N=number; NR=not reported; ORBIT= ORBIT=Obesity Reduction Black Intervention Trial; RR=relative risk; SD=standard deviation; Subclincl=subclinical; Unsel=unselected.

Figure 3 displays a forest plot of studies reporting the relative risk of participants losing at least 5 percent of baseline weight in the intervention group compared with the control group. Data from Figure 3 are presented in Appendix C, Tables 1 and 2. This figure is described further in the section “Results: Key Question 3: Behaviorally-based Interventions: Weight Loss” as follows: “In addition to reporting amount of weight loss, six trials also reported the proportion of participants losing at least 5 percent of their baseline weight (Figure 3).” This figure is also described in the section “Results: Key Question 3: Pharmacotherapy: Orlistat: Weight Loss” as follows: “Overweight and obese participants randomized to orlistat had a 1.6-fold greater chance of losing 5 percent of their initial weight than those randomized to placebo (RR=1.57, 95% CI 1.40, 1.75, I2= 76.2%; k=13, n=8,579; Figure 3).”

Figure 4 Relative Risk of Participants Losing at Least 10% of Baseline Weight in Intervention Group Compared With Control Group

Abbreviations: CI=confidence interval; CV=cardiovascular; HI=intensive intervention; IV=intervention; LO=brief intervention; N=number; NR=not reported; RR=relative risk; SD=standard deviation; Subclincl=subclinical; Unsel=unselected.

Figure 4 displays a forest plot of studies reporting the relative risk of participants losing at least 10 percent of baseline weight in the intervention group compared with the control group. Data from Figure 4 are presented in Appendix C, Tables 1 and 2. This figure is described further in the section “Results: Key Question 3: Behaviorally-based Interventions: Weight Loss” as follows: “Only one trial reported the proportion losing 10 percent or more of their baseline weight and found an almost 5-fold increase in the intervention group compared with the control group (Figure 4).” This figure is also described in the section “Results: Key Question 3: Pharmacotherapy: Orlistat: Weight Loss” as follows: “The probability of losing 10 percent of one’s initial weight was about two times greater in orlistat, compared to placebo treated overweight and obese patients (RR=1.99, 95% CI 1.69, 2.35, I2=49.2%, k=11, n=7,500; Figure 4).”

Interventions with more sessions generally showed greater amounts of weight loss. Meta-regression indicates that number of sessions was a predictor of variability in effect size (coefficient, -0.01; p<0.02), after controlling for the risk status of the population. The effect remained statistically significant even after including each of the following factors: study quality, specific outcome reported (weight vs. BMI/other), year of publication, followup rate, method of participant identification (self vs. study identified), presence of physical activity sessions, use of group sessions, type of control group used, role of primary care, US vs. nonUS setting, and baseline BMI. Trials with interventions that involved 12 to 26 sessions generally reported 4 to 7 kg of total weight loss (weighted average, 5.3 kg [6 percent of baseline weight]) in intervention group participants. Weight loss in less intensive interventions was more on the order of 1.5 to 4 kg (weighted average, 2.3 kg [2.8 percent of baseline weight]) compared with less than 1 percent average weight loss in the control groups.

One trial, although being coded as low intensity because it had no face-to-face or phone contact sessions, had an average of 269 text messages or Web site contacts with participants over 1 year. The intervention group lost 3 kg more compared with the control group. 151

A meta-analysis limited to primary care-based trials showed a statistically significant but smaller effect size than seen in all trials (weighted mean difference [WMD], -1.1 kg [95% CI, -1.7 to -0.6]; I^2^=0.0; k=5; n=957) (figure not shown).146,147,158,171,178 Examined individually, only one of the five trials showed a benefit of treatment.171 Three of four additional primary care-based trials (one U.S.-based159 and three nonU.S.-based155,162,165) that were not included in the meta-analysis showed a benefit of treatment. Of the four U.S.-based trials, three focused on training primary care clinicians to deliver weight loss interventions,146,147,158 and two146,158 of these offered training in motivational techniques. The fourth trial had two treatment arms, one of which was designed for implementation in primary care and involved one individual and three 1-hour group visits with a study interventionist.159

Six trials either screened consecutive patients in primary care practice158,162,165 or identified potentially eligible participants through medical records or disease registries.146,159,178 Only two of these reported greater weight loss in intervention participants,159,165 although all but one159 involved interventions with fewer than 10 sessions.

Weight maintenance and longer-term results. Data from 12 trials (36 percent) demonstrated that weight loss can be maintained in the longer term (Table 3).142,143,149,153,155,160,166,167,169,172,174,175 Six of these trials reported outcomes immediately after a long-running (24 to 54 months) intervention was completed and all found greater weight loss at the end of the trials, with participants generally showing 2 to 4 kg greater weight loss than controls.143,160,167,169,172,175

Table 3 Long-Term Weight Loss and Blood Pressure Outcomes in Behavioral-Based Interventions Beyond 18 Months

Study | Time to followup/ since intervention ended (mo) | Population risk status (risk group) | # Sessions in first 12 months | N | Weight (kg) or BMI (kg/m^2^) change | | | | | Average greater reduction in SBP/DBP in intervention vs. control (mmHg)
Long-term interventions
Mensink 2003^160^ | 24/0 | Prediabetes | 4 | IG: 55 CG: 59 | Mean (SE) at baseline, mean change (SE) at 24 mo | | | | | NR
Mensink 2003^160^ | 24/0 | Prediabetes | 4 | IG: 55 CG: 59 | | BL | 24 mo | | | NR
Mensink 2003^160^ | 24/0 | Prediabetes | 4 | IG: 55 CG: 59 | | | | | | NR
Mensink 2003^160^ | 24/0 | Prediabetes | 4 | IG: 55 CG: 59 | IG | 86 (1.9) | -2.4 (0.7) | | | NR
Mensink 2003^160^ | 24/0 | Prediabetes | 4 | IG: 55 CG: 59 | CG | 83.7 (1.5) | -0.1 (0.5) | | | NR
Tuomilento 2001^172^ (FDPS) | 24/0 | Prediabetes | 7 | IG: 265 CG: 257 | Mean (SD) at baseline, mean change (SD) at 24 mo | | | | | 5 vs. 2
Tuomilento 2001^172^ (FDPS) | 24/0 | Prediabetes | 7 | IG: 265 CG: 257 | | BL | 24 mo | | | 5 vs. 2
Tuomilento 2001^172^ (FDPS) | 24/0 | Prediabetes | 7 | IG: 265 CG: 257 | | | | | | 5 vs. 2
Tuomilento 2001^172^ (FDPS) | 24/0 | Prediabetes | 7 | IG: 265 CG: 257 | IG | -- | -3.5 (5.5) | | | 5 vs. 2
Tuomilento 2001^172^ (FDPS) | 24/0 | Prediabetes | 7 | IG: 265 CG: 257 | CG | -- | -0.8 (4.4) | | | 5 vs. 2
HPT 1990^143^ | 36/0 | Prehypertension | 16 | IG: 125 CG: 126 | Mean at baseline,mean change (SE) at 36 mo | | | | | 2.4 vs. 1.8
HPT 1990^143^ | 36/0 | Prehypertension | 16 | IG: 125 CG: 126 | | BL | 36 mo | | | 2.4 vs. 1.8
HPT 1990^143^ | 36/0 | Prehypertension | 16 | IG: 125 CG: 126 | | | | | | 2.4 vs. 1.8
HPT 1990^143^ | 36/0 | Prehypertension | 16 | IG: 125 CG: 126 | IG | 87.4 | -1.63 (0.41) | | | 2.4 vs. 1.8
HPT 1990^143^ | 36/0 | Prehypertension | 16 | IG: 125 CG: 126 | CG | 83.4 | 1.86 (0.41) | | | 2.4 vs. 1.8
Simkin-Silverman 2003^167^ (WHLP) | 30, 42, 54/0, 0, 0 | Unselected/low risk | 20 | IG: 260 CG: 275 | Mean (SD) at baseline, mean change (SD) at 30, 42, 54 mo | | | | | 2.2 vs. 0.6
Simkin-Silverman 2003^167^ (WHLP) | 30, 42, 54/0, 0, 0 | Unselected/low risk | 20 | IG: 260 CG: 275 | | BL | 30 mo | 42 mo | 54 mo | 2.2 vs. 0.6
Simkin-Silverman 2003^167^ (WHLP) | 30, 42, 54/0, 0, 0 | Unselected/low risk | 20 | IG: 260 CG: 275 | | | | | | 2.2 vs. 0.6
Simkin-Silverman 2003^167^ (WHLP) | 30, 42, 54/0, 0, 0 | Unselected/low risk | 20 | IG: 260 CG: 275 | IG | 24.9 (3.2) | -0.67 (1.8) | -0.34 (1.9) | 0.05 (2.0) | 2.2 vs. 0.6
Simkin-Silverman 2003^167^ (WHLP) | 30, 42, 54/0, 0, 0 | Unselected/low risk | 20 | IG: 260 CG: 275 | CG | 25.1 (3.3) | 0.44 (1.6) | 0.67 (1.7) | 0.96 (1.8) | 2.2 vs. 0.6
Whelton 1998^175^ (TONE) | 30/0 | Hypertension | 26 | IG: 147 CG: 147 | Mean at baseline, mean change at 18, 30 mo | | | | | HR=0.70 for being free of hypertension, its medications, or cardiovascular events
Whelton 1998^175^ (TONE) | 30/0 | Hypertension | 26 | IG: 147 CG: 147 | | BL | 30 mo | | | HR=0.70 for being free of hypertension, its medications, or cardiovascular events
Whelton 1998^175^ (TONE) | 30/0 | Hypertension | 26 | IG: 147 CG: 147 | | | | | | HR=0.70 for being free of hypertension, its medications, or cardiovascular events
Whelton 1998^175^ (TONE) | 30/0 | Hypertension | 26 | IG: 147 CG: 147 | IG | -- | -4.7 | | | HR=0.70 for being free of hypertension, its medications, or cardiovascular events
Whelton 1998^175^ (TONE) | 30/0 | Hypertension | 26 | IG: 147 CG: 147 | CG | -- | -0.9 | | | HR=0.70 for being free of hypertension, its medications, or cardiovascular events
Stevens 2001^169^ (TOHP II) | 36/0 | Prehypertension | 32 | IG: 595 CG: 596 | Mean (SD) at baseline, mean change (95% CI) at 18 mo | | | | | 0.2 vs. 0.8
Stevens 2001^169^ (TOHP II) | 36/0 | Prehypertension | 32 | IG: 595 CG: 596 | | BL | | 36 mo | | 0.2 vs. 0.8
Stevens 2001^169^ (TOHP II) | 36/0 | Prehypertension | 32 | IG: 595 CG: 596 | | | | | | 0.2 vs. 0.8
Stevens 2001^169^ (TOHP II) | 36/0 | Prehypertension | 32 | IG: 595 CG: 596 | IG | 93.4 (14.1) | -0.2 (-0.7 to 0.3) | | | 0.2 vs. 0.8
Stevens 2001^169^ (TOHP II) | 36/0 | Prehypertension | 32 | IG: 595 CG: 596 | CG | 93.6 (13.5) | 1.8 (1.3 to 2.2) | | | 0.2 vs. 0.8
Time lag since intervention completed
Davis 1992^149^ (TAIM) | 30/18 (duration=18) | Hypertension | 10 | IG: 100 CG: 100 | NR (figure shows differences through 30 mo) | | | | | NR (figure shows differences from 12-30 mo)
DPP 2005^212^ | 34/4 (duration=30) | Prediabetes | 23 | IG: 1079 CG: 1082 | Mean (SD) at baseline, mean change at 34 mo | | | | | 2.7 vs. 1.9
DPP 2005^212^ | 34/4 (duration=30) | Prediabetes | 23 | IG: 1079 CG: 1082 | | BL | 34 mo | | | 2.7 vs. 1.9
DPP 2005^212^ | 34/4 (duration=30) | Prediabetes | 23 | IG: 1079 CG: 1082 | | | | | | 2.7 vs. 1.9
DPP 2005^212^ | 34/4 (duration=30) | Prediabetes | 23 | IG: 1079 CG: 1082 | IG | 94.1 (20.8) | -5.6 | | | 2.7 vs. 1.9
DPP 2005^212^ | 34/4 (duration=30) | Prediabetes | 23 | IG: 1079 CG: 1082 | CG | 94.3 (20.2) | -0.1 | | | 2.7 vs. 1.9
Jeffery 1993^153^ | 30/12 (duration=18) | Unselected/low risk | 27 | IG: 41 CG: 40 | Mean at baseline, mean change (SD) at 30 mo | | | | | NR
Jeffery 1993^153^ | 30/12 (duration=18) | Unselected/low risk | 27 | IG: 41 CG: 40 | | BL | 30 mo | | | NR
Jeffery 1993^153^ | 30/12 (duration=18) | Unselected/low risk | 27 | IG: 41 CG: 40 | | | | | | NR
Jeffery 1993^153^ | 30/12 (duration=18) | Unselected/low risk | 27 | IG: 41 CG: 40 | IG4^*^ | 91.1 | -1.6 (6.3) | | | NR
Jeffery 1993^153^ | 30/12 (duration=18) | Unselected/low risk | 27 | IG: 41 CG: 40 | CG | 88.2 | 0.6 (5.3) | | | NR
Kastarinen 2002^155^ (LIHEF) | 24/6 (duration=18) | Hypertension | 5 | IG: 360 CG: 355 | Mean (SD) at baseline, mean change at 24 mo | | | | | 2 vs. 0.9
Kastarinen 2002^155^ (LIHEF) | 24/6 (duration=18) | Hypertension | 5 | IG: 360 CG: 355 | | BL | 24 mo | | | 2 vs. 0.9
Kastarinen 2002^155^ (LIHEF) | 24/6 (duration=18) | Hypertension | 5 | IG: 360 CG: 355 | | | | | | 2 vs. 0.9
Kastarinen 2002^155^ (LIHEF) | 24/6 (duration=18) | Hypertension | 5 | IG: 360 CG: 355 | IG | 81.1 (15.7) | -1.5 | | | 2 vs. 0.9
Kastarinen 2002^155^ (LIHEF) | 24/6 (duration=18) | Hypertension | 5 | IG: 360 CG: 355 | CG | 80.0 (14.8) | -0.3 | | | 2 vs. 0.9
Silva 2009^166^ | 24/12 (duration=12) | Unselected/low risk | 30 | IG: 123 CG: 116 | NR (% weight lost and % losing 5% and 10% >in IG vs. CG; p<0.05) | | | | | NR
Werkman 2010^174^ | 24/12 (duration=12) | Unselected/low risk | 0 (online only) | IG: 174 CG: 178 | Mean (SD) at baseline, mean change (SD) at 24 mo | | | | | 0.4 increase vs. 0.4 decrease
Werkman 2010^174^ | 24/12 (duration=12) | Unselected/low risk | 0 (online only) | IG: 174 CG: 178 | | BL | 24 mo | | | 0.4 increase vs. 0.4 decrease
Werkman 2010^174^ | 24/12 (duration=12) | Unselected/low risk | 0 (online only) | IG: 174 CG: 178 | | | | | | 0.4 increase vs. 0.4 decrease
Werkman 2010^174^ | 24/12 (duration=12) | Unselected/low risk | 0 (online only) | IG: 174 CG: 178 | IG | 85.1 (11.9) | -0.37 (1.12) | | | 0.4 increase vs. 0.4 decrease
Werkman 2010^174^ | 24/12 (duration=12) | Unselected/low risk | 0 (online only) | IG: 174 CG: 178 | CG | 86.1 (11.4) | -0.40 (1.29) | | | 0.4 increase vs. 0.4 decrease

* Other intervention groups showed similar results.

Bold=statistically significant difference between intervention and control groups.

Abbreviations: BL=baseline; BMI=body mass index; CG=control group; CI=confidence interval; DBP=diastolic blood pressure; DPP=Diabetes Prevention Program; FDPS Finnish Diabetes Prevention Study; HPT=Hypertension Prevention Trial; HR=hazard ratio; IG=intervention group; LIHEF=Lifestyle Intervention Against Hypertension in Eastern Finland; Mo=month; NR=not reported; SBP=systolic blood pressure; SD=standard deviation; SE=standard error; TAIM=Trial of Antihypertensive Interventions and Management; TOHP=Trials of Hypertension Prevention; TONE=Trial of Nonpharmacologic Interventions in the Elderly; WHLP=Women's Healthy Lifestyle Project.

The other six trials reported long-term outcomes 4 to 18 months after an intervention had ended.142,149,153,155,166,174 Weight loss was greater in the intervention group in four of these six trials.142,149,155,166 The trials showing a treatment benefit varied in intensity from five to 30 intervention contacts. Of the two that showed no benefit, one had an online-only intervention174 and the other was a high-intensity (27 contacts over 12 months) behavioral program in which some treatment arms received meal provisions and/or cash incentives.153

Three trials targeted maintenance after weight loss in seven different active treatment arms (Table 4).148,164,170 The intervention arms with 26 or more sessions over 18 to 24 months had better weight maintenance.164,170 These intensive intervention groups generally had weight regain of 2 to 4 kg compared with 5 to 7 kg in the control groups over the 1- to 2-year maintenance sessions. In lower-intensity interventions (two added maintenance sessions or Web only), there were no group differences.148,170

Table 4 Weight Change in Behavioral-Based Weight Maintenance Interventions

Reference | Time since baseline | Time since weight loss intervention ended | Time since maintenance intervention ended | # of maintenance sessions | Baseline weight and weight change (kg)
Cussler 2008^148^ | 16 mo | 12 mo | 0 mo | 2 | Mean (SD) at baseline, mean change (SD) at 16 mo (12 mo since end of weight loss phase)
Cussler 2008^148^ | 16 mo | 12 mo | 0 mo | 2 | | BL | | 16 mo
Cussler 2008^148^ | 16 mo | 12 mo | 0 mo | 2
Cussler 2008^148^ | 16 mo | 12 mo | 0 mo | 2 | IG | 84.4 (12.6) | | 0.7 (5.4)
Cussler 2008^148^ | 16 mo | 12 mo | 0 mo | 2 | CG | 82.0 (10.8) | | 1.0 (4.6)
Perri 1988^164^ | 24 mo | 18 mo | 6 mo | 26 | Mean at baseline, mean change (SD) at 6, 12, 18,and 24 mo
Perri 1988^164^ | 24 mo | 18 mo | 6 mo | 26 | | BL | 6 mo^*^ | 12 mo | 18 mo | 24 mo
Perri 1988^164^ | 24 mo | 18 mo | 6 mo | 26
Perri 1988^164^ | 24 mo | 18 mo | 6 mo | 26 | IG1 | 97.4 | -13.2 (5.4) | -15.8 (11.8) | -12.9 (12.4) | -11.4 (12.1)
Perri 1988^164^ | 24 mo | 18 mo | 6 mo | 26 | IG2 | 96.9 | -11.3 (3.1) | -13.5 (6.2) | -13.4 (7.4) | -8.4 (7.5)
Perri 1988^164^ | 24 mo | 18 mo | 6 mo | 26 | IG3 | 95.2 | -13.1 (4.8) | -15.2 (6.2) | -13.0 (7.6) | -9.1 (6.4)
Perri 1988^164^ | 24 mo | 18 mo | 6 mo | 26 | IG4 | 97.4 | -13.7 (5.9) | -17.8 (11.7) | -15.7 (14.3) | -13.5 (15.2)
Perri 1988^164^ | 24 mo | 18 mo | 6 mo | 26 | CG | 89.0 | -10.8 (7.6) | -8.9 (8.8) | -5.7 (6.9) | -3.6 (6.2)
Svetkey 2008^170^ (WLM)^†^ | 30 mo | 24 mo | 0 mo | IG1: 0^**^ IG2: 30 | Mean (SD) at baseline and 6 mo, mean change (SE) at 30 mo
Svetkey 2008^170^ (WLM)^†^ | 30 mo | 24 mo | 0 mo | IG1: 0^**^ IG2: 30 | | BL | 6 mo^*^ | | 30 mo
Svetkey 2008^170^ (WLM)^†^ | 30 mo | 24 mo | 0 mo | IG1: 0^**^ IG2: 30
Svetkey 2008^170^ (WLM)^†^ | 30 mo | 24 mo | 0 mo | IG1: 0^**^ IG2: 30 | IG1 | 97.2 (16.2) | 88.6 (15.4) | | -3.3 (0.4)
Svetkey 2008^170^ (WLM)^†^ | 30 mo | 24 mo | 0 mo | IG1: 0^**^ IG2: 30 | IG2 | 97.1 (17.5) | 88.7 (16.9) | | -4.2 (0.4)
Svetkey 2008^170^ (WLM)^†^ | 30 mo | 24 mo | 0 mo | IG1: 0^**^ IG2: 30 | CG | 95.9 (16.2) | 87.4 (15.3) | | -2.9 (0.4)

Bold=statistically significant difference between intervention and control groups.

* End of weight loss phase

** IG1 was a Web- and email-based intervention with no face-to-face or phone contact.

† Randomization occurred at the end of the weight loss phase, as apposed to the beginning (such as in Cussler et al and Perri et al).

Abbreviations: BL=baseline; CG=control group; IG=intervention group; mo=month; SD=standard deviation; SE=standard error; WLM= Weight Loss Maintenance.

Decrease in waist circumference. Waist circumference was reported in only 14 of the 38 trials, 12 of which were included in the meta-analysis (Figure 5).142,145,146,151,152,156,160,161,171,172,174,208 Waist circumference declined by an average of 2.7 cm more for participants in weight loss interventions than those in control conditions (WMD, -2.7 [95% CI, -4.1 to -1.4]; I^2^=93.8%; n=4,427). Statistical heterogeneity was very high, but most trials did show statistically significant group differences. Statistical heterogeneity was reduced slightly (to 78 percent) when DPP was dropped from the analysis. In DPP, a good-quality study of adults with prediabetes, the estimated 23 intervention sessions resulted in an almost 6.4 cm reduction in waist circumference in the lifestyle intervention group, almost 6 cm more than the control group.212 Because DPP was a very large trial, the confidence interval was very small, so it did not overlap estimates from many of the other trials. While generalizability to primary care may be somewhat questionable in the self-identified sample, internal validity was good and its generalizability was improved by the use of a large number of interventionists at many different sites. The two trials not included in the meta-analysis were contradictory.155,163 Three additional trials reported only WHR.167,177,178 Two of these trials found a greater improvement in the intervention group than in the control group.

Figure 5 Difference Between Intervention and Control Groups in Change in Waist Circumference (cm) at 12 to 18 Months

Abbreviations: ADAPT=Activity, Diet, and Blood Pressure Trial; CI=confidence interval; CV=cardiovascular; DISH=Dietary Intervention to Study Hypertension; DPP=Diabetes Prevention Program; FDPS=Finnish Diabetes Prevention Study; HEED=Help Educate to Eliminate Diabetes; HI=intensive intervention; IV=intervention; LO=brief intervention; N=number; NR=not reported; PATH=Physical Activity for Total Health; PREDIAS=Prevention of Diabetes Self-Management Program; SD=standard deviation; Subclincl=subclinical; TOHP=Trials of Hypertension Prevention; Unsel=unselected; WHLP=Women's Healthy Lifestyle Project; WMD=weighted mean difference.

Figure 5 displays a forest plot of studies reporting the weighted mean difference in waist circumference between the intervention group and control group. Data from Figure 5 are presented in Appendix C, Tables 1 and 2. This figure is described further in the section “Results: Key Question 3: Behaviorally-based Interventions: Decrease in Waist Circumference” as follows: “Waist circumference was reported in only 14 of the 38 trials, 12 of which were included in the meta-analysis.” This figure is also described in “Results: Key Question 3: Pharmacotherapy: Orlistat: Effect of Orlistat on Other Measures of Adiposity” as follows: “Waist circumference declined 2.3 cm more in the orlistat, compared to placebo-treated participants, over 12 to 18 months (WMD= -2.3, 95% CI -3.6, -0.9, k=7, I2=87.7%, n=2,227; Figure 5).”

Improvement in lipid levels. Only 16 of the 38 weight loss or weight maintenance trials reported lipid outcomes. 144-146,152,155,156,160,161,163,167,171,172,176-178,208 According to meta-analysis, weight loss intervention groups showed an average 5.8 mg/dL greater decline in total cholesterol (95% CI, -8.6 to -2.9; I^2^=26.1%; k=10; n=2,414) (Figure 6), 4.9 mg/dL greater decline in LDL cholesterol (95% CI, -7.3 to -2.6; I^2^=0.0%,;k=8; n=1,755) (Figure 7), and 11.1 mg/dL greater decline in triglycerides (95% CI, -15.6 to -6.5; I^2^=25.0%; k=8; n=1,955) (Figure 9) compared with control groups at 12 to 18 months. The pooled average showed no group differences in HDL cholesterol (Figure 8). Five additional trials could not be included in the meta-analysis, and most showed no statistically significant group differences in lipid level changes (Table 5).144,145,155,163,178 Because outcomes were sparsely reported (and therefore subject to reporting bias) and more likely to have null findings if not included in the meta-analysis, the meta-analysis likely overestimated the true effect size. The three good-quality trials reporting lipid levels had either null findings or small group differences in only some lipids outcomes.152,167,172 No trials were limited to patients with dyslipidemia. Results were mixed in the three trials limited to patients with hypertension or dyslipidemia.144,170,171

Figure 6 Difference Between Intervention and Control Groups in Total Cholesterol (mg/dL)

Abbreviations: CI=confidence interval; CV=cardiovascular; FDPS=Finnish Diabetes Prevention Study; HI=intensive intervention; IV=intervention; LO=brief intervention; N=number; NR=not reported; PATH=Physical Activity for Total Health; PREDIAS=Prevention of Diabetes Self-Management Program; SD=standard deviation; Subclincl=subclinical; Unsel=unselected; WHLP=Women's Healthy Lifestyle Project; WMD=weighted mean difference.

Figure 6 displays a forest plot of studies reporting the weighted mean difference in total cholesterol between the intervention group and control group. Data from Figure 6 are presented in Appendix C, Tables 1 and 2. This figure is described further in the section “Results: Key Question 3: Behaviorally-based Interventions: Improvement in Lipids” as follows: “According to meta-analysis, weight loss intervention groups showed an average 5.8 mg/dl greater decline in total cholesterol (95% CI -8.6, -2.9, I2=26.1%, k=10, n=2,414, Figure 6)...compared with control groups, at 12 to 18 months.” This figure is also described in “Results: Key Question 3: Pharmacotherapy: Orlistat: Effect of Orlistat on Lipids” as follows: “Overweight and obese participants in the orlistat group had a 12.6 mg/dl greater decline in total cholesterol (95% CI -17.0, -8.2 k=12, I2=84.1%, N=4,213; Figure 6).”

Figure 7 Difference Between Intervention and Control Groups in Change in Low-Density Lipoprotein (mg/dL)

Abbreviations: CI=confidence interval; CV=cardiovascular; HEED=Help Educate to Eliminate Diabetes; HI=intensive intervention; IV=intervention; LO=brief intervention; N=number; NR=not reported; PATH=Physical Activity for Total Health; SD=standard deviation; Subclincl=subclinical; Unsel=unselected; WHLP=Women's Healthy Lifestyle Project; WMD=weighted mean difference.

Figure 7 displays a forest plot of studies reporting the weighted mean difference in low-density lipoprotein between the intervention group and control group. Data from Figure 7 are presented in Appendix C, Tables 1 and 2. This figure is described further in the section “Results: Key Question 3: Behaviorally-based Interventions: Improvement in Lipids” as follows: “According to meta-analysis, weight loss intervention groups showed an average…4.9 mg/dl greater decline in LDLs (95% CI -7.3, -2.6, I2=0.0%, k=8, n=1,755, Figure 7)...compared with control groups, at 12 to 18 months.” This figure is also described in “Results: Key Question 3: Pharmacotherapy: Orlistat: Effect of Orlistat on Lipids” as follows: “Overweight and obese participants in the orlistat group had a…11.4 mg/dl greater decline in LDL (95% CI -15.8, -7.0; k=12, I2=86.3%, N=4,213; Figure 7)…compared to placebo participants, over 12 to 18 months.”

Figure 9 Difference Between Intervention and Control Groups in Change in Triglycerides (mg/dL)

Abbreviations: CI=confidence interval; CV=cardiovascular; FDPS=Finnish Diabetes Prevention Study; HI=intensive intervention; IV=intervention; LO=brief intervention; N=number; NR=not reported; PATH=Physical Activity for Total Health; PREDIAS=Prevention of Diabetes Self-Management Program; SD=standard deviation; Subclincl=subclinical; Unsel=unselected; WHLP=Women's Healthy Lifestyle Project; WMD=weighted mean difference.

Figure 9 displays a forest plot of studies reporting the weighted mean difference in triglycerides between the intervention group and control group. Data from Figure 9 are presented in Appendix C, Tables 1 and 2. This figure is described further in the section “Results: Key Question 3: Behaviorally-based Interventions: Improvement in Lipids” as follows: “According to meta-analysis, weight loss intervention groups showed an average…11.1 mg/dl greater decline in triglycerides (95% CI -15.6, -6.5, I2=25.0%, k=8, n=1,955, Figure 9), compared with control groups, at 12 to 18 months.” This figure is also described in “Results: Key Question 3: Pharmacotherapy: Orlistat: Effect of Orlistat on Lipids” as follows: “Triglycerides did not change differently between groups (WMD -4.8 95% CI -10.4, 0.7, k=10, I2=80.1%, N=3,626; Figure 9).”

Figure 8 Difference Between Intervention and Control Groups in Change in High-Density Lipoprotein (mg/dL)

Abbreviations: CI=confidence interval; CV=cardiovascular; FDPS=Finnish Diabetes Prevention Study; HI=intensive intervention; IV=intervention; LO=brief intervention; N=number; NR=not reported; PATH=Physical Activity for Total Health; PREDIAS=Prevention of Diabetes Self-Management Program; SD=standard deviation; Subclincl=subclinical; Unsel=unselected; WHLP=Women's Healthy Lifestyle Project; WMD=weighted mean difference.

Figure 8 displays a forest plot of studies reporting the weighted mean difference in high-density lipoprotein between the intervention group and control group. Data from Figure 8 are presented in Appendix C, Tables 1 and 2. This figure is described further in the section “Results: Key Question 3: Behaviorally-based interventions: Improvement in lipids” as follows: “The pooled average showed no group differences in HDL (Figure 8).” This figure is also described in “Results: Key Question 3: Pharmacotherapy: Orlistat: Effect of Orlistat on Lipids” as follows: “Overweight and obese participants in the orlistat group had a…0.9 mg/dl greater decline in HDL (95% CI -1.7, -0.1; k=12, I2=58.0%, N=4,213; Figure 8), compared to placebo participants, over 12 to 18 months.”

Table 5 Trials Not Included in Meta-Analysis: Lipids Data in Behavioral Trials, 12- to 18-Month Outcomes

Study | Population risk status (risk group) | # of sessions in first 12 mo | N | Total cholesterol, HDL, LDL, and triglyceride outcomes (mg/dL)
Anderssen 1995^144^ | Multiple risk factors | 159 | IG: 67 CG: 43 | IG1(diet only): differs from control for HDL but not for total cholesterol or triglycerides IG2 (physical activity only): no group differences IG3 (diet+exercise): differs from control for HDL and triglycerides but not for total cholesterol
Woollard 2003^178^ | Multiple risk factors | 12 | IG: 74 CG: 69 | Total serum cholesterol, LDL, HDL, and triglycerides: group differences NS at both 12 and 18 mo (data shown in a figure only)
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | Mean at baseline (SD), mean change at 12 mo
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | | BL | 12 mo
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | Total cholesterol
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | IG | 218.5 (35.1) | -1.9
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | CG | 215.8 (35.9) | -1.2
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | LDL cholesterol
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | IG | 140.5 (31.3) | -2.3
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | CG | 3.56 (12.7) | 0.8
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | HDL cholesterol
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | IG | 51.0 (12.7) | 0.8
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | CG | 52.5 (14.7) | 0.4
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | Triglycerides
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | IG | 138.1 (89.4) | -2.7
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | CG | 131.9 (88.5) | -5.3
Burke 2005^145^ | Hypertension | 20 | IG: 123 CG: 118 | Group differences in LDL at 16 mo but no differences in total cholesterol or HDL at 16 mo (data shown in a figure only)
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | Median (range) at baseline, median change at 12 mo
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | | BL | 12 mo
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | Total cholesterol
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | IG | 173.7 (81.1-235.5) | 7.7
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | CG | 173.7 (123.6-239.4) | 3.9
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | Triglycerides
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | IG | 123.9 (26.6-318.6) | 0.5
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | CG | 115.1 (53.1-123.9) | 7.2

Bold=statistically significant difference between intervention and control groups.

Abbreviations: BL=baseline; CG=control group; HDL=high-density lipoprotein; IG=intervention group; LDL=low-density lipoprotein; Mo=month; NS=not statistically significant; SD=standard deviation.

Improvement in blood pressure. Twenty-two of 38 trials reported blood pressure.143-147,149,154-157,161,163,167-169,171,172,174,175,177,207,208 In the 14 trials combined by meta-analysis, 144-146,156,161,167-169,171,172,174,177,207,208 intervention groups showed an average 2 mm Hg greater reduction in both SBP and DBP compared with control groups (SBP: WMD, -2.5 [95% CI, -3.2 to -1.7]; I^2^=32.8%; DBP: WMD, -1.9 [95% CI, -2.6 to -1.2]; I^2^=64.0%; n=6,427) (Figures 10 and 11). Although blood pressure was not frequently reported in the behavioral trials, the pooled effect sizes are less likely to be biased than the pooled effect sizes for lipid outcomes. Most of the good-quality trials reported blood pressure, and the nine trials that could not be included in the meta-analysis were mixed, but generally supported the meta-analysis results of a small treatment benefit (Table 6).143,144,147,149,154,155,157,163,175 In addition, 12 of the 13 trials that recruited participants with hypertension,145,147,149,154,155,157,175 prehypertension,143,168,169 or hypertension or another cardiovascular risk factor144,171,178 provided blood pressure outcomes, and effect sizes were very similar in these trials.

Figure 10 Difference Between Intervention and Control Groups in Change in Systolic Blood Pressure (mm Hg)

Abbreviations: ADAPT=Activity, Diet, and Blood Pressure Trial; CI=confidence interval; CV=cardiovascular; DPP=Diabetes Prevention Program; FDPS=Finnish Diabetes Prevention Study; HEED=Help Educate to Eliminate Diabetes; HI=intensive intervention; IV=intervention; LO=brief intervention; N=number; NR=not reported; ODES=Oslo Diet and Exercise Study; PREDIAS=Prevention of Diabetes Self-Management Program; SD=standard deviation; Subclincl=subclinical; TOHP=Trials of Hypertension Prevention; Unsel=unselected; WHLP=Women's Healthy Lifestyle Project; WMD=weighted mean difference.

Figure 10 displays a forest plot of studies reporting the weighted mean difference in systolic blood pressure between the intervention group and control group. Data from Figure 10 are presented in Appendix C, Tables 1 and 2. This figure is described further in the section “Results: Key Question 3: Behaviorally-based Interventions: Improvement in Blood Pressure” as follows: “In the 14 trials combined by meta-analysis, intervention groups showed an average 2 mmHg greater reduction in both systolic blood pressure (SBP) and diastolic blood pressure (DBP) compared to control groups (SBP WMD=-2.5, 95% CI -3.2, -1.7, I2=32.8%; Figure 10; DBP WMD=-1.9, 95% CI -2.6, -1.2, I2=64.0%; n=6,427; Figure 11).” This figure is also described in “Results: Key Question 3: Pharmacotherapy: Orlistat: Effect of Orlistat on Blood Pressure” as follows: “Participants randomized to orlistat had a 2.0 mm greater decline in SBP (WMD=-2.0, 95% CI -3.1, -1.0, I2=0.0%, n=3,683; k=7; Figure 10)…after 12 to 18 months, compared to those given placebo.”

Figure 11 Difference Between Intervention and Control Groups in Change in Diastolic Blood Pressure (mm Hg)

Abbreviations: ADAPT=Activity, Diet, and Blood Pressure Trial; CI=confidence interval; CV=cardiovascular; DPP=Diabetes Prevention Program; FDPS=Finnish Diabetes Prevention Study; HEED=Help Educate to Eliminate Diabetes; HI=intensive intervention; IV=intervention; LO=brief intervention; N=number; NR=not reported; ODES=Oslo Diet and Exercise Study; PREDIAS=Prevention of Diabetes Self-Management Program; SD=standard deviation; Subclincl=subclinical; TOHP=Trials of Hypertension Prevention; Unsel=unselected; WHLP=Women's Healthy Lifestyle Project; WMD=weighted mean difference.

Figure 12 displays a forest plot of studies reporting the weighted mean difference in plasma glucose between the intervention group and control group. Data from Figure 12 are presented in Appendix C, Tables 1 and 2. This figure is described further in the section “Results: Key Question 3: Behaviorally-based Interventions: Glucose Tolerance” as follows: “Twelve of 38 trials reported glucose tolerance. When eight were pooled, behavioral interventions reduced fasting glucose by an average of 3.4 mg/dl more than control conditions (WMD= -3.4, 95% CI -5.5, -1.4, I2=82.8%, k=8, n=3,849; Figure 12), although with high statistical heterogeneity.” This figure is also described in “Results: Key Question 3: Pharmacotherapy: Orlistat: Effect of Orlistat on Glucose Tolerance” as follows: “Those randomized to orlistat experienced a 5.7 mg/dl greater reduction in fasting glucose over 12 months, compared to those given placebo (95% CI -8.3, -3.0, I2=79.6%, k=9; n=3,727; Figure 12).”

Table 6 Trials Not Included in Meta-Analysis: Changes in Blood Pressure in Behavioral Trials, 12- to 18-Month Outcomes

Study | Population risk status (risk group) | # of sessions in first 12 mo | N | Blood pressure (mmHg)
Cohen 1991^147^ | Hypertension | 12 | IG: 15 CG:15 | Mean change (SD) in arterial pressure at 12 mo
Cohen 1991^147^ | Hypertension | 12 | IG: 15 CG:15 | IG | 3.0 (14.2)
Cohen 1991^147^ | Hypertension | 12 | IG: 15 CG:15 | CG | -0.7 (11.3)
Cohen 1991^147^ | Hypertension | 12 | IG: 15 CG:15 | No group difference in number of antihypertension medications
Davis 1992^149^ | Hypertension | 10 | IG: 100 CG: 100 | 3 of the 4 medication groups showed differences in DBP between weight loss and usual care groups at 12 mo (p<0.05); SBP not reported (data shown in figure only)
Jones 1999^154^ (HOT) | Hypertension | 10 | IG: 55 CG: 56 | No group differences in % achieving target DBP at any time interval (3-30 mo); no group differences in average change in SBP or DBP
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | Mean (SD) at baseline, mean change at 12 mo
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | | BL | 12 mo
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | Systolic blood pressure
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | IG | 149 (16) | -4.7
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | CG | 148 (16) | -3.4
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | Diastolic blood pressure
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | IG | 91(9) | -4.0
Kastarinen 2002^155^ (LIHEF) | Hypertension | 5 | IG: 360 CG: 355 | CG | 91 (8) | -2.4
Whelton 1998^175^ (TONE) | Hypertension | 26 | IG: 147 CG: 147 | Mean (SD) at baseline, mean change (95% SE) at last visit prior to attempted medication withdrawal (median, 3.2 mo)
Whelton 1998^175^ (TONE) | Hypertension | 26 | IG: 147 CG: 147 | | BL | Last visit
Whelton 1998^175^ (TONE) | Hypertension | 26 | IG: 147 CG: 147
Whelton 1998^175^ (TONE) | Hypertension | 26 | IG: 147 CG: 147 | Systolic blood pressure
Whelton 1998^175^ (TONE) | Hypertension | 26 | IG: 147 CG: 147 | IG | 128.6 (10.8) | -4.0 (1.3)
Whelton 1998^175^ (TONE) | Hypertension | 26 | IG: 147 CG: 147 | CG | 127.7 (12.1) | -0.8 (0.8)
Whelton 1998^175^ (TONE) | Hypertension | 26 | IG: 147 CG: 147 | Diastolic blood pressure
Whelton 1998^175^ (TONE) | Hypertension | 26 | IG: 147 CG: 147 | IG | 70.7 (9.6) | -1.1 (0.8)
Whelton 1998^175^ (TONE) | Hypertension | 26 | IG: 147 CG: 147 | CG | 71.5 (8.5) | -0.8 (0.5)
Hypertension Prevention Trial Research Group 1990^143^ | Prehypertension | 16 | IG: 125 CG: 126 | Mean at baseline, mean change (SE) at 36 mo
Hypertension Prevention Trial Research Group 1990^143^ | Prehypertension | 16 | IG: 125 CG: 126 | | BL | 36 mo
Hypertension Prevention Trial Research Group 1990^143^ | Prehypertension | 16 | IG: 125 CG: 126
Hypertension Prevention Trial Research Group 1990^143^ | Prehypertension | 16 | IG: 125 CG: 126 | Systolic blood pressure
Hypertension Prevention Trial Research Group 1990^143^ | Prehypertension | 16 | IG: 125 CG: 126 | IG | 125.3 | -5.0 (0.9)
Hypertension Prevention Trial Research Group 1990^143^ | Prehypertension | 16 | IG: 125 CG: 126 | CG | 124.7 | -2.6 (0.9)
Hypertension Prevention Trial Research Group 1990^143^ | Prehypertension | 16 | IG: 125 CG: 126 | Diastolic blood pressure
Hypertension Prevention Trial Research Group 1990^143^ | Prehypertension | 16 | IG: 125 CG: 126 | IG | 83.0 | -4.2 (0.8)
Hypertension Prevention Trial Research Group 1990^143^ | Prehypertension | 16 | IG: 125 CG: 126 | CG | 83.3 | -2.4 (0.8)
Langford 1985^157^ | Prehypertension | 18 | IG: 52 CG: 31 | % not taking antihypertension medication
Langford 1985^157^ | Prehypertension | 18 | IG: 52 CG: 31 | | 56 weeks
Langford 1985^157^ | Prehypertension | 18 | IG: 52 CG: 31
Langford 1985^157^ | Prehypertension | 18 | IG: 52 CG: 31 | IG | 59.5
Langford 1985^157^ | Prehypertension | 18 | IG: 52 CG: 31 | CG | 35.3
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | Median (range) at baseline, median change at 12 mo
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | | BL | 12 mo
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | Systolic blood pressure
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | IG | 116 (90-146) | 6.0
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | CG | 116 (92-176) | 4.1
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | Diastolic blood pressure
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | IG | 70 (48-90) | 1.1
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | CG | 72 (53-98) | -1.0

Bold=statistically significant difference between intervention and control groups.

Abbreviations: BL=baseline; CG=control group; DBP=diastolic blood pressure; HOT=Hypertension Optimal Treatment; IG=intervention group; LIHEF=Lifestyle Intervention Against Hypertension in Eastern Finland; Mo=month; SBP=systolic blood pressure; SD=standard deviation; SE=standard error; TONE=Trial of Nonpharmacologic Interventions in the Elderly.

Five out of six long-term (24 to 54 month) intervention trials reported blood pressure outcomes at the end of the intervention phase (Table 3). All five interventions found group differences.143,167,169,172,175 A good-quality trial, the Finnish Diabetes Prevention Study, reported the largest intervention effect: an average reduction of 5 mm Hg in both SBP and DBP (compared with 0 and 3 mm Hg in the control group, respectively) after 24 months.172

Maintenance of blood pressure improvements after intervention completion varied. After two long-term (30 to 34 months) intensive interventions (≥10 sessions), blood pressure improvements were maintained for 4 to 18 months.142,149,207 Two less intensive trials (0 to 5 sessions) showed no group differences 12 to 18 months later.155,174

Behavioral treatment was successful in reducing the risk of a hypertension diagnosis in participants with prehypertension. Trials of Hypertension (TOHP) I and II, both good-quality trials, reported reduced risk of incident hypertension at 12 and 18 months of 34 and 22 percent, respectively.168,169 By 3 years in TOHP II, fewer participants in the intervention group (32 percent) met criteria for hypertension compared with the control group (39 percent) (absolute RD, 7.3 [NNT=14]).169 The effect was no longer statistically significant at 4 years.

Development of diabetes. Two large, good-quality behavioral trials of diabetes prevention in overweight and obese patients with elevated plasma glucose showed reduced onset of diabetes in the intervention group compared with control, with similar effect sizes (Table 7).172,206 In DPP, twice as many people in the control group than the lifestyle management group had developed diabetes by 3 years (absolute RR, 14.5 [28.9 vs.14.4%]; NNT=7).206 Ten-year followup from DPP reported long-term diabetes onset, but did not meet inclusion criteria (see discussion section).213 Similarly, the Finnish Diabetes Prevention Study intervention resulted in incidence rates that were less than half of the control group rates at 2- and 6-year followup (2 years: 5.7 vs. 14.4%; 6 years: 10.2 vs. 23.0% in intervention and control groups, respectively).172 There was no reduction in diabetes onset at 12-month followup in a third, smaller (n=90) fair-quality trial of persons with prediabetes who were primarily Hispanic residents of the East Harlem neighborhood in New York City. This population had very high rates of elevated fasting glucose levels; only 29 percent of those screened had normal glucose levels.208

Table 7 Diabetes Incidence

Study | # Randomized | Time to followup (mo) | Population risk group | Weight loss (kg) | | | | | Diabetes incidence | | | | NNT | Quality rating and issues noted with study
Behavioral
DPP 2005 | IG: 1079 CG: 1082 | 12, 36 | Prediabetes | Mean (SD) at baseline, mean change (SE) at 12 mo | | | | | Diabetes mellitus, crude cumulative incidence (cases/100 person-years) | | | | | Good
DPP 2005 | IG: 1079 CG: 1082 | 12, 36 | Prediabetes | | BL | | 12 mo | | | BL | 36 mo | | | Good
DPP 2005 | IG: 1079 CG: 1082 | 12, 36 | Prediabetes | | | | | | | | | | | Good
DPP 2005 | IG: 1079 CG: 1082 | 12, 36 | Prediabetes | IG | 94.1 (20.8) | | -6.8 (0.2) | | IG | -- | 4.8 | | | Good
DPP 2005 | IG: 1079 CG: 1082 | 12, 36 | Prediabetes | CG | 94.3 (20.2) | | -0.4 (0.2) | | CG | -- | 11.0 | | | Good
Tuomilehto 2001 | IG: 265 CG: 257 | 12, 24, 72 | Prediabetes | Mean (SD) BMI at baseline (kg/m^2^), mean change (SD) at 12, 24 mo | | | | | n (%) | | | | 8 | Good
Tuomilehto 2001 | IG: 265 CG: 257 | 12, 24, 72 | Prediabetes | | BL | 12 mo | 24 mo | | | BL | 24 mo | 72 mo | 8 | Good
Tuomilehto 2001 | IG: 265 CG: 257 | 12, 24, 72 | Prediabetes | | | | | | | | | | 8 | Good
Tuomilehto 2001 | IG: 265 CG: 257 | 12, 24, 72 | Prediabetes | IG | 31.3 (4.6) | -4.2 (5.1) | | -3.5 (5.5) | IG | -- | 15 (5.7) | 27(10.2) | 8 | Good
Tuomilehto 2001 | IG: 265 CG: 257 | 12, 24, 72 | Prediabetes | CG | 31.0 (4.5) | -0.8 (3.7) | | 0.8 (4.4) | CG | -- | 37 (14.4) | 59(23.0) | 8 | Good
Parikh 2010 | IG: 50 CG: 49 | 12 | Prediabetes | Mean (SD) at baseline, mean change (SD) at 12 mo | | | | | Diabetes mellitus, crude cumulative incidence (cases/100 person-years) | | | | | Fair; high attrition; no report of blinding outcomes assessment or treatment allocation
Parikh 2010 | IG: 50 CG: 49 | 12 | Prediabetes | | BL | | 18 mo | | | BL | 12 mo | | | Fair; high attrition; no report of blinding outcomes assessment or treatment allocation
Parikh 2010 | IG: 50 CG: 49 | 12 | Prediabetes | | | | | | | | | | | Fair; high attrition; no report of blinding outcomes assessment or treatment allocation
Parikh 2010 | IG: 50 CG: 49 | 12 | Prediabetes | IG | 79.1 (17.7) | | - 3.3 (3.3) | | IG | -- | 36 | | | Fair; high attrition; no report of blinding outcomes assessment or treatment allocation
Parikh 2010 | IG: 50 CG: 49 | 12 | Prediabetes | CG | 73.6 (12.3) | | -1.1 (3.7) | | CG | -- | 33 | | | Fair; high attrition; no report of blinding outcomes assessment or treatment allocation
Orlistat
Richelsen 2007^198^ | IG: 153 CG: 156 | 12, 18, 36 | Prediabetes Predyslipidemia | Mean (SD) at baseline, mean change at 18 mo | | | | | n (%) | | | | 18 | Fair; high attrition
Richelsen 2007^198^ | IG: 153 CG: 156 | 12, 18, 36 | Prediabetes Predyslipidemia | | -2 mo | BL | 12 mo | 18 mo | | BL | 36 mo | | 18 | Fair; high attrition
Richelsen 2007^198^ | IG: 153 CG: 156 | 12, 18, 36 | Prediabetes Predyslipidemia | | | | | | | | | | 18 | Fair; high attrition
Richelsen 2007^198^ | IG: 153 CG: 156 | 12, 18, 36 | Prediabetes Predyslipidemia | IG | 110.7 (17.9) | -14.5 | -- | -11.7 | IG | -- | 8 (5.2) | | 18 | Fair; high attrition
Richelsen 2007^198^ | IG: 153 CG: 156 | 12, 18, 36 | Prediabetes Predyslipidemia | CG | 111.9 (16.0) | -14.3 | -- | -9.6 | CG | -- | 17 (10.9) | | 18 | Fair; high attrition
Torgerson 2004^202^ | IG: 1650 CG: 1655 | 12, 48 | Prediabetes | Mean (SD) at baseline, mean change at 12 mo | | | | | Diabetes mellitus, cumulative incid ence (%) | | | | 35 | Fair; high attrition, especially by 48 mo
Torgerson 2004^202^ | IG: 1650 CG: 1655 | 12, 48 | Prediabetes | | BL | 1 yr | 4 yr^*^ | | | BL | 4 yr | | 35 | Fair; high attrition, especially by 48 mo
Torgerson 2004^202^ | IG: 1650 CG: 1655 | 12, 48 | Prediabetes | | | | | | | | | | 35 | Fair; high attrition, especially by 48 mo
Torgerson 2004^202^ | IG: 1650 CG: 1655 | 12, 48 | Prediabetes | IG | 110.4 (16.3) | -10.6 | -- | | IG | 0 | 102 (6.2) | | 35 | Fair; high attrition, especially by 48 mo
Torgerson 2004^202^ | IG: 1650 CG: 1655 | 12, 48 | Prediabetes | CG | 110.6 (16.5) | -6.2 | -- | | CG | 0 | 149 (9.0) | | 35 | Fair; high attrition, especially by 48 mo
Metformin
DPP 2005^212^ | IG: 1073 CG: 1082 | 12, 36 | Prediabetes | Mean (SD) at baseline, mean change (SE) at 12 mo | | | | | Diabetes mellitus, crude cumulative incidence (cases/100 person-years) | | | | | Good
DPP 2005^212^ | IG: 1073 CG: 1082 | 12, 36 | Prediabetes | | BL | | 12 mo | | | BL | 36 mo | | | Good
DPP 2005^212^ | IG: 1073 CG: 1082 | 12, 36 | Prediabetes | | | | | | | | | | | Good
DPP 2005^212^ | IG: 1073 CG: 1082 | 12, 36 | Prediabetes | IG | 94.3 (19.9) | | -2.7 (0.2) | | IG | -- | 7.8 | | | Good
DPP 2005^212^ | IG: 1073 CG: 1082 | 12, 36 | Prediabetes | CG | 94.3 (20.2) | | -0.4 (0.2) | | CG | -- | 11.0 | | | Good
Fontbonne 1996^185^ | IG: 227 CG: 230 | 12 | Unselected/ low risk | Mean change (95% CI) at 12 mo | | | | | # diagnosed with diabetes during course of trial IG: 0 CG: 5 | | | | | Fair; participants were diagnosed with diabetes by local investigators; lack of central adjustments; high attrition
Fontbonne 1996^185^ | IG: 227 CG: 230 | 12 | Unselected/ low risk | | BL | | 12 mo | | # diagnosed with diabetes during course of trial IG: 0 CG: 5 | | | | | Fair; participants were diagnosed with diabetes by local investigators; lack of central adjustments; high attrition
Fontbonne 1996^185^ | IG: 227 CG: 230 | 12 | Unselected/ low risk | | | | | | # diagnosed with diabetes during course of trial IG: 0 CG: 5 | | | | | Fair; participants were diagnosed with diabetes by local investigators; lack of central adjustments; high attrition
Fontbonne 1996^185^ | IG: 227 CG: 230 | 12 | Unselected/ low risk | IG | -- | | -2.0 (-3.0 to -1.1) | | # diagnosed with diabetes during course of trial IG: 0 CG: 5 | | | | | Fair; participants were diagnosed with diabetes by local investigators; lack of central adjustments; high attrition
Fontbonne 1996^185^ | IG: 227 CG: 230 | 12 | Unselected/ low risk | CG | -- | | -0.8 (-1.6 to 0.1) | | # diagnosed with diabetes during course of trial IG: 0 CG: 5 | | | | | Fair; participants were diagnosed with diabetes by local investigators; lack of central adjustments; high attrition

* Not abstracted due to high attrition.

Bold=statistically significant difference between intervention and control groups.

Abbreviations: BL=baseline; BMI=body mass index; CG=control group; CI=confidence interval; DPP=Diabetes Prevention Program; IG=intervention group; mo=months; NNT=number needed to treat; SD=standard deviation; SE=standard error.

Glucose tolerance. Twelve of 38 trials reported glucose tolerance.145,146,152,156,161-163,167,171,172,208,212 When eight were pooled, behavioral interventions reduced fasting glucose levels by an average of 3.4 mg/dL more than control conditions (WMD, -3.4 [95% CI, -5.5 to -1.4]; I^2^=82.8%; k=8; n=3,849) (Figure 12), although with high statistical heterogeneity.156,160,161,167,171,172,208,212 These outcomes were rarely reported, and the four trials that could not be included in the meta-analysis145,146,152,163 were uniformly lacking in group differences (Table 8), suggesting that the pooled result overestimated the true effect.

Figure 12 Difference Between Intervention and Control Groups in Change in Plasma Glucose (mg/dL)

Abbreviations: CI=confidence interval; CV=cardiovascular; DPP=Diabetes Prevention Program; FDPS=Finnish Diabetes Prevention Study; HEED=Help Educate to Eliminate Diabetes; HI=intensive intervention; IV=intervention; LO=brief intervention; N=number; NR=not reported; PREDIAS=Prevention of Diabetes Self-Management Program; SD=standard deviation; Subclincl=subclinical; Unsel=unselected; WHLP=Women's Healthy Lifestyle Project; WMD=weighted mean difference.

Figure 12 displays a forest plot of studies reporting the weighted mean difference in plasma glucose between the intervention group and control group. Data from Figure 12 are presented in Appendix C, Tables 1 and 2. This figure is described further in the section “Results: Key Question 3: Behaviorally-based Interventions: Glucose Tolerance” as follows: “Twelve of 38 trials reported glucose tolerance. When eight were pooled, behavioral interventions reduced fasting glucose by an average of 3.4 mg/dl more than control conditions (WMD= -3.4, 95% CI -5.5, -1.4, I2=82.8%, k=8, n=3,849; Figure 12), although with high statistical heterogeneity.” This figure is also described in “Results: Key Question 3: Pharmacotherapy: Orlistat: Effect of Orlistat on Glucose Tolerance” as follows: “Those randomized to orlistat experienced a 5.7 mg/dl greater reduction in fasting glucose over 12 months, compared to those given placebo (95% CI -8.3, -3.0, I2=79.6%, k=9; n=3,727; Figure 12).”

Table 8 Trials Not Included in Meta-Analysis: Glucose Tolerance in Behavioral Trials, 12- to 18-Month Outcomes

Study | Population risk status (risk group) | # of sessions in first 12 mo | N | Glucose tolerance
Burke 2005^145^ | Hypertension | 20 | IG: 123 CG: 118 | No group differences at 16 mo (figure only)
Christian 2008^142^ | Diabetes | 4 | IG: 155 CG: 155 | Mean (SD) hemoglobinA_1C_ at baseline and 12 mo (%)
Christian 2008^142^ | Diabetes | 4 | IG: 155 CG: 155 | | BL | 12 mo
Christian 2008^142^ | Diabetes | 4 | IG: 155 CG: 155
Christian 2008^142^ | Diabetes | 4 | IG: 155 CG: 155 | IG | 8.08 (2.02) | -0.141 (1.76)
Christian 2008^142^ | Diabetes | 4 | IG: 155 CG: 155 | CG | 8.29 (1.93) | -0.46 (1.63)
Irwin 2003^152^ | Unselected/low risk | 128 | IG: 87 CG: 86 | Mean (95% CI) fasting glucose at baseline and 12 mo (mg/dL)
Irwin 2003^152^ | Unselected/low risk | 128 | IG: 87 CG: 86 | | BL | 12 mo
Irwin 2003^152^ | Unselected/low risk | 128 | IG: 87 CG: 86
Irwin 2003^152^ | Unselected/low risk | 128 | IG: 87 CG: 86 | IG | 97.8 (81.4-117.4) | 98.9 (81.8-119.5)
Irwin 2003^152^ | Unselected/low risk | 128 | IG: 87 CG: 86 | CG | 97.4 (82.5-115.1) | 98.4 (83.5-115.9)
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | Median (range) fasting glucose at baseline, median change at 12 mo (mg/dL)
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | | BL | 12 mo
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | IG | 97.3 (81.1-117.1) | 1.8
Narayan 1998^163^ | Unselected/low risk | 52 | IG: 48 CG: 47 | CG | 91.9 (75.7-109.9) | 1.8

Bold=statistically significant difference between intervention and control groups.

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; IG=intervention group; Mo=month; SD=standard deviation.

Six of the seven weight loss trials targeting adults with type 2 diabetes or type 2 prediabetes measured change in glucose control at 12–18 months.142,146,156,159,160,172,208 Five trials measuring change in fasting glucose levels that could be pooled showed similar treatment effects, ranging from a 1.0 to 6.1 mg/dL greater decline in fasting glucose level in the intervention group compared with the control group (WMD, -5.3 [95% CI, -6.2 to -4.5]; I^2^=0.0%; k=5; n=2,901) (figure not shown). The sixth trial, which was not in the meta-analysis, showed no differences in hemoglobin A_1C_ levels between treatment groups.146 Pooled results from this subset of trials were less subject to bias since most trials limited to populations with diabetes or prediabetes reported glucose outcomes, which was presumably identified a priori as a major outcome.

Common elements of efficacious interventions. We present a number of intervention components in Table 9. However, it was difficult to qualitatively and quantitatively determine important components of efficacious interventions in this body of literature. First, some trials provided much greater detail about their interventions, so the reliability of coding was limited. Second, because most interventions were successful, there were very few nonefficacious trials for comparison. Finally, with so many outcomes of potential interest, there was a risk of over-interpreting spurious results. To address these concerns, we limited our analysis to a single outcome—weight loss. And, instead of comparing efficacious with nonefficacious trials, we used meta-regression to examine whether any components were predictive of effect size. The components examined were chosen based on expert advice and our ability to robustly identify that component in the published trials.

Table 9 Behavioral Intervention Components

| | | Study | Estimated # sessions in 12 months | Physical activity sessions | Group sessions | Individual sessions | Technology-based | Primary care provider training | Involved spouse/family | Weight loss goal set | Addressed barriers | Addressed pros/cons or motivation | Active use of self-monitoring | Incentives | Support for weight maintenance
Diabetes, hypertension, or dyslipidemia | US | PC | Christian 2008^146^ | 4 | | | X | X | | | | X | X
Diabetes, hypertension, or dyslipidemia | US | PC | Cohen 1991^147^ | 12 | | | X | | X
Diabetes, hypertension, or dyslipidemia | US | PC | Mayer-Davis 2004^159^ (POWER)^*^ | 30 | | X | X | | | | X | | | X | X | X
Diabetes, hypertension, or dyslipidemia | US | NPC | Jones 1999^154^ (HOT) | 10 | | X | X | | | | | | | | | X
Diabetes, hypertension, or dyslipidemia | US | NPC | Davis 1992^149^(TAIM)^*^ | 16 | | X | | | | | X | | | | | X
Diabetes, hypertension, or dyslipidemia | US | NPC | Langford 1985^157^ (DISH)^*^ | 18 | | X | X | | | X | X | | | X | | X
Diabetes, hypertension, or dyslipidemia | US | NPC | Whelton 1998^175^ (TONE)^*^ | 26 | | X | X | | | | X | X | | X | | X
Diabetes, hypertension, or dyslipidemia | Non-US | PC | Kastarinen 2002^155^ (LIHEF)^*^ | 5 | | X | X
Diabetes, hypertension, or dyslipidemia | Non-US | PC | ter Bogt 2009^171^ | 5 | | | X | X | | | | | X | | | X
Diabetes, hypertension, or dyslipidemia | Non-US | PC | Woollard 2003^178^ | 12 | | | X | | | | | | X
Diabetes, hypertension, or dyslipidemia | Non-US | NPC | Burke 2005^145^ (ADAPT)^*^ | 20 | | X | X | | | X | | X | X | | | X
Diabetes, hypertension, or dyslipidemia | Non-US | NPC | Anderssen 1995^144^ (ODES)^*^ | 159 | X | X | X | | | | X
Subclinical | US | NPC | Parikh 2010^204^ (HEED) | 8 | | X | | | | | | | | | X
Subclinical | US | NPC | HPT 1990^143,*^ | 16 | | X | | | | | X | X | X | X | | X
Subclinical | US | NPC | DPP 2005^212,*^ | 23 | | X | X | | | | X | | | X | X | X
Subclinical | US | NPC | Stevens 1993^168^ (TOHP I)^*^ | 23 | | X | X | | | | | X | | X | | X
Subclinical | US | NPC | Stevens 2001^169^ (TOHP II)^*^ | 32 | | X | X | | | X | X | X | X | X | | X
Subclinical | US | NPC | Villareal 2008^173,*^ | 208 | X | X | | | | | X | X | | X
Subclinical | Non-US | NPC | Mensink 2003^160,*^ | 4 | X | X | X
Subclinical | Non-US | NPC | Tuomilento 2001^172^ (FDPS)^*^ | 7^**^ | X | X | X | | | X | X
Subclinical | Non-US | NPC | Kulzer 2009^156^ (PREDIAS)^*^ | 12 | | X | | | | X | | X | X | | | X
Subclinical | Non-US | NPC | Mitsui 2008^161^ | 24 | X | X | | | | | | | | X | | X
Low risk or unselected | US | PC | Martin 2008^158^ | 6 | | | X | | X | | | X
Low risk or unselected | US | NPC | Wood 1988^176,*^ | 23 | | X | X
Low risk or unselected | US | NPC | Simkin-Silverman 2003 (WHLP)167,* | 20 | | X | X | | | | X | X | | X | X | X
Low risk or unselected | US | NPC | Wood 1991^177,*^ | 25 | X | X | | | | | | | | X | | X
Low risk or unselected | US | NPC | Jeffery 1993^153,*^ | 27 | | X | | | | | X | | | X | X | X
Low risk or unselected | US | NPC | Narayan 1998^163^ | 52 | X | X
Low risk or unselected | US | NPC | Fitzgibbon 2010^200^ (ORBIT) | 116 | | X | X | | | | X | X | X | X | | X
Low risk or unselected | US | NPC | Irwin 2003^152^ (PATH)^*,‡^ | 128 | X | X | X | | | | | | | X | X | X
Low risk or unselected | Non-US | PC | Moore 2003^162^ | . | | | | | X | | | | | | | X
Low risk or unselected | Non-US | PC | Pritchard 1999^165,*^ | 8 | | | X | | | | | | | X
Low risk or unselected | Non-US | NPC | Haapala 2009^151,*^ | 0 | | | | X | | | X | | | X
Low risk or unselected | Non-US | NPC | Werkman 2010^174^ | 0 | | | | X
Low risk or unselected | Non-US | NPC | Silva 2009^166,*^ | 30 | | X | | | | | | X | X | X | | X

* Statistically significant between intervention and control groups for weight loss.

** Indicates an undetermined number of additional physical activity-focused sessions were offered.

‡ Intervention focus was physical activity.

Abbreviations: ADAPT= Activity, Diet, and Blood Pressure Trial; DISH=Dietary Intervention to Study Hypertension; DPP=Diabetes Prevention Program; FDPS=Finnish Diabetes Prevention Study; HEED=Help Educate to Eliminate Diabetes; HOT=Hypertension Optimal Treatment; HPT=Hypertension Prevention Trial; LIHEF=Lifestyle Intervention Against Hypertension in Eastern Finland; NPC=non-primary care; ODES=Oslo Diet and Exercise Study; ORBIT=Obesity Reduction Black Intervention Trial; PATH=Physical Activity for Total Health; PC=primary care; POWER=Pounds Off With Empowerment; PREDIAS=Prevention of Diabetes Self-Management Program; TAIM=Trial of Antihypertensive Interventions and Management; TOHP=Trials of Hypertension Prevention; TONE=Trial of Nonpharmacologic Interventions in the Elderly; WHLP=Women's Healthy Lifestyle Project; US=United States.

As described previously, meta-regression suggests that the number of sessions provided in the first 12 months was predictive of weight loss; a greater number of sessions correlated with greater effect size. After controlling for number of sessions in the first year, none of the following components demonstrated a relationship with effect size: physical activity sessions, group sessions, individual sessions, technology-based intervention, specific weight loss goals, spouse or family involvement, addressed barriers to weight loss, motivational assessment (i.e., pros and cons of weight loss), self monitoring, incentives for weight loss or participation, or support after active intervention phase. However, our confidence in these results is limited because these components were not always explicitly reported, especially not in primary care settings and trials with less intensive interventions.

Differences in patient subgroups. Data on subgroup differences should be viewed as exploratory due to incomplete reporting of these data across all included trials.

Age. Data on age effects were mixed, but suggest that older adults may benefit even more than younger adults. Of five trials examining the effect of age on treatment effect,152,169-171,210 two good-quality studies found increasing treatment benefits with increasing age.169,210 In DPP, increasing age was associated with more weight loss, greater decrease in waist circumference, and lower diabetes incidence with treatment.210 In DPP, diabetes incidence decreased more in the oldest age group compared with the youngest in the behavioral intervention group, although the effect disappeared after controlling for weight loss and behavior change.210 However, the older DPP participants were likely healthier than the general population, so the results may not be representative.142 In a trial of hypertension prevention in adults ages 30 to 54 years, increasing age was associated with greater weight loss at 36 months (but not 18 months).169

Sex. Five trials examined sex differences in the impact of treatment on weight loss168-171,214 and four found that men showed greater weight loss than women.168,169,171,214 However, in one study (DPP), the difference was primarily seen in black women, as black women in the intervention group lost little weight; five other sex-by-race groups showed comparable differences between intervention and control group participants.214 In another trial (TOHP I), the sex-by-treatment interaction disappeared after controlling for baseline BMI.168

Six of the included trials were limited to women.148,152,158,166,167,204 One focused on weight maintenance148 and had comparable findings to a similar intensity weight maintenance trial of men and women.170 Four152,166,167,204 of the five152,158,166,167,204 weight loss trials demonstrated a treatment effect, with 1.4 to 3.3 kg greater weight loss in the intervention groups than in control groups, which was slightly less than the overall pooled effect of 3.3 kg. Four studies examined sex differences for additional intermediate health outcomes.145,157,168,177 Sex differences were absent for blood pressure outcomes.145,157,168 In one trial, men had improvements in HDL cholesterol, while women showed no group differences. In contrast, women had improvements in LDL and total cholesterol while men did not, but the sex-by-treatment interactions were not directly tested.177 In DPP, diabetes incidence did not differ significantly according to sex. However, DPP was not powered to assess the significance of effects within the subgroups.206

Race. Four trials169,170,175,214 examined the effect of race on response to behavioral weight loss or weight maintenance treatment. Three169,175,214 found that black participants lost a smaller amount of weight than nonblack participants. In one of these trials, the effect was limited to black women.214 However, in another trial, the effect of race remained after controlling for sex and multiple other covariates.175 Two trials examined the effect of race on hypertension,157,168 with mixed results: one trial found no race-by-treatment interaction,168 but another reported that black participants were twice as likely to resume taking hypertension medications compared with white participants.157 In DPP, diabetes incidence did not differ significantly according to ethnicity. However, DPP was not powered to assess the significance of effects within the subgroups.206

Baseline obesity. Four trials examined whether weight loss was modified by baseline BMI152,168,169,171 and three found no relationship.152,169,171 One trial's finding that greater weight loss was associated with a higher BMI168 was not replicated in a similar, larger followup trial by the same author, in which the effect of baseline obesity that had been present at 6 months disappeared by 18- and 36-month followup.169 In meta-regression, baseline BMI did not predict effect size in the behavioral trials (p=0.70).

### Pharmacotherapy

All 21 pharmacotherapy trials reported a measure of weight loss, and most also reported one or more other physiologic intermediate health outcomes.142,179-203 Eighteen of the included trials tested the effects of orlistat (n=11,256 randomized to orlistat or placebo treatment arms)180-184,187,189-191,193,194,197-202 and three examined metformin (n=2,652 randomized to orlistat or placebo treatment arms).142,185,186

#### Orlistat

General characteristics of trials. Eighteen trials examined the effect of 120 mg tid of orlistat on some measure of weight over at least 12 to 18 months. One was rated as good quality215 and 17 were rated as fair quality.180-184,187,189-191,193,194,197-202,215 Three of the trials were conducted in primary care settings.181,189,209 Three additional studies were possibly conducted in primary care.180,187,215 The role of the primary care provider was not described in any study. Five trials were conducted in the United States,182,189-191,197 but only one study was conducted in a U.S. primary care setting.189 This fair-quality study suffered from higher attrition in the control group (43 percent) compared with the orlistat group (28 percent) at 12 months.189

The orlistat data were limited in that there was only one good-quality trial.215 All of the remaining trials were rated as fair quality. The most common defect was a high attrition rate. Only five studies had greater than 80 percent followup at 12 to 18 months (followup ranged from 61 to 96 percent among all orlistat trials).189,191,199,202,215 Followup in the control group was often more than 10 percent lower than in the orlistat group.189,191,199,202 In addition, randomization procedures (including allocation concealment) and medication adherence rates were rarely reported.

Participants in the orlistat studies were required to have a BMI of at least 28 to 30 kg/m^2^. Participants with at least one established or subclinical risk factor were allowed to have a minimum BMI in the overweight (27 to 28 kg/m^2^)180,181,187,191,197,209 to obese range (at least 30 kg/m^2^).183,201,202,215 In studies of unselected or low-risk populations, a minority of trials required a BMI of at least 30 kg/m^2^.182,184,189 The remaining trials required a BMI of at least 28 kg/m^2^.190,193,199,200 Participants overall were moderately obese, with a weighted average baseline BMI of 36.1 kg/m^2^ (range, 32 to 38 kg/m^2^) across all trials.

Nonwhite Americans were not highly represented in the included trials. Only eight of 18 trials (including all of the U.S. trials) reported the percentage of nonwhite participants.180,182,184,189-191,197,215 The weighted average percent of nonwhite participants was 12.3 percent among the eight trials reporting ethnicity (range, 0 to 19.2 percent). All studies included both men and women.

The weighted average percent of female participants in all trials was 65.9 percent (range, 45 to 88 percent). The age ranges were wide in most of the trials. Thirteen trials included participants ages 18 to at least 60 years.181,182,184,187,189-191,193,194,198-200,215 The remaining five trials included participants ages 30 to 40 years to at least 60 years.180,183,197,201,202 The average age of participants ranged from 41 to 59 years and the overall weighted average age of the entire group was 46.2 years.

The trials were conducted in a range of participants, from those who were healthy to those with multiple risk factors. Seven of the trials were conducted in overweight and obese participants who did not necessarily have a cardiovascular risk factor.182,184,189,190,193,199,200 Six trials were conducted in overweight and obese subjects with diabetes180,187,191,197,215 or prediabetes (IGT or IFG).202 One included only obese participants with dyslipidemia.183 Four additional trials were conducted in overweight and obese participants who had at least one cardiovascular risk factor.181,194,198,201

One trial implemented a 6-month, very low calorie diet (VLCD) with the requirement that overweight and obese participants lose at least 6 percent of their body weight prior to entry in the orlistat phase of the trial.190 This study was considered a weight maintenance trial. Only 55 percent of the participants from the weight loss phase of the trial were entered into the randomized weight maintenance phase of the trial.

The majority (64.7 percent) of the weight loss studies (not counting the weight maintenance trial) used a pretrial run-in period prior to randomization to orlistat or placebo. The duration of the run-in period ranged from 2 to 5 weeks. To be randomized, participants often needed to meet a certain level of compliance with the medication and/or behavioral component and/or a prespecified degree of weight loss during the run-in period. Seventy-five to 98 percent of the participants successfully fulfilled the run-in requirements.

All of the studies applied some dietary education and/or behavioral therapy to both the orlistat and placebo groups. Almost all trials prescribed a low-calorie diet, and 10 of 18 trials reported that a physical activity recommendation was given to participants.180,182,183,189,194,197,198,201,202,215 Fourteen trials provided enough detail to ascertain the intensity of their behavioral intervention, and they were all rated as having an “intense” behavioral intervention (i.e., monthly to quarterly dietary reinforcement, with or without behavioral modification, combined with monthly to quarterly weigh-ins). While all 18 studies prescribed 120 mg tid of orlistat, three trials (two weight loss trials and one maintenance trial) randomized additional intervention groups to smaller doses of orlistat (30 or 60 mg tid).189,190,199

No trials examined whether treatment effects were maintained after medication was discontinued; however, two trials provided data on the effects of longer-term (beyond 12 to 18 months) orlistat treatment on intermediate health outcomes.198,199 One trial examined the effects of orlistat over 24 months in an unselected overweight and obese population in Europe.199 The other examined 36 months of orlistat treatment in obese Scandinavians following a pretrial 8-week VLCD.198 We did not include long-term data from two additional trials189,202 because there was high attrition at 2 to 4 years (41 to 43 percent followup at 2 to 4 years); however, 12-month data from these studies were included.

Weight loss. Treatment with orlistat resulted in more weight loss than treatment with placebo. All 18 trials of orlistat reported some measure of weight loss over 12–18 months (N=11,256). Of these, 17 addressed weight loss,180-184,187,189,191,193,194,197-202,215 and one addressed weight maintenance.190 Twelve of the 17 weight loss trials could be combined into a meta-analysis (n=5,190).181-183,187,189,191,193,194,197,199,201,215 Overweight and obese participants who were randomized to orlistat lost an average of 3 kg more than those randomized to placebo after 12 months (WMD, -3.0 [95% CI, -3.9 to -2.0]; I^2^=84.9%; k=12) (Figure 2). With one exception,215 the studies were not highly variable, with 1.0 to 3.8 kg more lost in the orlistat group compared with the placebo group. The outlier study was the only good-quality study. In this study, obese participants with uncontrolled diabetes who were randomized to orlistat lost nearly 7 kg more than those given placebo.215 In terms of overall weight loss, most trials reported a weight loss of 6 to 9 kg among those taking orlistat compared with 3 to 6 kg in those taking placebo. Five orlistat weight loss trials could not be included in the meta-analysis (Table 10),180,184,198,200,202 including one of the largest and better conducted studies,202 but these studies generally confirmed the meta-analysis results. The only trial conducted in a U.S. primary care setting had very similar results to the other trials, showing a weight loss of 7 kg in those taking orlistat and 4 kg in those taking placebo.189

Table 10 Trials Not Included in Meta-Analysis: Weight Loss in Medication Trials, 12- to 18-Month Outcomes

Study | Population risk status (risk group) | Behavioral intervention intensity | N | Weight loss (kg)
Orlistat trials
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109 | Mean (SD) at baseline, % change at 12 mo
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109 | | BL | 12 mo
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109 | IG | 95.3 (12.6) | -5.0
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109 | CG | 95.7 (12.5) | -1.8
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | Mean (SD) at baseline, % change at 12 mo
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | | BL | 12 mo
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | IG | 110.4 (16.3) | -10.6
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | CG | 110.6 (16.5) | -6.2
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | Mean (SD) at baseline, mean change at 18 mo
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | | -2 mo^*^ | BL | 18 mo
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | IG | 110.7 (17.9) | -14.5 | -11.7
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | CG | 111.9 (16.0) | -14.3 | -9.6
Finer 2000^184^ | Unselected/low risk | NR | IG: 114 CG: 114 | Mean (SD) at baseline, % change at 12 mo
Finer 2000^184^ | Unselected/low risk | NR | IG: 114 CG: 114 | | BL | 12 mo
Finer 2000^184^ | Unselected/low risk | NR | IG: 114 CG: 114
Finer 2000^184^ | Unselected/low risk | NR | IG: 114 CG: 114 | IG | 97.9 (12.9) | -3.29
Finer 2000^184^ | Unselected/low risk | NR | IG: 114 CG: 114 | CG | 98.4 (15.0) | -1.31
Sjostrom 1998^200^ | Unselected/low risk | NR | IG: 345 CG: 343 | Mean (range) at baseline, mean change at 12 mo
Sjostrom 1998^200^ | Unselected/low risk | NR | IG: 345 CG: 343 | | BL | 12 mo
Sjostrom 1998^200^ | Unselected/low risk | NR | IG: 345 CG: 343
Sjostrom 1998^200^ | Unselected/low risk | NR | IG: 345 CG: 343 | IG | 99.1 (61.0-148.6) | -10.3 †
Sjostrom 1998^200^ | Unselected/low risk | NR | IG: 345 CG: 343 | CG | 99.8 (64.2-137.2) | -6.1
Maintenance trial
Hill 1999^190^ | Unselected/low risk | Intense | IG: 181 CG: 188 | Mean (SE) at -6 mo, mean change (SE) from -6 mo to baseline and 12 mo
Hill 1999^190^ | Unselected/low risk | Intense | IG: 181 CG: 188 | | -6 mo^*^ | BL | 12 mo
Hill 1999^190^ | Unselected/low risk | Intense | IG: 181 CG: 188
Hill 1999^190^ | Unselected/low risk | Intense | IG: 181 CG: 188 | IG | 89.7 (0.9) | -9.86 (0.27) | -7.24 (0.52)
Hill 1999^190^ | Unselected/low risk | Intense | IG: 181 CG: 188 | CG | 90.8 (0.9) | -10.33 (0.31) | -5.93 (0.69)

* Before a very low calorie diet.

† Change in weight at 12 months is measured from the start of the 4-week run-in period.

Bold=statistically significant difference between intervention and control groups.

Abbreviations: BL=baseline; CG=control group; IG=intervention group; mo=month; NR=not reported; SD=standard deviation; SE=standard error.

Visual inspection of the forest plots suggests that weight loss did not vary by risk status. This impression was confirmed by a meta-regression of all medication trials, controlling for medication type (samples with cardiovascular risk factors vs. unselected or low-risk samples; p=0.75).

In 13 of 18 studies, the probability of losing 5 percent of one's initial weight was evaluated.180-182,184,187,189,191,193,194,197,198,200,202 Overweight and obese participants who were randomized to orlistat had a 1.6-fold greater chance of losing 5 percent of their initial weight than those who were randomized to placebo (RR, 1.57 [95% CI, 1.40 to 1.75]; I^2^= 76.2%; k=13; n=8,579) (Figure 3). This is an absolute risk difference of 19 percentage points, which translates into a NNT benefit of 5 (RD, 0.19 [95% CI, -0.05 to 0.43]). The relatively high statistical heterogeneity is likely due to one trial with a substantially larger risk reduction than the other trials.180 The reason for the higher risk reduction in this trial is not clear, although there was a particularly low rate of 5 percent weight loss in the placebo group. The probability of losing 10 percent of one's initial weight was about 2 times greater in overweight and obese patients receiving orlistat compared with placebo (RR, 1.99 [95% CI, 1.69 to 2.35]; I^2^=49.2%; k=11; n=7,500) (Figure 4). The absolute risk difference was 12 percentage points, which translates into a NNT benefit of 8 (RD, 0.12 [95% CI, -0.05 to 0.29]). Based on average baseline and posttreatment weight, the orlistat trials reported an average weight loss of 5 percent in the placebo groups and 8 percent in the orlistat groups.

No trials screened consecutive patients in primary care practices. Three studies identified potentially eligible participants through medical records or disease registries, and then invited them for further screening. Two found that orlistat was associated with more weight loss than placebo,200,215 but the other did not.183

Dose effects. Different dosages were compared in two weight loss trials and in the maintenance trial. In the two weight loss trials, weight loss in both the 60 mg and 120 mg tid dosage groups was greater than in the placebo groups.189,199 Neither trial tested for group differences between the 60 mg and 120 mg groups, but absolute weight loss appeared very similar; those in the 60 mg tid groups lost 7.1^189^ and 6.6 kg199 compared with 7.9 and 7.4 kg in the 120 mg tid groups. In the maintenance trial of orlistat after a VLCD, only overweight and obese participants who took orlistat 120 mg tid (not 30 or 60 mg tid) had a statistically significant smaller weight regain than placebo over 12 months.190

Long-term weight loss. According to two trials, weight loss was maintained in the longer term (24 to 36 months) with continued treatment (Table 11).198,199 Overweight and obese participants who were randomized to orlistat lost 2 to 3 kg more than those receiving placebo in both trials.198,199 The amount of weight loss at 24 to 36 months was not greater, and perhaps a bit less, than at 12 months, although statistical testing of weight loss between the time points was not conducted. No trials reported long-term outcomes after an intervention had ended.

Table 11 Longer-Term Outcomes, Medication Trials

Study | Time to followup (mo) | Weight loss (kg) | | | Cholesterol (mg/dL) | | | Blood Pressure (mmHg) | | | | Glucose tolerance
Orlistat
Richelsen 2007^198^ | 36 | Mean (SD) at baseline, mean change at 36 mo | | | Mean (SD) at baseline, mean change at 36 mo | | | Mean (SD) at baseline, mean change at 36 mo | | | | Mean (SD) at baseline, mean change at 36 mo
Richelsen 2007^198^ | 36 | | -2 mo | 36 mo | | -2 mo | 36 mo | | -2 mo | 36 mo | | | -2 mo | 36 mo
Richelsen 2007^198^ | 36
Richelsen 2007^198^ | 36 | IG | 110.7 (17.9) | -9.4 | LDL cholesterol | | | Systolic blood pressure | | | | Hemoglobin A _1C_ (%)
Richelsen 2007^198^ | 36 | CG | 111.9 (16.0) | -7.2 | IG | 143.2 (40.2) | -13.1 | IG | 144 (19.3) | -7.8 | | IG | 6.32 (0.93) | -0.69
Richelsen 2007^198^ | 36 | | | | CG | 145.6 (36.3) | -14.7 | CG | 144 (17.3) | -8.2 | | CG | 6.28 (0.64) | -0.51
Richelsen 2007^198^ | 36 | | | | HDL cholesterol | | | Diastolic blood pressure | | | | Fasting glucose (mg/dL)
Richelsen 2007^198^ | 36 | | | | IG | 43.6 (10.0) | 1.5 | IG | 90.8 (11.6) | -3.7 | | IG | 116.0 (33.0) | -8.8
Richelsen 2007^198^ | 36 | | | | CG | 44.4 (10.0) | 2.3 | CG | 90.7 (10.4) | -4.7 | | CG | 113.0 (27.8) | -5.8
Rossner 2000^199^ | 24 | Mean (SD) at baseline, mean change (SD) from -4 weeks | | | Mean (SD) at baseline and 24 mo | | | Mean (SD) at baseline and 24 mo | | | | Mean (SD) at baseline and 24 mo
Rossner 2000^199^ | 24 | | BL | 24 mo | | BL | 24 mo | | BL | 24 mo | | | BL | 24 mo
Rossner 2000^199^ | 24
Rossner 2000^199^ | 24 | IG | 96.7 (13.8) | -7.4 (7.1) | Total cholesterol | | | Systolic blood pressure | | | | Fasting glucose (mg/dL)
Rossner 2000^199^ | 24 | CG | 97.7 (14.6) | -4.3 (7.4) | IG | 203.1 (37.5) | 204.2 (37.1) | IG | 125.5 (14.9) | 124.9 (16.5) | | IG | 98.6 (12.3) | 99.3 (23.2)
Rossner 2000^199^ | 24 | | | | CG | 209.7 (44.0) | 221.6 (40.2) | CG | 127.3 (16.1) | 128.5 (17.5) | | CG | 100.2 (17.1) | 99.8 (12.3)
Rossner 2000^199^ | 24 | | | | LDL cholesterol | | | Diastolic blood pressure
Rossner 2000^199^ | 24 | | | | IG | 132.8 (33.2) | 134.4 (33.6) | IG | 79.5 (9.4) | 79.9 (9.5)
Rossner 2000^199^ | 24 | | | | CG | 137.1 (37.8) | 147.9 (35.1) | CG | 81.2 (9.8) | 81.2 (9.9)
Rossner 2000^199^ | 24 | | | | HDL cholesterol
Rossner 2000^199^ | 24 | | | | IG | 45.2 (11.6) | 49.8 (12.4)
Rossner 2000^199^ | 24 | | | | CG | 45.2 (13.9) | 51.4 (13.1)
Metformin
DPP 2005^212^ | 34 | Mean (SD) at baseline, mean change at 34 mo | | | Mean (SD) at baseline, % change at 36 mo | | | Mean (SD) at baseline, mean change (SE) at 24, 36 mo | | | | NR
DPP 2005^212^ | 34 | | BL | 34 mo | | BL | 36 mo | | BL | 24 mo | 36 mo | NR
DPP 2005^212^ | 34 | | | | | | | | | | | NR
DPP 2005^212^ | 34 | IG | 94.3 (19.9) | -2.1 | LDL cholesterol | | | Systolic blood pressure | | | | NR
DPP 2005^212^ | 34 | CG | 94.3 (20.2) | -0.1 | IG | 123.6 | -0.3 | IG | 124.0 (14.9) | -0.94 (0.4) | -0.29 (0.5) | NR
DPP 2005^212^ | 34 | | | | CG | 123.6 | -1.3 | CG | 123.5 (14.4) | -0.52 (0.4) | -0.57 (0.5) | NR
DPP 2005^212^ | 34 | | | | HDL cholesterol | | | Diastolic blood pressure | | | | NR
DPP 2005^212^ | 34 | | | | IG | -- | -0.008 | IG | 78.2 (9.5) | -1.06 (0.2) | -1.59 (0.3) | NR
DPP 2005^212^ | 34 | | | | CG | -- | -0.002 | CG | -78.0 (9.2) | -1.07 (0.2) | -1.88 (0.3) | NR

Bold=statistically significant difference between intervention and control groups.

Abbreviations: BL=baseline; CG=control group; DPP=Diabetes Prevention Program; HDL=high-density lipoprotein; IG=intervention group; LDL=low-density lipoprotein; mo=month; NR=not reported; SD=standard deviation; SE=standard error.

Maintenance of weight loss. One trial found that orlistat was helpful in maintaining the weight loss that occurred during a 6-month VLCD combined with an intensive behavioral intervention, which led to an average weight loss of 10 kg.190 By 12 months followup, those who were randomized to 120 mg tid of orlistat regained 2.7 kg compared with 4.4 kg in those taking placebo, which was statistically significant.190 Only 55.5 percent of participants who started the VLCD were ultimately randomized to orlistat or placebo.

Effect of orlistat on other measures of adiposity. Orlistat was generally associated with a decrease in waist circumference, although data were somewhat mixed. Twelve trials reported the effects of orlistat on waist circumference.180,181,183,187,191,193,194,198,199,201,202,215 Seven studies could be combined by meta-analysis.180,183,187,191,193,201,215 Waist circumference declined 2.3 cm more in participants taking orlistat compared with placebo over 12 to 18 months (WMD, -2.3 [95% CI, -3.6 to -0.9]; k=7; I^2^=87.7%; n=2,227) (Figure 5).

The pooled data on waist circumference were quite heterogeneous (I^2^=87.7%), as were the results from studies that could not be pooled (Table 12). The main outlier was a good-quality trial that reported a decrease in waist circumference of 5 cm more in participants with diabetes taking orlistat compared with those taking placebo.215 Among the 12 trials, there was an absolute 5 to 7 cm decline in waist circumference in those taking orlistat compared with a 2 to 6.5 cm decline in the placebo groups. No trials reported WHR.

Table 12 Trials Not Included in Meta-Analysis: Central Adiposity in Orlistat Trials, 12- to 18-Month Outcomes

Study | Population risk status (risk group) | Behavioral intervention intensity | N | Waist circumference (cm)
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | Mean (SD) at baseline,mean change (SD) at 12 mo
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | | BL | | 12 mo
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | IG | 107.8 (15.6) | | -5.99 (--)
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | CG | 108.6 (16.4) | | -2.60 (--)
Lindgarde 2000^194^ | Multiple risk factors | Intense | IG: 190 CG: 186 | Mean (SD) at -2 weeks, mean change (SD) from -2 weeks at baseline and 12 mo
Lindgarde 2000^194^ | Multiple risk factors | Intense | IG: 190 CG: 186 | | -2 wk^*^ | BL | 12 mo
Lindgarde 2000^194^ | Multiple risk factors | Intense | IG: 190 CG: 186
Lindgarde 2000^194^ | Multiple risk factors | Intense | IG: 190 CG: 186 | IG | 106 (10.8) | -- | -4.8 (--)
Lindgarde 2000^194^ | Multiple risk factors | Intense | IG: 190 CG: 186 | CG | 106 (11.0) | -- | -4.1 (--)
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | Mean (SD) at baseline,mean change at 12 mo
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | | BL | | 12 mo
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | IG | 115.0 (10.4) | | -9.6
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | CG | 115.4 (10.4) | | -7.0
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | Mean(SD) at -2 mo, mean change at baseline and 18, 36 mo
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | | -2 mo | BL | 12 mo | 18 mo | 36 mo
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | IG | 119 (12.1) | -12 | -- | -12 | -7.7
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | CG | 119 (10.9) | -12 | -- | -9 | -5.4
Rossner 2000^199^ | Unselected/low risk | Intense | IG: 244 CG: 243 | Mean (SD) at baseline, mean change (SD) at 12 mo
Rossner 2000^199^ | Unselected/low risk | Intense | IG: 244 CG: 243 | | BL | | 12 mo
Rossner 2000^199^ | Unselected/low risk | Intense | IG: 244 CG: 243
Rossner 2000^199^ | Unselected/low risk | Intense | IG: 244 CG: 243 | IG | -- | | -6.2
Rossner 2000^199^ | Unselected/low risk | Intense | IG: 244 CG: 243 | CG | -- | | -4.7
Maintenance trial
Hill 1999^190^ | Unselected/low risk | Intense | IG: 181 CG: 188 | Reduced in 4 treatment groups during run-in weight loss phase. During 1-year treatment period, waist circumference increased slightly in all groups, and the resulting mean reductions (6 to 8 cm) after 1 year of treatment were not significantly different.

* Before a very low calorie diet.

Bold=statistically significant difference between intervention and control groups.

Abbreviations: BL=baseline; CG=control group; IG=intervention group; mo=month; NR=not reported; SD=standard deviation.

Effect of orlistat on lipid levels. Orlistat was associated with a greater decrease in total and LDL cholesterol than placebo, but also a decrease in HDL cholesterol. Triglycerides were not affected. All 18 trials examined the effect of orlistat on at one least lipid measure. Twelve of the weight loss trials had data that could be combined in meta-analyses.180,183,184,187,189,191,194,197,199-201,215 Overweight and obese participants in the orlistat group had a 12.6 mg/dL greater decline in total cholesterol (95% CI, -17.0 to -8.2; I^2^=84.1%; k=12; n=4,213) (Figure 6), 11.4 mg/dL greater decline in LDL cholesterol (95% CI, -15.8 to -7.0; I^2^=86.3%,;k=12; n=4,213) (Figure 7), and 0.9 mg/dL greater decline in HDL cholesterol (95% CI, -1.7 to -0.1; I^2^=58.0%; k=12; n=4,213) (Figure 8) compared with placebo over 12 to 18 months. Triglycerides did not change differently between groups (WMD, -4.8 [95% CI, -10.4 to 0.7]; I^2^=80.1%,;k=10; N=3,626) (Figure 9). The five weight loss trials that measured lipid levels but could not be included in the meta-analyses reported similar results (Table 13).181,182,193,198,202 Additionally, the trial of weight maintenance showed greater improvement in total and LDL cholesterol in participants taking any dose of orlistat, but minimal effect on HDL cholesterol and triglycerides.190 Two studies examined the effects of orlistat on the use of lipid-lowering medications and did not find any differences between groups.198,201

Table 13 Trials Not Included in Meta-Analysis: Lipids Data in Orlistat Trials, 12- to 18-Month Outcomes

Study | Population risk Status (risk group) | Behavioral intervention intensity | N | Total cholesterol, HDL, LDL, and triglyceride outcomes (mg/dL)
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | Mean (SD) at baseline, mean change (SD) at 12 mo
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | | BL | | 12 mo
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | Total cholesterol
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | IG | 223.9 (42.5) | | -4.6 (--)
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | CG | 220.1 (38.6) | | 6.2 (--)
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | HDL holesterol
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | IG | 54.1 (15.4) | | --
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | CG | 54.1 (11.6) | | --
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | LDL cholesterol
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | IG | 146.7 (34.7) | | -11.6 (--)
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | CG | 146.7 (34.7) | | -0.7 (--)
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | Triglycerides
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | IG | 159.3 (70.8) | | 38.9
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | CG | 168.2 (88.5) | | 15.0
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | Mean (SD) at baseline, % mean change at 12 mo
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | | BL | | 12 mo
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | Total cholesterol
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | IG | 223.9 (38.6) | | -8.8
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | CG | 223.9 (38.6) | | -1.3
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | HDL cholesterol
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | IG | 46.3 (11.6) | | 3.4
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | CG | 46.3 (11.6) | | 8.5
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | LDL cholesterol
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | IG | 142.9 (34.7) | | -11.4
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | CG | 146.7 (34.7) | | -1.6
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | Triglycerides
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | IG | 168.2 (88.5) | | -6.2
Torgerson 2004^202^ | Diabetes | Intense | IG: 1650 CG: 1655 | CG | 168.2 (106.2) | | -6.3
Richelsen 2007^198^ | Prediabetes/hypertension | Intense | IG: 153 CG: 156 | Mean (SD) at -2 mo, mean change at baseline and 18 mo
Richelsen 2007^198^ | Prediabetes/hypertension | Intense | IG: 153 CG: 156 | | -2 mo^*^ | BL | 18 mo
Richelsen 2007^198^ | Prediabetes/hypertension | Intense | IG: 153 CG: 156
Richelsen 2007^198^ | Prediabetes/hypertension | Intense | IG: 153 CG: 156 | Total cholesterol
Richelsen 2007^198^ | Prediabetes/hypertension | Intense | IG: 153 CG: 156 | IG | 228.2 (48.6) | -46.3 | -13.9
Richelsen 2007^198^ | Prediabetes/hypertension | Intense | IG: 153 CG: 156 | CG | 232.4 (41.7) | -46.3 | -5.0
Richelsen 2007^198^ | Prediabetes/hypertension | Intense | IG: 153 CG: 156 | HDL cholesterol
Richelsen 2007^198^ | Prediabetes/hypertension | Intense | IG: 153 CG: 156 | IG | 43.6 (10.1) | -1.9 | 2.3
Richelsen 2007^198^ | Prediabetes/hypertension | Intense | IG: 153 CG: 156 | CG | 44.4 (10.0) | -2.7 | 4.2
Richelsen 2007^198^ | Prediabetes/hypertension | Intense | IG: 153 CG: 156 | LDL cholesterol
Richelsen 2007^198^ | Prediabetes/hypertension | Intense | IG: 153 CG: 156 | IG | 143.2 (40.2) | -29.0 | -11.2
Richelsen 2007^198^ | Prediabetes/hypertension | Intense | IG: 153 CG: 156 | CG | 145.6 (36.3) | -30.9 | -4.6
Richelsen 2007^198^ | Prediabetes/hypertension | Intense | IG: 153 CG: 156 | Triglycerides
Richelsen 2007^198^ | Prediabetes/hypertension | Intense | IG: 153 CG: 156 | IG | 208.9 (109.7) | -78.8 | -28.3
Richelsen 2007^198^ | Prediabetes/hypertension | Intense | IG: 153 CG: 156 | CG | 221.3 (124.8) | -83.2 | -30.1
Davidson 1999^182^ | Unselected/low risk | Intense | IG: 668 CG: 224 | IG had greater reductions than CG; p<0.05 for LDL and total cholesterol (data shown in figure only)
Krempf 2003^193^ | Unselected/low risk | Intense | IG: 346 CG: 350 | Proportion of patients (%) at baseline and 18 mo
Krempf 2003^193^ | Unselected/low risk | Intense | IG: 346 CG: 350 | | BL | 18 mo
Krempf 2003^193^ | Unselected/low risk | Intense | IG: 346 CG: 350
Krempf 2003^193^ | Unselected/low risk | Intense | IG: 346 CG: 350 | Total cholesterol reduced by ≥20%
Krempf 2003^193^ | Unselected/low risk | Intense | IG: 346 CG: 350 | IG | -- | | 10.1
Krempf 2003^193^ | Unselected/low risk | Intense | IG: 346 CG: 350 | CG | -- | | 2.6
Krempf 2003^193^ | Unselected/low risk | Intense | IG: 346 CG: 350 | LDL cholesterol reduced by ≥20%
Krempf 2003^193^ | Unselected/low risk | Intense | IG: 346 CG: 350 | IG | -- | | 19.9
Krempf 2003^193^ | Unselected/low risk | Intense | IG: 346 CG: 350 | CG | -- | | 6.6

* Before a very low calorie diet.

Bold=statistically significant difference between intervention and control groups.

Abbreviations: BL=baseline; CG=control group; HDL=high-density lipoprotein; IG=intervention group; LDL=low-density lipoprotein; mo=month; NR=not reported; SD=standard deviation.

Only one trial recruited participants with dyslipidemia.183 Obese participants in this study who received orlistat showed greater declines in LDL and total cholesterol, but did not have a greater change in triglycerides or HDL cholesterol compared with placebo.183 In the intervention group, LDL cholesterol declined by 37 mg/dL (vs. 24 mg/dL in placebo group) and total cholesterol declined by 39 mg/dL (vs. 32 mg/dL in placebo group). In the one study that examined the subgroup of participants with dyslipidemia, overweight and obese participants who received orlistat had a significant decrease in total and LDL cholesterol but experienced no change in HDL cholesterol compared with the placebo group.181 This result was similar to the study's findings for the entire population.181

Only two trials reported long-term effect of orlistat treatment (>12 to 18 months) on lipid levels (Table 11).198,199 One trial found group differences in the longer term (LDL and total cholesterol)199 and one did not (LDL cholesterol).198 The latter trial also reported no differences at 12 months.

Effect of orlistat on blood pressure. Orlistat treatment was associated with a decrease in blood pressure compared with placebo. Fourteen of 18 RCTs of orlistat evaluated blood pressure.180-183,187,189,190,197-202,209 Seven of the weight loss trials could be included in a meta-analysis.182,189,197,199-201,209 Participants who were randomized to orlistat had a 2.0 mm Hg greater decline in SBP (WMD, -2.0 [95% CI, -3.1 to -1.0]; I^2^=0.0%, k=7; n=3,683) (Figure 10) and a 1.3 mm Hg greater decline in DBP (WMD, -1.3 [95% CI, -2.5 to -0.2]; I^2^=52.2%; k=6; n=3,179) (Figure 11) after 12 to 18 months compared with those given placebo.

Five trials, including one of the largest and better conducted trials,202 measured blood pressure but could not be included in the meta-analysis (Table 14).180,181,187,198,202 They supported the meta-analysis results in that they all reported no or small changes in blood pressure.

Table 14 Trials Not Included in Meta-Analysis: Changes in Blood Pressure in Orlistat Trials, 12- to 18-Month Outcomes

Study | Population risk status (risk group) | Behavioral intervention intensity | N | Blood pressure (mmHg)
Broom, 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | Mean (SD) at baseline, mean change at 12 mo
Broom, 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | | BL | 12 mo
Broom, 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266
Broom, 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | Systolic blood pressure
Broom, 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | IG | 141.1 (15.0) | -6.0
Broom, 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | CG | 139.2 (15.7) | -2.3
Broom, 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | Diastolic blood pressure
Broom, 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | IG | 89.0 (9.7) | -5.5
Broom, 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | CG | 88.1 (10.1) | -3.1
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109 | Mean (SD) at baseline, mean change at 12 mo
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109 | | BL | 12 mo
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109 | Systolic blood pressure
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109 | IG | 145.0 (18.2) | -3.2
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109 | CG | 145.0 (16.1) | -3.1
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109 | Diastolic blood pressure
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109 | IG | 84.5 (9.7) | -2.4
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109 | CG | 84.3 (10.0) | -1.9
Hanefeld 2002^187^ | Diabetes | Intense | IG: 195 CG: 188 | Mean (SD) at baseline, mean change at 12 mo
Hanefeld 2002^187^ | Diabetes | Intense | IG: 195 CG: 188 | | BL | 12 mo
Hanefeld 2002^187^ | Diabetes | Intense | IG: 195 CG: 188
Hanefeld 2002^187^ | Diabetes | Intense | IG: 195 CG: 188 | Systolic blood pressure
Hanefeld 2002^187^ | Diabetes | Intense | IG: 195 CG: 188 | IG | 148.0 (20.4) | -4.96
Hanefeld 2002^187^ | Diabetes | Intense | IG: 195 CG: 188 | CG | 147.9 (17.8) | -4.98
Hanefeld 2002^187^ | Diabetes | Intense | IG: 195 CG: 188 | Diastolic blood pressure
Hanefeld 2002^187^ | Diabetes | Intense | IG: 195 CG: 188 | IG | 87.0 (10.8) | -4.78
Hanefeld 2002^187^ | Diabetes | Intense | IG: 195 CG: 188 | CG | 87.2 (10.7) | -4.80
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | Mean (SD) at baseline, mean change at 18 mo
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | | -2 mo^*^ | BL | 18 mo
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | Systolic blood pressure
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | IG | 144 (19.3) | -13 | -8.2
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | CG | 144 (17.3) | -12 | -7.2
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | Diastolic blood pressure
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | IG | 90.8 (11.6) | -7.2 | -5.1
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | CG | 90.7 (10.4) | -7.6 | -4.8
Torgerson 2004^202^ | Prediabetes | Intense | IG: 1650 CG: 1655 | Mean (SD) at baseline, mean change at 12 mo
Torgerson 2004^202^ | Prediabetes | Intense | IG: 1650 CG: 1655 | | BL | 12 mo
Torgerson 2004^202^ | Prediabetes | Intense | IG: 1650 CG: 1655
Torgerson 2004^202^ | Prediabetes | Intense | IG: 1650 CG: 1655 | Systolic blood pressure
Torgerson 2004^202^ | Prediabetes | Intense | IG: 1650 CG: 1655 | IG | 130.8 (15.8) | -7.3
Torgerson 2004^202^ | Prediabetes | Intense | IG: 1650 CG: 1655 | CG | 130.4 (15.4) | -5.2
Torgerson 2004^202^ | Prediabetes | Intense | IG: 1650 CG: 1655 | Diastolic blood pressure
Torgerson 2004^202^ | Prediabetes | Intense | IG: 1650 CG: 1655 | IG | 82.0 (10.0) | -3.6
Torgerson 2004^202^ | Prediabetes | Intense | IG: 1650 CG: 1655 | CG | 82.3 (10.0) | -2.6

* Before a very low calorie diet.

Bold=statistically significant difference between intervention and control groups.

Abbreviations: BL=baseline; CG=control group; IG=intervention group; mo=month; NR=not reported; SD=standard deviation.

There were little data about the effect of orlistat on persons with hypertension. No trials evaluated only participants with hypertension. One trial examined separately the 43 percent of participants with hypertension at baseline and found no treatment effect.181 Two studies examined the effects of orlistat on the use of blood pressure medications with conflicting results.198,201

There was also very little data on the long-term effect of orlistat on blood pressure. Two studies had longer-term followup (Table 11).198,199 Neither study found that long-term orlistat use was associated with a greater decrease in blood pressure compared with placebo. However, neither study had found a difference in blood pressure in the treatment groups at 12 months.198,199 No study evaluated whether the decrease in blood pressure associated with orlistat was maintained after stopping the medication.

Development of diabetes. Limited data suggest that orlistat may be associated with a decreased risk of type 2 diabetes in both low- and high-risk obese individuals. Two of 18 orlistat trials reported the risk of developing new-onset type 2 diabetes.198,202 Both studies were rated as fair quality for attrition issues; one study had 35.3 percent attrition at 36 months198 and the other had somewhat differential attrition (90 percent followup in the orlistat group compared with 77 percent in the placebo group) at 12 months (Table 7).202

The first orlistat trial examined type 2 diabetes risk in obese individuals with an elevated waist circumference and IFG and/or dyslipidemia. To enter into the trial, participants had to lose at least 5 percent of their weight during an 8-week VLCD (600–800 kcal); 80.7 percent of participants were retained after the run-in period. Eight percent of participants who were randomized to orlistat compared with 17 percent of those who were randomized to placebo were newly diagnosed with type 2 diabetes by the final visit at 36 months (p=0.04).198

In the largest trial of orlistat, cumulative incidence of diabetes was reported over 4 years of study followup. Although the study's attrition by 4 years was high (48 and 68 percent in orlistat and placebo groups, respectively), we present these data because they are cumulative (see methods for a full description of quality rating and data abstraction) and because the data on the association between orlistat and diabetes risk are limited. Both high-risk (IGT) and low-risk (normal glucose tolerance) obese populations who received orlistat had a lower incidence of type 2 diabetes compared with those given placebo. In the high-risk population, the cumulative incidence of type 2 diabetes was 19 percent in the orlistat group compared with 29 percent in the placebo group over 4 years. The respective cumulative incidence in the low-risk population was 6 percent versus 17 percent.202 In both studies, participants in the orlistat group lost more weight than those in the control group. However, the relationship between the degree of weight loss with orlistat and the subsequent risk of type 2 diabetes was not evaluated.

Effect of orlistat on glucose tolerance. Orlistat was generally associated with a decrease in fasting glucose level, but with mixed results. Fourteen trials examined the effect of orlistat on fasting glucose in individuals with diabetes and prediabetes and in unselected/low-risk overweight and obese populations.180,181,187,189-191,194,197-202,215 Nine weight loss trials could be combined in a meta-analysis.187,189,191,194,197,199-201,215 Those participants who were randomized to orlistat experienced a 5.7 mg/dL greater reduction in fasting glucose over 12 months compared with those given placebo (95% CI, -8.3 to -3.0; I^2^=79.6%; k=9; n=3,727) (Figure 12). These results were heterogeneous due to different degrees of glucose reduction in participants with diabetes versus those without. When only the four RCTs that recruited individuals with type 2 diabetes were combined,187,191,197,215 overweight and obese individuals with diabetes who were randomized to orlistat had a 12 mg/dL greater decline in fasting glucose level compared with those given placebo (WMD, -12.1 [95% CI, -21.9 to -2.4]; I^2^=86.6%; k=4; n=1,428) (figure not shown), with absolute reductions of up to 36 mg/dL.197

A greater effect of orlistat on glucose reduction in individuals with diabetes compared with those without it was supported by a subgroup analysis in a study of overweight and obese participants with multiple cardiovascular risk factors. The 26 percent of the population with diabetes had a greater decrease in fasting glucose (-29.4 vs. +5.0 mg/dL for orlistat compared with placebo) compared with the entire population (-9.9 vs. -1.6 mg/dL for orlistat compared with placebo), although this interaction was not statistically tested.209 A second study suggested that these effects do not extend to individuals with prediabetes. The small subgroup with IGT (17 percent [n=125]) did not have a greater improvement in fasting glucose compared with the whole population.181

The five orlistat trials that were not included in the meta-analysis were heterogeneous, but generally showed that orlistat improved fasting glucose levels with a similar effect size as the meta-analysis, with the largest effect seen in the trial of patients with diabetes (Table 15).180,181,190,198,202

Table 15 Trials Not Included in Meta-Analysis: Changes in Glucose Tolerance in Medication Trials, 12- to 18-Month Outcomes

Study | Population risk Status (risk group) | Behavioral intervention intensity | N | Glucose tolerance
Orlistat trials
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | Mean (SD) at baseline, mean change at 12 mo
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | | BL | 12 mo
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | Fasting glucose (mg/dL)
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | IG | -- | -3.4
Broom 2002^181^ | Multiple risk factors | NR | IG: 265 CG: 266 | CG | -- | 1.1
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109 | Mean (SD) at baseline, mean change at 12 mo
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109 | | BL | 12 mo
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109 | Fasting glucose (mg/dL)
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109 | IG | 201.8 (46.9) | -34.2
Berne 2004^180^ | Diabetes | Intense | IG: 111 CG: 109 | CG | 196.4 (45.1) | -4.7
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | Mean (SD) at baseline, mean change at 18 mo
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | | -2 mo^*^ | BL | 18 mo
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | Fasting glucose (mg/dL)
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | IG | 116.0 (33.0) | -19.8 | -12.1
Richelsen 2007^198^ | Prediabetes/ hypertension | Intense | IG: 153 CG: 156 | CG | 113.0 (27.8) | -17.1 | -8.1
Torgerson 2004^202^ | Prediabetes | Intense | IG: 1650 CG: 1655 | Mean (SD) at baseline, mean change at 12 mo
Torgerson 2004^202^ | Prediabetes | Intense | IG: 1650 CG: 1655 | | BL | 12 mo
Torgerson 2004^202^ | Prediabetes | Intense | IG: 1650 CG: 1655
Torgerson 2004^202^ | Prediabetes | Intense | IG: 1650 CG: 1655 | Fasting glucose (mg/dL)
Torgerson 2004^202^ | Prediabetes | Intense | IG: 1650 CG: 1655 | IG | 82.9 (10.8) | 1.8
Torgerson 2004^202^ | Prediabetes | Intense | IG: 1650 CG: 1655 | CG | 82.9 (10.8) | 3.6
Maintenance trial
Hill 1999^190^ | Unselected/low risk | Intense | IG: 181 CG: 188 | Fasting glucose levels decreased slightly (0.4-1.8 mg/dL) in all groups during the 6-mo run-in period. After 12 mo of treatment, mean increases of 1%-2% above initial values were noted in the CG compared with slight (~1%) reductions in IG, but were not statistically significant.

* Before a very low calorie diet.

Bold=statistically significant difference between intervention and control groups.

Abbreviations: BL=baseline; CG=control group; IG=intervention group; mo=month; NR=not reported; SD=standard deviation.

Orlistat appeared to have a favorable impact on diabetes medication use. Three trials found that orlistat resulted in either a greater discontinuation rate (12 percent) or greater dose reduction than placebo.191,197,201 However, a fourth trial found that orlistat did not affect the use of diabetes medications.187 Neither of the two trials reporting longer-term effects found group differences at 24 to 36 months.198,199

Results in different subgroups. Differences in efficacy between ethnic, sex, or age subgroups could not be determined. No study examined weight loss by ethnicity and the percentage of minorities included in the trials was very small (5.1 to 19.2 percent of the study population in the few studies that reported ethnicity).182,184,189-191,197 No study examined results by sex, age, or baseline BMI. Weight loss with orlistat did not vary by the cardiovascular risk status of the population.

#### Metformin

General characteristics of studies. We included three trials examining the effect of metformin (850 mg twice daily) on weight loss over 12 to 18 months in 2,652 overweight and obese participants selected for prediabetes,142 polycystic ovary syndrome,186 or an elevated WHR.185 None of the studies recruited exclusively from primary care or were conducted in the primary care setting. Only one study, DPP, was conducted in the United States.142 The largest trial (n=2,155 in the metformin and placebo arms), DPP was rated as good quality and was conducted in overweight and obese participants with prediabetes (IFG or IGT).142 The other two trials were rated as fair quality. Neither trial described how treatment allocation was concealed185,186 and one trial also suffered from high attrition: only 70.9 percent had followup at 12 months.185 Although the other fair-quality study had adequate followup, the number of participants was quite small (N=40).186 This small study was also not double blind—the providers were aware of the participants' treatment allocation and the blinding of the outcome assessors was not described.186

All of the studies applied some dietary education and/or behavioral therapy to both the metformin and placebo groups. Only one study specifically prescribed a hypocaloric diet.186 In the other trials, participants were told to follow the NHLBI National Cholesterol Education Program step 1 diet (DPP) or were given dietary advice to reduce insulin resistance.185 Two studies recommended an increase in physical activity,142,185 while the other encouraged participants to continue their usual activities.186 The trials provided enough detail to ascertain the intensity of their behavioral intervention (see methods for definition). One was rated as having an intensive behavioral intervention.186 Participants had monthly meetings and weigh-ins with the dietician.186 In DPP, there was a yearly 20- to 30-minute meeting with a case manager addressing the importance of a healthy lifestyle, so we considered this trial to have a brief behavioral component. We also considered the third study as brief, as there were quarterly weigh-ins with dietary and exercise advice of unclear frequency.185 All three studies prescribed a dose of metformin of 850 mg twice daily.

The second largest trial examined overweight and obese participants with an elevated WHR.185 The two larger trials included both men and women (67 percent female) and the mean age of the population was 50 years.185,212 The final trial was a small study of relatively young (average age, 27 years) overweight and obese women with polycystic ovary syndrome.186 Participants in the studies were required to have a BMI of at least 24^142^ or 28 kg/m^2^ 186 or an elevated WHR (≥0.95 for men; ≥0.80 for women).185 Participants overall were moderately obese, with baseline mean BMI values ranging from 33 to 37 kg/m^2^.

Only one trial, DPP, reported the ethnicity of participants: 54.7 percent were white, 19.9 percent black, 15.7 percent Hispanic, 5.3 percent American Indian, and 4.4 percent Asian/Pacific Islanders.206

No study examined weight loss after stopping metformin or the use of metformin for weight maintenance.

The validity of the meta-analyses were limited by the marked differences in study populations. None of the studies used the same adiposity or risk factor criteria for study entry and had varying baseline demographics. Therefore, we include the metformin trials in Figures 2-12 for comparison purposes, but do not discuss meta-analysis results.

Effect of metformin on weight loss. Metformin treatment generally led to more weight loss than placebo. All three RCTs of metformin reported some measure of weight loss over 12 months.185,186,212 In DPP participants who were randomized to metformin lost 2.7 kg after 12 months, 2.3 kg more than those who were randomized to placebo.212 After 3 years, weight loss was greatest in the older (ages 60 to 85 years) participants, who lost an average of 2.7 kg compared with 1.5 to 1.7 kg in younger age groups. Effect size did not appear to vary by sex, race, or ethnicity, but DPP reported inadequate power to assess subgroup effects.206 A second study examined the effects of metformin in overweight and obese individuals with a high WHR.185 Approximately 22 percent had abnormal glucose tolerance. The metformin group lost 2 kg over 12 months, which was 1.2 kg more than in the placebo group, a nonsignificant difference.185 The final study involved younger overweight and obese women with polycystic ovary syndrome.186 There was no differential weight change between the metformin and placebo groups: both lost 4 to 5 kg. None of the studies examined weight loss of 5 and 10 percent of baseline weight.

Long-term weight loss with metformin. Longer-term metformin treatment (> 12 to 18 months) was associated with greater weight loss than placebo (Table 11). In DPP, overweight and obese participants who were randomized to metformin lost 2.0 kg more after 2.8 years than those in the placebo group. This was similar to the 1-year results of 2.3 kg more than the placebo group.206 Ten-year followup from DPP is reviewed in the discussion section (this 10-year outcomes study did not meet criteria for inclusion in this evidence review).

Effect of metformin on other measures of adiposity. Metformin decreased waist circumference by 1.5 cm compared with placebo in DPP.212 Waist circumference declined more in the oldest age group (-2.8 cm in ages 60 to 85 years vs. -1.2 in ages 25 to 44 years; p<0.001).210 However, there were no group differences in the small trial of patients with polycystic ovary syndrome, in which both groups had 4 to 5 cm declines in waist circumference.186 No trials reported WHR.

Effect of metformin on lipid levels. Twelve months of metformin treatment did not have favorable effects on total, HDL, or LDL cholesterol or triglycerides compared with placebo in the two fair-quality trials.185,186 In DPP, long-term (36 months) metformin treatment led to favorable effects on HDL cholesterol compared with placebo, but the changes in both groups were less than 1 mg/dL (Table 11).207 No trial recruited participants with dyslipidemia at baseline.

Effect of metformin on blood pressure. Metformin treatment did not improve blood pressure outcomes compared with placebo in DPP.207 In DPP and a second trial, blood pressure changes between metformin and placebo groups did not differ by more than 1 mm Hg after 12 to 36 months.185,207 No study recruited participants with elevated blood pressure.

Effect of metformin on diabetes incidence. Data reported in two trials suggest that metformin reduced the risk of developing diabetes (Table 7).185,206 In DPP, overweight and obese participants with IFG or IGT who were randomized to metformin had a reduced cumulative incidence of diabetes after 3 years compared with those given placebo (21.7 vs. 28.9 percent, respectively).206 This absolute risk reduction of 7.2 percentage points translates into a NNT of 14. Ten-year followup from DPP is reviewed in the discussion section (it did not meet inclusion criteria for this evidence review). In DPP, diabetes incidence was marginally lower in the youngest age group in the metformin intervention group compared with the oldest, but this effect disappeared after controlling for baseline glucose levels. There was no difference in diabetes incidence by age in the placebo group.210 Metformin had greater effects in those with lower fasting glucose levels and higher BMI compared with those with higher values for those variables. Treatment effects did not differ significantly according to either sex or ethnicity. However, DPP was not powered to assess the significance of effects within these subgroups.206

A smaller, fair-quality study examined overweight and obese participants with a high WHR, 22 percent of whom also had IGT.185 Five (2.2 percent) overweight and obese participants with prediabetes who were given placebo were diagnosed with diabetes during the study compared with none of those with prediabetes in the metformin group.185 However, diabetes diagnosis was done at the local investigator level, with unclear adjudication.

Effect of metformin on glucose tolerance. Data suggest that metformin may reduce fasting glucose levels. All three trials examined the effect of metformin on fasting glucose. In DPP, participants taking metformin had average reductions of 4.2 mg/dL in fasting glucose level compared with an average 0.6 mg/dL increase in those taking placebo at 12 months.212 Neither of the other two fair-quality trials showed group differences.185,186

Heterogeneity of medication studies (meta-regression analysis). To examine how study characteristics may have influenced the treatment effects of the medications, we performed a meta-regression analysis on the main outcome of weight loss. We examined multiple trial factors, including how many participants returned for followup, the percentage of participants that were retained after a run-in period, whether subjects were self- or study-identified, the intensity of the behavioral component, the role of primary care in the study, whether the study was conducted in the United States, and study quality. Study quality was associated with treatment effect sizes; however, the results should be interpreted with great caution because of the truncated range of study quality—only two of the medication trials were rated as good-quality trials,142,215 both of which had very large effect sizes. Meta-regression also showed that trials which relied on participants to contact the researchers to enroll in the trial (self-identified) had smaller effect sizes than trials which identified potentially eligible participants through medical records or registries (study-identified). However, again, this result should be interpreted very cautiously because this effect was driven primarily by a single trial with a very large effect size;215 the participant identification approach was not statistically significant when this trial was dropped from the analysis. None of the other factors influenced treatment effect size. The characteristics of the participants, including the presence of cardiovascular risk factors, sex, age, and ethnicity, also did not predict effect size for weight loss with medications. The type of medication also did not influence treatment effect size.

## KQs 4 and 4a What Are the Adverse Effects of Primary Care–Relevant Interventions in Obese or Overweight Adults? Are There Differences in Adverse Effects Between Patient Subgroups?

In addition to evaluating all 58 studies from KQs 2 and 3 for harms, we abstracted an additional 12 weight loss studies for harms data (Appendix A).

### Behavioral-Based Interventions

General characteristics of studies. Ten studies reported on possible harms of behavioral weight loss interventions. Six were RCTs from KQs 2 and 3,142,152,160,167,173,175 three were additional published RCTs,128,137,138 and one was a prospective cohort study.135 The three additional trials did not meet inclusion criteria for KQ 3 due to high or differential attrition.

Adverse events. Four fair- to good-quality trials of adults ages 40 to 80 years examined bone density.135,167,173,175 In three studies, weight loss reduced total175or hip bone mineral density (BMD).167,173 In one trial, a small subset of participants (67/975) were studied, and those who lost weight had a greater decrease in total bone density (0.05 percent decrease in BMD per pound of weight lost) at 12 months, although there was not a statistically significant difference between the intervention and control groups. The other two studies noted a decrease in hip (0.9 to 2.4 percent) BMD with 12 months of intervention that was greater than the control condition.167,173 Changes in body weight were correlated with changes in BMD.167,173 A more recent trial reported no change in bone mineral content at any site after a 12-month weight loss program, even among those in the highest tertile of weight loss.135 No study noted a significant decrease in spine BMD.

Four trials reported no serious adverse effects or serious injuries with increased physical activity over 1 to 2 years.128,138,152,160 One trial of only female participants ages 25 to 44 years reported an increase in physical activity- and strength training-related injuries in the intervention group compared with the control group (odds ratio [OR], 4.0 [95% CI, 1.8 to 9.0] and OR, 10.1 [95% CI, 3.0 to 34.2], respectively).138 The cumulative incidence of physical activity- and strength training-related injuries was 46.9 and 33.3 per 100 women, respectively, although the number of participants who lost work time or had to make major changes in daily activities was low (7 percent) and not different from the control group.138

One trial found that participants in the intervention group either showed no difference or greater improvement in eating disorder measures.137

### Pharmacotherapy

#### Orlistat

General characteristics of studies. We included a total of 24 placebo-controlled studies on the harms of orlistat (120 mg tid) and one comparing orlistat with metformin (Table 16).136 Eighteen were RCTs from KQs 2 and 3,180-184,187,189-191,193,194,197-202,215 five were additional published RCTs,126,127,129,130,132 and one was an event monitoring study from the United Kingdom.133 The event monitoring study relied on doctors' retrospective reports of adverse events and had low response rates. We chose to include the study because we wanted to capture rare adverse events that might not be picked up in relatively small RCTs. Of the placebo-controlled RCTs, eight recruited unselected populations129,182,184,189,190,193,199,200 and 15 recruited participants with at least one clinical or subclinical cardiovascular risk factor. 126,127,130,132,180,181,183,187,191,194,197,198,201,202,215

Table 16 Harms Data Summary for Medication Interventions

Risk group | Reference; Medication type; Type of study | # Randomized | Average age (yrs) | % Female | % Nonwhite | Baseline BMI (kg/m^2^) Mean, minimum | Dosage (mg) | Duration (wks)
With cardiovascular risk factors
Diabetes | Berne 2005^180^; Orlistat; RCT | 220 | 59.1 | 45.5 | 0 | 32.7 ≥28 | 120 tid | 52
Diabetes | Derosa 2010^215^; Orlistat; RCT | 254 | 52.5 | 49.6 | 0 | 32.8 ≥30 | 120 tid | 52
Diabetes | Hanefeld 2002^187^; Orlistat; RCT | 383 | 56.2 | 50.9 | NR | 34.1 ≥28 | 120 tid | 48
Diabetes | Hollander 1998^191^; Orlistat; RCT | 322 | 55.1 | 48.9 | 12.5 | 34.3 ≥28 | 120 tid | 52
Diabetes | Kelley 2002^127,†^; Orlistat; RCT | 550 | 57.9 | 56 | 28 | 35.7 ≥28 | 120 tid | 52
Diabetes | Miles 2002^197^; Orlistat; RCT | 516 | 53.1 | 48.0 | 18 | NR ≥28 | 120 tid | 52
Hypertension | Bakris 2002^126,†^; Orlistat; RCT | 554 | 52.8 | 61.1 | 14.5 | 35.6 ≥28 | 120 tid | 52
Dyslipidemia | Broom 2002^132,†^; Orlistat; RCT | 142 | 51.6 | 60.5 | NR | 36.8 ≥30 | 120 tid | 24
Dyslipidemia | Derosa 2003^183^; Orlistat; RCT | 50 | 52.0 | 52.0 | NR | 31.9 >30 | 120 tid | 52
Dyslipidemia | Muls 2001^130,†^; Orlistat; RCT | 294 | 48.6 | 80.7 | NR | 32.9 ≥27 | 120 tid | 48
Multiple risk factors | Broom 2002^132^ (UK Multimorbidity Study); Orlistat; RCT | 531 | 46.0 | 78.4 | NR | 37.0 ≥28 | 120 tid | 52
Multiple risk factors | Lindgarde 2000^194^ (Swedish Multimorbidity Study); Orlistat; RCT | 376 | 53.5 | 63.6 | NR | 33.2 ≥28 | 120 tid | 52
Multiple risk factors | Swinburn 2005^201^; Orlistat; RCT | 339 | 52.2 | 56.9 | NR | 37.8 ≥30 | 120 tid | 52
Total trials (n) in subgroup: 12 (4,277)
With subclinical increase in cardiovascular risk or risk factors
Prediabetes | DPP 2005^142^; Metformin; RCT | 2155 | 50.6 | 67.7 | 45.3 | 34.1 ≥24 | 850 bid | 208
Prediabetes | Torgerson 2004^202^ (XENDOS); Orlistat; RCT | 3305 | 43.3 | 55.2 | NR | 37.4 ≥30 | 120 tid | 208
Multiple risk factors | Richelsen 2007^198^; Orlistat; RCT | 309 | 47.0 | 50.8 | NR | 37.5 ≥30 | 120 tid | 156
Total trials (n) in subgroup: 3 (5,769)
Without cardiovascular risk factors
| Acharya 2006^133,†^; Orlistat; Observational cohort | NR | 45 | 80.1 | NR | NR NR | 120 tid | 21
| Davidson 1999^182^; Orlistat; RCT | 892 | 43.5 | 84.2 | 19.2 | 36.3 ≥30 | 120 tid | 52
| Finer 2000^184^; Orlistat; RCT | 228 | 41.5 | 88.5 | 5.1 | 36.8 ≥30 | 120 tid | 52
| Fontbonne 1996^185^ (BIGPRO); Metformin; RCT | 457 | 49.5 | 66.7 | NR | 33.1 None (high WHR) | 850 bid | 52
| Gambineri 2006^186^; Metformin; RCT | 40 | 27.0 | 100 | NR | 36.0 ≥28 | 850 bid | 52
| Gokcel 2002^136,†^; Metformin and orlistat; RCT | 150 | 42.7 | 100 | NR | 37.2 >30 | Sibutramine: 10 bid Orlistat:120 tid Metformin: 850 bid | 26
| Hauptman 2000^189^; Orlistat; RCT | 422 | 42.5 | 78.3 | 9.1 | 36.1 ≥30 | 120 tid | 104
| Hill 1999^190^; Orlistat; RCT | 369 | 46.3 | 84.0 | 11.7 | 32.8 ≥28 | 120 tid | 52
| Krempf 2003^193^; Orlistat; RCT | 696 | 41.0 | 86.4 | NR | 36.1 ≥28 | 120 tid | 78
| Rossner 2000^199^; Orlistat; RCT | 487 | 44.2 | 82.3 | NR | 35.0 ≥28 | 120 tid | 104
| Sjostrom 1998^200^; Orlistat; RCT | 688 | 44.8 | 83.0 | NR | 36.0 ≥28 | 120 tid | 52
| Trolle 2007^131,†^; Metformin; RCT | 60 | 32 | 100 | NR | 33.8 NR | 850 bid | 26
| Van Gaal 1998^129,†^; Orlistat; RCT | 247 | 41.8 | 76.6 | NR | 34.6 ≥28 | 120 tid | 24
Total trials (n) in subgroup: 13 (4,736)
Total trials (n): 28 (14,782)

† Trials included for key question 4 only.

Abbreviations: bid=twice a day; BIGPRO=Biguanides and Prevention of Risks in Obesity; BMI=body mass index; DPP=Diabetes Prevention Program; NR=not reported; RCT=randomized, controlled trial; tid=three times a day; UK=United Kingdom; WHR=waist-to-hip ratio; XENDOS=Xenical in the Prevention of Diabetes in Obese Subjects.

Seven of the 23 placebo-controlled trials (30 percent) were conducted in the United States.126,127,182,189-191,197 All trials included both men and women (overall weighted average percent of female participants, 66 percent). The overall weighted average age of the entire group was 47.1 years (range, 41 to 59 years). Only 10 of 23 trials reported ethnicity of the participants, and in these trials the weighted average percent of nonwhite participants was 14.7 percent (range, 0 to 28 percent). The median trial duration was 52 weeks (range, 24 to 208 weeks), but five trials provided data beyond 52 weeks.

Adverse events. Participants who were randomized to orlistat were more likely to experience adverse effects (Figure 13) and withdrawals due to adverse effects (Figure 14) compared with those who were randomized to placebo. However, a similar number of participants reported serious adverse effects in the orlistat group compared with the placebo group (Figure 15). Data were limited and contradictory regarding whether orlistat led to hypoglycemia in drug-treated participants with type 2 diabetes.127,187,197 Data were insufficient to determine whether orlistat had detrimental effects on bone density.216

Figure 13 Relative Risk of Experiencing Any Adverse Effects

Abbreviations: CI=confidence interval; CV=cardiovascular; IV=intervention; N=number; RR=relative risk; SD=standard deviation; Subclincl=subclinical; Unsel=unselected.

Figure 13 displays a forest plot of studies reporting the relative risk of adverse effects in the intervention group compared to the control group. Data from Figure 13 are presented in Appendix C, Tables 2 and 4. This figure is described further in “Results: Key Question 4: Pharmacotherapy: Orlistat: Adverse Events” as follows: “Participants randomized to orlistat were more likely to experience adverse effects (Figure 13)…compared to those randomized to placebo.”

Figure 14 Relative Risk of Study Withdrawal Due to Adverse Effects

Abbreviations: CI=confidence interval; CV=cardiovascular; IV=intervention; N=number; RR=relative risk; SD=standard deviation; Subclincl=subclinical; Unsel=unselected.

Figure 14 displays a forest plot of studies reporting the relative risk of withdrawing from adverse effects in the intervention group compared to the control group. Data from Figure 14 are presented in Appendix C, Tables 2 and 4. This figure is described further in “Results: Key Question 4: Pharmacotherapy: Orlistat: Adverse Events” as follows: “Participants randomized to orlistat were more likely to experience…withdrawals for adverse effects (Figure 14) compared to those randomized to placebo.”

Figure 15 Relative Risk of Experiencing Serious Adverse Effects

Abbreviations: CI=confidence interval; CV=cardiovascular; IV=intervention; N=number; RR=relative risk; SD=standard deviation; Subclincl=subclinical; Unsel=unselected.

Figure 15 displays a forest plot of studies reporting the relative risk of serious adverse effects in the intervention group compared to the control group. Data from Figure 15 are presented in Appendix C, Tables 2 and 4. This figure is described further in “Results: Key Question 4: Pharmacotherapy: Orlistat: Adverse Events” as follows: “However, a similar number of participants reported serious adverse effects in the orlistat compared to placebo group (Figure 15).”

Gastrointestinal-related adverse effects were more common in the orlistat group compared with the placebo group and were the main cause of excess adverse effects in the orlistat group (Figure 16). Gastrointestinal side effects included loose stools, increased defecation, uncontrolled oily discharge/oily evacuation, oily spotting, fatty/oily stool, fecal urgency, discolored feces, flatus with discharge, fecal incontinence, and abdominal pain. Most gastrointestinal adverse effects were mild to moderate in intensity, occurred early in treatment, and resolved spontaneously. Orlistat treatment appeared to be associated with a decrease in some fat-soluble vitamin levels compared with placebo.129,190,191,199,202 Data were strongest for vitamin E and beta-carotene, but there were also several reports for vitamin D. There were insufficient data to evaluate orlistat's effects on the liver.

Figure 16 Relative Risk of Experiencing Gastrointestinal Adverse Effects in Orlistat Trials

Abbreviations: CI=confidence interval; CV=cardiovascular; IV=intervention; N=number; RR=relative risk; SD=standard deviation; Subclincl=subclinical; Unsel=unselected.

Figure 16 displays a forest plot of studies reporting the relative risk of experiencing gastrointestinal adverse effects in the intervention group compared to the control group. Data from Figure 16 are presented in Appendix C, Tables 2 and 4. This figure is described further in “Results: Key Question 4: Pharmacotherapy: Orlistat: Adverse Events” as follows: “GI-related adverse effects were more common in the orlistat compared to placebo group and were the main cause of excess adverse effects in the orlistat group (Figure 16).”

In the trial comparing orlistat and metformin, there were no differences in withdrawals due to adverse effects, but more people reported abdominal discomfort using orlistat (44 percent) than metformin (28 percent). These percentages were not tested for statistical significance. Table 17 and Appendix F provide more details on adverse events.

Table 17 Summary of Medication Harms

Adverse events | N Trials (meta-analysis, other) | Meta-analysis results RR (95% CI) | Weighted means | Results from studies not in meta-analysis | Dosage effects | Subgroup analysis | Comments
Orlistat
Withdrawals due to adverse events | 23, 0 | 1.67 (1.32- 2.13) | IG: 8% CG: 4% | -- | 3 of 4 studies present no difference; 1 study had slightly higher withdrawal rate with 120 mg (but no statistical testing) | Trials of unselected populations: RR, 2.2 (95% CI,1.6-3.0) Trials of those with CV risk: RR, 1.43 (95% CI, 0.99-2.06) | Gastrointestinal symptoms were main reason for withdrawal
Any | 8, 0 | 1.10 (1.03-1.17) | IG: 78% CG: 70% | -- | NR | -- | Gastrointestinal symptoms were main reason for withdrawal
Serious | 11, 2 | 1.21 (0.88-1.68) | IG: 10% CG: 9% | No serious adverse events in either treatment group in 2 trials | NR | Trials of unselected populations: RR, 2.0 (95% CI, 0.9-4.5) Trials of those with CV risk: RR, 1.1 (95% CI, 0.6-2.0) | Fecal incontinence, diverticulitis, abdominal pain
Gastrointestinal | 18, 0 | 1.42 (1.33-1.52) | IG: 83% CG: 59% | -- | 3 of 3 studies did not report statistically high gastrointestinal adverse events with higher dose; 1 had slightly higher rate but was not labeled as statistically significant | -- | Mild to moderate intensity and often resolved spontaneously
Hypoglycemia | 0, 3 | -- | -- | 2 of 3 studies found increased incidence of hypoglycemia with orlistat | NR | NR | --
Bone mineral density | 0, 1 | -- | -- | In small subsample (N=30) of larger study, bone density did not differ between groups | -- | -- | --
Vitamin deficiency | 0, 5 | -- | -- | 5 of 5 studies found lower vitamin E with orlistat; 4 of 4 studies found lower beta-carotene; 1 of 2 trials found lower vitamin A; 1 of 1 study found lower vitamin K; 5 of 5 studies found orlistat participants required more vitamin supplementation during the study | 2 of 2 studies showed no clear relation to dose, although not clear if tested statistically | NR | --
Liver injury | 0, 1 (event monitoring cohort) | -- | -- | UK monitoring study reported elevated liver tests in 2 cases; no cases of serious hepatic adverse reactions | NR | NR | FDA recently added warning to label about risk of severe liver disease with orlistat
Metformin
Withdrawals | 2, 0 | 3.92 (1.23-12.57) | IG: 5% CG: 1% | -- | -- | -- | --
Any | 2, 0 | 4.83 (0.84-27.63) | IG: 46% CG: 16% | -- | -- | -- | --
Serious | 0 | -- | -- | -- | -- | -- | --
Gastrointestinal | 1, 3 | -- | -- | Increased risk of gastrointestinal adverse events in metformin group | All same dosage | Not different by age | Main gastrointestinal symptoms included diarrhea, flatulence, nausea, vomiting
Hypoglycemia | 0 | -- | -- | -- | -- | -- | --
Bone density | 0 | -- | -- | -- | -- | -- | --

Abbreviations: CG=control group; CI=confidence interval; CV=cardiovascular; FDA=U.S. Food and Drug Administration; IG=intervention group; NR=not reported; RR=relative risk; UK=United Kingdom.

Dosage effects. All 24 trials prescribed orlistat 120 mg tid.126,127,129,130,132,136,180-184,187,189-191,193,194,197-202,215 Four trials included additional dosage regimens (30 to 240 mg tid), but did not present statistical comparisons between dosage groups.129,189,190,199 Data do not suggest that higher dosages were associated with elevated adverse effect rates, although the results were somewhat mixed.

Subgroup analysis. Withdrawals due to adverse effects and serious adverse events were more likely in trials of unselected participants taking orlistat129,182,184,189,190,193,199,200 than in participants with cardiovascular risk factors,126,127,130,132,180,181,183,187,191,194,197,198,201,202 regardless of age.

#### Metformin

General characteristics of studies. We included a total of four trials on the harms of metformin (850 mg twice daily) (Table 16). Three trials were RCTs from KQs 2 and 3,142,185,186 and one was an additional published RCT.131 Recruitment criteria included IFG or IGT,142 high WHR,185 or polycystic ovary syndrome.131,186 One trial additionally compared metformin with orlistat, and was described previously.136 Only one of the four trials was conducted in the United States.142 The overall weighted average percent of female participants in all trials was 68.7 percent (range, 67 to 100 percent); two small trials included only women. The overall weighted average age of participants was 49.7 years (range, 27 to 50 years), and 45.3 percent of the participants in the largest trial of metformin were nonwhite.142 The other trials did not describe ethnicity. Two trials had a duration of 1 year (range, 26 to 208 weeks).

Withdrawals and adverse effects. Participants who were randomized to metformin were more likely to have any adverse event and to withdraw due to adverse effects (Table 17) compared with those who were randomized to placebo.131,185,186 No studies reported the proportion of participants with serious adverse effects, although one listed all adverse effects and none fit our criteria for serious.186 There were no data about the effects of metformin on bone density or hypoglycemia. Gastrointestinal adverse effects (abdominal swelling, diarrhea, flatulence, nausea, vomiting) were more likely to occur in those who were randomized to metformin compared with placebo and were the main reason for excess adverse effects (Table 17).131,185,186,210Table 17 and Appendix F provide more details on adverse events.

Dosage effects. We were unable to examine the relationship between metformin dose and adverse effects, as all studies prescribed the same dose of 850 mg twice daily.

Subgroup analysis. In DPP, the relative increase in gastrointestinal adverse events in the metformin group did not appear to differ by age.210

Heterogeneity of medication studies (meta-regression analysis). We performed meta-regression to examine whether study characteristics influenced the association between medication and the proportion of participants who withdrew due to adverse effects or reported any adverse effects, any serious adverse effects, or gastrointestinal-related adverse effects, in all cases controlling for risk status of the participants and medication type. We examined multiple trial factors, including how many participants returned for followup, whether the study was conducted in the United States, and the duration of the study. None of these trial factors influenced the harms effect size of the medications. Sex and age did not predict effect size for any adverse event associated with medications. We were unable to examine ethnicity because of the paucity of reporting and low percentage of nonwhite participants in the medication studies.

The type of medication did not influence withdrawals due to adverse effects, total adverse effects, or serious adverse effects in any of the meta-regression models, although the number of metformin trials was fairly small. We had limited ability to detect differences in harms between medications since we did not include trials that did not have placebo comparison groups. Only one trial of obese women included a head-to-head comparison of orlistat and metformin.136 Two participants withdrew due to side effects (none serious) from the orlistat group and none withdrew from the metformin group.