# Methods

## Key Questions and Analytic Framework

Building on the methods and approach of the 2003 USPSTF evidence review, we developed an analytic framework (Figure 1) and formulated four key questions (KQs) to guide our literature search and targeted systematic review.83 The KQs were designed to evaluate the benefits of programs to screen for and manage overweight and obesity in adults in primary care, and the benefits and harms of primary care–feasible or –referable weight loss interventions for obese or overweight adults.

Figure 1 Analytic Framework: Primary Care Screening and Interventions for Obesity and Overweight in Adults

Key Questions

Key Question 1. Is there direct evidence that primary care screening programs for adult obesity or overweight improve health outcomes or result in short-term (12 months) or sustained (>12 months) weight loss or improved physiological measures (i.e., glucose tolerance, blood pressure, or dyslipidemia)?

1a. How well is weight loss maintained after an intervention is completed?

Key Question 2. Do primary care–relevant interventions (behavioral-based interventions and/or pharmacotherapy) in obese or overweight adults lead to improved health outcomes?

2a. What are common elements of efficacious interventions?

2b. Are there differences in efficacy between patient subgroups (i.e., ages 65 years or older, sex, race/ethnicity, degree of obesity, or baseline cardiovascular risk status)?

Key Question 3. Do primary care–relevant interventions in obese or overweight adults lead to short-term or sustained weight loss, with or without improved physiological measures?

3a. How well is weight loss maintained after an intervention is completed?

3b. What are common elements of efficacious interventions?

3c. Are there differences in efficacy between patient subgroups (i.e., ages 65 years or older, sex, race/ethnicity, degree of obesity, or baseline cardiovascular risk status)?

Key Question 4. What are the adverse effects of primary care–relevant interventions in obese or overweight adults (e.g., nutritional deficits, cardiovascular disease, bone mass loss, injuries, or death)?

4a. Are there differences in adverse effects between patient subgroups (i.e., ages 65 years or older, sex, race/-ethnicity, degree of obesity, or baseline cardiovascular risk status)?

Figure 1 is an analytic framework for the key questions of this report that depicts the events that adults (18-64 years) and older adults (65 years and older) could experience while undergoing screening and interventions for obesity. In general, the figure illustrates how obesity screening in adults leads to interventions. The obesity interventions may lead to short-term or maintained weight loss, and/or improved glucose tolerance, blood pressure, and dyslipidemia. These intermediate outcomes may also lead to decreased morbidity from selected conditions, improved physical fitness, reduced disability, improved emotional functioning, and reduced mortality. The figure also depicts the possibility of harms or adverse events occurring as a result of screening or interventions

KQ 1. Is there direct evidence that primary care screening programs for adult obesity or overweight improve health outcomes or result in short-term (12 months) or sustained (over 12 months) weight loss or improved physiological measures (e.g., glucose tolerance, blood pressure, and dyslipidemia)?

KQ 1a How well is weight loss maintained after an intervention is completed?

KQ 2. Do primary care–relevant interventions (behavioral-based interventions and/or pharmacotherapy) in obese or overweight adults lead to improved health outcomes?

KQ 2a What are common elements of efficacious interventions?
KQ 2b Are there differences in efficacy between patient subgroups (e.g., ages 65 years or older, sex, race/ethnicity, degrees of obesity, baseline cardiovascular risk status)?

KQ 3. Do primary care–relevant interventions in obese or overweight adults lead to short-term or sustained weight loss, with or without improved physiological measures?

KQ 3a How well is weight loss maintained after an intervention is completed?
KQ 3b What are common elements of efficacious interventions?
KQ 3c Are there differences in efficacy between patient subgroups (e.g., ages 65 years or older, sex, race/ethnicity, degrees of obesity, baseline cardiovascular risk status)?

KQ 4. What are the adverse effects of primary care–relevant interventions in obese or overweight adults (e.g., nutritional deficits, cardiovascular disease, bone mass loss, injuries, and death)?

KQ 4a Are there differences in adverse effects between patient subgroups (e.g., ages 65 years or older, sex, race/ethnicity, degrees of obesity, baseline cardiovascular risk status)?

## Literature Search Strategy

In addition to evaluating all trials included in the previous reviews for inclusion in the current review, we conducted a search (Appendix B) for relevant existing systematic reviews in databases (Cochrane Database of Systematic Reviews, the Database of Abstracts of Reviews of Effects, and MEDLINE), as well as Web sites (Institute of Medicine, NIH, and National Institute for Health and Clinical Excellence [NICE]). We identified a 2006 NICE systematic review with detailed reporting on behavioral weight loss interventions and orlistat which was current through November 2005. We used this review as the foundation for our literature search for KQs 1-4.^123^ The NICE review, however, did not include metformin, so we identified an additional review to locate metformin trials published since the previous USPSTF review. This review focused specifically on metformin treatment for weight loss and searched into February 2008.^124^ We then conducted a search for all four KQs (Appendix B) in MEDLINE, the Cochrane Central Registry of Controlled Trials, and PsycINFO beginning in January 1, 2005 through September 9, 2010. We supplemented our searches with suggestions from experts and reference lists from other relevant publications.

## Study Selection

Two investigators independently reviewed all abstracts and articles against inclusion and exclusion criteria (Appendix B Table 2). Discrepancies were resolved by consensus. Articles excluded for not meeting inclusion criteria or for poor quality are listed in Appendix D Tables 1–4. Briefly, we included randomized or controlled clinical trials (additionally, cohort or case-control studies for KQ 4) conducted among adults (ages 18 years and older) in settings generalizable to or referable from primary care. Because we were examining the effects of weight loss programs versus usual care, we excluded trials with control groups receiving frequent weigh-ins, advice more frequently than annually, or at-home study materials; these studies were considered to be comparative effectiveness studies. Interventions were restricted to those focusing on weight loss and those not reporting weight outcomes were excluded. Only outcomes reported at 12 months or longer were included (with the exception of KQ 4).

## Data Extraction and Quality Assessment

Two independent investigators dual-reviewed 6,498 abstracts and 648 articles (Appendix B Figure 1) for inclusion and critically appraised all included articles using design-specific criteria (Appendix B Table 2) and USPSTF methods.125 The USPSTF has defined quality ratings of “good,” “fair,” and “poor” based on specific criteria. Discrepancies in quality ratings were resolved by consultation with a third investigator. All studies rated as poor quality were excluded from the review.

Briefly, for KQs 1–3, we assessed the validity of the randomization and measurement procedures, attrition, similarities between the groups in baseline characteristics and attrition, intervention fidelity, and statistical methods. Among other things, good-quality trials blinded researchers to participant randomization if they performed tasks related to assessment, had followup data on 90 percent or more of participants, reported group-specific followup with less than 10 percent difference between groups, and described important details related to the measurement of anthropomorphic measures. Trials were rated as “poor” if attrition in the treatment and control groups differed by more the 20 percent or if overall attrition was higher than 40 percent, or had other important flaws. All trials meeting quality criteria for KQs 1–3 were also examined for KQ 4 outcomes.

In addition, we developed separate quality assessment procedures for trials that were not included for KQs 1–3 (either due to quality issues or other inclusion criteria) but reported harms outcomes. The quality rating of KQ 4-only studies specifically focused on the assessment and analysis of harms. We did not have minimum attrition standards or duration of followup requirements because high attrition may be directly related to harms and a 12-month duration requirement would miss immediate harms. Because we had different standards for KQ 4 that focused only on factors specifically related to the assessment of harms, we simply rated them as “acceptable” or “poor.” A poor-quality study was one that had a fatal flaw that made the harms data of questionable validity.

One investigator abstracted data from included studies into standardized evidence tables and a second investigator reviewed abstracted data for accuracy. We abstracted study design, setting, population characteristics, baseline health, intervention characteristics, outcomes, and adverse events (Appendix C Tables 1–3).

For KQ 1, no trials were included in this review. For KQs 2 and 3, 98 articles representing 58 unique trials were included, 30 of which were conducted in the United States. For KQ 4, we included an additional 12 articles representing 10 randomized, controlled trials (RCTs) and two cohort studies that were not included in KQs 2 and 3 for various reasons, including three trials for poor quality,126-128 four for short duration (<12 months),129-132 three for study design (not RCTs),133-135 two for comparative effectiveness,136,137 and one because the exercise intervention was not designed to promote weight loss.138

## Data Synthesis and Analysis

We separately synthesized identified evidence for trials of behavioral-based interventions and each weight loss medication. Within each intervention type, trials were grouped according to the study population risk status (cardiovascular risk, subclinical risk, unselected/low risk) and then ordered by the intensity of the behavioral interventions within each risk status (number of sessions for behavioral trials, brief or intensive intensity for medication trials). Risk status and intensity are discussed in detail in Appendix A.

We conducted random effects meta-analyses to estimate the effect size of weight loss interventions on intermediate health outcomes (adiposity, systolic and diastolic blood pressure [SBP, DBP], total cholesterol, high-density and low-density lipoprotein [HDL, LDL] cholesterol, triglycerides, and glucose). For continuous outcomes, we analyzed change from baseline. Risk ratios were analyzed for dichotomous outcomes. Absolute risk difference was also estimated through meta-analysis in many cases so that the number needed to treat (NNT) could be calculated. We selected a single intervention arm for trials that included multiple active treatment arms and calculated change from baseline and standard deviations based on the information provided in the individual articles if they were not provided. We converted measurements into common units using standard conversion factors, which are provided in Appendix A. Additional details of the meta-analysis data management and calculations can also be found in Appendix A.

We assessed the presence of statistical heterogeneity among the studies using standard chi-square tests and estimated the magnitude of heterogeneity using the I^2^ statistic.139 We considered an I^2^ statistic of <50 percent to represent low heterogeneity, 50–75 percent to represent moderate heterogeneity, and >75 percent to indicate high heterogeneity among the studies. Tests of publication bias on whether the distribution of the effect sizes was symmetrical with respect to the precision measure were performed using funnel plots and Egger's linear regression method140 when the number of studies was about 10 or more.141

Meta-regressions were used to explore heterogeneity in effect sizes among the KQs 1–3 trials. Due to concerns about type I errors, we limited most exploration of heterogeneity to a single outcome—weight loss. Some factors were explored for the entire body of trials, combining behavioral interventions and all three medication types, while other factors were run separately for the medication trials only and the behavioral trials only. Continuous variables were left as continuous variables, and categorical variables were converted to one or more dummy variables.

Heterogeneity was explored with several factors. Prominent sources of heterogeneity were the risk status of the populations and the participant identification approach (see Appendix A for more details). Additional factors explored for the entire combined body of literature were: percent of participants retained at 12 to 18 months, whether the trial focused on weight maintenance as opposed to weight loss, whether primary care was the setting for either recruitment or the intervention, whether the trial was set in the United States, study quality rating, and selected patient-level characteristics.

For medication trials, we also examined the percent of participants that were retained after a run-in period, the specific type of medication, and whether the behavioral intervention was more intensive than would be delivered in primary care (see intensity definitions in Appendix A). The variables explored for the entire group of trials listed above were also examined separately in the medication trials. All meta-regression of the medication trials controlled for medication type and population risk status.

For behavioral trials, we also examined the number of sessions in the first year and, in separate models, the presence of each of the following intervention components: supervised physical activity sessions, group sessions, individual sessions, technology-based assessment or intervention, specific weight loss goals, spouse or family involvement, addressed barriers to weight loss, pros and cons of weight loss or similar motivational assessment, self monitoring, use of incentives for weight loss or intervention participation, and support for weight loss or lifestyle maintenance after active intervention phase. The variables examined in the combined medication and behavioral trials were also examined separately in the behavioral subgroup. Number of sessions in the first year and risk status of the patients were included in all models.

All analyses were performed using Stata 10.0 software (StataCorp, College Station, TX).

## USPSTF Involvement

The authors worked with four USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and KQs, to address methodological decisions on applicable evidence, and to resolve issues regarding scope of the final evidence synthesis. This research was funded by the Agency for Healthcare Research and Quality (AHRQ) under a contract to support the work of the USPSTF. AHRQ staff provided oversight for the project, reviewed the draft report, and assisted in external review of the draft evidence synthesis.