# Surgical Interventions

## Surgical Interventions to Treat Obesity

The use of bariatric surgery to treat obesity in adults is increasing in the United States. This increase is likely due to advancing surgical expertise and a recognition of bariatric surgery's effectiveness for weight loss and reducing obesity-related health problems. Current practice is to refer patients to specialized multidisciplinary centers in order to reduce risks of surgery, while providing support before and after bariatric surgery.296 Bariatric surgery results in significant short- and intermediate-term weight loss for patients who meet current criteria for surgery.239,244, 296 Criteria for bariatric surgery are usually defined as class III obesity (BMI of >40 kg/m^2^) or class II obesity (BMI of 35 to 40 kg/m^2^) with comorbidity such as diabetes.297

### Health Outcomes

A recent Health Technology Assessment (HTA) summarized evidence on the clinical and cost effectiveness of bariatric surgery for obesity.239 This HTA identified 26 studies with a followup of at least 12 months that included outcomes on weight change, quality of life, perioperative and postoperative morbidity and mortality, and change in obesity-related comorbidity.239

Weight reduction. Although the degree of weight reduction varied, all surgical methods resulted in significant weight loss. The Swedish Obese Subjects (SOS) study was the largest and longest study included in the HTA. The SOS study is an ongoing prospective cohort study of 2010 subjects who underwent bariatric surgery and 2037 matched controls.244 After 15 years of followup, the vertical banded gastroplasty (VBG) group had a weight reduction of 16 percent, the gastric bypass (GBP) group had a reduction of 25 percent, and the banding group had a reduction of 14 percent. This translates to an average sustained weight loss of 19.7 kg from the presurgical weight and BMI reduction from 42 to 35.3 kg/m^2^.

The remaining included studies generally reported followup of 1 to 3 years and a range of weight reduction from baseline of 16 to 29 percent. BMI losses were as much as 8 to 11 kg/m^2^ below baseline, and average weight lost ranged from around 21 kg to over 50 kg. Weight loss differed significantly depending on procedure, sex, and baseline weight and/or BMI.

Harms of surgery. Deaths rarely occurred due to surgical complications. In the SOS study, postoperative mortality was 0.25 percent (5 of 2010 at 90 days).244 Long- and short-term complications, however, can be quite significant. Common complications included infections, bleeding, deep vein thrombosis and pulmonary embolism, leakage, symptomatic ulcer and gastroesophageal reflux disease, diarrhea, gallstones, and vitamin deficiency. Complications requiring reoperation in the postoperative period occurred in 2 to 13 percent of patients. Surgical reoperations or conversions during 10 years of followup in the SOS study were high at 17 percent for GBP, 21 percent for VBG), and 31 percent for banding (excluding early postoperative complications requiring surgery).239,243,244 However, reporting of adverse events has not been standardized, and they were generally not reported well.

Other health outcomes. The SOS study provides the only longer-term data on bariatric surgery's mortality benefit. At 10 years, unadjusted overall mortality was reduced by 23.7 percent in the surgery group (p=0.0419). Sex-, age-, and risk factor-adjusted mortality reduction was 30.7 percent (p=0.0102). The most common cause of death were myocardial infarction and cancer.244

Physiologic measures also improved with weight loss. The most significant reduction was apparent in the development of metabolic syndrome and remission of type 2 diabetes. For diabetes resolution, data at 2 years reported that 72 percent of those with type 2 diabetes had reversed, and 36 percent were still in remission at 10 years. Other studies reported higher rates, but did not have as long of followup. In one small study included in the HTA, for example, diabetes resolution was reported as high as 100 percent at 3 years, but it referred to only five of 59 patients after laparoscopic Roux-en-Y gastric bypass.239 Even using the most conservative estimates available, the treatment effect is quite marked for surgery and diabetes reversal. In modeling of cost effectiveness over 20 years, the delay in developing or redeveloping diabetes still results in a quality-adjusted life year improvement.

Comorbidity improved after surgery in all groups, but the quality of this data was poor in general. At 10 years, the SOS study found a statistically significant reduction in the incidence of diabetes, hypertriglyceridemia, and hyperuricemia compared with conventional therapy. Other reported improved (although not necessarily significant) comorbidities include sleep apnea, pulmonary problems, joint problems, reflux disease, and psychological problems. Although the SOS study found that cancer rates were statistically significantly lower for women treated with surgery, men did not show the same results. More data on cancer and obesity is needed to further characterize this effect. In surgical patients, triglycerides and low HDL cholesterol did improve even after 10 years, but there was no statistically significant recovery from hypercholesterolemia; hypertension also improved at 2 years, but not to statistical significance at 10 years. Pooled comparisons of comorbidity across different surgical procedure groups showed no significant difference between procedures.

### Generalizability

Data included in the referenced review was strongest for women, whites, patients with diabetes, and those meeting current surgical criteria. This is probably because these groups were the most likely to have been recommended for surgery, and thus the most studied. The positive effects of surgery on health over time were significant for these populations. Unfortunately, there is a paucity of data related to race and ethnicity, as the vast majority of patients studied thus far have been of European origin/ethnicity. More studies targeting specific populations are needed, especially because many nonwhite populations have higher rates of diabetes and other obesity-related diseases.298 We cannot generalize the current recommendations for surgery without specific data. For example, morbidity and mortality do not follow the same BMI data curves in some groups—most notably blacks. More information is also needed on whether other methods of classification of obesity should be used, such as waist-to-hip ratio or waist circumference instead of (or in addition to) BMI, and/or different cutoff values.86,98,99,299

There are likely other factors that may influence obesity's complex relationship with health outcomes that differ based on genetic susceptibility and other societal and cultural factors that have not yet been identified. For example, one of the few studies that examined differences in obesity and surgical weight loss between black and white females found that the former had greater adiposity and lost significantly less body fat after surgery.300 The clinical significance of this is not clear, but is suggestive of the need for more and larger studies to examine these questions.

The complexity of evaluating bariatric surgery, with multiple surgeons and surgical techniques, staffing-related factors, and range of outcomes, makes it very difficult to eliminate bias and standardize results. Improved study techniques are needed for more accurate conclusions based on effects of surgical interventions.301 This is particularly true for the evolution of management and study of surgical weight loss, where techniques and effects are still being studied and additional innovations tried, at the same time as recommendations and payer coverage are changing.