# Trials Pending Assessment

Investigator, Study Name | Location | Number of Participants | Intervention | Outcomes | 2010 Status
Dr. R. Ross PROACTIVE | Ontario, Canada | 491 | Behaviorally based physical activity and diet composition program | Primary: waist circumference and prevalence of metabolic syndrome Secondary: body composition, serum cholesterol, physical activity, barriers to physical activity and other psychosocial barriers | Last data collection planned for January 2010
Dr. M. Silva | Lisbon, Portugal | 259 | Behavioral group sessions covering physical activity, eating/nutrition, body image, and other cognitive-behavioral contents | Weight, physical activity and exercise levels, dietary intake, psychosocial measures | Completed July 2009, results not yet published
Dr. Marieke F van Wier | The Netherlands | 1386 | Phone-based and internet-based behavioral intervention addressing diet and physical activity | Body weight, BMI, diet, physical activity, perceived health, empowerment, stage of change and self-efficacy concerning weight control, physical activity and eating and eating habits, work performance/productivity, waist circumference, sum of skin folds, blood pressure, total blood cholesterol level, and aerobic fitness | Results at 6 months published. 12, 18, and 24 months not yet published
Dr. Neree Claes PreCardio | Belgium | 350 | Prevention consultations using a cardiovascular risk calculator with personalized feedback on behavioral risk factors, followup with intensive support of health behavior change | Cardiovascular risk factors, cardiovascular events, quality of life, costs, and incremental cost effectiveness ratios | Protocol published in 2007, 3-year followup planned
Dr. Karen Hosper Exercise on Prescription | The Netherlands | 360 | Weekly exercise sessions for 20 weeks | Minutes of self-reported physical activity per week, mediating motivational factors regarding physical activity, wellbeing, perceived health, fitness, body size, and use of health care | Protocol published in December 2008, 12 months of followup planned
Dr. Jacqueline Kerr Illinois WISEWOMAN | Chicago, Illinois | 1021 | CVD risk factor screening, educational materials, and a 12-week lifestyle intervention | Dietary intake, physical activity, blood pressure, cholesterol, blood glucose, BMI | Baseline results published in 2009
Dr. Philip Merriam LLDPP | Lawrence, Massachusetts | 312 | 13 group sessions and 3 individual home visits intended to increase awareness of diabetes prevention strategies, foster positive diabetes prevention attitudes, and promote healthy lifestyle behaviors. | Stern equation components, weight, glycosylated hemoglobin, diet, physical activity, depression, social support, and quality of life | Baseline results published in 2009, 12 months of followup planned
Dr. Truls Ostbye AMP | Durham, North Carolina | 450 | 10 physical activity group sessions, 8 healthy eating classes, 6 telephone counseling sessions promoting a reduction in BMI up to 2 years postpartum | Teachable moment factors, intervention participation, Nutrition Data System, brief food frequency questions, 7-Day Physical Activity Recall, weight, and height | Baseline results published in 2008, 10.5 month results published in 2009, 24 months of followup planned
Dr. Kristin Schneider | Massachusetts | 174 | Behavioral Activation condition: 10 weekly individual visits of behavior therapy for treatment of depression followed by 16 group behavioral weight loss visits Standard Weight Loss condition: 10 individual visits of health education (attention control) followed by 16 group behavioral weight loss visits | Weight, depression, physical activity and dietary intake, emotional eating, quality of life, blood pressure, serum lipids, C-reactive protein | Protocol published 2008, 24 months of followup planned
Dr. Mark Vander Weg The Treatment and Prevention Study | Iowa City, Iowa Memphis, Tennessee Rochester, Minnesota | 1267 | 3-4 individual smoking-cessation sessions; 5 individual and 12 weekly group sessions for modifying diet and physical activity; weight loss and sodium restriction modeled after the TONE study | Blood pressure, height, weight, body composition, waist circumference, smoking status, dietary intake, urinary chloride excretion, physical activity, and assessment of predictor, mediator, and moderator variables | Protocol published 2008, 5 years of followup planned
Dr. Deborah Parra-Medina HHER | Columbia and Orangeburg, SC | 266 | Stage-based behavioral counseling from primary-care provider, nurse-assisted goal setting, community resource guide of free or low-cost programs and facilities, and ethnically tailored educational materials. 12 newsletters, 14 brief telephone counseling calls over 12 months. | Physical activity, food consumption, BMI, waist circumference, total cholesterol, barriers-based self-efficacy for exercise, self-efficacy for low-fat diet, social support for physical activity and low-fat diet, decisional balance for physical activity and low-fat diet | Protocol and baseline measures published 2010, 12 months of followup planned
Dr. Juan Jose Rodriguez Cristobal | Spain | 1200 | 32 group sessions. 4 sessions to provide information about the benefits of change and recommended diets. 8 sessions to have patients feel motivated to make a change and be committed to continuing the program. 20 sessions to work with changed and maintenance. | Age, ethnicity, sex, medical history, medications, quality of life, dietary survey, height, weight, BP, pulse, fasting serum glucose, fasting lipid panel | Protocol published in 2010, 26 moths of followup planned
Dr. Jun Ma BE WELL | California | 324 | Goal-based approach with the same weight loss and physical activity goals for each participant. Physical activity time gradually increased and a moderate reduction of calories. 12 weekly small group sessions, 2 individual counseling sessions, optional contact with interventionist. | QOL, 3-day food record, pedometer, angina and peripheral vascular disease, depression, adverse events, height, weight, waist circumference, waist-to-hip ratio, blood pressure, current medical problems | Protocol published in 2010, 12 moths of followup planned
Dr. Gianluca Castelnuovo TECNOB | Italy | 154 | In hospital treatment for 1 month for diet, physical activity, psychological and dietitian counseling. Extensive outpatient telecare through a web platform and mobile phones for 12 months. | Weight, height, binge eating, eating disorder inventory, psychological problems, QOL | Protocol published in 2010, 13 months of followup planned.
Dr. Giovanni Cizza | Maryland | 150 | During first 12 months strive to increase sleep duration. During subsequent 36 months, individual counseling on sleep, nutrition, and physical activity offered to all participants; individualized sleep plans, long-term lifestyle changes to daily routine encouraged. | Body composition, psychological assessment, insulin resistance, endocrine assessment, metabolic assessment, QOL | Protocol published in 2010, 48 months of followup planned.
Dr. Elizabeth Eakin Living Well with Diabetes | Australia | 300 | Repeated assessment of study outcomes and participant self-monitoring; feedback provided for weight, dietary intake, and physical activity using motivational interviewing techniques; collaborative goals for weight, physical activity, and dietary change with telephone counselor; behaviorally-specific action plan; barriers and supports identified; confidence is assessed and problem-solving discussed as necessary (up to 27 calls). | Weight, physical activity, HbA1c, dietary and energy intake, waist circumference, percent body fat, fasting plasma glucose, blood lipids, liver function enzymes, blood pressure, health-related QOL. | Protocol published in 2010, 24 months of followup planned
Dr. Kate Jolly Lighten Up | UK | 740 | Weight Watchers: Food points system, beating hunger, taking more physical activity, keeping motivated Slimming World: Encouraged to eat low energy dense foods plus some extras rich in calcium and fiber with controlled amounts of high energy dense foods. Rosemary Conley: Weight loss and improved diet, fitness, and improvement of physical condition, motivation and self esteem, use of group support. NHS Size Down: Managing behavior around food and relapse prevention, eatwell plate, nutrition information. General practice/pharmacy: Client-led sessions, weight and dieting history, goals and expectations, eatwell plate, goals to reduce calorie intake and increase physical activity. | Weight, physical activity. | Protocol published in 2010, 12 months of followup planned.
Dr. Hsin-Chieh Yeh POWER Trials Collaborative Group | Maryland, Pennsylvania, Massachusetts | ~1100 | Be Fit, Be Well: Behavior change prescription and skills training via internet or a combination of tailored print materials and an interactive voice response system. POWER Hopkins: Phone calls with Healthways coach, interactive website, PCP reinforcement (IG1). Individual and group meetings and phone calls with Hopkins interventionist, interactive website, PCP reinforcement (IG2). POWER-UP: Usual medical care plus 26 brief counseling sessions with auxiliary health care provider (IG1). Usual medical care plus 26 brief counseling sessions plus the choice of adjunctive meal replacements or pharmacotherapy (IG2). | Be Fit, Be Well: Blood pressure, dietary change, physical activity, medication adherence POWER Hopkins: Weight, BMI, blood pressure, hypertension control, lipid levels, HOMA-IR, Framingham risk score POWER-UP: Weight, BMI, metabolic syndrome, eating and activity habit changes, quality of life, cardiovascular disease risk factors, HOMA-IR | Protocol for all 3 published in 2010. Be Fit, Be Well: Followup at 24 months POWER Hopkins: Followup at 24 months POWER-UP: Followup at 12 and 24 months