# Excluded Studies

Appendix D Table 1 Studies Excluded From Review for Key Question 1

Reference | Reason for Exclusion
Ashley JM, St Jeor ST, Schrage JP, Perumean-Chaney SE, Gilbertson MC, McCall NL, et al. Weight control in the physician's office. Arch Intern Med. 2001;161(13):1599-604. | Does not meet design requirements in inclusion criteria
Bemelmans WJ, Broer J, de Vries JH, Hulshof KF, May JF, Meyboom-De Jong B. Impact of Mediterranean diet education versus posted leaflet on dietary habits and serum cholesterol in a high risk population for cardiovascular disease. Public Health Nutr. 2000;3(3):273-83. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
de Wit LT, Mathus-Vliegen L, Hey C, Rademaker B, Gouma DJ, Obertop H. Open versus laparoscopic adjustable silicone gastric banding: a prospective randomized trial for treatment of morbid obesity. Ann Surg. 1999;230(6):800-5. | Not one of the specified interventions
Donnelly JE, Kirk EP, Jacobsen DJ, Hill JO, Sullivan DK, Johnson SL. Effects of 16 mo of verified, supervised aerobic exercise on macronutrient intake in overweight men and women: the Midwest Exercise Trial. Am J Clin Nutr. 2003;78(5):950-6. | High or differential attrition
Dujovne CA, Zavoral JH, Rowe E, Mendel CM. Effects of sibutramine on body weight and serum lipids: a double-blind, randomized, placebo-controlled study in 322 overweight and obese patients with dyslipidemia. Am Heart J. 2001;142(3):489-97. | Less than 12 months followup
Muir J, Mant D, Jones L, Yudkin P. Effectiveness of health checks conducted by nurses in primary care: results of the OXCHECK study after one year. BMJ. 1994;308(6924):308-12. | Not one of the specified interventions
Eiben G, Lissner L. Health Hunters—an intervention to prevent overweight and obesity in young high-risk women. Int J Obes. 2006;30(4):691-6. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Fogelholm M, Kukkonen-Harjula K, Nenonen A, Pasanen M. Effects of walking training on weight maintenance after a very-low-energy diet in premenopausal obese women: a randomized controlled trial. Arch Intern Med. 2000;160(14):2177-84. | Does not meet design requirements in inclusion criteria
Giugliano D, Quatraro A, Consoli G, Minei A, Ceriello A, De RN, et al. Metformin for obese, insulin-treated diabetic patients: improvement in glycaemic control and reduction of metabolic risk factors. Eur J Clin Pharmacol 1993;44(2):107-12. | Less than 12 months followup
Gokcel A, Karakose H, Ertorer EM, Tanaci N, Tutuncu NB, Guvener N. Effects of sibutramine in obese female subjects with type 2 diabetes and poor blood glucose control. Diabetes Care. 2001;24(11):1957-60. | Not on list of countries with HDI >0.90
Hiratsuka VY, Loo R, Will JC, Oberrecht R, Poindexter P. Cardiovascular disease risk factor screening among Alaska Native women: the Traditions of the Heart Project. Int J Circumpolar Health. 2007;66(Suppl 1):39-44. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Imperial Cancer Research Fund OXCHECK Study Group. Effectiveness of health checks conducted by nurses in primary care: final results of the OXCHECK study. BMJ. 1995;310(6987):1099-104. | Not one of the specified interventions
Jakicic JM, Winters C, Lang W, Wing RR. Effects of intermittent exercise and use of home exercise equipment on adherence, weight loss, and fitness in overweight women: a randomized trial. JAMA. 1999;282(16):1554-60. | Does not meet design requirements in inclusion criteria
Jeffery RW, French SA. Preventing weight gain in adults: design, methods and one year results from the Pound of Prevention study. Int J Obes Relat Metab Disord. 1997;21(6):457-64. | Study of overweight/obesity prevention
Leermakers EA, Perri MG, Shigaki CL, Fuller PR. Effects of exercise-focused versus weight-focused maintenance programs on the management of obesity. Addict Behav. 1999;24(2):219-27. | Does not meet design requirements in inclusion criteria
Rothacker DQ, Staniszewski BA, Ellis PK. Liquid meal replacement vs traditional food: a potential model for women who cannot maintain eating habit change. J Am Diet Assoc. 2001;101(3):345-7. | Does not meet design requirements in inclusion criteria
Sbrocco T, Nedegaard RC, Stone JM, Lewis EL. Behavioral choice treatment promotes continuing weight loss: preliminary results of a cognitive-behavioral decision-based treatment for obesity. J Consult Clin Psychol. 1999;67(2):260-6. | Does not meet design requirements in inclusion criteria
Schriefer SP, Landis SE, Turbow DJ, Patch SC. Effect of a computerized body mass index prompt on diagnosis and treatment of adult obesity. Fam Med. 2009;41(7):502-7. | No weight outcomes
Van Gaal LF, Broom JI, Enzi G, Toplak H. Efficacy and tolerability of orlistat in the treatment of obesity: a 6-month dose-ranging study. Eur J Clin Pharmacol. 1998;54(2): 125-32. | Less than 12 months followup
Wadden TA, Berkowitz RI, Sarwer DB, Prus-Wisniewski R, Steinberg C. Benefits of lifestyle modification in the pharmacologic treatment of obesity: a randomized trial. Arch Intern Med. 2001;161(2):218-27. | Does not meet design requirements in inclusion criteria
Weiner R, Bockhorn H, Rosenthal R, Wagner D. A prospective randomized trial of different laparoscopic gastric banding techniques for morbid obesity. Surg Endosc. 2001;15(1):63-8. | Not one of the specified interventions
Wing RR, Anglin K. Effectiveness of a behavioral weight control program for blacks and whites with NIDDM. Diabetes Care. 1996;19(5):409-13. | Does not meet design requirements in inclusion criteria

Appendix D Table 2 Studies Excluded From Review for Key Question 2

Reference | Reason for Exclusion
Aadahl M, von Huth Smith L, Pisinger C, et al. Five-year change in physical activity is associated with changes in cardiovascular disease risk factors. Prev Med. 2009;48(4):326-31. | Does not meet design requirements in inclusion criteria
Acharya NV, Wilton LV, Shakir SA. Safety profile of orlistat: results of a prescription-event monitoring study. Int J Obes. 2006;30:1645-52. | Does not meet design requirements in inclusion criteria
Agurs-Collins TD, Kumanyika SK, Ten Have TR, Adams-Campbell LL. A randomized controlled trial of weight reduction and exercise for diabetes management in older African-American subjects. Diabetes Care. 1997;20:1503-11. | Less than 12 months followup
Akinson RL. Conjugated linoleic acid for altering body composition and treating obesity. In: Yurawecz MP, Mossoba MM, Kramer JK, et al, eds. Advances in Conjugated Linoleic Acid Research. Vol 1. Champaign, IL: AOCS Press; 1999:348-53. | Does not meet design requirements in inclusion criteria
Alhassan S, Kim S, Bersamin A, et al. Dietary adherence and weight loss success among overweight women: results from the A TO Z weight loss study. Int J Obes. 2008;32:985-91. | Comparative effectiveness
Allen P, Thompson JL, Herman CJ, et al. Impact of periodic follow-up testing among urban American Indian women with impaired fasting glucose. Prev Chronic Dis. 2008;5(3):A76. | Not one of the specified interventions
Andersen RE, Wadden TA, Bartlett SJ, et al. Effects of lifestyle activity vs structured aerobic exercise in obese women: a randomized trial. JAMA. 1999;281:335-40. | Comparative effectiveness
Anderson JW, Grant L, Gotthelf L, Stifler LT. Weight loss and long-term follow-up of severely obese individuals treated with an intense behavioral program. Int J Obes. 2007;31:488-93. | Does not meet design requirements in inclusion criteria
Anderssen SA, Carroll S, Urdal P, Holme I. Combined diet and exercise intervention reverses the metabolic syndrome in middle-aged males: results from the Oslo Diet and Exercise Study. Scand J Med Sci Sports. 2007;17:687-95. | No weight or harms outcomes
Anderssen SA, Holme I, Urdal P, Hjermann I. Associations between central obesity and indexes of hemostatic, carbohydrate and lipid metabolism: results of a 1-year intervention from the Oslo Diet and Exercise Study. Scand J Med Sci Sports. 1998;8:109-15. | Does not include specified weight outcomes
Andersson K, Karlstrom B, Freden S, et al. A two-year clinical lifestyle intervention program for weight loss in obesity. Food Nutr Res. 2008;52. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Andrade AM, Coutinho SR, Silva MN, et al. The effect of physical activity on weight loss is mediated by eating self-regulation. Patient Educ Couns. 2010;79(3):320-6. | No weight or harms outcomes
Annunziato RA, Timko CA, Crerand CE, et al. A randomized trial examining differential meal replacement adherence in a weight loss maintenance program after one-year follow-up. Eat Behav. 2009;10:176-83. | Comparative effectiveness
Apfelbaum M, Vague P, Ziegler O, et al. Long-term maintenance of weight loss after a very-low-calorie diet: a randomized blinded trial of the efficacy and tolerability of sibutramine. Am J Med. 1999;106:179-84. | Sibutramine intervention
Appel LJ, Champagne CM, Harsha DW, et al. Effects of comprehensive lifestyle modification on blood pressure control: main results of the PREMIER clinical trial. JAMA. 2003;289:2083-93. | Not one of the specified interventions
Appel LJ, Espeland MA, Easter L, et al. Effects of reduced sodium intake on hypertension control in older individuals: results from the Trial of Nonpharmacologic Interventions in the Elderly (TONE). Arch Intern Med. 2001;161:685-93. | No weight or harms outcomes
Arterburn D, DeLaet D, Schauer D. Obesity in adults. Clin Evid (Online). 2008. | Does not meet design requirements in inclusion criteria
Ash S, Reeves M, Bauer J, et al. A randomised control trial comparing lifestyle groups, individual counselling and written information in the management of weight and health outcomes over 12 months. Int J Obes. 2006;30:1557-64. | Comparative effectiveness
Ashley JM, St Jeor ST, Schrage JP, et al. Weight control in the physician's office. Arch Intern Med. 2001;161:1599-604. | Comparative effectiveness
Ashutosh K, Methrotra K, Fragale-Jackson J. Effects of sustained weight loss and exercise on aerobic fitness in obese women. J Sports Med Phys Fitness. 1997;37:252-7. | Comparative effectiveness
Avenell A, Brown TJ, McGee MA, et al. What are the long-term benefits of weight reducing diets in adults? A systematic review of randomized controlled trials. J Hum Nutr Diet. 2004;17:317-35. | Does not meet design requirements in inclusion criteria
Babamoto KS, Sey KA, Camilleri AJ, et al. Improving diabetes care and health measures among Hispanics using community health workers: results from a randomized controlled trial. Health Educ Behav. 2009;36:113-26. | Less than 12 months followup
Bach DS, Rissanen AM, Mendel CM, et al. Absence of cardiac valve dysfunction in obese patients treated with sibutramine. Obes Res. 1999;7:363-9. | Sibutramine intervention
Bacon L, Keim NL, Van Loan MD, et al. Evaluating a “non-diet” wellness intervention for improvement of metabolic fitness, psychological well-being and eating and activity behaviors. Int J Obes Relat Metab Disord. 2002;26:854-65. | Comparative effectiveness
Bakris G, Calhoun D, Egan B, et al. Orlistat improves blood pressure control in obese subjects with treated but inadequately controlled hypertension. J Hypertens. 2002;20:2257-67. | High or differential attrition
Balducci S, Zanuso S, Nicolucci A, et al. Anti-inflammatory effect of exercise training in subjects with type 2 diabetes and the metabolic syndrome is dependent on exercise modalities and independent of weight loss. Nutr Metab Cardiovasc Dis. 2010;20:608-17. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Barr SI, McCarron DA, Heaney RP, et al. Effects of increased consumption of fluid milk on energy and nutrient intake, body weight, and cardiovascular risk factors in healthy older adults. J Am Diet Assoc. 2000;100:810-7. | Not one of the specified interventions
Bauer C, Fischer A, Keller U. Effect of sibutramine and of cognitive-behavioural weight loss therapy in obesity and subclinical binge eating disorder. Diabetes Obes Metab. 2006;8:289-95. | Less than 12 months followup
Beck-da-Silva L, Higginson L, Fraser M, et al. Effect of orlistat in obese patients with heart failure: a pilot study. Congest Heart Fail. 2005;11:118-23. | Less than 12 months followup
Bemelmans WJ, Broer J, de Vries JH, et al. Impact of Mediterranean diet education versus posted leaflet on dietary habits and serum cholesterol in a high risk population for cardiovascular disease. Public Health Nutr. 2000;3:273-83. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Bergstrom I, Lombardo C, Brinck J. Physical training decreases waist circumference in postmenopausal borderline overweight women. Acta Obstet Gynecol Scand. 2009;88:308-13. | Focus on patients in subgroups other than specified conditions
Bhargava A, Guthrie JF. Unhealthy eating habits, physical exercise and macronutrient intakes are predictors of anthropometric indicators in the Women's Health Trial Feasibility Study In Minority Populations. Br J Nutr. 2002;88:719-28. | Not one of the specified interventions
Blumenthal JA, Sherwood A, Gullette EC, et al. Exercise and weight loss reduce blood pressure in men and women with mild hypertension: effects on cardiovascular, metabolic, and hemodynamic functioning. Arch Intern Med. 2000;160:1947-58. | Less than 12 months followup
Bo S, Ciccone G, Baldi C, et al. Effectiveness of a lifestyle intervention on metabolic syndrome: a randomized controlled trial. J Gen Intern Med. 2007;22:1695-703. | Not one of the specified interventions
Bo S, Ciccone G, Guidi S, et al. Diet or exercise: what is more effective in preventing or reducing metabolic alterations? Eur J Endocrinol. 2008;159:685-91. | Not one of the specified interventions
Borg P, Kukkonen-Harjula K, Fogelholm M, Pasanen M. Effects of walking or resistance training on weight loss maintenance in obese, middle-aged men: a randomized trial. Int J Obes Relat Metab Disord. 2002;26:676-83. | Comparative effectiveness
Botomino A, Bruppacher R, Krahenbuhl S, Hersberger KE. Change of body weight and lifestyle of persons at risk for diabetes after screening and counselling in pharmacies. Pharm World Sci. 2008;30:222-6. | Does not meet design requirements in inclusion criteria
Bowen D, Clifford CK, Coates R, et al. The Women's Health Trial Feasibility Study in Minority Populations: design and baseline descriptions. Ann Epidemiol. 1996;6:507-19. | Not one of the specified interventions
Bowen J, Noakes M, Clifton PM. A high dairy protein, high-calcium diet minimizes bone turnover in overweight adults during weight loss. J Nutr. 2004;134:568-73. | Less than 12 months followup
Bowerman S, Bellman M, Saltsman P, et al. Implementation of a primary care physician network obesity management program. Obes Res. 2001;9(Suppl 4):S321-5. | Less than 12 months followup
Bravata DM, Smith-Spangler C, Sundaram V, et al. Using pedometers to increase physical activity and improve health: a systematic review. JAMA. 2007;298:2296-304. | Does not meet design requirements in inclusion criteria
Brinkworth GD, Noakes M, Keogh JB, et al. Long-term effects of a high-protein, low-carbohydrate diet on weight control and cardiovascular risk markers in obese hyperinsulinemic subjects. Int J Obes Relat Metab Disord. 2004;28:661-70. | Comparative effectiveness
Brinkworth GD, Noakes M, Parker B, et al. Long-term effects of advice to consume a high-protein, low-fat diet, rather than a conventional weight-loss diet, in obese adults with type 2 diabetes: one-year follow-up of a randomised trial. Diabetologia. 2004;47:1677-86. | Comparative effectiveness
Broom I, Hughes E, Dodson P, Reckless J. The role of orlistat in the treatment of obese patients with mild to moderate hypercholesterolaemia: consequences for coronary risk. Br J Cardiol. 2002;9:460-8. | Less than 12 months followup
Brownell KD. The LEARN Program for Weight Management. New Haven, CT: American Health Publishing Company; 2000. | Comparative effectiveness
Bryan J, Tiggemann M. The effect of weight-loss dieting on cognitive performance and psychological well-being in overweight women. Appetite. 2001;36:147-56. | Less than 12 months followup
Buchwald H, Avidor Y, Braunwald E, et al. Bariatric surgery: a systematic review and meta-analysis. JAMA. 2004;292:1724-37. | Does not meet design requirements in inclusion criteria
Burke V, Beilin LJ, Cutt HE, et al. A lifestyle program for treated hypertensives improved health-related behaviors and cardiovascular risk factors, a randomized controlled trial. J Clin Epidemiol. 2007;60:133-41. | No weight or harms outcomes
Burke V, Mansour J, Beilin LJ, Mori TA. Long-term follow-up of participants in a health promotion program for treated hypertensives (ADAPT). Nutr Metab Cardiovasc Dis. 2008;18:198-206. | No weight or harms outcomes
Burke V, Mori TA, Giangiulio N, et al. An innovative program for changing health behaviours. Asia Pac J Clin Nutr. 2002;11(Suppl 3):S586-97. | High or differential attrition
Caan B, Neuhouser M, Aragaki A, et al. Calcium plus vitamin D supplementation and the risk of postmenopausal weight gain. Arch Intern Med. 2007;167:893-902. | Not one of the specified interventions
Calle-Pascual AL, Rodriguez C, Camacho F, et al. Behaviour modification in obese subjects with type 2 diabetes mellitus. Diabetes Res Clin Pract. 1992;15:157-62. | Does not meet design requirements in inclusion criteria
Campbell PT, Campbell KL, Wener MH, et al. A yearlong exercise intervention decreases CRP among obese postmenopausal women. Med Sci Sports Exerc. 2009;41:1533-9. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Carr DB, Utzschneider KM, Boyko EJ, et al. A reduced-fat diet and aerobic exercise in Japanese Americans with impaired glucose tolerance decreases intra-abdominal fat and improves insulin sensitivity but not beta-cell function. Diabetes. 2005;54:340-7. | Comparative effectiveness
Carr LJ, Bartee RT, Dorozynski CM, et al. Eight-month follow-up of physical activity and central adiposity: results from an Internet-delivered randomized control trial intervention. J Phys Act Health. 2009;6:444-55. | Comparative effectiveness
Castaneda C, Layne JE, Munoz-Orians L, et al. A randomized controlled trial of resistance exercise training to improve glycemic control in older adults with type 2 diabetes. Diabetes Care. 2002;25:2335-41. | Less than 12 months followup
Chang MW, Nitzke S, Brown R. Design and outcomes of a Mothers In Motion behavioral intervention pilot study. J Nutr Educ Behav. 2010;42(Suppl 3):S11-21. | Less than 12 months followup
Charles MA, Morange P, Eschwege E, et al. Effect of weight change and metformin on fibrinolysis and the von Willebrand factor in obese nondiabetic subjects: the BIGPRO1 study. Diabetes Care. 1998;21:1967-72. | No weight or harms outcomes
Cheyette C. Weight No More: a randomised controlled trial for people with type 2 diabetes on insulin therapy. Pract Diabetes Int. 2007;24:450-6. | High or differential attrition
Chiasson JL, Lau DC, Leiter LA, et al. Fluoxetine has potential in obese NIDDM—multicenter Canadian trial. Diabetes. 1989;38(Suppl 2):A154. | Not one of the specified interventions
Clark M, Hampson SE, Avery L, Simpson R. Effects of a tailored lifestyle self-management intervention in patients with type 2 diabetes. Br J Health Psychol. 2004;9:365-79. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Clarke KK, Freeland-Graves J, Klohe-Lehman DM, et al. Promotion of physical activity in low-income mothers using pedometers. J Am Diet Assoc. 2007;107:962-7. | Less than 12 months followup
Clifford PA, Tan SY, Gorsuch RL. Efficacy of a self-directed behavioral health change program: weight, body composition, cardiovascular fitness, blood pressure, health risk, and psychosocial mediating variables. J Behav Med. 1991;14:303-23. | Comparative effectiveness
Cocco G, Pandolfi S, Rousson V. Sufficient weight reduction decreases cardiovascular complications in diabetic patients with the metabolic syndrome: a randomized study of orlistat as an adjunct to lifestyle changes (diet and exercise). Heart Drug. 2005;5:68-74. | Less than 12 months followup
Coker RH, Williams RH, Yeo SE, et al. The impact of exercise training compared to caloric restriction on hepatic and peripheral insulin resistance in obesity. J Clin Endocrinol Metabol. 2009;94:4258-66. | Less than 12 months followup
Corpeleijn E, Feskens EJ, Jansen EH, et al. Improvements in glucose tolerance and insulin sensitivity after lifestyle intervention are related to changes in serum fatty acid profile and desaturase activities: the SLIM study. Diabetologia. 2006;49:2392-401. | Not one of the specified interventions
Counterweight Project Team. Evaluation of the Counterweight Programme for obesity management in primary care: a starting point for continuous improvement. Br J Gen Pract. 2008;58:548-54. | Does not meet design requirements in inclusion criteria
Counterweight Project Team. Influence of body mass index on prescribing costs and potential cost savings of a weight management programme in primary care. J Health Serv Res Policy. 2008;13:158-66. | Does not meet design requirements in inclusion criteria
Cousins JH, Rubovits DS, Dunn JK, et al. Family versus individually oriented intervention for weight loss in Mexican American women. Public Health Rep. 1992;107:549-55. | Comparative effectiveness
Cuellar GE, Ruiz AM, Monsalve MC, Berber A. Six-month treatment of obesity with sibutramine 15 mg; a double-blind, placebo-controlled monocenter clinical trial in a Hispanic population. Obes Res. 2000;8:71-82. | Not on list of countries with HDI > 0.90
Culturally appropriate lifestyle interventions promote weight loss in rural dwelling people with type 2 diabetes. Evid Based Healthc Pub Health. 2005;9:231-2. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Dale KS, Mann JI, McAuley KA, et al. Sustainability of lifestyle changes following an intensive lifestyle intervention in insulin resistant adults: follow-up at 2-years. Asia Pac J Clin Nutri. 2009;18:114-20. | Comparative effectiveness
Dale KS, McAuley KA, Taylor RW, et al. Determining optimal approaches for weight maintenance: a randomized controlled trial. Can Med Assoc J. 2009;180:E39-46. | Comparative effectiveness
Davies MJ, Heller S, Skinner TC, et al. Effectiveness of the Diabetes Education and Self Management for Ongoing and Newly Diagnosed (DESMOND) programme for people with newly diagnosed type 2 diabetes: cluster randomised controlled trial. BMJ. 2008;336:491-5. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Davis BR, Blaufox MD, Oberman A, et al. Reduction in long-term antihypertensive medication requirements: effects of weight reduction by dietary intervention in overweight persons with mild hypertension. Arch Intern Med. 1993;153:1773-82. | No weight or harms outcomes
de Wit LT, Mathus-Vliegen L, Hey C, et al. Open versus laparoscopic adjustable silicone gastric banding: a prospective randomized trial for treatment of morbid obesity. Ann Surg. 1999;230:800-5. | Not one of the specified interventions
Delahanty LM, Nathan DM. Implications of the Diabetes Prevention Program and Look AHEAD clinical trials for lifestyle interventions. J Am Diet Assoc. 2008;108(Suppl 1):S66-72. | Comparative effectiveness
Delecluse C, Colman V, Roelants M, et al. Exercise programs for older men: mode and intensity to induce the highest possible health-related benefits. Prev Med. 2004;39:823-33. | Less than 12 months followup
Dennis KE, Tomoyasu N, McCrone SH, et al. Self-efficacy targeted treatments for weight loss in postmenopausal women. Sch Inq Nurs Pract. 2001;15:259-76. | Comparative effectiveness
Derosa G, Cicero AF, Murdolo G, et al. Efficacy and safety comparative evaluation of orlistat and sibutramine treatment in hypertensive obese patients. Diabetes Obes Metab. 2005;7:47-55. | Comparative effectiveness
Devine A, Prince RL, Bell R. Nutritional effect of calcium supplementation by skim milk powder or calcium tablets on total nutrient intake in postmenopausal women. Am J Clin Nutr. 1996;64:731-7. | Comparative effectiveness
Di Francesco V, Sacco T, Zamboni M, et al. Weight loss and quality of life improvement in obese subjects treated with sibutramine: a double-blind randomized multicenter study. Ann Nutr Metab. 2007;51:75-81. | Sibutramine intervention
Di Loreto C, Fanelli C, Lucidi P, et al. Validation of a counseling strategy to promote the adoption and the maintenance of physical activity by type 2 diabetic subjects. Diabetes Care. 2003;26:404-8. | Comparative effectiveness
Ditschuneit HH, Flechtner-Mors M, Johnson TD, Adler G. Metabolic and weight-loss effects of a long-term dietary intervention in obese patients. Am J Clin Nutr. 1999;69:198-204. | Comparative effectiveness
Donnelly JE, Hill JO, Jacobsen DJ, et al. Effects of a 16-month randomized controlled exercise trial on body weight and composition in young, overweight men and women: the Midwest Exercise Trial. Arch Intern Med. 2003;163:1343-50. | High or differential attrition
Donnelly JE, Jacobsen DJ, Heelan KS, et al. The effects of 18 months of intermittent vs. continuous exercise on aerobic capacity, body weight and composition, and metabolic fitness in previously sedentary, moderately obese females. Int J Obes Relat Metab Disord. 2000;24:566-72. | Comparative effectiveness
Donnelly JE, Kirk EP, Jacobsen DJ, et al. Effects of 16 mo of verified, supervised aerobic exercise on macronutrient intake in overweight men and women: the Midwest Exercise Trial. Am J Clin Nutr. 2003;78:950-6. | High or differential attrition
Donnelly JE, Smith BK, Dunn L, et al. Comparison of a phone vs clinic approach to achieve 10% weight loss. Int J Obes (London). 2007;31:1270-6. | Less than 12 months followup
Due A, Larsen TM, Mu H, et al. Comparison of 3 ad libitum diets for weight-loss maintenance, risk of cardiovascular disease, and diabetes: a 6-mo randomized, controlled trial. Am J Clin Nutr. 2008;88:1232-41. | Less than 12 months followup
Dujovne CA, Zavoral JH, Rowe E, Mendel CM. Effects of sibutramine on body weight and serum lipids: a double-blind, randomized, placebo-controlled study in 322 overweight and obese patients with dyslipidemia. Am Heart J. 2001;142:489-97. | Sibutramine intervention
Dunn AL, Marcus BH, Kampert JB, et al. Comparison of lifestyle and structured interventions to increase physical activity and cardiorespiratory fitness: a randomized trial. JAMA. 1999;281:327-34. | Comparative effectiveness
Dunstan DW, Daly RM, Owen N, et al. Home-based resistance training is not sufficient to maintain improved glycemic control following supervised training in older individuals with type 2 diabetes. Diabetes Care. 2005;28:3-9. | Comparative effectiveness
Dutton GR, Davis MP, Welsch MA, Brantley PJ. Promoting physical activity for low-income minority women in primary care. Am J Health Behav. 2007;31:622-31. | No weight or harms outcomes
Dymek MP, Le Grange D, Neven K, Alverdy J. Quality of life after gastric bypass surgery: a cross-sectional study. Obes Res. 2002;10:1135-42. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Dymek MP, Le Grange D, Neven K, Alverdy J. Quality of life and psychosocial adjustment in patients after Roux-en-Y gastric bypass: a brief report. Obes Surg. 2001;11:32-9. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Dyson PA, Hammersley MS, Morris RJ, et al. The Fasting Hyperglycaemia Study, II: randomized controlled trial of reinforced healthy-living advice in subjects with increased but not diabetic fasting plasma glucose. Metabolism. 1997;46:50-5. | Not one of the specified interventions
Dzator JA, Hendrie D, Burke V, et al. A randomized trial of interactive group sessions achieved greater improvements in nutrition and physical activity at a tiny increase in cost. J Clin Epidemiol. 2004;57:610-19. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Early JL, Apovian CM, Aronne LJ, et al. Sibutramine plus meal replacement therapy for body weight loss and maintenance in obese patients. Obesity (Silver Spring). 2007;15:1464-72. | Sibutramine intervention
Eddy DM, Schlessinger L, Kahn R. Clinical outcomes and cost-effectiveness of strategies for managing people at high risk for diabetes. Ann Intern Med. 2005;143:251-64. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Eiben G, Lissner L. Health Hunters—an intervention to prevent overweight and obesity in young high-risk women. Int J Obes. 2006;30:691-6. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Elhayany A, Lustman A, Abel R, et al. A low carbohydrate Mediterranean diet improves cardiovascular risk factors and diabetes control among overweight patients with type 2 diabetes mellitus: a 1-year prospective randomized intervention study. Diabetes Obes Metab. 2010;12:204-9. | Comparative effectiveness
Elmer PJ, Obarzanek E, Vollmer WM, et al. Effects of comprehensive lifestyle modification on diet, weight, physical fitness, and blood pressure control: 18-month results of a randomized trial. Ann Intern Med. 2006;144:485-95. | Comparative effectiveness
Ely AC, Banitt A, Befort C, et al. Kansas primary care weighs in: a pilot randomized trial of a chronic care model program for obesity in 3 rural Kansas primary care practices. J Rural Health. 2008;24:125-32. | Less than 12 months followup
Eriksson KM, Westborg CJ, Eliasson MC. A randomized trial of lifestyle intervention in primary healthcare for the modification of cardiovascular risk factors. Scand J Pub Health. 2006;34:453-61. | Not one of the specified interventions
Esposito K, Giugliano F, Di Palo C, et al. Effect of lifestyle changes on erectile dysfunction in obese men: a randomized controlled trial. JAMA. 2004;291:2978-84. | Comparative effectiveness
Esposito K, Marfella R, Ciotola M, et al. Effect of a Mediterranean-style diet on endothelial dysfunction and markers of vascular inflammation in the metabolic syndrome: a randomized trial. JAMA. 2004;292:1440-6. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Esposito K, Pontillo A, Di Palo C, et al. Effect of weight loss and lifestyle changes on vascular inflammatory markers in obese women: a randomized trial. JAMA. 2003;289:1799-804. | Comparative effectiveness
Fabricatore AN, Wadden TA, Moore RH, et al. Predictors of attrition and weight loss success: results from a randomized controlled trial. Behav Res Ther. 2009;47:685-91. | Comparative effectiveness
Fanghanel G, Cortinas L, Sanchez-Reyes L, Berber A. A clinical trial of the use of sibutramine for the treatment of patients suffering essential obesity. Int J Obes Relat Metab Disord. 2000;24:144-50. | Less than 12 months followup
Fanghanel G, Cortinas L, Sanchez-Reyes L, et al. Safety and efficacy of sibutramine in overweight Hispanic patients with hypertension. Adv Ther. 2003;20:101-13. | Less than 12 months followup
Faria AN, Ribeiro Filho FF, Kohlmann NE, et al. Effects of sibutramine on abdominal fat mass, insulin resistance and blood pressure in obese hypertensive patients. Diabetes Obes Metab. 2005;7:246-53. | Less than 12 months followup
Faria AN, Ribeiro Filho FF, Lerario DD, et al. Effects of sibutramine on the treatment of obesity in patients with arterial hypertension. Arq Bras Cardiol. 2002;78:172-80. | Less than 12 months followup
Faulconbridge LF, Wadden TA, Berkowitz RI, et al. Changes in symptoms of depression with weight loss: results of a randomized trial. Obesity (Silver Spring). 2009;17:1009-16. | No placebo in medication trial
Ferre R, Plana N, Merino J, et al. Effects of therapeutic lifestyle changes on peripheral artery tonometry in patients with abdominal obesity. Nutr Metab Cardiovasc Dis. 2010 Aug 11. [Epub ahead of print] | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Figueroa A, Going SB, Milliken LA, et al. Effects of exercise training and hormone replacement therapy on lean and fat mass in postmenopausal women. J Gerontol A Biol Sci Med Sci. 2003;58:266-70. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Finer N, Bloom SR, Frost GS, et al. Sibutramine is effective for weight loss and diabetic control in obesity with type 2 diabetes: a randomised, double-blind, placebo-controlled study. Diabetes Obes Metab. 2000;2:105-12. | Sibutramine intervention
Finkelstein EA, Linnan LA, Tate DF, Leese PJ. A longitudinal study on the relationship between weight loss, medical expenditures, and absenteeism among overweight employees in the WAY to Health study. J Occup Environ Med. 2009;51:1367-73. | Conducted primarily in a non-relevant setting
Finley CE, Barlow CE, Greenway FL, et al. Retention rates and weight loss in a commercial weight loss program. Int J Obes (Lond). 2007;31:292-8. | Does not meet design requirements in inclusion criteria
Fitzgibbon ML, Stolley MR, Schiffer L, et al. Obesity Reduction Black Intervention Trial (ORBIT): 18-month results. Obesity (Silver Spring). 2010;18:2317-25. | No weight or harms outcomes
Flechtner-Mors M, Ditschuneit HH, Johnson TD, et al. Metabolic and weight loss effects of long-term dietary intervention in obese patients: four-year results. Obes Res. 2000;8:399-402. | Comparative effectiveness
Fleming RM. The effect of high-, moderate-, and low-fat diets on weight loss and cardiovascular disease risk factors. Prev Cardiol. 2002;5:110-8. | Comparative effectiveness
Flood A, Mitchell N, Jaeb M, et al. Energy density and weight change in a long-term weight-loss trial. Int J Behav Nutr Phys Act. 2009;6:57. | Study of overweight/obesity prevention
Focht BC, Rejeski WJ, Ambrosius WT, et al. Exercise, self-efficacy, and mobility performance in overweight and obese older adults with knee osteoarthritis. Arthritis Rheum. 2005;53:659-65. | Comparative effectiveness
Fogelholm M, Kukkonen-Harjula K, Nenonen A, Pasanen M. Effects of walking training on weight maintenance after a very-low-energy diet in premenopausal obese women: a randomized controlled trial. Arch Intern Med. 2000;160:2177-84. | Comparative effectiveness
Fogelholm M, Kukkonen-Harjula K, Oja P. Eating control and physical activity as determinants of short-term weight maintenance after a very-low-calorie diet among obese women. Int J Obes Relat Metab Disord. 1999;23:203-10. | Comparative effectiveness
Fontana L, Villareal DT, Weiss EP, et al. Calorie restriction or exercise: effects on coronary heart disease risk factors: a randomized, controlled trial. Am J Physiol Endocrinol Metab. 2007;293:E197-202. | Comparative effectiveness
Fontbonne A, Diouf I, Baccara-Dinet M, et al. Effects of 1-year treatment with metformin on metabolic and cardiovascular risk factors in non-diabetic upper-body obese subjects with mild glucose anomalies: a post-hoc analysis of the BIGPRO1 trial. Diabetes Metab. 2009;35:385-91. | No weight or harms outcomes
Fossati M, Amati F, Painot D, et al. Cognitive-behavioral therapy with simultaneous nutritional and physical activity education in obese patients with binge eating disorder. Eat Weight Disord. 2004;9:134-8. | Focus on patients in subgroups other than specified conditions
Foster GD, Borradaile KE, Sanders MH, et al. A randomized study on the effect of weight loss on obstructive sleep apnea among obese patients with type 2 diabetes: the Sleep AHEAD study. Arch Intern Med. 2009;169:1619-26. | Comparative effectiveness
Foster GD, Wyatt HR, Hill JO, et al. A randomized trial of a low-carbohydrate diet for obesity. N Engl J Med. 2003;348:2082-90. | Comparative effectiveness
Foster-Schubert KE, McTiernan A, Frayo RS, et al. Human plasma ghrelin levels increase during a one-year exercise program. J Clin Endocrinol Metab. 2005;90:820-5. | No weight or harms outcomes
Fujimoto WY, Jablonski KA, Bray GA, et al. Body size and shape changes and the risk of diabetes in the Diabetes Prevention Program. Diabetes. 2007;56:1680-5. | No weight or harms outcomes
Gambineri A, Pelusi C, Genghini S, et al. Effect of flutamide and metformin administered alone or in combination in dieting obese women with polycystic ovary syndrome. Clin Endocrinol. 2004;60:241-9. | No weight or harms outcomes
Gaullier JM, Halse J, Hoye K, et al. Conjugated linoleic acid supplementation for 1 y reduces body fat mass in healthy overweight humans. Am J Clin Nutr. 2004;79:1118-25. | Not one of the specified interventions
Gaullier JM, Halse J, Hoye K, et al. Supplementation with conjugated linoleic acid for 24 months is well tolerated by and reduces body fat mass in healthy, overweight humans. J Nutr. 2005;135:778-84. | Not one of the specified interventions
Ghroubi S, Elleuch H, Chikh T, et al. Physical training combined with dietary measures in the treatment of adult obesity: a comparison of two protocols. Ann Phys Rehab Med. 2009;52:394-413. | Not on list of countries with HDI > 0.90
Giugliano D, Quatraro A, Consoli G, et al. Metformin for obese, insulin-treated diabetic patients: improvement in glycaemic control and reduction of metabolic risk factors. Eur J Clin Pharmacol. 1993;44:107-12. | Less than 12 months followup
Glasgow RE, La Chance PA, Toobert DJ, et al. Long-term effects and costs of brief behavioural dietary intervention for patients with diabetes delivered from the medical office. Patient Educ Couns. 1997;32:175-84. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Glasgow RE, Nelson CC, Kearney KA, et al. Reach, engagement, and retention in an Internet-based weight loss program in a multi-site randomized controlled trial. J Med Internet Res. 2007;9:e11. | No weight or harms outcomes
Godoy-Matos A, Carraro L, Vieira A, et al. Treatment of obese adolescents with sibutramine: a randomized, double-blind, controlled study. J Clin Endocrinol Metab. 2005;90:1460-5. | Focus on children or adolescents
Gokcel A, Gumurdulu Y, Karakose H, et al. Evaluation of the safety and efficacy of sibutramine, orlistat and metformin in the treatment of obesity. Diabetes Obes Metab. 2002;4:49-55. | Comparative effectiveness
Gokcel A, Karakose H, Ertorer EM, et al. Effects of sibutramine in obese female subjects with type 2 diabetes and poor blood glucose control. Diabetes Care. 2001;24:1957-60. | Not on list of countries with HDI >0.90
Gold BC, Burke S, Pintauro S, et al. Weight loss on the web: a pilot study comparing a structured behavioral intervention to a commercial program. Obesity (Silver Spring). 2007;15:155-64. | Comparative effectiveness
Gotfredsen A, Westergren HH, Andersen T. Influence of orlistat on bone turnover and body composition. Int J Obes Relat Metab Disord. 2001;25:1154-60. | No weight or harms outcomes
Greaves CJ, Middlebrooke A, O'Loughlin L, et al. Motivational interviewing for modifying diabetes risk: a randomised controlled trial. Br J Gen Pract. 2008;58:535-40. | Less than 12 months followup
Grimm RH Jr, Grandits GA, Cutler JA, et al. Relationships of quality-of-life measures to long-term lifestyle and drug treatment in the Treatment of Mild Hypertension Study. Arch Intern Med. 1997;157:638-48. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Guisado JA, Vaz FJ, Alarcon J, et al. Psychopathological status and interpersonal functioning following weight loss in morbidly obese patients undergoing bariatric surgery. Obes Surg. 2002;12:835-40. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Gunther CW, Legowski PA, Lyle RM, et al. Dairy products do not lead to alterations in body weight or fat mass in young women in a 1-y intervention. Am J Clin Nutr. 2005;81:751-6. | Study of overweight/obesity prevention
Gurka MJ, Wolf AM, Conaway MR, et al. Lifestyle intervention in obese patients with type 2 diabetes: impact of the patient's educational background. Obesity (Silver Spring). 2006;14:1085-92. | Comparative effectiveness
Gustafson A, Khavjou O, Stearns SC, et al. Cost-effectiveness of a behavioral weight loss intervention for low-income women: the Weight-Wise Program. Prev Med. 2009;49:390-5. | Less than 12 months followup
Guy-Grand B, Drouin P, Eschwege E, et al. Effects of orlistat on obesity-related diseases—a six-month randomized trial. Diabetes Obes Metab. 2004;6:375-83. | Less than 12 months followup
Hainer V, Kunesova M, Bellisle F, et al. Psychobehavioral and nutritional predictors of weight loss in obese women treated with sibutramine. Int J Obes (Lond). 2005;29:208-16. | Less than 12 months followup
Hakala K, Maasilta P, Sovijarvi AR. Upright body position and weight loss improve respiratory mechanics and daytime oxygenation in obese patients with obstructive sleep apnoea. Clin Physiol. 2000;20:50-5. | Does not meet design requirements in inclusion criteria
Hall WD, Feng Z, George VA, et al. Low-fat diet: effect on anthropometrics, blood pressure, glucose, and insulin in older women. Ethn Dis. 2003;13:337-43. | Less than 12 months followup
Hansen D, Astrup A, Toubro S, et al. Predictors of weight loss and maintenance during 2 years of treatment by sibutramine in obesity: results from the European multi-centre STORM trial. Int J Obes Rel Metab Dis. 2001;25:496-501. | High or differential attrition
Hansen DL, Toubro S, Stock MJ, et al. The effect of sibutramine on energy expenditure and appetite during chronic treatment without dietary restriction. Int J Obes Relat Metab Disord. 1999;23:1016-24. | Sibutramine intervention
Harvey BJ, Gold BC, Lauber R, Starinski A. The impact of calcium and dairy product consumption on weight loss. Obes Res. 2005;13:1720-6. | Comparative effectiveness
Harvey-Berino J, Pintauro S, Buzzell P, et al. Does using the Internet facilitate the maintenance of weight loss? Int J Obes Relat Metab Disord. 2002;26:1254-60. | Comparative effectiveness
Harvey-Berino J, Pintauro S, Buzzell P, Gold EC. Effect of internet support on the long-term maintenance of weight loss. Obes Res. 2004;12:320-9. | Comparative effectiveness
Harvey-Berino J, Pintauro SJ, Gold EC. The feasibility of using Internet support for the maintenance of weight loss. Behav Modif. 2002;26:103-16. | Less than 12 months followup
Haskell WL, Alderman EL, Fair JM, et al. Effects of intensive multiple risk factor reduction on coronary atherosclerosis and clinical cardiac events in men and women with coronary artery disease: the Stanford Coronary Risk Intervention Project (SCRIP). Circulation. 1994;89:975-90. | Not one of the specified interventions
Haub MD, Simons TR, Cook CM, et al. Calcium-fortified beverage supplementation on body composition in postmenopausal women. Nutr J. 2005;4:21. | Not one of the specified interventions
Hauner H, Meier M, Wendland G, et al. Weight reduction by sibutramine in obese subjects in primary care medicine: the SAT Study. Exp Clin Endocrinol Diabetes. 2004;112:201-7. | Sibutramine intervention
Hawley G, Horwath C, Gray A, et al. Sustainability of health and lifestyle improvements following a non-dieting randomised trial in overweight women. Prev Med. 2008;47:593-9. | Comparative effectiveness
Hays NP, Starling RD, Sullivan DH, et al. Effects of an ad libitum, high carbohydrate diet and aerobic exercise training on insulin action and muscle metabolism in older men and women. J Gerontol A Biol Sci Med Sci. 2006;61:299-304. | Comparative effectiveness
Hazenberg BP. Randomized, double-blind, placebo-controlled, multicenter study of sibutramine in obese hypertensive patients. Cardiology. 2000;94:152-8. | Sibutramine intervention
Hensrud DD. Dietary treatment and long-term weight loss and maintenance in type 2 diabetes. Obes Res. 2001;9(Suppl 4):S348-53. | Does not meet design requirements in inclusion criteria
Herman WH, Hoerger TJ, Brandle M, et al. The cost-effectiveness of lifestyle modification or metformin in preventing type 2 diabetes in adults with impaired glucose tolerance. Ann Intern Med. 2005;142:323-32. | No weight or harms outcomes
Hermann LS, Kalen J, Katzman P, et al. Long-term glycaemic improvement after addition of metformin to insulin in insulin-treated obese type 2 diabetes patients. Diabetes Obes Metab. 2001;3:428-34. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Heshka S, Anderson JW, Atkinson RL, et al. Weight loss with self-help compared with a structured commercial program: a randomized trial. JAMA. 2003;289:1792-8. | Comparative effectiveness
Heymsfield SB, Segal KR, Hauptman J, et al. Effects of weight loss with orlistat on glucose tolerance and progression to type 2 diabetes in obese adults. Arch Intern Med. 2000;160:1321-6. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Hivert MF, Langlois MF, Berard P, et al. Prevention of weight gain in young adults through a seminar-based intervention program. Int J Obes (London). 2007;31:1262-9. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Hoeger KM, Kochman L, Wixom N, et al. A randomized, 48-week, placebo-controlled trial of intensive lifestyle modification and/or metformin therapy in overweight women with polycystic ovary syndrome: a pilot study. Fertil Steril. 2004;82:421-9. | High or differential attrition
Hooper L. Primary prevention of CVD: diet and weight loss. Clin Evid. 2007. | Does not meet design requirements in inclusion criteria
Hope AA, Kumanyika SK, Shults J, Holmes WC. Changes in health-related quality of life among African-Americans in a lifestyle weight loss program. Qual Life Res. 2010;19:1025-33. | Does not meet design requirements in inclusion criteria
Howard BV, Manson JE, Stefanick ML, et al. Low-fat dietary pattern and weight change over 7 years: the Women's Health Initiative Dietary Modification Trial. JAMA. 2006;295:39-49. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Hsieh CJ, Wang PW, Liu RT, et al. Orlistat for obesity: benefits beyond weight loss. Diabetes Res Clin Pract. 2005;67:78-83. | Not on list of countries with HDI > 0.90
Hunter GR, Brock DW, Byrne NM, et al. Exercise training prevents regain of visceral fat for 1 year following weight loss. Obesity. 2010;18:690-5. | Comparative effectiveness
Jacobs DR, Sluik D, Rokling-Andersen MH, et al. Association of 1-y changes in diet pattern with cardiovascular disease risk factors and adipokines: results from the 1-y randomized Oslo Diet and Exercise Study. Am J Clin Nutr. 2009;89:509-17. | No weight or harms outcomes
Jakicic JM, Jaramillo SA, Balasubramanyam A, et al. Effect of a lifestyle intervention on change in cardiorespiratory fitness in adults with type 2 diabetes: results from the Look AHEAD Study. Int J Obes. 2009;33:305-16. | Comparative effectiveness
Jakicic JM, Marcus BH, Gallagher KI, et al. Effect of exercise duration and intensity on weight loss in overweight, sedentary women: a randomized trial. JAMA. 2003;290:1323-30. | Comparative effectiveness
Jakicic JM, Otto AD, Lang W, et al. The effect of physical activity on 18-month weight change in overweight adults. Obesity (Silver Spring). 2011;19:100-9. | Comparative effectiveness
Jakicic JM, Winters C, Lang W, Wing RR. Effects of intermittent exercise and use of home exercise equipment on adherence, weight loss, and fitness in overweight women: a randomized trial. JAMA. 1999;282:1554-60. | Comparative effectiveness
Jalkanen L. The effect of a weight reduction program on cardiovascular risk factors among overweight hypertensives in primary health care. Scand J Soc Med. 1991;19:66-71. | Other quality issues
James WP, Astrup A, Finer N, et al. Effect of sibutramine on weight maintenance after weight loss: a randomised trial. Lancet. 2000;356:2119-25. | Sibutramine intervention
Janssen I, Fortier A, Hudson R, Ross R. Effects of an energy-restrictive diet with or without exercise on abdominal fat, intermuscular fat, and metabolic risk factors in obese women. Diabetes Care. 2002;25:431-8. | Comparative effectiveness
Jarjou LM, Prentice A, Sawo Y, et al. Randomized, placebo-controlled, calcium supplementation study in pregnant Gambian women: effects on breast-milk calcium concentrations and infant birth weight, growth, and bone mineral accretion in the first year of life. Am J Clin Nutr. 2006;83:657-66. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Jarrett RJ, Keen H, Murrells T. Changes in blood pressure and body weight over ten years in men selected for glucose intolerance. J Epidemiol Community Health. 1987;41:145-51. | Comparative effectiveness
Jeffery RW, French SA. Preventing weight gain in adults: design, methods and one year results from the Pound of Prevention study. Int J Obes Relat Metab Disord. 1997;21:457-64. | Study of overweight/obesity prevention
Jeffery RW, Wing RR, Sherwood NE, Tate DF. Physical activity and weight loss: does prescribing higher physical activity goals improve outcome? Am J Clin Nutr. 2003;78:684-9. | Comparative effectiveness
Jehn ML, Patt MR, Appel LJ, Miller ER III. One year follow-up of overweight and obese hypertensive adults following intensive lifestyle therapy. J Hum Nutr Diet. 2006;19:349-54. | Comparative effectiveness
Jensen LB, Kollerup G, Quaade F, Sorensen OH. Bone minerals changes in obese women during a moderate weight loss with and without calcium supplementation. J Bone Miner Res. 2001;16:141-7. | Less than 12 months followup
Jirik-Babb P, Geliebter A. Comparison of psychological characteristics of binging and nonbinging obese, adult, female outpatients. Eat Weight Disord. 2003;8:173-7. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Johansson K, Neovius M, Lagerros YT, et al. Effect of a very low energy diet on moderate and severe obstructive sleep apnoea in obese men: a randomised controlled trial. BMJ. 2009;339:b4609. | Less than 12 months followup
Jordan J, Scholze J, Matiba B, et al. Influence of sibutramine on blood pressure: evidence from placebo-controlled trials. Int J Obes. 2005;29:509-16. | Does not meet design requirements in inclusion criteria
Kajaste S, Brander PE, Telakivi T, et al. A cognitive-behavioral weight reduction program in the treatment of obstructive sleep apnea syndrome with or without initial nasal CPAP: a randomized study. Sleep Med. 2004;5:125-31. | Not one of the specified interventions
Kalter-Leibovici O, Younis-Zeidan N, Atamna A, et al. Lifestyle intervention in obese Arab women: a randomized controlled trial. Arch Intern Med. 2010;170:970-6. | Comparative effectiveness
Kamioka H, Nakamura Y, Okada S, et al. Effectiveness of comprehensive health education combining lifestyle education and hot spa bathing for male white-collar employees: a randomized controlled trial with 1-year follow-up. J Epidemiol. 2009;19:219-30. | Conducted primarily in a non-relevant setting
Kansanen M, Vanninen E, Tuunainen A, et al. The effect of a very low-calorie diet-induced weight loss on the severity of obstructive sleep apnoea and autonomic nervous function in obese patients with obstructive sleep apnoea syndrome. Clin Physiol. 1998;18:377-85. | Does not meet design requirements in inclusion criteria
Karhunen L, Franssila-Kallunki A, Rissanen P, et al. Effect of orlistat treatment on body composition and resting energy expenditure during a two-year weight-reduction programme in obese Finns. Int J Obes Relat Metab Disord. 2000;24:1567-72. | No weight or harms outcomes
Katzer L, Bradshaw AJ, Horwath CC, et al. Evaluation of a “nondieting” stress reduction program for overweight women: a randomized trial. Am J Health Promot. 2008;22:264-74. | Comparative effectiveness
Kaukua JK, Pekkarinen TA, Rissanen AM. Health-related quality of life in a randomised placebo-controlled trial of sibutramine in obese patients with type II diabetes. Int J Obes Relat Metab Disord. 2004;28:600-5. | Sibutramine intervention
Kawano M, Shono N, Yoshimura T, et al. Improved cardio-respiratory fitness correlates with changes in the number and size of small dense LDL: randomized controlled trial with exercise training and dietary instruction. Intern Med. 2009;48:25-32. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Keating GM, Jarvis B. Orlistat: in the prevention and treatment of type 2 diabetes mellitus. Drugs. 2120;61:2107-19. | Does not meet design requirements in inclusion criteria
Kelley DE, Bray GA, Pi-Sunyer FX, et al. Clinical efficacy of orlistat therapy in overweight and obese patients with insulin-treated type 2 diabetes: a 1-year randomized controlled trial. Diabetes Care. 2002;25:1033-41. | High or differential attrition
Keogh JB, Luscombe-Marsh ND, Noakes M, et al. Long-term weight maintenance and cardiovascular risk factors are not different following weight loss on carbohydrate-restricted diets high in either monounsaturated fat or protein in obese hyperinsulinaemic men and women. Br J Nutr. 2007;97:405-10. | Comparative effectiveness
Keranen AM, Savolainen MJ, Reponen AH, et al. The effect of eating behavior on weight loss and maintenance during a lifestyle intervention. Prev Med. 2009;49:32-8. | Comparative effectiveness
Kerr J, Patrick K, Norman G, et al. Randomized control trial of a behavioral intervention for overweight women: impact on depressive symptoms. Depress Anxiety. 2008;25:555-8. | No weight or harms outcomes
Ketola E, Makela M, Klockars M. Individualised multifactorial lifestyle intervention trial for high-risk cardiovascular patients in primary care. Br J Gen Pract. 2001;51:291-4. | Not one of the specified interventions
Kim SH, Lee YM, Jee SH, Nam CM. Effect of sibutramine on weight loss and blood pressure: a meta-analysis of controlled trials. Obes Res. 2003;11:1116-23. | Does not meet design requirements in inclusion criteria
Kim SI, Kim HS. Effectiveness of mobile and Internet intervention in patients with obese type 2 diabetes. Int J Med Inf. 2008;77:399-404. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Kim Y, Pike J, Adams H, et al. Telephone intervention promoting weight-related health behaviors. Prev Med. 2010;50:112-7. | Comparative effectiveness
Kirk EP, Jacobsen DJ, Gibson C, et al. Time course for changes in aerobic capacity and body composition in overweight men and women in response to long-term exercise: the Midwest Exercise Trial (MET). Int J Obes Relat Metab Disord. 2003;27:912-9. | High or differential attrition
Kirk SF, Harvey EL, McConnon A, et al. A randomised trial of an Internet weight control resource: the UK Weight Control Trial. BMC Health Serv Res. 2003;3:19. | No weight or harms outcomes
Knowler WC, Fowler SE, Hamman RF, et al. 10-year follow-up of diabetes incidence and weight loss in the Diabetes Prevention Program Outcomes Study. Lancet. 2009;274:1677-86. | No weight or harms outcomes
Kolotkin RL, Norquist JM, Crosby RD, et al. One-year health-related quality of life outcomes in weight loss trial participants: comparison of three measures. Health Qual Life Outcomes. 2009;7:53. | Not one of the specified interventions
Kostis JB, Wilson AC, Hooper WC, et al. Association of angiotensin-converting enzyme DD genotype with blood pressure sensitivity to weight loss. Am Heart J. 2002;144:625-9. | No weight or harms outcomes
Kostis JB, Wilson AC, Shindler DM, et al. Persistence of normotension after discontinuation of lifestyle intervention in the trial of TONE. Am J Hypertens. 2002;15:732-4. | No weight or harms outcomes
Krakoff J, Clark JM, Crandall JP, et al. Effects of metformin and weight loss on serum alanine aminotransferase activity in the Diabetes Prevention Program. Obesity (Silver Spring). 2010;18:1762-7. | No weight or harms outcomes
Kraus WE, Houmard JA, Duscha BD, et al. Effects of the amount and intensity of exercise on plasma lipoproteins. N Engl J Med. 2002;347:1483-92. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Kukkonen-Harjula KT, Borg PT, Nenonen AM, Fogelholm MG. Effects of a weight maintenance program with or without exercise on the metabolic syndrome: a randomized trial in obese men. Prev Med. 2005;41:784-90. | Comparative effectiveness
Kuller LH, Kinzel LS, Pettee KK, et al. Lifestyle intervention and coronary heart disease risk factor changes over 18 months in postmenopausal women: the Women On the Move Through Activity and Nutrition (WOMAN study) clinical trial. J Womens Health (Larchmt). 2006;15:962-74. | Comparative effectiveness
Kuller LH, Kriska AM, Kinzel LS, et al. The clinical trial of Women On the Move Through Activity and Nutrition (WOMAN) study. Contemp Clin Trials. 2006;28:370-81. | Comparative effectiveness
Kumanyika SK, Cook NR, Cutler JA, et al. Sodium reduction for hypertension prevention in overweight adults: further results from the Trials of Hypertension Prevention phase II. J Hum Hypertens. 2005;19:33-45. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Kumanyika SK, Shults J, Fassbender J, et al. Outpatient weight management in African-Americans: the Healthy Eating and Lifestyle Program (HELP) study. Prev Med. 2005;41:488-502. | Comparative effectiveness
Kumanyika SK, Wadden TA, Shults J, et al. Trial of family and friend support for weight loss in African American adults. Arch Intern Med. 2009;169:1795-804. | Comparative effectiveness
Laaksonen DE, Laitinen T, Schonberg J, et al. Weight loss and weight maintenance, ambulatory blood pressure and cardiac autonomic tone in obese persons with the metabolic syndrome. J Hypertens. 2003;21:371-8. | No weight or harms outcomes
Laaksonen DE, Lindstrom J, Lakka TA, et al. Physical activity in the prevention of type 2 diabetes: the Finnish Diabetes Prevention Study. Diabetes. 2005;54:158-65. | No weight or harms outcomes
Lally P, Chipperfield A, Wardle J. Healthy habits: efficacy of simple advice on weight control based on a habit-formation model. Int J Obes (Lond). 2008;32:700-7. | Less than 12 months followup
Larsen TM, Dalskov S, van Baak M, et al. The Diet, Obesity and Genes (Diogenes) dietary study in eight European countries—a comprehensive design for long-term intervention. Obes Rev. 2009;76-91. | Comparative effectiveness
Lasser VI, Raczynski JM, Stevens VJ, et al. Trials of Hypertension Prevention, phase II: structure and content of the weight loss and dietary sodium reduction interventions. Ann Epidemiol. 1995;5:156-64. | No weight or harms outcomes
Laws R; Counterweight Project Team. A new evidence-based model for weight management in primary care: the Counterweight Programme. J Hum Nutr Diet. 2004;17:191-208. | Does not meet design requirements in inclusion criteria
Layman DK, Evans EM, Erickson D, et al. A moderate-protein diet produces sustained weight loss and long-term changes in body composition and blood lipids in obese adults. J Nutr. 2009;139:514-21. | Comparative effectiveness
Leermakers EA, Perri MG, Shigaki CL, Fuller PR. Effects of exercise-focused versus weight-focused maintenance programs on the management of obesity. Addict Behav. 1999;24:219-27. | Comparative effectiveness
Lehtovirta M, Forsen B, Gullstrom M, et al. Metabolic effects of metformin in patients with impaired glucose tolerance. Diabet Med. 2001;18:578-83. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Leibbrand R, Fichter MM. Maintenance of weight loss after obesity treatment: is continuous support necessary? Behav Res Ther. 2002;40:1275-89. | Focus on patients in subgroups other than specified conditions
Leinum CJ, Dopp JM, Morgan BJ. Sleep-disordered breathing and obesity: pathophysiology, complications, and treatment. Nutr Clin Pract. 2009;24:675-87. | Does not meet design requirements in inclusion criteria
Lejeune MP, Kovacs EM, Westerterp-Plantenga MS. Additional protein intake limits weight regain after weight loss in humans. Br J Nutr. 2005;93:281-9. | Less than 12 months followup
Liao D, Asberry PJ, Shofer JB, et al. Improvement of BMI, body composition, and body fat distribution with lifestyle modification in Japanese Americans with impaired glucose tolerance. Diabetes Care. 2002;25:1504-10. | Comparative effectiveness
Lien LF, Brown AJ, Ard JD, et al. Effects of PREMIER lifestyle modifications on participants with and without the metabolic syndrome. Hypertension. 2007;50:609-16. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Ligibel JA, Giobbie-Hurder A, Olenczuk D, et al. Impact of a mixed strength and endurance exercise intervention on levels of adiponectin, high molecular weight adiponectin and leptin in breast cancer survivors. Cancer Causes Control. 2009;20:1523-8. | Less than 12 months followup
Linde JA, Jeffery RW, Finch EA, et al. Are unrealistic weight loss goals associated with outcomes for overweight women? Obes Res. 2004;12:569-76. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Lindegarde F. Orlistat with diet was effective and safe for weight loss and coronary risk reduction in obesity. Evid Based Med. 2001;6:54. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Lindholm A, Bixo M, Bjorn I, et al. Effect of sibutramine on weight reduction in women with polycystic ovary syndrome: a randomized, double-blind, placebo-controlled trial. Fertil Steril. 2008;89:1221-8. | Less than 12 months followup
Lindholm LH, Ekbom T, Dash C, et al. The impact of health care advice given in primary care on cardiovascular risk. BMJ. 1995;310:1105-9. | Comparative effectiveness
Lindstrom J, Eriksson JG, Valle TT, et al. Prevention of diabetes mellitus in subjects with impaired glucose tolerance in the Finnish Diabetes Prevention Study: results from a randomized clinical trial. J Am Soc Nephrol. 2003;14:S108-13. | No weight or harms outcomes
Lindström J, Ilanne PP, Peltonen M et al. Sustained reduction in the incidence of type 2 diabetes by lifestyle intervention: follow-up of the Finnish Diabetes Prevention Study. Lancet. 2006;368:1673-1679. | No weight or harms outcomes
Lindstrom J, Peltonen M, Eriksson JG et al. High-fibre, low-fat diet predicts long-term weight loss and decreased type 2 diabetes risk: the Finnish Diabetes Prevention Study. Diabetologia. 2006;49:912-920. | No weight or harms outcomes
Littman AJ, Vitiello MV, Foster-Schubert K et al. Sleep, ghrelin, leptin and changes in body weight during a 1-year moderate-intensity physical activity intervention. Int J Obes. 2007;31:466-475. | No weight or harms outcomes
Logue E, Sutton K, Jarjoura D, Smucker W, Baughman K, Capers C. Transtheoretical model-chronic disease care for obesity in primary care: a randomized trial. Obes Res. 2005;13:917-927. | Comparative effectiveness
Logue EE, Jarjoura DG, Sutton KS, Smucker WD, Baughman KR, Capers CF. Longitudinal relationship between elapsed time in the action stages of change and weight loss. Obes Res. 2004;12:1499-1508. | Does not meet design requirements in inclusion criteria
Lojander J, Mustajoki P, Ronka S, Mecklin P, Maasilta P. A nurse-managed weight reduction programme for obstructive sleep apnoea syndrome. J Intern Med. 1998;244:251-255. | Does not meet design requirements in inclusion criteria
Lombard CB, Deeks AA, Ball K, Jolley D, Teede HJ. Weight, physical activity and dietary behavior change in young mothers: short term results of the HeLP-her cluster randomized controlled trial. Nutrition Journal. 2009;8:17. | Less than 12 months followup
Look AHEAD Research Group, Bray G, Gregg E et al. Baseline characteristics of the randomised cohort from the Look AHEAD (Action for Health in Diabetes) study. Diabetes & Vascular Disease Research. 2006;3:202-215. | Comparative effectiveness
Look AHEAD Research Group, Wadden TA, West DS et al. The Look AHEAD study: a description of the lifestyle intervention and the evidence supporting it. Obesity. 2006;14:737-752. | Comparative effectiveness
Lucas CP, Boldrin MN, Reaven GM. Effect of orlistat added to diet (30% of calories from fat) on plasma lipids, glucose, and insulin in obese patients with hypercholesterolemia. Am J Cardiol. 2003;91:961-964. | Comparative effectiveness
Lucas KH, Kaplan-Machlis B. Orlistat--a novel weight loss therapy. Ann Pharmacother. 2001;35:314-328. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Major GC, Alarie F, Dore J, Phouttama S, Tremblay A. Supplementation with calcium + vitamin D enhances the beneficial effect of weight loss on plasma lipid and lipoprotein concentrations. Am J Clin Nutr. 2007;85:54 | Not one of the specified interventions
Malone DC, Raebel MA, Porter JA et al. Cost-effectiveness of sibutramine in the LOSE Weight Study: evaluating the role of pharmacologic weight-loss therapy within a weight management program. Journal of Managed Care Pharmacy. 2005;11:458-468. | Comparative effectiveness
Malone M, Alger-Mayer S. Binge status and quality of life after gastric bypass surgery: a one-year study. Obes Res. 2004;12:473-481. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Manini TM, Newman AB, Fielding R, et al. Effects of exercise on mobility in obese and nonobese older adults. Obesity (Silver Spring). 2010;18:1168-75. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Manning RM, Jung RT, Leese GP, Newton RW. The comparison of four weight reduction strategies aimed at overweight patients with diabetes mellitus: four-year follow-up. Diabet Med. 1998;15:497-502. | Comparative effectiveness
Marinilli PA, Gorin AA, Raynor HA, Tate DF, Fava JL, Wing RR. Successful weight-loss maintenance in relation to method of weight loss. Obesity. 2008;16:2456-2461. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Marshall NS, Grunstein RR. Losing weight in moderate to severe obstructive sleep apnoea. BMJ. 2009;339:b4363. | Conducted primarily in a non-relevant setting
Maruthur NM, Wang NY, Appel LJ. Lifestyle interventions reduce coronary heart disease risk: results from the PREMIER Trial. Circulation. 2009;119:2026 | Not one of the specified interventions
Mata J, Silva MN, Vieira PN et al. Motivational “spill-over” during weight control: increased self-determination and exercise intrinsic motivation predict eating self-regulation. Health Psychol. 2009;28:709-716. | No weight or harms outcomes
Mathus-Vliegen EM; Balance Study Group. Long-term maintenance of weight loss with sibutramine in a GP setting following a specialist guided very-low-calorie diet: a double-blind, placebo-controlled, parallel group study. Eur J Clin Nutr. 2005;59(Suppl 1):S31-8. | Sibutramine intervention
Matvienko OA, Hoehns JD. A lifestyle intervention study in patients with diabetes or impaired glucose tolerance: translation of a research intervention into practice. J Am Board Fam Med. 2009;22:535-43. | Does not meet design requirements in inclusion criteria
McConnon A, Kirk SF, Cockroft JE, et al. The Internet for weight control in an obese sample: results of a randomised controlled trial. BMC Health Serv Res. 2007;7:206. | High or differential attrition
McConnon A, Kirk SF, Ransley JK. Process evaluation of an Internet-based resource for weight control: use and views of an obese sample. J Nutr Educ Beha. 2009;41:261-7. | No weight or harms outcomes
McLaughlin T, Carter S, Lamendola C, et al. Clinical efficacy of two hypocaloric diets that vary in overweight patients with type 2 diabetes: comparison of moderate fat versus carbohydrate reductions. Diabetes Care. 2007;30:1877-9. | Comparative effectiveness
McMahon FG, Fujioka K, Singh BN, et al. Efficacy and safety of sibutramine in obese white and African American patients with hypertension: a 1-year, double-blind, placebo-controlled, multicenter trial. Arch Intern Med. 2000;160:2185-91. | Sibutramine intervention
McMahon FG, Weinstein SP, Rowe E, et al. Sibutramine is safe and effective for weight loss in obese patients whose hypertension is well controlled with angiotensin-converting enzyme inhibitors. J Hum Hypertens. 2002;16:5-11. | Sibutramine intervention
McManus K, Antinoro L, Sacks F. A randomized controlled trial of a moderate-fat, low-energy diet compared with a low fat, low-energy diet for weight loss in overweight adults. Int J Obes Relat Metab Disord. 2001;25:1503-11. | Comparative effectiveness
McNulty SJ, Ur E, Williams G. A randomized trial of sibutramine in the management of obese type 2 diabetic patients treated with metformin. Diabetes Care. 2003;26:125-31. | Sibutramine intervention
McTiernan A, Sorensen B, Irwin ML et al. Exercise effect on weight and body fat in men and women. Obesity. 2007;15:1496-512. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Meenan RT, Vogt TM, Williams AE, et al. Economic evaluation of a worksite obesity prevention and intervention trial among hotel workers in Hawaii. J Occup Environ Med. 2010;52(Suppl 1):S8-13. | Conducted primarily in a non-relevant setting
Mengham LH, Morris BF, Palmer CR, White AJ. Is intensive dietetic intervention effective for overweight patients with diabetes mellitus? A randomised controlled trial in a general practice. Pract Diab Int. 1999;16:8. | Comparative effectiveness
Menon T, Quaddus S, Cohen L. Revision of failed vertical banded gastroplasty to non-resectional Scopinaro biliopancreatic diversion: early experience. Obes Surg. 2006;16:1420-4. | Comparative effectiveness
Messerli-Burgy N, Znoj H, Laederach K. Eating behavior, emotional regulation, and coping strategies in obese patients following a comprehensive weight reduction program. Verhaltenstherapie. 2007;17:56. | Does not meet design requirements in inclusion criteria
Messier SP, Loeser RF, Miller GD, et al. Exercise and dietary weight loss in overweight and obese older adults with knee osteoarthritis: the Arthritis, Diet, and Activity Promotion Trial. Arthritis Rheum. 2004;50:1501-10. | Comparative effectiveness
Micic D, Ivkovic-Lazar T, Dragojevic R, et al. Orlistat, a gastrointestinal lipase inhibitor, in therapy of obesity with concomitant hyperlipidemia. Med Pregl. 1999;52:323-33. | Less than 12 months followup
Molenaar EA, van Ameijden EJ, Vergouwe Y, et al. Effect of nutritional counselling and nutritional plus exercise counselling in overweight adults: a randomized trial in multidisciplinary primary care practice. Fam Pract. 2010;27:143-50. | High or differential attrition
Molitch ME, Fujimoto W, Hamman RF, et al. The Diabetes Prevention Program and its global implications. J Am Soc Nephrol. 2003;14(Suppl 2):S103-7. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Morgan PJ, Lubans DR, Collins CE, et al. 12-Month outcomes and process evaluation of the SHED-IT RCT: an Internet-based weight loss program targeting men. Obesity (Silver Spring). 2011;19:142-51. | Conducted primarily in a non-relevant setting
Muls E, Kolanowski J, Scheen A, Van Gaal L. The effects of orlistat on weight and on serum lipids in obese patients with hypercholesterolemia: a randomized, double-blind, placebo-controlled, multicentre study. Int J Obes Relat Metab Disord. 2001;25:1713-21. | Less than 12 months followup
Multiple Risk Factor Intervention Trial Research Group. Multiple Risk Factor Intervention Trial: risk factor changes and mortality results. JAMA. 1982;248:1465-77 | Not one of the specified interventions
Munsch S, Biedert E, Keller U. Evaluation of a lifestyle change programme for the treatment of obesity in general practice. Swiss Med Wkly. 2003;133:148-54. | High or differential attrition
Murawski ME. Problem solving and the management of obesity in women from underserved rural settings. Dissert Abstr Int B Sci Eng. 2008;69:690. | Comparative effectiveness
Nahmias J, Kirschner M, Karetzky MS. Weight loss and OSA and pulmonary function in obesity. N J Med. 1993;90:48-53. | Does not meet design requirements in inclusion criteria
Nakata Y, Ohkawara K, Lee DJ, et al. Effects of additional resistance training during diet-induced weight loss on bone mineral density in overweight premenopausal women. J Bone Min Metab. 2008;26:172-7. | Less than 12 months followup
Nanchahal K, Townsend J, Letley L, et al. Weight-management interventions in primary care: a pilot randomised controlled trial. Br J Gen Pract. 2009;59:e157-66. | Less than 12 months followup
Nauta H, Hospers H, Jansen A. One-year follow-up effects of two obesity treatments on psychological well-being and weight. Br J Health Psychol. 2001;6:271-84. | Comparative effectiveness
Neaton JD, Grimm RH Jr, Cutler JA. Recruitment of participants for the Multiple Risk Factor Intervention Trial (MRFIT). Control Clin Trials. 1987;8(Suppl 4):S41-53. | Not one of the specified interventions
Nelson MS, Robbins AS, Thornton JA. An intervention to reduce excess body weight in adults with or at risk for type 2 diabetes. Mil Med. 2006;171:409-14. | Less than 12 months followup
Nicklas BJ, Ambrosius W, Messier SP, et al. Diet-induced weight loss, exercise, and chronic inflammation in older, obese adults: a randomized controlled clinical trial. Am J Clin Nutr. 2004;79:544-51. | Comparative effectiveness
Nowson CA, Worsley A, Margerison C, et al. Blood pressure change with weight loss is affected by diet type in men. Am J Clin Nutr. 2005;81:983-9. | Comparative effectiveness
Ockene IS, Hebert JR, Ockene JK, et al. Effect of physician-delivered nutrition counseling training and an office-support program on saturated fat intake, weight, and serum lipid measurements in a hyperlipidemic population: Worcester Area Trial for Counseling in Hyperlipidemia (WATCH). Arch Intern Med. 1999;159:725-31. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Olson TP, Dengel DR, Leon AS, Schmitz KH. Changes in inflammatory biomarkers following one-year of moderate resistance training in overweight women. Int J Obes (Lond). 2007;31:996-1003. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Olson TP, Dengel DR, Leon AS, Schmitz KH. Moderate resistance training and vascular health in overweight women. Med Sci Sports Exerc. 2006;38:1558-64. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Osei-Assibey G, Kyrou I, Adi Y, et al. Dietary and lifestyle interventions for weight management in adults from minority ethnic/non-white groups: a systematic review. Obes Rev. 2010;11:769-76. | Does not meet design requirements in inclusion criteria
Ostbye T, Krause KM, Lovelady CA, et al. Active Mothers Postpartum: a randomized controlled weight-loss intervention trial. Am J Prev Med. 2009;37:173-80. | Less than 12 months followup
O'Toole ML, Sawicki MA, Artal R. Structured diet and physical activity prevent postpartum weight retention. J Womens Health. 2003;12:991-8. | Comparative effectiveness
Page RC, Harnden KE, Cook JT, Turner RC. Can life-styles of subjects with impaired glucose tolerance be changed? A feasibility study. Diabet Med. 1992;9:562-6. | Not one of the specified interventions
Pan XR, Li GW, Hu YH, et al. Effects of diet and exercise in preventing NIDDM in people with impaired glucose tolerance. Diabetes Care. 1997;20:537-44. | Not on list of countries with HDI > 0.90
Papalazarou A, Yannakoulia M, Kavouras SA, et al. Lifestyle intervention favorably affects weight loss and maintenance following obesity surgery. Obesity (Silver Spring). 2010;18:1348-53. | Comparative effectiveness
Park SK, Park JH, Kwon YC, et al. The effect of combined aerobic and resistance exercise training on abdominal fat in obese middle-aged women. J Physiol Anthropol Appl Human Sci. 2003;22:129-35. | Does not meet design requirements in inclusion criteria
Pasquali R, Colella P, Cirignotta F, et al. Treatment of obese patients with obstructive sleep apnea syndrome (OSAS): effect of weight loss and interference of otorhinolaryngoiatric pathology. Int J Obes. 1990;14:207-17. | Does not meet design requirements in inclusion criteria
Paul-Ebhohimhen V, Avenell A. A systematic review of the effectiveness of group versus individual treatments for adult obesity. Obesity Facts. 2009;2:17-24. | Does not meet design requirements in inclusion criteria
Perreault L, Kahn SE, Christophi CA, et al. Regression from pre-diabetes to normal glucose regulation in the diabetes prevention program. Diabetes Care. 2009;32:1583-8. | No weight or harms outcomes
Perreault L, Ma Y, Dagogo-Jack S, et al. Sex differences in diabetes risk and the effect of intensive lifestyle modification in the Diabetes Prevention Program. Diabetes Care. 2008;31:1416-21. | No weight or harms outcomes
Perri MG, Limacher MC, Durning PE, et al. Extended-care programs for weight management in rural communities: the Treatment of Obesity in Underserved Rural Settings (TOURS) randomized trial. Arch Intern Med. 2008;168:2347-54. | Comparative effectiveness
Perrio MJ, Wilton LV, Shakir SA. The safety profiles of orlistat and sibutramine: results of prescription-event monitoring studies in England. Obesity. 2007;15:2712-22. | Does not meet design requirements in inclusion criteria
Petrofsky J, Batt J, Berk L, et al. The effect of an aerobic dance and diet program on cardiovascular fitness, body composition, and weight loss in women. J Appl Res. 2008;8:179-88. | Less than 12 months followup
Phelan S, Wadden TA, Berkowitz RI, et al. Impact of weight loss on the metabolic syndrome. Int J Obes. 2007;31:1442-8. | Does not meet design requirements in inclusion criteria
Philippou E, Neary NM, Chaudhri O, et al. The effect of dietary glycemic index on weight maintenance in overweight subjects: a pilot study. Obesity. 2009;17:396-401. | Comparative effectiveness
Pinkston MM, Poston WS, Reeves RS, et al. Does metabolic syndrome mitigate weight loss in overweight Mexican American women treated for 1-year with orlistat and lifestyle modification? Eat Weight Disord. 2006;11:e35-41. | No placebo in medication trial
Pi-Sunyer X, Blackburn G, Brancati FL, et al. Reduction in weight and cardiovascular disease risk factors in individuals with type 2 diabetes: one-year results of the Look AHEAD trial. Diabetes Care. 2007;30:1374-83. | Comparative effectiveness
Porter JA, Raebel MA, Conner DA, et al. The Long-term Outcomes of Sibutramine Effectiveness on Weight (LOSE Weight) study: evaluating the role of drug therapy within a weight management program in a group-model health maintenance organization. Am J Manag Care. 2004;10:369-76. | No placebo in medication trial
Poston WS 2nd, Haddock CK, Olvera NE, et al. Evaluation of a culturally appropriate intervention to increase physical activity. Am J Health Behav. 2001;25:396-406. | Not one of the specified interventions
Poston WS 2nd, Haddock CK, Pinkston MM, et al. Evaluation of a primary care-oriented brief counselling intervention for obesity with and without orlistat. J Intern Med. 2006;260:388-98. | Does not meet design requirements in inclusion criteria
Poston WS, Reeves RS, Haddock CK, et al. Weight loss in obese Mexican Americans treated for 1-year with orlistat and lifestyle modification. Int J Obes Relat Metab Disord. 2003;27:1486-93. | No placebo in medication trial
Potteiger JA, Jacobsen DJ, Donnelly JE, Hill JO. Glucose and insulin responses following 16 months of exercise training in overweight adults: the Midwest Exercise Trial. Metabolism. 2003;52:1175-81. | High or differential attrition
Potteiger JA, Kirk EP, Jacobsen DJ, Donnelly JE. Changes in resting metabolic rate and substrate oxidation after 16 months of exercise training in overweight adults. Int J Sport Nutr Exerc Metab. 2008;18:79-95. | High or differential attrition
Pritchard JE, Nowson CA, Wark JD. A worksite program for overweight middle-aged men achieves lesser weight loss with exercise than with dietary change. J Am Diet Assoc. 1997;97:37-42. | Conducted primarily in a non-relevant setting
Promrat K, Kleiner DE, Niemeier HM, et al. Randomized controlled trial testing the effects of weight loss on nonalcoholic steatohepatitis. Hepatology. 2010;51:121-9. | Focus on patients in subgroups other than specified conditions
Proper KI, Hildebrandt VH, Van der Beek AJ, et a.. Effect of individual counseling on physical activity fitness and health: a randomized controlled trial in a workplace setting. Am J Prev Med. 2003;24:218-26. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Provencher V, Begin C, Tremblay A, et al. Health-at-every-size and eating behaviors: 1-year follow-up results of a size acceptance intervention. J Am Diet Assoc. 2009;109:1854-61. | Not one of the specified interventions
Racette SB, Deusinger SS, Inman CL, et al. Worksite Opportunities for Wellness (WOW): effects on cardiovascular disease risk factors after 1 year. Prev Med. 2009;49:108-14. | Conducted primarily in a non-relevant setting
Racette SB, Weiss EP, Obert KA, et al. Modest lifestyle intervention and glucose tolerance in obese African Americans. Obes Res. 2001;9:348-55. | Comparative effectiveness
Racette SB, Weiss EP, Villareal DT, et al. One year of caloric restriction in humans: feasibility and effects on body composition and abdominal adipose tissue. J Gerontol A Biol Sci Med Sci. 2006;61:943-50. | Comparative effectiveness
Ramachandran A, Snehalatha C, Mary S, et al. The Indian Diabetes Prevention Programme shows that lifestyle modification and metformin prevent type 2 diabetes in Asian Indian subjects with impaired glucose tolerance (IDPP-1). Diabetologia. 2006;49:289-97. | Not on list of countries with HDI > 0.90
Ramirez EM, Rosen JC. A comparison of weight control and weight control plus body image therapy for obese men and women. J Consult Clin Psychol. 2001;69:440-6. | Comparative effectiveness
Randomised trial of jejunoileal bypass versus medical treatment in morbid obesity. Lancet. 1979;2:1255-8. | Not one of the specified interventions
Rapoport L, Clark M, Wardle J. Evaluation of a modified cognitive-behavioural programme for weight management. Int J Obes Relat Metab Disord. 2000;24:1726-37. | Comparative effectiveness
Ratner RE; Diabetes Prevention Program. An update on the Diabetes Prevention Program. Endocr Pract. 2006;12(Suppl 1):20-4. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Razquin C, Martinez JA, Martinez-Gonzalez MA, et al. A 3 years follow-up of a Mediterranean diet rich in virgin olive oil is associated with high plasma antioxidant capacity and reduced body weight gain. Eur J Clin Nutr. 2009;63:1387-93. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Reaven G, Segal K, Hauptman J, et al. Effect of orlistat-assisted weight loss in decreasing coronary heart disease risk in patients with syndrome X. Am J Cardiol. 2001;87:827-31. | Other quality issues
Redmon JB, Bertoni AG, Connelly S, et al. Effect of the Look AHEAD study intervention on medication use and related cost to treat cardiovascular disease risk factors in individuals with type 2 diabetes. Diabetes Care. 2010;33:1153-8. | Comparative effectiveness
Reid IR, Horne A, Mason B, et al. Effects of calcium supplementation on body weight and blood pressure in normal older women: a randomized controlled trial. J Clin Endocrinol Metab. 2005;90:3824-9. | Not one of the specified interventions
Rejeski WJ, Focht BC, Messier SP, et al. Obese, older adults with knee osteoarthritis: weight loss, exercise, and quality of life. Health Psychol. 2002;21:419-26. | Comparative effectiveness
Renzaho AM, Mellor D, Boulton K, Swinburn B. Effectiveness of prevention programmes for obesity and chronic diseases among immigrants to developed countries—a systematic review. Pub Health Nutr. 2010;13:438-50. | Does not meet design requirements in inclusion criteria
Ricci TA, Chowdhury HA, Heymsfield SB, et al. Calcium supplementation suppresses bone turnover during weight reduction in postmenopausal women. J Bone Miner Res. 1998;13:1045-50. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Rimmer JH, Rauworth A, Wang E, et al. A randomized controlled trial to increase physical activity and reduce obesity in a predominantly African American group of women with mobility disabilities and severe obesity. Prev Med. 2009;48:473-9. | Less than 12 months followup
Rissanen P, Vahtera E, Krusius T, et al. Weight change and blood coagulability and fibrinolysis in healthy obese women. Int J Obes Relat Metab Disord. 2001;25:212-8. | No weight or harms outcomes
Rock CL, Flatt SW, Sherwood NE, et al. Effect of a free prepared meal and incentivized weight loss program on weight loss and weight loss maintenance in obese and overweight women: a randomized controlled trial. JAMA. 2010;304:1803-10. | Comparative effectiveness
Rock CL, Pakiz B, Flatt SW, Quintana EL. Randomized trial of a multifaceted commercial weight loss program. Obesity. 2007;15:939-49. | Comparative effectiveness
Rosenfalck AM, Hendel H, Rasmussen MH, et al. Minor long-term changes in weight have beneficial effects on insulin sensitivity and beta-cell function in obese subjects. Diabetes Obes Metab. 2002;4:19-28. | No weight or harms outcomes
Ross R, Blair SN, Godwin M, et al. Prevention and Reduction of Obesity Through Active Living (PROACTIVE): rationale, design and methods. Br J Sports Med. 2009;43:57-63. | No weight or harms outcomes
Ross R, Janssen I, Dawson J, et al. Exercise-induced reduction in obesity and insulin resistance in women: a randomized controlled trial. Obes Res. 2004;12:789-98. | Comparative effectiveness
Rothacker DQ, Staniszewski BA, Ellis PK. Liquid meal replacement vs traditional food: a potential model for women who cannot maintain eating habit change. J Am Diet Assoc. 2001;101:345-7. | Comparative effectiveness
Rothert K, Strecher VJ, Doyle LA, et al. Web-based weight management programs in an integrated health care setting: a randomized, controlled trial. Obesity. 2006;14:266-72. | Less than 12 months followup
Ryan DH, Johnson WD, Myers VH, et al. Nonsurgical weight loss for extreme obesity in primary care settings: results of the Louisiana Obese Subjects Study. Arch Intern Med. 2010;170:146-54. | No placebo in medication trial
Sabbioni ME, Dickson MH, Eychmuller S, et al. Intermediate results of health related quality of life after vertical banded gastroplasty. Int J Obes Relat Metab Disord. 2002;26:277-80. | Not one of the specified interventions
Saccone A, Israel A. Effects of experimenter versus significant other-controlled reinforcement and choice of target behavior on weight loss. Behav Ther. 1978;9:271-8. | Precedes search period
Salas SJ, Fernández BJ, Ros E, et al. Effect of a Mediterranean diet supplemented with nuts on metabolic syndrome status: one-year results of the PREDIMED randomized trial. Arch Intern Med. 2008;168:2449-58. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Samaras K, Ashwell S, Mackintosh AM, et al. Will older sedentary people with non-insulin-dependent diabetes mellitus start exercising? A health promotion model. Diabetes Res Clin Pract. 1997;37:121-8. | Not one of the specified interventions
Sampol G, Munoz X, Sagales MT, et al. Long-term efficacy of dietary weight loss in sleep apnoea/hypopnoea syndrome. Eur Respir J. 1998;12:1156-9. | Does not meet design requirements in inclusion criteria
Samsa GP, Kolotkin RL, Williams GR, et al. Effect of moderate weight loss on health-related quality of life: an analysis of combined data from 4 randomized trials of sibutramine vs placebo. Am J Manag Care. 2001;7:875-83. | Does not meet design requirements in inclusion criteria
Sanchez-Reyes L, Fanghanel G, Yamamoto J, et al. Use of sibutramine in overweight adult Hispanic patients with type 2 diabetes mellitus: a 12-month, randomized, double-blind, placebo-controlled clinical trial. Clin Ther. 2004;26:1427-35. | Not on list of countries with HDI > 0.90
Sarac S, Sarac F. Cardiac valve evaluation and adipokine levels in obese women treated with sibutramine. Anadolu Kardiyoloji Dergisi. 2010;10:226-32. | Does not meet design requirements in inclusion criteria
Sarwer DB, von Sydow GA, Vetter ML, Wadden TA. Behavior therapy for obesity: where are we now? Curr Opin Endocrinol Diabetes Obes. 2009;16:347-52. | Does not meet design requirements in inclusion criteria
Sbrocco T, Nedegaard RC, Stone JM, Lewis EL. Behavioral choice treatment promotes continuing weight loss: preliminary results of a cognitive-behavioral decision-based treatment for obesity. J Consult Clin Psychol. 1999;67:260-6. | Comparative effectiveness
Schmitz KH, Hannan PJ, Stovitz SD, et al. Strength training and adiposity in premenopausal women: Strong, Healthy, and Empowered study. Am J Clin Nutr. 2007;86:566-72. | No weight or harms outcomes
Schuler G, Hambrecht R, Schlierf G, et al. Regular physical exercise and low-fat diet: effects on progression of coronary artery disease. Circulation. 1992;86:1-11. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Schuster RJ, Tasosa J, Terwoord NA. Translational research—implementation of NHLBI Obesity Guidelines in a primary care community setting: the Physician Obesity Awareness Project. J Nutr Health Aging. 2008;12:S764-9. | Comparative effectiveness
Serrano-Rios M, Melchionda N, Moreno-Carretero E. Role of sibutramine in the treatment of obese type 2 diabetic patients receiving sulphonylurea therapy. Diabet Med. 2002;19:119-24. | Sibutramine intervention
Shapses SA, Heshka S, Heymsfield SB. Effect of calcium supplementation on weight and fat loss in women. J Clin Endocrinol Metab. 2004;89:632-7. | Not one of the specified interventions
Shea MK, Houston DK, Nicklas BJ, et al. The effect of randomization to weight loss on total mortality in older overweight and obese adults: the ADAPT Study. J Gerontol A Biol Sci Med Sci. 2010;65:519-25. | Comparative effectiveness
Sherwood NE, Jeffery RW, Pronk NP, et al. Mail and phone interventions for weight loss in a managed-care setting: Weigh-To-Be 2-year outcomes. Int J Obes. 2006;30:1565-73. | High or differential attrition
Short KR, Vittone JL, Bigelow ML, et al. Impact of aerobic exercise training on age-related changes in insulin sensitivity and muscle oxidative capacity. Diabetes. 2003;52:1888-96. | Less than 12 months followup
Siegel JM, Prelip ML, Erausquin JT, Kim SA. A worksite obesity intervention: results from a group-randomized trial. Am J Public Health. 2010;100:327-33. | Conducted primarily in a non-relevant setting
Silva MN, Markland D, Carraca EV, et al. Exercise autonomous motivation predicts three-year weight loss in women. Med Sci Sports Exerc. 2011;43:728-37. | Study of overweight/obesity prevention
Simmons D, Rush E, Crook N; Te Wai o Rona Diabetes Prevention Strategy Team. Development and piloting of a community health worker-based intervention for the prevention of diabetes among New Zealand Maori in Te Wai o Rona: Diabetes Prevention Strategy. Public Health Nutr. 2008;11:1318-25. | Focus on patients in subgroups other than specified conditions
Sircar AR, Kumar A, Lal M. Clinical evaluation of sibutramine in obese type 2 diabetic patients refractory to dietary management. J Assoc Physicians India. 2001;49:885-8. | Less than 12 months followup
Sjostrom L. Analysis of the XENDOS study (Xenical in the Prevention of Diabetes in Obese Subjects). Endocr Pract. 2006;12(Suppl 1):31-3. | No weight or harms outcomes
Skender ML, Goodrick GK, Del Junco DJ, et al. Comparison of 2-year weight loss trends in behavioral treatments of obesity: diet, exercise, and combination interventions. J Am Diet Assoc. 1996;96:342-6. | Comparative effectiveness
Skinner TC, Carey ME, Cradock S, et al. Diabetes Education and Self-Management for Ongoing and Newly Diagnosed (DESMOND): process modelling of pilot study. Patient Educ Couns. 2006;64:369-77. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Slentz CA, Duscha BD, Johnson JL, et al. Effects of the amount of exercise on body weight, body composition, and measures of central obesity: STRRIDE—a randomized controlled study. Arch Intern Med. 2004;164:31-9. | Less than 12 months followup
Smith IG, Goulder MA. Randomized placebo-controlled trial of long-term treatment with sibutramine in mild to moderate obesity. J Fam Pract. 2001;50:505-12. | Sibutramine intervention
Smith PL, Gold AR, Meyers DA, et al. Weight loss in mildly to moderately obese patients with obstructive sleep apnea. Ann Intern Med. 1985;103:850-5. | Less than 12 months followup
Southard BH, Southard DR, Nuckolls J. Clinical trial of an Internet-based case management system for secondary prevention of heart disease. J Cardiopulm Rehabil. 2003;23:341-8. | Less than 12 months followup
Sramek JJ, Leibowitz MT, Weinstein SP, et al. Efficacy and safety of sibutramine for weight loss in obese patients with hypertension well controlled by beta-adrenergic blocking agents: a placebo-controlled, double-blind, randomised trial. J Hum Hypertens. 2002;16:13-9. | Less than 12 months followup
Stahre L, Hallstrom T. A short-term cognitive group treatment program gives substantial weight reduction up to 18 months from the end of treatment: a randomized controlled trial. Eat Weight Disord. 2005;10:51-8. | High or differential attrition
Stefanick ML, Mackey S, Sheehan M, et al. Effects of diet and exercise in men and postmenopausal women with low levels of HDL cholesterol and high levels of LDL cholesterol. N Engl J Med. 1998;339:12-20. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Stenius-Aarniala B, Poussa T, Kvarnstrom J, et al. Immediate and long term effects of weight reduction in obese people with asthma: randomised controlled study. BMJ. 2000;320:827-32. | Comparative effectiveness
Stensel DJ, Brooke-Wavell K, Hardman AE, et al. The influence of a 1-year programme of brisk walking on endurance fitness and body composition in previously sedentary men aged 42-59 years. Eur J Appl Physiol Occup Physiol. 1994;68:531-7. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Stern L, Iqbal N, Seshadri P, et al. The effects of low-carbohydrate versus conventional weight loss diets in severely obese adults: one-year follow-up of a randomized trial. Ann Intern Med. 2004;140:778-85. | Comparative effectiveness
Stuart RB. A three-dimensional program for the treatment of obesity. Behav Res Ther. 1971;9:177-86. | Precedes search period
Sun Q, Townsend MK, Okereke OI, et al. Adiposity and weight change in mid-life in relation to healthy survival after age 70 in women: prospective cohort study. BMJ. 2009;339:b3796. | Does not meet design requirements in inclusion criteria
Suratt PM, McTier RF, Findley LJ, et al. Effect of very-low-calorie diets with weight loss on obstructive sleep apnea. Am J Clin Nutr. 1992;56:S182-4. | Does not meet design requirements in inclusion criteria
Svendsen M, Helgeland M, Tonstad S. The long-term influence of orlistat on dietary intake in obese subjects with components of metabolic syndrome. J Hum Nutr Diet. 2009;22:55-63. | No weight or harms outcomes
Svetkey LP, Pollak KI, Yancy WS Jr, et al. Hypertension Improvement Project: randomized trial of quality improvement for physicians and lifestyle modification for patients. Hypertension. 2009;54:1226-33. | Not one of the specified interventions
Swinburn BA, Metcalf PA, Ley SJ. Long-term (5-year) effects of a reduced-fat diet intervention in individuals with glucose intolerance. Diabetes Care. 2001;24:619-24. | Conducted primarily in a non-relevant setting
Swinburn BA, Woollard GA, Chang EC, Wilson MR. Effects of reduced-fat diets consumed ad libitum on intake of nutrients, particularly antioxidant vitamins. J Am Diet Assoc. 1999;99:1400-5. | Conducted primarily in a non-relevant setting
Tanco S, Linden W, Earle T. Well-being and morbid obesity in women: a controlled therapy evaluation. Int J Eat Disord. 1998;23:325-39. | Less than 12 months followup
Tanumihardjo SA, Valentine AR, Zhang Z, et al. Strategies to increase vegetable or reduce energy and fat intake induce weight loss in adults. Exp Biol Med. 2009;234:542-52. | Comparative effectiveness
Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med. 2006;166:1620-5. | Less than 12 months followup
Tate DF, Jackvony EH, Wing RR. Effects of Internet behavioral counseling on weight loss in adults at risk for type 2 diabetes: a randomized trial. JAMA. 2003;289:1833-6. | Comparative effectiveness
Tate DF, Jeffery RW, Sherwood NE, Wing RR. Long-term weight losses associated with prescription of higher physical activity goals: are higher levels of physical activity protective against weight regain? Am J Clin Nutr. 2007;85:954-9. | Comparative effectiveness
Tate DF, Wing RR, Winett RA. Using Internet technology to deliver a behavioral weight loss program. JAMA. 2001;285:1172-7. | Less than 12 months followup
Teixeira PJ, Going SB, Houtkooper LB, et al. Resistance training in postmenopausal women with and without hormone therapy. Med Sci Sports Exerc. 2003;35:555-62. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
ODES Investigators. The Oslo Diet and Exercise Study (ODES): design and objectives. Control Clin Trials. 1993;14:229-43. | No weight or harms outcomes
Thomas TR, Warner SO, Dellsperger KC, et al. Exercise and the metabolic syndrome with weight regain. J Appl Physiol. 2010;109:3-10. | Comparative effectiveness
Thompson WG, Rostad HN, Janzow DJ, et al. Effect of energy-reduced diets high in dairy products and fiber on weight loss in obese adults. Obes Res. 2005;13:1344-53. | Comparative effectiveness
Tiikkainen M, Bergholm R, Rissanen A, et al. Effects of equal weight loss with orlistat and placebo on body fat and serum fatty acid composition and insulin resistance in obese women. Am J Clin Nutr. 2004;79:22-30. | Less than 12 months followup
Tinker LF, Bonds DE, Margolis KL, et al. Low-fat dietary pattern and risk of treated diabetes mellitus in postmenopausal women: the Women's Health Initiative randomized controlled dietary modification trial. Arch Intern Med. 2008;168:1500-11. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Toft U, Kristoffersen L, Ladelund S, et al. The effect of adding group-based counselling to individual lifestyle counselling on changes in dietary intake: the Inter99 study—a randomized controlled trial. Int J Behav Nutr Phys Act. 2008;5:59. | No weight or harms outcomes
Toobert DJ, Glasgow RE, Radcliffe JL. Physiologic and related behavioral outcomes from the Women's Lifestyle Heart Trial. Ann Behav Med. 2000;22:1-9. | Focus on patients in subgroups other than specified conditions
What is TOPS (Take Off Pounds Sensibly). Milwaukee, WI: TOPS Club, Inc; 2011. http://www.tops.org/TOPSInformation/AboutTOPS.aspx | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Trento M, Passera P, Tomalino M, et al. Group visits improve metabolic control in type 2 diabetes: a 2-year follow-up. Diabetes Care. 2001;24:995-1000. | Comparative effectiveness
Trolle B, Flyvbjerg A, Kesmodel U, Lauszus FF. Efficacy of metformin in obese and non-obese women with polycystic ovary syndrome: a randomized, double-blinded, placebo-controlled cross-over trial. Hum Reprod. 2007;22:2967-73. | Less than 12 months followup
Tsai AG, Wadden TA, Rogers MA, et al. A primary care intervention for weight loss: results of a randomized controlled pilot study. Obesity (Silver Spring). 2010;18:1614-8. | Comparative effectiveness
Tsai AG, Wadden TA. Treatment of obesity in primary care practice in the United States: a systematic review. J Gen Intern Med. 2009;24:1073-9. | Does not meet design requirements in inclusion criteria
Tseng MC, Lee MB, Chen SY, et al. Response of Taiwanese obese binge eaters to a hospital-based weight reduction program. J Psychosom Res. 2004;57:279-85. | Focus on patients in subgroups other than specified conditions
Tuomilehto H, Peltonen M, Partinen M, et al. Sleep duration, lifestyle intervention, and incidence of type 2 diabetes in impaired glucose tolerance: the Finnish Diabetes Prevention Study. Diabetes Care. 2009;32:1965-71. | No weight or harms outcomes
Tuomilehto HP, Seppa JM, Partinen MM, et al. Lifestyle intervention with weight reduction: first-line treatment in mild obstructive sleep apnea. Am J Resp Crit Care Med. 2009;179:320-7. | Less than 12 months followup
Turnin MC, Bourgeois O, Cathelineau G, et al. Multicenter randomized evaluation of a nutritional education software in obese patients. Diabetes Metab. 2001;27:139-47. | Comparative effectiveness
Tuthill A, Quinn A, McColgan D, et al. A prospective randomized controlled trial of lifestyle intervention on quality of life and cardiovascular risk score in patients with obesity and type 2 diabetes. Diabetes Obes Metab. 2007;9:917-9 | Less than 12 months followup
Uusi-Rasi K, Rauhio A, Kannus P, et al. Three-month weight reduction does not compromise bone strength in obese premenopausal women. Bone. 2010;46:1286-93. | Does not meet design requirements in inclusion criteria
Van Aggel-Leijssen DP, Saris WH, Hul GB, van Baak MA. Long-term effects of low-intensity exercise training on fat metabolism in weight-reduced obese men. Metabolism. 2002;51:1003-10. | Comparative effectiveness
Van Aggel-Leijssen DP, Saris WH, Hul GB, van Baak MA. Short-term effects of weight loss with or without low-intensity exercise training on fat metabolism in obese men. Am J Clin Nutr. 2001;73:523-31. | Comparative effectiveness
Van Aggel-Leijssen DP, Saris WH, Wagenmakers AJ, et al. The effect of low-intensity exercise training on fat metabolism of obese women. Obes Res. 2001;9:86-96. | Comparative effectiveness
Van Aggel-Leijssen DP, Saris WH, Wagenmakers AJ, et al. Effect of exercise training at different intensities on fat metabolism of obese men. J Appl Physiol. 2002;92:1300-9. | Comparative effectiveness
Van Gaal LF, Broom JI, Enzi G, Toplak H. Efficacy and tolerability of orlistat in the treatment of obesity: a 6-month dose-ranging study. Eur J Clin Pharmacol. 1998;54:125-32. | Less than 12 months followup
van Sluijs EM, van Poppel MN, Twisk JW, et al. Effect of a tailored physical activity intervention delivered in general practice settings: results of a randomized controlled trial. Am J Public Health. 2005;95:1825-31. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
van Wier MF, Ariens GA, Dekkers JC, et al. ALIFE@Work: a randomised controlled trial of a distance counselling lifestyle programme for weight control among an overweight working population. BMC Public Health. 2006;6:140. | Less than 12 months followup
van Wier MF, Ariens GA, Dekkers JC, et al. Phone and e-mail counselling are effective for weight management in an overweight working population: a randomized controlled trial. BMC Public Health. 2009;9:6. | Less than 12 months followup
VanWormer JJ, Martinez AM, Benson GA, et al. Telephone counseling and home telemonitoring: the Weigh By Day Trial. Am J Health Behav. 2009;33:445-54. | Comparative effectiveness
Velthuis MJ, Schuit AJ, Peeters PH, Monninkhof EM. Exercise program affects body composition but not weight in postmenopausal women. Menopause. 2009;16:777-84. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Venditti EM, Bray GA, Carrion-Petersen ML, et al. First versus repeat treatment with a lifestyle intervention program: attendance and weight loss outcomes. Int J Obes. 2008;32:1537-44. | No weight or harms outcomes
Veverka DV, Anderson J, Auld GW, et al. Use of the stages of change model in improving nutrition and exercise habits in enlisted Air Force men. Mil Med. 2003;168:373-9. | Less than 12 months followup
Vidgren HM, Agren JJ, Valve RS, et al. The effect of orlistat on the fatty acid composition of serum lipid fractions in obese subjects. Clin Pharmacol Ther. 1999;66:315-22. | No weight or harms outcomes
Villareal DT, Banks MR, Patterson BW, et al. Weight loss therapy improves pancreatic endocrine function in obese older adults. Obesity. 2008;16:1349-54. | No weight or harms outcomes
Villareal DT, Fontana L, Weiss EP, et al. Bone mineral density response to caloric restriction-induced weight loss or exercise-induced weight loss: a randomized controlled trial. Arch Intern Med. 2006;166:2502-10. | Comparative effectiveness
Vissers D, Verrijken A, Mertens I, et al. Effect of long-term whole body vibration training on visceral adipose tissue: a preliminary report. Obesity Facts. 2010;3:93-100. | Other quality issues
Volpe SL, Kobusingye H, Bailur S, Stanek E. Effect of diet and exercise on body composition, energy intake and leptin levels in overweight women and men. J Am Coll Nutr. 2008;27:195-208. | Comparative effectiveness
von Huth SL, Ladelund S, Borch-Johnsen K, Jorgensen T. A randomized multifactorial intervention study for prevention of ischaemic heart disease (Inter99): the long-term effect on physical activity. Scand J Public Health. 2008;36:380-8. | No weight or harms outcomes
Wadden TA, Berkowitz RI, Sarwer DB, et al. Benefits of lifestyle modification in the pharmacologic treatment of obesity: a randomized trial. Arch Intern Med. 2001;161:218-27. | Comparative effectiveness
Wadden TA, Berkowitz RI, Womble LG, et al. Randomized trial of lifestyle modification and pharmacotherapy for obesity. N Engl J Med. 2005;353:2111-20. | No placebo in medication trial
Wadden TA, West DS, Neiberg RH, et al. One-year weight losses in the Look AHEAD study: factors associated with success. Obesity. 2009;17:713-22. | Comparative effectiveness
Wardle J, Rogers P, Judd P, et al. Randomized trial of the effects of cholesterol-lowering dietary treatment on psychological function. Am J Med. 2000;108:547-53. | Less than 12 months followup
Waring ME, Roberts MB, Parker DR, Eaton CB. Documentation and management of overweight and obesity in primary care. J Am Board Fam Med. 2009;22:544-52. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Warren M, Schmitz KH. Safety of strength training in premenopausal women: musculoskeletal injuries from a two-year randomized trial. Am J Health Promot. 2009;23:309-14. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Warziski MT, Sereika SM, Styn MA, et al. Changes in self-efficacy and dietary adherence: the impact on weight loss in the PREFER study. J Behav Med. 2008;31:81-92. | Comparative effectiveness
Wassertheil-Smoller S, Oberman A, Blaufox MD, et al. The Trial of Antihypertensive Interventions and Management (TAIM) study: final results with regard to blood pressure, cardiovascular risk, and quality of life. Am J Hypertens. 1992;5:37-44. | No weight or harms outcomes
Wee CC, Davis RB, Phillips RS. Stage of readiness to control weight and adopt weight control behaviors in primary care. J Gen Intern Med. 2005;20:410-5. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Weiner R, Bockhorn H, Rosenthal R, Wagner D. A prospective randomized trial of different laparoscopic gastric banding techniques for morbid obesity. Surg Endosc. 2001;15:63-8. | Not one of the specified interventions
Weiss EP, Racette SB, Villareal DT, et al. Improvements in glucose tolerance and insulin action induced by increasing energy expenditure or decreasing energy intake: a randomized controlled trial. Am J Clin Nutr. 2006;84:1033-42. | Comparative effectiveness
West DS, DiLillo V, Bursac Z, et al. Motivational interviewing improves weight loss in women with type 2 diabetes. Diabetes Care. 2007;30:1081-7. | Comparative effectiveness
Whittemore R, Melkus G, Wagner J, et al. Translating the Diabetes Prevention Program to primary care: a pilot study. Nurs Res. 2009;58:2-12. | Less than 12 months followup
Williamson DA, Martin CK, Anton SD, et al. Is caloric restriction associated with development of eating-disorder symptoms? Results from the CALERIE trial. Health Psychol. 2008;27(Suppl 1)S32:-42. | Comparative effectiveness
Williamson DA, Rejeski J, Lang W, et al. Impact of a weight management program on health-related quality of life in overweight adults with type 2 diabetes. Arch Intern Med. 2009;169:163-71. | Comparative effectiveness
Williamson DF. Re: randomized trial of weight loss and total mortality. J Gerontol A Biol Sci Med Sci. 2010;65:904. | Does not meet design requirements in inclusion criteria
Wing RR, Anglin K. Effectiveness of a behavioral weight control program for blacks and whites with NIDDM. Diabetes Care. 1996;19:409-13. | Comparative effectiveness
Wing RR, Creasman JM, West DS, et al. Improving urinary incontinence in overweight and obese women through modest weight loss. Obstetrics Gynecol. 2010;116:284-92. | Comparative effectiveness
Wing RR, Epstein LH, Paternostro-Bayles M, et al. Exercise in a behavioural weight control programme for obese patients with type 2 (non-insulin-dependent) diabetes. Diabetologia. 1988;31:902-9. | Comparative effectiveness
Wing RR, Tate DF, Gorin AA, et al. STOP regain: are there negative effects of daily weighing? J Consult Clin Psychol. 2007;75:652-6. | No weight or harms outcomes
Wing RR, Tate DF, Gorin AA, et al. A self-regulation program for maintenance of weight loss. N Engl J Med. 2006;355:1563-71. | Comparative effectiveness
Wing RR, West DS, Grady D, et al. Effect of weight loss on urinary incontinence in overweight and obese women: results at 12 and 18 months. J Urol. 2010;184:1005-10. | Comparative effectiveness
Wing RR. Behavioral approaches to the treatment of obesity. In: Bray G, Bouchard C, James WP, eds. Handbook of Obesity. New York: Marcel Dekker; 1998:855-73. | Does not meet design requirements in inclusion criteria
Wing RR. Behavioral weight control. In: Wadden TA, Stunkard AJ, eds. Handbook of Obesity Treatment. New York: Guilford Press; 2002:301-16. | Does not meet design requirements in inclusion criteria
Wirth A, Krause J. Long-term weight loss with sibutramine: a randomized controlled trial. JAMA. 2001;286:1331-9. | Sibutramine intervention
Wister A, Loewen N, Kennedy-Symonds H, et al. One-year follow-up of a therapeutic lifestyle intervention targeting cardiovascular disease risk. Can Med Assoc J. 2007;177:859-65. | Not one of the specified interventions
Wolf AM, Conaway MR, Crowther JQ, et al. Translating lifestyle intervention to practice in obese patients with type 2 diabetes: Improving Control with Activity and Nutrition (ICAN) study. Diabetes Care. 2004;27:1570-6. | Comparative effectiveness
Wolf AM, Siadaty MS, Crowther JQ, et al. Impact of lifestyle intervention on lost productivity and disability: Improving Control with Activity and Nutrition. J Occup Environ Med. 2009;51:139-45. | Comparative effectiveness
Womble LG, Wadden TA, McGuckin BG, et al. A randomized controlled trial of a commercial internet weight loss program. Obes Res. 2004;12:1011-8. | Comparative effectiveness
Wong SY, Lau EM, Lau WW, Lynn HS. Is dietary counselling effective in increasing dietary calcium, protein and energy intake in patients with osteoporotic fractures? A randomized controlled clinical trial. J Hum Nutr Diet. 2004;17:359-64. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Woo J, Sea MM, Tong P, et al. Effectiveness of a lifestyle modification programme in weight maintenance in obese subjects after cessation of treatment with orlistat. J Eval Clin Pract. 2007;13:853-9. | Less than 12 months followup
Wosje KS, Kalkwarf HJ. Lactation, weaning, and calcium supplementation: effects on body composition in postpartum women. Am J Clin Nutr. 2004;80:423-9. | Not one of the specified interventions
Wright AD, Cull CA, MacLeod KM, et al. Hypoglycemia in type 2 diabetic patients randomized to and maintained on monotherapy with diet, sulfonylurea, metformin, or insulin for 6 years from diagnosis: UKPDS73. J Diabetes Complications. 2006;20:395-401. | Comparative effectiveness
Wylie-Rosett J, Swencionis C, Ginsberg M, et al. Computerized weight loss intervention optimizes staff time: the clinical and cost results of a controlled clinical trial conducted in a managed care setting. J Am Diet Assoc. 2001;101:1155-62. | Comparative effectiveness
Yancey AK, McCarthy WJ, Harrison GG, et al. Challenges in improving fitness: results of a community-based, randomized, controlled lifestyle change intervention. J Womens Health. 2006;15:412-29. | Not one of the specified interventions
Yassine HN, Marchetti CM, Krishnan RK, et al. Effects of exercise and caloric restriction on insulin resistance and cardiometabolic risk factors in older obese adults—a randomized clinical trial. J Gerontol A Biol Sci Med Sci. 2009;64:90-5. | Comparative effectiveness
Yates T, Davies M, Gorely T, et al. Effectiveness of a pragmatic education program designed to promote walking activity in individuals with impaired glucose tolerance: a randomized controlled trial. Diabetes Care. 2009;32:1404-10. | Not one of the specified interventions
Yeh MC, Rodriguez E, Nawaz H, et al. Technical skills for weight loss: 2-y follow-up results of a randomized trial. Int J Obes Relat Metab Disord. 2003;27:1500-6. | Comparative effectiveness
Zannad F, Gille B, Grentzinger A, et al. Effects of sibutramine on ventricular dimensions and heart valves in obese patients during weight reduction. Am Heart J. 2002;144:508-15. | Sibutramine intervention
Zavoral JH. Treatment with orlistat reduces cardiovascular risk in obese patients. J Hypertens. 1998;16:2013-7. | Other quality issues
Zemel MB, Richards J, Mathis S, et al. Dairy augmentation of total and central fat loss in obese subjects. Int J Obes. 2005;29:391-7. | Not one of the specified interventions
Zemel MB, Richards J, Milstead A, Campbell P. Effects of calcium and dairy on body composition and weight loss in African-American adults. Obes Res. 2005;13:1218-25. | Less than 12 months followup
Zemel MB, Thompson W, Milstead A, et al. Calcium and dairy acceleration of weight and fat loss during energy restriction in obese adults. Obes Res. 2004;12:582-90. | Comparative effectiveness
The Hypertension Prevention Trial: three-year effects of dietary changes on blood pressure. Arch Intern Med. 1990;150:153-62. | No weight outcomes
Anderssen S, Holme I, Urdal P, Hjermann I. Diet and exercise intervention have favourable effects on blood pressure in mild hypertensives: the Oslo Diet and Exercise Study (ODES). Blood Press. 1995;4:343-9. | No weight outcomes
Berne C; Orlistat Study Team. A randomized study of orlistat in combination with a weight management programme in obese patients with type 2 diabetes treated with metformin. Diabet Med. 2005;22:612-8. | No weight outcomes
Burke V, Beilin LJ, Cutt HE, et al. Effects of a lifestyle programme on ambulatory blood pressure and drug dosage in treated hypertensive patients: a randomized controlled trial. J Hypertens. 2005;23:1241-9. | No weight outcomes
Christian JG, Bessesen DH, Byers TE, et al. Clinic-based support to help overweight patients with type 2 diabetes increase physical activity and lose weight. Arch Intern Med. 2008;168:141-6. | No weight outcomes
Cohen MD, D'Amico FJ, Merenstein JH. Weight reduction in obese hypertensive patients. Fam Med. 1991;23:25-8. | No weight outcomes
Cussler EC, Teixeira PJ, Going SB, et al. Maintenance of weight loss in overweight middle-aged women through the Internet. Obesity. 2008;16:1052-60. | No weight outcomes
Davidson MH, Hauptman J, DiGirolamo M, et al. Weight control and risk factor reduction in obese subjects treated for 2 years with orlistat: a randomized controlled trial. JAMA. 1999;281:235-42. | No weight outcomes
Davis BR, Oberman A, Blaufox MD, et al. Effect of antihypertensive therapy on weight loss. Hypertension. 1992;19:393-9. | No weight outcomes
Davis BR, Blaufox MD, Hawkins CM, et al. Trial of Antihypertensive Interventions and Management: design, methods, and selected baseline results. Control Clin Trials. 1989;10:11-30. | No weight outcomes
Derosa G, Maffioli P, Salvadeo SA, et al. Comparison of orlistat treatment and placebo in obese type 2 diabetic patients. Exp Opin Pharmacother. 2010;11:1971-82. | No weight outcomes
Derosa G, Mugellini A, Ciccarelli L, Fogari R. Randomized, double-blind, placebo-controlled comparison of the action of orlistat, fluvastatin, or both on anthropometric measurements, blood pressure, and lipid profile in obese patients with hypercholesterolemia prescribed a standardized diet. Clin Ther. 2003;25:1107-22. | No weight outcomes
Finer N, James WP, Kopelman PG, et al. One-year treatment of obesity: a randomized, double-blind, placebo-controlled, multicentre study of orlistat, a gastrointestinal lipase inhibitor. Int J Obes Relat Metab Disord. 2000;24:306-13. | No weight outcomes
Frank LL, Sorensen BE, Yasui Y, et al. Effects of exercise on metabolic risk variables in overweight postmenopausal women: a randomized clinical trial. Obes Res. 2005;13:615-25. | No weight outcomes
Gambineri A, Patton L, Vaccina A, et al. Treatment with flutamide, metformin, and their combination added to a hypocaloric diet in overweight-obese women with polycystic ovary syndrome: a randomized, 12-month, placebo-controlled study. J Clin Endocrinol Metab. 2006;91:3970-80. | No weight outcomes
Haapala I, Barengo NC, Biggs S, et al. Weight loss by mobile phone: a 1-year effectiveness study. Public Health Nutr. 2009;12:2382-91. | No weight outcomes
Hanefeld M, Sachse G. The effects of orlistat on body weight and glycaemic control in overweight patients with type 2 diabetes: a randomized, placebo-controlled trial. Diabetes Obes Metab. 2002;4:415-23. | No weight outcomes
Hansson L, Zanchetti A. The Hypertension Optimal Treatment (HOT) study—patient characteristics: randomization, risk profiles, and early blood pressure results. Blood Press. 1994;3:322-7. | No weight outcomes
Hill JO, Hauptman J, Anderson JW, et al. Orlistat, a lipase inhibitor, for weight maintenance after conventional dieting: a 1-y study. Am J Clin Nutr. 1999;69:1108-16. | No weight outcomes
Hollander PA, Elbein SC, Hirsch IB, et al. Role of orlistat in the treatment of obese patients with type 2 diabetes: a 1-year randomized double-blind study. Diabetes Care. 1998;21:1288-94. | No weight outcomes
Hollis JF, Satterfield S, Smith F, et al. Recruitment for phase II of the Trials of Hypertension Prevention: effective strategies and predictors of randomization. Ann Epidemiol. 1995;5:140-8. | No weight outcomes
Irwin ML, Yasui Y, Ulrich CM, et al. Effect of exercise on total and intra-abdominal body fat in postmenopausal women: a randomized controlled trial. JAMA. 2003;289:323-30. | No weight outcomes
James WP, Avenell A, Broom J, Whitehead J. A one-year trial to assess the value of orlistat in the management of obesity. Int J Obes Relat Metab Disord. 1997;21(Suppl 3):S24-30. | No weight outcomes
Jeffery RW, Wing RR. Long-term effects of interventions for weight loss using food provision and monetary incentives. J Consult Clin Psychol. 1995;63:793-6. | No weight outcomes
Jeffery RW, Wing RR, Thorson C, et al. Strengthening behavioral interventions for weight loss: a randomized trial of food provision and monetary incentives. J Consult Clin Psychol. 1993;61:1038-45. | No weight outcomes
Jones DW, Miller ME, Wofford MR, et al. The effect of weight loss intervention on antihypertensive medication requirements in the Hypertension Optimal Treatment (HOT) study. Am J Hypertens. 1999;12:1175-80. | No weight outcomes
Kastarinen MJ, Puska PM, Korhonen MH, et al. Non-pharmacological treatment of hypertension in primary health care: a 2-year open randomized controlled trial of lifestyle intervention against hypertension in eastern Finland. J Hypertens. 2002;20:2505-12. | No weight outcomes
Krempf M, Louvet JP, Allanic H, et al. Weight reduction and long-term maintenance after 18 months treatment with orlistat for obesity. Int J Obes Relat Metab Disord. 2003;27:591-7. | No weight outcomes
Kuller LH, Simkin-Silverman LR, Wing RR, et al. Women's Healthy Lifestyle Project—a randomized clinical trial: results at 54 months. Circulation. 2001;103:32-7. | No weight outcomes
Langford HG, Blaufox MD, Oberman A, et al. Dietary therapy slows the return of hypertension after stopping prolonged medication. JAMA. 1985;253:657-64. | No weight outcomes
Langford HG, Davis BR, Blaufox D, et al. Effect of drug and diet treatment of mild hypertension on diastolic blood pressure. Hypertension. 1991;17:210-7. | No weight outcomes
Lindgarde F. The effect of orlistat on body weight and coronary heart disease risk profile in obese patients: the Swedish Multimorbidity Study. J Intern Med. 2000;248:245-54. | No weight outcomes
Martin DP, Rhode PC, Dutton GR, et al. A primary care weight management intervention for low-income African-American women. Obesity. 2006;14:1412-20. | No weight outcomes
Martin PD, Dutton GR, Rhode PC, et al. Weight loss maintenance following a primary care intervention for low-income minority women. Obesity. 2008;16:2462-7. | No weight outcomes
Mayer-Davis EJ, D'Antonio AM, Smith SM, et al. Pounds Off With Empowerment (POWER): a clinical trial of weight management strategies for black and white adults with diabetes who live in medically underserved rural communities. Am J Public Health. 2004;94:1736-42. | No weight outcomes
Mensink M, Blaak EE, Corpeleijn E, et al. Lifestyle intervention according to general recommendations improves glucose tolerance. Obes Res. 2003;11:1588-96. | No weight outcomes
Mensink M, Corpeleijn E, Feskens EJ, et al. Study on Lifestyle-intervention and Impaired Glucose Tolerance Maastricht (SLIM): design and screening results. Diabetes Res Clin Pract. 2003;61:49-58. | No weight outcomes
Miles JM, Leiter L, Hollander P, et al. Effect of orlistat in overweight and obese patients with type 2 diabetes treated with metformin. Diabetes Care. 2002;25:1123-8. | No weight outcomes
Mitsui T, Shimaoka K, Tsuzuku S, et al. Gentle exercise of 40 minutes with dietary counseling is effective in treating metabolic syndrome. Tohoku J Exp Med. 2008;215:355-61. | No weight outcomes
Mohanka M, Irwin M, Heckbert SR, et al. Serum lipoproteins in overweight/obese postmenopausal women: a one-year exercise trial. Med Sci Sports Exerc. 2006;38:231-9. | No weight outcomes
Moore H, Summerbell CD, Greenwood DC, et al. Improving management of obesity in primary care: cluster randomised trial. BMJ. 2003;327:1085. | No weight outcomes
Narayan KM, Hoskin M, Kozak D, et al. Randomized clinical trial of lifestyle interventions in Pima Indians: a pilot study. Diabet Med. 1998;15:66-72. | No weight outcomes
Park HA, Lee JS, Kuller LH, Cauley JA. Effects of weight control during the menopausal transition on bone mineral density. J Clin Endocrinol Metab. 2007;92:3809-15. | No weight outcomes
Perri MG, McAllister DA, Gange JJ, et al. Effects of four maintenance programs on the long-term management of obesity. J Consult Clin Psychol. 1988;56:529-34. | No weight outcomes
Pritchard DA, Hyndman J, Taba F. Nutritional counselling in general practice: a cost effective analysis. J Epidemiol Community Health. 1999;53:311-6. | No weight outcomes
Silva MN, Markland D, Minderico CS, et al. A randomized controlled trial to evaluate self-determination theory for exercise adherence and weight control: rationale and intervention description. BMC Public Health. 2008;8:234. | No weight outcomes
Silva MN, Vieira PN, Coutinho SR, et al. Using self-determination theory to promote physical activity and weight control: a randomized controlled trial in women. J Behav Med. 2010;33:110-22. | No weight outcomes
Simkin-Silverman LR, Wing RR, Boraz MA, Kuller LH. Lifestyle intervention can prevent weight gain during menopause: results from a 5-year randomized clinical trial. Ann Behav Med. 2003;26:212-20. | No weight outcomes
Simkin-Silverman LR, Wing RR, Boraz MA, et al. Maintenance of cardiovascular risk factor changes among middle-aged women in a lifestyle intervention trial. Womens Health. 1998;4:255-71. | No weight outcomes
Sjostrom L, Rissanen A, Andersen T, et al. Randomised placebo-controlled trial of orlistat for weight loss and prevention of weight regain in obese patients. Lancet. 1998;352:167-72. | No weight outcomes
Stevens VJ, Obarzanek E, Cook NR, et al. Long-term weight loss and changes in blood pressure: results of the Trials of Hypertension Prevention, phase II. Ann Intern Med. 2001;134:1-11. | No weight outcomes
Stevens VJ, Corrigan SA, Obarzanek E, et al. Weight loss intervention in phase 1 of the Trials of Hypertension Prevention. Arch Intern Med. 1993;153:849-58. | No weight outcomes
Teixeira PJ, Silva MN, Coutinho SR, et al. Mediators of weight loss and weight loss maintenance in middle-aged women. Obesity (Silver Spring). 2010;18:725-35. | No weight outcomes
ter Bogt NC, Bemelmans WJ, Beltman FW, et al. Preventing weight gain: one-year results of a randomized lifestyle intervention. Am J Prev Med. 2009;37:270-7. | No weight outcomes
HOT Study Group. The Hypertension Optimal Treatment study (the HOT study). Blood Press. 1993;2:62-8. | No weight outcomes
Trials of Hypertention Prevention Collaborative Research Group. Effects of weight loss and sodium reduction intervention on blood pressure and hypertension incidence in overweight people with high-normal blood pressure. Arch Intern Med. 1997;157:657-67. | No weight outcomes
Trials of Hypertension Prevention Collaborative Research Group. The effects of nonpharmacologic interventions on blood pressure of persons with high normal levels: results of the Trials of Hypertension Prevention, phase I. JAMA. 1992;267:1213-20. | No weight outcomes
Villareal DT, Miller BV III, Banks M, et al. Effect of lifestyle intervention on metabolic coronary heart disease risk factors in obese older adults. Am J Clin Nutr. 2006;84:1317-23. | No weight outcomes
Villareal DT, Banks M, Sinacore DR, et al. Effect of weight loss and exercise on frailty in obese older adults. Arch Intern Med. 2006;166:860-6. | No weight outcomes
Villareal DT, Shah K, Banks MR, et al. Effect of weight loss and exercise therapy on bone metabolism and mass in obese older adults: a one-year randomized controlled trial. J Clin Endocrinol Metab. 2008;93:2181-7. | No weight outcomes
Wassertheil-Smoller S, Langford HG, Blaufox MD, et al. Effective dietary intervention in hypertensives: sodium restriction and weight reduction. J Am Diet Assoc. 1985;85:423-30. | No weight outcomes
Werkman A, Hulshof PJ, Stafleu A, et al. Effect of an individually tailored one-year energy balance programme on body weight, body composition and lifestyle in recent retirees: a cluster randomised controlled trial. BMC Public Health. 2010;10:110. | No weight outcomes
Whelton PK, Hebert PR, Cutler J, et al. Baseline characteristics of participants in phase I of the Trials of Hypertension Prevention. Ann Epidemiol. 1992;2:295-310. | No weight outcomes
Wood PD, Stefanick ML, Dreon DM, et al. Changes in plasma lipids and lipoproteins in overweight men during weight loss through dieting as compared with exercise. N Engl J Med. 1988;319:1173-9. | No weight outcomes
Woollard J, Burke V, Beilin LJ, et al. Effects of a general practice-based intervention on diet, body mass index and blood lipids in patients at cardiovascular risk. J Cardiovasc Risk. 2003;10:31-40. | No weight outcomes
Lakerveld J, Bot SD, Chinapaw MJ, et al. Primary prevention of diabetes mellitus type 2 and cardiovascular diseases using a cognitive behavior program aimed at lifestyle changes in people at risk: design of a randomized controlled trial. BMC Endocr Disord. 2008;8:6. | No weight or harms outcomes
Davey SG, Bracha Y, Svendsen KH, et al. Incidence of type 2 diabetes in the randomized Multiple Risk Factor Intervention Trial. Ann Intern Med. 2005;142:313-22 | Not one of the specified interventions
Kosaka K, Noda M, Kuzuya T. Prevention of type 2 diabetes by lifestyle intervention: a Japanese trial in IGT males. Diabetes Res Clin Pract. 2005;67:152-62. | Comparative effectiveness
Jakicic JM, Marcus BH, Lang W, Janney C. Effect of exercise on 24-month weight loss maintenance in overweight women. Arch Intern Med. 1559;168:1550-9. | Comparative effectiveness
Jacob S, Rabbia M, Meier MK, Hauptman J. Orlistat 120 mg improves glycaemic control in type 2 diabetic patients with or without concurrent weight loss. Diabetes Obes Metab. 2009;11:361-71. | Less than 12 months followup

Appendix D Table 3 Studies Excluded From Review for Key Question 3

Reference | Reason for Exclusion
Aadahl M, von Huth SL, Pisinger C, et al. Five-year change in physical activity is associated with changes in cardiovascular disease risk factors. Prev Med. 2009;48(4):326-31. | Does not meet design requirements in inclusion criteria
Acharya NV, Wilton LV, Shakir SA. Safety profile of orlistat: results of a prescription-event monitoring study. Int J Obes. 2006;30:1645-52. | Does not meet design requirements in inclusion criteria
Agurs-Collins TD, Kumanyika SK, Ten Have TR, Adams-Campbell LL. A randomized controlled trial of weight reduction and exercise for diabetes management in older African-American subjects. Diabetes Care. 1997;20:1503-11. | Less than 12 months followup
Akinson RL. Conjugated linoleic acid for altering body composition and treating obesity. In: Yurawecz MP, Mossoba MM, Kramer JK, et al, eds. Advances in Conjugated Linoleic Acid Research. Vol 1. Champaign, IL: AOCS Press; 1999:348-53. | Does not meet design requirements in inclusion criteria
Alhassan S, Kim S, Bersamin A, et al. Dietary adherence and weight loss success among overweight women: results from the A TO Z weight loss study. Int J Obes. 2008;32:985-91. | Comparative effectiveness
Allen P, Thompson JL, Herman CJ,, et al. Impact of periodic follow-up testing among urban American Indian women with impaired fasting glucose. Preventing Chronic Disease. 2008;5:A76. | Not one of the specified interventions
Andersen RE, Wadden TA, Bartlett SJ, et al. Effects of lifestyle activity vs structured aerobic exercise in obese women: a randomized trial. JAMA. 1999;281:335-40. | Comparative effectiveness
Anderson JW, Grant L, Gotthelf L, Stifler LT. Weight loss and long-term follow-up of severely obese individuals treated with an intense behavioral program. Int J Obes. 2007;31:488-93. | Does not meet design requirements in inclusion criteria
Anderssen SA, Carroll S, Urdal P, Holme I. Combined diet and exercise intervention reverses the metabolic syndrome in middle-aged males: results from the Oslo Diet and Exercise Study. Scand J Med Sci Sports. 2007;17:687-95. | No weight outcomes
Anderssen SA, Holme I, Urdal P, Hjermann I. Associations between central obesity and indexes of hemostatic, carbohydrate and lipid metabolism: results of a 1-year intervention from the Oslo Diet and Exercise Study. Scand J Med Sci Sports. 1998;8:109-15. | Does not include specified weight outcomes
Andersson K, Karlstrom B, Freden S, et al. A two-year clinical lifestyle intervention program for weight loss in obesity. Food Nutr Res. 2008;52. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Andrade AM, Coutinho SR, Silva MN, et al. The effect of physical activity on weight loss is mediated by eating self-regulation. Patient Educ Couns. 2010;79(3):320-6. | No weight outcomes
Annunziato RA, Timko CA, Crerand CE, et al. A randomized trial examining differential meal replacement adherence in a weight loss maintenance program after one-year follow-up. Eat Behav. 2009;10:176-83. | Comparative effectiveness
Lakerveld J, Bot SD, Chinapaw MJ, et al. Primary prevention of diabetes mellitus type 2 and cardiovascular diseases using a cognitive behavior program aimed at lifestyle changes in people at risk: design of a randomized controlled trial. BMC Endocr Disord. 2008;8:6. | No weight outcomes
Apfelbaum M, Vague P, Ziegler O, et al. Long-term maintenance of weight loss after a very-low-calorie diet: a randomized blinded trial of the efficacy and tolerability of sibutramine. Am J Med. 1999;106:179-84. | Sibutramine intervention
Appel LJ, Champagne CM, Harsha DW, et al. Effects of comprehensive lifestyle modification on blood pressure control: main results of the PREMIER clinical trial. JAMA. 2003;289:2083-93. | Not one of the specified interventions
Appel LJ, Espeland MA, Easter L, et al. Effects of reduced sodium intake on hypertension control in older individuals: results from the Trial of Nonpharmacologic Interventions in the Elderly (TONE). Arch Intern Med. 2001;161:685-93. | No weight outcomes
Arterburn D, DeLaet D, Schauer D. Obesity in adults. Clin Evid (Online). 2008. | Does not meet design requirements in inclusion criteria
Ash S, Reeves M, Bauer J, et al. A randomised control trial comparing lifestyle groups, individual counselling and written information in the management of weight and health outcomes over 12 months. Int J Obes. 2006;30:1557-64. | Comparative effectiveness
Ashley JM, St Jeor ST, Schrage JP, et al. Weight control in the physician's office. Arch Intern Med. 2001;161:1599-604. | Comparative effectiveness
Ashutosh K, Methrotra K, Fragale-Jackson J. Effects of sustained weight loss and exercise on aerobic fitness in obese women. J Sports Med Phys Fitness. 1997;37:252-7. | Comparative effectiveness
Avenell A, Brown TJ, McGee MA, et al. What are the long-term benefits of weight reducing diets in adults? A systematic review of randomized controlled trials. J Hum Nutr Diet. 2004;17:317-35. | Does not meet design requirements in inclusion criteria
Babamoto KS, Sey KA, Camilleri AJ, et al. Improving diabetes care and health measures among Hispanics using community health workers: results from a randomized controlled trial. Health Educ Behav. 2009;36:113-26. | Less than 12 months followup
Bach DS, Rissanen AM, Mendel CM, et al. Absence of cardiac valve dysfunction in obese patients treated with sibutramine. Obes Res. 1999;7:363-9. | Sibutramine intervention
Bacon L, Keim NL, Van L, et al. Evaluating a “non-diet” wellness intervention for improvement of metabolic fitness, psychological well-being and eating and activity behaviors. Int J Obes Relat Metab Disord. 2002;26:854-65. | Comparative effectiveness
Bakris G, Calhoun D, Egan B, et al. Orlistat improves blood pressure control in obese subjects with treated but inadequately controlled hypertension. J Hypertens. 2002;20:2257-67. | High or differential attrition
Balducci S, Zanuso S, Nicolucci A, et al. Anti-inflammatory effect of exercise training in subjects with type 2 diabetes and the metabolic syndrome is dependent on exercise modalities and independent of weight loss. Nutr Metab Cardiovasc Dis. 2010;20:608-17. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Barr SI, McCarron DA, Heaney RP, et al. Effects of increased consumption of fluid milk on energy and nutrient intake, body weight, and cardiovascular risk factors in healthy older adults. J Am Diet Assoc. 2000;100:810-7. | Not one of the specified interventions
Bauer C, Fischer A, Keller U. Effect of sibutramine and of cognitive-behavioural weight loss therapy in obesity and subclinical binge eating disorder. Diabetes Obes Metab. 2006;8:289-95. | Less than 12 months followup
Beck-da-Silva L, Higginson L, Fraser M, et al. Effect of orlistat in obese patients with heart failure: a pilot study. Congest Heart Fail. 2005;11:118-23. | Less than 12 months followup
Bemelmans WJ, Broer J, de Vries JH, et al. Impact of Mediterranean diet education versus posted leaflet on dietary habits and serum cholesterol in a high risk population for cardiovascular disease. Public Health Nutr. 2000;3:273-83. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Bergstrom I, Lombardo C, Brinck J. Physical training decreases waist circumference in postmenopausal borderline overweight women. Acta Obstet Gynecol Scand. 2009;88:308-13. | Focus on patients in subgroups other than specified conditions
Bhargava A, Guthrie JF. Unhealthy eating habits, physical exercise and macronutrient intakes are predictors of anthropometric indicators in the Women's Health Trial Feasibility Study in Minority Populations. Br J Nutr. 2002;88:719-28. | Not one of the specified interventions
Blumenthal JA, Sherwood A, Gullette EC, et al. Exercise and weight loss reduce blood pressure in men and women with mild hypertension: effects on cardiovascular, metabolic, and hemodynamic functioning. Arch Intern Med. 2000;160:1947-58. | Less than 12 months followup
Bo S, Ciccone G, Baldi C, et al. Effectiveness of a lifestyle intervention on metabolic syndrome: a randomized controlled trial. J Gen Intern Med. 2007;22:1695-703. | Not one of the specified interventions
Bo S, Ciccone G, Guidi S, et al. Diet or exercise: what is more effective in preventing or reducing metabolic alterations? Eur J Endocrinol. 2008;159:685-91. | Not one of the specified interventions
Borg P, Kukkonen-Harjula K, Fogelholm M, Pasanen M. Effects of walking or resistance training on weight loss maintenance in obese, middle-aged men: a randomized trial. Int J Obes Relat Metab Disord. 2002;26:676-83. | Comparative effectiveness
Botomino A, Bruppacher R, Krahenbuhl S, Hersberger KE. Change of body weight and lifestyle of persons at risk for diabetes after screening and counselling in pharmacies. Pharm World Sci. 2008;30:222-6. | Does not meet design requirements in inclusion criteria
Bowen D, Clifford CK, Coates R, et al. The Women's Health Trial Feasibility Study in Minority Populations: design and baseline descriptions. Ann Epidemiol. 1996;6:507-19. | Not one of the specified interventions
Bowen J, Noakes M, Clifton PM. A high dairy protein, high-calcium diet minimizes bone turnover in overweight adults during weight loss. J Nutr. 2004;134:568-73. | Less than 12 months followup
Bowerman S, Bellman M, Saltsman P, et al. Implementation of a primary care physician network obesity management program. Obes Res. 2001;9(Suppl 4):S321-5. | Less than 12 months followup
Bravata DM, Smith-Spangler C, Sundaram V, et al. Using pedometers to increase physical activity and improve health: a systematic review. JAMA. 2007;298:2296-304. | Does not meet design requirements in inclusion criteria
Brinkworth GD, Noakes M, Keogh JB, et al. Long-term effects of a high-protein, low-carbohydrate diet on weight control and cardiovascular risk markers in obese hyperinsulinemic subjects. Int J Obes Relat Metab Disord. 2004;28:661-70. | Comparative effectiveness
Brinkworth GD, Noakes M, Parker B, et al. Long-term effects of advice to consume a high-protein, low-fat diet, rather than a conventional weight-loss diet, in obese adults with type 2 diabetes: one-year follow-up of a randomised trial. Diabetologia. 2004;47:1677-86. | Comparative effectiveness
Broom I, Hughes E, Dodson P, Reckless J. The role of orlistat in the treatment of obese patients with mild to moderate hypercholesterolaemia: consequences for coronary risk. Br J Cardiol. 2002;9:460-8. | Less than 12 months followup
Brownell KD. The LEARN Program for Weight Management. New Haven, CT: American Health Publishing Company; 2000. | Comparative effectiveness
Bryan J, Tiggemann M. The effect of weight-loss dieting on cognitive performance and psychological well-being in overweight women. Appetite. 2001;36:147-56. | Less than 12 months followup
Buchwald H, Avidor Y, Braunwald E, et al. Bariatric surgery: a systematic review and meta-analysis. JAMA. 2004;292:1724-37. | Does not meet design requirements in inclusion criteria
Burke V, Beilin LJ, Cutt HE, et al. A lifestyle program for treated hypertensives improved health-related behaviors and cardiovascular risk factors, a randomized controlled trial. J Clin Epidemiol. 2007;60:133-41. | No weight outcomes
Burke V, Mansour J, Beilin LJ, Mori TA. Long-term follow-up of participants in a health promotion program for treated hypertensives (ADAPT). Nutr Metab Cardiovasc Dis. 2008;18:198-206. | No weight outcomes
Burke V, Mori TA, Giangiulio N, et al. An innovative program for changing health behaviours. Asia Pac J Clin Nutr. 2002;11(Suppl 3):S586-97. | High or differential attrition
Caan B, Neuhouser M, Aragaki A, et al. Calcium plus vitamin D supplementation and the risk of postmenopausal weight gain. Arch Intern Med. 2007;167:893-902. | Not one of the specified interventions
Calle-Pascual AL, Rodriguez C, Camacho F, et al. Behaviour modification in obese subjects with type 2 diabetes mellitus. Diabetes Res Clin Pract. 1992;15:157-62. | Does not meet design requirements in inclusion criteria
Campbell PT, Campbell KL, Wener MH, et al. A yearlong exercise intervention decreases CRP among obese postmenopausal women. Med Sci Sports Exerc. 2009;41:1533-9. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Carr DB, Utzschneider KM, Boyko EJ, et al. A reduced-fat diet and aerobic exercise in Japanese Americans with impaired glucose tolerance decreases intra-abdominal fat and improves insulin sensitivity but not beta-cell function. Diabetes. 2005;54:340-7. | Comparative effectiveness
Carr LJ, Bartee RT, Dorozynski CM, et al. Eight-month follow-up of physical activity and central adiposity: results from an Internet-delivered randomized control trial intervention. J Phys Act Health. 2009;6:444-55. | Comparative effectiveness
Castaneda C, Layne JE, Munoz-Orians L, et al. A randomized controlled trial of resistance exercise training to improve glycemic control in older adults with type 2 diabetes. Diabetes Care. 2002;25:2335-41. | Less than 12 months followup
Chang MW, Nitzke S, Brown R. Design and outcomes of a Mothers In Motion behavioral intervention pilot study. J Nutr Educ Behav. 2010;42(Suppl 3):S11-21. | Less than 12 months followup
Charles MA, Morange P, Eschwege E, et al. Effect of weight change and metformin on fibrinolysis and the von Willebrand factor in obese nondiabetic subjects: the BIGPRO1 study. Diabetes Care. 1998;21:1967-72. | No weight outcomes
Cheyette C. Weight No More: a randomised controlled trial for people with type 2 diabetes on insulin therapy. Pract Diabetes Int. 2007;24:450-6. | High or differential attrition
Chiasson JL, Lau DC, Leiter LA, et al. Fluoxetine has potential in obese NIDDM—multicenter Canadian trial. Diabetes. 1989;38(Suppl 2):A154. | Not one of the specified interventions
Clark M, Hampson SE, Avery L, Simpson R. Effects of a tailored lifestyle self-management intervention in patients with type 2 diabetes. Br J Health Psychol. 2004;9:365-79. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Clarke KK, Freeland-Graves J, Klohe-Lehman DM, et al. Promotion of physical activity in low-income mothers using pedometers. J Am Diet Assoc. 2007;107:962-7. | Less than 12 months followup
Clifford PA, Tan SY, Gorsuch RL. Efficacy of a self-directed behavioral health change program: weight, body composition, cardiovascular fitness, blood pressure, health risk, and psychosocial mediating variables. J Behav Med. 1991;14:303-23. | Comparative effectiveness
Cocco G, Pandolfi S, Rousson V. Sufficient weight reduction decreases cardiovascular complications in diabetic patients with the metabolic syndrome: a randomized study of orlistat as an adjunct to lifestyle changes (diet and exercise). Heart Drug. 2005;5:68-74. | Less than 12 months followup
Coker RH, Williams RH, Yeo SE, et al. The impact of exercise training compared to caloric restriction on hepatic and peripheral insulin resistance in obesity. J Clin Endocrinol Metab. 2009;94:4258-66. | Less than 12 months followup
Corpeleijn E, Feskens EJ, Jansen EH, et al. Improvements in glucose tolerance and insulin sensitivity after lifestyle intervention are related to changes in serum fatty acid profile and desaturase activities: the SLIM study. Diabetologia. 2006;49:2392-401. | Not one of the specified interventions
Counterweight Project Team. Evaluation of the Counterweight Programme for obesity management in primary care: a starting point for continuous improvement. Br J Gen Pract. 2008;58:548-54. | Does not meet design requirements in inclusion criteria
Counterweight Project Team. Influence of body mass index on prescribing costs and potential cost savings of a weight management programme in primary care. J Health Serv Res Policy. 2008;13:158-66. | Does not meet design requirements in inclusion criteria
Cousins JH, Rubovits DS, Dunn JK, et al. Family versus individually oriented intervention for weight loss in Mexican American women. Public Health Rep. 1992;107:549-55. | Comparative effectiveness
Cuellar GE, Ruiz AM, Monsalve MC, Berber A. Six-month treatment of obesity with sibutramine 15 mg; a double-blind, placebo-controlled monocenter clinical trial in a Hispanic population. Obes Res. 2000;8:71-82. | Not on list of countries with HDI > 0.90
Culturally appropriate lifestyle interventions promote weight loss in rural dwelling people with type 2 diabetes. Evid Based Healthc Public Health. 2005;9:231-2. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Dale KS, Mann JI, McAuley KA, et al. Sustainability of lifestyle changes following an intensive lifestyle intervention in insulin resistant adults: follow-up at 2-years. Asia Pac J Clin Nutr. 2009;18:114-20. | Comparative effectiveness
Dale KS, McAuley KA, Taylor RW, et al. Determining optimal approaches for weight maintenance: a randomized controlled trial. Can Med Assoc J. 2009;180:E39-46. | Comparative effectiveness
Davey SG, Bracha Y, Svendsen KH, et al. Incidence of type 2 diabetes in the randomized Multiple Risk Factor Intervention Trial. Ann Intern Med. 2005;142:313-22. | Not one of the specified interventions
Davies MJ, Heller S, Skinner TC, et al. Effectiveness of the Diabetes Education and Self Management for Ongoing and Newly Diagnosed (DESMOND) Programme for people with newly diagnosed type 2 diabetes: cluster randomised controlled trial. BMJ. 2008;336:491-5. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Davis BR, Blaufox MD, Oberman A, et al. Reduction in long-term antihypertensive medication requirements: effects of weight reduction by dietary intervention in overweight persons with mild hypertension. Arch Intern Med. 1993;153:1773-82. | No weight outcomes
de Waard F, Ramlau R, Mulders Y, et al. A feasibility study on weight reduction in obese postmenopausal breast cancer patients. Eur J Cancer Prev. 1993;2:233-8. | Focus on patients in subgroups other than specified conditions
de Wit LT, Mathus-Vliegen L, Hey C, et al. Open versus laparoscopic adjustable silicone gastric banding: a prospective randomized trial for treatment of morbid obesity. Ann Surg. 1999;230:800-5. | Not one of the specified interventions
Delahanty LM, Nathan DM. Implications of the Diabetes Prevention Program and Look AHEAD clinical trials for lifestyle interventions. J Am Diet Assoc. 2008;108(Suppl 1):S66-72. | Comparative effectiveness
Delecluse C, Colman V, Roelants M, et al. Exercise programs for older men: mode and intensity to induce the highest possible health-related benefits. Prev Med. 2004;39:823-33. | Less than 12 months followup
Dennis KE, Tomoyasu N, McCrone SH, et al. Self-efficacy targeted treatments for weight loss in postmenopausal women. Sch Inq Nurs Pract. 2001;15:259-76. | Comparative effectiveness
Derosa G, Cicero AF, Murdolo G, et al. Efficacy and safety comparative evaluation of orlistat and sibutramine treatment in hypertensive obese patients. Diabetes Obes Metab. 2005;7:47-55. | Comparative effectiveness
Devine A, Prince RL, Bell R. Nutritional effect of calcium supplementation by skim milk powder or calcium tablets on total nutrient intake in postmenopausal women. Am J Clin Nutr. 1996;64:731-7. | Comparative effectiveness
Di Francesco V, Sacco T, Zamboni M, et al. Weight loss and quality of life improvement in obese subjects treated with sibutramine: a double-blind randomized multicenter study. Ann Nutr Metab. 2007;51:75-81. | Sibutramine intervention
Di Loreto C, Fanelli C, Lucidi P, et al. Validation of a counseling strategy to promote the adoption and the maintenance of physical activity by type 2 diabetic subjects. Diabetes Care. 2003;26:404-8. | Comparative effectiveness
Ditschuneit HH, Flechtner-Mors M, Johnson TD, Adler G. Metabolic and weight-loss effects of a long-term dietary intervention in obese patients. Am J Clin Nutr. 1999;69:198-204. | Comparative effectiveness
Djuric Z, DiLaura NM, Jenkins I, et al. Combining weight-loss counseling with the Weight Watchers plan for obese breast cancer survivors. Obes Res. 2002;10:657-65. | Focus on patients in subgroups other than specified conditions
Donnelly JE, Hill JO, Jacobsen DJ, et al. Effects of a 16-month randomized controlled exercise trial on body weight and composition in young, overweight men and women: the Midwest Exercise Trial. Arch Intern Med. 2003;163:1343-50. | High or differential attrition
Donnelly JE, Jacobsen DJ, Heelan KS, et al. The effects of 18 months of intermittent vs. continuous exercise on aerobic capacity, body weight and composition, and metabolic fitness in previously sedentary, moderately obese females. Int J Obes Relat Metab Disord. 2000;24:566-72. | Comparative effectiveness
Donnelly JE, Kirk EP, Jacobsen DJ, et al. Effects of 16 mo of verified, supervised aerobic exercise on macronutrient intake in overweight men and women: the Midwest Exercise Trial. Am J Clin Nutr. 2003;78:950-6. | High or differential attrition
Donnelly JE, Smith BK, Dunn L, et al. Comparison of a phone vs clinic approach to achieve 10% weight loss. Int J Obes. 2007;31:1270-6. | Less than 12 months followup
Due A, Larsen TM, Mu H, et al. Comparison of 3 ad libitum diets for weight-loss maintenance, risk of cardiovascular disease, and diabetes: a 6-mo randomized, controlled trial. Am J Clin Nutr. 2008;88:1232-41. | Less than 12 months followup
Dujovne CA, Zavoral JH, Rowe E, Mendel CM. Effects of sibutramine on body weight and serum lipids: a double-blind, randomized, placebo-controlled study in 322 overweight and obese patients with dyslipidemia. Am Heart J. 2001;142:489-97. | Sibutramine intervention
Dunn AL, Marcus BH, Kampert JB, et al. Comparison of lifestyle and structured interventions to increase physical activity and cardiorespiratory fitness: a randomized trial. JAMA. 1999;281:327-34. | Comparative effectiveness
Dunstan DW, Daly RM, Owen N, et al. Home-based resistance training is not sufficient to maintain improved glycemic control following supervised training in older individuals with type 2 diabetes. Diabetes Care. 2005;28:3-9. | Comparative effectiveness
Dutton GR, Davis MP, Welsch MA, Brantley PJ. Promoting physical activity for low-income minority women in primary care. Am J Health Behavior. 2007;31:622-31. | No weight outcomes
Dymek MP, Le Grange D, Neven K, Alverdy J. Quality of life after gastric bypass surgery: a cross-sectional study. Obes Res. 2002;10:1135-42. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Dymek MP, Le Grange D, Neven K, Alverdy J. Quality of life and psychosocial adjustment in patients after Roux-en-Y gastric bypass: a brief report. Obes Surg. 2001;11:32-9. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Dyson PA, Hammersley MS, Morris RJ, et al. The Fasting Hyperglycaemia Study, II: randomized controlled trial of reinforced healthy-living advice in subjects with increased but not diabetic fasting plasma glucose. Metabolism. 1997;46:50-5. | Not one of the specified interventions
Dzator JA, Hendrie D, Burke V, et al. A randomized trial of interactive group sessions achieved greater improvements in nutrition and physical activity at a tiny increase in cost. J Clin Epidemiol. 2004;57:610-9. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Early JL, Apovian CM, Aronne LJ, et al. Sibutramine plus meal replacement therapy for body weight loss and maintenance in obese patients. Obesity. 2007;15:1464-72. | Sibutramine intervention
Eddy DM, Schlessinger L, Kahn R. Clinical outcomes and cost-effectiveness of strategies for managing people at high risk for diabetes. Ann Intern Med. 2005;143:251-64. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Eiben G, Lissner L. Health Hunters—an intervention to prevent overweight and obesity in young high-risk women. Int J Obes. 2006;30:691-6. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Elhayany A, Lustman A, Abel R, et al. A low carbohydrate Mediterranean diet improves cardiovascular risk factors and diabetes control among overweight patients with type 2 diabetes mellitus: a 1-year prospective randomized intervention study. Diabetes Obes Metab. 2010;12:204-9. | Comparative effectiveness
Elmer PJ, Obarzanek E, Vollmer WM, et al. Effects of comprehensive lifestyle modification on diet, weight, physical fitness, and blood pressure control: 18-month results of a randomized trial. Ann Intern Med. 2006;144:485-95. | Comparative effectiveness
Ely AC, Banitt A, Befort C, et al. Kansas primary care weighs in: a pilot randomized trial of a chronic care model program for obesity in 3 rural Kansas primary care practices. J Rural Health. 2008;24:125-32. | Less than 12 months followup
Eriksson KM, Westborg CJ, Eliasson MC. A randomized trial of lifestyle intervention in primary healthcare for the modification of cardiovascular risk factors. Scand J Public Health. 2006;34:453-61. | Not one of the specified interventions
Esposito K, Giugliano F, Di Palo C, et al. Effect of lifestyle changes on erectile dysfunction in obese men: a randomized controlled trial. JAMA. 2004;291:2978-84. | Comparative effectiveness
Esposito K, Marfella R, Ciotola M, et al. Effect of a Mediterranean-style diet on endothelial dysfunction and markers of vascular inflammation in the metabolic syndrome: a randomized trial. JAMA. 2004;292:1440-6. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Esposito K, Pontillo A, Di Palo C, et al. Effect of weight loss and lifestyle changes on vascular inflammatory markers in obese women: a randomized trial. JAMA. 2003;289:1799-804. | Comparative effectiveness
Fabricatore AN, Wadden TA, Moore RH, et al. Predictors of attrition and weight loss success: results from a randomized controlled trial. Behav Res Ther. 2009;47:685-91. | Comparative effectiveness
Fanghanel G, Cortinas L, Sanchez-Reyes L, Berber A. A clinical trial of the use of sibutramine for the treatment of patients suffering essential obesity. Int J Obes Relat Metab Disord. 2000;24:144-50. | Less than 12 months followup
Fanghanel G, Cortinas L, Sanchez-Reyes L, et al. Safety and efficacy of sibutramine in overweight Hispanic patients with hypertension. Adv Ther. 2003;20:101-13. | Less than 12 months followup
Faria AN, Ribeiro Filho FF, Kohlmann NE, et al. Effects of sibutramine on abdominal fat mass, insulin resistance and blood pressure in obese hypertensive patients. Diabetes Obes Metab. 2005;7:246-53. | Less than 12 months followup
Faria AN, Ribeiro Filho FF, Lerario DD, et al. Effects of sibutramine on the treatment of obesity in patients with arterial hypertension. Arq Bras Cardiol. 2002;78:172-80. | Less than 12 months followup
Faulconbridge LF, Wadden TA, Berkowitz RI, et al. Changes in symptoms of depression with weight loss: results of a randomized trial. Obesity. 2009;17:1009-16. | No placebo in medication trial
Ferre R, Plana N, Merino J, et al. Effects of therapeutic lifestyle changes on peripheral artery tonometry in patients with abdominal obesity. Nutr Metab Cardiovasc Dis. 2010 Aug 11. [Epub ahead of print] | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Figueroa A, Going SB, Milliken LA, et al. Effects of exercise training and hormone replacement therapy on lean and fat mass in postmenopausal women. J Gerontol A Biol Sci Med Sci. 2003;58:266-70. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Finer N, Bloom SR, Frost GS, et al. Sibutramine is effective for weight loss and diabetic control in obesity with type 2 diabetes: a randomised, double-blind, placebo-controlled study. Diabetes Obes Metab. 2000;2:105-12. | Sibutramine intervention
Finkelstein EA, Linnan LA, Tate DF, Leese PJ. A longitudinal study on the relationship between weight loss, medical expenditures, and absenteeism among overweight employees in the WAY to Health study. J Occup Environ Med. 2009;51:1367-73. | Conducted primarily in a non-relevant setting
Finley CE, Barlow CE, Greenway FL, et al. Retention rates and weight loss in a commercial weight loss program. Int J Obes (Lond). 2007;31:292-8. | Does not meet design requirements in inclusion criteria
Flechtner-Mors M, Ditschuneit HH, Johnson TD, et al. Metabolic and weight loss effects of long-term dietary intervention in obese patients: four-year results. Obes Res. 2000;8:399-402. | Comparative effectiveness
Fleming RM. The effect of high-, moderate-, and low-fat diets on weight loss and cardiovascular disease risk factors. Prev Cardiol. 2002;5:110-8. | Comparative effectiveness
Flood A, Mitchell N, Jaeb M, et al. Energy density and weight change in a long-term weight-loss trial. Int J Behav Nutr Phys Act. 2009;6:57. | Study of overweight/obesity prevention
Focht BC, Rejeski WJ, Ambrosius WT, et al. Exercise, self-efficacy, and mobility performance in overweight and obese older adults with knee osteoarthritis. Arthritis Rheum. 2005;53:659-65. | Comparative effectiveness
Fogelholm M, Kukkonen-Harjula K, Nenonen A, Pasanen M. Effects of walking training on weight maintenance after a very-low-energy diet in premenopausal obese women: a randomized controlled trial. Arch Intern Med. 2000;160:2177-84. | Comparative effectiveness
Fogelholm M, Kukkonen-Harjula K, Oja P. Eating control and physical activity as determinants of short-term weight maintenance after a very-low-calorie diet among obese women. Int J Obes Relat Metab Disord. 1999;23:203-10. | Comparative effectiveness
Fontana L, Villareal DT, Weiss EP, et al. Calorie restriction or exercise: effects on coronary heart disease risk factors: a randomized, controlled trial. Am J Physiol Endocrinol Metab. 2007;293:E197-202. | Comparative effectiveness
Fontbonne A, Diouf I, Baccara-Dinet M, et al. Effects of 1-year treatment with metformin on metabolic and cardiovascular risk factors in non-diabetic upper-body obese subjects with mild glucose anomalies: a post-hoc analysis of the BIGPRO1 trial. Diabetes Metab. 2009;35:385-91. | No weight outcomes
Fossati M, Amati F, Painot D, et al. Cognitive-behavioral therapy with simultaneous nutritional and physical activity education in obese patients with binge eating disorder. Eat Weight Disord. 2004;9:134-8. | Focus on patients in subgroups other than specified conditions
Foster GD, Borradaile KE, Sanders MH, et al. A randomized study on the effect of weight loss on obstructive sleep apnea among obese patients with type 2 diabetes: the Sleep AHEAD study. Arch Intern Med. 2009;169:1619-26. | Comparative effectiveness
Foster GD, Wyatt HR, Hill JO, et al. A randomized trial of a low-carbohydrate diet for obesity. N Engl J Med. 2003;348:2082-90. | Comparative effectiveness
Foster-Schubert KE, McTiernan A, Frayo RS, et al. Human plasma ghrelin levels increase during a one-year exercise program. J Clin Endocrinol Metab. 2005;90:820-5. | No weight outcomes
Fujimoto WY, Jablonski KA, Bray GA, et al. Body size and shape changes and the risk of diabetes in the Diabetes Prevention Program. Diabetes. 2007;56:1680-5. | No weight outcomes
Gambineri A, Pelusi C, Genghini S, et al. Effect of flutamide and metformin administered alone or in combination in dieting obese women with polycystic ovary syndrome. Clin Endocrinol. 2004;60:241-9. | No weight outcomes
Gaullier JM, Halse J, Hoye K, et al. Conjugated linoleic acid supplementation for 1 y reduces body fat mass in healthy overweight humans. Am J Clin Nutr. 2004;79:1118-25. | Not one of the specified interventions
Gaullier JM, Halse J, Hoye K, et al. Supplementation with conjugated linoleic acid for 24 months is well tolerated by and reduces body fat mass in healthy, overweight humans. J Nutr. 2005;135:778-84. | Not one of the specified interventions
Ghroubi S, Elleuch H, Chikh T, et al. Physical training combined with dietary measures in the treatment of adult obesity: a comparison of two protocols. Ann Phys Rehab Med. 2009;52:394-413. | Not on list of countries with HDI > 0.90
Giugliano D, Quatraro A, Consoli G, et al. Metformin for obese, insulin-treated diabetic patients: improvement in glycaemic control and reduction of metabolic risk factors. Eur J Clin Pharmacol. 1993;44:107-12. | Less than 12 months followup
Glasgow RE, La Chance PA, Toobert DJ, et al. Long-term effects and costs of brief behavioural dietary intervention for patients with diabetes delivered from the medical office. Patient Educ Couns. 1997;32:175-84. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Glasgow RE, Nelson CC, Kearney KA, et al. Reach, engagement, and retention in an Internet-based weight loss program in a multi-site randomized controlled trial. J Med Internet Res. 2007;9:e11. | No weight outcomes
Godoy-Matos A, Carraro L, Vieira A, et al. Treatment of obese adolescents with sibutramine: a randomized, double-blind, controlled study. J Clin Endocrinol Metab. 2005;90:1460-5. | Focus on children or adolescents
Gokcel A, Gumurdulu Y, Karakose H, et al. Evaluation of the safety and efficacy of sibutramine, orlistat and metformin in the treatment of obesity. Diabetes Obes Metab. 2002;4:49-55. | Comparative effectiveness
Gokcel A, Karakose H, Ertorer EM, et al. Effects of sibutramine in obese female subjects with type 2 diabetes and poor blood glucose control. Diabetes Care. 2001;24:1957-60. | Not on list of countries with HDI > 0.90
Gold BC, Burke S, Pintauro S, et al. Weight loss on the web: a pilot study comparing a structured behavioral intervention to a commercial program. Obesity. 2007;15:155-64. | Comparative effectiveness
Gotfredsen A, Westergren HH, Andersen T. Influence of orlistat on bone turnover and body composition. Int J Obes Relat Metab Disord. 2001;25:1154-60. | No weight outcomes
Greaves CJ, Middlebrooke A, O'Loughlin L, et al. Motivational interviewing for modifying diabetes risk: a randomised controlled trial. Br J Gen Pract. 2008;58:535-40. | Less than 12 months followup
Grimm RH Jr, Grandits GA, Cutler JA, et al. Relationships of quality-of-life measures to long-term lifestyle and drug treatment in the Treatment of Mild Hypertension Study. Arch Intern Med. 1997;157:638-48. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Guisado JA, Vaz FJ, Alarcon J, et al. Psychopathological status and interpersonal functioning following weight loss in morbidly obese patients undergoing bariatric surgery. Obes Surg. 2002;12:835-40. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Gunther CW, Legowski PA, Lyle RM, et al. Dairy products do not lead to alterations in body weight or fat mass in young women in a 1-y intervention. Am J Clin Nutr. 2005;81:751-6. | Study of overweight/obesity prevention
Gurka MJ, Wolf AM, Conaway MR, et al. Lifestyle intervention in obese patients with type 2 diabetes: impact of the patient's educational background. Obesity. 2006;14:1085-92. | Comparative effectiveness
Gustafson A, Khavjou O, Stearns SC, et al. Cost-effectiveness of a behavioral weight loss intervention for low-income women: the Weight-Wise Program. Prev Med. 2009;49:390-5. | Less than 12 months followup
Guy-Grand B, Drouin P, Eschwege E, et al. Effects of orlistat on obesity-related diseases—a six-month randomized trial. Diabetes Obes Metab. 2004;6:375-83. | Less than 12 months followup
Hainer V, Kunesova M, Bellisle F, et al. Psychobehavioral and nutritional predictors of weight loss in obese women treated with sibutramine. Int J Obes (Lond). 2005;29:208-16. | Less than 12 months followup
Hakala K, Maasilta P, Sovijarvi AR. Upright body position and weight loss improve respiratory mechanics and daytime oxygenation in obese patients with obstructive sleep apnoea. Clin Physiol. 2000;20:50-5. | Does not meet design requirements in inclusion criteria
Hall WD, Feng Z, George VA, et al. Low-fat diet: effect on anthropometrics, blood pressure, glucose, and insulin in older women. Ethn Dis. 2003;13:337-43. | Less than 12 months followup
Hansen D, Astrup A, Toubro S, et al. Predictors of weight loss and maintenance during 2 years of treatment by sibutramine in obesity: results from the European multi-centre STORM trial. Int J Obes Rel Metab Disord. 2001;25:496-501. | High or differential attrition
Hansen DL, Toubro S, Stock MJ, et al. The effect of sibutramine on energy expenditure and appetite during chronic treatment without dietary restriction. Int J Obes Relat Metab Disord. 1999;23:1016-24. | Sibutramine intervention
Harvey BJ, Gold BC, Lauber R, Starinski A. The impact of calcium and dairy product consumption on weight loss. Obes Res. 2005;13:1720-6. | Comparative effectiveness
Harvey-Berino J, Pintauro S, Buzzell P, et al. Does using the Internet facilitate the maintenance of weight loss? Int J Obes Relat Metab Disord. 2002;26:1254-60. | Comparative effectiveness
Harvey-Berino J, Pintauro S, Buzzell P, Gold EC. Effect of Internet support on the long-term maintenance of weight loss. Obes Res. 2004;12:320-9. | Comparative effectiveness
Harvey-Berino J, Pintauro SJ, Gold EC. The feasibility of using Internet support for the maintenance of weight loss. Behav Modif. 2002;26:103-16. | Less than 12 months followup
Haskell WL, Alderman EL, Fair JM, et al. Effects of intensive multiple risk factor reduction on coronary atherosclerosis and clinical cardiac events in men and women with coronary artery disease. Circulation. 1994;89:975-90. | Not one of the specified interventions
Haub MD, Simons TR, Cook CM, et al. Calcium-fortified beverage supplementation on body composition in postmenopausal women. Nutr J. 2005;4:21. | Not one of the specified interventions
Hauner H, Meier M, Wendland G, et al. Weight reduction by sibutramine in obese subjects in primary care medicine: the SAT Study. Exp Clin Endocrinol Diabetes. 2004;112:201-7. | Sibutramine intervention
Hawley G, Horwath C, Gray A, et al. Sustainability of health and lifestyle improvements following a non-dieting randomised trial in overweight women. Prev Med. 2008;47:593-9. | Comparative effectiveness
Hays NP, Starling RD, Sullivan DH, et al. Effects of an ad libitum, high carbohydrate diet and aerobic exercise training on insulin action and muscle metabolism in older men and women. J Gerontol A Biol Sci Med Sci. 2006;61:299-304. | Comparative effectiveness
Hazenberg BP. Randomized, double-blind, placebo-controlled, multicenter study of sibutramine in obese hypertensive patients. Cardiology. 2000;94:152-8. | Sibutramine intervention
Hensrud DD. Dietary treatment and long-term weight loss and maintenance in type 2 diabetes. Obes Res. 2001;9(Suppl 4):S348-53. | Does not meet design requirements in inclusion criteria
Herman WH, Hoerger TJ, Brandle M, et al. The cost-effectiveness of lifestyle modification or metformin in preventing type 2 diabetes in adults with impaired glucose tolerance. Ann Intern Med. 2005;142:323-32. | No weight outcomes
Hermann LS, Kalen J, Katzman P, et al. Long-term glycaemic improvement after addition of metformin to insulin in insulin-treated obese type 2 diabetes patients. Diabetes Obes Metab. 2001;3:428-34. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Heshka S, Anderson JW, Atkinson RL, et al. Weight loss with self-help compared with a structured commercial program: a randomized trial. JAMA. 2003;289:1792-8. | Comparative effectiveness
Heymsfield SB, Segal KR, Hauptman J, et al. Effects of weight loss with orlistat on glucose tolerance and progression to type 2 diabetes in obese adults. Arch Intern Med. 2000;160:1321-6. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Hivert MF, Langlois MF, Berard P, et al. Prevention of weight gain in young adults through a seminar-based intervention program. Int J Obes. 2007;31:1262-9. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Hoeger KM, Kochman L, Wixom N, et al. A randomized, 48-week, placebo-controlled trial of intensive lifestyle modification and/or metformin therapy in overweight women with polycystic ovary syndrome: a pilot study. Fertil Steri. 2004;82:421-9. | High or differential attrition
Hooper L. Primary prevention of CVD: diet and weight loss. Clin Evid (Online). 2007. | Does not meet design requirements in inclusion criteria
Hope AA, Kumanyika SK, Shults J, Holmes WC. Changes in health-related quality of life among African-Americans in a lifestyle weight loss program. Qual Life Res. 2010;19:1025-33. | Does not meet design requirements in inclusion criteria
Howard BV, Manson JE, Stefanick ML, et al. Low-fat dietary pattern and weight change over 7 years: the Women's Health Initiative Dietary Modification Trial. JAMA. 2006;295:39-49. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Hsieh CJ, Wang PW, Liu RT, et al. Orlistat for obesity: benefits beyond weight loss. Diabetes Res Clin Pract. 2005;67:78-83. | Not on list of countries with HDI > 0.90
Hunter GR, Brock DW, Byrne NM, et al. Exercise training prevents regain of visceral fat for 1 year following weight loss. Obesity. 2010;18:690-5. | Comparative effectiveness
Jacob S, Rabbia M, Meier MK, Hauptman J. Orlistat 120 mg improves glycaemic control in type 2 diabetic patients with or without concurrent weight loss. Diabetes Obes Metab. 2009;11:361-71. | Less than 12 months followup
Jacobs DR, Sluik D, Rokling-Andersen MH, et al. Association of 1-y changes in diet pattern with cardiovascular disease risk factors and adipokines: results from the 1-y randomized Oslo Diet and Exercise Study. Am J Clin Nutr. 2009;89:509-17. | No weight outcomes
Jakicic JM, Jaramillo SA, Balasubramanyam A, et al. Effect of a lifestyle intervention on change in cardiorespiratory fitness in adults with type 2 diabetes: results from the Look AHEAD Study. Int J Obes. 2009;33:305-16. | Comparative effectiveness
Jakicic JM, Marcus BH, Gallagher KI, et al. Effect of exercise duration and intensity on weight loss in overweight, sedentary women: a randomized trial. JAMA. 2003;290:1323-30. | Comparative effectiveness
Jakicic JM, Marcus BH, Lang W, Janney C. Effect of exercise on 24-month weight loss maintenance in overweight women. Arch Intern Med. 1559;168:1550-9. | Comparative effectiveness
Jakicic JM, Otto AD, Lang W, et al. The effect of physical activity on 18-month weight change in overweight adults. Obesity (Silver Spring). 2011;19:100-9. | Comparative effectiveness
Jakicic JM, Winters C, Lang W, Wing RR. Effects of intermittent exercise and use of home exercise equipment on adherence, weight loss, and fitness in overweight women: a randomized trial. JAMA. 1999;282:1554-60. | Comparative effectiveness
Jalkanen L. The effect of a weight reduction program on cardiovascular risk factors among overweight hypertensives in primary health care. Scand J Soc Med. 1991;19:66-71. | Other quality issues
James WP, Astrup A, Finer N, et al. Effect of sibutramine on weight maintenance after weight loss: a randomised trial. Lancet. 2000;356:2119-25. | Sibutramine intervention
Janssen I, Fortier A, Hudson R, Ross R. Effects of an energy-restrictive diet with or without exercise on abdominal fat, intermuscular fat, and metabolic risk factors in obese women. Diabetes Care. 2002;25:431-8. | Comparative effectiveness
Jarjou LM, Prentice A, Sawo Y, et al. Randomized, placebo-controlled, calcium supplementation study in pregnant Gambian women: effects on breast-milk calcium concentrations and infant birth weight, growth, and bone mineral accretion in the first year of life. Am J Clin Nutr. 2006;83:657-66. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Jarrett RJ, Keen H, Murrells T. Changes in blood pressure and body weight over ten years in men selected for glucose intolerance. J Epidemiol Community Health. 1987;41:145-51. | Comparative effectiveness
Jeffery RW, French SA. Preventing weight gain in adults: design, methods and one year results from the Pound of Prevention study. Int J Obes Relat Metab Disord. 1997;21:457-64. | Study of overweight/obesity prevention
Jeffery RW, Wing RR, Sherwood NE, Tate DF. Physical activity and weight loss: does prescribing higher physical activity goals improve outcome? Am J Clin Nutr. 2003;78:684-9. | Comparative effectiveness
Jehn ML, Patt MR, Appel LJ, Miller ER III. One year follow-up of overweight and obese hypertensive adults following intensive lifestyle therapy. J Hum Nutr Diet. 2006;19:349-54. | Comparative effectiveness
Jensen LB, Kollerup G, Quaade F, Sorensen OH. Bone minerals changes in obese women during a moderate weight loss with and without calcium supplementation. J Bone Miner Res. 2001;16:141-7. | Less than 12 months followup
Jirik-Babb P, Geliebter A. Comparison of psychological characteristics of binging and nonbinging obese, adult, female outpatients. Eat Weight Disord. 2003;8:173-7. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Jordan J, Scholze J, Matiba B, et al. Influence of sibutramine on blood pressure: evidence from placebo-controlled trials. Int J Obes. 2005;29:509-16. | Does not meet design requirements in inclusion criteria
Kajaste S, Brander PE, Telakivi T, et al. A cognitive-behavioral weight reduction program in the treatment of obstructive sleep apnea syndrome with or without initial nasal CPAP: a randomized study. Sleep Med. 2004;5:125-31. | Not one of the specified interventions
Kalter-Leibovici O, Younis-Zeidan N, Atamna A, et al. Lifestyle intervention in obese Arab women: a randomized controlled trial. Arch Intern Med. 2010;170:970-6. | Comparative effectiveness
Kamioka H, Nakamura Y, Okada S, et al. Effectiveness of comprehensive health education combining lifestyle education and hot spa bathing for male white-collar employees: a randomized controlled trial with 1-year follow-up. J Epidemiol. 2009;19:219-30. | Conducted primarily in a non-relevant setting
Kansanen M, Vanninen E, Tuunainen A, et al. The effect of a very low-calorie diet-induced weight loss on the severity of obstructive sleep apnoea and autonomic nervous function in obese patients with obstructive sleep apnoea syndrome. Clin Physiol. 1998;18:377-85. | Does not meet design requirements in inclusion criteria
Karhunen L, Franssila-Kallunki A, Rissanen P, et al. Effect of orlistat treatment on body composition and resting energy expenditure during a two-year weight-reduction programme in obese Finns. Int J Obes Relat Metab Disord. 2000;24:1567-72. | No weight outcomes
Katzer L, Bradshaw AJ, Horwath CC, et al. Evaluation of a “nondieting” stress reduction program for overweight women: a randomized trial. Am J Health Promot. 2008;22:264-74. | Comparative effectiveness
Kaukua JK, Pekkarinen TA, Rissanen AM. Health-related quality of life in a randomised placebo-controlled trial of sibutramine in obese patients with type II diabetes. Int J Obes Relat Metab Disord. 2004;28:600-5. | Sibutramine intervention
Kawano M, Shono N, Yoshimura T, et al. Improved cardio-respiratory fitness correlates with changes in the number and size of small dense LDL: randomized controlled trial with exercise training and dietary instruction. Intern Med. 2009;48:25-32. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Keating GM, Jarvis B. Orlistat: in the prevention and treatment of type 2 diabetes mellitus. Drugs. 2120;61:2107-19. | Does not meet design requirements in inclusion criteria
Kelley DE, Bray GA, Pi-Sunyer FX, et al. Clinical efficacy of orlistat therapy in overweight and obese patients with insulin-treated type 2 diabetes: a 1-year randomized controlled trial. Diabetes Care. 2002;25:1033-41. | High or differential attrition
Keogh JB, Luscombe-Marsh ND, Noakes M, et al. Long-term weight maintenance and cardiovascular risk factors are not different following weight loss on carbohydrate-restricted diets high in either monounsaturated fat or protein in obese hyperinsulinaemic men and women. Br J Nutr. 2007;97:405-10. | Comparative effectiveness
Keranen AM, Savolainen MJ, Reponen AH, et al. The effect of eating behavior on weight loss and maintenance during a lifestyle intervention. Prev Med. 2009;49:32-8. | Comparative effectiveness
Kerr J, Patrick K, Norman G, et al. Randomized control trial of a behavioral intervention for overweight women: impact on depressive symptoms. Depress Anxiety. 2008;25:555-8. | No weight outcomes
Ketola E, Makela M, Klockars M. Individualised multifactorial lifestyle intervention trial for high-risk cardiovascular patients in primary care. Br J Gen Pract. 2001;51:291-4. | Not one of the specified interventions
Kim SH, Lee YM, Jee SH, Nam CM. Effect of sibutramine on weight loss and blood pressure: a meta-analysis of controlled trials. Obes Res. 2003;11:1116-23. | Does not meet design requirements in inclusion criteria
Kim SI, Kim HS. Effectiveness of mobile and Internet intervention in patients with obese type 2 diabetes. Int J Med Inf. 2008;77:399-404. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Kim Y, Pike J, Adams H, et al. Telephone intervention promoting weight-related health behaviors. Prev Med. 2010;50:112-7. | Comparative effectiveness
Kirk EP, Jacobsen DJ, Gibson C, et al. Time course for changes in aerobic capacity and body composition in overweight men and women in response to long-term exercise: the Midwest Exercise Trial (MET). Int J Obes Relat Metab Disord. 2003;27:912-9. | High or differential attrition
Kirk SF, Harvey EL, McConnon A, et al. A randomised trial of an Internet weight control resource: the UK Weight Control Trial. BMC Health Serv Res. 2003;3:19. | No weight outcomes
Knowler WC, Fowler SE, Hamman RF, et al. 10-year follow-up of diabetes incidence and weight loss in the Diabetes Prevention Program Outcomes Study. Lancet. 2009;274:1677-86. | No weight outcomes
Kolotkin RL, Norquist JM, Crosby RD, et al. One-year health-related quality of life outcomes in weight loss trial participants: comparison of three measures. Health Qual Life Outcomes. 2009;7:53. | Not one of the specified interventions
Kosaka K, Noda M, Kuzuya T. Prevention of type 2 diabetes by lifestyle intervention: a Japanese trial in IGT males. Diabetes Res Clin Pract. 2005;67:152-62. | Comparative effectiveness
Kostis JB, Wilson AC, Hooper WC, et al. Association of angiotensin-converting enzyme DD genotype with blood pressure sensitivity to weight loss. Am Heart J. 2002;144:625-9. | No weight outcomes
Kostis JB, Wilson AC, Shindler DM, et al. Persistence of normotension after discontinuation of lifestyle intervention in the trial of TONE. Am J Hypertens. 2002;15:732-4. | No weight outcomes
Krakoff J, Clark JM, Crandall JP, et al. Effects of metformin and weight loss on serum alanine aminotransferase activity in the Diabetes Prevention Program. Obesity (Silver Spring). 2010;18:1762-7. | No weight outcomes
Kraus WE, Houmard JA, Duscha BD, et al. Effects of the amount and intensity of exercise on plasma lipoproteins. N Engl J Med. 2002;347:1483-92. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Kukkonen-Harjula KT, Borg PT, Nenonen AM, Fogelholm MG. Effects of a weight maintenance program with or without exercise on the metabolic syndrome: a randomized trial in obese men. Prev Med. 2005;41:784-90. | Comparative effectiveness
Kuller LH, Kinzel LS, Pettee KK, et al. Lifestyle intervention and coronary heart disease risk factor changes over 18 months in postmenopausal women: the Women On the Move through Activity and Nutrition (WOMAN study) clinical trial. J Womens Health. 2006;15:962-74. | Comparative effectiveness
Kuller LH, Kriska AM, Kinzel LS, et al. The clinical trial of Women On the Move through Activity and Nutrition (WOMAN) study. Contemp Clin Trials. 2006;28:370-81. | Comparative effectiveness
Kumanyika SK, Cook NR, Cutler JA, et al. Sodium reduction for hypertension prevention in overweight adults: further results from the Trials of Hypertension Prevention phase II. J Hum Hypertens. 2005;19:33-45. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Kumanyika SK, Shults J, Fassbender J, et al. Outpatient weight management in African-Americans: the Healthy Eating and Lifestyle Program (HELP) study. Prev Med. 2005;41:488-502. | Comparative effectiveness
Kumanyika SK, Wadden TA, Shults J, et al. Trial of family and friend support for weight loss in African American adults. Arch Intern Med. 2009;169:1795-804. | Comparative effectiveness
Laaksonen DE, Laitinen T, Schonberg J, et al. Weight loss and weight maintenance, ambulatory blood pressure and cardiac autonomic tone in obese persons with the metabolic syndrome. J Hypertens. 2003;21:371-8. | No weight outcomes
Laaksonen DE, Lindstrom J, Lakka TA, et al. Physical activity in the prevention of type 2 diabetes: the Finnish Diabetes Prevention Study. Diabetes. 2005;54:158-65. | No weight outcomes
Lally P, Chipperfield A, Wardle J. Healthy habits: efficacy of simple advice on weight control based on a habit-formation model. Int J Obes (Lond). 2008;32:700-7. | Less than 12 months followup
Larsen TM, Dalskov S, van Baak M, et al. The Diet, Obesity and Genes (Diogenes) dietary study in eight European countries—a comprehensive design for long-term intervention. Obes Rev. 2009;76-91. | Comparative effectiveness
Lasser VI, Raczynski JM, Stevens VJ, et al. Trials of Hypertension Prevention, phase II: structure and content of the weight loss and dietary sodium reduction interventions. Ann Epidemiol. 1995;5:156-64. | No weight outcomes
Laws R; Counterweight Project Team. A new evidence-based model for weight management in primary care: the Counterweight Programme. J Hum Nutr Diet. 2004;17:191-208. | Does not meet design requirements in inclusion criteria
Layman DK, Evans EM, Erickson D, et al. A moderate-protein diet produces sustained weight loss and long-term changes in body composition and blood lipids in obese adults. J Nutr. 2009;139:514-21. | Comparative effectiveness
Leermakers EA, Perri MG, Shigaki CL, Fuller PR. Effects of exercise-focused versus weight-focused maintenance programs on the management of obesity. Addict Behav. 1999;24:219-27. | Comparative effectiveness
Lehtovirta M, Forsen B, Gullstrom M, et al. Metabolic effects of metformin in patients with impaired glucose tolerance. Diabet Med. 2001;18:578-83. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Leibbrand R, Fichter MM. Maintenance of weight loss after obesity treatment: is continuous support necessary? Behav Res Ther. 2002;40:1275-89. | Focus on patients in subgroups other than specified conditions
Leinum CJ, Dopp JM, Morgan BJ. Sleep-disordered breathing and obesity: pathophysiology, complications, and treatment. Nutr Clin Pract. 2009;24:675-87. | Does not meet design requirements in inclusion criteria
Lejeune MP, Kovacs EM, Westerterp-Plantenga MS. Additional protein intake limits weight regain after weight loss in humans. Br J Nutr. 2005;93:281-9. | Less than 12 months followup
Liao D, Asberry PJ, Shofer JB, et al. Improvement of BMI, body composition, and body fat distribution with lifestyle modification in Japanese Americans with impaired glucose tolerance. Diabetes Care. 2002;25:1504-10. | Comparative effectiveness
Lien LF, Brown AJ, Ard JD, et al. Effects of PREMIER lifestyle modifications on participants with and without the metabolic syndrome. Hypertension. 2007;50:609-16. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Ligibel JA, Giobbie-Hurder A, Olenczuk D, et al. Impact of a mixed strength and endurance exercise intervention on levels of adiponectin, high molecular weight adiponectin and leptin in breast cancer survivors. Cancer Causes Control. 2009;20:1523-8. | Less than 12 months followup
Lindahl B, Nilsson TK, Jansson JH, et al. Improved fibrinolysis by intense lifestyle intervention: a randomized trial in subjects with impaired glucose tolerance. J Intern Med. 1999;246:105-12. | Not primary care feasible or referable
Linde JA, Jeffery RW, Finch EA, et al. Are unrealistic weight loss goals associated with outcomes for overweight women? Obes Res. 2004;12:569-76. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Lindegarde F. Orlistat with diet was effective and safe for weight loss and coronary risk reduction in obesity. Evid Based Med. 2001;6:54. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Lindholm A, Bixo M, Bjorn I, et al. Effect of sibutramine on weight reduction in women with polycystic ovary syndrome: a randomized, double-blind, placebo-controlled trial. Fertil Steril. 2008;89:1221-8. | Less than 12 months followup
Lindholm LH, Ekbom T, Dash C, et al. The impact of health care advice given in primary care on cardiovascular risk. BMJ. 1995;310:1105-9. | Comparative effectiveness
Lindstrom J, Eriksson JG, Valle TT, et al. Prevention of diabetes mellitus in subjects with impaired glucose tolerance in the Finnish Diabetes Prevention Study: results from a randomized clinical trial. J Am Soc Nephrol. 2003;14:S108-13. | No weight outcomes
Lindström J, Ilanne PP, Peltonen M, et al. Sustained reduction in the incidence of type 2 diabetes by lifestyle intervention: follow-up of the Finnish Diabetes Prevention Study. Lancet. 2006;368:1673-19. | No weight outcomes
Lindstrom J, Peltonen M, Eriksson JG, et al. High-fibre, low-fat diet predicts long-term weight loss and decreased type 2 diabetes risk: the Finnish Diabetes Prevention Study. Diabetologia. 2006;49:912-20. | No weight outcomes
Littman AJ, Vitiello MV, Foster-Schubert K, et al. Sleep, ghrelin, leptin and changes in body weight during a 1-year moderate-intensity physical activity intervention. Int J Obes. 2007;31:466-75. | No weight outcomes
Logue E, Sutton K, Jarjoura D, et al. Transtheoretical model-chronic disease care for obesity in primary care: a randomized trial. Obes Res. 2005;13:917-27. | Comparative effectiveness
Logue EE, Jarjoura DG, Sutton KS, et al. Longitudinal relationship between elapsed time in the action stages of change and weight loss. Obes Res. 2004;12:1499-508. | Does not meet design requirements in inclusion criteria
Lojander J, Mustajoki P, Ronka S, et al. A nurse-managed weight reduction programme for obstructive sleep apnoea syndrome. J Intern Med. 1998;244:251-5. | Does not meet design requirements in inclusion criteria
Lombard CB, Deeks AA, Ball K, et al. Weight, physical activity and dietary behavior change in young mothers: short term results of the HELP-HER cluster randomized controlled trial. Nutr J. 2009;8:17. | Less than 12 months followup
Bray G, Gregg E, et al; Look AHEAD Research Group. Baseline characteristics of the randomised cohort from the Look AHEAD (Action for Health in Diabetes) study. Diabetes Vasc Dis Res. 2006;3:202-15. | Comparative effectiveness
Wadden TA, West DS, et al; Look AHEAD Research Group. The Look AHEAD study: a description of the lifestyle intervention and the evidence supporting it. Obesity. 2006;14:737-52. | Comparative effectiveness
Lucas CP, Boldrin MN, Reaven GM. Effect of orlistat added to diet (30% of calories from fat) on plasma lipids, glucose, and insulin in obese patients with hypercholesterolemia. Am J Cardiol. 2003;91:961-4. | Comparative effectiveness
Lucas KH, Kaplan-Machlis B. Orlistat—a novel weight loss therapy. Ann Pharmacother. 2001;35:314-28. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Major GC, Alarie F, Dore J, et al. Supplementation with calcium + vitamin D enhances the beneficial effect of weight loss on plasma lipid and lipoprotein concentrations. Am J Clin Nutr. 2007;85:54-9. | Not one of the specified interventions
Malone DC, Raebel MA, Porter JA, et al. Cost-effectiveness of sibutramine in the LOSE Weight Study: evaluating the role of pharmacologic weight-loss therapy within a weight management program. J Manag Care Pharm. 2005;11:458-68. | Comparative effectiveness
Malone M, Alger-Mayer S. Binge status and quality of life after gastric bypass surgery: a one-year study. Obes Res. 2004;12:473-81. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Manini TM, Newman AB, Fielding R, et al. Effects of exercise on mobility in obese and nonobese older adults. Obesity (Silver Spring). 2010;18:1168-75. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Manning RM, Jung RT, Leese GP, Newton RW. The comparison of four weight reduction strategies aimed at overweight patients with diabetes mellitus: four-year follow-up. Diabet Med. 1998;15:497-502. | Comparative effectiveness
Marinilli PA, Gorin AA, Raynor HA, et al. Successful weight-loss maintenance in relation to method of weight loss. Obesity. 2008;16:2456-61. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Marshall NS, Grunstein RR. Losing weight in moderate to severe obstructive sleep apnoea. BMJ. 2009;339:b4363. | Conducted primarily in a non-relevant setting
Maruthur NM, Wang NY, Appel LJ. Lifestyle interventions reduce coronary heart disease risk: results from the PREMIER trial. Circulation. 2009;119:2026-31. | Not one of the specified interventions
Mata J, Silva MN, Vieira PN, et al. Motivational “spill-over” during weight control: increased self-determination and exercise intrinsic motivation predict eating self-regulation. Health Psychol. 2009;28:709-16. | No weight outcomes
Mathus-Vliegen EM; Balance Study Group. Long-term maintenance of weight loss with sibutramine in a GP setting following a specialist guided very-low-calorie diet: a double-blind, placebo-controlled, parallel group study. Eur J Clin Nutr. 2005;59(Suppl 1):S31-8. | Sibutramine intervention
Matvienko OA, Hoehns JD. A lifestyle intervention study in patients with diabetes or impaired glucose tolerance: translation of a research intervention into practice. J Am Board Fam Med. 2009;22:535-43. | Does not meet design requirements in inclusion criteria
McConnon A, Kirk SF, Cockroft JE, et al. The Internet for weight control in an obese sample: results of a randomised controlled trial. BMC Health Serv Res. 2007;7:206. | High or differential attrition
McConnon A, Kirk SF, Ransley JK. Process evaluation of an Internet-based resource for weight control: use and views of an obese sample. J Nutr Educ Behav. 2009;41:261-7. | No weight outcomes
McLaughlin T, Carter S, Lamendola C, et al. Clinical efficacy of two hypocaloric diets that vary in overweight patients with type 2 diabetes: comparison of moderate fat versus carbohydrate reductions. Diabetes Care. 2007;30:1877-9. | Comparative effectiveness
McMahon FG, Fujioka K, Singh BN, et al. Efficacy and safety of sibutramine in obese white and African American patients with hypertension: a 1-year, double-blind, placebo-controlled, multicenter trial. Arch Intern Med. 2000;160:2185-91. | Sibutramine intervention
McMahon FG, Weinstein SP, Rowe E, et al. Sibutramine is safe and effective for weight loss in obese patients whose hypertension is well controlled with angiotensin-converting enzyme inhibitors. J Hum Hypertens. 2002;16:5-11. | Sibutramine intervention
McManus K, Antinoro L, Sacks F. A randomized controlled trial of a moderate-fat, low-energy diet compared with a low fat, low-energy diet for weight loss in overweight adults. Int J Obes Relat Metab Disord. 2001;25:1503-11. | Comparative effectiveness
McNulty SJ, Ur E, Williams G. A randomized trial of sibutramine in the management of obese type 2 diabetic patients treated with metformin. Diabetes Care. 2003;26:125-31. | Sibutramine intervention
McTiernan A, Sorensen B, Irwin ML, et al. Exercise effect on weight and body fat in men and women. Obesity. 2007;15:1496-512. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Meenan RT, Vogt TM, Williams AE, et al. Economic evaluation of a worksite obesity prevention and intervention trial among hotel workers in Hawaii. J Occup Environ Med. 2010;52(Suppl 1):S8-13. | Conducted primarily in a non-relevant setting
Mengham LH, Morris BF, Palmer CR, White AJ. Is intensive dietetic intervention effective for overweight patients with diabetes mellitus? A randomised controlled trial in a general practice. Pract Diab Int. 1999;16:8. | Comparative effectiveness
Menon T, Quaddus S, Cohen L. Revision of failed vertical banded gastroplasty to non-resectional Scopinaro biliopancreatic diversion: early experience. Obes Surg. 2006;16:1420-4. | Comparative effectiveness
Messerli-Burgy N, Znoj H, Laederach K. Eating behavior, emotional regulation, and coping strategies in obese patients following a comprehensive weight reduction program. Verhaltenstherapie. 2007;17:56. | Does not meet design requirements in inclusion criteria
Messier SP, Loeser RF, Miller GD, et al. Exercise and dietary weight loss in overweight and obese older adults with knee osteoarthritis: the Arthritis, Diet, and Activity Promotion Trial. Arthritis Rheum. 2004;50:1501-10. | Comparative effectiveness
Micic D, Ivkovic-Lazar T, Dragojevic R, et al. Orlistat, a gastrointestinal lipase inhibitor, in therapy of obesity with concomitant hyperlipidemia. Med Pregl. 1999;52:323-33. | Less than 12 months followup
Molenaar EA, van Ameijden EJ, Vergouwe Y, et al. Effect of nutritional counselling and nutritional plus exercise counselling in overweight adults: a randomized trial in multidisciplinary primary care practice. Fam Pract. 2010;27:143-50. | High or differential attrition
Molitch ME, Fujimoto W, Hamman RF, et al. The Diabetes Prevention Program and its global implications. J Am Soc Nephrol. 2003;14(Suppl 2):S103-7. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Morgan PJ, Lubans DR, Collins CE, et al. 12-Month outcomes and process evaluation of the SHED-IT RCT: an Internet-based weight loss program targeting men. Obesity (Silver Spring). 2011;19:142-51. | Conducted primarily in a non-relevant setting
Muls E, Kolanowski J, Scheen A, Van Gaal L. The effects of orlistat on weight and on serum lipids in obese patients with hypercholesterolemia: a randomized, double-blind, placebo-controlled, multicentre study. Int J Obes Relat Metab Disord. 2001;25:1713-21. | Less than 12 months followup
Multiple Risk Factor Intervention Trial Research Group. Multiple Risk Factor Intervention Trial: risk factor changes and mortality results. JAMA. 1982;248:1465-77 | Not one of the specified interventions
Munsch S, Biedert E, Keller U. Evaluation of a lifestyle change programme for the treatment of obesity in general practice. Swiss Med Wkly. 2003;133:148-54. | High or differential attrition
Murawski ME. Problem solving and the management of obesity in women from underserved rural settings. Dissert Abstr Int B Sci Eng. 2008;69:690. | Comparative effectiveness
Nahmias J, Kirschner M, Karetzky MS. Weight loss and OSA and pulmonary function in obesity. N J Med. 1993;90:48-53. | Does not meet design requirements in inclusion criteria
Nakata Y, Ohkawara K, Lee DJ, et al. Effects of additional resistance training during diet-induced weight loss on bone mineral density in overweight premenopausal women. J Bone Miner Metab. 2008;26:172-7. | Less than 12 months followup
Nanchahal K, Townsend J, Letley L, et al. Weight-management interventions in primary care: a pilot randomised controlled trial. Br J Gen Pract. 2009;59:e157-66. | Less than 12 months followup
Nauta H, Hospers H, Jansen A. One-year follow-up effects of two obesity treatments on psychological well-being and weight. Br J Health Psychol. 2001;6:271-84. | Comparative effectiveness
Neaton JD, Grimm RH Jr, Cutler JA. Recruitment of participants for the Multiple Risk Factor Intervention Trial (MRFIT). Control Clin Trials. 1987;8:S41-53. | Not one of the specified interventions
Nelson MS, Robbins AS, Thornton JA. An intervention to reduce excess body weight in adults with or at risk for type 2 diabetes. Mil Med. 2006;171:409-14. | Less than 12 months followup
Nicklas BJ, Ambrosius W, Messier SP, et al. Diet-induced weight loss, exercise, and chronic inflammation in older, obese adults: a randomized controlled clinical trial. Am J Clin Nutr. 2004;79:544-51. | Comparative effectiveness
Nowson CA, Worsley A, Margerison C, et al. Blood pressure change with weight loss is affected by diet type in men. Am J Clin Nutr. 2005;81:983-9. | Comparative effectiveness
Ockene IS, Hebert JR, Ockene JK, et al. Effect of physician-delivered nutrition counseling training and an office-support program on saturated fat intake, weight, and serum lipid measurements in a hyperlipidemic population: Worcester Area Trial for Counseling in Hyperlipidemia (WATCH). Arch Intern Med. 1999;159:725-31. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Olson TP, Dengel DR, Leon AS, Schmitz KH. Changes in inflammatory biomarkers following one-year of moderate resistance training in overweight women. Int J Obes (Lond). 2007;31:996-1003. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Olson TP, Dengel DR, Leon AS, Schmitz KH. Moderate resistance training and vascular health in overweight women. Med Sci Sports Exerc. 2006;38:1558-64. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Osei-Assibey G, Kyrou I, Adi Y, et al. Dietary and lifestyle interventions for weight management in adults from minority ethnic/non-white groups: a systematic review. Obes Rev. 2010;11:769-76. | Does not meet design requirements in inclusion criteria
Ost LG, Gotestam KG. Behavioral and pharmacological treatments for obesity: an experimental comparison. Addict Behav. 1976;1:331-8. | Precedes search period
Ostbye T, Krause KM, Lovelady CA, et al. Active Mothers Postpartum: a randomized controlled weight-loss intervention trial. Am J Prev Med. 2009;37:173-80. | Less than 12 months followup
O'Toole ML, Sawicki MA, Artal R. Structured diet and physical activity prevent postpartum weight retention. J Womens Health (Larchmt). 2003;12:991-8. | Comparative effectiveness
Page RC, Harnden KE, Cook JT, Turner RC. Can life-styles of subjects with impaired glucose tolerance be changed? A feasibility study. Diabet Med. 1992;9:562-6. | Not one of the specified interventions
Pan XR, Li GW, Hu YH, et al. Effects of diet and exercise in preventing NIDDM in people with impaired glucose tolerance: the Da Qing IGT and Diabetes Study. Diabetes Care. 1997;20:537-44. | Not on list of countries with HDI > 0.90
Papalazarou A, Yannakoulia M, Kavouras SA, et al. Lifestyle intervention favorably affects weight loss and maintenance following obesity surgery. Obesity (Silver Spring). 2010;18:1348-53. | Comparative effectiveness
Park SK, Park JH, Kwon YC, et al. The effect of combined aerobic and resistance exercise training on abdominal fat in obese middle-aged women. J Physiol Anthropol Appl Human Sci. 2003;22:129-35. | Does not meet design requirements in inclusion criteria
Pasquali R, Colella P, Cirignotta F, et al. Treatment of obese patients with obstructive sleep apnea syndrome (OSAS): effect of weight loss and interference of otorhinolaryngoiatric pathology. Int J Obes. 1990;14:207-17. | Does not meet design requirements in inclusion criteria
Paul-Ebhohimhen V, Avenell A. A systematic review of the effectiveness of group versus individual treatments for adult obesity. Obesity Facts. 2009;2:17-24. | Does not meet design requirements in inclusion criteria
Perreault L, Kahn SE, Christophi CA, et al. Regression from pre-diabetes to normal glucose regulation in the Diabetes Prevention Program. Diabetes Care. 2009;32:1583-8. | No weight outcomes
Perreault L, Ma Y, Dagogo-Jack S, et al. Sex differences in diabetes risk and the effect of intensive lifestyle modification in the Diabetes Prevention Program. Diabetes Care. 2008;31:1416-21. | No weight outcomes
Perri MG, Limacher MC, Durning PE, et al. Extended-care programs for weight management in rural communities: the Treatment of Obesity in Underserved Rural Settings (TOURS) randomized trial. Arch Intern Med. 2008;168:2347-54. | Comparative effectiveness
Perrio MJ, Wilton LV, Shakir SA. The safety profiles of orlistat and sibutramine: results of prescription-event monitoring studies in England. Obesity. 2007;15:2712-22. | Does not meet design requirements in inclusion criteria
Petrofsky J, Batt J, Berk L, et al. The effect of an aerobic dance and diet program on cardiovascular fitness, body composition, and weight loss in women. J Appl Res. 2008;8:179-88. | Less than 12 months followup
Phelan S, Wadden TA, Berkowitz RI, et al. Impact of weight loss on the metabolic syndrome. Int J Obes. 2007;31:1442-8. | Does not meet design requirements in inclusion criteria
Philippou E, Neary NM, Chaudhri O, et al. The effect of dietary glycemic index on weight maintenance in overweight subjects: a pilot study. Obesity. 2009;17:396-401. | Comparative effectiveness
Pinkston MM, Poston WS, Reeves RS, et al. Does metabolic syndrome mitigate weight loss in overweight Mexican American women treated for 1-year with orlistat and lifestyle modification? Eat Weight Disord. 2006;11:e35-41. | No placebo in medication trial
Pi-Sunyer X, Blackburn G, Brancati FL, et al. Reduction in weight and cardiovascular disease risk factors in individuals with type 2 diabetes: one-year results of the Look AHEAD trial. Diabetes Care. 2007;30:1374-83. | Comparative effectiveness
Porter JA, Raebel MA, Conner DA, et al. The Long-term Outcomes of Sibutramine Effectiveness on Weight (LOSE Weight) study: evaluating the role of drug therapy within a weight management program in a group-model health maintenance organization. Am J Manag Care. 2004;10:369-76. | No placebo in medication trial
Poston WS, Haddock CK, Olvera NE, et al. Evaluation of a culturally appropriate intervention to increase physical activity. Am J Health Behav. 2001;25:396-406. | Not one of the specified interventions
Poston WS, Haddock CK, Pinkston MM, et al. Evaluation of a primary care-oriented brief counselling intervention for obesity with and without orlistat. J Intern Med. 2006;260:388-98. | Does not meet design requirements in inclusion criteria
Poston WS, Reeves RS, Haddock CK, et al. Weight loss in obese Mexican Americans treated for 1-year with orlistat and lifestyle modification. Int J Obes Relat Metab Disord. 2003;27:1486-93. | No placebo in medication trial
Potteiger JA, Jacobsen DJ, Donnelly JE, Hill JO. Glucose and insulin responses following 16 months of exercise training in overweight adults: the Midwest Exercise Trial. Metab. 2003;52:1175-81. | High or differential attrition
Potteiger JA, Kirk EP, Jacobsen DJ, Donnelly JE. Changes in resting metabolic rate and substrate oxidation after 16 months of exercise training in overweight adults. Int J Sport Nutr Exerc Metab. 2008;18:79-95. | High or differential attrition
Pritchard JE, Nowson CA, Wark JD. A worksite program for overweight middle-aged men achieves lesser weight loss with exercise than with dietary change. J Am Diet Assoc. 1997;97:37-42. | Conducted primarily in a non-relevant setting
Promrat K, Kleiner DE, Niemeier HM, et al. Randomized controlled trial testing the effects of weight loss on nonalcoholic steatohepatitis. Hepatology. 2010;51:121-9. | Focus on patients in subgroups other than specified conditions
Proper KI, Hildebrandt VH, Van der Beek AJ, et al. Effect of individual counseling on physical activity fitness and health: a randomized controlled trial in a workplace setting. Am J Prev Med. 2003;24:218-26. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Provencher V, Begin C, Tremblay A, et al. Health-at-every-size and eating behaviors: 1-year follow-up results of a size acceptance intervention. J Am Diet Assoc. 2009;109:1854-61. | Not one of the specified interventions
Racette SB, Deusinger SS, Inman CL, et al. Worksite Opportunities for Wellness (WOW): effects on cardiovascular disease risk factors after 1 year. Prev Med. 2009;49:108-14. | Conducted primarily in a non-relevant setting
Racette SB, Weiss EP, Obert KA, et al. Modest lifestyle intervention and glucose tolerance in obese African Americans. Obes Res. 2001;9:348-55. | Comparative effectiveness
Racette SB, Weiss EP, Villareal DT, et al. One year of caloric restriction in humans: feasibility and effects on body composition and abdominal adipose tissue. J Gerontol A Biol Sci Med Sci. 2006;61:943-50. | Comparative effectiveness
Ramachandran A, Snehalatha C, Mary S, et al. The Indian Diabetes Prevention Programme shows that lifestyle modification and metformin prevent type 2 diabetes in Asian Indian subjects with impaired glucose tolerance (IDPP-1). Diabetologia. 2006;49:289-97. | Not on list of countries with HDI > 0.90
Ramirez EM, Rosen JC. A comparison of weight control and weight control plus body image therapy for obese men and women. J Consult Clin Psychol. 2001;69:440-6. | Comparative effectiveness
Randomised trial of jejunoileal bypass versus medical treatment in morbid obesity. Lancet. 1979;2:1255-8. | Not one of the specified interventions
Rapoport L, Clark M, Wardle J. Evaluation of a modified cognitive-behavioural programme for weight management. Int J Obes Relat Metab Disord. 2000;24:1726-37. | Comparative effectiveness
Ratner RE; Diabetes Prevention Program. An update on the Diabetes Prevention Program. Endocr Pract. 2006; 12(Suppl 1):20-4. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Razquin C, Martinez JA, Martinez-Gonzalez MA, et al. A 3 years follow-up of a Mediterranean diet rich in virgin olive oil is associated with high plasma antioxidant capacity and reduced body weight gain. Eur J Clin Nutr. 2009;63:1387-93. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Reaven G, Segal K, Hauptman J, et al. Effect of orlistat-assisted weight loss in decreasing coronary heart disease risk in patients with syndrome X. Am J Cardiol. 2001;87:827-31. | Other quality issues
Redmon JB, Bertoni AG, Connelly S, et al. Effect of the Look AHEAD study intervention on medication use and related cost to treat cardiovascular disease risk factors in individuals with type 2 diabetes. Diabetes Care. 2010;33:1153-8. | Comparative effectiveness
Redmon JB, Raatz SK, Reck KP, et al. One-year outcome of a combination of weight loss therapies for subjects with type 2 diabetes: a randomized trial. Diabetes Care. 2003;26:2505-11. | Not one of the specified interventions
Redmon JB, Reck KP, Raatz SK, et al. Two-year outcome of a combination of weight loss therapies for type 2 diabetes. Diabetes Care. 2005;28:1311-5. | Comparative effectiveness
Reid IR, Horne A, Mason B, et al. Effects of calcium supplementation on body weight and blood pressure in normal older women: a randomized controlled trial. J Clin Endocrinol Metab. 2005;90:3824-9. | Not one of the specified interventions
Rejeski WJ, Focht BC, Messier SP, et al. Obese, older adults with knee osteoarthritis: weight loss, exercise, and quality of life. Health Psychol. 2002;21:419-26. | Comparative effectiveness
Renzaho AM, Mellor D, Boulton K, Swinburn B. Effectiveness of prevention programmes for obesity and chronic diseases among immigrants to developed countries—a systematic review. Public Health Nutr. 2010;13:438-50. | Does not meet design requirements in inclusion criteria
Ricci TA, Chowdhury HA, Heymsfield SB, et al. Calcium supplementation suppresses bone turnover during weight reduction in postmenopausal women. J Bone Miner Res. 1998;13:1045-50. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Rimmer JH, Rauworth A, Wang E, et al. A randomized controlled trial to increase physical activity and reduce obesity in a predominantly African American group of women with mobility disabilities and severe obesity. Prev Med. 2009;48:473-9. | Less than 12 months followup
Rissanen P, Vahtera E, Krusius T, et al. Weight change and blood coagulability and fibrinolysis in healthy obese women. Int J Obes Relat Metab Disord. 2001;25:212-8. | No weight outcomes
Rock CL, Flatt SW, Sherwood NE, et al. Effect of a free prepared meal and incentivized weight loss program on weight loss and weight loss maintenance in obese and overweight women: a randomized controlled trial. JAMA. 2010;304:1803-10. | Comparative effectiveness
Rock CL, Pakiz B, Flatt SW, Quintana EL. Randomized trial of a multifaceted commercial weight loss program. Obesity. 2007;15:939-49. | Comparative effectiveness
Rosenfalck AM, Hendel H, Rasmussen MH, et al. Minor long-term changes in weight have beneficial effects on insulin sensitivity and beta-cell function in obese subjects. Diabetes Obes Metab. 2002;4:19-28. | No weight outcomes
Ross R, Blair SN, Godwin M, et al. Prevention and Reduction of Obesity through Active Living (PROACTIVE): rationale, design and methods. Br J Sports Med. 2009;43:57-63. | No weight outcomes
Ross R, Janssen I, Dawson J, et al. Exercise-induced reduction in obesity and insulin resistance in women: a randomized controlled trial. Obes Res. 2004;12:789-98. | Comparative effectiveness
Rothacker DQ, Staniszewski BA, Ellis PK. Liquid meal replacement vs traditional food: a potential model for women who cannot maintain eating habit change. J Am Diet Assoc. 2001;101:345-7. | Comparative effectiveness
Rothert K, Strecher VJ, Doyle LA, et al. Web-based weight management programs in an integrated health care setting: a randomized, controlled trial. Obesity. 2006;14:266-72. | Less than 12 months followup
Ryan DH, Johnson WD, Myers VH, et al. Nonsurgical weight loss for extreme obesity in primary care settings: results of the Louisiana Obese Subjects Study. Arch Intern Med. 2010;170:146-54. | No placebo in medication trial
Sabbioni ME, Dickson MH, Eychmuller S, et al. Intermediate results of health related quality of life after vertical banded gastroplasty. Int J Obes Relat Metab Disord. 2002;26:277-80. | Not one of the specified interventions
Saccone A, Israel A. Effects of experimenter versus significant other-controlled reinforcement and choice of target behavior on weight loss. Behav Ther. 1978;9:271-8. | Precedes search period
Salas SJ, Fernández BJ, Ros E, et al. Effect of a Mediterranean diet supplemented with nuts on metabolic syndrome status: one-year results of the PREDIMED randomized trial. Arch Intern Med. 2008;168:2449-58. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Samaras K, Ashwell S, Mackintosh AM, et al. Will older sedentary people with non-insulin-dependent diabetes mellitus start exercising? A health promotion model. Diabetes Res Clin Pract. 1997;37:121-8. | Not one of the specified interventions
Sampol G, Munoz X, Sagales MT, et al. Long-term efficacy of dietary weight loss in sleep apnoea/hypopnoea syndrome. Eur Respir J. 1998;12:1156-9. | Does not meet design requirements in inclusion criteria
Samsa GP, Kolotkin RL, Williams GR, et al. Effect of moderate weight loss on health-related quality of life: an analysis of combined data from 4 randomized trials of sibutramine vs placebo. Am J Manag Care. 2001;7:875-83. | Does not meet design requirements in inclusion criteria
Sanchez-Reyes L, Fanghanel G, Yamamoto J, et al. Use of sibutramine in overweight adult Hispanic patients with type 2 diabetes mellitus: a 12-month, randomized, double-blind, placebo-controlled clinical trial. Clin Ther. 2004;26:1427-35. | Not on list of countries with HDI > 0.90
Sarac S, Sarac F. Cardiac valve evaluation and adipokine levels in obese women treated with sibutramine. Anadolu Kardiyoloji Dergisi. 2010;10:226-32. | Does not meet design requirements in inclusion criteria
Sarwer DB, von Sydow GA, Vetter ML, Wadden TA. Behavior therapy for obesity: where are we now? Curr Opin Endocr Diabetes Obes. 2009;16:347-52. | Does not meet design requirements in inclusion criteria
Sbrocco T, Nedegaard RC, Stone JM, Lewis EL. Behavioral choice treatment promotes continuing weight loss: preliminary results of a cognitive-behavioral decision-based treatment for obesity. J Consult Clin Psychol. 1999;67:260-6. | Comparative effectiveness
Schmitz KH, Hannan PJ, Stovitz SD, et al. Strength training and adiposity in premenopausal women: Strong, Healthy, and Empowered study. Am J Clin Nutr. 2007;86:566-72. | No weight outcomes
Schuler G, Hambrecht R, Schlierf G, et al. Regular physical exercise and low-fat diet: effects on progression of coronary artery disease. Circulation. 1992;86:1-11. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Schuster RJ, Tasosa J, Terwoord NA. Translational research—implementation of NHLBI Obesity Guidelines in a primary care community setting: the Physician Obesity Awareness Project. J Nutr Health Aging. 2008;12:S764-9. | Comparative effectiveness
Serrano-Rios M, Melchionda N, Moreno-Carretero E. Role of sibutramine in the treatment of obese type 2 diabetic patients receiving sulphonylurea therapy. Diabetes Med. 2002;19:119-24. | Sibutramine intervention
Shapses SA, Heshka S, Heymsfield SB. Effect of calcium supplementation on weight and fat loss in women. J Clin Endocrinol Metab. 2004;89:632-7. | Not one of the specified interventions
Shea MK, Houston DK, Nicklas BJ, et al. The effect of randomization to weight loss on total mortality in older overweight and obese adults: the ADAPT study. J Gerontol A Biol Sci Med Sci. 2010;65:519-25. | Comparative effectiveness
Sherwood NE, Jeffery RW, Pronk NP, et al. Mail and phone interventions for weight loss in a managed-care setting: Weigh-To-Be 2-year outcomes. Int J Obes. 2006;30:1565-73. | High or differential attrition
Short KR, Vittone JL, Bigelow ML, et al. Impact of aerobic exercise training on age-related changes in insulin sensitivity and muscle oxidative capacity. Diabetes. 2003;52:1888-96. | Less than 12 months followup
Siegel JM, Prelip ML, Erausquin JT, Kim SA. A worksite obesity intervention: results from a group-randomized trial. Am J Public Health. 2010;100:327-33. | Conducted primarily in a non-relevant setting
Silva MN, Markland D, Carraca EV, et al. Exercise autonomous motivation predicts three-year weight loss in women. Med Sci Sports Exerc. 2011;43:728-37. | Study of overweight/obesity prevention
Simmons D, Rush E, Crook N; Te Wai o Rona Diabetes Prevention Strategy Team. Development and piloting of a community health worker-based intervention for the prevention of diabetes among New Zealand Maori in Te Wai o Rona: Diabetes Prevention Strategy. Public Health Nutr. 2008;11:1318-25. | Focus on patients in subgroups other than specified conditions
Sircar AR, Kumar A, Lal M. Clinical evaluation of sibutramine in obese type 2 diabetic patients refractory to dietary management. J Assoc Physicians India. 2001;49:885-8. | Less than 12 months followup
Sjostrom L. Analysis of the XENDOS study (Xenical in the Prevention of Diabetes in Obese Subjects). Endocr Pract. 2006;12(Suppl 1):31-3. | No weight outcomes
Skender ML, Goodrick GK, Del Junco DJ, et al. Comparison of 2-year weight loss trends in behavioral treatments of obesity: diet, exercise, and combination interventions. J Am Diet Assoc. 1996;96:342-6. | Comparative effectiveness
Skinner TC, Carey ME, Cradock S, et al. Diabetes Education and Self-Management for Ongoing and Newly Diagnosed (DESMOND): process modelling of pilot study. Patient Educ Couns. 2006;64:369-77. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Slentz CA, Duscha BD, Johnson JL, et al. Effects of the amount of exercise on body weight, body composition, and measures of central obesity: STRRIDE—a randomized controlled study. Arch Intern Med. 2004;164:31-9. | Less than 12 months followup
Smith IG, Goulder MA. Randomized placebo-controlled trial of long-term treatment with sibutramine in mild to moderate obesity. J Fam Pract. 2001;50:505-12. | Sibutramine intervention
Smith PL, Gold AR, Meyers DA, et al. Weight loss in mildly to moderately obese patients with obstructive sleep apnea. Ann Intern Med. 1985;103:850-5. | Less than 12 months followup
Southard BH, Southard DR, Nuckolls J. Clinical trial of an Internet-based case management system for secondary prevention of heart disease. J Cardiopulm Rehabil. 2003;23:341-8. | Less than 12 months followup
Sramek JJ, Leibowitz MT, Weinstein SP, et al. Efficacy and safety of sibutramine for weight loss in obese patients with hypertension well controlled by beta-adrenergic blocking agents: a placebo-controlled, double-blind, randomised trial. J Hum Hypertens. 2002;16:13-9. | Less than 12 months followup
Stahre L, Hallstrom T. A short-term cognitive group treatment program gives substantial weight reduction up to 18 months from the end of treatment: a randomized controlled trial. Eat Weight Disord. 2005;10:51-8. | High or differential attrition
Stefanick ML, Mackey S, Sheehan M, et al. Effects of diet and exercise in men and postmenopausal women with low levels of HDL cholesterol and high levels of LDL cholesterol. N Engl J Med. 1998;339:12-20. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Stenius-Aarniala B, Poussa T, Kvarnstrom J, et al. Immediate and long term effects of weight reduction in obese people with asthma: randomised controlled study. BMJ. 2000;320:827-32. | Comparative effectiveness
Stensel DJ, Brooke-Wavell K, Hardman AE, et al. The influence of a 1-year programme of brisk walking on endurance fitness and body composition in previously sedentary men aged 42-59 years. Eur J Appl Physiol Occup Physiol. 1994;68:531-7. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Stern L, Iqbal N, Seshadri P, et al. The effects of low-carbohydrate versus conventional weight loss diets in severely obese adults: one-year follow-up of a randomized trial. Ann Intern Med. 2004;140:778-85. | Comparative effectiveness
Stuart RB. A three-dimensional program for the treatment of obesity. Behav Res Ther. 1971;9:177-86. | Precedes search period
Sun Q, Townsend MK, Okereke OI, et al. Adiposity and weight change in mid-life in relation to healthy survival after age 70 in women: prospective cohort study. BMJ. 2009;339:b3796. | Does not meet design requirements in inclusion criteria
Suratt PM, McTier RF, Findley LJ, et al. Effect of very-low-calorie diets with weight loss on obstructive sleep apnea. Am J Clin Nutr. 1992;56:S182-4. | Does not meet design requirements in inclusion criteria
Svendsen M, Helgeland M, Tonstad S. The long-term influence of orlistat on dietary intake in obese subjects with components of metabolic syndrome. J Hum Nutr Diet. 2009;22:55-63. | No weight outcomes
Svetkey LP, Pollak KI, Yancy WS Jr, et al. Hypertension Improvement Project: randomized trial of quality improvement for physicians and lifestyle modification for patients. Hypertension. 2009;54:1226-33. | Not one of the specified interventions
Swinburn BA, Metcalf PA, Ley SJ. Long-term (5-year) effects of a reduced-fat diet intervention in individuals with glucose intolerance. Diabetes Care. 2001;24:619-24. | Conducted primarily in a non-relevant setting
Swinburn BA, Woollard GA, Chang EC, Wilson MR. Effects of reduced-fat diets consumed ad libitum on intake of nutrients, particularly antioxidant vitamins. J Am Diet Assoc. 1999;99:1400-5. | Conducted primarily in a non-relevant setting
Tanco S, Linden W, Earle T. Well-being and morbid obesity in women: a controlled therapy evaluation. Int J Eat Disord. 1998;23:325-39. | Less than 12 months followup
Tanumihardjo SA, Valentine AR, Zhang Zet al. Strategies to increase vegetable or reduce energy and fat intake induce weight loss in adults. Exp Biol Med. 2009;234:542-52. | Comparative effectiveness
Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med. 2006;166:1620-5. | Less than 12 months followup
Tate DF, Jackvony EH, Wing RR. Effects of Internet behavioral counseling on weight loss in adults at risk for type 2 diabetes: a randomized trial. JAMA. 2003;289:1833-6. | Comparative effectiveness
Tate DF, Jeffery RW, Sherwood NE, Wing RR. Long-term weight losses associated with prescription of higher physical activity goals: are higher levels of physical activity protective against weight regain? Am J Clin Nutr. 2007;85:954-9. | Comparative effectiveness
Tate DF, Wing RR, Winett RA. Using Internet technology to deliver a behavioral weight loss program. JAMA. 2001;285:1172-7. | Less than 12 months followup
Teixeira PJ, Going SB, Houtkooper LB, et al. Resistance training in postmenopausal women with and without hormone therapy. Med Sci Sports Exerc. 2003;35:555-62. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
ODES Investigators. The Oslo Diet and Exercise Study (ODES): design and objectives. Control Clin Trials. 1993;14:229-43. | No weight outcomes
Thomas TR, Warner SO, Dellsperger KC, et al. Exercise and the metabolic syndrome with weight regain. J Appl Physiol. 2010;109:3-10. | Comparative effectiveness
Thompson WG, Rostad HN, Janzow DJ, et al. Effect of energy-reduced diets high in dairy products and fiber on weight loss in obese adults. Obes Res. 2005;13:1344-53. | Comparative effectiveness
Tiikkainen M, Bergholm R, Rissanen A, et al. Effects of equal weight loss with orlistat and placebo on body fat and serum fatty acid composition and insulin resistance in obese women. Am J Clin Nutr. 2004;79:22-30. | Less than 12 months followup
Tinker LF, Bonds DE, Margolis KL, et al. Low-fat dietary pattern and risk of treated diabetes mellitus in postmenopausal women: the Women's Health Initiative randomized controlled dietary modification trial. Arch Intern Med. 2008;168:1500-11. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Toft U, Kristoffersen L, Ladelund S, et al. The effect of adding group-based counselling to individual lifestyle counselling on changes in dietary intake: the Inter99 Study—a randomized controlled trial. Int J Behav Nutr Phys Act. 2008;5:59. | No weight outcomes
Toobert DJ, Glasgow RE, Radcliffe JL. Physiologic and related behavioral outcomes from the Women's Lifestyle Heart Trial. Ann Behav Med. 2000;22:1-9. | Focus on patients in subgroups other than specified conditions
Toplak H, Ziegler O, Keller U, et al. X-PERT: weight reduction with orlistat in obese subjects receiving a mildly or moderately reduced-energy diet—early response to treatment predicts weight maintenance. Diabetes Obes Metab. 2005;7:699-708. | Comparative effectiveness
What is TOPS (Take Off Pounds Sensibly). Milwaukee, WI: TOPS Club, Inc; 2011. http://www.tops.org/TOPSInformation/AboutTOPS.aspx | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Trento M, Passera P, Tomalino M, et al. Group visits improve metabolic control in type 2 diabetes: a 2-year follow-up. Diabetes Care. 2001;24:995-1000. | Comparative effectiveness
Trolle B, Flyvbjerg A, Kesmodel U, Lauszus FF. Efficacy of metformin in obese and non-obese women with polycystic ovary syndrome: a randomized, double-blinded, placebo-controlled cross-over trial. Hum Reprod. 2007;22:2967-73. | Less than 12 months followup
Tsai AG, Wadden TA, Rogers MA, et al. A primary care intervention for weight loss: results of a randomized controlled pilot study. Obesity (Silver Spring). 2010;18:1614-8. | Comparative effectiveness
Tsai AG, Wadden TA. Treatment of obesity in primary care practice in the United States: a systematic review. J Gen Intern Med. 2009;24:1073-9. | Does not meet design requirements in inclusion criteria
Tseng MC, Lee MB, Chen SY, et al. Response of Taiwanese obese binge eaters to a hospital-based weight reduction program. J Psychosom Res. 2004;57:279-85. | Focus on patients in subgroups other than specified conditions
Turnin MC, Bourgeois O, Cathelineau G, et al. Multicenter randomized evaluation of a nutritional education software in obese patients. Diabetes Metab. 2001;27:139-47. | Comparative effectiveness
Tuthill A, Quinn A, McColgan D, et al. A prospective randomized controlled trial of lifestyle intervention on quality of life and cardiovascular risk score in patients with obesity and type 2 diabetes. Diabetes Obes Metab. 2007;9:917-9. | Less than 12 months followup
Uusi-Rasi K, Rauhio A, Kannus P, et al. Three-month weight reduction does not compromise bone strength in obese premenopausal women. Bone. 2010;46:1286-93. | Does not meet design requirements in inclusion criteria
Van Aggel-Leijssen DP, Saris WH, Hul GB, van Baak MA. Long-term effects of low-intensity exercise training on fat metabolism in weight-reduced obese men. Metab. 2002;51:1003-10. | Comparative effectiveness
Van Aggel-Leijssen DP, Saris WH, Hul GB, van Baak MA. Short-term effects of weight loss with or without low-intensity exercise training on fat metabolism in obese men. Am J Clin Nutr. 2001;73:523-31. | Comparative effectiveness
Van Aggel-Leijssen DP, Saris WH, Wagenmakers AJ, et al. The effect of low-intensity exercise training on fat metabolism of obese women. Obes Res. 2001;9:86-96. | Comparative effectiveness
Van Aggel-Leijssen DP, Saris WH, Wagenmakers AJ, et al. Effect of exercise training at different intensities on fat metabolism of obese men. J Appl Physiol. 2002;92:1300-9. | Comparative effectiveness
Van Gaal LF, Broom JI, Enzi G, Toplak H. Efficacy and tolerability of orlistat in the treatment of obesity: a 6-month dose-ranging study. Eur J Clin Pharmacol. 1998;54:125-32. | Less than 12 months followup
van Sluijs EM, van Poppel MN, Twisk JW, et al. Effect of a tailored physical activity intervention delivered in general practice settings: results of a randomized controlled trial. Am J Public Health. 2005;95:1825-31. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
van Wier MF, Ariens GA, Dekkers JC, et al. ALIFE@Work: a randomised controlled trial of a distance counselling lifestyle programme for weight control among an overweight working population. BMC Public Health. 2006;6:140. | Less than 12 months followup
van Wier MF, Ariens GA, Dekkers JC, et al. Phone and e-mail counselling are effective for weight management in an overweight working population: a randomized controlled trial. BMC Public Health. 2009;9:6. | Less than 12 months followup
VanWormer JJ, Martinez AM, Benson GA, et al. Telephone counseling and home telemonitoring: the Weigh By Day Trial. Am J Health Behavior. 2009;33:445-54. | Comparative effectiveness
Velthuis MJ, Schuit AJ, Peeters PH, Monninkhof EM. Exercise program affects body composition but not weight in postmenopausal women. Menopause. 2009;16:777-84. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Venditti EM, Bray GA, Carrion-Petersen ML, et al. First versus repeat treatment with a lifestyle intervention program: attendance and weight loss outcomes. Int J Obes. 2008;32:1537-44. | No weight outcomes
Veverka DV, Anderson J, Auld GW, et al. Use of the stages of change model in improving nutrition and exercise habits in enlisted Air Force men. Mil Med. 2003;168:373-9. | Less than 12 months followup
Vidgren HM, Agren JJ, Valve RS, et al. The effect of orlistat on the fatty acid composition of serum lipid fractions in obese subjects. Clin Pharmacol Ther. 1999;66:315-22. | No weight outcomes
Villareal DT, Banks MR, Patterson BW, et al. Weight loss therapy improves pancreatic endocrine function in obese older adults. Obesity. 2008;16:1349-54. | No weight outcomes
Villareal DT, Fontana L, Weiss EP, et al. Bone mineral density response to caloric restriction-induced weight loss or exercise-induced weight loss: a randomized controlled trial. Arch Intern Med. 2006;166:2502-10. | Comparative effectiveness
Vissers D, Verrijken A, Mertens I, et al. Effect of long-term whole body vibration training on visceral adipose tissue: a preliminary report. Obesity Facts. 2010;3:93-100. | Other quality issues
Volpe SL, Kobusingye H, Bailur S, Stanek E. Effect of diet and exercise on body composition, energy intake and leptin levels in overweight women and men. J Am Coll Nutr. 2008;27:195-208. | Comparative effectiveness
von Huth SL, Ladelund S, Borch-Johnsen K, Jorgensen T. A randomized multifactorial intervention study for prevention of ischaemic heart disease (Inter99): the long-term effect on physical activity. Scand J Public Health. 2008;36:380-8. | No weight outcomes
Wadden TA, Berkowitz RI, Sarwer DB, et al. Benefits of lifestyle modification in the pharmacologic treatment of obesity: a randomized trial. Arch Intern Med. 2001;161:218-27. | Comparative effectiveness
Wadden TA, Berkowitz RI, Womble LG, et al. Randomized trial of lifestyle modification and pharmacotherapy for obesity. N Engl J Med. 2005;353:2111-20. | No placebo in medication trial
Wadden TA, West DS, Neiberg RH, et al. One-year weight losses in the Look AHEAD Study: factors associated with success. Obesity. 2009;17:713-22. | Comparative effectiveness
Wardle J, Rogers P, Judd P, et al. Randomized trial of the effects of cholesterol-lowering dietary treatment on psychological function. Am J Med. 2000;108:547-53. | Less than 12 months followup
Waring ME, Roberts MB, Parker DR, Eaton CB. Documentation and management of overweight and obesity in primary care. J Am Board Fam Med. 2009;22:544-52. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Warren M, Schmitz KH. Safety of strength training in premenopausal women: musculoskeletal injuries from a two-year randomized trial. Am J Health Promot. 2009;23:309-14. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Warziski MT, Sereika SM, Styn MA, et al. Changes in self-efficacy and dietary adherence: the impact on weight loss in the PREFER study. J Behav Med. 2008;31:81-92. | Comparative effectiveness
Wassertheil-Smoller S, Oberman A, Blaufox MD, et al. The Trial of Antihypertensive Interventions and Management (TAIM) study: final results with regard to blood pressure, cardiovascular risk, and quality of life. Am J Hypertens. 1992;5:37-44. | No weight outcomes
Wee CC, Davis RB, Phillips RS. Stage of readiness to control weight and adopt weight control behaviors in primary care. J Gen Intern Med. 2005;20:410-5. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Weiner R, Bockhorn H, Rosenthal R, Wagner D. A prospective randomized trial of different laparoscopic gastric banding techniques for morbid obesity. Surg Endosc. 2001;15:63-8. | Not one of the specified interventions
Weiss EP, Racette SB, Villareal DT, et al. Improvements in glucose tolerance and insulin action induced by increasing energy expenditure or decreasing energy intake: a randomized controlled trial. Am J Clin Nutr. 2006;84:1033-42. | Comparative effectiveness
West DS, DiLillo V, Bursac Z, et al. Motivational interviewing improves weight loss in women with type 2 diabetes. Diabetes Care. 2007;30:1081-7. | Comparative effectiveness
Whittemore R, Melkus G, Wagner J, et al. Translating the Diabetes Prevention Program to primary care: a pilot study. Nurs Res. 2009;58:2-12. | Less than 12 months followup
Williamson DA, Martin CK, Anton SD, et al. Is caloric restriction associated with development of eating-disorder symptoms? Results from the CALERIE trial. Health Psychol. 2008;27(Suppl 1):S32-42. | Comparative effectiveness
Williamson DA, Rejeski J, Lang W, et al. Impact of a weight management program on health-related quality of life in overweight adults with type 2 diabetes. Arch Intern Med. 2009;169:163-71. | Comparative effectiveness
Williamson DF. Re: randomized trial of weight loss and total mortality. J Gerontol A Biol Sci Med Sci. 2010;65:904. | Does not meet design requirements in inclusion criteria
Wing RR, Anglin K. Effectiveness of a behavioral weight control program for blacks and whites with NIDDM. Diabetes Care. 1996;19:409-13. | Comparative effectiveness
Wing RR, Creasman JM, West DS, et al. Improving urinary incontinence in overweight and obese women through modest weight loss. Obstetrics Gynecol. 2010;116:284-92. | Comparative effectiveness
Wing RR, Epstein LH, Paternostro-Bayles M, et al. Exercise in a behavioural weight control programme for obese patients with type 2 (non-insulin-dependent) diabetes. Diabetologia. 1988;31:902-9. | Comparative effectiveness
Wing RR, Tate DF, Gorin AA, et al. STOP regain: are there negative effects of daily weighing? J Consult Clin Psychol. 2007;75:652-6. | No weight outcomes
Wing RR, Tate DF, Gorin AA, et al. A self-regulation program for maintenance of weight loss. New Engl J Med. 2006;355:1563-71. | Comparative effectiveness
Wing RR, Venditti E, Jakicic JM, et al. Lifestyle intervention in overweight individuals with a family history of diabetes. Diabetes Care. 1998;21:350-9. | Comparative effectiveness
Wing RR, West DS, Grady D, et al. Effect of weight loss on urinary incontinence in overweight and obese women: results at 12 and 18 months. J Urol. 2010;184:1005-10. | Comparative effectiveness
Wing RR. Behavioral approaches to the treatment of obesity. In: Bray G, Bouchard C, James WP, eds. Handbook of Obesity. New York: Marcel Dekker; 1998:855-73. | Does not meet design requirements in inclusion criteria
Wing RR. Behavioral weight control. In: Wadden TA, Stunkard AJ, eds. Handbook of Obesity Treatment. New York: Guilford Press; 2002:301-16. | Does not meet design requirements in inclusion criteria
Wirth A, Krause J. Long-term weight loss with sibutramine: a randomized controlled trial. JAMA. 2001;286:1331-9. | Sibutramine intervention
Wister A, Loewen N, Kennedy-Symonds H, et al. One-year follow-up of a therapeutic lifestyle intervention targeting cardiovascular disease risk. Can Med Assoc J. 2007;177:859-65. | Not one of the specified interventions
Wolf AM, Conaway MR, Crowther JQ, et al. Translating lifestyle intervention to practice in obese patients with type 2 diabetes: Improving Control with Activity and Nutrition (ICAN) study. Diabetes Care. 2004;27:1570-6. | Comparative effectiveness
Wolf AM, Siadaty MS, Crowther JQ, et al. Impact of lifestyle intervention on lost productivity and disability: improving control with activity and nutrition. J Occup Environ Med. 2009;51:139-45. | Comparative effectiveness
Womble LG, Wadden TA, McGuckin BG. A randomized controlled trial of a commercial Internet weight loss program. Obes Res. 2004;12:1011-8. | Comparative effectiveness
Wong SY, Lau EM, Lau WW, Lynn HS. Is dietary counselling effective in increasing dietary calcium, protein and energy intake in patients with osteoporotic fractures? A randomized controlled clinical trial. J Hum Nutr Diet. 2004;17:359-64. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Woo J, Sea MM, Tong P, et al. Effectiveness of a lifestyle modification programme in weight maintenance in obese subjects after cessation of treatment with orlistat. J Eval Clin Pract. 2007;13:853-9. | Less than 12 months followup
Wosje KS, Kalkwarf HJ. Lactation, weaning, and calcium supplementation: effects on body composition in postpartum women. Am J Clin Nutr. 2004;80:423-9. | Not one of the specified interventions
Wright AD, Cull CA, MacLeod KM, et al. Hypoglycemia in type 2 diabetic patients randomized to and maintained on monotherapy with diet, sulfonylurea, metformin, or insulin for 6 years from diagnosis: UKPDS73. J Diabetes Complications. 2006;20:395-401. | Comparative effectiveness
Wylie-Rosett J, Swencionis C, Ginsberg M, et al. Computerized weight loss intervention optimizes staff time: the clinical and cost results of a controlled clinical trial conducted in a managed care setting. J Am Diet Assoc. 2001;101:1155-62. | Comparative effectiveness
Yancey AK, McCarthy WJ, Harrison GG, et al. Challenges in improving fitness: results of a community-based, randomized, controlled lifestyle change intervention. J Womens Health. 2006;15:412-29. | Not one of the specified interventions
Yassine HN, Marchetti CM, Krishnan RK, et al. Effects of exercise and caloric restriction on insulin resistance and cardiometabolic risk factors in older obese adults—a randomized clinical trial. J Gerontol A Biol Sci Med Sci. 2009;64:90-5. | Comparative effectiveness
Yates T, Davies M, Gorely T, et al. Effectiveness of a pragmatic education program designed to promote walking activity in individuals with impaired glucose tolerance: a randomized controlled trial. Diabetes Care. 2009;32:1404-10. | Not one of the specified interventions
Yeh MC, Rodriguez E, Nawaz H, et al. Technical skills for weight loss: 2-y follow-up results of a randomized trial. Int J Obes Relat Metab Disord. 2003;27:1500-6. | Comparative effectiveness
Zannad F, Gille B, Grentzinger A, et al. Effects of sibutramine on ventricular dimensions and heart valves in obese patients during weight reduction. Am Heart J. 2002;144:508-15. | Sibutramine intervention
Zavoral JH. Treatment with orlistat reduces cardiovascular risk in obese patients. J Hypertens. 1998;16:2013-7. | Other quality issues
Zemel MB, Richards J, Mathis S, et al. Dairy augmentation of total and central fat loss in obese subjects. Int J Obes. 2005;29:391-7. | Not one of the specified interventions
Zemel MB, Richards J, Milstead A, Campbell P. Effects of calcium and dairy on body composition and weight loss in African-American adults. Obes Res. 2005;13:1218-25. | Less than 12 months followup
Zemel MB, Thompson W, Milstead Aet al. Calcium and dairy acceleration of weight and fat loss during energy restriction in obese adults. Obes Res. 2004;12:582-90. | Comparative effectiveness

Appendix D Table 4 Studies Excluded From Review for Key Question 4

Reference | Reason for Exclusion
Aadahl M, von Huth SL, Pisinger C, et al. Five-year change in physical activity is associated with changes in cardiovascular disease risk factors: the Inter99 study. Prev Med. 2009;48(4):326-31. | Does not meet design requirements in inclusion criteria
Agurs-Collins TD, Kumanyika SK, Ten Have TR, Adams-Campbell LL. A randomized controlled trial of weight reduction and exercise for diabetes management in older African-American subjects. Diabetes Care. 1997;20:1503-11. | No harms outcomes
Akinson RL. Conjugated linoleic acid for altering body composition and treating obesity. In: Yurawecz MP, Mossoba MM, Kramer JK, et al, eds. Advances in Conjugated Linoleic Acid Research. vol 1. Champaign, IL: AOCS Press; 1999:348-53. | Does not meet design requirements in inclusion criteria
Alhassan S, Kim S, Bersamin A, et al. Dietary adherence and weight loss success among overweight women: results from the A TO Z weight loss study. Int J Obes. 2008;32:985-91. | Comparative effectiveness
Allen P, Thompson JL, Herman CJ, et al. Impact of periodic follow-up testing among urban American Indian women with impaired fasting glucose. Prev Chron Dis. 2008;5:A76. | Not one of the specified interventions
Andersen RE, Wadden TA, Bartlett SJ, et al. Effects of lifestyle activity vs structured aerobic exercise in obese women: a randomized trial. JAMA. 1999;281:335-40. | Comparative effectiveness
Anderson JW, Grant L, Gotthelf L, Stifler LT. Weight loss and long-term follow-up of severely obese individuals treated with an intense behavioral program. Int J Obes. 2007;31:488-93. | No harms outcomes
Anderssen SA, Carroll S, Urdal P, Holme I. Combined diet and exercise intervention reverses the metabolic syndrome in middle-aged males: results from the Oslo Diet and Exercise Study. Scand J Med Sci Sports. 2007;17:687-95. | No harms outcomes
Anderssen SA, Holme I, Urdal P, Hjermann I. Associations between central obesity and indexes of hemostatic, carbohydrate and lipid metabolism: results of a 1-year intervention from the Oslo Diet and Exercise Study. Scand J Med Sci Sports. 1998;8:109-15. | No harms outcomes
Andersson K, Karlstrom B, Freden S, et al. A two-year clinical lifestyle intervention program for weight loss in obesity. Food Nutr Res. 2008;52. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Andrade AM, Coutinho SR, Silva MN, et al. The effect of physical activity on weight loss is mediated by eating self-regulation. Patient Educ Couns. 2010;79(3):320-6. | No harms outcomes
Annunziato RA, Timko CA, Crerand CE, et al. A randomized trial examining differential meal replacement adherence in a weight loss maintenance program after one-year follow-up. Eat Behav. 2009;10:176-83. | Comparative effectiveness
Apfelbaum M, Vague P, Ziegler O, et al. Long-term maintenance of weight loss after a very-low-calorie diet: a randomized blinded trial of the efficacy and tolerability of sibutramine. Am J Med. 1999;106:179-84. | Sibutramine intervention
Appel LJ, Champagne CM, Harsha DW, et al. Effects of comprehensive lifestyle modification on blood pressure control: main results of the PREMIER clinical trial. JAMA. 2003;289:2083-93. | Not one of the specified interventions
Appel LJ, Espeland MA, Easter L, et al. Effects of reduced sodium intake on hypertension control in older individuals: results from the Trial of Nonpharmacologic Interventions in the Elderly (TONE). Arch Intern Med. 2001;161:685-93. | No harms outcomes
Arterburn D, DeLaet D, Schauer D. Obesity in adults. Clin Evid (Online). 2008. | Does not meet design requirements in inclusion criteria
Ash S, Reeves M, Bauer J, et al. A randomised control trial comparing lifestyle groups, individual counselling and written information in the management of weight and health outcomes over 12 months. Int J Obes. 2006;30:1557-64. | Comparative effectiveness
Ashley JM, St Jeor ST, Schrage JP, et al. Weight control in the physician's office. Arch Intern Med. 2001;161:1599-604. | Comparative effectiveness
Ashutosh K, Methrotra K, Fragale-Jackson J. Effects of sustained weight loss and exercise on aerobic fitness in obese women. J Sports Med Phys Fitness. 1997;37:252-7. | Comparative effectiveness
Avenell A, Brown TJ, McGee MA, et al. What are the long-term benefits of weight reducing diets in adults? A systematic review of randomized controlled trials. J Hum Nutr Diet. 2004;17:317-35. | Does not meet design requirements in inclusion criteria
Babamoto KS, Sey KA, Camilleri AJ, et al. Improving diabetes care and health measures among Hispanics using community health workers: results from a randomized controlled trial. Health Educ Behav. 2009;36:113-26. | No harms outcomes
Bach DS, Rissanen AM, Mendel CM, et al. Absence of cardiac valve dysfunction in obese patients treated with sibutramine. Obes Res. 1999;7:363-9. | Sibutramine intervention
Bacon L, Keim NL, Van L, et al. Evaluating a “non-diet” wellness intervention for improvement of metabolic fitness, psychological well-being and eating and activity behaviors. Int J Obes Relat Metab Disord. 2002;26:854-65. | Comparative effectiveness
Balducci S, Zanuso S, Nicolucci A, et al. Anti-inflammatory effect of exercise training in subjects with type 2 diabetes and the metabolic syndrome is dependent on exercise modalities and independent of weight loss. Nutr Metab Cardiovasc Dis. 2010;20:608-17. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Barba M, Schunemann HJ, Sperati F, et al. The effects of metformin on endogenous androgens and SHBG in women: a systematic review and meta-analysis. Clin Endocrinol (Oxf). 2009;70:661-70. | No harms outcomes
Barr SI, McCarron DA, Heaney RP, et al. Effects of increased consumption of fluid milk on energy and nutrient intake, body weight, and cardiovascular risk factors in healthy older adults. J Am Diet Assoc. 2000;100:810-7. | Not one of the specified interventions
Bauer C, Fischer A, Keller U. Effect of sibutramine and of cognitive-behavioural weight loss therapy in obesity and subclinical binge eating disorder. Diabetes Obes Metab. 2006;8:289-95. | No harms outcomes
Beck-da-Silva L, Higginson L, Fraser M, et al. Effect of orlistat in obese patients with heart failure: a pilot study. Congest Heart Fail. 2005;11:118-23. | Focus on patients with obesity secondary to genetic or medical conditions, or medically induced weight gain
Bemelmans WJ, Broer J, de Vries JH, et al. Impact of Mediterranean diet education versus posted leaflet on dietary habits and serum cholesterol in a high risk population for cardiovascular disease. Public Health Nutr. 2000;3:273-83. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Bergstrom I, Lombardo C, Brinck J. Physical training decreases waist circumference in postmenopausal borderline overweight women. Acta Obstet Gynecol Scand. 2009;88:308-13. | Focus on patients in subgroups other than specified conditions
Berven G, Bye A, Hals O, et al. Safety of conjugated linoleic acid (CLA) in overweight or obese human volunteers. Eur J Lipid Sci Tech. 2009;102:455-62. | Not one of the specified interventions
Bhargava A, Guthrie JF. Unhealthy eating habits, physical exercise and macronutrient intakes are predictors of anthropometric indicators in the Women's Health Trial Feasibility Study in Minority Populations. Br J Nutr. 2002;88:719-28. | Not one of the specified interventions
Blankson H, Stakkestad JA, Fagertun H, et al. Conjugated linoleic acid reduces body fat mass in overweight and obese humans. J Nutr. 2000;130:2943-8. | Not one of the specified interventions
Blumenthal JA, Sherwood A, Gullette EC, et al. Exercise and weight loss reduce blood pressure in men and women with mild hypertension: effects on cardiovascular, metabolic, and hemodynamic functioning. Arch Intern Med. 2000;160:1947-58. | No harms outcomes
Bo S, Ciccone G, Baldi C, et al. Effectiveness of a lifestyle intervention on metabolic syndrome: a randomized controlled trial. J Gen Intern Med. 2007;22:1695-703. | Not one of the specified interventions
Bo S, Ciccone G, Guidi S, et al. Diet or exercise: what is more effective in preventing or reducing metabolic alterations? Eur J Endocrinol. 2008;159:685-91. | Not one of the specified interventions
Borg P, Kukkonen-Harjula K, Fogelholm M, Pasanen M. Effects of walking or resistance training on weight loss maintenance in obese, middle-aged men: a randomized trial. Int J Obes Relat Metab Disord. 2002;26:676-83. | Comparative effectiveness
Botomino A, Bruppacher R, Krahenbuhl S, Hersberger KE. Change of body weight and lifestyle of persons at risk for diabetes after screening and counselling in pharmacies. Pharm World Sci. 2008;30:222-6. | Does not meet design requirements in inclusion criteria
Bowen D, Clifford CK, Coates R, et al. The Women's Health Trial Feasibility Study in Minority Populations: design and baseline descriptions. Ann Epidemiol. 1996;6:507-19. | Not one of the specified interventions
Bowen J, Noakes M, Clifton PM. A high dairy protein, high-calcium diet minimizes bone turnover in overweight adults during weight loss. J Nutr. 2004;134:568-73. | No harms outcomes
Bowerman S, Bellman M, Saltsman P, et al. Implementation of a primary care physician network obesity management program. Obes Res. 2001;9(Suppl 4):S321-5. | No harms outcomes
Bravata DM, Smith-Spangler C, Sundaram V, et al. Using pedometers to increase physical activity and improve health: a systematic review. JAMA. 2007;298:2296-304. | Does not meet design requirements in inclusion criteria
Brinkworth GD, Noakes M, Keogh JB, et al. Long-term effects of a high-protein, low-carbohydrate diet on weight control and cardiovascular risk markers in obese hyperinsulinemic subjects. Int J Obes Relat Metab Disord. 2004;28:661-70. | Comparative effectiveness
Brinkworth GD, Noakes M, Parker B, et al. Long-term effects of advice to consume a high-protein, low-fat diet, rather than a conventional weight-loss diet, in obese adults with type 2 diabetes: one-year follow-up of a randomised trial. Diabetologia. 2004;47:1677-86. | Comparative effectiveness
Brownell KD. The LEARN Program for Weight Management. New Haven, CT: American Health Publishing Company; 2000. | Comparative effectiveness
Bryan J, Tiggemann M. The effect of weight-loss dieting on cognitive performance and psychological well-being in overweight women. Appetite. 2001;36:147-56. | No harms outcomes
Buchwald H, Avidor Y, Braunwald E, et al. Bariatric surgery: a systematic review and meta-analysis. JAMA. 2004;292:1724-37. | Does not meet design requirements in inclusion criteria
Burke V, Beilin LJ, Cutt HE, et al. A lifestyle program for treated hypertensives improved health-related behaviors and cardiovascular risk factors, a randomized controlled trial. J Clin Epidemiol. 2007;60:133-41. | No harms outcomes
Burke V, Mansour J, Beilin LJ, Mori TA. Long-term follow-up of participants in a health promotion program for treated hypertensives (ADAPT). Nutr Metab Cardiovasc Dis. 2008;18:198-206. | No harms outcomes
Burke V, Mori TA, Giangiulio N, et al. An innovative program for changing health behaviours. Asia Pac J Clin Nutr. 2002;11(Suppl 3):S586-97. | No harms outcomes
Caan B, Neuhouser M, Aragaki A, et al. Calcium plus vitamin D supplementation and the risk of postmenopausal weight gain. Arch Intern Med. 2007;167:893-902. | Not one of the specified interventions
Calle-Pascual AL, Rodriguez C, Camacho F, et al. Behaviour modification in obese subjects with type 2 diabetes mellitus. Diabetes Res Clin Pract. 1992;15:157-62. | Does not meet design requirements in inclusion criteria
Campbell PT, Campbell KL, Wener MH, et al. A yearlong exercise intervention decreases CRP among obese postmenopausal women. Med Sci Sports Exerc. 2009;41:1533-9. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Carr DB, Utzschneider KM, Boyko EJ, et al. A reduced-fat diet and aerobic exercise in Japanese Americans with impaired glucose tolerance decreases intra-abdominal fat and improves insulin sensitivity but not beta-cell function. Diabetes. 2005;54:340-7. | Comparative effectiveness
Carr LJ, Bartee RT, Dorozynski CM, et al. Eight-month follow-up of physical activity and central adiposity: results from an Internet-delivered randomized control trial intervention. J Phys Act Health. 2009;6:444-55. | Comparative effectiveness
Carter JD, Vasey FB, Valeriano J. The effect of a low-carbohydrate diet on bone turnover. Osteoporos Int. 2006;17:1398-403. | Does not include specified harms outcomes
Castaneda C, Layne JE, Munoz-Orians L, et al. A randomized controlled trial of resistance exercise training to improve glycemic control in older adults with type 2 diabetes. Diabetes Care. 2002;25:2335-41. | No harms outcomes
Chang MW, Nitzke S, Brown R. Design and outcomes of a Mothers In Motion behavioral intervention pilot study. J Nutr Educ Behav. 2010;42(Suppl 3):11-21. | No harms outcomes
Charles MA, Morange P, Eschwege E, et al. Effect of weight change and metformin on fibrinolysis and the von Willebrand factor in obese nondiabetic subjects: the BIGPRO1 study. Diabetes Care. 1998;21:1967-72. | No harms outcomes
Cheatham RA, Roberts SB, Das SK, et al. Long-term effects of provided low and high glycemic load low energy diets on mood and cognition. Physiol Behav. 2009;98:374-9. | Comparative effectiveness
Cheyette C. Weight No More: a randomised controlled trial for people with type 2 diabetes on insulin therapy. Pract Diabetes Int. 2007;24:450-6. | Does not include specified harms outcomes
Chiasson JL, Lau DC, Leiter LA, et al. Fluoxetine has potential in obese NIDDM—multicenter Canadian trial. Diabetes. 1989;38(Suppl 2):A154. | Not one of the specified interventions
Clark M, Hampson SE, Avery L, Simpson R. Effects of a tailored lifestyle self-management intervention in patients with type 2 diabetes. Br J Health Psychol. 2004;9:365-79. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Clarke KK, Freeland-Graves J, Klohe-Lehman DM, et al. Promotion of physical activity in low-income mothers using pedometers. J Am Diet Assoc. 2007;107:962-7. | No harms outcomes
Clifford PA, Tan SY, Gorsuch RL. Efficacy of a self-directed behavioral health change program: weight, body composition, cardiovascular fitness, blood pressure, health risk, and psychosocial mediating variables. J Behav Med. 1991;14:303-23. | Comparative effectiveness
Cocco G, Pandolfi S, Rousson V. Sufficient weight reduction decreases cardiovascular complications in diabetic patients with the metabolic syndrome: a randomized study of orlistat as an adjunct to lifestyle changes (diet and exercise). Heart Drug. 2005;5:68-74. | Does not include specified harms outcomes
Coker RH, Williams RH, Yeo SE, et al. The impact of exercise training compared to caloric restriction on hepatic and peripheral insulin resistance in obesity. J Clin Endocrinol Metab. 2009;94:4258-66. | No harms outcomes
Conradt M, Dierk JM, Schlumberger P, et al. A consultation with genetic information about obesity decreases self-blame about eating and leads to realistic weight loss goals in obese individuals. J Psychosom Res. 2009;66:287-95. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Corpeleijn E, Feskens EJ, Jansen EH, et al. Improvements in glucose tolerance and insulin sensitivity after lifestyle intervention are related to changes in serum fatty acid profile and desaturase activities: the SLIM study. Diabetologia. 2006;49:2392-401. | Not one of the specified interventions
Counterweight Project Team. Evaluation of the Counterweight Programme for obesity management in primary care: a starting point for continuous improvement. Br J Gen Pract. 2008;58:548-54. | Does not meet design requirements in inclusion criteria
Counterweight Project Team. Influence of body mass index on prescribing costs and potential cost savings of a weight management programme in primary care. J Health Serv Res Policy. 2008;13:158-66. | Does not meet design requirements in inclusion criteria
Cousins JH, Rubovits DS, Dunn JK, et al. Family versus individually oriented intervention for weight loss in Mexican American women. Public Health Rep. 1992;107:549-55. | Comparative effectiveness
Cox KL, Burke V, Morton AR, et al. Independent and additive effects of energy restriction and exercise on glucose and insulin concentrations in sedentary overweight men. Am J Clin Nutr. 2004;80:308-16. | No harms outcomes
Cuellar GE, Ruiz AM, Monsalve MC, Berber A. Six-month treatment of obesity with sibutramine 15 mg; a double-blind, placebo-controlled monocenter clinical trial in a Hispanic population. Obes Res. 2000;8:71-82. | Not on list of countries with HDI > 0.90
Dale KS, Mann JI, McAuley KA, et al. Sustainability of lifestyle changes following an intensive lifestyle intervention in insulin resistant adults: follow-up at 2-years. Asia Pac J Clin Nutr. 2009;18:114-20. | Comparative effectiveness
Dale KS, McAuley KA, Taylor RW, et al. Determining optimal approaches for weight maintenance: a randomized controlled trial. Can Med Assoc J. 2009;180:E39-46. | Comparative effectiveness
Davies MJ, Heller S, Skinner TC, et al. Effectiveness of the Diabetes Education and Self Management for Ongoing and Newly Diagnosed (DESMOND) Programme for people with newly diagnosed type 2 diabetes: cluster randomised controlled trial. BMJ. 2008;336:491-5. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Davis BR, Blaufox MD, Oberman A, et al. Reduction in long-term antihypertensive medication requirements: effects of weight reduction by dietary intervention in overweight persons with mild hypertension. Arch Intern Med. 1993;153:1773-82. | No harms outcomes
de Jager J, Kooy A, Lehert P, et al. Long term treatment with metformin in patients with type 2 diabetes and risk of vitamin B-12 deficiency: randomised placebo controlled trial. BMJ. 2010;340:c2181. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
de Wit LT, Mathus-Vliegen L, Hey C, et al. Open versus laparoscopic adjustable silicone gastric banding: a prospective randomized trial for treatment of morbid obesity. Ann Surg. 1999;230:800-5. | Not one of the specified interventions
Delahanty LM, Nathan DM. Implications of the Diabetes Prevention Program and Look AHEAD clinical trials for lifestyle interventions. J Am Diet Assoc. 2008;108(Suppl 1):66-72. | Comparative effectiveness
Delecluse C, Colman V, Roelants M, et al. Exercise programs for older men: mode and intensity to induce the highest possible health-related benefits. Prev Med. 2004;39:823-33. | Does not include specified harms outcomes
Dennis KE, Tomoyasu N, McCrone SH, et al. Self-efficacy targeted treatments for weight loss in postmenopausal women. Sch Inq Nurs Pract. 2001;15:259-76. | Comparative effectiveness
Derosa G, Cicero AF, Murdolo G, et al. Efficacy and safety comparative evaluation of orlistat and sibutramine treatment in hypertensive obese patients. Diabetes Obes Metab. 2005;7:47-55. | Comparative effectiveness
Devine A, Prince RL, Bell R. Nutritional effect of calcium supplementation by skim milk powder or calcium tablets on total nutrient intake in postmenopausal women. Am J Clin Nutr. 1996;64:731-7. | Comparative effectiveness
Di Francesco V, Sacco T, Zamboni M, et al. Weight loss and quality of life improvement in obese subjects treated with sibutramine: a double-blind randomized multicenter study. Ann Nutr Metab. 2007;51:75-81. | Sibutramine intervention
Di Loreto C, Fanelli C, Lucidi P, et al. Validation of a counseling strategy to promote the adoption and the maintenance of physical activity by type 2 diabetic subjects. Diabetes Care. 2003;26:404-8. | Comparative effectiveness
Ditschuneit HH, Flechtner-Mors M, Johnson TD, Adler G. Metabolic and weight-loss effects of a long-term dietary intervention in obese patients. Am J Clin Nutr. 1999;69:198-204. | Comparative effectiveness
Djuric Z, Lababidi S, Heilbrun LK, et al. Effect of low-fat and/or low-energy diets on anthropometric measures in participants of the Women's Diet Study. J Am Coll Nutr. 2002;21:38-46. | No harms outcomes
Donnelly JE, Hill JO, Jacobsen DJ, et al. Effects of a 16-month randomized controlled exercise trial on body weight and composition in young, overweight men and women: the Midwest Exercise Trial. Arch Intern Med. 2003;163:1343-50. | No harms outcomes
Donnelly JE, Jacobsen DJ, Heelan KS, et al. The effects of 18 months of intermittent vs. continuous exercise on aerobic capacity, body weight and composition, and metabolic fitness in previously sedentary, moderately obese females. Int J Obes Relat Metab Disord. 2000;24:566-72. | Comparative effectiveness
Donnelly JE, Smith BK, Dunn L, et al. Comparison of a phone vs clinic approach to achieve 10% weight loss. Int J Obes. 2007;31:1270-6. | No harms outcomes
Due A, Larsen TM, Mu H, et al. Comparison of 3 ad libitum diets for weight-loss maintenance, risk of cardiovascular disease, and diabetes: a 6-mo randomized, controlled trial. Am J Clin Nutr. 2008;88:1232-41. | No harms outcomes
Dujovne CA, Zavoral JH, Rowe E, Mendel CM. Effects of sibutramine on body weight and serum lipids: a double-blind, randomized, placebo-controlled study in 322 overweight and obese patients with dyslipidemia. Am Heart J. 2001;142:489-97. | Sibutramine intervention
Dunn AL, Marcus BH, Kampert JB, et al. Comparison of lifestyle and structured interventions to increase physical activity and cardiorespiratory fitness: a randomized trial. JAMA. 1999;281:327-34. | Comparative effectiveness
Dunstan DW, Daly RM, Owen N, et al. Home-based resistance training is not sufficient to maintain improved glycemic control following supervised training in older individuals with type 2 diabetes. Diabetes Care. 2005;28:3-9. | Comparative effectiveness
Dutton GR, Davis MP, Welsch MA, Brantley PJ. Promoting physical activity for low-income minority women in primary care. Am J Health Behav. 2007;31:622-31. | No harms outcomes
Dymek MP, Le Grange D, Neven K, Alverdy J. Quality of life after gastric bypass surgery: a cross-sectional study. Obes Res. 2002;10:1135-42. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Dymek MP, Le Grange D, Neven K, Alverdy J. Quality of life and psychosocial adjustment in patients after Roux-en-Y gastric bypass: a brief report. Obes Surg. 2001;11:32-9. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Dyson PA, Hammersley MS, Morris RJ, et al. The Fasting Hyperglycaemia Study, II: randomized controlled trial of reinforced healthy-living advice in subjects with increased but not diabetic fasting plasma glucose. Metabolism. 1997;46:50-5. | Not one of the specified interventions
Dzator JA, Hendrie D, Burke V, et al. A randomized trial of interactive group sessions achieved greater improvements in nutrition and physical activity at a tiny increase in cost. J Clin Epidemiol. 2004;57:610-9. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Early JL, Apovian CM, Aronne LJ, et al. Sibutramine plus meal replacement therapy for body weight loss and maintenance in obese patients. Obesity. 2007;15:1464-72. | Sibutramine intervention
Eddy DM, Schlessinger L, Kahn R. Clinical outcomes and cost-effectiveness of strategies for managing people at high risk for diabetes. Ann Intern Med. 2005;143:251-64. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Elhayany A, Lustman A, Abel R, et al. A low carbohydrate Mediterranean diet improves cardiovascular risk factors and diabetes control among overweight patients with type 2 diabetes mellitus: a 1-year prospective randomized intervention study. Diabetes Obes Metab. 2010;12:204-9. | Comparative effectiveness
Elmer PJ, Obarzanek E, Vollmer WM, et al. Effects of comprehensive lifestyle modification on diet, weight, physical fitness, and blood pressure control: 18-month results of a randomized trial. Ann Intern Med. 2006;144:485-95. | Comparative effectiveness
Ely AC, Banitt A, Befort C, et al. Kansas primary care weighs in: a pilot randomized trial of a chronic care model program for obesity in 3 rural Kansas primary care practices. J Rural Health. 2008;24:125-32. | No harms outcomes
Eriksson KM, Westborg CJ, Eliasson MC. A randomized trial of lifestyle intervention in primary healthcare for the modification of cardiovascular risk factors. Scand J Public Health. 2006;34:453-61. | Not one of the specified interventions
Esposito K, Giugliano F, Di Palo C, et al. Effect of lifestyle changes on erectile dysfunction in obese men: a randomized controlled trial. JAMA. 2004;291:2978-84. | Comparative effectiveness
Esposito K, Marfella R, Ciotola M, et al. Effect of a Mediterranean-style diet on endothelial dysfunction and markers of vascular inflammation in the metabolic syndrome: a randomized trial. JAMA. 2004;292:1440-6. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Esposito K, Pontillo A, Di Palo C, et al. Effect of weight loss and lifestyle changes on vascular inflammatory markers in obese women: a randomized trial. JAMA. 2003;289:1799-804. | Comparative effectiveness
Eyjolfson V, Spriet LL, Dyck DJ. Conjugated linoleic acid improves insulin sensitivity in young, sedentary humans. Med Sci Sports Exerc. 2004;36:814-20. | Not one of the specified interventions
Fabricatore AN, Wadden TA, Moore RH, et al. Predictors of attrition and weight loss success: results from a randomized controlled trial. Behav Res Ther. 2009;47:685-91. | Comparative effectiveness
Fanghanel G, Cortinas L, Sanchez-Reyes L, Berber A. A clinical trial of the use of sibutramine for the treatment of patients suffering essential obesity. Int J Obes Relat Metab Disord. 2000;24:144-50. | Does not include specified harms outcomes
Fanghanel G, Cortinas L, Sanchez-Reyes L, et al. Safety and efficacy of sibutramine in overweight Hispanic patients with hypertension. Adv Ther. 2003;20:101-13. | No harms outcomes
Faria AN, Ribeiro Filho FF, Kohlmann NE, et al. Effects of sibutramine on abdominal fat mass, insulin resistance and blood pressure in obese hypertensive patients. Diabetes Obes Metab. 2005;7:246-53. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Faria AN, Ribeiro Filho FF, Lerario DD, et al. Effects of sibutramine on the treatment of obesity in patients with arterial hypertension. Arq Bras Cardiol. 2002;78:172-80. | No harms outcomes
Faulconbridge LF, Wadden TA, Berkowitz RI, et al. Changes in symptoms of depression with weight loss: results of a randomized trial. Obesity. 2009;17:1009-16. | No placebo in medication trial
Ferre R, Plana N, Merino J, et al. Effects of therapeutic lifestyle changes on peripheral artery tonometry in patients with abdominal obesity. Nutr Metab Cardiovasc Dis. 2010 Aug 11. [Epub ahead of print] | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Field AE, Malspeis S, Willett WC. Weight cycling and mortality among middle-aged or older women. Arch Intern Med. 2009;169:881-6. | Other quality issues
Figueroa A, Going SB, Milliken LA, et al. Effects of exercise training and hormone replacement therapy on lean and fat mass in postmenopausal women. J Gerontol A Biol Sci Med Sci. 2003;58:266-70. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Finer N, Bloom SR, Frost GS, et al. Sibutramine is effective for weight loss and diabetic control in obesity with type 2 diabetes: a randomised, double-blind, placebo-controlled study. Diabetes Obes Metab. 2000;2:105-12. | Sibutramine intervention
Finkelstein EA, Linnan LA, Tate DF, Leese PJ. A longitudinal study on the relationship between weight loss, medical expenditures, and absenteeism among overweight employees in the WAY to Health study. J Occup Environ Med. 2009;51:1367-73. | Conducted primarily in a non-relevant setting
Finley CE, Barlow CE, Greenway FL, et al. Retention rates and weight loss in a commercial weight loss program. Int J Obes (Lond). 2007;31:292-8. | Does not meet design requirements in inclusion criteria
Fitzgibbon ML, Stolley MR, Ganschow P, et al. Results of a faith-based weight loss intervention for black women. J Natl Med Assoc. 2005;97:1393-402. | Comparative effectiveness
Fitzgibbon ML, Stolley MR, Schiffer L, et al. A combined breast health/weight loss intervention for black women. Prev Med. 2005;40:373-83. | No harms outcomes
Fitzgibbon ML, Stolley MR, Schiffer L, et al. Obesity Reduction Black Intervention Trial (ORBIT): 18-month results. Obesity (Silver Spring). 2010;18:2317-25. | No harms outcomes
Flechtner-Mors M, Ditschuneit HH, Johnson TD, et al. Metabolic and weight loss effects of long-term dietary intervention in obese patients: four-year results. Obes Res. 2000;8:399-402. | Comparative effectiveness
Fleming R, Hopkinson ZE, Wallace AM, et al. Ovarian function and metabolic factors in women with oligomenorrhea treated with metformin in a randomized double blind placebo-controlled trial. J Clin Endocrinol Metab. 2002;87:569-74. | No harms outcomes
Fleming RM. The effect of high-, moderate-, and low-fat diets on weight loss and cardiovascular disease risk factors. Prev Cardiol. 2002;5:110-8. | Comparative effectiveness
Flood A, Mitchell N, Jaeb M, et al. Energy density and weight change in a long-term weight-loss trial. Int J Behav Nutr Phys Act. 2009;6:57. | Study of overweight/obesity prevention
Focht BC, Rejeski WJ, Ambrosius WT, et al. Exercise, self-efficacy, and mobility performance in overweight and obese older adults with knee osteoarthritis. Arthritis Rheum. 2005;53:659-65. | Comparative effectiveness
Fogelholm M, Kukkonen-Harjula K, Nenonen A, Pasanen M. Effects of walking training on weight maintenance after a very-low-energy diet in premenopausal obese women: a randomized controlled trial. Arch Intern Med. 2000;160:2177-84. | Comparative effectiveness
Fogelholm M, Kukkonen-Harjula K, Oja P. Eating control and physical activity as determinants of short-term weight maintenance after a very-low-calorie diet among obese women. Int J Obes Relat Metab Disord. 1999;23:203-10. | Comparative effectiveness
Fontana L, Villareal DT, Weiss EP, et al. Calorie restriction or exercise: effects on coronary heart disease risk factors: a randomized, controlled trial. Am J Physiol Endocrinol Metab. 2007;293:E197-202. | Comparative effectiveness
Fontbonne A, Diouf I, Baccara-Dinet M, et al. Effects of 1-year treatment with metformin on metabolic and cardiovascular risk factors in non-diabetic upper-body obese subjects with mild glucose anomalies: a post-hoc analysis of the BIGPRO1 trial. Diabetes Metab. 2009;35:385-91. | No harms outcomes
Fossati M, Amati F, Painot D, et al. Cognitive-behavioral therapy with simultaneous nutritional and physical activity education in obese patients with binge eating disorder. Eat Weight Disord. 2004;9:134-8. | Focus on patients in subgroups other than specified conditions
Foster GD, Borradaile KE, Sanders MH, et al. A randomized study on the effect of weight loss on obstructive sleep apnea among obese patients with type 2 diabetes: the Sleep AHEAD study. Arch Intern Med. 2009;169:1619-26. | Comparative effectiveness
Foster GD, Wyatt HR, Hill JO, et al. A randomized trial of a low-carbohydrate diet for obesity. N Engl J Med. 2003;348:2082-90. | Comparative effectiveness
Foster-Schubert KE, McTiernan A, Frayo RS, et al. Human plasma ghrelin levels increase during a one-year exercise program. J Clin Endocrinol Metab. 2005;90:820-5. | No harms outcomes
Fujimoto WY, Jablonski KA, Bray GA, et al. Body size and shape changes and the risk of diabetes in the Diabetes Prevention Program. Diabetes. 2007;56:1680-5. | No harms outcomes
Fujioka K, Seaton TB, Rowe E, et al. Weight loss with sibutramine improves glycaemic control and other metabolic parameters in obese patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2000;2:175-87. | Sibutramine intervention
Gambineri A, Pelusi C, Genghini S, et al. Effect of flutamide and metformin administered alone or in combination in dieting obese women with polycystic ovary syndrome. Clin Endocrinol (Oxf). 2004;60:241-9. | No harms outcomes
Gaullier JM, Halse J, Hoivik HO, et al. Six months supplementation with conjugated linoleic acid induces regional-specific fat mass decreases in overweight and obese. Br J Nutr. 2007;97:550-60. | Not one of the specified interventions
Gaullier JM, Halse J, Hoye K, et al. Conjugated linoleic acid supplementation for 1 y reduces body fat mass in healthy overweight humans. Am J Clin Nutr. 2004;79:1118-25. | Not one of the specified interventions
Gaullier JM, Halse J, Hoye K, et al. Supplementation with conjugated linoleic acid for 24 months is well tolerated by and reduces body fat mass in healthy, overweight humans. J Nutr. 2005;135:778-84. | Not one of the specified interventions
Ghroubi S, Elleuch H, Chikh T, et al. Physical training combined with dietary measures in the treatment of adult obesity; a comparison of two protocols. Ann Phys Rehab Med. 2009;52:394-413. | Not on list of countries with HDI > 0.90
Giugliano D, Quatraro A, Consoli G, et al. Metformin for obese, insulin-treated diabetic patients: improvement in glycaemic control and reduction of metabolic risk factors. Eur J Clin Pharmacol. 1993;44:107-12. | No harms outcomes
Glasgow RE, La Chance PA, Toobert DJ, et al. Long-term effects and costs of brief behavioural dietary intervention for patients with diabetes delivered from the medical office. Patient Educ Couns. 1997;32:175-84. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Glasgow RE, Nelson CC, Kearney KA, et al. Reach, engagement, and retention in an Internet-based weight loss program in a multi-site randomized controlled trial. J Med Internet Res. 2007;9:e11. | No harms outcomes
Godoy-Matos A, Carraro L, Vieira A, et al. Treatment of obese adolescents with sibutramine: a randomized, double-blind, controlled study. J Clin Endocrinol Metab. 2005;90:1460-5. | Focus on children or adolescents
Gokcel A, Karakose H, Ertorer EM, et al. Effects of sibutramine in obese female subjects with type 2 diabetes and poor blood glucose control. Diabetes Care. 2001;24:1957-60. | Not on list of countries with HDI > 0.90
Gold BC, Burke S, Pintauro S, et al. Weight loss on the web: a pilot study comparing a structured behavioral intervention to a commercial program. Obesity. 2007;15:155-64. | Comparative effectiveness
Gotfredsen A, Westergren HH, Andersen T. Influence of orlistat on bone turnover and body composition. Int J Obes Relat Metab Disord. 2001;25:1154-60. | No harms outcomes
Greaves CJ, Middlebrooke A, O'Loughlin L, et al. Motivational interviewing for modifying diabetes risk: a randomised controlled trial. Br J Gen Pract. 2008;58:535-40. | No harms outcomes
Grimm RH Jr, Grandits GA, Cutler JA, et al. Relationships of quality-of-life measures to long-term lifestyle and drug treatment in the Treatment of Mild Hypertension Study. Arch Intern Med. 1997;157:638-48. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Guisado JA, Vaz FJ, Alarcon J, et al. Psychopathological status and interpersonal functioning following weight loss in morbidly obese patients undergoing bariatric surgery. Obes Surg. 2002;12:835-40. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Gunther CW, Legowski PA, Lyle RM, et al. Dairy products do not lead to alterations in body weight or fat mass in young women in a 1-y intervention. Am J Clin Nutr. 2005;81:751-6. | Study of overweight/obesity prevention
Gurka MJ, Wolf AM, Conaway MR, et al. Lifestyle intervention in obese patients with type 2 diabetes: impact of the patient's educational background. Obesity. 2006;14:1085-92. | Comparative effectiveness
Gustafson A, Khavjou O, Stearns SC, et al. Cost-effectiveness of a behavioral weight loss intervention for low-income women: the Weight-Wise Program. Prev Med. 2009;49:390-5. | No harms outcomes
Guy-Grand B, Drouin P, Eschwege E, et al. Effects of orlistat on obesity-related diseases—a six-month randomized trial. Diabetes Obes Metab. 2004;6:375-83. | No harms outcomes
Hainer V, Kunesova M, Bellisle F, et al. Psychobehavioral and nutritional predictors of weight loss in obese women treated with sibutramine. Int J Obes (Lond). 2005;29:208-16. | No harms outcomes
Hakala K, Maasilta P, Sovijarvi AR. Upright body position and weight loss improve respiratory mechanics and daytime oxygenation in obese patients with obstructive sleep apnoea. Clin Physiol. 2000;20:50-5. | Does not meet design requirements in inclusion criteria
Hall WD, Feng Z, George VA, et al. Low-fat diet: effect on anthropometrics, blood pressure, glucose, and insulin in older women. Ethn Dis. 2003;13:337-43. | No harms outcomes
Halpern A, Leite CC, Herszkowicz N, et al. Evaluation of efficacy, reliability, and tolerability of sibutramine in obese patients, with an echocardiographic study. Rev Hosp Clin Fac Med Sao Paulo. 2002;57:98-102. | Does not include specified harms outcomes
Hansen D, Astrup A, Toubro S, et al. Predictors of weight loss and maintenance during 2 years of treatment by sibutramine in obesity: results from the European multi-centre STORM trial. Int J Obes Rel Metab Disord. 2001;25:496-501. | No harms outcomes
Hansen DL, Toubro S, Stock MJ, et al. The effect of sibutramine on energy expenditure and appetite during chronic treatment without dietary restriction. Int J Obes Relat Metab Disord. 1999;23:1016-24. | Sibutramine intervention
Harvey BJ, Gold BC, Lauber R, Starinski A. The impact of calcium and dairy product consumption on weight loss. Obes Res. 2005;13:1720-6. | Comparative effectiveness
Harvey-Berino J, Pintauro S, Buzzell P, et al. Does using the Internet facilitate the maintenance of weight loss? Int J Obes Relat Metab Disord. 2002;26:1254-60. | Comparative effectiveness
Harvey-Berino J, Pintauro S, Buzzell P, Gold EC. Effect of Internet support on the long-term maintenance of weight loss. Obes Res. 2004;12:320-9. | Comparative effectiveness
Harvey-Berino J, Pintauro SJ, Gold EC. The feasibility of using Internet support for the maintenance of weight loss. Behav Modif. 2002;26:103-16. | No harms outcomes
Haskell WL, Alderman EL, Fair JM, et al. Effects of intensive multiple risk factor reduction on coronary atherosclerosis and clinical cardiac events in men and women with coronary artery disease. Circulation. 1994;89:975-90. | Not one of the specified interventions
Haub MD, Simons TR, Cook CM, et al. Calcium-fortified beverage supplementation on body composition in postmenopausal women. Nutr J. 2005;4:21. | Not one of the specified interventions
Hauner H, Meier M, Wendland G, et al. Weight reduction by sibutramine in obese subjects in primary care medicine: the SAT Study. Exp Clin Endocrinol Diabetes. 2004;112:201-7. | Sibutramine intervention
Hawley G, Horwath C, Gray A, et al. Sustainability of health and lifestyle improvements following a non-dieting randomised trial in overweight women. Prev Med. 2008;47:593-9. | Comparative effectiveness
Hays NP, Starling RD, Sullivan DH, et al. Effects of an ad libitum, high carbohydrate diet and aerobic exercise training on insulin action and muscle metabolism in older men and women. J Gerontol A Biol Sci Med Sci. 2006;61:299-304. | No harms outcomes
Hazenberg BP. Randomized, double-blind, placebo-controlled, multicenter study of sibutramine in obese hypertensive patients. Cardiology. 2000;94:152-8. | Sibutramine intervention
Hensrud DD. Dietary treatment and long-term weight loss and maintenance in type 2 diabetes. Obes Res. 2001;9(Suppl 4):S348-53. | Does not meet design requirements in inclusion criteria
Herman WH, Hoerger TJ, Brandle M, et al. The cost-effectiveness of lifestyle modification or metformin in preventing type 2 diabetes in adults with impaired glucose tolerance. Ann Intern Med. 2005;142:323-32. | No harms outcomes
Hermann LS, Kalen J, Katzman P, et al. Long-term glycaemic improvement after addition of metformin to insulin in insulin-treated obese type 2 diabetes patients. Diabetes Obes Metab. 2001;3:428-34. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Heshka S, Anderson JW, Atkinson RL, et al. Weight loss with self-help compared with a structured commercial program: a randomized trial. JAMA. 2003;289:1792-8. | Comparative effectiveness
Heymsfield SB, Segal KR, Hauptman J, et al. Effects of weight loss with orlistat on glucose tolerance and progression to type 2 diabetes in obese adults. Arch Intern Med. 2000;160:1321-6. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Hivert MF, Langlois MF, Berard P, et al. Prevention of weight gain in young adults through a seminar-based intervention program. Int J Obes. 2007;31:1262-9. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Hoeger KM, Kochman L, Wixom N, et al. A randomized, 48-week, placebo-controlled trial of intensive lifestyle modification and/or metformin therapy in overweight women with polycystic ovary syndrome: a pilot study. Fertil Steril. 2004;82:421-9. | Does not include specified harms outcomes
Hooper L. Primary prevention of CVD: diet and weight loss. Clin Evid (Online). 2007. | Does not meet design requirements in inclusion criteria
Hope AA, Kumanyika SK, Shults J, Holmes WC. Changes in health-related quality of life among African-Americans in a lifestyle weight loss program. Qual Life Res. 2010;19:1025-33. | Does not meet design requirements in inclusion criteria
Howard BV, Manson JE, Stefanick ML, et al. Low-fat dietary pattern and weight change over 7 years: the Women's Health Initiative Dietary Modification Trial. JAMA. 2006;295:39-49. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Hsieh CJ, Wang PW, Liu RT, et al. Orlistat for obesity: benefits beyond weight loss. Diabetes Res Clin Pract. 2005;67:78-83. | Not on list of countries with HDI > 0.90
Hunter GR, Brock DW, Byrne NM, et al. Exercise training prevents regain of visceral fat for 1 year following weight loss. Obesity. 2010;18:690-5. | Comparative effectiveness
Jacobs DR, Sluik D, Rokling-Andersen MH, et al. Association of 1-y changes in diet pattern with cardiovascular disease risk factors and adipokines: results from the 1-y randomized Oslo Diet and Exercise Study. Am J Clin Nutr. 2009;89:509-17. | No harms outcomes
Jakicic JM, Jaramillo SA, Balasubramanyam A, et al. Effect of a lifestyle intervention on change in cardiorespiratory fitness in adults with type 2 diabetes: results from the Look AHEAD Study. Int J Obes. 2009;33:305-16. | Comparative effectiveness
Jakicic JM, Marcus BH, Gallagher KI, et al. Effect of exercise duration and intensity on weight loss in overweight, sedentary women: a randomized trial. JAMA. 2003;290:1323-30. | Comparative effectiveness
Jakicic JM, Otto AD, Lang W, et al. The effect of physical activity on 18-month weight change in overweight adults. Obesity (Silver Spring). 2011;19:100-9. | Comparative effectiveness
Jakicic JM, Winters C, Lang W, Wing RR. Effects of intermittent exercise and use of home exercise equipment on adherence, weight loss, and fitness in overweight women: a randomized trial. JAMA. 1999;282:1554-60. | Comparative effectiveness
Jakubowicz DJ, Seppala M, Jakubowicz S, et al. Insulin reduction with metformin increases luteal phase serum glycodelin and insulin-like growth factor-binding protein 1 concentrations and enhances uterine vascularity and blood flow in the polycystic ovary syndrome. J Clin Endocrinol Metab. 2001;86:1126-33. | No harms outcomes
Jalkanen L. The effect of a weight reduction program on cardiovascular risk factors among overweight hypertensives in primary health care. Scand J Soc Med. 1991;19:66-71. | Other quality issues
James WP, Astrup A, Finer N, et al. Effect of sibutramine on weight maintenance after weight loss: a randomised trial. Lancet. 2000;356:2119-25. | Sibutramine intervention
Janssen I, Fortier A, Hudson R, Ross R. Effects of an energy-restrictive diet with or without exercise on abdominal fat, intermuscular fat, and metabolic risk factors in obese women. Diabetes Care. 2002;25:431-8. | No harms outcomes
Jarjou LM, Prentice A, Sawo Y, et al. Randomized, placebo-controlled, calcium supplementation study in pregnant Gambian women: effects on breast-milk calcium concentrations and infant birth weight, growth, and bone mineral accretion in the first year of life. Am J Clin Nutr. 2006;83:657-66. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Jarrett RJ, Keen H, Murrells T. Changes in blood pressure and body weight over ten years in men selected for glucose intolerance. J Epidemiol Community Health. 1987;41:145-51. | Comparative effectiveness
Jeffery RW, French SA. Preventing weight gain in adults: design, methods and one year results from the Pound of Prevention study. Int J Obes Relat Metab Disord. 1997;21:457-64. | Study of overweight/obesity prevention
Jeffery RW, Wing RR, Sherwood NE, Tate DF. Physical activity and weight loss: does prescribing higher physical activity goals improve outcome? Am J Clin Nutr. 2003;78:684-9. | Comparative effectiveness
Jehn ML, Patt MR, Appel LJ, Miller ER III. One year follow-up of overweight and obese hypertensive adults following intensive lifestyle therapy. J Hum Nutr Diet. 2006;19:349-54. | Comparative effectiveness
Jensen LB, Kollerup G, Quaade F, Sorensen OH. Bone minerals changes in obese women during a moderate weight loss with and without calcium supplementation. J Bone Miner Res. 2001;16:141-7. | Comparative effectiveness
Jirik-Babb P, Geliebter A. Comparison of psychological characteristics of binging and nonbinging obese, adult, female outpatients. Eat Weight Disord. 2003;8:173-7. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Jordan J, Scholze J, Matiba B, et al. Influence of sibutramine on blood pressure: evidence from placebo-controlled trials. Int J Obes. 2005;29:509-16. | Does not meet design requirements in inclusion criteria
Kajaste S, Brander PE, Telakivi T, et al. A cognitive-behavioral weight reduction program in the treatment of obstructive sleep apnea syndrome with or without initial nasal CPAP: a randomized study. Sleep Med. 2004;5:125-31. | Not one of the specified interventions
Kalter-Leibovici O, Younis-Zeidan N, Atamna A, et al. Lifestyle intervention in obese Arab women: a randomized controlled trial. Arch Intern Med. 2010;170:970-6. | Comparative effectiveness
Kamioka H, Nakamura Y, Okada S, et al. Effectiveness of comprehensive health education combining lifestyle education and hot spa bathing for male white-collar employees: a randomized controlled trial with 1-year follow-up. J Epidemiol. 2009;19:219-30. | Conducted primarily in a non-relevant setting
Kansanen M, Vanninen E, Tuunainen A, et al. The effect of a very low-calorie diet-induced weight loss on the severity of obstructive sleep apnoea and autonomic nervous function in obese patients with obstructive sleep apnoea syndrome. Clin Physiol. 1998;18:377-85. | Does not meet design requirements in inclusion criteria
Karhunen L, Franssila-Kallunki A, Rissanen P, et al. Effect of orlistat treatment on body composition and resting energy expenditure during a two-year weight-reduction programme in obese Finns. Int J Obes Relat Metab Disord. 2000;24:1567-72. | No harms outcomes
Katzer L, Bradshaw AJ, Horwath CC, et al. Evaluation of a “nondieting” stress reduction program for overweight women: a randomized trial. Am J Health Promot. 2008;22:264-74. | Comparative effectiveness
Kaukua JK, Pekkarinen TA, Rissanen AM. Health-related quality of life in a randomised placebo-controlled trial of sibutramine in obese patients with type II diabetes. Int J Obes Relat Metab Disord. 2004;28:600-5. | Sibutramine intervention
Kawano M, Shono N, Yoshimura T, et al. Improved cardio-respiratory fitness correlates with changes in the number and size of small dense LDL: randomized controlled trial with exercise training and dietary instruction. Intern Med. 2009;48:25-32. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Keating GM, Jarvis B. Orlistat: in the prevention and treatment of type 2 diabetes mellitus. Drugs. 2120;61:2107-19. | Does not meet design requirements in inclusion criteria
Keller C, Trevino RP. Effects of two frequencies of walking on cardiovascular risk factor reduction in Mexican American women. Res Nurs Health. 2001;24:390-401. | No harms outcomes
Keogh JB, Luscombe-Marsh ND, Noakes M, et al. Long-term weight maintenance and cardiovascular risk factors are not different following weight loss on carbohydrate-restricted diets high in either monounsaturated fat or protein in obese hyperinsulinaemic men and women. Br J Nutr. 2007;97:405-10. | Comparative effectiveness
Keranen AM, Savolainen MJ, Reponen AH, et al. The effect of eating behavior on weight loss and maintenance during a lifestyle intervention. Prev Med. 2009;49:32-8. | Comparative effectiveness
Kerr J, Patrick K, Norman G, et al. Randomized control trial of a behavioral intervention for overweight women: impact on depressive symptoms. Depress Anxiety. 2008;25:555-8. | No harms outcomes
Ketola E, Makela M, Klockars M. Individualised multifactorial lifestyle intervention trial for high-risk cardiovascular patients in primary care. Br J Gen Pract. 2001;51:291-4. | Not one of the specified interventions
Kilicdag EB, Bagis T, Zeyneloglu HB, et al. Homocysteine levels in women with polycystic ovary syndrome treated with metformin versus rosiglitazone: a randomized study. Hum Reprod. 2005;20:894-9. | Does not meet design requirements in inclusion criteria
Kim SH, Lee YM, Jee SH, Nam CM. Effect of sibutramine on weight loss and blood pressure: a meta-analysis of controlled trials. Obes Res. 2003;11:1116-23. | Does not meet design requirements in inclusion criteria
Kim SI, Kim HS. Effectiveness of mobile and Internet intervention in patients with obese type 2 diabetes. Int J Med Inf. 2008;77:399-404. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Kim Y, Pike J, Adams H, et al. Telephone intervention promoting weight-related health behaviors. Prev Med. 2010;50:112-7. | Comparative effectiveness
Kirk SF, Harvey EL, McConnon A, et al. A randomised trial of an Internet weight control resource: the UK Weight Control Trial. BMC Health Serv Res. 2003;3:19. | No harms outcomes
Kjotrod SB, von During V, Carlsen SM. Metformin treatment before IVF/ICSI in women with polycystic ovary syndrome; a prospective, randomized, double blind study. Hum Reprod. 2004;19:1315-22. | No harms outcomes
Knopp RH, Paramsothy P, Retzlaff BM, et al. Undesirable effects of extreme dietary carbohydrate and saturated fat intakes: the search for the middle ground. Curr Atheroscler Rep. 2005;7:409-11. | Comparative effectiveness
Knowler WC, Fowler SE, Hamman RF, et al. 10-year follow-up of diabetes incidence and weight loss in the Diabetes Prevention Program Outcomes Study. Lancet. 2009;274:1677-86. | No harms outcomes
Kocak M, Caliskan E, Simsir C, Haberal A. Metformin therapy improves ovulatory rates, cervical scores, and pregnancy rates in clomiphene citrate-resistant women with polycystic ovary syndrome. Fertil Steril. 2002;77:101-6. | No harms outcomes
Kolotkin RL, Norquist JM, Crosby RD, et al. One-year health-related quality of life outcomes in weight loss trial participants: comparison of three measures. Health Qual Life Outcomes. 2009;7:53. | Not one of the specified interventions
Kostis JB, Wilson AC, Hooper WC, et al. Association of angiotensin-converting enzyme DD genotype with blood pressure sensitivity to weight loss. Am Heart J. 2002;144:625-9. | No harms outcomes
Kostis JB, Wilson AC, Shindler DM, et al. Persistence of normotension after discontinuation of lifestyle intervention in the trial of TONE. Am J Hypertens. 2002;15:732-4. | No harms outcomes
Krakoff J, Clark JM, Crandall JP, et al. Effects of metformin and weight loss on serum alanine aminotransferase activity in the Diabetes Prevention Program. Obesity (Silver Spring). 2010;18:1762-7. | No harms outcomes
Kraus WE, Houmard JA, Duscha BD, et al. Effects of the amount and intensity of exercise on plasma lipoproteins. N Engl J Med. 2002;347:1483-92. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Kreider RB, Ferreira MP, Greenwood M, et al. Effects of conjugated linoleic acid supplementation during resistance training on body composition, bone density, strength, and selected hematological markers. J Strength Cond Res. 2002;16:325-34. | Not one of the specified interventions
Kukkonen-Harjula KT, Borg PT, Nenonen AM, Fogelholm MG. Effects of a weight maintenance program with or without exercise on the metabolic syndrome: a randomized trial in obese men. Prev Med. 2005;41:784-90. | Comparative effectiveness
Kuller LH, Kinzel LS, Pettee KK, et al. Lifestyle intervention and coronary heart disease risk factor changes over 18 months in postmenopausal women: the Women On the Move through Activity and Nutrition (WOMAN study) clinical trial. J Womens Health. 2006;15:962-74. | Comparative effectiveness
Kuller LH, Kriska AM, Kinzel LS, et al. The clinical trial of Women On the Move through Activity and Nutrition (WOMAN) study. Contemp Clin Trials. 2006;28:370-81. | Comparative effectiveness
Kumanyika SK, Cook NR, Cutler JA, et al. Sodium reduction for hypertension prevention in overweight adults: further results from the Trials of Hypertension Prevention phase II. J Hum Hypertens. 2005;19:33-45. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Kumanyika SK, Shults J, Fassbender J, et al. Outpatient weight management in African-Americans: the Healthy Eating and Lifestyle Program (HELP) study. Prev Med. 2005;41:488-502. | Comparative effectiveness
Kumanyika SK, Wadden TA, Shults J, et al. Trial of family and friend support for weight loss in African American adults. Arch Intern Med. 2009;169:1795-804. | Comparative effectiveness
Laaksonen DE, Laitinen T, Schonberg J, et al. Weight loss and weight maintenance, ambulatory blood pressure and cardiac autonomic tone in obese persons with the metabolic syndrome. J Hypertens. 2003;21:371-8. | No harms outcomes
Laaksonen DE, Lindstrom J, Lakka TA, et al. Physical activity in the prevention of type 2 diabetes: the Finnish Diabetes Prevention Study. Diabetes. 2005;54:158-65. | No harms outcomes
Lally P, Chipperfield A, Wardle J. Healthy habits: efficacy of simple advice on weight control based on a habit-formation model. Int J Obes (Lond). 2008;32:700-7. | No harms outcomes
Lambert EV, Goedecke JH, Bluett K, et al. Conjugated linoleic acid versus high-oleic acid sunflower oil: effects on energy metabolism, glucose tolerance, blood lipids, appetite and body composition in regularly exercising individuals. Br J Nutr. 2007;97:1001-11. | Not one of the specified interventions
Larsen TM, Dalskov S, van Baak M, et al. The Diet, Obesity and Genes (Diogenes) dietary study in eight European countries—a comprehensive design for long-term intervention. Obes Rev. 2009;76-91. | Comparative effectiveness
Lasser VI, Raczynski JM, Stevens VJ, et al. Trials of Hypertension Prevention, phase II: structure and content of the weight loss and dietary sodium reduction interventions. Ann Epidemiol. 1995;5:156-64. | No harms outcomes
Laws R; Counterweight Project Team. A new evidence-based model for weight management in primary care: the Counterweight Programme. J Hum Nutr Diet. 2004;17:191-208. | Does not meet design requirements in inclusion criteria
Layman DK, Evans EM, Erickson D, et al. A moderate-protein diet produces sustained weight loss and long-term changes in body composition and blood lipids in obese adults. J Nutr. 2009;139:514-21. | Comparative effectiveness
Lee JS, Visser M, Tylavsky FA, et al. Weight loss and regain and effects on body composition: the Health, Aging, and Body Composition Study. J Gerontol A Biol Sci Med Sci. 2010;65:78-83. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Leermakers EA, Perri MG, Shigaki CL, Fuller PR. Effects of exercise-focused versus weight-focused maintenance programs on the management of obesity. Addict Behav. 1999;24:219-27. | Comparative effectiveness
Lehtovirta M, Forsen B, Gullstrom M, et al. Metabolic effects of metformin in patients with impaired glucose tolerance. Diabet Med. 2001;18:578-83. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Leibbrand R, Fichter MM. Maintenance of weight loss after obesity treatment: is continuous support necessary? Behav Res Ther. 2002;40:1275-89. | Focus on patients in subgroups other than specified conditions
Leinum CJ, Dopp JM, Morgan BJ. Sleep-disordered breathing and obesity: pathophysiology, complications, and treatment. Nutr Clin Pract. 2009;24:675-87. | Does not meet design requirements in inclusion criteria
Lejeune MP, Kovacs EM, Westerterp-Plantenga MS. Additional protein intake limits weight regain after weight loss in humans. Br J Nutr. 2005;93:281-9. | Not one of the specified interventions
Liao D, Asberry PJ, Shofer JB, et al. Improvement of BMI, body composition, and body fat distribution with lifestyle modification in Japanese Americans with impaired glucose tolerance. Diabetes Care. 2002;25:1504-10. | Comparative effectiveness
Lien LF, Brown AJ, Ard JD, et al. Effects of PREMIER lifestyle modifications on participants with and without the metabolic syndrome. Hypertension. 2007;50:609-16. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Ligibel JA, Giobbie-Hurder A, Olenczuk D, et al. Impact of a mixed strength and endurance exercise intervention on levels of adiponectin, high molecular weight adiponectin and leptin in breast cancer survivors. Cancer Causes Control. 2009;20:1523-8. | No harms outcomes
Linde JA, Jeffery RW, Finch EA, et al. Are unrealistic weight loss goals associated with outcomes for overweight women? Obes Res. 2004;12:569-76. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Lindegarde F. Orlistat with diet was effective and safe for weight loss and coronary risk reduction in obesity. Evid Based Med. 2001;6:54. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Lindholm A, Bixo M, Bjorn I, et al. Effect of sibutramine on weight reduction in women with polycystic ovary syndrome: a randomized, double-blind, placebo-controlled trial. Fertil Steril. 2008;89:1221-8. | No harms outcomes
Lindholm LH, Ekbom T, Dash C, et al. The impact of health care advice given in primary care on cardiovascular risk. BMJ. 1995;310:1105-9. | Comparative effectiveness
Lindstrom J, Eriksson JG, Valle TT, et al. Prevention of diabetes mellitus in subjects with impaired glucose tolerance in the Finnish Diabetes Prevention Study: results from a randomized clinical trial. J Am Soc Nephrol. 2003;14:S108-13. | No harms outcomes
Lindstrom J, Ilanne PP, Peltonen M, et al. Sustained reduction in the incidence of type 2 diabetes by lifestyle intervention: follow-up of the Finnish Diabetes Prevention Study. Lancet. 2006;368:1673-9. | No harms outcomes
Lindstrom J, Peltonen M, Eriksson JG, et al. High-fibre, low-fat diet predicts long-term weight loss and decreased type 2 diabetes risk: the Finnish Diabetes Prevention Study. Diabetologia. 2006;49:912-20. | No harms outcomes
Littman AJ, Vitiello MV, Foster-Schubert K, et al. Sleep, ghrelin, leptin and changes in body weight during a 1-year moderate-intensity physical activity intervention. Int J Obes. 2007;31:466-75. | No harms outcomes
Logue E, Sutton K, Jarjoura D, et al. Transtheoretical model-chronic disease care for obesity in primary care: a randomized trial. Obes Res. 2005;13:917-27. | Comparative effectiveness
Logue EE, Jarjoura DG, Sutton KS, et al. Longitudinal relationship between elapsed time in the action stages of change and weight loss. Obes Res. 2004;12:1499-508. | Does not meet design requirements in inclusion criteria
Lojander J, Mustajoki P, Ronka S, et al. A nurse-managed weight reduction programme for obstructive sleep apnoea syndrome. J Intern Med. 1998;244:251-5. | Does not meet design requirements in inclusion criteria
Lombard CB, Deeks AA, Ball K, et al. Weight, physical activity and dietary behavior change in young mothers: short term results of the HeLP-HER cluster randomized controlled trial. Nutr J. 2009;8:17. | No harms outcomes
Bray G, Gregg E, et al; Look AHEAD Research Group. Baseline characteristics of the randomised cohort from the Look AHEAD (Action for Health in Diabetes) study. Diabetes Vasc Dis Res. 2006;3:202-15. | Comparative effectiveness
Wadden TA, West DS, et al; Look AHEAD Research Group. The Look AHEAD study: a description of the lifestyle intervention and the evidence supporting it. Obesity. 2006;14:737-52. | Comparative effectiveness
Lucas CP, Boldrin MN, Reaven GM. Effect of orlistat added to diet (30% of calories from fat) on plasma lipids, glucose, and insulin in obese patients with hypercholesterolemia. Am J Cardiol. 2003;91:961-4. | Comparative effectiveness
Lucas KH, Kaplan-Machlis B. Orlistat—a novel weight loss therapy. Ann Pharmacother. 2001;35:314-28. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Major GC, Alarie F, Dore J, et al. Supplementation with calcium + vitamin D enhances the beneficial effect of weight loss on plasma lipid and lipoprotein concentrations. Am J Clin Nutr. 2007;85:54-9. | Not one of the specified interventions
Malone DC, Raebel MA, Porter JA, et al. Cost-effectiveness of sibutramine in the LOSE Weight Study: evaluating the role of pharmacologic weight-loss therapy within a weight management program. J Manag Care Pharm. 2005;11:458-68. | Comparative effectiveness
Malone M, Alger-Mayer S. Binge status and quality of life after gastric bypass surgery: a one-year study. Obes Res. 2004;12:473-81. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Malpuech-Brugere C, Verboeket-van de Venne WP, Mensink RP, et al. Effects of two conjugated linoleic acid isomers on body fat mass in overweight humans. Obes Res. 2004;12:591-8. | Not one of the specified interventions
Manini TM, Newman AB, Fielding R, et al. Effects of exercise on mobility in obese and nonobese older adults. Obesity (Silver Spring). 2010;18:1168-75. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Manning RM, Jung RT, Leese GP, Newton RW. The comparison of four weight reduction strategies aimed at overweight patients with diabetes mellitus: four-year follow-up. Diabet Med. 1998;15:497-502. | Comparative effectiveness
Marinilli PA, Gorin AA, Raynor HA, et al. Successful weight-loss maintenance in relation to method of weight loss. Obesity. 2008;16:2456-61. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Marshall NS, Grunstein RR. Losing weight in moderate to severe obstructive sleep apnoea. BMJ. 2009;339:b4363. | Conducted primarily in a non-relevant setting
Maruthur NM, Wang NY, Appel LJ. Lifestyle interventions reduce coronary heart disease risk: results from the PREMIER trial. Circulation. 2009;119:2026-31. | Not one of the specified interventions
Mata J, Silva MN, Vieira PN, et al. Motivational “spill-over” during weight control: increased self-determination and exercise intrinsic motivation predict eating self-regulation. Health Psychol. 2009;28:709-16. | No harms outcomes
Mathus-Vliegen EM; Balance Study Group. Long-term maintenance of weight loss with sibutramine in a GP setting following a specialist guided very-low-calorie diet: a double-blind, placebo-controlled, parallel group study. Eur J Clin Nutr. 2005;59(Suppl 1):31-8. | Sibutramine intervention
Matvienko OA, Hoehns JD. A lifestyle intervention study in patients with diabetes or impaired glucose tolerance: translation of a research intervention into practice. J Am Board Fam Med. 2009;22:535-43. | Does not meet design requirements in inclusion criteria
McConnon A, Kirk SF, Cockroft JE, et al. The Internet for weight control in an obese sample: results of a randomised controlled trial. BMC Health Serv Res. 2007;7:206. | No harms outcomes
McConnon A, Kirk SF, Ransley JK. Process evaluation of an Internet-based resource for weight control: use and views of an obese sample. J Nutr Educ Behav. 2009;41:261-7. | No harms outcomes
McLaughlin T, Carter S, Lamendola C, et al. Clinical efficacy of two hypocaloric diets that vary in overweight patients with type 2 diabetes: comparison of moderate fat versus carbohydrate reductions. Diabetes Care. 2007;30:1877-9. | Comparative effectiveness
McMahon FG, Fujioka K, Singh BN, et al. Efficacy and safety of sibutramine in obese white and African American patients with hypertension: a 1-year, double-blind, placebo-controlled, multicenter trial. Arch Intern Med. 2000;160:2185-91. | Sibutramine intervention
McMahon FG, Weinstein SP, Rowe E, et al. Sibutramine is safe and effective for weight loss in obese patients whose hypertension is well controlled with angiotensin-converting enzyme inhibitors. J Hum Hypertens. 2002;16:5-11. | Sibutramine intervention
McManus K, Antinoro L, Sacks F. A randomized controlled trial of a moderate-fat, low-energy diet compared with a low fat, low-energy diet for weight loss in overweight adults. Int J Obes Relat Metab Disord. 2001;25:1503-11. | Comparative effectiveness
McNulty SJ, Ur E, Williams G. A randomized trial of sibutramine in the management of obese type 2 diabetic patients treated with metformin. Diabetes Care. 2003;26:125-31. | Sibutramine intervention
McTiernan A, Sorensen B, Irwin ML, et al. Exercise effect on weight and body fat in men and women. Obesity. 2007;15:1496-512. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Meenan RT, Vogt TM, Williams AE, et al. Economic evaluation of a worksite obesity prevention and intervention trial among hotel workers in Hawaii. J Occup Environ Med. 2010;52(Suppl 1):8-13. | Conducted primarily in a non-relevant setting
Mengham LH, Morris BF, Palmer CR, White AJ. Is intensive dietetic intervention effective for overweight patients with diabetes mellitus? A randomised controlled trial in a general practice. Pract Diab Int. 1999;16:8. | Comparative effectiveness
Menon T, Quaddus S, Cohen L. Revision of failed vertical banded gastroplasty to non-resectional Scopinaro biliopancreatic diversion: early experience. Obes Surg. 2006;16:1420-4. | Comparative effectiveness
Messerli-Burgy N, Znoj H, Laederach K. Eating behavior, emotional regulation, and coping strategies in obese patients following a comprehensive weight reduction program. Verhaltenstherapie. 2007;17:56. | Does not meet design requirements in inclusion criteria
Messier SP, Loeser RF, Miller GD, et al. Exercise and dietary weight loss in overweight and obese older adults with knee osteoarthritis: the Arthritis, Diet, and Activity Promotion Trial. Arthritis Rheum. 2004;50:1501-10. | Comparative effectiveness
Meyer HE, Sogaard AJ, Falch JA, et al. Weight change over three decades and the risk of osteoporosis in men: the Norwegian Epidemiological Osteoporosis Studies (NOREPOS). Am J Epidemiol. 2008;168:454-60. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Micic D, Ivkovic-Lazar T, Dragojevic R, et al. Orlistat, a gastrointestinal lipase inhibitor, in therapy of obesity with concomitant hyperlipidemia. Med Pregl. 1999;52:323-33. | No harms outcomes
Mitkov M, Pehlivanov B, Terzieva D. Metformin versus rosiglitazone in the treatment of polycystic ovary syndrome. Eur J Obstet Gynecol Reprod Biol. 2006;126:93-8. | Does not meet design requirements in inclusion criteria
Miyatake N, Nishikawa H, Morishita A, et al. Daily walking reduces visceral adipose tissue areas and improves insulin resistance in Japanese obese subjects. Diabetes Res Clin Pract. 2002;58:101-7. | Does not meet design requirements in inclusion criteria
Molenaar EA, van Ameijden EJ, Vergouwe Y, et al. Effect of nutritional counselling and nutritional plus exercise counselling in overweight adults: a randomized trial in multidisciplinary primary care practice. Fam Pract. 2010;27:143-50. | High or differential attrition.
Molitch ME, Fujimoto W, Hamman RF, et al. The Diabetes Prevention Program and its global implications. J Am Soc Nephrol. 2003;14(Suppl 2):103-7. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Morgan PJ, Lubans DR, Collins CE, et al. 12-Month outcomes and process evaluation of the SHED-IT RCT: an Internet-based weight loss program targeting men. Obesity (Silver Spring). 2011;19:142-51. | Conducted primarily in a non-relevant setting
Mougios V, Matsakas A, Petridou A, et al. Effect of supplementation with conjugated linoleic acid on human serum lipids and body fat. J Nutr Biochem. 2001;12:585-94. | Not one of the specified interventions
Multiple Risk Factor Intervention Trial Research Group. Risk factor changes and mortality results: Multiple Risk Factor Intervention Trial. JAMA. 1982;248:1465-77. | Not one of the specified interventions
Munsch S, Biedert E, Keller U. Evaluation of a lifestyle change programme for the treatment of obesity in general practice. Swiss Med Wkly. 2003;133:148-54. | No harms outcomes
Murawski ME. Problem solving and the management of obesity in women from underserved rural settings. Dissert Abstr Int B Sci Eng. 2008;69:690. | Comparative effectiveness
Nahmias J, Kirschner M, Karetzky MS. Weight loss and OSA and pulmonary function in obesity. N J Med. 1993;90:48-53. | Does not meet design requirements in inclusion criteria
Nakata Y, Ohkawara K, Lee DJ, et al. Effects of additional resistance training during diet-induced weight loss on bone mineral density in overweight premenopausal women. J Bone Miner Metab. 2008;26:172-7. | Comparative effectiveness
Nanchahal K, Townsend J, Letley L, et al. Weight-management interventions in primary care: a pilot randomised controlled trial. Br J Gen Pract. 2009;59:e157-66. | No harms outcomes
Nauta H, Hospers H, Jansen A. One-year follow-up effects of two obesity treatments on psychological well-being and weight. Br J Health Psychol. 2001;6:271-84. | Comparative effectiveness
Neaton JD, Grimm RH Jr, Cutler JA. Recruitment of participants for the Multiple Risk Factor Intervention Trial (MRFIT). Control Clin Trials. 1987;8:S41-53. | Not one of the specified interventions
Nelson MS, Robbins AS, Thornton JA. An intervention to reduce excess body weight in adults with or at risk for type 2 diabetes. Mil Med. 2006;171:409-14. | No harms outcomes
Nicklas BJ, Ambrosius W, Messier SP, et al. Diet-induced weight loss, exercise, and chronic inflammation in older, obese adults: a randomized controlled clinical trial. Am J Clin Nutr. 2004;79:544-51. | Comparative effectiveness
Nowson CA, Worsley A, Margerison C, et al. Blood pressure change with weight loss is affected by diet type in men. Am J Clin Nutr. 2005;81:983-9. | Comparative effectiveness
Ockene IS, Hebert JR, Ockene JK, et al. Effect of physician-delivered nutrition counseling training and an office-support program on saturated fat intake, weight, and serum lipid measurements in a hyperlipidemic population: Worcester Area Trial for Counseling in Hyperlipidemia (WATCH). Arch Intern Med. 1999;159:725-31. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Olson TP, Dengel DR, Leon AS, Schmitz KH. Changes in inflammatory biomarkers following one-year of moderate resistance training in overweight women. Int J Obes (Lond). 2007;31:996-1003. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Olson TP, Dengel DR, Leon AS, Schmitz KH. Moderate resistance training and vascular health in overweight women. Med Sci Sports Exerc. 2006;38:1558-64. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Omsland TK, Schei B, Gronskag AB, et al. Weight loss and distal forearm fractures in postmenopausal women: the Nord-Trondelag health study, Norway. Osteoporos Int. 2009;20:2009-16. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Ortega-Gonzalez C, Luna S, Hernandez L, et al. Responses of serum androgen and insulin resistance to metformin and pioglitazone in obese, insulin-resistant women with polycystic ovary syndrome. J Clin Endocrinol Metab. 2005;90:1360-5. | No harms outcomes
Osei-Assibey G, Kyrou I, Adi Y, et al. Dietary and lifestyle interventions for weight management in adults from minority ethnic/non-white groups: a systematic review. Obes Rev. 2010;11:769-76. | Does not meet design requirements in inclusion criteria
Ostbye T, Krause KM, Lovelady CA, et al. Active Mothers Postpartum: a randomized controlled weight-loss intervention trial. Am J Prev Med. 2009;37:173-80. | No harms outcomes
O'Toole ML, Sawicki MA, Artal R. Structured diet and physical activity prevent postpartum weight retention. J Womens Health (Larchmt). 2003;12:991-8. | Comparative effectiveness
Page RC, Harnden KE, Cook JT, Turner RC. Can life-styles of subjects with impaired glucose tolerance be changed? A feasibility study. Diabet Med. 1992;9:562-6. | Not one of the specified interventions
Pan XR, Li GW, Hu YH, et al. Effects of diet and exercise in preventing NIDDM in people with impaired glucose tolerance: the Da Qing IGT and Diabetes Study. Diabetes Care. 1997;20:537-44. | Not on list of countries with HDI > 0.90
Papalazarou A, Yannakoulia M, Kavouras SA, et al. Lifestyle intervention favorably affects weight loss and maintenance following obesity surgery. Obesity (Silver Spring). 2010;18:1348-53. | Comparative effectiveness
Parikh P, Simon EP, Fei K, et al. Results of a pilot diabetes prevention intervention in East Harlem, New York City: Project HEED. Am J Public Health. 2010;100(Suppl 1):S232-9. | No harms outcomes
Park SK, Park JH, Kwon YC, et al. The effect of combined aerobic and resistance exercise training on abdominal fat in obese middle-aged women. J Physiol Anthropol Appl Human Sci. 2003;22:129-35. | No harms outcomes
Pasquali R, Colella P, Cirignotta F, et al. Treatment of obese patients with obstructive sleep apnea syndrome (OSAS): effect of weight loss and interference of otorhinolaryngoiatric pathology. Int J Obes. 1990;14:207-17. | Does not meet design requirements in inclusion criteria
Paul-Ebhohimhen V, Avenell A. A systematic review of the effectiveness of group versus individual treatments for adult obesity. Obesity Facts. 2009;2:17-24. | No harms outcomes
Perreault L, Kahn SE, Christophi CA, et al. Regression from pre-diabetes to normal glucose regulation in the Diabetes Prevention Program. Diabetes Care. 2009;32:1583-8. | No harms outcomes
Perreault L, Ma Y, Dagogo-Jack S, et al. Sex differences in diabetes risk and the effect of intensive lifestyle modification in the Diabetes Prevention Program. Diabetes Care. 2008;31:1416-21. | No harms outcomes
Perri MG, Limacher MC, Durning PE, et al. Extended-care programs for weight management in rural communities: the Treatment of Obesity in Underserved Rural Settings (TOURS) randomized trial. Arch Intern Med. 2008;168:2347-54. | Comparative effectiveness
Petridou A, Mougios V, Sagredos A. Supplementation with CLA: isomer incorporation into serum lipids and effect on body fat of women. Lipids. 2003;38:805-11. | Not one of the specified interventions
Petrofsky J, Batt J, Berk L, et al. The effect of an aerobic dance and diet program on cardiovascular fitness, body composition, and weight loss in women. J Appl Res. 2008;8:179-88. | No harms outcomes
Phelan S, Wadden TA, Berkowitz RI, et al. Impact of weight loss on the metabolic syndrome. Int J Obes. 2007;31:1442-8. | Does not meet design requirements in inclusion criteria
Philippou E, Neary NM, Chaudhri O, et al. The effect of dietary glycemic index on weight maintenance in overweight subjects: a pilot study. Obesity. 2009;17:396-401. | Comparative effectiveness
Pinkston MM, Poston WS, Reeves RS, et al. Does metabolic syndrome mitigate weight loss in overweight Mexican American women treated for 1-year with orlistat and lifestyle modification? Eat Weight Disord. 2006;11:e35-41. | No placebo in medication trial
Pi-Sunyer X, Blackburn G, Brancati FL, et al. Reduction in weight and cardiovascular disease risk factors in individuals with type 2 diabetes: one-year results of the Look AHEAD trial. Diabetes Care. 2007;30:1374-83. | Comparative effectiveness
Porter JA, Raebel MA, Conner DA, et al. The Long-term Outcomes of Sibutramine Effectiveness on Weight (LOSE Weight) study: evaluating the role of drug therapy within a weight management program in a group-model health maintenance organization. Am J Manag Care. 2004;10:369-76. | No placebo in medication trial
Poston WS, Haddock CK, Olvera NE, et al. Evaluation of a culturally appropriate intervention to increase physical activity. Am J Health Behav. 2001;25:396-406. | Not one of the specified interventions
Poston WS, Haddock CK, Pinkston MM, et al. Evaluation of a primary care-oriented brief counselling intervention for obesity with and without orlistat. J Intern Med. 2006;260:388-98. | Does not meet design requirements in inclusion criteria
Poston WS, Reeves RS, Haddock CK, et al. Weight loss in obese Mexican Americans treated for 1-year with orlistat and lifestyle modification. Int J Obes Relat Metab Disord. 2003;27:1486-93. | No placebo in medication trial
Potteiger JA, Jacobsen DJ, Donnelly JE, Hill JO. Glucose and insulin responses following 16 months of exercise training in overweight adults: the Midwest Exercise Trial. Metabolism. 2003;52:1175-81. | No harms outcomes
Potteiger JA, Kirk EP, Jacobsen DJ, Donnelly JE. Changes in resting metabolic rate and substrate oxidation after 16 months of exercise training in overweight adults. Int J Sport Nutr Exerc Metab. 2008;18:79-95. | No harms outcomes
Pritchard JE, Nowson CA, Wark JD. A worksite program for overweight middle-aged men achieves lesser weight loss with exercise than with dietary change. J Am Diet Assoc. 1997;97:37-42. | Conducted primarily in a non-relevant setting
Promrat K, Kleiner DE, Niemeier HM, et al. Randomized controlled trial testing the effects of weight loss on nonalcoholic steatohepatitis. Hepatology. 2010;51:121-9. | Focus on patients in subgroups other than specified conditions
Proper KI, Hildebrandt VH, Van der Beek AJ, et al. Effect of individual counseling on physical activity fitness and health: a randomized controlled trial in a workplace setting. Am J Prev Med. 2003;24:218-26. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Provencher V, Begin C, Tremblay A, et al. Health-at-every-size and eating behaviors: 1-year follow-up results of a size acceptance intervention. J Am Diet Assoc. 2009;109:1854-61. | Not one of the specified interventions
Racette SB, Deusinger SS, Inman CL, et al. Worksite Opportunities for Wellness (WOW): effects on cardiovascular disease risk factors after 1 year. Prev Med. 2009;49:108-14. | Conducted primarily in a non-relevant setting
Racette SB, Weiss EP, Obert KA, et al. Modest lifestyle intervention and glucose tolerance in obese African Americans. Obes Res. 2001;9:348-55. | Comparative effectiveness
Racette SB, Weiss EP, Villareal DT, et al. One year of caloric restriction in humans: feasibility and effects on body composition and abdominal adipose tissue. J Gerontol A Biol Sci Med Sci. 2006;61:943-50. | Comparative effectiveness
Ramachandran A, Snehalatha C, Mary S, et al. The Indian Diabetes Prevention Programme shows that lifestyle modification and metformin prevent type 2 diabetes in Asian Indian subjects with impaired glucose tolerance (IDPP-1). Diabetologia. 2006;49:289-97. | Not on list of countries with HDI > 0.90
Ramirez EM, Rosen JC. A comparison of weight control and weight control plus body image therapy for obese men and women. J Consult Clin Psychol. 2001;69:440-6. | Comparative effectiveness
Randomised trial of jejunoileal bypass versus medical treatment in morbid obesity. Lancet. 1979;2:1255-8. | Not one of the specified interventions
Rapoport L, Clark M, Wardle J. Evaluation of a modified cognitive-behavioural programme for weight management. Int J Obes Relat Metab Disord. 2000;24:1726-37. | Comparative effectiveness
Ratner RE; Diabetes Prevention Program. An update on the Diabetes Prevention Program. Endocr Pract. 2006;12(Suppl 1):20-4. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Razquin C, Martinez JA, Martinez-Gonzalez MA, et al. A 3 years follow-up of a Mediterranean diet rich in virgin olive oil is associated with high plasma antioxidant capacity and reduced body weight gain. Eur J Clin Nutr. 2009;63:1387-93. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Reaven G, Segal K, Hauptman J, et al. Effect of orlistat-assisted weight loss in decreasing coronary heart disease risk in patients with syndrome X. Am J Cardiol. 2001;87:827-31. | Other quality issues
Redman LM, Rood J, Anton SD, et al. Calorie restriction and bone health in young, overweight individuals. Arch Intern Med. 2008;168:1859-66. | No harms outcomes
Redmon JB, Bertoni AG, Connelly S, et al. Effect of the Look AHEAD study intervention on medication use and related cost to treat cardiovascular disease risk factors in individuals with type 2 diabetes. Diabetes Care. 2010;33:1153-8. | Comparative effectiveness
Reid IR, Horne A, Mason B, et al. Effects of calcium supplementation on body weight and blood pressure in normal older women: a randomized controlled trial. J Clin Endocrinol Metab. 2005;90:3824-9. | Not one of the specified interventions
Rejeski WJ, Focht BC, Messier SP, et al. Obese, older adults with knee osteoarthritis: weight loss, exercise, and quality of life. Health Psychol. 2002;21:419-26. | Comparative effectiveness
Renzaho AM, Mellor D, Boulton K, Swinburn B. Effectiveness of prevention programmes for obesity and chronic diseases among immigrants to developed countries—a systematic review. Public Health Nutr. 2010;13:438-50. | Does not meet design requirements in inclusion criteria
Ricci TA, Chowdhury HA, Heymsfield SB, et al. Calcium supplementation suppresses bone turnover during weight reduction in postmenopausal women. J Bone Miner Res. 1998;13:1045-50. | No harms outcomes
Riedt CS, Schlussel Y, von Thun N, et al. Premenopausal overweight women do not lose bone during moderate weight loss with adequate or higher calcium intake. Am J Clin Nutr. 2007;85:972-80. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Rimmer JH, Rauworth A, Wang E, et al. A randomized controlled trial to increase physical activity and reduce obesity in a predominantly African American group of women with mobility disabilities and severe obesity. Prev Med. 2009;48:473-9. | No harms outcomes
Riserus U, Arner P, Brismar K, Vessby B. Treatment with dietary trans10cis12 conjugated linoleic acid causes isomer-specific insulin resistance in obese men with the metabolic syndrome. Diabetes Care. 2002;25:1516-21. | Not one of the specified interventions
Rissanen P, Vahtera E, Krusius T, et al. Weight change and blood coagulability and fibrinolysis in healthy obese women. Int J Obes Relat Metab Disord. 2001;25:212-8. | No harms outcomes
Rock CL, Flatt SW, Sherwood NE, et al. Effect of a free prepared meal and incentivized weight loss program on weight loss and weight loss maintenance in obese and overweight women: a randomized controlled trial. JAMA. 2010;304:1803-10. | Comparative effectiveness
Rock CL, Pakiz B, Flatt SW, Quintana EL. Randomized trial of a multifaceted commercial weight loss program. Obesity. 2007;15:939-49. | Comparative effectiveness
Rosenfalck AM, Hendel H, Rasmussen MH, et al. Minor long-term changes in weight have beneficial effects on insulin sensitivity and beta-cell function in obese subjects. Diabetes Obes Metab. 2002;4:19-28. | No harms outcomes
Ross R, Blair SN, Godwin M, et al. Prevention and Reduction of Obesity through Active Living (PROACTIVE): rationale, design and methods. Br J Sports Med. 2009;43:57-63. | No harms outcomes
Ross R, Janssen I, Dawson J, et al. Exercise-induced reduction in obesity and insulin resistance in women: a randomized controlled trial. Obes Res. 2004;12:789-98. | No harms outcomes
Rothacker DQ, Staniszewski BA, Ellis PK. Liquid meal replacement vs traditional food: a potential model for women who cannot maintain eating habit change. J Am Diet Assoc. 2001;101:345-7. | Comparative effectiveness
Rothert K, Strecher VJ, Doyle LA, et al. Web-based weight management programs in an integrated health care setting: a randomized, controlled trial. Obesity. 2006;14:266-72. | No harms outcomes
Ryan DH, Johnson WD, Myers VH, et al. Nonsurgical weight loss for extreme obesity in primary care settings: results of the Louisiana Obese Subjects Study. Arch Intern Med. 2010;170:146-54. | No placebo in medication trial
Sabbioni ME, Dickson MH, Eychmuller S, et al. Intermediate results of health related quality of life after vertical banded gastroplasty. Int J Obes Relat Metab Disord. 2002;26:277-80. | Not one of the specified interventions
Saccone A, Israel A. Effects of experimenter versus significant other-controlled reinforcement and choice of target behavior on weight loss. Behav Ther. 1978;9:271-8. | Precedes search period
Salas SJ, Fernández BJ, Ros E, et al. Effect of a Mediterranean diet supplemented with nuts on metabolic syndrome status: one-year results of the PREDIMED randomized trial. Arch Intern Med. 2008;168:2449-58. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Samaras K, Ashwell S, Mackintosh AM, et al. Will older sedentary people with non-insulin-dependent diabetes mellitus start exercising? A health promotion model. Diabetes Res Clin Pract. 1997;37:121-8. | Not one of the specified interventions
Sampol G, Munoz X, Sagales MT, et al. Long-term efficacy of dietary weight loss in sleep apnoea/hypopnoea syndrome. Eur Respir J. 1998;12:1156-9. | Does not meet design requirements in inclusion criteria
Samsa GP, Kolotkin RL, Williams GR, et al. Effect of moderate weight loss on health-related quality of life: an analysis of combined data from 4 randomized trials of sibutramine vs placebo. Am J Manag Care. 2001;7:875-83. | Does not meet design requirements in inclusion criteria
Sanchez-Reyes L, Fanghanel G, Yamamoto J, et al. Use of sibutramine in overweight adult Hispanic patients with type 2 diabetes mellitus: a 12-month, randomized, double-blind, placebo-controlled clinical trial. Clin Ther. 2004;26:1427-35. | Not on list of countries with HDI > 0.90
Sarac S, Sarac F. Cardiac valve evaluation and adipokine levels in obese women treated with sibutramine. Anadolu Kardiyoloji Dergisi. 2010;10:226-32. | Sibutramine intervention
Sari R, Eray E, Ozdem S, et al. Comparison of the effects of sibutramine versus sibutramine plus metformin in obese women. Clin Exp Med. 2010;10:179-84. | Sibutramine intervention
Sarwer DB, von Sydow GA, Vetter ML, Wadden TA. Behavior therapy for obesity: where are we now? Curr Opin Endocrinol Diabetes Obes. 2009;16:347-52. | Does not meet design requirements in inclusion criteria
Sbrocco T, Nedegaard RC, Stone JM, Lewis EL. Behavioral choice treatment promotes continuing weight loss: preliminary results of a cognitive-behavioral decision-based treatment for obesity. J Consult Clin Psychol. 1999;67:260-6. | Comparative effectiveness
Schmitz KH, Hannan PJ, Stovitz SD, et al. Strength training and adiposity in premenopausal women: Strong, Healthy, and Empowered Study. Am J Clin Nutr. 2007;86:566-72. | No harms outcomes
Schneider PL, Bassett DR Jr, Thompson DL, et al. Effects of a 10,000 steps per day goal in overweight adults. Am J Health Promot. 2006;21:85-9. | No harms outcomes
Scholze J, Grimm E, Herrmann D, et al. Optimal treatment of obesity-related hypertension: the Hypertension-Obesity-Sibutramine (HOS) study. Circulation. 2007;115:1991-8. | Sibutramine intervention
Schuler G, Hambrecht R, Schlierf G, et al. Regular physical exercise and low-fat diet: effects on progression of coronary artery disease. Circulation. 1992;86:1-11. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Schuster RJ, Tasosa J, Terwoord NA. Translational research—implementation of NHLBI Obesity Guidelines in a primary care community setting: the Physician Obesity Awareness Project. J Nutr Health Aging. 2008;12:S764-9. | Comparative effectiveness
Serrano-Rios M, Melchionda N, Moreno-Carretero E. Role of sibutramine in the treatment of obese type 2 diabetic patients receiving sulphonylurea therapy. Diabet Med. 2002;19:119-24. | Sibutramine intervention
Shapses SA, Heshka S, Heymsfield SB. Effect of calcium supplementation on weight and fat loss in women. J Clin Endocrinol Metab. 2004;89:632-7. | Not one of the specified interventions
Shea MK, Houston DK, Nicklas BJ, et al. The effect of randomization to weight loss on total mortality in older overweight and obese adults: the ADAPT study. J Gerontol A Biol Sci Med Sci. 2010;65:519-25. | Comparative effectiveness
Sherwood NE, Jeffery RW, Pronk NP, et al. Mail and phone interventions for weight loss in a managed-care setting: Weigh-To-Be 2-year outcomes. Int J Obes. 2006;30:1565-73. | No harms outcomes
Short KR, Vittone JL, Bigelow ML, et al. Impact of aerobic exercise training on age-related changes in insulin sensitivity and muscle oxidative capacity. Diabetes. 2003;52:1888-96. | No harms outcomes
Siegel JM, Prelip ML, Erausquin JT, Kim SA. A worksite obesity intervention: results from a group-randomized trial. Am J Public Health. 2010;100:327-33. | Conducted primarily in a non-relevant setting
Silva MN, Markland D, Carraca EV, et al. Exercise autonomous motivation predicts three-year weight loss in women. Med Sci Sports Exerc. 2011;43:728-37. | Study of overweight/obesity prevention
Simmons D, Rush E, Crook N; Te Wai o Rona Diabetes Prevention Strategy Team. Development and piloting of a community health worker-based intervention for the prevention of diabetes among New Zealand Maori in Te Wai o Rona: Diabetes Prevention Strategy. Public Health Nutr. 2008;11:1318-25. | Focus on patients in subgroups other than specified conditions
Sircar AR, Kumar A, Lal M. Clinical evaluation of sibutramine in obese type 2 diabetic patients refractory to dietary management. J Assoc Physicians India. 2001;49:885-8. | Other quality issues
Sjostrom L. Analysis of the XENDOS study (Xenical in the Prevention of Diabetes in Obese Subjects). Endocr Pract. 2006;12(Suppl 1):31-3. | No harms outcomes
Skender ML, Goodrick GK, Del Junco DJ, et al. Comparison of 2-year weight loss trends in behavioral treatments of obesity: diet, exercise, and combination interventions. J Am Diet Assoc. 1996;96:342-6. | Comparative effectiveness
Skinner TC, Carey ME, Cradock S, et al. Diabetes Education and Self-Management for Ongoing and Newly Diagnosed (DESMOND): process modelling of pilot study. Patient Educ Couns. 2006;64:369-77. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Slentz CA, Aiken LB, Houmard JA, et al. Inactivity, exercise, and visceral fat—STRRIDE: a randomized, controlled study of exercise intensity and amount. J Appl Physiol. 2005;99:1613-8. | No harms outcomes
Slentz CA, Duscha BD, Johnson JL, et al. Effects of the amount of exercise on body weight, body composition, and measures of central obesity: STRRIDE—a randomized controlled study. Arch Intern Med. 2004;164:31-9. | No harms outcomes
Smedman A, Vessby B. Conjugated linoleic acid supplementation in humans—metabolic effects. Lipids. 2001;36:773-81. | Not one of the specified interventions
Smith IG, Goulder MA. Randomized placebo-controlled trial of long-term treatment with sibutramine in mild to moderate obesity. J Fam Pract. 2001;50:505-12. | Sibutramine intervention
Smith PL, Gold AR, Meyers DA, et al. Weight loss in mildly to moderately obese patients with obstructive sleep apnea. Ann Intern Med. 1985;103:850-5. | No harms outcomes
Southard BH, Southard DR, Nuckolls J. Clinical trial of an Internet-based case management system for secondary prevention of heart disease. J Cardiopulm Rehabil. 2003;23:341-8. | No harms outcomes
Sramek JJ, Leibowitz MT, Weinstein SP, et al. Efficacy and safety of sibutramine for weight loss in obese patients with hypertension well controlled by beta-adrenergic blocking agents: a placebo-controlled, double-blind, randomised trial. J Hum Hypertens. 2002;16:13-9. | No harms outcomes
Stahre L, Hallstrom T. A short-term cognitive group treatment program gives substantial weight reduction up to 18 months from the end of treatment: a randomized controlled trial. Eat Weight Disord. 2005;10:51-8. | No harms outcomes
Stefanick ML, Mackey S, Sheehan M, et al. Effects of diet and exercise in men and postmenopausal women with low levels of HDL cholesterol and high levels of LDL cholesterol. N Engl J Med. 1998;339:12-20. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Stenius-Aarniala B, Poussa T, Kvarnstrom J, et al. Immediate and long term effects of weight reduction in obese people with asthma: randomised controlled study. BMJ. 2000;320:827-32. | Comparative effectiveness
Stensel DJ, Brooke-Wavell K, Hardman AE, et al. The influence of a 1-year programme of brisk walking on endurance fitness and body composition in previously sedentary men aged 42-59 years. Eur J Appl Physiol Occup Physiol. 1994;68:531-7. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Stern L, Iqbal N, Seshadri P, et al. The effects of low-carbohydrate versus conventional weight loss diets in severely obese adults: one-year follow-up of a randomized trial. Ann Intern Med. 2004;140:778-85. | Comparative effectiveness
Stuart RB. A three-dimensional program for the treatment of obesity. Behav Res Ther. 1971;9:177-86. | Precedes search period
Sun Q, Townsend MK, Okereke OI, et al. Adiposity and weight change in mid-life in relation to healthy survival after age 70 in women: prospective cohort study. BMJ. 2009;339:b3796. | Does not meet design requirements in inclusion criteria
Suratt PM, McTier RF, Findley LJ, et al. Effect of very-low-calorie diets with weight loss on obstructive sleep apnea. Am J Clin Nutr. 1992;56:S182-4. | Does not meet design requirements in inclusion criteria
Svendsen M, Helgeland M, Tonstad S. The long-term influence of orlistat on dietary intake in obese subjects with components of metabolic syndrome. J Human Nutr Diet. 2009;22:55-63. | No harms outcomes
Svetkey LP, Pollak KI, Yancy WS Jr, et al. Hypertension Improvement Project: randomized trial of quality improvement for physicians and lifestyle modification for patients. Hypertension. 2009;54:1226-33. | Not one of the specified interventions
Swartz AM, Strath SJ, Bassett DR, et al. Increasing daily walking improves glucose tolerance in overweight women. Prev Med. 2003;37:356-62. | No harms outcomes
Swinburn BA, Metcalf PA, Ley SJ. Long-term (5-year) effects of a reduced-fat diet intervention in individuals with glucose intolerance. Diabetes Care. 2001;24:619-24. | Conducted primarily in a non-relevant setting
Swinburn BA, Woollard GA, Chang EC, Wilson MR. Effects of reduced-fat diets consumed ad libitum on intake of nutrients, particularly antioxidant vitamins. J Am Diet Assoc. 1999;99:1400-5. | Conducted primarily in a non-relevant setting
Tanco S, Linden W, Earle T. Well-being and morbid obesity in women: a controlled therapy evaluation. Int J Eat Disord. 1998;23:325-39. | No harms outcomes
Taner ED, Yavuz B, Okhan AK, et al. An obesity drug sibutramine reduces brain natriuretic peptide (BNP) levels in severely obese patients. Int J Clin Pract. 2010;64:518-22. | Does not include specified harms outcomes
Tang T, Glanville J, Hayden CJ, et al. Combined lifestyle modification and metformin in obese patients with polycystic ovary syndrome: a randomized, placebo-controlled, double-blind multicentre study. Hum Reprod. 2006;21:80-9. | No harms outcomes
Tanumihardjo SA, Valentine AR, Zhang Z, et al. Strategies to increase vegetable or reduce energy and fat intake induce weight loss in adults. Exp Biol Med. 2009;234:542-52. | Comparative effectiveness
Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med. 2006;166:1620-5. | No harms outcomes
Tate DF, Jackvony EH, Wing RR. Effects of Internet behavioral counseling on weight loss in adults at risk for type 2 diabetes: a randomized trial. JAMA. 2003;289:1833-6. | Comparative effectiveness
Tate DF, Jeffery RW, Sherwood NE, Wing RR. Long-term weight losses associated with prescription of higher physical activity goals: are higher levels of physical activity protective against weight regain? Am J Clin Nutr. 2007;85:954-9. | Comparative effectiveness
Tate DF, Wing RR, Winett RA. Using Internet technology to deliver a behavioral weight loss program. JAMA. 2001;285:1172-7. | No harms outcomes
Taylor JS, Williams SR, Rhys R, et al. Conjugated linoleic acid impairs endothelial function. Arterioscler Thromb Vasc Biol. 2006;26:307-12. | Not one of the specified interventions
Teixeira PJ, Going SB, Houtkooper LB, et al. Resistance training in postmenopausal women with and without hormone therapy. Med Sci Sports Exerc. 2003;35:555-62. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
ODES Investigators. The Oslo Diet and Exercise Study (ODES): design and objectives. Control Clin Trials. 1993;14:229-43. | No harms outcomes
Thomas TR, Warner SO, Dellsperger KC, et al. Exercise and the metabolic syndrome with weight regain. J Appl Physiol. 2010;109:3-10. | Comparative effectiveness
Thompson WG, Rostad HN, Janzow DJ, et al. Effect of energy-reduced diets high in dairy products and fiber on weight loss in obese adults. Obes Res. 2005;13:1344-53. | Comparative effectiveness
Thorpe MP, Jacobson EH, Layman DK, et al. A diet high in protein, dairy, and calcium attenuates bone loss over twelve months of weight loss and maintenance relative to a conventional high-carbohydrate diet in adults. J Nutr. 2008;138:1096-100. | Comparative effectiveness
Tiikkainen M, Bergholm R, Rissanen A, et al. Effects of equal weight loss with orlistat and placebo on body fat and serum fatty acid composition and insulin resistance in obese women. Am J Clin Nutr. 2004;79:22-30. | Does not include specified harms outcomes
Tinker LF, Bonds DE, Margolis KL, et al. Low-fat dietary pattern and risk of treated diabetes mellitus in postmenopausal women: the Women's Health Initiative randomized controlled dietary modification trial. Arch Intern Med. 2008;168:1500-11. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Toft U, Kristoffersen L, Ladelund S, et al. The effect of adding group-based counselling to individual lifestyle counselling on changes in dietary intake: the Inter99 Study—a randomized controlled trial. Int J Behav Nutr Phys Act. 2008;5:59. | No harms outcomes
Toobert DJ, Glasgow RE, Radcliffe JL. Physiologic and related behavioral outcomes from the Women's Lifestyle Heart Trial. Ann Behav Med. 2000;22:1-9. | Focus on patients in subgroups other than specified conditions
What is TOPS (Take Off Pounds Sensibly). Milwaukee, WI: TOPS Club, Inc; 2011. http://www.tops.org/TOPSInformation/AboutTOPS.aspx | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Trento M, Passera P, Tomalino M, et al. Group visits improve metabolic control in type 2 diabetes: a 2-year follow-up. Diabetes Care. 2001;24:995-1000. | Comparative effectiveness
Tsai AG, Wadden TA, Rogers MA, et al. A primary care intervention for weight loss: results of a randomized controlled pilot study. Obesity (Silver Spring). 2010;18:1614-8. | Comparative effectiveness
Tsai AG, Wadden TA. Treatment of obesity in primary care practice in the United States: a systematic review. J Gen Intern Med. 2009;24:1073-9. | Does not meet design requirements in inclusion criteria
Tseng MC, Lee MB, Chen SY, et al. Response of Taiwanese obese binge eaters to a hospital-based weight reduction program. J Psychosom Res. 2004;57:279-85. | Focus on patients in subgroups other than specified conditions
Turnin MC, Bourgeois O, Cathelineau G, et al. Multicenter randomized evaluation of a nutritional education software in obese patients. Diabetes Metab. 2001;27:139-47. | Comparative effectiveness
Tuthill A, Quinn A, McColgan D, et al. A prospective randomized controlled trial of lifestyle intervention on quality of life and cardiovascular risk score in patients with obesity and type 2 diabetes. Diabetes Obes Metab. 2007;9:917-9. | No harms outcomes
Van Aggel-Leijssen DP, Saris WH, Hul GB, van Baak MA. Long-term effects of low-intensity exercise training on fat metabolism in weight-reduced obese men. Metabolism. 2002;51:1003-10. | Comparative effectiveness
Van Aggel-Leijssen DP, Saris WH, Hul GB, van Baak MA. Short-term effects of weight loss with or without low-intensity exercise training on fat metabolism in obese men. Am J Clin Nutr. 2001;73:523-31. | No harms outcomes
Van Aggel-Leijssen DP, Saris WH, Wagenmakers AJ, et al. The effect of low-intensity exercise training on fat metabolism of obese women. Obes Res. 2001;9:86-96. | No harms outcomes
Van Aggel-Leijssen DP, Saris WH, Wagenmakers AJ, et al. Effect of exercise training at different intensities on fat metabolism of obese men. J Appl Physiol. 2002;92:1300-9. | No harms outcomes
van Sluijs EM, van Poppel MN, Twisk JW, et al. Effect of a tailored physical activity intervention delivered in general practice settings: results of a randomized controlled trial. Am J Public Health. 2005;95:1825-31. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
van Wier MF, Ariens GA, Dekkers JC, et al. ALIFE@Work: a randomised controlled trial of a distance counselling lifestyle programme for weight control among an overweight working population. BMC Public Health. 2006;6:140. | No harms outcomes
van Wier MF, Ariens GA, Dekkers JC, et al. Phone and e-mail counselling are effective for weight management in an overweight working population: a randomized controlled trial. BMC Public Health. 2009;9:6. | No harms outcomes
VanWormer JJ, Martinez AM, Benson GA, et al. Telephone counseling and home telemonitoring: the Weigh by Day Trial. Am J Health Behav. 2009;33:445-54. | Comparative effectiveness
Velthuis MJ, Schuit AJ, Peeters PH, Monninkhof EM. Exercise program affects body composition but not weight in postmenopausal women. Menopause. 2009;16:777-84. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Venditti EM, Bray GA, Carrion-Petersen ML, et al. First versus repeat treatment with a lifestyle intervention program: attendance and weight loss outcomes. Int J Obes. 2008;32:1537-44. | No harms outcomes
Veverka DV, Anderson J, Auld GW, et al. Use of the stages of change model in improving nutrition and exercise habits in enlisted Air Force men. Mil Med. 2003;168:373-9. | No harms outcomes
Vidgren HM, Agren JJ, Valve RS, et al. The effect of orlistat on the fatty acid composition of serum lipid fractions in obese subjects. Clin Pharmacol Ther. 1999;66:315-22. | No harms outcomes
Villareal DT, Banks MR, Patterson BW, et al. Weight loss therapy improves pancreatic endocrine function in obese older adults. Obesity. 2008;16:1349-54. | No harms outcomes
Villareal DT, Fontana L, Weiss EP, et al. Bone mineral density response to caloric restriction-induced weight loss or exercise-induced weight loss: a randomized controlled trial. Arch Intern Med. 2006;166:2502-10. | Comparative effectiveness
Vissers D, Verrijken A, Mertens I, et al. Effect of long-term whole body vibration training on visceral adipose tissue: a preliminary report. Obesity Facts. 2010;3:93-100. | No harms outcomes
Volpe SL, Kobusingye H, Bailur S, Stanek E. Effect of diet and exercise on body composition, energy intake and leptin levels in overweight women and men. J Am Coll Nutr. 2008;27:195-208. | Comparative effectiveness
von Huth SL, Ladelund S, Borch-Johnsen K, Jorgensen T. A randomized multifactorial intervention study for prevention of ischaemic heart disease (Inter99): the long-term effect on physical activity. Scand J Public Health. 2008;36:380-8. | No harms outcomes
Wadden TA, Berkowitz RI, Sarwer DB, et al. Benefits of lifestyle modification in the pharmacologic treatment of obesity: a randomized trial. Arch Intern Med. 2001;161:218-27. | Comparative effectiveness
Wadden TA, Berkowitz RI, Womble LG, et al. Randomized trial of lifestyle modification and pharmacotherapy for obesity. N Engl J Med. 2005;353:2111-20. | No placebo in medication trial
Wadden TA, Foster GD, Sarwer DB, et al. Dieting and the development of eating disorders in obese women: results of a randomized controlled trial. Am J Clin Nutr. 2004;80:560-8. | Comparative effectiveness
Wadden TA, West DS, Neiberg RH, et al. One-year weight losses in the Look AHEAD study: factors associated with success. Obesity. 2009;17:713-22. | Comparative effectiveness
Wardle J, Rogers P, Judd P, et al. Randomized trial of the effects of cholesterol-lowering dietary treatment on psychological function. Am J Med. 2000;108:547-53. | No harms outcomes
Waring ME, Roberts MB, Parker DR, Eaton CB. Documentation and management of overweight and obesity in primary care. J Am Board Fam Med. 2009;22:544-52. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Warziski MT, Sereika SM, Styn MA, et al. Changes in self-efficacy and dietary adherence: the impact on weight loss in the PREFER study. J Behav Med. 2008;31:81-92. | Comparative effectiveness
Wassertheil-Smoller S, Oberman A, Blaufox MD, et al. The Trial of Antihypertensive Interventions and Management (TAIM) study: final results with regard to blood pressure, cardiovascular risk, and quality of life. Am J Hypertens. 1992;5:37-44. | No harms outcomes
Wee CC, Davis RB, Phillips RS. Stage of readiness to control weight and adopt weight control behaviors in primary care. J Gen Intern Med. 2005;20:410-5. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Weiner R, Bockhorn H, Rosenthal R, Wagner D. A prospective randomized trial of different laparoscopic gastric banding techniques for morbid obesity. Surg Endosc. 2001;15:63-8. | Not one of the specified interventions
Weiss EP, Racette SB, Villareal DT, et al. Improvements in glucose tolerance and insulin action induced by increasing energy expenditure or decreasing energy intake: a randomized controlled trial. Am J Clin Nutr. 2006;84:1033-42. | Comparative effectiveness
Whittemore R, Melkus G, Wagner J, et al. Translating the Diabetes Prevention Program to primary care: a pilot study. Nurs Res. 2009;58:2-12. | No harms outcomes
Williamson DA, Rejeski J, Lang W, et al. Impact of a weight management program on health-related quality of life in overweight adults with type 2 diabetes. Arch Intern Med. 2009;169:163-71. | Comparative effectiveness
Williamson DF. Re: randomized trial of weight loss and total mortality. J Gerontol A Biol Sci Med Sci. 2010;65:904. | Does not meet design requirements in inclusion criteria
Wing RR, Anglin K. Effectiveness of a behavioral weight control program for blacks and whites with NIDDM. Diabetes Care. 1996;19:409-13. | Comparative effectiveness
Wing RR, Creasman JM, West DS, et al. Improving urinary incontinence in overweight and obese women through modest weight loss. Obstetrics Gynecol. 2010;116:284-92. | Comparative effectiveness
Wing RR, Epstein LH, Paternostro-Bayles M, et al. Exercise in a behavioural weight control programme for obese patients with type 2 (non-insulin-dependent) diabetes. Diabetologia. 1988;31:902-9. | Comparative effectiveness
Wing RR, Tate DF, Gorin AA, et al. STOP regain: are there negative effects of daily weighing? J Consult Clin Psychol. 2007;75:652-6. | No harms outcomes
Wing RR, Tate DF, Gorin AA, et al. A self-regulation program for maintenance of weight loss. New Engl J Med. 2006;355:1563-71. | Comparative effectiveness
Wing RR, West DS, Grady D, et al. Effect of weight loss on urinary incontinence in overweight and obese women: results at 12 and 18 months. J Urol. 2010;184:1005-10. | Comparative effectiveness
Wing RR. Behavioral approaches to the treatment of obesity. In: Bray G, Bouchard C, James WP, eds. Handbook of Obesity. New York: Marcel Dekker; 1998:855-73. | Does not meet design requirements in inclusion criteria
Wing RR. Behavioral weight control. In: Wadden TA, Stunkard AJ, eds. Handbook of Obesity Treatment. New York: Guilford Press; 2002:301-16. | Does not meet design requirements in inclusion criteria
Wirth A, Krause J. Long-term weight loss with sibutramine: a randomized controlled trial. JAMA. 2001;286:1331-9. | Sibutramine intervention
Wister A, Loewen N, Kennedy-Symonds H, et al. One-year follow-up of a therapeutic lifestyle intervention targeting cardiovascular disease risk. Can Med Assoc J. 2007;177:859-65. | Not one of the specified interventions
Wolf AM, Conaway MR, Crowther JQ, et al. Translating lifestyle intervention to practice in obese patients with type 2 diabetes: Improving Control with Activity and Nutrition (ICAN) study. Diabetes Care. 2004;27:1570-6. | Comparative effectiveness
Wolf AM, Siadaty MS, Crowther JQ, et al. Impact of lifestyle intervention on lost productivity and disability: improving control with activity and nutrition. J Occup Environ Med. 2009;51:139-45. | Comparative effectiveness
Womble LG, Wadden TA, McGuckin BG, et al. A randomized controlled trial of a commercial Internet weight loss program. Obes Res. 2004;12:1011-8. | Comparative effectiveness
Wong SY, Lau EM, Lau WW, Lynn HS. Is dietary counselling effective in increasing dietary calcium, protein and energy intake in patients with osteoporotic fractures? A randomized controlled clinical trial. J Hum Nutr Diet. 2004;17:359-64. | Not focused on behavioral or pharmacological interventions designed to promote weight loss
Woo J, Sea MM, Tong P, et al. Effectiveness of a lifestyle modification programme in weight maintenance in obese subjects after cessation of treatment with orlistat. J Eval Clin Pract. 2007;13:853-9. | Does not include specified harms outcomes
Wosje KS, Kalkwarf HJ. Lactation, weaning, and calcium supplementation: effects on body composition in postpartum women. Am J Clin Nutr. 2004;80:423-9. | Not one of the specified interventions
Wright AD, Cull CA, MacLeod KM, et al. Hypoglycemia in type 2 diabetic patients randomized to and maintained on monotherapy with diet, sulfonylurea, metformin, or insulin for 6 years from diagnosis: UKPDS73. J Diabetes Complications. 2006;20:395-401. | Comparative effectiveness
Wylie-Rosett J, Swencionis C, Ginsberg M, et al. Computerized weight loss intervention optimizes staff time: the clinical and cost results of a controlled clinical trial conducted in a managed care setting. J Am Diet Assoc. 2001;101:1155-62. | Comparative effectiveness
Yalcin AA, Yavuz B, Ertugrul DT, et al. Elevation of QT dispersion after obesity drug sibutramine. J Cardiovasc Med (Hagerstown). 2010;11:832-5. | Sibutramine intervention
Yancey AK, McCarthy WJ, Harrison GG, et al. Challenges in improving fitness: results of a community-based, randomized, controlled lifestyle change intervention. J Womens Health. 2006;15:412-29. | Not one of the specified interventions
Yarali H, Yildiz BO, Demirol A, et al. Co-administration of metformin during rFSH treatment in patients with clomiphene citrate-resistant polycystic ovarian syndrome: a prospective randomized trial. Hum Reprod. 2002;17:289-94. | No harms outcomes
Yassine HN, Marchetti CM, Krishnan RK, et al. Effects of exercise and caloric restriction on insulin resistance and cardiometabolic risk factors in older obese adults—a randomized clinical trial. J Gerontol A Biol Sci Med Sci. 2009;64:90-5. | Comparative effectiveness
Yates T, Davies M, Gorely T, et al. Effectiveness of a pragmatic education program designed to promote walking activity in individuals with impaired glucose tolerance: a randomized controlled trial. Diabetes Care. 2009;32:1404-10. | Not one of the specified interventions
Yeh MC, Rodriguez E, Nawaz H, et al. Technical skills for weight loss: 2-y follow-up results of a randomized trial. Int J Obes Relat Metab Disord. 2003;27:1500-6. | Comparative effectiveness
Zannad F, Gille B, Grentzinger A, et al. Effects of sibutramine on ventricular dimensions and heart valves in obese patients during weight reduction. Am Heart J. 2002;144:508-15. | Sibutramine intervention
Zavoral JH. Treatment with orlistat reduces cardiovascular risk in obese patients. J Hypertens. 1998;16:2013-7. | Other quality issues
Zemel MB, Richards J, Mathis S, et al. Dairy augmentation of total and central fat loss in obese subjects. Int J Obes. 2005;29:391-7. | Not one of the specified interventions
Zemel MB, Richards J, Milstead A, Campbell P. Effects of calcium and dairy on body composition and weight loss in African-American adults. Obes Res. 2005;13:1218-25. | No harms outcomes
Zemel MB, Thompson W, Milstead A, et al. Calcium and dairy acceleration of weight and fat loss during energy restriction in obese adults. Obes Res. 2004;12:582-90. | Comparative effectiveness
The Hypertension Prevention Trial: three-year effects of dietary changes on blood pressure. Arch Intern Med. 1990;150:153-62. | No harms outcomes
Anderssen S, Holme I, Urdal P, Hjermann I. Diet and exercise intervention have favourable effects on blood pressure in mild hypertensives: the Oslo Diet and Exercise Study (ODES). Blood Press. 1995;4:343-9. | No harms outcomes
Burke V, Beilin LJ, Cutt HE, et al. Effects of a lifestyle programme on ambulatory blood pressure and drug dosage in treated hypertensive patients: a randomized controlled trial. J Hypertens. 2005;23:1241-9. | No harms outcomes
Christian JG, Bessesen DH, Byers TE, et al. Clinic-based support to help overweight patients with type 2 diabetes increase physical activity and lose weight. Arch Intern Med. 2008;168:141-6. | No harms outcomes
Cohen MD, D'Amico FJ, Merenstein JH. Weight reduction in obese hypertensive patients. Fam Med. 1991;23:25-8. | No harms outcomes
Cussler EC, Teixeira PJ, Going SB, et al. Maintenance of weight loss in overweight middle-aged women through the Internet. Obesity. 2008;16:1052-60. | No harms outcomes
Davis BR, Oberman A, Blaufox MD, et al. Effect of antihypertensive therapy on weight loss. Hypertension. 1992;19:393-9. | No harms outcomes
Davis BR, Blaufox MD, Hawkins CM, et al. Trial of antihypertensive interventions and management: design, methods, and selected baseline results. Control Clin Trials. 1989;10:11-30. | No harms outcomes
Eriksson J, Lindstrom J, Valle T, et al. Prevention of type II diabetes in subjects with impaired glucose tolerance: the Diabetes Prevention Study (DPS) in Finland—study design and 1-year interim report on the feasibility of the lifestyle intervention programme. Diabetologia. 1999;42:793-801. | No harms outcomes
Frey-Hewitt B, Vranizan KM, Dreon DM, Wood PD. The effect of weight loss by dieting or exercise on resting metabolic rate in overweight men. Int J Obes. 1990;14:327-34. | No harms outcomes
Haapala I, Barengo NC, Biggs S, et al. Weight loss by mobile phone: a 1-year effectiveness study. Public Health Nutr. 2009;12:2382-91. | No harms outcomes
Hansson L, Zanchetti A. The Hypertension Optimal Treatment (HOT) study—patient characteristics: randomization, risk profiles, and early blood pressure results. Blood Press. 1994;3:322-7. | No harms outcomes
Hollis JF, Satterfield S, Smith F, et al. Recruitment for phase II of the Trials of Hypertension Prevention: effective strategies and predictors of randomization. Ann Epidemiol. 1995;5:140-8. | No harms outcomes
Jeffery RW, Wing RR. Long-term effects of interventions for weight loss using food provision and monetary incentives. J Consult Clin Psychol. 1995;63:793-6. | No harms outcomes
Jeffery RW, Wing RR, Thorson C, et al. Strengthening behavioral interventions for weight loss: a randomized trial of food provision and monetary incentives. J Consult Clin Psychol. 1993;61:1038-45. | No harms outcomes
Jones DW, Miller ME, Wofford MR, et al. The effect of weight loss intervention on antihypertensive medication requirements in the Hypertension Optimal Treatment (HOT) study. Am J Hypertens. 1999;12:1175-80. | No harms outcomes
Kastarinen MJ, Puska PM, Korhonen MH, et al. Non-pharmacological treatment of hypertension in primary health care: a 2-year open randomized controlled trial of lifestyle intervention against hypertension in eastern Finland. J Hypertens. 2002;20:2505-12. | No harms outcomes
Kiernan M, King AC, Stefanick ML, Killen JD. Men gain additional psychological benefits by adding exercise to a weight-loss program. Obes Res. 2001;9:770-7. | No harms outcomes
Kulzer B, Hermanns N, Gorges D, et al. Prevention of Diabetes Self-Management Program (PREDIAS): effects on weight, metabolic risk factors, and behavioral outcomes. Diabetes Care. 2009;32:1143-6. | No harms outcomes
Langford HG, Blaufox MD, Oberman A, et al. Dietary therapy slows the return of hypertension after stopping prolonged medication. JAMA. 1985;253:657-64. | No harms outcomes
Langford HG, Davis BR, Blaufox D, et al. Effect of drug and diet treatment of mild hypertension on diastolic blood pressure. Hypertension. 1991;17:210-7. | No harms outcomes
Lindstrom J, Louheranta A, Mannelin M, et al. The Finnish Diabetes Prevention Study (DPS): lifestyle intervention and 3-year results on diet and physical activity. Diabetes Care. 2003;26:3230-6. | No harms outcomes
Martin DP, Rhode PC, Dutton GR, et al. A primary care weight management intervention for low-income African-American women. Obesity. 2006;14:1412-20. | No harms outcomes
Martin PD, Dutton GR, Rhode PC, et al. Weight loss maintenance following a primary care intervention for low-income minority women. Obesity. 2008;16:2462-7. | No harms outcomes
Mayer-Davis EJ, D'Antonio AM, Smith SM, et al. Pounds Off With Empowerment (POWER): a clinical trial of weight management strategies for black and white adults with diabetes who live in medically underserved rural communities. Am J Public Health. 2004;94:1736-42. | No harms outcomes
Mitsui T, Shimaoka K, Tsuzuku S, et al. Gentle exercise of 40 minutes with dietary counseling is effective in treating metabolic syndrome. Tohoku J Exp Med. 2008;215:355-61. | No harms outcomes
Moore H, Summerbell CD, Greenwood DC, et al. Improving management of obesity in primary care: cluster randomised trial. BMJ. 2003;327:1085. | No harms outcomes
Narayan KM, Hoskin M, Kozak D, et al. Randomized clinical trial of lifestyle interventions in Pima Indians: a pilot study. Diabet Med. 1998;15:66-72. | No harms outcomes
Perri MG, McAllister DA, Gange JJ, et al. Effects of four maintenance programs on the long-term management of obesity. J Consult Clin Psychol. 1988;56:529-34. | No harms outcomes
Pritchard DA, Hyndman J, Taba F. Nutritional counselling in general practice: a cost effective analysis. J Epidemiol Community Health. 1999;53:311-6. | No harms outcomes
Silva MN, Markland D, Minderico CS, et al. A randomized controlled trial to evaluate self-determination theory for exercise adherence and weight control: rationale and intervention description. BMC Public Health. 2008;8:234. | No harms outcomes
Silva MN, Vieira PN, Coutinho SR, et al. Using self-determination theory to promote physical activity and weight control: a randomized controlled trial in women. J Behav Med. 2010;33:110-22. | No harms outcomes
Stevens VJ, Obarzanek E, Cook NR, et al. Long-term weight loss and changes in blood pressure: results of the Trials of Hypertension Prevention, phase II. Ann Intern Med. 2001;134:1-11. | No harms outcomes
Stevens VJ, Corrigan SA, Obarzanek E, et al. Weight loss intervention in phase 1 of the Trials of Hypertension Prevention. Arch Intern Med. 1993;153:849-58. | No harms outcomes
Svetkey LP, Stevens VJ, Brantley PJ, et al. Comparison of strategies for sustaining weight loss: the weight loss maintenance randomized controlled trial. JAMA. 2008;299:1139-48. | No harms outcomes
Teixeira PJ, Silva MN, Coutinho SR, et al. Mediators of weight loss and weight loss maintenance in middle-aged women. Obesity (Silver Spring). 2010;18:725-35. | No harms outcomes
ter Bogt NC, Bemelmans WJ, Beltman FW, et al. Preventing weight gain: one-year results of a randomized lifestyle intervention. Am J Prev Med. 2009;37:270-7. | No harms outcomes
HOT Study Group. The Hypertension Optimal Treatment Study (the HOT Study). Blood Press. 1993;2:62-8. | No harms outcomes
Trials of Hypertention Prevention Collaborative Research Group. Effects of weight loss and sodium reduction intervention on blood pressure and hypertension incidence in overweight people with high-normal blood pressure. Arch Intern Med. 1997;157:657-67. | No harms outcomes
Trials of Hypertension Prevention Collaborative Research Group. The effects of nonpharmacologic interventions on blood pressure of persons with high normal levels: results of the Trials of Hypertension Prevention, phase I. JAMA. 1992;267:1213-20. | No harms outcomes
Tuomilehto J, Lindstrom J, Eriksson JG, et al. Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. N Engl J Med. 2001;344:1343-50. | No harms outcomes
Uusitupa M, Peltonen M, Lindstrom J, et al. Ten-year mortality and cardiovascular morbidity in the Finnish Diabetes Prevention Study—secondary analysis of the randomized trial. PLoS One. 2009;4:e5656. | No harms outcomes
Wassertheil-Smoller S, Langford HG, Blaufox MD, et al. Effective dietary intervention in hypertensives: sodium restriction and weight reduction. J Am Diet Assoc. 1985;85:423-30. | No harms outcomes
Weight Loss Maintenance Trial: Protocol. Portland, OR: Kaiser Permanente Center for Health Research; 2008. http://www.kpchr.org/wlmpublic/public/common/getdoc.aspx?docid=02E06ADF-1194-456A-904F-8AD81DB8EB8B | No harms outcomes
Werkman A, Hulshof PJ, Stafleu A, et al. Effect of an individually tailored one-year energy balance programme on body weight, body composition and lifestyle in recent retirees: a cluster randomised controlled trial. BMC Public Health. 2010;10:110. | No harms outcomes
Whelton PK, Hebert PR, Cutler J, et al. Baseline characteristics of participants in phase I of the Trials of Hypertension Prevention. Ann Epidemiol. 1992;2:295-310. | No harms outcomes
Wood PD, Stefanick ML, Dreon DM, et al. Changes in plasma lipids and lipoproteins in overweight men during weight loss through dieting as compared with exercise. N Engl J Med. 1988;319:1173-9. | No harms outcomes
Wood PD, Stefanick ML, Williams PT, Haskell WL. The effects on plasma lipoproteins of a prudent weight-reducing diet, with or without exercise, in overweight men and women. N Engl J Med. 1991;325:461-6. | No harms outcomes
Woollard J, Burke V, Beilin LJ, et al. Effects of a general practice-based intervention on diet, body mass index and blood lipids in patients at cardiovascular risk. J Cardiovasc Risk. 2003;10:31-40. | No harms outcomes
Riserus U, Vessby B, Arnlov J, Basu S. Effects of cis-9,trans-11 conjugated linoleic acid supplementation on insulin sensitivity, lipid peroxidation, and proinflammatory markers in obese men. Am J Clin Nutr. 2004;80:279-83. | Not one of the specified interventions
Lakerveld J, Bot SD, Chinapaw MJ, et al. Primary prevention of diabetes mellitus type 2 and cardiovascular diseases using a cognitive behavior program aimed at lifestyle changes in people at risk: design of a randomized controlled trial. BMC Endocr Disord. 2008;8:6. | No harms outcomes
Davey SG, Bracha Y, Svendsen KH, et al. Incidence of type 2 diabetes in the randomized Multiple Risk Factor Intervention Trial. Ann Intern Med. 2005;142:313-22. | Not one of the specified interventions
Kosaka K, Noda M, Kuzuya T. Prevention of type 2 diabetes by lifestyle intervention: a Japanese trial in IGT males. Diabetes Res Clin Pract. 2005;67:152-62. | Comparative effectiveness
Jakicic JM, Marcus BH, Lang W, Janney C. Effect of exercise on 24-month weight loss maintenance in overweight women. Arch Intern Med. 1559;168:1550-9. | Comparative effectiveness
Jacob S, Rabbia M, Meier MK, Hauptman J. Orlistat 120 mg improves glycaemic control in type 2 diabetic patients with or without concurrent weight loss. Diabetes Obes Metab. 2009;11:361-71. | No harms outcomes
Gaciong Z, Placha G. Efficacy and safety of sibutramine in 2225 subjects with cardiovascular risk factors: short-term, open-label, observational study. J Hum Hypertens. 2005;19:737-43. | Sibutramine intervention