# Evidence Tables

Appendix C Table 1a Evidence Table of Behavioral Trials: Study Characteristics

Appendix C Table 1b Evidence Table of Behavioral Trials: Intervention Details

Appendix C Table 1c Evidence Table of Behavioral Trials: Intermediate Outcomes

Appendix C Table 1d Evidence Table of Behavioral Trials: Health Outcomes and Adverse Effects

Appendix C Table 2a Evidence Table of Medication Trials: Study Characteristics

Appendix C Table 2b Evidence Table of Medication Trials: Intervention Details

Appendix C Table 2c Evidence Table of Medication Trials: Intermediate Outcomes

Appendix C Table 2d Evidence Table of Medication Trials: Health Outcomes

Appendix C Table 3a Evidence Table of Behavioral Harms Trials: Study Characteristics

Appendix C Table 3b Evidence Table of Behavioral Harms Trials: Intervention Details and Adverse Effects

Appendix C Table 4a Evidence Table of Medication Harms Trials: Study Characteristics

Appendix C Table 4b Evidence Table of Medication Harms Trials: Intervention Details and Intermediate Outcomes

Appendix C Table 4c Evidence Table of Medication Harms Trials: Adverse Effects