# Appendixes

Appendix A Detailed Methods

Appendix B Search Strategies

Appendix C Evidence Tables

Appendix D Excluded Studies

Appendix E Trials Pending Assessment

Appendix F Details on Pharmacology Harms

Appendix G Surgical Interventions