# References

1 Centers for Disease Control and Prevention. Heart Disease. Atlanta, GA. Centers for Disease Control and Prevention. 2011. Accessed at http://www.cdc.gov/heartdisease/index.htm. 15 August 2011.
2 Ferdinand KC. Coronary artery disease in minority racial and ethnic groups in the United States. Am J Cardiol. 2006;97(2A):12A-9.
3 Greenland P, Knoll MD, Stamler J, et al. Major risk factors as antecedents of fatal and nonfatal coronary heart disease events. JAMA. 2003;290(7):891-7. [pmid: 12928465].
4 Khot UN, Khot MB, Bajzer CT, et al. Prevalence of conventional risk factors in patients with coronary heart disease. JAMA. 2003;290(7):898-904. [pmid: 12928466].
5 Pasternak RC, Abrams J, Greenland P, et al. Task force #1—identification of coronary heart disease risk: is there a detection gap?. J Am Coll Cardiol. 2003;41(11):1863-74. [pmid: 12798553].
6 O’Malley PG, Redberg RF. Risk refinement, reclassification, and treatment thresholds in primary prevention of cardiovascular disease: incremental progress but significant gaps remain. Arch Intern Med. 2010;170(17):1602-3. [pmid: 20876413].
7 Pignone M, Fowler-Brown A, Pletcher M, Tice JA. Screening for Asymptomatic Coronary Artery Disease: A Systematic Review for the US Preventive Services Task Force, Systematic Evidence Review No 22. Rockville, MD. Agency for Healthcare Research and Quality. 2003. Accessed at http://www.ncbi.nlm.nih.gov/books/NBK42804/. 15 August 2011.
8 Fowler-Brown A, Pignone M, Pletcher M, et al. Exercise tolerance testing to screen for coronary heart disease: a systematic review for the technical support for the U.S. Preventive Services Task Force. Ann Intern Med. 2004;140(4):W9-24. [pmid: 15069009].
9 Lloyd-Jones DM, Adams RJ, Brown TM, et al. Heart disease and stroke statistics—2010 update: a report from the American Heart Association. Circulation. 2010;121(7):e46-215. [pmid: 20019324].
10 Vasan RS, Sullivan LM, Wilson PW, et al. Relative importance of boderline and elevated levels of coronary heart disease risk factors. Ann Intern Med. 2005;142(6):393-402. [pmid: 15767617].
11 Lloyd-Jones DM, Leip EP, Larson MG, et al. Prediction of lifetime risk for cardiovascular disease by risk factor burden at 50 years of age. Circulation. 2006;113(6):791-8. [pmid: 16461820].
12 Christopher Jones R, Pothier CE, Blackstone EH, Lauer MS. Prognostic importance of presenting symptoms in patients undergoing exercise testing for evaluation of known or suspected coronary disease. Am J Med. 2004;117(6):380-9. [pmid: 15380494].
13 Screening for Peripheral Arterial Disease: A Brief Evidence Update for the US Preventive Services Task Force, AHRQ Publication No 05-0583-B-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2005. Accessed at http://www.uspreventiveservicestaskforce.org/uspstf05/pad/padup.htm. 15 August 2011.
14 Helfand M, Buckley D, Fleming C, et al. Screening for Intermediate Risk Factors for Coronary Heart Disease: Systematic Evidence Synthesis, Evidence Synthesis No 73. Rockville, MD. Agency for Healthcare Research and Quality. 2009. Accessed at http://www.ncbi.nlm.nih.gov/books/NBK35208/. 15 August 2011.
15 Wolff T, Guirguis-Blake J, Miller T, et al. Screening for Asymptomatic Carotid Artery Stenosis, Evidence Synthesis No 50. Rockville, MD. Agency for Healthcare Research and Quality. 2007. Accessed at http://www.ncbi.nlm.nih.gov/books/NBK33504/. 15 August 2011.
16 Redberg RF, Benjamin EJ, Bittner V, et al. ACCF/AHA 2009 performance measures for primary prevention of cardiovascular disease in adults: a report of the American College of Cardiology Foundation/American Heart Association task force on performance measures. Circulation. 2009;120(13):1296-336. [pmid: 19770388].
17 Sox HC Jr, Littenberg B, Garber AM. The role of exercise testing in screening for coronary artery disease. Ann Intern Med. 1989;110(6):456-69. [pmid: 2493211].
18 Sox HC Jr, Garber AM, Littenberg B. The resting electrocardiogram as a screening test: a clinical analysis. Ann Intern Med. 1989;111(6):489-502. [pmid: 2528311].
19 American Academy of Family Physicians. Recommendations for clinical preventive services: coronary heart disease. Leawood, KS. American Academy of Family Physicians. 2004. Accessed at http://www.aafp.org/online/en/home/clinical/exam/coronaryheartdisease.html. 15 August 2011.
20 Lauer M, Froelicher ES, Williams M, Kligfield P. Exercise testing in asymptomatic adults: a statement for professionals from the American Heart Association Council on Clinical Cardiology, Subcommittee on Exercise, Cardiac Rehabilitation, and Prevention. Circulation. 2005;112(5):771-6. [pmid: 15998671].
21 Lim LS, Haq N, Mahmood S, Hoeksema L. Atherosclerotic cardiovascular disease screening in adults: American College of Preventive Medicine position statement on preventive practice. Am J Prev Med. 2011;40(3):381. [pmid: 21335273].
22 American College of Sports Medicine. ACSM’s Guidelines for Exercise Testing and Prescription. 6. Philadelphia. Lippincott Williams & Wilkins. 2000.
23 American Academy of Family Physicians. Family physician interpretation of electrocardiograms. Leawood, KS. American Academy of Family Physicians. 2007. Accessed at http://www.aafp.org/online/en/home/policy/policies/e/electrocardiogramsfamilyphysicianinterpretation.html. 15 August 2011.
24 U.S. Preventive Services Task Force. Procedure Manual. Rockville, MD. U.S. Preventive Services Task Force. 2008. Accessed at http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm. 15 August 2011.
25 Guirguis-Blake J, Calonge N, Miller T, et al. Current processes of the U.S. Preventive Services Task Force: refining evidence-based recommendation development. Ann Intern Med. 2007;147(2):117-22. [pmid: 17576998].
26 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
27 Grundy SM, Cleeman JI, Merz CN, et al. Implications of recent clinical trials for the National Cholesterol Education Program Adult Treatment Panel III guidelines. Circulation. 2004;110(2):227-39. [pmid: 15249516].
28 U.S. Preventive Services Task Force. Aspirin for the prevention of cardiovascular disease: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2009;150(6):396-404. [pmid: 19293072].
29 Chobanian AV, Bakris GL, Black HR, et al. The seventh report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report. JAMA. 2003;289(19):2560-72. [pmid: 12748199].
30 U.S. Preventive Services Task Force. Counseling and interventions to prevent tobacco use and tobacco-caused disease in adults and pregnant women: U.S. Preventive Services Task Force reaffirmation recommendation statement. Ann Intern Med. 2009;150(8):551-5. [pmid: 19380855].
31 McTigue KM, Harris R, Hemphill B, et al. Screening and interventions for obesity in adults: summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2003;139(11):933-49. [pmid: 14644897].
32 Cushman WC, Evans GW, Byington RP, et al. Accord Study Group. Effects of intensive blood-pressure control in type 2 diabetes mellitus. N Engl J Med. 2010;362(17):1575-85. [pmid: 20228401].
33 Pignone M, Phillips CJ, Atkins D, et al. Screening and treating adults for lipid disorders. Am J Prev Med. 2001;20(3 Suppl):77-89. [pmid: 11306236].
34 Wolff T, Miller T, Ko S. Aspirin for the primary prevention of cardiovascular events: an update of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2009;150(6):405-10. [pmid: 19293073].
35 Allen WH, Aronow WS, Goodman P, Stinson P. Five-year follow-up of maximal treadmill stress test in asymptomatic men and women. Circulation. 1980;62(3):522-7. [pmid: 7398012].
36 Blumenthal RS, Becker DM, Moy TF, et al. Exercise thallium tomography predicts future clinically manifest coronary heart disease in high-risk asymptomatic men. Circulation. 1996;93(5):915-23. [pmid: 8598082].
37 Cullen K, Stenhouse NS, Wearne KL, Cumpston GN. Electrocardiograms and 13 year cardiovascular mortality in Busselton study. Br Heart J. 1982;47(3):209-12. [pmid: 6174132].
38 Dunn FG, McLenachan J, Isles CG, et al. Left ventricular hypertrophy and mortality in hypertension: an analysis of data from the Glasgow Blood Pressure Clinic. J Hypertens. 1990;8(8):775-82. [pmid: 2170517].
39 Froelicher VF Jr, Thomas MM, Pillow C, Lancaster MC. Epidemiologic study of asymptomatic men screened by maximal treadmill testing for latent coronary artery disease. Am J Cardiol. 1974;34(7):770-6. [pmid: 4432807].
40 Gibbons LW, Mitchell TL, Wei M, Blair SN, Cooper KH. Maximal exercise test as a predictor of risk for mortality from coronary heart disease in asymptomatic men. Am J Cardiol. 2000;86(1):53-58. [pmid: 10867092].
41 Jones DW, Chambless LE, Folsom AR, et al. Risk factors for coronary heart disease in African Americans: the Atherosclerosis Risk in Communities study, 1987–1997. Arch Intern Med. 2002;162(22):2565-71. [pmid: 12456228].
42 Kannel WB, Abbott RD. A prognostic comparison of asymptomatic left ventricular hypertrophy and unrecognized myocardial infarction: the Framingham Study. Am Heart J. 1986;111(2):391-7. [pmid: 2936230].
43 Kannel WB, Anderson K, McGee DL, Degatano LS, Stampfer MJ. Nonspecific electrocardiographic abnormality as a predictor of coronary heart disease: the Framingham Study. Am Heart J. 1987;113(2 Pt 1):370-6. [pmid: 3812192].
44 Kannel WB, Cobb J. Left ventricular hypertrophy and mortality—results from the Framingham Study. Cardiology. 1992;81(4–5):291-8. [pmid: 1301257].
45 Katzel LI, Sorkin JD, Goldberg AP. Exercise-induced silent myocardial ischemia and future cardiac events in healthy, sedentary, middle-aged and older men. J Am Geriatr Soc. 1999;47(8):923-9. [pmid: 10443851].
46 Knutsen R, Knutsen SF, Curb JD, Reed DM, Kautz JA, Yano K. The predictive value of resting electrocardiograms for 12-year incidence of coronary heart disease in the Honolulu Heart Program. J Clin Epidemiol. 1988;41(3):293-302. [pmid: 3339383].
47 McHenry PL, O’Donnell J, Morris SN, Jordan JJ. The abnormal exercise electrocardiogram in apparently healthy men: a predictor of angina pectoris as an initial coronary event during long-term follow-up. Circulation. 1984;70(4):547-51. [pmid: 6478560].
48 Pedoe HD. Predictability of sudden death from resting electrocardiogram: effect of previous manifestations of coronary heart disease. Br Heart J. 1978;40(6):630-5. [pmid: 656237].
49 Rabkin SW, Mathewson FL, Tate RB. The electrocardiogram in apparently healthy men and the risk of sudden death. Br Heart J. 1982;47(6):546-52. [pmid: 6177327].
50 Reunanen A, Pyörälä K, Punsar S, Aromaa A. Predictive value of ECG findings with respect to coronary heart disease mortality. Adv Cardiol. 1978;21:310-2. [pmid: 619560].
51 Rose G, Baxter PJ, Reid DD, McCartney P. Prevalence and prognosis of electrocardiographic findings in middle-aged men. Br Heart J. 1978;40(6):636-43. [pmid: 656238].
52 Sullivan JM, Vander Zwaag RV, el-Zeky F, Ramanathan KB, Mirvis DM. Left ventricular hypertrophy: effect on survival. J Am Coll Cardiol. 1993;22(2):508-13. [pmid: 8335822].
53 Verdecchia P, Dovellini EV, Gorini M, et al. Comparison of electrocardiographic criteria for diagnosis of left ventricular hypertrophy in hypertension: the MAVI study. Ital Heart J. 2000;1(3):207-15. [pmid: 10806988].
54 Frolkis JP, Pothier CE, Blackstone EH, Lauer MS. Frequent ventricular ectopy after exercise as a predictor of death. N Engl J Med. 2003;348(9):781-90. [pmid: 12606732].
55 Hames CG, Rose K, Knowles M, Davis CE, Tyroler HA. Black-white comparisons of 20-year coronary heart disease mortality in the Evans County Heart Study. Cardiology. 1993;82(2–3):122-36. [pmid: 8324775].
56 Scott IA. Evaluating cardiovascular risk assessment for asymptomatic people. BMJ. 2009;338:a2844. [pmid: 19124547].
57 Janes H, Pepe MS, Gu W. Assessing the value of risk predictions by using risk stratification tables. Ann Intern Med. 2008;149(10):751-60. [pmid: 19017593].
58 Cook NR, Buring JE, Ridker PM. The effect of including C-reactive protein in cardiovascular risk prediction models for women. Ann Intern Med. 2006;145(1):21-9. [pmid: 16818925].
59 Cook NR. Statistical evaluation of prognostic versus diagnostic models: beyond the ROC curve. Clin Chem. 2008;54(1):17-23. [pmid: 18024533].
60 Pencina MJ, D’Agostino RB Sr, D’Agostino RB Jr, et al. Evaluating the added predictive ability of a new marker: from area under the ROC curve to reclassification and beyond. Stat Med. 2008;27(2):157-72. [pmid: 17569110].
61 Stern RH. Evaluating new cardiovascular risk factors for risk stratification. J Clin Hypertens. 2008;10(6):485-8.
62 Ohman EM, Granger CB, Harrington RA, Lee KL. Risk stratification and therapeutic decision making in acute coronary syndromes. JAMA. 2000;284(7):876-8. [pmid: 10938178].
63 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
64 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
65 Multiple Risk Factor Intervention Trial Research Group. Exercise electrocardiogram and coronary heart disease mortality in the Multiple Risk Factor Intervention Trial. Am J Cardiol. 1985;55(1):16-24. [pmid: 2857061].
66 Bodegard J, Erikssen G, Bjørnholt JV, et al. Symptom-limited exercise testing, ST depressions and long-term coronary heart disease mortality in apparently healthy middle-aged men. Eur J Cardiovasc Prev Rehabil. 2004;11(4):320-7. [pmid: 15292766].
67 Brown DW, Giles WH, Croft JB. Left ventricular hypertrophy as a predictor of coronary heart disease mortality and the effect of hypertension. Am Heart J. 2000;140(6):848-56. [pmid: 11099987].
68 Crow RS, Hannan PJ, Folsom AR. Prognostic significance of corrected QT and corrected JT interval for incident coronary heart disease in a general population sample stratified by presence or absence of wide QRS complex: the ARIC study with 13 years of follow-up. Circulation. 2003;108(16):1985-9. [pmid: 14517173].
69 Cuddy TE, Tate RB. Sudden unexpected cardiac death as a function of time since the detection of electrocardiographic and clinical risk factors in apparently healthy men: the Manitoba Follow-Up Study, 1948 to 2004. Can J Cardiol. 2006;22(3):205-11. [pmid: 16520850].
70 Daviglus ML, Liao Y, Greenland P, et al. Association of nonspecific minor ST-T abnormalities with cardiovascular mortality: the Chicago Western Electric Study. JAMA. 1999;281(6):530-6. [pmid: 10022109].
71 De Bacquer D, De Backer G, Kornitzer M, Blackburn H. Prognostic value of ECG findings for total, cardiovascular disease, and coronary heart disease death in men and women. Heart. 1998;80(6):570-7. [pmid: 10065025].
72 Denes P, Larson JC, Lloyd-Jones DM, Prineas RJ, Greenland P. Major and minor ECG abnormalities in asymptomatic women and risk of cardiovascular events and mortality. JAMA. 2007;297(9):978-85. [pmid: 17341712].
73 Dhingra R, Pencina MJ, Wang TJ, et al. Electrocardiographic QRS duration and the risk of congestive heart failure: the Framingham Heart Study. Hypertension. 2006;47(5):861-7. [pmid: 16585411].
74 Diercks GF, Hillege HL, van Boven AJ, et al. Microalbuminuria modifies the mortality risk associated with electrocardiographic ST-T segment changes. J Am Coll Cardiol. 2002;40(8):1401-7. [pmid: 12392828].
75 Gottdiener JS, Arnold AM, Aurigemma GP, et al. Predictors of congestive heart failure in the elderly: the Cardiovascular Health Study. J Am Coll Cardiol. 2000;35(6):1628-37. [pmid: 10807470].
76 Greenland P, Xie X, Liu K, et al. Impact of minor electrocardiographic ST-segment and/or T-wave abnormalities on cardiovascular mortality during long-term follow-up. Am J Cardiol. 2003;91(9):1068-74. [pmid: 12714148].
77 Macfarlane PW, Norrie J. WOSCOPS Executive Committee. The value of the electrocardiogram in risk assessment in primary prevention: experience from the West of Scotland Coronary Prevention Study. J Electrocardiol. 2007;40(1):101-9. [pmid: 17069838].
78 Jouven X, Empana JP, Schwartz PJ, et al. Heart-rate profile during exercise as a predictor of sudden death. JAMA. 2005;352(19):1951-8.
79 Kahn S, Frishman WH, Weissman S, Ooi WL, Aronson M. Left ventricular hypertrophy on electrocardiogram: prognostic implications from a 10-year cohort study of older subjects: a report from the Bronx Longitudinal Aging Study. J Am Geriatr Soc. 1996;44(5):524-9. [pmid: 8617900].
80 Larsen CT, Dahlin J, Blackburn H, et al. Prevalence and prognosis of electrocardiographic left ventricular hypertrophy, ST segment depression and negative T-wave; the Copenhagen City Heart Study. Eur Heart J. 2002;23(4):315-24. [pmid: 11812068].
81 Liao YL, Liu KA, Dyer A, et al. Major and minor electrocardiographic abnormalities and risk of death from coronary heart disease, cardiovascular diseases and all causes in men and women. J Am Coll Cardiol. 1988;12(6):1494-500. [pmid: 3192848].
82 Machado DB, Crow RS, Boland LL, et al. Electrocardiographic findings and incident coronary heart disease among participants in the Atherosclerosis Risk in Communities (ARIC) study. Am J Cardiol. 2006;97(8):1176-81. [pmid: 16616022].
83 Massing MW, Simpson RJ Jr, Rautaharju PM, et al. Usefulness of ventricular premature complexes to predict coronary heart disease events and mortality (from the Atherosclerosis Risk In Communities cohort). Am J Cardiol. 2006;98(12):1609-12. [pmid: 17145219].
84 Menotti A, Mulder I, Kromhout D, et al. The association of silent electrocardiographic findings with coronary deaths among elderly men in three European countries: the FINE study. Acta Cardiol. 2001;56(1):27-36. [pmid: 11315121].
85 Menotti A, Seccareccia F. Electrocardiographic Minnesota code findings predicting short-term mortality in asymptomatic subjects: the Italian RIFLE pooling project (risk factors and life expectancy). G Ital Cardiol. 1997;27(1):40-9. [pmid: 9199942].
86 Möller CS, Häggström J, Zethelius B, et al. Age and follow-up time affect the prognostic value of the ECG and conventional cardiovascular risk factors for stroke in adult men. J Epidemiol Community Health. 2007;61(8):704-12. [pmid: 17630370].
87 Prineas RJ, Rautaharju PM, Grandits G, Crow R. Independent risk for cardiovascular disease predicted by modified continuous score electrocardiographic criteria for 6-year incidence and regression of left ventricular hypertrophy among clinically disease free men: 16-year follow-up for the Multiple Risk Factor Intervention Trial. J Electrocardiol. 2001;34(2):91-101. [pmid: 11320456].
88 Prineas RJ, Grandits G, Rautaharju PM, et al. Long-term prognostic significance of isolated minor electrocardiographic T-wave abnormalities in middle-aged men free of clinical cardiovascular disease (the Multiple Risk Factor Intervention Trial [MRFIT]). Am J Cardiol. 2002;90(12):1391-5. [pmid: 12480053].
89 Rautaharju PM, Ge S, Nelson JC, et al. Comparison of mortality risk for electrocardiographic abnormalities in men and women with and without coronary heart disease (from the Cardiovascular Health Study). Am J Cardiol. 2006;97(3):309-15. [pmid: 16442387].
90 Rautaharju PM, Kooperberg C, Larson JC, LaCroix A. Electrocardiographic abnormalities that predict coronary heart disease events and mortality in postmenopausal women: the Women’s Health Initiative. Circulation. 2006;113(4):473-80. [pmid: 16449726].
91 Rautaharju PM, Kooperberg C, Larson JC, et al. Electrocardiographic predictors of incident congestive heart failure and all-cause mortality in postmenopausal women: the Women’s Health Initiative. Circulation. 2006;113(4):481-9. [pmid: 16449727].
92 Sigurdsson E, Sigfusson N, Sigvaldason H, Thorgeirsson G. Silent ST-T changes in an epidemiologic cohort study—a marker of hypertension or coronary heart disease, or both: the Reykjavik Study. J Am Coll Cardiol. 1996;27(5):1140-7. [pmid: 8609333].
93 Sutherland SE, Gazes PC, Keil JE, Gilbert GE, Knapp RG. Electrocardiographic abnormalities and 30-year mortality among white and black men of the Charleston Heart Study. Circulation. 1993;88(6):2685-92. [pmid: 8252679].
94 Adabag AS, Grandits GA, Prineas RJ, et al. Relation of heart rate parameters during exercise test to sudden death and all-cause mortality in asymptomatic men. Am J Cardiol. 2008;101(10):1437-43. [pmid: 18471455].
95 Aktas MK, Ozduran V, Pothier CE, Lang R, Lauer MS. Global risk scores and exercise testing for predicting all-cause mortality in a preventive medicine program. JAMA. 2004;292(12):1462-8. [pmid: 15383517].
96 Balady GJ, Larson MG, Vasan RS, et al. Usefulness of exercise testing in the prediction of coronary disease risk among asymptomatic persons as a function of the Framingham risk score. Circulation. 2004;110(14):1920-5. [pmid: 15451778].
97 Blair SN, Kampert JB, Kohl HW 3rd, et al. Influences of cardiorespiratory fitness and other precursors on cardiovascular disease and all-cause mortality in men and women. JAMA. 1996;276(3):205-10. [pmid: 8667564].
98 Cole CR, Foody JM, Blackstone EH, Lauer MS. Heart rate recovery after submaximal exercise testing as a predictor of mortality in a cardiovascularly healthy cohort. Ann Intern Med. 2000;132(7):552-5. [pmid: 10744592].
99 Cournot M, Taraszkiewicz D, Galinier M, et al. Is exercise testing useful to improve the prediction of coronary events in asymptomatic subjects?. Eur J Cardiovasc Prev Rehabil. 2006;13(1):37-44. [pmid: 16449862].
100 Ekelund LG, Suchindran CM, McMahon RP, et al. Coronary heart disease morbidity and mortality in hypercholesterolemic men predicted from an exercise test: the Lipid Research Clinics Coronary Primary Prevention Trial. J Am Coll Cardiol. 1989;14(3):556-63. [pmid: 2768706].
101 Fleg JL, Gerstenblith G, Zonderman AB, et al. Prevalence and prognostic significance of exercise-induced silent myocardial ischemia detected by thallium scintigraphy and electrocardiography in asymptomatic volunteers. Circulation. 1990;81(2):428-36. [pmid: 2297853].
102 Giagnoni E, Secchi MB, Wu SC, et al. Prognostic value of exercise EKG testing in asymptomatic normotensive subjects: a prospective matched study. N Engl J Med. 1983;309(18):1085-9. [pmid: 6621650].
103 Gordon DJ, Ekelund LG, Karon JM, et al. Predictive value of the exercise tolerance test for mortality in North American men: the Lipid Research Clinics Mortality Follow-up Study. Circulation. 1986;74(2):252-61. [pmid: 3731417].
104 Gulati M, Arnsdorf MF, Shaw LJ, et al. Prognostic value of the Duke treadmill score in asymptomatic women. Am J Cardiol. 2005;96(3):369-75. [pmid: 16054460].
105 Gulati M, Pandey DK, Arnsdorf MF, et al. Exercise capacity and the risk of death in women: the St James Women Take Heart Project. Circulation. 2003;108(13):1554-9. [pmid: 12975254].
106 Josephson RA, Shefrin E, Lakatta EG, Brant LJ, Fleg JL. Can serial exercise testing improve the prediction of coronary events in asymptomatic individuals?. Circulation. 1990;81(1):20-4. [pmid: 2297826].
107 Jouven X, Ducimetiere P. Long-term outcome in asymptomatic men with exercise-induced premature ventricular depolarizations. N Engl J Med. 2000;343(12):826-32. [pmid: 10995861].
108 Kurl S, Laukkanen JA, Tuomainen TP, et al. Association of exercise-induced, silent ST-segment depression with the risk of stroke and cardiovascular diseases in men. Stroke. 2003;34(7):1760-5. [pmid: 12829872].
109 Kurl S, Sivenius J, Mäkikallio TH, Rauramaa R, Laukkanen JA. Exercise workload, cardiovascular risk factor evaluation and the risk of stroke in middle-aged men. J Intern Med. 2009;265(2):229-37. [pmid: 18793247].
110 Lauer MS, Okin PM, Larson MG, Evans JC, Levy D. Impaired heart rate response to graded exercise: prognostic implications of chronotropic incompetence in the Framingham Heart Study. Circulation. 1996;93(8):1520-6. [pmid: 8608620].
111 Laukkanen JA, Kurl S, Lakka TA, et al. Exercise-induced silent myocardial ischemia and coronary morbidity and mortality in middle-aged men. J Am Coll Cardiol. 2001;38(1):72-9. [pmid: 11451298].
112 Laukkanen JA, Kurl S, Rauramaa R, et al. Systolic blood pressure response to exercise testing is related to the risk of acute myocardial infarction in middle-aged men. Eur J Cardiovasc Prev Rehabil. 2006;13(3):421-8. [pmid: 16926673].
113 Laukkanen JA, Rauramaa R, Kurl S. Exercise workload, coronary risk evaluation and the risk of cardiovascular and all-cause death in middle-aged men. Eur J Cardiovasc Prev Rehabil. 2008;15(3):285-92. [pmid: 18525382].
114 Lyerly GW, Sui X, Church TS, et al. Maximal exercise electrocardiography responses and coronary heart disease mortality among men with diabetes mellitus. Circulation. 2008;117(21):2734-42. [pmid: 18490521].
115 Lyerly GW, Sui X, Lavie CJ, et al. The association between cardiorespiratory fitness and risk of all-cause mortality among women with impaired fasting glucose or undiagnosed diabetes mellitus. Mayo Clin Proc. 2009;84(9):780-6. [pmid: 19720775].
116 Mora S, Redberg RF, Cui Y, et al. Ability of exercise testing to predict cardiovascular and all-cause death in asymptomatic women: a 20-year follow-up of the Lipid Research Clinics Prevalence Study. JAMA. 2003;290(12):1600-7. [pmid: 14506119].
117 Mora S, Redberg RF, Sharrett AR, Blumenthal RS. Enhanced risk assessment in asymptomatic individuals with exercise testing and Framingham risk scores. Circulation. 2005;112(11):1566-72. [pmid: 16144993].
118 Morshedi-Meibodi A, Larson MG, Levy D, O’Donnell CJ, Vasan RS. Heart rate recovery after treadmill exercise testing and risk of cardiovascular disease events (the Framingham Heart Study). Am J Cardiol. 2002;90(8):848-52. [pmid: 12372572].
119 Okin PM, Anderson KM, Levy D, Kligfield P. Heart rate adjustment of exercise-induced ST segment depression: improved risk stratification in the Framingham Offspring Study. Circulation. 1991;83(3):866-74. [pmid: 1999037].
120 Okin PM, Grandits G, Rautaharju PM, et al. Prognostic value of heart rate adjustment of exercise-induced ST segment depression in the Multiple Risk Factor Intervention Trial. J Am Coll Cardiol. 1996;27(6):1437-43. [pmid: 8626955].
121 Peters RK, Cady LD Jr, Bischoff DP, Bernstein L, Pike MC. Physical fitness and subsequent myocardial infarction in healthy workers. JAMA. 1983;249(22):3052-6. [pmid: 6854827].
122 Rautaharju PM, Prineas RJ, Eifler WJ, et al. Prognostic value of exercise electrocardiogram in men at high risk of future coronary heart disease: Multiple Risk Factor Intervention Trial experience. J Am Coll Cardiol. 1986;8(1):1-10. [pmid: 3711503].
123 Rutter MK, Wahid ST, McComb JM, Marshall SM. Significance of silent ischemia and microalbuminuria in predicting coronary events in asymptomatic patients with type 2 diabetes. J Am Coll Cardiol. 2002;40(1):56-61. [pmid: 12103256].
124 Rywik TM, Zink RC, Gittings NS, et al. Independent prognostic significance of ischemic ST-segment response limited to recovery from treadmill exercise in asymptomatic subjects. Circulation. 1998;97(21):2117-22. [pmid: 9626171].
125 Rywik TM, O’Connor FC, Gittings NS, et al. Role of nondiagnostic exercise-induced ST-segment abnormalities in predicting future coronary events in asymptomatic volunteers. Circulation. 2002;106(22):2787-92. [pmid: 12451004].
126 Savonen KP, Lakka TA, Laukkanen JA, et al. Effectiveness of workload at the heart rate of 100 beats/min in predicting cardiovascular mortality in men aged 42, 48, 54, or 60 years at baseline. Am J Cardiol. 2007;100(4):563-8. [pmid: 17697806].
127 Siscovick DS, Ekelund LG, Johnson JL, Truong Y, Adler A. Sensitivity of exercise electrocardiography for acute cardiac events during moderate and strenuous physical activity: the Lipid Research Clinics Coronary Primary Prevention Trial. Arch Intern Med. 1991;151(2):325-30. [pmid: 1992960].
128 Slattery ML, Jacobs DR. Physical fitness and cardiovascular disease mortality. Am J Epidemiol. 1988;127(3):571-80. [pmid: 3341361].
129 Sui X, LaMonte MJ, Blair SN. Cardiorespiratory fitness as a predictor of nonfatal cardiovascular events in asymptomatic women and men. Am J Epidemiol. 2007;165(12):1413-23. [pmid: 17406007].
130 Moller CS, Byberg L, Sundstrom J, Lind L. T wave abnormalities, high body mass index, current smoking and high lipoprotein(a) levels predict the development of major abnormal Q/QS patterns 20 years later: a population-based study. BMC Cardiovasc Disord. 2006;6:10. [pmid: 16519804].
131 Laukkanen JA, Kurl S, Salonen JT, Lakka TA, Rauramaa R. Peak oxygen pulse during exercise as a predictor for coronary heart disease and all cause death. Heart. 2006;92(9):1219-24. [pmid: 16467459].
132 Hollenberg M, Zoltick JM, Go M, et al. Comparison of a quantitative treadmill exercise score with standard electrocardiographic criteria in screening asymptomatic young men for coronary artery disease. N Engl J Med. 1985;313(10):600-6. [pmid: 4022047].
133 Myers J, Arena R, Franklin B, et al. Recommendations for clinical exercise laboratories: a scientific statement from the American Heart Association. Circulation. 2009;119(24):3144-61. [pmid: 19487589].
134 Blumenthal RS, Becker DM, Yanek LR, et al. Detecting occult coronary disease in a high-risk asymptomatic population. Circulation. 2003;107(5):702-7. [pmid: 12578872].
135 Boyle RM, Adlakha HL, Mary DA. Diagnostic value of the maximal ST segment/heart rate slope in asymptomatic factory populations. J Electrocardiol. 1987;20(Suppl):128-34. [pmid: 3320257].
136 Davies B, Ashton WD, Rowlands DJ, et al. Association of conventional and exertional coronary heart disease risk factors in 5,000 apparently healthy men. Clin Cardiol. 1996;19(4):303-8. [pmid: 8706370].
137 Dunn RL, Matzen RN, VanderBrug-Medendorp S. Screening for the detection of coronary artery disease by using the exercise tolerance test in a preventive medicine population. Am J Prev Med. 1991;7(5):255-62. [pmid: 1790029].
138 Livschitz S, Sharabi Y, Yushin J, et al. Limited clinical value of exercise stress test for the screening of coronary artery disease in young, asymptomatic adult men. Am J Cardiol. 2000;86(4):462-4. [pmid: 10946046].
139 Massie BM, Szlachcic Y, Tubau JF, et al. Scintigraphic and electrocardiographic evidence of silent coronary artery disease in asymptomatic hypertension: a case-control study. J Am Coll Cardiol. 1993;22(6):1598-606. [pmid: 8227826].
140 Piepgrass SR, Uhl GS, Hickman JR Jr, Hopkirk JA, Plowman K. Limitations of the exercise stress test in the detection of coronary artery disease in apparently healthy men. Aviat Space Environ Med. 1982;53(4):379-82. [pmid: 7082255].
141 Pilote L, Pashkow F, Thomas JD, et al. Clinical yield and cost of exercise treadmill testing to screen for coronary artery disease in asymptomatic adults. Am J Cardiol. 1998;81(2):219-24. [pmid: 9591907].
142 Noto TJ Jr, Johnson LW, Krone R, et al. Cardiac catheterization 1990: a report of the Registry of the Society for Cardiac Angiography and Interventions (SCA&I). Cathet Cardiovasc Diagn. 1991;24(2):75-83. [pmid: 1742788].
143 Fazel R, Krumholz HM, Wang Y, et al. Exposure to low-dose ionizing radiation from medical imaging procedures. N Engl J Med. 2009;361(9):849-57. [pmid: 19710483].
144 Patel MR, Peterson ED, Dai D, et al. Low diagnostic yield of elective coronary angiography. N Engl J Med. 2010;362(10):886-95. [pmid: 20220183].
145 Kligfield P, Lauer MS. Exercise electrocardiogram testing: beyond the ST segment. Circulation. 2006;114(19):2070-82. [pmid: 17088475].
146 Paul O, Lepper MH, Phelan WH, et al. A longitudinal study of coronary heart disease. Circulation. 1963;28:20-31. [pmid: 13941964].
147 Furberg CD, Manolio TA, Psaty BM, et al. Major electrocardiographic abnormalities in persons aged 65 years and older (the Cardiovascular Health Study). Am J Cardiol. 1992;69(16):1329-35. [pmid: 1585868].
148 The ARIC Investigators. The Atherosclerosis Risk in Communities (ARIC) study: design and objectives. Am J Epidemiol. 1989;129(4):687-702. [pmid: 2646917].
149 The RIFLE Research Group. Presentation of the RIFLE project risk factors and life expectancy. Eur J Epidemiol. 1993;9(5):459-76. [pmid: 8307130].
150 Cupples LA, D’Agostino RB. Survival following initial cardiovascular events: 30-year follow-up. Framingham Heart Study, Section 35. Kannel WB, Wolf PA, Garrison RJ, editors. The Framingham Study: An Epidemiological Investigation of Cardiovascular Disease. Bethesda, MD. National Heart, Lung, and Blood Institute. 1988.
151 Wei M, Kampert JB, Barlow CE, et al. Relationship between low cardiorespiratory fitness and mortality in normal weight, overweight and obese men. JAMA. 1999;282(16):1547-53. [pmid: 10546694].
152 Filipovsky J, Ducimetiere P, Safar M. Prognostic significance of exercise blood pressure and heart rate in middle-aged men. Hypertension. 1992;20(3):333-9. [pmid: 1387630].
153 Rutter MK, McComb JM, Brady S, Marshall SM. Silent myocardial ischemia and microalbuminuria in asymptomatic subjects with non-insulin-dependent diabetes mellitus. Am J Cardiol. 1999;83(1):27-31. [pmid: 10073780].
154 The Lipid Research Clinics Coronary Primary Prevention Trial results, I: reduction in incidence of coronary heart disease. JAMA. 1984;251(3):351-64. [pmid: 6361299].
155 Women’s Health Initiative Study Group. Design of the Women’s Health Initiative clinical trial and observational study. Control Clin Trials. 1998;19(1):61-109. [pmid: 9492970].
156 Menotti A, Kromhout D, Nissinen A, et al. Short-term all-cause mortality and its determinants in elderly male populations in Finland, the Netherlands, and Italy: the FINE Study. Prev Med. 1996;25(3):319-26. [pmid: 8781010].