# Results

## Key Question 1 What are the Benefits of Screening for Abnormalities With Resting or Exercise Electrocardiography Compared With No Screening on Coronary Heart Disease Outcomes?

### Summary

We identified no randomized controlled trials or controlled observational studies that reported clinical outcomes of screening for CHD with resting or exercise ECG compared with no screening in asymptomatic adults.

### Evidence

Like the previous USPSTF review,7 we found no randomized controlled trials or controlled observational studies on the effects on clinical outcomes of screening asymptomatic adults for CHD with resting or exercise ECG versus no screening. The prior USPSTF review discussed a subgroup analysis from the Multiple Risk Factor Intervention Trial (MRFIT)65 that found that subjects with an abnormal ETT who underwent risk factor modification experienced better outcomes compared with those who underwent usual care. However, these findings are not directly applicable to this key question, as they do not address the effects of screening versus no screening.

## Key Question 2 How Does the Identification of High-Risk Persons Via Resting or Exercise Electrocardiography Affect Use of Treatments to Reduce Cardiovascular Risk?

### Summary

We identified no studies that evaluated how screening individuals using resting or exercise ECG affects use of interventions (e.g., lipid-lowering therapy or aspirin) to reduce cardiovascular risk.

### Evidence

Abnormalities on resting or exercise ECG could identify patients who might benefit from interventions to reduce cardiovascular risk, such as lipid-lowering therapy or aspirin. However, like the previous USPSTF review,7 we identified no studies that evaluated how screening affects use of such interventions.

## Key Question 3 What is the Accuracy of Resting or Exercise Electrocardiography for Stratifying Persons Into High-, Intermediate-, and Low-Risk Groups?

### Summary

Twenty-seven prospective cohort studies (10 rated good quality) with over 170,000 subjects evaluated resting ECG abnormalities66–93 and 38 prospective cohort studies (19 rated good quality) with over 90,000 subjects evaluated exercise ECG abnormalities as predictors of subsequent cardiovascular events,66,78,94–129 after adjusting for traditional risk factors. No study estimated how accurately resting or exercise ECG plus traditional risk factor assessment classified subjects into high-, intermediate-, or low-risk groups compared with classification based on traditional risk factor assessment alone, or provided data to enable the construction of risk stratification tables. One study each reported that resting or exercise ECG findings plus traditional risk factor assessment resulted in a slight increase in discrimination (based on the C statistic) compared with traditional risk factor assessment alone.

Pooled analyses showed that abnormalities on resting (ST segment abnormalities, T wave abnormalities, ST segment or T wave abnormalities, LVH, bundle branch block, left axis deviation) or exercise (ST segment depression with exercise, failure to reach maximum target heart rate) ECG were associated with an increased risk (pooled hazard ratio [HR] estimates from 1.4 to 2.1) of subsequent cardiovascular events, after adjusting for traditional risk factors (Table 1). Statistical heterogeneity was present in a number of analyses, but stratification of studies by method of defining the ECG abnormality, study quality, or the type of cardiovascular events evaluated did not reduce heterogeneity and resulted in similar estimates. Meta-regression analyses also showed no effect on estimates based on differential duration of followup, number of Framingham risk factors adjusted for in the analysis, or proportion of male subjects. Low exercise capacity or physical fitness during exercise ECG was also associated with increased risk of subsequent cardiovascular events or all-cause mortality, with hazard ratio estimates ranging from 1.7 to 3.1, but data could not be pooled.

Table 1 Summary of Pooled Risk Estimates for Resting or Exercise ECG Abnormalities and Subsequent Cardiovascular Events

Resting ECG abnormality | Number of studies (references) | Pooled adjusted HR (95% CI); Heterogeneity | Exercise ECG abnormality | Number of studies (references) | Pooled adjusted HR (95% CI); Heterogeneity
ST segment abnormalities | 5 (69, 71, 76, 80, 82) | 1.9 (1.4–2.5); I^2^=62% | ST depression with exercise | 12 (66, 95, 96, 99, 100, 102, 103, 107, 113, 120, 125, 166) | 2.1 (1.6–2.9); I^2^=71%
T wave abnormalities | 6 (80, 69, 71, 76, 82, 88) | 1.6 (1.3–1.8); I^2^=56% | Chronotropic incompetence | 4 (94, 96, 110, 116) | 1.4 (1.3–1.6); I^2^=0%
ST or T wave abnormalities | 7 (70, 74, 76, 84, 85, 92, 93) | 1.9 (1.6–2.4); I^2^=50% | Abnormal heart rate recovery^*^ | 3 (95, 98, 118) | 1.5 (1.3–1.9); I^2^=0%
Left ventricular hypertrophy | 8 (66, 67, 71, 79, 80, 82, 84, 93) | 1.6 (1.3–2.0); I^2^=46% | Decreased exercise capacity or fitness | 6 (95, 97, 105, 113, 121, 129) | Range, 1.7–3.1 (could not be pooled)
Bundle branch block | 4 (71, 82, 84, 85) | 1.5 (0.98–2.3); I^2^=46%
Left axis deviation | 3 (71, 84, 93) | 1.5 (1.1–1.9); I^2^=0%

* Estimate is for all-cause mortality; cardiovascular-specific outcomes could not be pooled.

Abbreviations: CI=confidence interval; ECG=electrocardiography; HR=hazard ratio.

### Evidence: Resting ECG

Twenty-seven prospective cohort studies of resting ECG met inclusion criteria (Table 2).66–93 Two studies evaluated both resting and exercise ECG abnormalities.66,78 Three studies reported results from the Atherosclerosis Risk in Community study,68,82,83 two studies (reported in three publications) reported results from the Women’s Health Initiative,72,90,91 two studies reported results from the Chicago Heart Association Detection Project in Industry,76,81 and two studies reported results from the Cardiovascular Health Study.75,89 Excluding double-counted populations, the studies evaluated a total of 173,710 subjects. Duration of followup ranged from 3^74^ to 56 years69 for resting ECG.

Table 2 Cohort Studies of Resting ECG Abnormalities as Predictors of Cardiovascular Events

Author, year | Study name Country Population | Sample size Demographics | ECG abnormalities evaluated; Prevalence | Mean followup (yrs) | Framingham risk factors adjusted | All-cause mortality and incident cardiovascular events | Quality
Bodegard et al, 2004^66^ | Study not named Norway Work volunteers | n=2,014 Mean age: 50 yrs (range, 40–59) 100% male Race NR | LVH: 5.3% | 22 | Age, sex, smoking, SBP, total cholesterol | CHD death: 15% All-cause mortality: 37% Acute MI: 19% Coronary artery bypass graft surgery: 6.0% Stroke: 7.7% | Good
Brown et al, 2000^67^ | Second National Health and Nutrition Examination Survey (NHANES II) United States General community | n=7,924 Mean age: 49 yrs (range, 25–74) 48% male 90% white 10% black | LVH: 1.9% | 15 | Sex, smoking, diabetes, SBP, total cholesterol | CHD death: 3.7% Heart disease death: 5.3% | Fair
Crow et al, 2003^68^ | Atherosclerosis Risk in Community (ARIC) Study United States General community | n=14,696 Mean age: 54 yrs (range, 45–64) 43% male 73% white | QTc: continuous variable JTc: continuous variable Wide QRS complex: 3.1% | 13 | Age, sex, smoking, diabetes, SBP, HDL, LDL | Incident MI or fatal CHD event: 5.6% | Fair
Cuddy et al, 2006^69^ Other sources: www.mfus.ca | Manitoba Follow-Up Study Canada Royal Canadian Air Force recruits | n=3,983 Mean age: 31 yrs (range, 20–39) 100% male Race NR | Atrial fibrillation: 7% VPC: 23% Atrioventricular block: 12% Right bundle branch block: 5% Left bundle branch block: 2% LVH: 12% ST and T wave abnormality: 22% (ST), 37% (T wave) | 56 | Age, sex (100% male), smoking, diabetes, SBP, DBP | Sudden unexpected cardiac death: 4.3% | Fair
Daviglus et al, 1999^70^ Other publications: Oglesby, 1963^146^ | Chicago Western Electric Study United States Male electric company workers | n=1,673 Mean age: 47 yrs (range, 40–55) 100% male Race NR | Minor ST-T abnormality: 10.3% | 29 | Age, sex (100% male), smoking, SBP, total cholesterol | CHD death: 21% MI death: 14% CVD death: 28% All-cause mortality: 53% | Fair
De Bacquer et al, 1998^71^ | Belgian Inter-University Research on Nutrition and Health (BIRNH) Study Belgium General community | n=9,954 Mean age: 48 yrs (range, 25–74) 52% male Race NR | Any ECG abnormality: 29% Major ECG abnormality: 29% Minor ECG abnormality: 3.6% Ischemic ECG abnormality: 10% ST depression: 2% Abnormal T wave: 8% Arrhythmia: 6% Bundle branch block: 1% LVH: 0.6% Left axis deviation: 4% | 10 | Age, sex, smoking, diabetes, SBP, HDL, LDL, total cholesterol | CHD death: 1.3% CVD death: 2.4% All-cause mortality: 7.9% | Good
Denes et al, 2007^72^ | Women’s Health Initiative United States Clinical trial enrollees | n=14,749 Mean age: 63 yrs (range, 50–79) 0% male 84% white | Major ECG abnormality: 6.2% Minor ECG abnormality: 28% | 5.2 | Age, sex (100% female), smoking, diabetes, hypertension, statin use | CHD events: 4.0% CVD events: 1.7% | Good
Dhingra et al, 2006^73^ | Framingham Heart Study United States General community | n=1,759 Mean age: 70 yrs (SD, 7) 37% male Race NR | QRS duration 100–119 ms (incomplete bundle branch block): 17% QRS duration ≥120 ms (complete bundle branch block): 6% | 12.7 | Age, sex, smoking, diabetes, hypertension, HDL, total cholesterol | CHF: 18% (men, 18%; women, 19%) | Good
Diercks et al, 2002^74^ | Prevention of Renal and Vascular End-Stage Disease Study The Netherlands General community | n=7,330 Mean age: 48 yrs (range, 28–75) 50% male Race NR | ST-T changes: 17% | 3 | Age, sex, smoking, diabetes, hypertension, total cholesterol | CVD death: 0.3% All-cause mortality: 1.2% | Fair
Gottdiener et al, 2000^75^ Other publications: Furberg et al, 1992^147^ | Cardiovascular Health Study United States General community | n=4,652 (analyzed group with no prevalent CHD) Mean age: 73 yrs (range, 65–100; entire cohort, including prevalent CHD) 40% male 85% nonblack | Major Q/QS wave: 5.2% LVH: 4.2% Isolated major ST-T wave abnormality: 6.3% Atrial fibrillation: 3.2% Atrioventricular block: 5.3% Ventricular conduction defect: 8.7% (based on entire study cohort) | 6.3 | Age, sex, smoking, diabetes, hypertension, HDL, LDL, total cholesterol | CHF: 8.5% | Good
Greenland et al, 2003^76^ | Chicago Heart Association Detection Project in Industry United States Work-based | n=17,615 Mean age: 50 yrs (range, 40–64) 55% male 95% white | Any ST changes: 3.6% men; 5.4% women Minor T wave abnormality: 1.6% men; 1.9% women Minor ST depression: 1.2% men; 1.5% women | 22 | Age, sex, smoking, blood glucose, SBP, total cholesterol | CHD death: 7.1% CVD death: 9.9% | Fair
Jouven et al, 2005^78^ | Paris Protective Study I France Civil servants | n=5,713 Mean age: 48 yrs (range, 42–53) 100% male Race NR | High (>75 bpm) resting heart rate: 8% | 23 | Age, sex (100% male), smoking, diabetes, SBP, cholesterol | Fatal MI (sudden death): 1.4% Fatal MI (nonsudden death): 2.3% All-cause mortality: 27% | Good
Kahn et al, 1996^79^ | Bronx Longitudinal Aging Study United States General community | n=459 Mean age: 79 yrs (range, 75–85) 35% male >95% white | LVH: 9.2% | 10 | Age, sex, smoking, hypertension, total cholesterol | CVD death: 19% MI death: 16% All-cause mortality: 34% Cerebrovascular accident mortality: 3.3% All cardiovascular disease: 56% Fatal or nonfatal MI: 14% Fatal or nonfatal cerebrovascular accident: 7.6% | Fair
Larsen et al, 2002^80^ | Copenhagen City Heart Study Denmark General community | n=10,982 Mean age: 54 yrs (range, 35–74) 45% male >98% white | LVH: 11% T wave inversion: 3.4% ST-T depression and T wave inversion: 0.7% LVH + T wave inversion: 0.8% LVH + ST-T depression + T wave inversion: 0.7% | 21 | Age, sex, smoking, diabetes, SBP, total cholesterol | CVD death: 18% Fatal or nonfatal MI: 10% Fatal or nonfatal CHD events: 19% | Good
Liao et al, 1988^81^ | Chicago Heart Association Detection Project in Industry United States Work-based | n=17,633 Mean age: 51 yrs 55% male 100% white | Major abnormality: 11.1% Minor abnormality: 6% Any abnormality: 17.5% | 11.5 | Age, sex, smoking, diabetes, DBP, total cholesterol | CHD death: 2.9% Cardiovascular death: 3.8% All-cause mortality: 7.8% | Fair
Macfarlane et al, 2007^77^ | West of Scotland Coronary Prevention Study (WOSCOPS) United Kingdom | n=6,595 Mean age: 55 yrs 100% male Race NR | [underlined: Left axis deviation] MN code 2.1: 2.7% [underlined: Right axis deviation] MN code 2.2 or 2.3: 0.5% [underlined: High voltage left ventricular lead] MN code 3.1: 5.1% [underlined: High voltage right ventricular lead] MN code 3.2: 0.06% [underlined: ST abnormality] MN code 4.2 or 4.3: 2.3% [underlined: T wave abnormality] MN code 5.2 or 5.3: 7.9% [underlined: Right bundle branch block] MN code 7.2.1 or 7.8: 1% [underlined: Definite or probable LVH] MN code 3.1 + ST or T wave abnormalities: 0.6%; 0.3% [underlined: Possible LVH] MN code 3.1 or 3.3: 7.3% [underlined: Minor ECG abnormality] MN code 4.2, 4.3, 5.2, or 5.3: 8.2% [underlined: T wave inversion] T wave amplitude <0 mV: 2.6% | 4.9 yrs | Age, sex (100% male), smoking, diabetes, hypertension, HDL, total cholesterol | Definite MI: 5.4% Suspected MI:1.5% All-cause mortality: NR | Fair
Machado et al, 2006^82^ Other publications: ARIC investigators 1989^148^ | Atherosclerosis Risk in Communities (ARIC) Study United States General community | n=12,987 Mean age: 54 yrs (range, 45–64) 43% male 74% white | Minor Q wave: 2% Prolonged QTc interval: 9% LVH (Cornell): 2% LVH (ST-T strain pattern): 2% Major ventricular conduction defect: 2% Major ST depression: <1% Minor ST depression: 1% ST elevation: 1% Major T wave findings: 4% Any ECG abnormality: 18.1% | 11.6 | Age, sex, smoking, diabetes, SBP, DBP, HDL, LDL | Incident CHD: 5.6% | Fair
Massing et al, 2006^83^ | Atherosclerosis Risk in Communities (ARIC) Study United States General community | n=15,070 Mean age: 54 yrs (range, 45–64) 45% male 74% white | Ventricular premature contractions: 6.2% | >10 (11.6 in other ARIC publications) | Age, sex, smoking, diabetes, hypertension, HDL, LDL | [underlined: Asymptomatic population] CHD death: 1.6% CHD events: 9.6% All-cause mortality: 10.5% | Fair
Menotti et al, 1997^85^ Other publications: RIFLE Research Group, 1993^149^ | Risk Factors and Life Expectancy (RIFLE) Study Italy General community | n=22,553 Mean age NR (50% 50–69 yrs) 54% male Race NR | Q-QS wave: 0.8% ST-T changes: 5.7% High R wave: 4.7% Arrhythmia: 1.2% Bundle branch block: 1.2% | 6 | Age, sex, smoking, SBP, total cholesterol | [underlined: All-cause mortality (by subgroup)] Q-QS: 1.6% ST-T: 1.6% High R wave: 0.9% Arrythmia: 1.5% Block: 1.3% | Fair
Menotti et al, 2001^84^ Other publications: Menotti et al, 1996^156^ | FINE Study Finland, the Netherlands, and Italy General community | n=1,785 Mean age NR (range, 65–84 yrs) 100% male Race NR | Q-QS wave: 6.8% ST-T abnormality: 22% High R wave: 15% Left axis deviation: 13% Arrhythmia: 8.5% Bundle branch block: 7.3% Major abnormality: 8.3% Minor abnormality: 39% | 10 | Age, sex (100% male), smoking hypertension, total cholesterol | CHD death: 9% | Fair
Moller et al, 2007^86^ | Uppsala Longitudinal Study of Adult Men Sweden General community | n=2,322 Age: 50 yrs (all were age 50 at enrollment) 100% male Race NR | Q/QS wave pattern: 1.3% LVH: 1.2% ST segment depression: 2.3% T wave abnormality: 5.9% Atrial fibrillation: 0.3% | NR; followup >20 yrs, max 32 | Age, sex (100% male), smoking, diabetes, hypertension, HDL, LDL | Fatal and nonfatal stroke: 15% Fatal and nonfatal ischemic stroke: 10% | Fair
Prineas et al, 2001^87^ | Multiple Risk Factor Intervention Trial (MRFIT) United States Clinical trial enrollees | n=12,866 Mean age: 46 yrs (range, 35–57), based on entire cohort 100% male 93% white | New (incident) LVH on 6-yr followup ECG based on various criteria: Sokolow-Lyon: 6% Cornell voltage: 1% Cornell product: 2% Novacode: 5% MN code 3.1 or 3.3 + 5.1, 5.2, or 5.3: 4% Significant increase in LVH on 6-yr followup ECG based on various criteria: Sokolow-Lyon: 0.5% Cornell voltage: 3.5% Cornell product: 2.8% Novacode: 1.4% ∑12 product (sum of peak-to-peak amplitudes of QRS complexes except lead avR, × QRS duration): 0.8% | 16 | Age, sex (100% male), DBP, total cholesterol, smoking | CHD death: 4.8% CVD death: 6.6% | Good
Prineas et al, 2002^88^ | Multiple Risk Factor Intervention Trial (MRFIT) United States Clinical trial enrollees | n=12,866 Mean age: 46 yrs (range, 35–57), based on entire cohort 100% male 93% white | Minor T wave abnormality: 7.1% | 18 | Age, sex (100% male), smoking, diabetes, DBP, HDL, LDL | CHD death: 7.3% CVD death: 10% All-cause mortality: 23% | Good
Rautaharju et al, 2006a and 2006b89,90 | Women’s Health Initiative (WHI) United States Clinical trial enrollees | n=35,715 Mean age: 62 yrs (range, 50–79) 0% male 82% white | QRS/T angle STV5 TV1 TV5 QTrr STV5 gradient MI by ECG Cornell voltage QRS nondipolar voltage Ultrashort heart rate variability | 6.2 | Age, sex (100% female), smoking, diabetes, SBP | CHD death: 0.3% Incident CHF: 1.0% All-cause mortality: 2.4% Nonfatal and fatal CHD events: 1.4% | Fair
Rautaharju et al, 2006c91 | Cardiovascular Health Study United States General community | n=4,085 Mean age: 73 yrs (inclusion criteria age ≥65) 37% male 85% nonblack | ST depression: continuous variable ECG-left ventricular mass: continuous variable QRS/T angle: continuous variable | 9.1 | Age, sex, smoking, diabetes, SBP (hypertensive status or use of anti-hypertensives) | CHD death: 7.2% All-cause mortality: 35% | Fair
Sigurdsson et al, 1996^92^ | Reykjavik Study Iceland General community | n=8,340 Mean age: 52 yrs (range, 35–60) 100% male Race NR | ST-T changes: 5% | 4 to 24 | Age, sex (100% male), smoking, fasting blood glucose, hypertension (SBP and DBP), total cholesterol | [underlined: Silent ST-T segment group] Angina: 9% MI: 5% All-cause mortality: 12% | Fair
Sutherland et al, 1993^93^ | Charleston Heart Study United States General community | n=993 Mean age: 48 yrs (range, 35–74) 100% male 66% white | Major ECG abnormality: 9% Minor ECG abnormality: 14% Left axis deviation: 8% Early repolarization: 23% Nonspecific ST-T changes: 16% LVH: 4% | 30 | Age, sex (100% male), smoking, diabetes, SBP, total cholesterol | CHD death: 19% | Good

Abbreviations: bpm=beats per minute; CHD=coronary heart disease; CHF=congestive heart failure; CVD=cardiovascular disease; DBP=diastolic blood pressure; ECG=electrocardiography; HDL=high-density lipoprotein; LDL=low-density lipoprotein; LVH=left ventricular hypertrophy; MN=Minnesota; MI=myocardial infarction; NR=not reported; SD=standard deviation; SBP=systolic blood pressure; VPC=ventricular premature complex; yrs=years.

Ten studies were rated as good quality,66,71–73,75,78,80,87,88,93 and the remainder were rated as fair quality (Appendix C1). The most common methodological shortcomings were failure to describe how patients with uninterpretable ECG results were handled (20/27 studies), failure to describe loss to followup (17/27), and failure to describe race when reporting baseline demographic characteristics (10/27).

Reclassification, calibration, and discrimination. No study estimated how accurately resting ECG plus traditional risk factor assessment classified subjects into high-, intermediate-, or low-risk groups compared with classification based on traditional risk factor assessment alone, or provided data to enable the construction of risk stratification tables.57 One study of women found that the addition of resting ECG findings to the Framingham risk score increased the C statistic for prediction of CHD events (nonfatal MI or CHD death) from 0.69 (95% confidence interval [CI], 0.61 to 0.86) to 0.74 (95% CI, 0.66 to 0.90), though confidence intervals overlapped.72

Adjusted risk estimates.

ST segment abnormalities. Six studies evaluated ST segment abnormalities (defined by various combinations of Minnesota codes 4.1, 4.2, 4.3, and 4.4) on resting ECG as a predictor of subsequent cardiovascular events (Table 3).69,71,76,80,82,86 Two studies evaluated CHD death,71,76 one study sudden unexpected cardiac death,69 one study CVD death,80 and one study nonfatal MI or CHD death.82 One study focused on stroke as an outcome and was excluded from the meta-analysis.86 Two studies restricted enrollment to male subjects.69,86 The proportion of male subjects in the other four studies ranged from 43 to 55 percent.

Table 3 ST and T Wave Changes on Resting ECG as a Predictor of Cardiovascular Events

Author, year Study | Sample size Demographics Duration of followup | Definition of segment abnormality; Prevalence | Risk associated with segment abnormality compared to no abnormality (95% CI)
ST Wave Change
Cuddy et al, 2006^69^ Manitoba Follow-Up Study | n=3,983 Mean age: 31 yrs (range, 20–39) 100% male Mean followup: 56 yrs | MN codes 4.1, 4.2, 4.4: 22% | [underlined: Sudden unexpected cardiac death] First 5 yrs following detection of ST changes: HR, 2.5 (1.5–4.4) >5 yrs since detection of ST changes: HR, 2.0 (1.2–3.3)^*^
De Bacquer et al, 1998^71^ Belgian Inter-University Research on Nutrition and Health (BIRNH) Study | n=9,954 Mean age: 48 yrs (range, 25–74) 52% male Mean followup: 10 yrs | MN codes 4.1, 4.2, 4.3: 2% | CHD death: HR, 3.0 (1.7–5.2)^*^
Greenland et al, 2003^76^ Chicago Heart Association Detection Project in Industry | n=17,615 Mean age: 50 yrs (range, 40–64) 55% male Mean followup: 22 yrs | MN codes 4.3, 4.4: 1.2% men; 1.5% women | CHD death: HR, 1.2 (0.81–1.7)^*^ CVD death: HR, 1.1 (0.81–1.5) All-cause mortality: HR, 1.0 (0.84–1.3)
Larsen et al, 2002^80^ Copenhagen City Heart Study | n=10,982 Mean age: 54 yrs (range, 35–74) 45% male Mean followup: 21 yrs | MN codes 4.1, 4.2, 4.3: 0.7% | CVD death: HR, 1.7 (1.4–2.2)^*^ MI (fatal and nonfatal): HR, 1.7 (1.2–2.3)
Machado et al, 2006^82^ Atherosclerosis Risk in Communities Study (ARIC) Other publications: ARIC Investigators, 1989^148^ | n=12,987 Mean age: 54 yrs (range, 45–64) 43% male Mean followup: 11.6 yrs | MN codes 4.3, 4.4: 1% | Nonfatal MI or CHD death: HR, 2.5 (1.7–3.7)^*^
Moller et al, 2007^86^ Uppsala Longitudinal Study of Adult Men | n=2,322 Mean age: 50 yrs (all 50 yrs) 100% male Mean followup: NR (followup >20 yrs with max 32 yrs) | MN codes 4.1, 4.2: 2.3% | Fatal and nonfatal stroke: HR, 3.4 (2.1–5.4); 0–30 yrs followup Fatal and nonfatal ischemic stroke: HR, 4.4 (2.6–7.4); 0–30 yrs followup
T Wave Change
Cuddy et al, 2006^69^ Manitoba Follow-Up Study | n=3,983 Mean age: 31 yrs (range, 20–39) 100% male Mean followup: 56 yrs | MN codes 5.2, 5.3, 5.4: 37% | [underlined: Sudden unexpected cardiac death] First 5 yrs following detection of T wave changes: HR, 2.1 (1.2–3.5) >5 yrs since detection of T wave changes: HR, 1.3 (0.79–2.0)^*^
De Bacquer et al, 1998^71^ Belgian Inter-University Research on Nutrition and Health (BIRNH) Study | n=9,954 Mean age: 48 yrs (range, 25–74) 52% male Mean followup: 10 yrs | MN codes 5.1, 5.2, 5.3: 8% | CHD death: HR, 2.0 (1.3–3.0)^*^
Greenland et al, 2003^76^ Chicago Heart Association Detection Project in Industry | n=17,615 Mean age: 50 yrs (range, 40–64) 55% male Mean followup: 22 yrs | MN codes 5.3, 5.4: 1.6% men; 1.9% women | CHD death: HR, 1.5 (1.1–2.0)^*^ CVD death: HR, 1.5 (1.1–1.9) All-cause mortality: HR, 1.1 (0.93–1.4)
Larsen et al, 2002^80^ Copenhagen City Heart Study | n=10,982 Mean age: 54 yrs (range, 35–74) 45% male Mean followup: 21 yrs | MN codes 5.1, 5.2, 5.3: 3.4% | CVD death: HR, 1.5 (1.3–1.8)^*^ MI (fatal and nonfatal): HR, 1.3 (1.1–1.6)
Machado et al, 2006^82^ Atherosclerosis Risk in Communities Study (ARIC) Other publications: ARIC Investigators, 1989^148^ | n=12,987 Mean age: 54 yrs (range, 45–64) 43% male Mean followup: 11.6 yrs | MN codes 5.1, 5.2: 4% | Nonfatal MI or CHD death: HR 2.1 (1.6 to 2.8)^*^
Moller et al, 2007^86^ Uppsala Longitudinal Study of Adult Men | n=2,322 Age: 50 yrs (all 50 yrs) 100% male Mean followup: NR (followup >20 yrs with max 32 yrs) | MN codes 5.1, 5.2, 5.3: 5.9% | Fatal and nonfatal stroke: NS; 0–30 yrs followup (data NR) Fatal and nonfatal ischemic stroke: NS; 0–30 yrs followup (data NR)
Prineas et al, 2002^88^ Multiple Risk Factor Intervention Trial (MRFIT) | n=12,866 Mean age: 46 yrs (range, 35–57), based on entire cohort 100% male Mean followup: 18 yrs | MN codes 5.3, 5.4: 7.1% | CHD death: HR, 1.2 (1.0–1.5)^*^ CVD death: HR, 1.3 (1.1–1.5) All-cause mortality: HR, 1.1 (1.0–1.2)
ST or T Wave Change
Menotti et al, 2001^84^ FINE Study Other publications: Menotti et al, 1996^156^ | n=1,785 Mean age: NR (range, 65–84 yrs) 100% male Mean followup: 10 yrs | MN codes 4.1, 4.2, 4.3, 5.1, 5.2, 5.3: 26% | CHD death: HR, 1.5 (1.1–2.2)^*^
Sigurdsson et al, 1996^92^ Reykjavik Study | n=8,340 Mean age: 52 yrs (range, 35–60) 100% male Followup: 4–24 yrs | MN codes 4.1 to 4.4; 5.1 to 5.4: 5% | CHD death: HR, 2.0 (1.6–2.6)^*^ Angina or MI: HR, 1.6 (1.0–2.8)
Sutherland et al, 1993^93^ Charleston Heart Study | n=993 Mean age: 48 yrs (range, 35–74) 100% male Mean followup: 30 yrs | Clinical interpretation (86% concordance with MN codes 4.1 to 4.3 and 5.1 to 5.3): 16% | [underlined: White men, black men] CHD death^*^: HR, 2.2 (1.2–3.8); HR, 2.0 (1.1–3.7) All-cause mortality: HR, 1.8 (1.2–2.6); HR, 1.1 (0.81–1.6)

* Outcome included in meta-analysis.

Abbreviations: CHD=coronary heart disease; CI=confidence interval; CVD=cardiovascular disease; ECG=electrocardiography; HR=hazard ratio; MI=myocardial infarction; MN=Minnesota; NR=not reported; NS=not significant; yrs=years.

After adjustment for traditional cardiac risk factors, the pooled hazard ratio for ST segment abnormalities, with regard to subsequent cardiovascular events, was 1.9 (95% CI, 1.4 to 2.5; I^2^=62 percent) (Figure 2).69,71,76,80,82 Estimates were similar when studies were stratified according to whether they evaluated CHD death (2 studies; HR, 1.8 [95% CI, 0.76 to 4.5]; I^2^=86 percent)71,76 or another cardiovascular outcome (3 studies; HR, 1.9 [95% CI, 1.5 to 2.4]; I^2^=21 percent),69,80,82 or when studies were stratified according to whether they were rated as good (2 studies; HR, 2.1 [95% CI, 1.2 to 3.6]; I^2^=70 percent)71,80 or fair quality (3 studies; HR, 1.8 [95% CI, 1.1 to 2.8]; I^2^=72 percent).69,76,82 Meta-regression analyses showed that variability in the proportion of male subjects (p=0.92), duration of followup (p=0.67), or the number of traditional risk factors adjusted for (p=0.33) did not explain the between-study variance in hazard ratio estimates. In one study not included in the meta-analysis, ST segment abnormalities were associated with an increased risk of stroke at 0–30 years of followup (HR, 3.4 [95% CI, 2.1 to 5.4]).86

Figure 2 Meta-Analyses of ST and T Wave Changes on Resting ECG as Predictors of Cardiovascular Events

Figure 2 displays a forest plot of studies reporting the hazard ratios for CHD death and other composite cardiovascular outcomes (e.g., fatal or nonfatal myocardial infarction) in study subjects with ST or T wave changes based on resting ECG results compared to subjects without ST or T wave changes. Data from Figure 2 are presented in Table 3 and described in Key Question 3 of the Results section of the evidence report. Data on ST changes are described as follows: "After adjustment for traditional cardiac risk factors, the pooled hazard ratio for ST segment abnormalities, with regard to subsequent cardiovascular events, was 1.9 (95% CI, 1.4 to 2.5; I2=62%)," while data on T wave changes are described as: "After adjustment for traditional cardiac risk factors, the pooled hazard ratio for T wave abnormalities, with regard to subsequent cardiovascular events, was 1.6 (95% CI, 1.3 to 1.8; I2=56%)." Finally, combined data on ST and T wave changes are described as: "After adjustment for traditional cardiac risk factors, the pooled hazard ratio for ST segment or T wave abnormalities, with regard to subsequent cardiovascular events, was 1.9 (95% CI, 1.6 to 2.4; I2=50%)."

T wave abnormalities. Seven studies evaluated T wave abnormalities (defined by various combinations of Minnesota codes 5.1, 5.2, 5.3, and 5.4) (Table 3).69,71,76,80,82,86,88 Three studies evaluated CHD death,71,76,88 one study CVD death,80 one study sudden unexpected cardiac death,69 and one study the combination of nonfatal MI or CHD death.82 One study focused on stroke as an outcome and was excluded from the meta-analysis.86 Three studies restricted enrollment to male subjects.69,86,88 In the other four studies, the proportion of male subjects ranged from 43 to 55 percent. Duration of followup ranged from 10 to 21 years and incidence of CHD or CVD death ranged from 1 to 18 percent.

After adjustment for traditional cardiac risk factors, the pooled hazard ratio for T wave abnormalities, with regard to subsequent cardiovascular events, was 1.6 (95% CI, 1.3 to 1.8; I^2^=56 percent) (Figure 2).69,71,76,80,82,88 Statistical heterogeneity was not reduced and estimates were similar when studies were stratified according to whether they evaluated CHD death (3 studies; HR, 1.5 [95% CI, 1.1 to 1.9]; I^2^=52 percent)71,76,88 or another cardiovascular outcome (3 studies; HR, 1.6 [95% CI, 1.3 to 2.1]; I^2^=58 percent),69,80,82 or when studies were stratified according to whether they were rated as good (3 studies; HR, 1.5 [95% CI, 1.2 to 1.8]; I^2^=62 percent)71,80,88 or fair quality (3 studies; HR, 1.6 [95% CI, 1.2 to 2.2]; I^2^=54 percent).69,76,82 Meta-regression analyses showed that restriction of enrollment to male subjects (p=0.10) and variability in duration of followup (p=0.22) or number of traditional risk factors adjusted for (p=0.66) did not explain the between-study variance in hazard ratio estimates. One study excluded from the meta-analysis found no association between T wave abnormalities and stroke at 0–30 years of followup, though estimates varied depending on the timing of followup (i.e., 0–10 years, 10–20 years, or 21–30 years).86

ST segment or T wave abnormalities. Eight studies evaluated the presence of either ST segment (defined by various combinations of Minnesota codes 4.1, 4.2, 4.3, or 4.4) or T wave abnormalities (defined by various combinations of Minnesota codes 5.1, 5.2, 5.3, or 5.4) (Table 3).70,74–76,84,85,92,93 One study evaluated CVD death74 and one study evaluated incident CHF75 (the latter was excluded from the meta-analysis). Five studies restricted enrollment to male subjects.70,84,92,93 In the other four studies, the proportion of male subjects ranged from 40 to 55 percent.74–76,85 Duration of followup ranged from 3 to 29 years and incidence of CHD or CVD death ranged from 0.3 to 21 percent.

After adjustment for traditional cardiac risk factors, the pooled hazard ratio for ST segment or T wave abnormalities, with regard to subsequent cardiovascular events, was 1.9 (95% CI, 1.6 to 2.4; I^2^=50 percent) (Figure 2).70,74,76,84,85,92,93 Although statistical heterogeneity was moderate, all of the studies found a statistically significant association (HR point estimates ranged from 1.5 to 3.8). Excluding the one study74 that evaluated CVD death instead of CHD death did not reduce the statistical heterogeneity and resulted in an unchanged pooled estimate (HR, 1.9 [95% CI, 1.6 to 2.3]; I^2^=45 percent). Only one study was rated as good quality (the others were rated as fair quality); the estimate from this study was similar to the pooled estimate (HR, 2.1 [95% CI, 1.4 to 3.2]).93 Meta-regression analyses showed that restriction of enrollment to male subjects (p=0.24) and variability in duration of followup (p=0.24) or number of traditional risk factors adjusted for (p=0.84) did not explain the between-study variance in hazard ratio estimates. One study that was excluded from the meta-analysis found an association between ST segment or T wave abnormalities and incident CHF (HR, 1.6 [95% CI, 1.3 to 2.l]).75

Left ventricular hypertrophy. Ten studies evaluated LVH on resting ECG as a predictor of various cardiovascular outcomes (Table 4).66,67,71,79,80,82,84,86,87,93 Six studies defined LVH based on Minnesota codes for high voltage plus ST segment or T wave abnormalities,67,71,79,80,84,86 one used the Cornell voltage criteria,82 one used the Romhilt and Estes criteria,93 one evaluated various criteria for new or increased LVH on 6-year followup ECG (this study was excluded from the meta-analysis),87 and one did not state how LVH was defined.66 Two studies evaluated CVD death,79,80 one evaluated nonfatal MI or CHD death,82 one focused on stroke (this study was excluded from the meta-analysis),86 and the remainder evaluated CHD death. Five studies restricted enrollment to male subjects.66,84,86,87,93 In the other five studies, the proportion of male subjects ranged from 35 to 52 percent. Duration of followup ranged from 10 to 21 years and incidence of CHD or CVD death ranged from 0.6 to 9 percent.

Table 4 Left Ventricular Hypertrophy, Left Axis Deviation, and Bundle Branch Block on Resting ECG as Predictors of Cardiovascular Events

Author, year Study | Sample size Demographics Duration of followup | Definition Prevalence | Risk associated with LVH, left axis deviation, and bundle branch block compared to none (95% CI)
Left Ventricular Hypertrophy
Bodegard et al, 2004^66^ Study not named | n=2,014 Mean age: 50 yrs (range, 40–59) 100% male Mean followup: 22 yrs | Criteria not described: 5.3% | CHD death: HR, 0.85 (0.55 to 1.3)^*^
Brown et al, 2000^67^ Second National Health and Nutrition Examination Survey (NHANES II) | n=7,924 Mean age: 49 yrs (range, 25–74) 48% male Mean followup: 15 yrs | MN codes 3.1 or 3.3 and 4.1 to 4.3 or 5.1 to 5.3 | CHD death: HR, 2.0 (1.2 to 3.4)^*^
De Bacquer et al, 1998^71^ Belgian Inter-University Research on Nutrition and Health (BIRNH) Study | n=9,954 Mean age: 48 yrs (range, 25–74) 52% male Mean followup: 10 yrs | MN codes 3.1 plus 4.1 to 4.3 or 5.1 to 5.3: 0.6% | CHD death: HR, 1.9 (0.58 to 5.9)^*^
Kahn et al, 1996^79^ Bronx Longitudinal Aging Study | n=459 Mean age: 79 yrs (range, 75–85) 35% male Mean followup: 10 yrs | MN codes 3.1; 3.3 + 4.1 to 4.3 or 5.1 to 5.3: 9.2% | CVD death: HR, 2.2 (1.4 to 3.4)^*^ All-cause mortality: HR, 0.81 (0.54 to 1.2) MI death: HR, 2.7 (1.4 to 5.3) CVA death: HR, 2.5 (0.73 to 8.4) MI (fatal or nonfatal): HR, 2.3 (1.4 to 4.0) CVA (fatal or nonfatal): HR, 1.6 (0.68 to 4.0)
Larsen et al, 2002^80^ Copenhagen City Heart Study | n=10,982 Mean age: 54 yrs (range, 35–74) 45% male Mean followup: 21 yrs | MN codes 3.1 or 3.3 and 5.1 to 5.3: 0.8% | CVD death: HR, 1.4 (1.0 to 1.8)^*^ MI (fatal and nonfatal): HR, 1.6 (1.0 to 2.3)
Machado et al, 2006^82^ Atherosclerosis Risk in Communities (ARIC) Study Other publications: ARIC Investigators, 1989^148^ | n=12,987 Mean age: 54 yrs (range, 45–64) 43% male Mean followup: 11.6 yrs | Cornell (men >28 mm; women >22 mm): 2% ST-T strain pattern (MN codes 3.1 or 3.3 + 4.3 or 4.2 or 4.1.1 or 4.1.2 or 5.1 to 5.3): 2% | [underlined: Nonfatal MI or CHD death] Cornell criteria: HR, 2.0 (1.3 to 2.9)^*^ ST-T strain pattern criteria: HR, 2.3 (1.2 to 4.3) for black women; HR, 1.1 (0.50 to 2.4) for black men; HR, 2.8 (0.69 to 12) for white women; HR, 6.5 (3.3 to 13) for white men
Menotti et al, 2001^84^ FINE Study Other publications: Menotti et al, 1996^156^ | n=1,785 Mean age: NR (range, 65–84 yrs) 100% male Mean followup: 10 yrs | MN codes 3.1 or 3.3, plus 4.1 to 4.3 or 5.1 to 5.3: 6.3% | CHD death: HR, 1.6 (0.93 to 2.9)^*^
Moller et al, 2007^86^ Uppsala Longitudinal Study of Adult Men | n=2,322 Age: 50 yrs (all 50 yrs) 100% male Mean followup: NR (followup >20 yrs with max 32 yrs) | MN codes 3.1, 3.3 + 4.1, 4.2: 1.2% | Fatal and nonfatal stroke: NS (data NR) Fatal and nonfatal ischemic stroke: NS (data NR)
Prineas et al, 2001^87^ Multiple Risk Factor Intervention Trial (MRFIT) | n=12,866 Mean age: 46 yrs (range, 35–57), based on entire cohort 100% male Mean followup: 10 yrs (from 6-yr followup ECG) | New (incident) LVH on 6-yr followup ECG, Sokolow-Lyon: 6% Cornell voltage: 1% Cornell product: 2% Novacode: 5% MN codes 3.1 or 3.3 + 5.1 to 5.3: 4% Significant increase in LVH on 6-yr followup ECG, Sokolow-Lyon: 0.5% Cornell voltage: 3.5% Cornell product: 2.8% Novacode: 1.4% ∑12 product (sum of peak-to-peak amplitudes of QRS complexes × QRS duration): 0.8% | New (incident) LVH: [underlined: CHD death] Sokolow-Lyon: HR, 1.5 (1.1 to 2.1) Cornell voltage: HR, 3.9 (2.5 to 6.0) Cornell product: HR, 2.9 (2.0 to 4.1) Novacode: HR, 3.8 (3.0 to 4.8) MN codes 3.1 or 3.3 + 5.1 to 5.3: HR, 2.6 (1.4 to 3.5) [underlined: CVD death] Sokolow-Lyon: HR, 1.6 (1.2 to 2.1) Cornell voltage: HR, 4.4 (3.1 to 6.3) Cornell product: HR, 3.0 (2.2 to 4.0) Novacode: HR, 3.5 (2.8 to 4.2) MN codes 3.1 or 3.3 + 5.1 to 5.3: HR, 2.5 (2.0 to 3.3) Significant increase in LVH: [underlined: CHD death] Sokolow-Lyon: HR, 1.3 (0.5 to 3.6) Cornell voltage: HR, 2.2 (1.6 to 3.0) Cornell product: HR, 3.1 (2.3 to 4.2) Novacode: HR, 4.5 (3.2 to 6.5) ∑12 product: HR, 2.4 (1.6 to 4.2) [underlined: CVD death] Sokolow-Lyon: HR, 1.2 (0.5 to 2.9) Cornell voltage: HR, 1.3 (1.0 to 1.6) Cornell product: HR, 3.4 (2.6 to 4.3) Novacode: HR, 4.8 (3.6 to 6.4) ∑12 product: HR, 2.3 (1.4 to 3.8)
Sutherland et al, 1993^93^ Charleston Heart Study | n=993 Mean age: 48 yrs (range, 35–74) 100% male Mean followup: 30 yrs | Romhilt and Estes criteria (point system): 4% | [underlined: White men, black men] CHD death^*^: HR, 5.6 (1.2 to 25); HR, 1.1 (0.46 to 2.7) All-cause mortality: HR, 5.5 (2.0 to 15); HR, 0.97 (0.60 to 1.6)
Left Axis Deviation
De Bacquer et al, 1998^71^ Belgian Inter-University Research on Nutrition and Health (BIRNH) Study | n=9,954 Mean age: 48 yrs (range, 25–74) 52% male Mean followup: 10 yrs | MN code 2.1: 4.2% | CHD death: HR, 1.5 (0.87 to 2.6)^*^
Menotti et al, 2001^84^ FINE Study Other publications: Menotti et al, 1996^156^ | n=1,785 Mean age: NR (range, 65–84 yrs) 100% male Mean followup: 10 yrs | MN code 2.1: 12% | CHD death: HR, 1.4 (0.89 to 2.0)^*^
Sutherland et al, 1993^93^ Charleston Heart Study | n=993 Mean age: 48 yrs (range, 35–74) 100% male Mean followup: 30 yrs | Clinical interpretation, not specified (95% concordance with MN code 2.1): 8% | [underlined: White men, black men] CHD death^*^: HR, 1.5 (0.79 to 2.7); HR, 2.0 (0.86 to 4.7) All-cause mortality: HR, 1.3 (0.88 to 1.9); HR, 1.4 (0.88 to 2.3)
Bundle Branch Block
De Bacquer et al, 1998^71^ Belgian Inter-University Research on Nutrition and Health (BIRNH) Study | n=9,954 Mean age: 48 yrs (range, 25–74) 52% male Mean followup: 10 yrs | MN codes 7.1, 7.2, 7.4: 1% | CHD death: HR, 1.9 (0.88 to 4.1)^*^
Dhingra et al, 2006^73^ Framingham Heart Study | n=1,759 Mean age: 70 yrs (SD, 7) 37% male Mean followup: 12.7 yrs | QRS duration 100–119 ms (incomplete bundle branch block): 17% QRS duration ≥120 ms (complete bundle branch block): 6% | [underlined: CHF incidence] QRS <100 ms: HR, 1 (reference) QRS 100–119 ms: HR, 1.4 (1.0 to 2.0) QRS ≥120 ms: HR, 1.7 (1.3 to 2.4)
Machado et al, 2006^82^ Atherosclerosis Risk in Communities (ARIC) Study Other publications: ARIC Investigators, 1989^148^ | n=12,987 Mean age: 54 yrs (range, 45–64) Mean followup: 11.6 yrs | MN codes 7.1, 7.2, 7.4: 2% | Nonfatal MI or CHD death: HR, 1.0 (0.67 to 1.6)^*^
Menotti et al 1997^85^ RIsk Factors and Life Expectancy (RIFLE) Study Other publications: RIFLE Research Group, 1993^149^ | n=22,553 Mean age: NR (50% ages 50–69 yrs) 54% male Mean followup: 6 yrs | MN codes 7.1, 7.2, 7.4: 1.2% | CHD death: RR, 3.3 (1.3 to 8.4) in men^*^; women not calculated CVD death: RR, 3.6 (1.7 to 7.6) in men; women not calculated All-cause mortality: RR, 1.9 (1.0 to 3.4) in men; RR, 0.79 (0.11 to 5.8) in women
Menotti et al, 2001^84^ FINE Study Other publications: Menotti et al, 1996^156^ | n=1,785 Mean age: NR (range, 65–84 yrs) 100% male Mean followup: 10 yrs | MN codes 7.1, 7.2, 7.4: 7.3% | CHD death: HR, 1.3 (0.76 to 2.2)^*^

* Outcome included in meta-analysis.

Abbreviations: CHD=coronary heart disease; CHF=congestive heart failure; CI=confidence interval; CVA=cerebral vascular accident; CVD=cardiovascular disease; ECG=electrocardiography; HR=hazard ratio; LVH=left ventricular hypertrophy; MI=myocardial infarction; MN=Minnesota; NR=not reported; NS=not significant; RR=relative risk; SD=standard deviation; yrs=years.

After adjustment for traditional risk factors, the pooled hazard ratio for LVH, with regard to subsequent cardiovascular events, was 1.6 (8 studies [95% CI, 1.3 to 2.0]; I^2^=46 percent) (Figure 3).66,67,71,79,80,82,84,93 Statistical heterogeneity appeared to be completely explained by inclusion of the lone study that did not find an increased risk or trend toward increased risk of cardiovascular events (HR, 0.85 [95% CI, 0.55 to 1.3]).66 Although statistical heterogeneity was no longer present after this study was excluded, the pooled estimate only changed slightly (HR, 1.7 [95% CI, 1.4 to 2.1]; I^2^=0 percent). It was not clear why this study was an outlier. Other than not describing how LVH was defined, it met criteria for a good-quality study. One study excluded from the meta-analysis found that increased LVH on 6-year followup ECG compared with baseline was associated with increased risk of CHD death,87 and another study excluded from the meta-analysis found no association between presence of LVH and subsequent stroke (estimates not reported).86

Figure 3 Meta-Analyses of Left Ventricular Hypertrophy, Left Axis Deviation, and Bundle Branch Block on Resting ECG as Predictors of Cardiovascular Events

Figure 3 displays a forest plot of studies reporting the hazard ratios for CHD death and other composite cardiovascular outcomes (e.g., fatal or nonfatal myocardial infarction) in study subjects with left ventricular hypertrophy (LVH), left axis deviation, or bundle branch block based on resting ECG results compared to subjects without left ventricular hypertrophy, left axis deviation, or bundle branch block. Data from Figure 3 are presented in Table 4 and described in Key Question 3 of the Results section of the evidence report. Results for LVH compared to no LVH are described as follows: "After adjustment for traditional risk factors, the pooled hazard ratio for LVH, with regard to subsequent cardiovascular events, from 8 studies was 1.6 (95% CI, 1.3 to 2.0; I2=46%)." For left axis deviation compared to no left axis deviation, results are described as: "The pooled hazard ratio after adjusting for traditional risk factors was 1.5 (95% CI, 1.1 to 1.9; 3 studies; I2=0%)," and the results for bundle branch block are described as: "The pooled hazard ratio after adjusting for traditional risk factors from 4 studies was also 1.5 (95% CI, 0.98 to 2.3; I2=46%), although results were not statistically significant, in part due to greater statistical heterogeneity and less precise estimates."

Pooled estimates were similar when studies were stratified according to whether LVH was defined based on Minnesota code criteria (5 studies; HR, 1.7 [95% CI, 1.4 to 2.0]; I^2^=0 percent) 67,71,79,80,84 or other criteria (3 studies; HR, 1.4 [95% CI, 0.77 to 2.5]; I^2^=46 percent),66,82,93 or according to whether they evaluated CHD death (5 studies; HR, 1.5 [95% CI, 0.99 to 2.1]; I^2^=48 percent)67,71,79,80,84 or another cardiovascular outcome (3 studies; HR, 1.8 [95% CI, 1.3 to 2.4]; I^2^=47 percent).79,80,82 Estimates were lower in studies rated as good quality (4 studies; HR, 1.2 [95% CI, 0.90 to 1.7]; I^2^=31 percent)66,71,80,93 compared with those rated as fair quality (4 studies; HR, 2.0 [95% CI, 1.6 to 2.5]; I^2^=0 percent) (p=0.03 for difference).67,79,82,84 Meta-regression analyses showed that the proportion of male enrollees (p=0.13), the duration of followup (p=0.06), and the number of traditional risk factors adjusted for (p=0.74) did not explain the between-study variance in hazard ratio estimates.

Left axis deviation and bundle branch block. Three studies71,84,93 evaluated left axis deviation (Table 4) and five studies71,73,82,84,85 evaluated bundle branch block (Table 4) on resting ECG as predictors of cardiovascular outcomes. One study defined bundle branch block as incomplete or complete based on QRS duration and evaluated CHF incidence.73 All of the other studies defined ECG abnormalities using Minnesota code criteria; of these, all except for one evaluated CHD death. The exception was a study that evaluated the association between bundle branch block and the combination of nonfatal MI or CHD death.82

For left axis deviation, the pooled hazard ratio, after adjusting for traditional risk factors, was 1.5 (3 studies [95% CI, 1.1 to 1.9]; I^2^=0 percent) (Figure 3).71,84,93

For bundle branch block, the pooled hazard ratio, after adjusting for traditional risk factors, was also 1.5 (4 studies [95% CI, 0.98 to 2.3]; I^2^=46 percent), although results were not statistically significant, in part due to greater statistical heterogeneity and less precise estimates (Figure 3).71, 82,84,85 One study not included in the meta-analysis found something of a dose-response, in that incomplete (QRS, 100–119 ms; HR, 1.4 [95% CI, 1.0 to 2.0]) and complete bundle branch block (QRS ≥120 ms; HR, 1.7 [95% CI, 1.3 to 2.4]) were associated with an increased risk of CHF compared with no bundle branch block at a mean followup of 12.7 years.73

Major and minor ECG abnormalities. Six studies evaluated the association between presence of major or minor resting ECG abnormalities and subsequent cardiovascular events (Table 5).71,72, 77,81,84,93 Because definitions for major and minor abnormalities varied widely between studies, we did not pool results. Two studies reported an association between presence of a major abnormality on resting ECG and CHD death through 10 years (HR, 2.3 [95% CI, 1.5 to 3.7]71 and HR, 3.1 [95% CI, 1.9 to 5.1]84), and a third study reported an association with CHD events through 5 years (HR, 3.0 [95% CI, 2.0 to 4.5]).72

Table 5 Major and Minor ECG Abnormalities as Predictors of Cardiovascular Events

Author, year Study | Sample size Demographics Duration of followup | Definition or major or minor ECG abnormalities; Prevalence | Risk associated with major or minor ECG abnormalities compared to no abnormalities (95% CI)
De Bacquer et al, 1998^71^ Belgian Inter-University Research on Nutrition and Health (BIRNH) Study | n=9,954 Mean age: 48 yrs (range, 25–74) 52% male Mean followup: 10 yrs | [underlined: Major ECG abnormality] MN codes 4.1, 4.2, 5.1, 5.2, 6.1, 6.2, 7.1, 7.2, 8.1, 8.3: 29% [underlined: Minor ECG abnormality] MN codes 1.3, 2.1, 2.2, 3.1, 3.2, 4.3, 5.3, 9.1: 3.6% | [underlined: CHD death] Major ECG abnormality: HR, 2.3 (1.5–3.7) Minor ECG abnormality: HR, 1.1 (0.77–1.7)
Denes et al, 2007^72^ Women's Health Initiative | n=14,749 Mean age: 63 yrs (range, 50–79) 0% male Mean followup: 5.2 yrs | [underlined: Major ECG abnormality] Novacodes 1.4, 1.5, 1.7, 1.8, 1.9, 2.3.1, 2.3.2, 2.4, 3.1.0, 3.1.1., 3.2.0, 3.3.0, 3.3.1, 5.1, 5.2, 5.3, 5.4, 5.5, 5.6, 6.1.1, 1.4, 1.7, 1.8: 6.2% [underlined: Minor ECG abnormality] Novacodes 2.1, 2.2.1, 3.4.1, 3.4.2, 4.1.1, 4.1.2, 5.7, 5.8, 6.1.0, 7.1, 8.1, 10.1, 10.2: 28% | [underlined: CHD events] Major ECG abnormality: HR, 3.0 (2.0–4.5) Minor ECG abnormality: HR, 1.6 (1.1–2.1) [underlined: CVD events] Major ECG abnormality: HR, 2.3 (1.8–3.0) Minor ECG abnormality: HR, 1.4 (1.1–1.7)
Liao et al, 1988^81^ Chicago Heart Association Detection Project in Industry | n=17,633 Mean age: 51 yrs 55% male Mean followup: 11.5 yrs | [underlined: Major ECG abnormality] MN codes 6.1 or 6.2; 7.1, 7.2, or 7.4; 8.3; 8.1; 4.1; 5.1 or 5.2: 11.1% [underlined: Minor ECG abnormality] MN codes 1.3, 4.3, 5.3, 6.3, 3.1, 3.2, 9.1, 2.1 or 2.2: 6% | [underlined: CHD death]^*^ Major ECG abnormality: HR, 3.7 in men; HR, 1.9 in women Minor ECG abnormality: HR, 2.1 in men; HR, 1.5 in women [underlined: CVD death]^*^ Major ECG abnormality: HR, 3.4 in men; HR, 2.1 in women Minor ECG abnormality: HR, 2.1 in men, HR, 1.5 in women [underlined: All-cause mortality]^*^ Major ECG abnormality: HR, 2.4 in men; HR, 1.4 in women Minor ECG abnormality: HR, 1.7 in men; HR, 1.2 in women
Macfarlane et al, 2007^77^ West of Scotland Coronary Prevention Study (WOSCOPS) | n=5,835 Mean age: 55 yrs 100% male Mean followup: 4.9 yrs | [underlined: Minor ECG abnormality] MN codes 4.2, 4.3, 5.2, 5.3: 8% | [underlined: CHD death of nonfatal MI] Minor ECG abnormality: HR, 1.7 (1.3–2.3) [underlined: All-cause mortality] Minor ECG abnormality: HR, 2.2 (1.5–3.1)
Menotti et al, 2001^84^ FINE Study Other publications: Menotti et al, 1996^156^ | n=1,785 Mean age: NR (range, 65–84 yrs) 100% male Mean followup: 10 yrs | [underlined: Major ECG abnormality] MN codes 1.1, 4.1, 5.1, 6.8, 7.1, 7.4, 8.3: 8% [underlined: Minor ECG abnormality] MN codes 1.2, 1.3, 2.1, 4.2–4, 5.2–5.3, 6.4, 7.2, 7.3, 8.1: 39% | [underlined: CHD death] Major ECG abnormality (vs. absent or marginal abnormality): HR, 3.1 (1.9–5.1) Minor ECG abnormality (vs. absent or marginal abnormality): HR, 1.8 (1.3–2.5)
Sutherland et al, 1993^93^ Charleston Heart Study | n=993 Mean age: 48 yrs (range, 35–74) 100% male Mean followup: 30 yrs | [underlined: Major ECG abnormality] MN codes 4.1, 4.2, 5.1, 5.2, 7.1, 7.2, 7.4, 8.1, 8.3: 9% [underlined: Minor ECG abnormality] MN codes 1.3, 4.3, 5.3, 6.3, 9.1, 3.1, 2.1, 2.2: 14% | [underlined: CHD death] Major ECG abnormality: HR, 2.7 (1.5–5.0) in white men; HR, 2.0 (0.93–4.1) in black men Minor ECG abnormality: HR, 1.3 (0.74–2.1) in white men; HR, 0.58 (0.24–1.4) in black men [underlined: All-cause mortality] Major ECG abnormality: HR, 2.1 (1.4–3.1) in white men; HR, 1.4 (0.91–2.1) in black men Minor ECG abnormality: HR, 1.2 (0.92–1.7) in white men; HR, 0.79 (0.52–1.2) in black men

* Confidence intervals not reported.

Abbreviations: CHD=coronary heart disease; CI=confidence interval; CVD=cardiovascular disease; ECG=electrocardiography; HR=hazard ratio; MI=myocardial infarction; MN=Minnesota; NR=not reported; yrs=years.

Six studies also evaluated the association between minor abnormalities on resting ECG and subsequent cardiovascular events.71,72,77,81,84,93 From a given study, risk estimates for minor abnormalities were weaker than estimates for major abnormalities, suggesting a potential dose effect. For example, one study reported a hazard ratio of 1.8 (95% CI, 1.3 to 2.5) for minor abnormalities and subsequent CHD death compared with a hazard ratio of 3.1 (95% CI, 1.9 to 5.1) for major abnormalities.84 In some cases, the association between minor abnormalities and subsequent CHD events did not reach statistical significance.71,93

Other resting ECG abnormalities. Other resting ECG abnormalities have been evaluated, including prolonged QT interval, ischemic changes, atrial fibrillation, right axis deviation, presence of Q waves, ventricular premature contractions, high resting heart rate, and others (Table 6).68,75,77,78,82,83,85,89–91,130 Two studies found that ischemic changes on resting ECG (defined using different Minnesota code criteria) was associated with increased risk of subsequent CHD death after 10 years of followup (HR, 1.7 [95% CI, 1.1 to 1.7]71 and HR, 1.5 [95% CI, 1.1 to 2.1]84), after adjustment for traditional risk factors (Table 7). Two other studies reported inconsistent results for the association between prolonged QT interval on resting ECG and subsequent cardiovascular events, but varied in how they defined QT prolongation, the outcomes assessed, and duration of followup (Table 8).82,90 Other ECG abnormalities were evaluated in only one study or too variably defined across studies to draw firm conclusions about their usefulness as predictors.

Table 6 Other Abnormalities on Resting ECG as Predictors of Cardiovascular Events

Author, year | Sample size Demographics Duration of followup | ECG abnormalities evaluated; Prevalence | Risk associated with abnormality present compared to no abnormality (95% CI)
Crow et al, 2003^68^ Atherosclerosis Risk in Community (ARIC) Study | n=14,696 Mean age: 54 yrs (range, 45–64) 43% male Mean followup: 13 yrs | QTc: continuous variable JTc: continuous variable Wide QRS complex (≥120 ms): 3.1% | [underlined: Incident MI or CHD death] No wide QRS complex QTc (per 10 ms): HR, 1.0 (1.0–1.1) in men; 1.1 (1.0–1.2) in women JTc (per 10 ms): HR, 1.0 (1.0–1.1) in men; 1.1 (1.0–1.1) in women Wide QRS complex QTc (per 10 ms): HR, 1.1 (0.90–1.2) in men; 1.0 (0.72–1.3) in women JTc (per 10 ms): HR, 1.2 (1.0–1.5) in men; 0.79 (0.56–1.1) in women
Gottdiener et al, 2000^75^ Cardiovascular Heart Study Other publications: Furberg et al, 1992^147^ | n=4,652 (analyzed group with no prevalent CHD) Mean age: 73 yrs (range, 65–100; entire cohort) 40% male Mean followup: 6.3 yrs | Atrial fibrillation: 3.2% Major Q/QS wave: 5.2% | [underlined: Incident CHF] Atrial fibrillation: HR, 1.94 (1.23–3.05) Major Q/QS wave: NS (estimate NR)
Jouven et al, 2005^78^ Paris Prospective Study I | n=5,713 Mean age: 48 yrs (range, 42–53) 100% male Mean followup: 23 yrs | Resting heart rate >75 bpm: 8.0% | [underlined: Resting heart rate >75 bpm vs. <60 bpm] Sudden death from MI: HR, 3.5 (1.6–7.4) Nonsudden death from MI: HR, 1.6 (0.90–2.7) All-cause mortality: HR, 1.9 (1.6–2.2)
Macfarlane et al, 2007^77^ West of Scotland Coronary Prevention Study (WOSCOPS) | n=5,835 Mean age: 55 yrs 100% male Mean followup: 4.9 yrs | Right axis deviation: 0.5% High voltage left ventricular lead: 5.1% High voltage right ventricular lead: 0.06% Heart rate Indexed LVM (Rautaharju criteria) Frontal T-axis Positive component of T wave amplitude in lead I Heart rate variability | [underlined: Nonfatal MI or CHD death] Heart rate (10 bpm): HR, 1.13 (1.04–1.24) Indexed LVM (Rautaharju criteria) (per 25 g/m^2^): HR, 1.19 (1.03–1.38) Frontal T-axis (per 20°): HR, 0.84 (0.77–0.91) Positive component of T wave amplitude in lead I (per 100 μV): HR, 0.81 (0.72–0.91) Other NS ECG findings in multivariate model: NR [underlined: All-cause mortality] Heart rate variability (per 15 ms): HR, 0.76 (0.67–0.87) Frontal T-axis (per 20°): HR, 0.82 (0.74–0.89) Other NS ECG findings in multivariate model: NR
Machado et al, 2006^82^ Atherosclerosis Risk in Communities Study (ARIC) Other publications: ARIC Investigators, 1989^148^ | n=12,987 Mean age: 54 yrs (range, 45–64) 43% male Mean followup: 11.6 yrs | Minor Q wave: 2% Prolonged QTc interval: 9% Major ventricular conduction defect: 2% | [underlined: Incident CHD (nonfatal MI or CHD death)] Minor Q wave: HR, 1.59 (1.08–2.34) Prolonged QTc interval: HR, 1.12 (0.87–1.43) Major ventricular conduction defect: 1.05 (0.67–1.64)
Massing et al, 2006^83^ Atherosclerosis Risk in Communities Study (ARIC) | n=15,070 Mean age: 54 yrs (range, 45–64) 45% male 74% white Mean followup: >10 yrs (11.6 yrs in other ARIC publications) | Ventricular premature contractions: 6.2% | [underlined: Asymptomatic patients at baseline] CHD event: HR, 1.30 (1.06–1.58) CHD death: HR, 2.14 (1.46–3.13) All-cause mortality: HR, 1.48 (1.25–1.75)
Menotti et al, 1997^85^ Risk Factors and Life Expectancy (RIFLE) Study Other publications: RIFLE Research Group, 1993^149^ | n=22,553 Mean age: NR (50% ages 50–69 yrs) 54% male Mean followup: 6 yrs | Q/QS wave High R wave Arrhythmia Any ECG abnormality: 12% | [underlined: CHD death] Q/QS wave: RR, 1.25 (0.29–5.31) in men; RR, 9.88 (1.05–92.6) in women High R wave: RR, 1.62 (0.86–3.05) in men; RR, 5.14 (0.94–28.1) in women Arrhythmia: RR, 2.28 (0.81–6.40) in men; RR, not calculated in women [underlined: Cardiovascular death] Q/QS wave: RR, 2.36 (0.91–6.11) in men; RR, 4.18 (0.51–34.5) in women High R wave: RR, 1.86 (1.13–3.07) in men; RR, 3.66 (0.96–14.0) in women Arrhythmia: RR, 1.58 (0.57–4.38) in men; RR, not calculated in women [underlined: All-cause mortality] Q/QS wave: RR, 1.63 (0.77–3.46) in men; RR, 1.00 (0.13–7.39) in women High R wave: RR, 1.28 (0.89–1.85) in men; RR, 2.17 (0.97–4.85) in women Arrhythmia: RR, 1.92 (1.04–3.54) in men; RR, 0.81 (0.11–5.93) in women
Moller et al, 2007^86^ Uppsala Longitudinal Study of Adult Men | n=2,322 Age: 50 yrs (all age 50 yrs) 100% male Mean followup: NR (followup >20 yrs with max 32 yrs) | Q/QS wave: 1.3% Atrial fibrillation: 0.3% | [underlined: Fatal and nonfatal stroke] Q/QS wave, atrial fibrillation: NS (estimates NR) [underlined: Fatal and nonfatal ischemic stroke] Atrial fibrillation, followup 0–9.9 yrs: HR, 15 (1.77–128) Atrial fibrillation, followup 0–30, 10–19.9, or 20–30 yrs: NS (estimates NR) Q/QS wave: NS (estimate NR)
Rautaharju et al, 2006a and 2006b89,90 Women's Health Initiative (WHI) Other publications: WHI 1998^155^ | n=35,715 Mean age: 62 yrs (range, 50–79) 0% male 82% white Mean followup: 6.2 yrs | QRS/T angle STV5 TV1 TV5 QTrr STV5 gradient MI by ECG Cornell voltage R nondipolar voltage Heart rate variability | [underlined: CHD event] T nondipolar voltage (≥13 μV): HR, 1.29 (0.97–1.72) Rest: NS [underlined: CHD death] Cornell voltage (≥1800 μV): HR, 1.91 (1.09–3.36) QTrr (≥437 ms): HR, 2.17 (1.24–3.73) Rest: NS [underlined: Incident CHF] MI by ECG: HR, 1.99 (1.53–2.59) Isolated ST-T abnormality or minor Q wave: HR, 1.55 (1.2–1.99) [underlined: All-cause mortality] MI by ECG: HR, 1.36 (1.10–1.68) Isolated ST-T abnormality or minor Q wave: HR, 1.15 (0.96–1.39)
Rautaharju et al, 2006c91 Cardiovascular Health Study | n=4,085 Mean age: 73 yrs (inclusion criteria age ≥65 yrs) 37% male 85% white and/or other 15% black | QRS/T angle STV5 TV1 TV5 QTrr STV5 gradient MI by ECG Cornell voltage QRS nondipolar voltage Ultrashort heart rate variability | [underlined: CHD death] ST depression: HR, 1.74 (1.28–2.36) MI by ECG, QRS/T angle, QRS nondipolar voltage, LVM by ECG: NS (estimates NR) [underlined: All-cause mortality] Previous MI: HR, 1.50 (1.20–1.87) ST depression: HR, 1.35 (1.14–1.59) LVM by ECG: HR, 1.27 (1.05–1.55) QRS/T angle: HR, 1.18 (0.99–1.40)

Abbreviations: bpm=beats per minute; CHD=coronary heart disease; CHF=congestive heart failure; CI=confidence interval; CVD=cardiovascular disease; ECG=electrocardiography; HR=hazard ratio; LVH=left ventricular hypertrophy; LVM=left ventricular mass; MI=myocardial infarction; NR=not reported; NS=not significant; RR=relative risk; yrs=years.

Table 7 Ischemic Changes on Resting ECG as a Predictor of Cardiovascular Events

Author, year Study | Sample size Demographics Duration of followup | Definition of ischemic changes Prevalence | Risk associated with ischemic changes compared to no ischemic changes (95% CI)
De Bacquer et al, 1998^71^ Belgian Inter-University Research on Nutrition and Health (BIRNH) Study | n=9,954 Mean age: 48 yrs (range, 25–74) 52% male Mean followup: 10 yrs | MN codes 1.3, 4.1–4.4, 5.1–5.3, 7.1: 10% | CHD death: HR, 1.7 (1.1–2.5)
Menotti et al, 2001^84^ FINE Study Other publications: Menotti and Seccareccia, 1996^156^ | n=1,785 Mean age: NR (range, 65–84 yrs) 100% male Mean followup: 10 yrs | MN codes 1.2 or 1.3, 4.1–4.3, 5.1–5.3: 35% | CHD death: HR, 1.5 (1.1–2.1)

Abbreviations: CHD=coronary heart disease; CI=confidence interval; HR=hazard ratio; ECG=electrocardiography; MN=Minnesota; NR=not reported; yrs=years.

Table 8 Prolonged QT Interval on Resting ECG as a Predictor of Cardiovascular Events

Author, year Study | Sample size Demographics Duration of followup | Definition of prolonged QT interval Prevalence | Risk associated with prolonged QT interval compared to no prolonged QT interval (95% CI)
Machado et al, 2006^82^ Atherosclerosis Risk in Communities (ARIC) Study Other publications: ARIC Investigators, 1989^148^ | n=12,987 Mean age: 54 yrs (range, 45–64) Mean followup: 11.6 yrs | QTc ≥460 ms: 9% | Nonfatal MI or CHD death: HR, 1.1 (0.87–1.4)
Rautaharju et al, 2006a89 Women's Health Initiative (WHI) Other publications: WHI, 1998^155^ | n=35,715 Mean age: 62 yrs (range, 50–79) 0% male Mean followup: 6.2 yrs | QTrr ≥437 ms: NR | CHD death: HR, 2.2 (1.2–3.7)

Abbreviations: CHD=coronary heart disease; CI=confidence interval; ECG=electrocardiography; HR=hazard ratio; MI=myocardial infarction; NR=not reported; yrs=years.

Stratification by sex. In studies that stratified results by sex, estimates of risk associated with various resting ECG abnormalities in men and women were similar, or had overlapping confidence intervals (Table 9).

Table 9 Estimates of Risk Associated With Resting ECG Abnormalities, Stratified By Sex

Author, year Study | Sample Size Demographics Duration of followup | Definition of abnormality Prevalence | Risk associated with abnormality compared to no abnormality in men (95% CI) | Risk associated with abnormality compared to no abnormality in women (95% CI)
Resting ECG
De Bacquer et al, 1998^71^ Belgian Inter-University Research on Nutrition and Health (BIRNH) Study | n=9,954 Mean age: 48 yrs (range, 25–74) 52% male Mean followup: 10 yrs | ST segment abnormality, MN codes 4.1–4.3: 2% | CHD death: HR, 3.5 (1.8–6.8) | CHD death: 2.6 (0.99–6.9)
Greenland et al, 2003^76^ Chicago Heart Association Detection Project in Industry | n=17,615 Mean age: 50 yrs (range, 40–64) 55% male Mean followup: 22 yrs | ST segment abnormality, MN codes 4.3, 4.4: 1.2% in men; 1.5% in women | CHD death: HR, 1.0 (0.66–1.6) CVD death: HR, 0.93 (0.61–1.4) All-cause mortality: HR, 0.95 (0.71–1.3) | CHD death: HR, 1.5 (0.84–2.8) CVD death: HR, 1.5 (0.94–2.5) All-cause mortality: HR, 1.2 (0.87–1.7)
De Bacquer et al, 1998^71^ Belgian Inter-University Research on Nutrition and Health (BIRNH) Study | n=9,954 Mean age: 48 yrs (range, 25–74) 52% male Mean followup: 10 yrs | T wave abnormality, MN codes 5.1–5.3: 8% | CHD death: HR, 2.0 (1.2–3.4) | CHD death: 1.9 (0.89–3.9)
Greenland et al, 2003^76^ Chicago Heart Association Detection Project in Industry | n=17,615 Mean age: 50 yrs (range, 40–64) 55% male Mean followup: 22 yrs | ST segment or T wave abnormality, MN codes 4.3, 4.4, 5.3, 5.4: 3.6% in men; 5.4% in women | CHD death: HR, 1.4 (0.81–2.3) CVD death: HR, 1.4 (0.90–2.2) All-cause mortality: HR, 1.2 (0.86–1.6) | CHD death: HR, 2.0 (1.2–3.2) CVD death: HR, 1.6 (1.1–2.4) All-cause mortality: HR, 1.3 (0.98–1.7)
De Bacquer et al, 1998^71^ Belgian Inter-University Research on Nutrition and Health (BIRNH) Study | n=9,954 Mean age: 48 yrs (range, 25–74) 52% male Mean followup: 10 yrs | LVH, MN codes 3.1 + 4.1–4.3 or 5.1–5.3: 0.6% | CHD death: HR, 1.8 (0.44–7.6) | CHD death: HR, 1.9 (0.25–14)
Machado et al, 2006^82^ Atherosclerosis Risk in Communities Study (ARIC) Other publications: ARIC Investigators, 1989^148^ | n=12,987 Mean age: 54 yrs (range, 45–64) 43% male Mean followup: 11.6 yrs | LVH, Cornell (men >28 mm; women >22 mm): 2% ST-T strain pattern: MN codes 3.1 or 3.3 + 4.3 or 4.2 or 4.1.1 or 4.1.2 or 5.1 or 5.2 or 5.3: 2% | [underlined: Nonfatal MI or CHD death] ST-T strain pattern: HR, 1.1 (0.50–2.4) in blacks; HR, 6.5 (3.3–13) in whites | [underlined: Nonfatal MI or CHD death] ST-T strain pattern: HR, 2.3 (1.2–4.3) in blacks; HR, 2.8 (0.69–12) in whites
De Bacquer et al, 1998^71^ Belgian Inter-University Research on Nutrition and Health (BIRNH) Study | n=9,954 Mean age: 48 yrs (range, 25–74) 52% male Mean followup: 10 yrs | Major ECG abnormality (MN codes 4.1, 4.2, 5.1, 5.2, 6.1, 6.2, 7.1, 7.2, 8.1, 8.3): 29% Minor ECG abnormality (MN codes 1.3, 2.1, 2.2, 3.1, 3.2, 4.3, 5.3, 9.1): 3.6% | [underlined: CHD death] Major ECG abnormality: HR, 2.1 (1.2–3.7) Minor ECG abnormality: HR, 0.99 (0.62–1.6) | [underlined: CHD death] Major ECG abnormality: HR, 3.1 (1.4–6.9) Minor ECG abnormality: HR, 1.6 (0.78–3.1)
Liao et al, 1988^81^ Chicago Heart Association Detection Project in Industry | n=17,633 Mean age: 51 yrs 55% male Mean followup: 11.5 yrs | Major ECG abnormality (MN codes 6.1 or 6.2; 7.1, 7.2, or 7.4; 8.3; 8.1; 4.1; 5.1 or 5.2): 11.1% Minor ECG abnormality (MN codes 1.3, 4.3, 5.3, 6.3, 3.1, 3.2, 9.1, 2.1 or 2.2): 6% | [underlined: CHD death]^*^ Major ECG abnormality: HR, 3.7 Minor ECG abnormality: HR, 2.1 [underlined: CVD death]^*^ Major ECG abnormality: HR, 3.4 Minor ECG abnormality: HR, 2.1 [underlined: All-cause mortality]^*^ Major ECG abnormality: HR, 2.4 Minor ECG abnormality: HR, 1.7 | [underlined: CHD death]^*^ Major ECG abnormality: HR, 1.9 Minor ECG abnormality: HR, 1.5 [underlined: CVD death]^*^ Major ECG abnormality: HR, 2.1 Minor ECG abnormality: HR, 1.5 [underlined: All-cause mortality]^*^ Major ECG abnormality: HR, 1.4 Minor ECG abnormality: HR, 1.2
De Bacquer et al, 1998^71^ Belgian Inter-University Research on Nutrition and Health (BIRNH) Study | n=9,954 Mean age: 48 yrs (range, 25–74) 52% male Mean followup: 10 yrs | Left axis deviation, MN code 2.1: 4.2% | CHD death: HR, 1.5 (0.79–2.7) | CHD death: HR, 1.6 (0.48–5.5)
De Bacquer et al, 1998^71^ Belgian Inter-University Research on Nutrition and Health (BIRNH) Study | n=9,954 Mean age: 48 yrs (range, 25–74) 52% male Mean followup: 10 yrs | Bundle branch block, MN codes 7.1, 7.2, 7.4: 1% | CHD death: HR, 1.8 (0.74–4.6) | CHD death: HR, 2.2 (0.50–10)
Menotti et al, 1997^85^ Risk Factors and Life Expectancy (RIFLE) Study Other publications: RIFLE Research Group, 1993^149^ | n=22,553 Mean age: NR (50% ages 50–69 yrs) 54% male Mean followup: 6 yrs | Bundle branch block, MN codes 7.1, 7.2, 7.4: 1.2% | All-cause mortality: RR, 1.9 (1.0–3.4) | All-cause mortality: RR, 0.79 (0.11–5.8)
Crow et al, 2003^68^ Atherosclerosis Risk in Community (ARIC) Study | n=14,696 Mean age: 54 yrs (range, 45- 64) 43% male Mean followup: 13 yrs | QTc: continuous variable JTc: continuous variable Wide QRS complex (≥120 ms): 3.1% | [underlined: Incident MI or CHD death] No wide QRS complex QTc (per 10 ms): HR, 1.0 (1.0–1.1) JTc (per 10 ms): HR, 1.0 (1.0–1.1) Wide QRS complex QTc (per 10 ms): HR, 1.1 (0.90–1.2) JTc (per 10 ms): HR, 1.2 (1.0–1.5) | [underlined: Incident MI or CHD death] No wide QRS complex QTc (per 10 ms): HR, 1.1 (1.0–1.2) JTc (per 10 ms): HR, 1.1 (1.0–1.1) Wide QRS complex QTc (per 10 ms): HR, 1.0 (0.72–1.3) JTc (per 10 ms): HR, 0.79 (0.56–1.1)
Menotti et al, 1997^85^ Risk Factors and Life Expectancy (RIFLE) Study Other publications: RIFLE Research Group, 1993^149^ | n=22,553 Mean age: NR (50% ages 50–69 yrs) 54% male Mean followup: 6 yrs | Q/QS wave, MN codes 1.1, 1.2, 1.3 ST-T abnormality, MN codes 4.1–4.3 or 5.1–5.3 High R wave, MN codes 3.1, 3.3 Arrhythmia, MN codes 8.1–8.6, 8.9, 9.0, 6.1, 6.2, 6.4 Block, MN codes 7.1, 7.2, 7.4 Any ECG abnormality: 12% | [underlined: CHD death] Q/QS wave: RR, 1.2 (0.29–5.3) High R wave: RR, 1.6 (0.86–3.0) [underlined: Cardiovascular death] Q/QS wave: RR, 2.4 (0.91–6.1) High R wave: RR, 1.9 (1.1–3.1) [underlined: All-cause mortality] Q/QS wave: RR, 1.6 (0.77–3.5) High R wave: RR, 1.3 (0.89–1.8) Arrhythmia: RR, 1.9 (1.0–3.5) | [underlined: CHD death] Q/QS wave: RR, 9.9 (1.0–93) High R wave: RR, 5.1 (0.94–28) [underlined: Cardiovascular death] Q/QS wave: RR, 4.2 (0.51–34) High R wave: RR, 3.7 (0.96–14) [underlined: All-cause mortality] Q/QS wave: RR, 1.0 (0.13–7.4) High R wave: RR, 2.2 (0.97–4.8) Arrhythmia: RR, 0.81 (0.11–5.9)
De Bacquer et al, 1998^71^ Belgian Inter-University Research on Nutrition and Health (BIRNH) Study | n=9,954 Mean age: 48 yrs (range, 25–74) 52% male Mean followup: 10 yrs | Ischemic changes, MN codes 1.3, 4.1–4.4, 5.1–5.3, 7.1: 10% | CHD death: HR, 1.7 (1.0–2.8) | CHD death: HR, 1.7 (0.81–3.5)

* Confidence intervals not reported.

Abbreviations: CHD=coronary heart disease; CI=confidence interval; CVD=cardiovascular disease; ECG=electrocardiography; HR=hazard ratio; LVH=left ventricular hypertrophy; MI=myocardial infarction; MN=Minnesota; RR=relative risk; yrs=years.

### Evidence: Exercise ECG

Thirty-eight prospective cohort studies of exercise ECG met inclusion criteria (Table 10).66,78,94–129 Six studies reported results from the Kuopio Ischemic Heart Disease Risk Factor Study,108,109,111–113,126 three from MRFIT,94,120,122 two from the St. James Women Take Heart Study,104,105 four from the Baltimore Longitudinal Study of Aging,101,106,124,125 three from the Framingham Offspring Study,110,118,119 three from the Lipid Research Clinics Prevalence Study, 98,116,117 two from the Lipid Research Clinics Coronary Primary Prevention Trial,100,127 two from the Paris Protective Study I,78,107 and two from the Aerobics Center Longitudinal Study.97,129 Excluding double-counted populations, the studies evaluated a total of 91,746 subjects. Duration of followup ranged from 2.8^123^ to 25 years.94

Table 10 Cohort Studies of Exercise ECG Abnormalities as Predictors of Cardiovascular Events

Author, year | Study name Exercise test Country Population | Sample size Demographics | Exercise ECG abnormality Prevalence | Mean followup (yrs) | Framingham risk factor adjusted | All-cause mortality and incident cardio-vascular events | Quality
Adabag et al, 2008^94^ | Multiple Risk Factor Intervention Trial (MRFIT) Treadmill/standard Bruce protocol United States Clinical trial enrollees | n=12,555 Mean age: 46 yrs (range, 35–57) 100% male 7% black; other races NR | Failure to reach target heart rate: 19% | 25 yrs: CHD death and all-cause mortality 7 yrs: sudden death and fatal/nonfatal MI | Age, sex, smoking, fasting glucose, SBP, HDL, LDL | CHD death (25 yrs): 13% All-cause mortality (25 yrs): 37% [underlined: 7-yr followup] Sudden death: 1.2% Fatal/nonfatal MI: 6.6% | Good
Aktas et al, 2004^95^ | Study not named Treadmill/primarily Bruce or modified Bruce protocols United States Self-referred, consecutive adults undergoing routine executive physical | n=3,554 Mean age: 57 yrs (range, 50–75) 81% male 1.8% black; other races NR | ST segment changes: <2 mm, 6%; ≥2 mm, 4.4% Any change: 10.4% Abnormal heart rate recovery: 15.4% (549/3554) | 8 | Age, sex, smoking, total cholesterol, HDL, SBP, diabetes | All-cause mortality: 3.2% (114/3554) | Fair
Balady et al, 2004^96^ Other publications: Framingham Study150 | Framingham Heart Study Treadmill/standard Bruce protocol United States General community | n=3,043 Mean age: 45 yrs (range, 30–70) 47% male Race NR | ST segment depression: 4.3% Failure to reach target heart rate: 9.0% | 18 | Age, sex, smoking, diabetes, SBP, DBP, HDL, total cholesterol | Any CHD event (angina, coronary insufficiency, MI, or CHD death): 10% | Good
Blair et al, 1996^97^ Other publications: Wei et al, 1999^151^ | Aerobics Center Longitudinal Study Treadmill/maximal Balke protocol United States General community | n=32,421 Mean age: 43 yrs (range, 20–88) 79% male Race NR | Abnormal ECG (not defined): 6.8% | 8.2 (8.4 in men; 7.5 in women) | Age, sex (results stratified by sex), smoking, SBP, total cholesterol, fasting glucose | CVD death: 0.8% All-cause mortality: 2.1% | Fair
Bodegard et al, 2004^66^ | Study not named Bicycle/maximal Norway Work volunteers | n=2,014 Mean age: 50 yrs (range, 40–59) 100% male Race NR | ST segment depression: 14% | 22 | Age, sex, smoking, SBP, total cholesterol | CHD death: 15% All-cause mortality: 37% Acute MI: 19% Coronary artery bypass graft surgery: 6.0% Stroke: 7.7% | Good
Cole et al, 2000^98^ | Lipid Research Clinics Prevalence Study Treadmill/standard or modified Bruce protocol United States General population | n=5,234 Mean age: 44 yrs 61% male 96% white (other races NR) | Heart rate recovery at 2 minutes <42 bpm: 33% | 12 | Age, sex, SBP, smoking, diabetes, lipid profiles (cholesterol) | CVD death: 2.2% All-cause mortality: 6.2% | Good
Cournot et al, 2006^99^ | Study not named Exercise method not described/submaximal France Cardiology clinic attendees | n=1,051 Mean age: 52 yrs (range, 18–79) 64% male Race NR | ST segment depression: 5.3% | 6 | Age, sex, smoking, diabetes, SBP, HDL, total cholesterol | CHD or CVD death: 0.6% Any coronary event (cardiac death, sudden death, MI, angina): 3.2% All-cause mortality: 1.7% CHD or CVD death: 0.6% Stable or unstable angina: 1.2% Nonfatal MI: 1.4% | Good
Ekelund et al, 1989^100^ | Lipid Research Clinics Coronary Primary Prevention Trial Treadmill/submaximal Bruce protocol United States Clinical trial enrollees | n=3,775 Mean age: 47 yrs (range, 35–59) 100% male Race NR | ST segment depression or elevation: 8.2% | 7.4 | Age, sex, smoking, diabetes, SBP, HDL, LDL | CHD death: 1.8% Nonfatal MI: 7.6% All-cause mortality: 3.7% | Good
Fleg et al, 1990^101^ | Baltimore Longitudinal Study of Aging Treadmill/modified Balke protocol United States General community | n=407 Mean age: 60 yrs (range, ≥40 yrs) 71% male 97% white | ST segment depression: 16% | 4.6 | Age, sex, smoking, diabetes, hypertension, total cholesterol | CVD death: 1.7% Nonfatal MI: 3.2% Angina: 4.9% Any coronary event: 9.8% | Good
Giagnoni et al, 1983^102^ | Study not named Supine ergometer/sub-maximal Italy Factory workers | n=514 Age: 44% ages 46–65 yrs (range, 18–65) 73% male Race NR | ST segment depression: 1.2% | 6.0 | Age, sex, smoking, SBP, total cholesterol | Any coronary event (angina, MI, sudden death): 6.6% All-cause mortality: 3.1% | Good
Gordon et al, 1986^103^ | Lipid Research Clinics Mortality Follow-Up Study Treadmill/submaximal modified Bruce protocol United States Lipid clinic attendees | n=3,640 Age: 35% ages 50–79 yrs (range, 30–79) 100% male 100% white | ST segment depression or elevation: 18% | 8.1 | Age, sex (100% male), smoking, hyperglycemia, hypertension, HDL, LDL | CHD death: 1.4% CVD death: 1.8% All-cause mortality: 4.1% | Fair
Gulati et al, 2003^105^ | St James Women Take Heart Treadmill/maximal Bruce protocol United States General community | n=5,271 Mean age: 52 yrs (range NR [SD, 11]) 0% male 86% white | Mean exercise capacity: 8.0 METs | 8.4 | Age, sex (100% female), smoking, SBP, DBP, HDL, total cholesterol | All-cause mortality: 3.2% | Fair
Gulati et al, 2005^104^ Same population as Gulati et al, 2003^105^ | St James Women Take Heart Treadmill/maximal Bruce protocol United States General community | n=5,636 Mean age: 52 yrs (range NR [SD, 11]) 0% male 86% white | Mean Duke treadmill score: 8 | 9 | Age, sex, smoking, diabetes, SBP, DBP, HDL, total cholesterol | CHD death: 0.9% All-cause mortality: 3.0% | Good
Josephson et al, 1990^106^ | Baltimore Longitudinal Study of Aging Treadmill/submaximal modified Balke protocol United States General population | n=726 Mean age: 55 yrs (range, 22–84) 63–87% male (varied by group) Race NR | ST segment depression: 12% on initial test; 13% on followup test | 6.4–7.7 | Age, sex, smoking, hypertension, cholesterol | Cardiac events (angina, nonfatal MI, cardiac death): 8.8% | Fair
Jouven et al, 2000^107^ Other publications: Filipovsky et al, 1992^152^ | Paris Protective Study Bicycle/standardized graded exercise test France Civil servants | n=6,101 Mean age: 48 yrs (range, 42–52) 100% male Race NR | ST segment depression: 4.4% Frequent premature ventricular contractions: 2.8% | 23 | Age, sex (100% male), smoking, diabetes, SBP, total cholesterol | CHD death: 7.1% All-cause mortality: 27% | Good
Jouven et al, 2005^78^ | Paris Protective Study I Bicycle/standardized graded exercise test France Civil servants | n=5,713 Mean age: 48 yrs (range, 42–53) 100% male Race NR | Abnormal (<89 bpm) heart rate increase during exercise: 8% Abnormal heart rate recovery (decrease of <25 bpm at 1 min after cessation): 6% | 23 | Age, sex (100% male), smoking, diabetes, SBP, cholesterol | Fatal MI (sudden death): 1.4% Fatal MI (nonsudden death): 2.3% All-cause mortality: 27% | Good
Kurl et al, 2003^108^ | Kuopio Ischemic Heart Disease Risk Factor Study Bicycle/maximal symptom-limited exercise test Finland General population | n=1,726 Mean age: 52 yrs (range, 42–60) 100% male Race NR | ST segment depression: 7.1% | 10 | Age, sex (100% male), smoking, diabetes, SBP, LDL | CHD death: 5.0% Stroke: 4.2% | Fair
Kurl et al, 2009^109^ | Kuopio Ischemic Heart Disease Risk Factor Study Bicycle/maximal symptom-limited exercise test Finland General population | n=1,639 Mean age: 52 yrs (range, 42–60) 100% male Race NR | ST segment depression: 6.7% | 16 | Age, sex, smoking, diabetes, SBP, HDL, total cholesterol | Stroke: 5.9% | Fair
Lauer et al, 1996^110^ | Framingham Offspring Study Treadmill/submaximal Bruce protocol United States Offspring and spouses of Framingham Heart Study participants | n=1,575 Mean age: 43 yrs (range NR) 100% male Race NR | Failure to reach target heart rate: 21% Increase in heart rate from rest to peak exercise: continuous outcome Ratio of heart rate to metabolic reserve used by stage 2 (7.1 METs) of exercise: continuous outcome | 7.7 | Age, sex, smoking, hypertension, diabetes, cholesterol | CHD events (MI, angina, sudden cardiac death): 6.0% All-cause mortality: 3.5% | Fair
Laukkanen et al, 2001^111^ | Kuopio Ischemic Heart Disease Risk Factor Study Bicycle/maximal symptom-limited exercise test Finland General population | n=1,769 Mean age: 52 yrs (range, 42–60) 100% male Race NR | ST segment depression during exercise: 10.7% After exercise: 3.1% | 10 | Age, sex (100% male), smoking, SBP, diabetes, LDL, HDL | CHD death: 3.0% CVD death: 4.4% Nonfatal coronary events (MI or typical angina): 9.8% | Good
Laukkanen et al, 2006^112^ | Kuopio Ischemic Heart Disease Risk Factor Study Bicycle/maximal symptom-limited exercise test Finland General population | n=1,596 Mean age: 52 yrs (range, 42–61) 100% male Race NR | Peak oxygen pulse (VO_2_ max/maximum heart beat): continuous variable ST segment depression: 6.8% | 14 | Age, sex (100% male), smoking, diabetes, SBP, DBP, HDL, LDL | CHD death: 4.2% All-cause mortality: 17% | Good
Laukkanen et al, 2008^113^ | Kuopio Ischemic Heart Disease Risk Factor Study Bicycle ergometer/maximal symptom-limited exercise test Finland General population | n=1,639 Mean age: 52 yrs (range, 42–60) 100% male Race NR | Exercise capacity (highest workload achieved during test): continuous outcome; also grouped into quartiles (>230 W; 196–230 W; 162–195 W; <162 W) Exercise-induced ST depression (horizontal or downsloping ST depression 1.0 mm 80 ms from J-point): 6.5% | 16.6 | Age, sex (100% male), smoking, diabetes, SBP, DBP, total cholesterol, HDL (Framingham risk score) or age, sex (100% male), total cholesterol, SBP, smoking (European SCORE) | CVD death: 7.1% Major CVD event: 21% All-cause mortality: 19% | Good
Lyerly et al, 2008^114^ | Aerobics Center Longitudinal Study Treadmill/maximal modified Balke protocol United States General population (subgroup of persons with diabetes) | n=2,854 Mean age: 50 yrs (range, 21–84) 100% male Race NR | ST segment depression or elevation ≥1 mm ≥0.08 s from J-point: 11% ST segment depression 0.5–1.0 mm ≥0.08 s: 11% | 16 | Age, sex (100% male), smoking, fasting glucose, hypertension, hypercholesterolemia | CHD death: 11% CVD death: 7.4% All-cause mortality: 15% | Fair
Lyerly et al, 2009^115^ | Aerobic Center Longitudinal Study Treadmill/maximal United States Impaired fasting glucose or undiagnosed diabetes mellitus population | n=3,044 Mean age: 47.4 yrs (range, 20–79) 100% female Mostly white (details NR) | [underlined: Cardiorespiratory fitness] Low: 17% (517/ 3044) Moderate: 34% (1041/3044) High: 49% (1486/ 3044) | 15.6 | Age, sex (100% female), smoking, alcohol use, hypertension, hypercholesterolemia, family history of diabetes | CVD death: 1.6% All-cause mortality: 5.6% | Fair
Mora et al, 2003^116^ | Lipid Research Clinics Prevalence Study Treadmill/maximal Bruce protocol United States General population | n=2,994 Mean age: 47 yrs 100% female 94% white (other races NR) | ST segment depression: 37% Ventricular pre-mature contractions or tachycardia: 7.6% Failure to reach target heart rate: 37% | 20.3 | Age, sex (100% female), smoking, diabetes, LDL, HDL, hypertension | CVD death: 4.9% All-cause mortality: 14% | Good
Mora et al, 2005^117^ | Lipid Research Clinics Prevalence Study Treadmill/standard Bruce protocol United States General population | n=6,126 Mean age: 45 yrs (SD, 10; range NR) 54% male 96% white; other races NR | Heart rate recovery and exercise capacity (based on sex-specific medians) High + high: 28% Either low: 41% Low + low: 31% | 20 | Age, sex, smoking, total cholesterol, HDL, hypertension | 10-yr followup, CVD death: 1.3% 20-yr followup, CVD death: 4% | Fair
Morshedi-Meibodi et al, 2002^118^ | Framingham Offspring Study Treadmill/Bruce protocol United States General population | n=2,967 Mean age: 43 yrs (range NR [SD, 10]) 47% male Race NR | Heart rate recovery: continuous variable Heart rate recovery at 1 min <12 bpm: NR Heart rate recovery at 2 min <42 bpm: NR | 15 | Age, sex, smoking, diabetes, SBP, DBP, HDL, total cholesterol | CHD events: 7.2% CVD events: 10% All-cause mortality: 5.6% | Fair
Okin et al, 1991^119^ | Framingham Offspring Study Treadmill/standard Bruce protocol United States General population | n=3,168 Mean age: 44 yrs (rage, 17–70 [SD, 10]) 48% male Race NR | Heart rate adjusted ST segment depression index ≥1.6 μV bpm: 8.7% Abnormal rate-recovery loop: 6.0% | 4.3 | Age, sex, smoking, diabetes (fasting blood glucose), hypertension (DBP), total cholesterol | CHD events (angina, ischemic chest pain, fatal/nonfatal MI, sudden/nonsudden coronary death): 2.1% (65/3168) | Good
Okin et al, 1996^120^ | Multiple Risk Factor Intervention Trial Treadmill/standard Bruce protocol United States Clinical trial enrollees | n=5,940 Mean age: NR (range, 35–57 yrs) 100% male Race NR | ST segment depression: 3.1% Heart rate adjusted ST segment depression index ≥1.60 μV bpm: 12% | 7 | Age, sex (100% male), DBP, total cholesterol, smoking | CHD death: 1.8% (109/5940) | Fair
Peters et al, 1983^121^ | Study not named Bicycle ergometer/20-min heart-rate-controlled graded exercise test United States Men employed in fire or law enforcement departments | n=2,779 Median age: 41 yrs (mean NR; range, 35–53) 100% male Race NR | Low physical work capacity, defined as <median for each age group (median for entire cohort, 140 W) | 4.8 | Age, sex (100% male), total cholesterol, smoking, hypertension | Fatal MI: 0.2% Nonfatal MI: 1.1% | Fair
Rautaharju et al, 1986^122^ | Multiple Risk Factor Intervention Trial Treadmill/standard Bruce protocol United States Clinical trial enrollees | n=6,150 Mean age: 46 yrs (range, 35–57) 100% male 93% white 7% black | ST segment depression: 12% | 7 | Age, sex (100% male), smoking, DBP, total cholesterol | CHD death: 1.8% CVD death: 2.1% All-cause mortality: 3.8% Silent MI: 2.4% Clinical MI: 3.5% | Good
Rutter et al, 2002^123^ Other publications: Rutter et al, 1999^153^ | Study not named Treadmill United Kingdom Diabetes clinic patients | n=86 Mean age: 62 yrs (range, 45–75) 72% male Race NR | ST segment depression (>1 mm horizontal or down-sloping ST-segment depression 80 ms after J-point for 3 cons. beats): 52% | 2.8 | Age, sex, smoking, hemoglobin A1c, clinic + 24-hr ambulatory BP, total cholesterol (Framingham risk score separate variable) | Any CHD event (cardiac death, MI, new-onset angina): 17% | Fair
Rywik et al, 1998^124^ | Baltimore Longitudinal Study of Aging Treadmill/submaximal modified Balke protocol United States General population | n=825 Mean age: 51 yrs (range, 22–89) 60% male Race NR | ST segment depression: 18% during exercise; 7.6% during recovery | 9 | Age, sex, smoking, cholesterol, hypertension, diabetes (fasting glucose) | Coronary events (angina, MI, coronary death): 6.7% (55/825) | Good
Rywik et al, 2002^125^ | Baltimore Longitudinal Study of Aging Treadmill/modified Balke protocol United States General population volunteers | n=1,083 Mean age: 52 yrs (SD, 18) 57% male Race NR | ≥1 mm horizontal or downsloping ST segment depression (MN code 11.1):16% 0.5–1 or ≥1 mm horizontal or down-sloping ST segment depression (MN codes 11.2, 11.1); <0.5 mm down-sloping ST segment depression or T nadir <0.5 mm below baseline (MN code 11.3); or ST segment depression <0.5 mm at rest or induced by postural shift/hyper-ventilation, worsened to MN code 11.1 during/after test:44% Duration of exercise: continuous variable | 7.9 | Age, sex, total cholesterol, glucose, hypertension | Any coronary event: 7% Specific events- Angina: 3% MI: 2% CHD death: 2% | Fair
Savonen et al, 2007^126^ | Kuopio Ischemic Heart Disease Risk Factor Study Bicycle/maximal symptom-limited exercise test Finland General population | n=1,314 Mean age: 52 yrs (range, 42–61) 100% male Race NR | ST segment depression: 14% Workload (chronotropic index at heart rate of 100 bpm): continuous variable | 12 | Age, sex (100% male), smoking, diabetes, SBP, DBP, HDL, LDL | CHD death: 2.7% CVD death: 3.9% All-cause mortality: 10% | Fair
Siscovick et al, 1991^127^ Other publications: Lipid Research Clinics Program 1984^154^ | Lipid Research Clinics Coronary Primary Prevention Trial Treadmill/submaximal Bruce protocol United States Men with hypercholesterolemia | n=3,617 Mean age: NR (range, 35–59 yrs) 100% male 100% white | ST depression or elevation ≥1 mm or 10 μV-s | 7.4 | Age, sex (100% male), LDL, HDL, smoking, SBP | Acute cardiac event (nonfatal MI and CHD death): 1.8% (51/2893) | Good
Slattery et al, 1988^128^ | US Railroad Study Treadmill/submaximal 3-mine exercise test United States Men employed in US railroad industry | n=2,431 Mean age: NR (range, 22–79 yrs) 100% male 100% white | Heart rate following 3-min submaximal exercise test, categorized into quartiles | NR (max duration, 20 yrs) | Age, sex (100% male), SBP, total cholesterol, smoking | CHD death: 11% All-cause mortality: 27% | Fair
Sui et al, 2007^129^ | Aerobics Center Longitudinal Study Treadmill/modified Balke protocol United States General population | n=26,637 Mean age: NR (range, 18–83 yrs) 78% male Race NR | [underlined: Fitness level, based on duration of maximal treadmill exercise test] Low: lowest quintile Moderate: 2nd and 3rd quintiles High: upper 2 quintiles | 10 | Age, smoking, hypertension, diabetes, dyslipidemia | Any CVD event (MI, revascularization, stroke): 5.7% MI: 1.8% Revascularization: 2.8% Stroke: 1.1% | Fair

Abbreviations: bpm=beats per minute; CHD=coronary heart disease; CVD=cardiovascular disease; DBP=diastolic blood pressure; ECG=electrocardiography; HDL=high-density lipoprotein; LDL=low-density lipoprotein; LVH=left ventricle hypertrophy; METs=metabolic equivalents; MI=myocardial infarction; MN=Minnesota; NR=not reported; SBP=systolic blood pressure; SD=standard deviation; yrs=years.

Nineteen studies were rated as good quality,66,78,94,96,98–102,104,107,111–113,116,119,122,124,127 and the remainder as fair quality (Appendix C2). The most common methodological shortcomings were failure to describe how patients with uninterpretable ECG results were handled (25/38 studies), failure to describe loss to followup (22/38), and failure to describe race when reporting baseline demographic characteristics (24/38). Three studies114,115,123 only enrolled persons with diabetes mellitus or impaired fasting glucose and are reviewed separately.

Reclassification, calibration, and discrimination. No study estimated how accurately exercise ECG plus traditional risk factor assessment classified subjects into high-, intermediate-, or low-risk groups compared with classification based on traditional risk factor assessment alone, or provided data to enable construction of risk stratification tables. One study evaluated risks associated with abnormalities on exercise ECG in subjects stratified into low, intermediate, or high 10-year predicted-risk groups based on traditional risk factors.96 It found that ST segment depression was associated with a slight trend toward progressively weaker risk estimates with lower baseline risk (HR, 2.1 [95% CI, 1.1 to 4.2]; HR, 2.0 [95% CI, 1.0 to 4.0]; and HR, 1.6 [95% CI, 0.56 to 4.3] for high-, intermediate-, and low-risk groups, respectively), but confidence intervals were wide and overlapping. For failure to reach target heart rate, the trend was somewhat more pronounced, but estimates also overlapped (HR, 2.7 [95% CI, 1.5 to 4.7]; HR, 1.7 [95% CI, 0.96 to 3.0]; and HR, 0.74 [95% CI, 0.23 to 2.4]).

One study found a C statistic of 0.73 (confidence intervals not reported) for traditional risk factor assessment using the European Systematic Coronary Risk Evaluation (SCORE) alone compared with 0.76 for SCORE plus exercise ECG variables (including number of metabolic equivalents [METs], peak heart rate, impaired functional capacity, heart rate recovery, ventricular ectopy, and ischemic ST segment changes).95 SCORE was used instead of Framingham risk factor assessment because the latter was associated with a C statistic of 0.57. One other study reported a similar C statistic when comparing a model with the Duke treadmill score to one with the number of METs achieved during exercise, with both controlling for Framingham risk score.104 However, the study did not report the C statistic for the Framingham risk score without exercise ECG findings.

Adjusted risk estimates.

ST depression with exercise. Twenty-one studies evaluated the association between ST depression with exercise and subsequent cardiovascular events (Table 11).66,95,96,99–103,106–109,111, 113,116,120,122,124–127 Estimates were pooled from 12 of the 20 studies.66,95,96,99,100,102,103,107,113,116,120, 125 One study was not included in the meta-analysis because it focused on stroke as an outcome.109 Eight other studies101,106,108,111,122,124,126,127 were excluded because other studies of the same population100,113,120,125,126 also evaluated ST depression and either reported longer duration followup, a preferred outcome (CHD or CVD death), or defined ST segment depression more like the other studies in the meta-analysis.

Table 11 ST Segment Changes on Exercise ECG as a Predictor of Cardiovascular Events

Author, year Study | Sample size Demographics Duration of followup | Definition of exercise-induced ST depression Prevalence | Risk associated with exercise-induced ST depression compared to no ST depression (95% CI)
Aktas, 2004^95^ Study not named | n=3,554 Mean age: 57 yrs (range, 50–75) 81% male Mean followup: 8 yrs | 1 to <2 mm horizontal or downsloping ST segment depression at 80 ms after the J-point: 6.0% ≥2 mm: 4.4% Any depression: 10.4% | All-cause mortality ST segment depression 1 to <2 mm: HR, 1.0 (0.57–1.9)^*^ ≥2 mm: HR, 0.86 (0.32–2.3)
Balady et al, 2004^96^ Framingham Heart Study | n=3,043 Mean age: 45 yrs (range, 30–70) 47% male Mean followup: 18 yrs | ≥1 mm horizontal or downsloping ST segment depression in 3 consecutive beats: 4.3% | Any CHD event^*^: HR, 1.8 (1.2–2.9) in men; HR, 1.9 (0.91–4.0) in women
Bodegard et al, 2004^66^ Study not named | n=2,014 Mean age: 50 yrs (range, 40–59) 100% male Mean followup: 22 yrs | ≥0.50 mm ST segment depression in 3 consecutive beats: 14% | CHD death: HR, 1.5 (1.1–2.0)^*^
Cournot et al, 2006^99^ Study not named | n=1,051 Mean age: 52 yrs (range, 18–79) 64% male Mean followup: 6 yrs | ≥1.0 mm ST segment depression at 80 ms after the J-point in at least 2 leads: 5.3% | Any coronary event (cardiac death, sudden death, MI, or angina) Adjusted for risk factors: HR, 2.3 (0.87–5.6) Adjusted for 10-yr Framingham risk: HR, 2.1 (0.86–5.0)^*^
Ekelund et al, 1989^100^ Lipid Research Clinics Coronary Primary Prevention Trial | n=3,775 Mean age: 47 yrs (range, 35–59) 100% male Mean followup: 7.4 yrs | ST segment depression or elevation ≥1 mm; ST integral decreased by ≥10 μV-s from rest or to negative if positive at rest; ST integral increased by ≥10 μV-s from rest: 8.2% | CHD death: HR, 5.7 (2.7–12)^*^ Nonfatal MI: HR, 1.2 (0.7–2.1) All-cause mortality: HR, 3.3 (1.8–5.9)
Fleg et al, 1990^101^ Baltimore Longitudinal Study of Aging | n=407 Mean age: 60 yrs (range, ≥40) 71% male Mean followup: 4.6 yrs | ≥1 mm horizontal or downsloping ST segment depression (MN code 11.1): 16% | Any coronary event: HR, NS (data NR) when adjusted for traditional risk factors; HR, 2.4 (CI NR) when also adjusted for duration of ETT and percentage of age-predicted maximal heart rate
Giagnoni et al, 1983^102^ Study not named | n=514 Mean age: 44% ages 46–65 yrs (range, 18–65) 73% male Mean followup: 6.0 yrs | ≥1 mm horizontal or downsloping ST segment depression (MN code 11.1): 1.2% | Any coronary event: HR, 4.5 (2.3–8.8)^*^ All-cause mortality: HR, 1.25 (0.39–3.99)
Gordon et al, 1986^103^ Lipid Research Clinics Mortality Follow-up | n=3,640 Mean age: 35% ages 50–79 yrs (range, 30–79) 100% male Mean followup: 8.1 yrs | ≥1 mm ST depression or elevation (with ST integral criteria): 18% | CVD death: HR, 4.2 (2.0–8.9)^*^ All-cause mortality: HR, 3.4 (2.0–5.8)
Josephson et al, 1990^106^ Baltimore Longitudinal Study of Aging | n=726 Mean age: 55 yrs (range, 22–84) 63–87% male (varied by group) Mean followup: 6.4–7.7 yrs | ≥1 mm flat or downsloping ST segment depression 0.08 s after the J-point in the majority of complexes: 12% on initial test, 13% on followup test | [underlined: Cardiac events (angina, nonfatal MI, cardiac death)] ST segment depression on initial test vs. no ST segment depression: HR, 2.7 (1.4–5.3) ST segment depression on followup test vs. no ST segment depression: HR, 2.8 (1.4–5.4)
Jouven et al 2000^107^ Paris Protective Study Other publications: Filipovsky et al, 1992^152^ | n=6,101 Mean age: 48 yrs (range, 42–52) 100% male Mean followup: 23 yrs | J-point depression of ≥1 mm with flat or downsloping ST segment either during exercise or recovery: 4.4% | CVD death: HR, 2.6 (1.9–3.6)^*^
Kurl et al, 2003^108^ Kuopio Ischemic Heart Disease Risk Factor Study | n=1,726 Mean age: 52 yrs (range, 42–60) 100% male Mean followup: 10 yrs | Horizontal or downsloping ST segment depression ≥1.0 mm at 80 ms after the J-point or any ST- segment depression >1.0 mm at 80 ms after the J-point: 7.1% | CHD death: HR, 3.5 (2.0–6.0) Stroke: HR, 2.2 (1.1–4.3)
Kurl et al, 2009^109^ Kuopio Ischemic Heart Disease Risk Factor Study | n=1,639 Mean age: 52 yrs (range, 42–60) 100% male Mean followup: 16 yrs | Horizontal or downsloping ST segment depression ≥1.0 mm at 80 ms after J-point or any ST segment depression of >1.0 mm at 80 ms after J-point: 6.7% | All stroke: HR, 1.6 (0.80–3.4) Ischemic stroke: HR, 1.7 (0.74–3.9)
Laukkanen et al, 2001^111^ Kuopio Ischemic Heart Disease Risk Factor Study | n=1,769 Mean age: 52 yrs (range, 42–60) 100% male Mean followup: 10 yrs | Horizontal or downsloping ST depression ≥1 mm 80 ms after the J-point or any ST depression of >1 mm at 80 ms after the J-point: 11% during exercise; 3.1% during recovery | [underlined: ST depression during exercise] CHD death: HR, 3.5 (1.9–6.5) CVD death: HR, 3.3 (1.9–5.5) Acute coronary event: HR, 1.7 (1.1–2.6) [underlined: ST depression during recovery] CHD death: HR, 4.7 (2.1–11) CVD death: HR, 3.7 (1.8–7.5) Acute coronary event: HR, 2.3 (1.3–4.2)
Laukkanen et al, 2008^113^ Kuopio Ischemic Heart Disease Risk Factor Study | n=1,639 Mean age: 52 yrs (range, 42–60) 100% male Mean followup: 16.6 yrs | Horizontal or downsloping ST depression 1.0 mm 80 ms after the J-point: 6.5% | CVD death: HR, 2.1 (1.1–3.8)^*^ Major CVD events (first fatal or nonfatal coronary or cerebrovascular event): HR, 1.4 (0.91–2.1) All-cause mortality: HR, 1.4 (0.89–2.1)
Mora et al, 2003^116^ Lipid Research Clinics Prevalence Study | n=2,994 Mean age: 46 yrs (range NR) 100% female Mean followup: 20.3 yrs | ≥1 mm horizontal or downsloping ST segment depression 0.08 s after the J-point in the last stage or exercise or recovery | CVD death: HR, 0.88 (0.48–1.6)^*^ All-cause mortality: 0.69 (0.45–1.0)
Okin et al, 1996^120^ Multiple Risk Factor Intervention Trial | n=5,940 Mean age: NR (range, 35–57 yrs) 100% male Mean followup: 7 yrs | ST segment depression: 3.1% Heart rate adjusted ST segment depression index ≥1.60 μV bpm: 12% | [underlined: CHD death] ST segment depression: HR, 1.4 (0.60–3.5)^*^ Abnormal heart rate adjusted ST segment depression index: HR, 3.6 (2.4–5.4)
Rautaharju et al, 1986^122^ Multiple Risk Factor Intervention Trial | n=6,150 Mean age: 46 yrs (range, 35–57), based on entire cohort 100% male Mean followup: 7 yrs | ST segment depression ≥16 μV-s in leads CS5, aVL, aVF, or V5 during or after exercise (in ECG with <6 μV-s ST segment depression at rest): 12% | CHD death: HR, 3.4 (p<0.05; CI NR) CVD death: HR, 3.0 (p<0.01; CI NR) All-cause mortality: HR, 1.6 (p<0.01; CI NR) Clinical MI: HR, 1.7 (p<0.05; CI NR)
Rywik et al, 1998^124^ Baltimore Longitudinal Study of Aging | n=825 Mean age: 51 yrs (range, 22–89) 60% male Mean followup: 9 yrs | ≥1 mm J-point depression with ST segment flat or downsloping in the majority of complexes in any ECG lead except AVR (MN code 4.1): 18% during exercise; 7.6% during recovery | [underlined: Coronary events (angina, nonfatal MI, CHD death)] ST segment depression during exercise vs. no ST segment depression: OR, 2.6 (1.3–5.2) ST segment depression during recovery vs. no ST segment depression: OR, 2.4 (1.0–5.5)
Rywik et al, 2002^125^ Baltimore Longitudinal Study of Aging | n=1,083 Mean age: 52 yrs (SD, 18) (range NR) 57% male Mean followup: 7.9 yrs | ≥1 mm horizontal or downsloping ST segment depression (MN code 11.1): 16% | Coronary events (angina, nonfatal MI, CHD death): HR, 2.7 (1.6–4.7)^*^
Savonen et al, 2007^126^ Kuopio Ischemic Heart Disease Risk Factor Study | n=1,314 Mean age: 52 yrs (range, 42–61) 100% male Mean followup: 12 yrs | Horizontal or downsloping ST segment depression ≥0.5 mm at 80 ms after the J point: 13.9% | CHD death: HR, 4.3 (2.2–8.5) CVD death: HR, 3.1 (1.8–5.6) All-cause mortality: NS (data NR)
Siscovick et al, 1991^127^ Lipid Research Clinics Coronary Primary Prevention Trial | n=3,617 Mean age: NR (range, 35–59 yrs) 100% male Mean followup: 7.4 yrs | ST segment depression or elevation ≥1 mm or 10 μV-s | Definite CHD death during activity: RR, 8.0 (1.5–42.4) Acute cardiac events (nonfatal MI and CHD death): RR, 2.6 (1.3–5.2) Definite nonfatal MI: RR, 1.7 (0.7–4.1)

* Outcome included in meta-analysis.

Abbreviations: AVR=aortic valve replacement; bpm=beats per minute; CHD=coronary heart disease; CI=confidence interval; CVD=cardiovascular disease; ECG=electrocardiography; ETT=exercise treadmill test; HR=hazard ratio; MI=myocardial infarction; MN=Minnesota; NR=not reported; NS=not significant; OR=odds ratio; RR=relative risk; SD=standard deviation; yrs=years.

Among the studies included in the meta-analysis, four studies66,120,124,126 defined abnormal ST segment depression with exercise as ≥0.5 mm and the rest defined abnormal ST segment depression as ≥1.0 mm. Three studies evaluated CHD death,66,100,120 four evaluated CVD death,103,107,113,116 one evaluated all-cause mortality,95 and four evaluated a composite cardiovascular outcome (various combinations of angina, MI, sudden cardiac death, and CHD death).96,99,102,125 Six studies restricted enrollment to men66,100,103,107,113,120 and one study restricted enrollment to women.116 In the remaining studies, the proportion of male subjects ranged from 47 to 81 percent. Duration of followup ranged from 6 to 23 years and the incidence of cardiovascular events ranged from 2 to 15 percent.

After adjusting for traditional cardiac risk factors, the pooled hazard ratio for ST depression with exercise and subsequent cardiovascular events was 2.1 (95% CI, 1.6 to 2.9) (Figure 4).66,95,96,99, 100,102,103,107,113,116,120,125 Although heterogeneity was present (I^2^=71 percent), all of the studies except for two found at least a trend toward an association between exercise-induced ST segment depression and subsequent cardiovascular events. One exception was a study that differed from the others in the meta-analysis because it only enrolled women (HR, 0.88 [95% CI, 0.48 to 1.6]).116 However, exclusion of this study from the meta-analysis resulted in a similar estimate (HR, 2.3 [95% CI, 1.7 to 3.1]) and did not decrease the heterogeneity (I^2^=68 percent). Another exception (HR, 1.0 [95% CI, 0.57 to 1.9]) was a study that only reported all-cause mortality and controlled for traditional risk factors using the SCORE instrument, which it found performed better than the Framingham risk score.95 Excluding this study also resulted in a similar estimate (HR, 2.3 [95% CI, 1.7 to 3.1]) and did not decrease the heterogeneity (I^2^=70 percent). Statistical heterogeneity was not reduced and estimates were similar when studies were stratified according to whether they used a treadmill for exercise (7 studies; HR, 2.0 [95% CI, 1.3 to 3.2]; I^2^=76 percent)95,96,100,103,116,120,125 or a bicycle (3 studies; HR, 2.0 [95% CI, 1.3 to 3.0]; I^2^=83 percent),66, 107,113 whether they evaluated CHD death (3 studies; HR, 2.2 [95% CI, 0.94 to 5.2]; I^2^=82 percent),66,100,120 CVD death (4 studies; HR, 2.1 [95% CI, 1.2 to 3.7]; I^2^=77 percent),103,107,113,116 or a composite cardiovascular outcome (4 studies; HR, 2.6 [95% CI, 1.8 to 3.8]; I^2^=43 percent),96,99,102,125 or whether they were rated as good quality (9 studies; HR, 2.2 [95% CI, 1.6 to 3.1]; I^2^=72 percent)66,96,99,100,102,107,113,116,125 or fair quality (3 studies; HR, 1.8 [95% CI, 0.7 to 4.4]; I^2^=77 percent).95,103,120 In meta-regression analyses, the degree of ST depression deemed abnormal (i.e., >0.5 mm vs. >1 mm) (p=0.53), the proportion of male enrollees (p=0.18), the number of risk factors adjusted for (p=0.52), and the duration of followup (p=0.36) did not explain the between-study variance in hazard ratio estimates.

Figure 4 Meta-Analysis of ST Segment Changes on Exercise ECG as Predictors of Cardiovascular Events

Figure 4 displays a forest plot of studies reporting the hazard ratio for CHD death, cardiovascular disease (CVD) death, and other composite cardiovascular outcomes in study subjects with ST segment changes on exercise ECG compared to subjects without ST changes. Data from Figure 4 are presented in Table 11 and described in Key Question 3 of the Results section of the evidence report, as follows: "After adjusting for traditional cardiac risk factors, the pooled hazard ratio for ST depression with exercise and subsequent cardiovascular events was 2.1 (95% CI, 1.6 to 2.9). Although heterogeneity was present (I2=71%), all of the studies except for two found at least a trend toward an association between exercise-induced ST segment depression and subsequent cardiovascular events."

Chronotropic incompetence. Seven studies evaluated chronotropic incompetence during exercise (Table 12, Figure 5).66,78,94,96,110,116,128 Four studies evaluated failure to achieve target heart rate (either 85 or 90 percent of maximum predicted heart rate) as a dichotomous variable.94,96,110,116 Of these studies, one study evaluated CVD death,116 one CHD death,94 and two various CHD events.110,116 After adjusting for traditional cardiovascular risk factors, the pooled hazard ratio for failure to reach target heart rate and subsequent cardiovascular events was 1.4 (95% CI, 1.3 to 1.6; I^2^=0 percent).94,96,110,116 Two other studies that evaluated chronotropic response as a multicategory variable found that the lowest category was associated with increased risk of cardiovascular events or all-cause mortality compared with the highest category.78,128 One other study evaluated maximum heart rate achieved during exercise as a continuous variable.66 It found that increased maximum heart rate was associated with decreased risk of CHD death (relative risk [RR], 0.75 per 13.3 beats/min [SD, 1] [95% CI, 0.66 to 0.8]).

Table 12 Chronotropic Incompetence, Heart Rate Recovery, and Ventricular Ectopy During Exercise ECG as a Predictor of Cardiovascular Events

Author, year Study | Sample size Demographics Duration of followup | Exercise ECG abnormality Prevalence | Effect Size of ECG abnormality compared to no abnormality (95% CI)
Chronotropic Incompetence
Adabag et al, 2008^94^ Multiple Risk Factor Intervention Trial | n=12,555 Mean age: 46 yrs (range, 35–57) 100% male Mean followup: 7 or 25 yrs (varied by outcome) | Failure to reach 85% of predicted maximum heart rate: 19% | CHD death (25 yrs): HR, 1.4 (1.2–1.5)^*^ All-cause mortality (25 yrs): HR, 1.3 (1.2–1.4) Sudden death (7 yrs): HR, 1.8 (1.3–2.6) Fatal or nonfatal MI (7 yrs): HR, 1.3 (1.1–1.5)
Balady et al, 2004^96^ Framingham Heart Study Other publications: Framingham Study150 | n=3,043 Mean age: 45 yrs (range, 30–70) 47% male Mean followup: 18 yrs | Failure to reach 85% of predicted maximum heart rate: 9.0% | Any CHD event: HR, 1.6 (1.2–2.2)^*^
Bodegard et al, 2004^66^ Study not named | n=2,014 Mean age: 50 yrs (range, 40–59) 100% male Mean followup: 22 yrs | Maximum heart rate: continuous variable | CHD death (per 1 SD maximum heart rate [13.3 bpm]): RR, 0.75 (0.66–0.85)
Jouven et al, 2005^78^ Paris Prospective Study I | n=5,713 Mean age: 48 yrs (range, 42–53) 100% male Mean followup: 23 yrs | Heart rate increase <89 bpm during exercise: 8.3% | [underlined: Heart rate increase <89 vs. >113 bpm during exercise] Sudden death from MI: HR, 4.0 (1.5–11) Nonsudden death from MI: HR, 1.2 (0.62–2.2) All-cause mortality: 1.5 (1.3–1.8)
Lauer et al, 1996^110^ Framingham Offspring Study | n=1,575 Mean age: 43 yrs (range NR) 100% male Mean followup: 7.7 yrs | Failure to reach 85% of predicted maximum heart rate: 21% Increase in heart rate from rest to peak exercise: continuous outcome Ratio of heart rate to metabolic reserve used by stage 2 (7.1 METs) of exercise: continuous outcome | [underlined: Failure to reach target heart rate] CHD events (MI, angina, sudden cardiac death): HR, 1.8 (1.1–2.7)^*^ All-cause mortality: HR, 1.1 (0.59–1.9) [underlined: Increase in heart rate from rest to peak exercise (per 1 SD decrease [12 bpm])] CHD events: HR, 1.3 (1.1–1.5) All-cause mortality: HR, 1.2 (1.0–1.5) [underlined: Ratio of heart rate to metabolic reserve used by stage 2 of exercise (per 1 SD decrease [0.20])] CHD events: HR, 1.4 (1.1–1.6) All-cause mortality: HR, 1.3 (1.0–1.6)
Mora et al, 2003^116^ Lipid Research Clinics Prevalence Study | n=2,994 Mean age: 46 yrs 100% female Mean followup: 20.3 yrs | Failure to reach 90% of predicted maximum heart rate: 37% | CVD death: HR, 1.4 (1.0–2.1) All-cause mortality: HR, 1.2 (1.0–1.5)
Slattery et al, 1988^128^ U.S. Railroad Study | n=2,431 Mean age: NR (range, 22–79 yrs) 100% male Mean followup: NR (max 20 yrs) | Heart rate following 3-min sub-maximal exercise test >127 bpm: 22% | [underlined: Submaximal exercise heart rate 105 vs. 135 bpm] CHD death: HR, 1.2 (1.1–1.3) All-cause mortality: HR, 1.4 (1.3–1.5)
Heart Rate Recovery
Aktas et al, 2004^95^ Study not named | n=3,554 Mean age: 57 yrs (range, 50–75) 81% male 1.8% black (other races NR) Mean followup: 8 yrs | Abnormal heart rate recovery (decrease of <12 beats during first minute following exercise): 15% (549/3554) | All-cause mortality: HR, 1.6 (1.0–2.4)^*^
Cole et al, 2000^98^ Lipid Research Clinics Prevalence Study | n=5,234 Mean age: 44 yrs 61% male 96% white (other races NR) Mean followup: 12 yrs | Abnormal heart rate recovery at 2 min (change in heart rate from peak to 2 minutes into recovery ≤42 bpm): 33% | All-cause mortality: HR, 1.6 (1.2–2.0)^*^ CVD death: HR, 2.0 (1.1–3.4)
Jouven et al, 2005^78^ Paris Prospective Study I | n=5,713 Mean age: 48 yrs (range, 42–53) 100% male Mean followup: 23 yrs | Decrease in heart rate 1 min after cessation of exercise <25 bpm: 5.6% | [underlined: Decrease in heart rate 1 min after cessation of exercise <25 vs. >40 bpm] Sudden death from MI: HR, 2.1 (0.92–4.6) Nonsudden death from MI: HR, 0.93 (0.41–1.7) All-cause mortality: HR, 1.3 (1.1–1.5)
Morshedi-Meibodi et al, 2002^118^ Framingham Offspring Study | n=2,967 Mean age: 43 yrs (range NR [SD, 10]) 47% male Mean followup: 15 yrs | Heart rate recovery index (change in heart rate during 1 min recovery from exercise): continuous variable Abnormal heart rate recovery at 1 min (change in heart rate from peak to 1 minute into recovery <12 bpm): NR Abnormal heart rate recovery at 2 min (change in heart rate from peak to 2 minutes into recovery <42 bpm): NR | [underlined: CHD event] Heart rate recovery index, per ΔHR_1min_: HR, 0.94 (0.83–1.1) Abnormal heart rate recovery at 1 min: HR, 1.1 (0.65–1.8) Abnormal heart rate recovery at 2 min: HR, 1.1 (0.81–1.5) [underlined: CVD event] Heart rate recovery index, per ΔHR_1min_: HR, 0.94 (0.84–1.1) Abnormal heart rate recovery at 1 min: HR, 1.0 (0.66–1.5) Abnormal heart rate recovery at 2 min: HR, 1.2 (0.90–1.5) [underlined: All-cause mortality] Heart rate recovery index, per ΔHR_1min_: HR, 1.1 (0.93–1.2) Abnormal heart rate recovery at 1 min: HR, 1.2 (0.71–2.1)^*^ Abnormal heart rate recovery at 2 min: HR, 0.75 (0.52–1.1)
Ventricular Ectopy
Jouven et al, 2000^107^ Paris Protective Study Other publications: Filipovsky et al, 1992^152^ | n=6,101 Mean age: 48 yrs (range, 42–52) 100% male Mean followup: 23 yrs | Run of ≥2 consecutive PVD or PVD totaling >10% of all VD on ECG: 2.8% | CVD death: RR, 2.5 (1.6–3.9)
Mora et al, 2003^116^ Lipid Research Clinics Prevalence Study | n=2,994 Mean age: 46 yrs 100% female Mean followup: 20.3 yrs | Multifocal or ≥10% PVD in last stage of exercise or recovery, or test terminated due to ventricular tachycardia: 7.6% | CVD death: HR, 1.7 (1.1–2.6) All-cause mortality: HR, 1.2 (0.90–1.6)

* Outcome included in meta-analysis.

Abbreviations: bpm=beats per minute; CHD=coronary heart disease; CI=confidence interval; CVD=cardiovascular disease; ECG=electrocardiography; HR=hazard ratio; METs=metabolic equivalents; MI=myocardial infarction; NR=not reported; PVD=premature ventricular depolarization; RR=relative risk; SD=standard deviation; VD=ventricular depolarization; yrs=years.

Figure 5 Meta-Analyses of Chronotropic Incompetence and Abnormal Heart Rate Recovery on Exercise ECG as Predictors of Cardiovascular Events

Figure 5 displays a forest plot of studies reporting the hazard ratio for cardiovascular events in subjects with chronotropic incompetence or abnormal heart rate recovery on exercise ECG compared to subjects without those abnormalitites. Data from Figure 5 are presented in Table 12 and described in Key Question 3 of the Results section of the evidence report. Results for chronotropic incompetence are described as follows: "After adjusting for traditional cardiovascular risk factors, the pooled hazard ratio for failure to reach target heart rate and subsequent cardiovascular events was 1.4 (95% CI, 1.3 to 1.6; I2=0%)" and results from abnormal heart rate recovery are described as: "The pooled hazard ratio for abnormal heart rate recovery and all-cause mortality based on 3 trials was 1.5 (95% CI, 1.3 to 1.9), with no statistical heterogeneity (I2=0%)."

Heart rate recovery. Four studies evaluated abnormal heart rate recovery after exercise as a predictor of cardiovascular events or all-cause mortality (Table 12, Figure 5).78,95,98,118 The trials varied in how they defined abnormal heart recovery (decrease of 12 or 25 beats/min from peak heart rate 1 minute into recovery, decrease of <42 beats/min after 2 minutes, or assessed as a continuous variable), and one study118 showed no association between abnormal heart rate recovery, based on several definitions, and cardiovascular outcomes or all-cause mortality after adjustment for traditional risk factors (HR, 1.2 [95% CI, 0.71 to 2.1] for abnormal heart rate recovery at 1 minute). Nonetheless, the pooled hazard ratio for abnormal heart rate recovery and all-cause mortality, based on three trials, was 1.5 (95% CI, 1.3 to 1.9), with no statistical heterogeneity (I^2^=0 percent). Cardiovascular-specific outcomes were not reported consistently across the trials and could not be pooled. The fourth trial could not be pooled because it did not analyze heart rate recovery as a dichotomous variable, but it found that recovery at 1 minute of <25 beats/min was associated with increased risk of all-cause mortality compared with heart rate recovery of >40 beats/min.78

Ventricular ectopy. Two studies found that ventricular ectopy during or after exercise ECG was associated with subsequent cardiovascular events (Table 12).107,116 In one study, having ≥2 consecutive premature ventricular depolarizations or frequent (>10 percent) ventricular depolarizations was associated with a hazard ratio of 2.5 (95% CI, 1.6 to 3.9) for cardiovascular death.107 In the other study, presence of multifocal or frequent premature ventricular depolarizations or termination of the test due to ventricular tachyarrhythmia was associated with increased risk of CVD death (HR, 1.7 [95% CI, 1.1 to 2.6]) and all-cause mortality (HR, 1.2 [95% CI, 0.90 to 1.6]).116

Exercise capacity or fitness level. Nine studies evaluated exercise capacity or fitness based on exercise ECG (Table 13).95,97,104,105,113,121,125,126,129 In each of the studies, increased exercise capacity or fitness was consistently associated with decreased risk of cardiovascular events or all-cause mortality. Results could not be pooled because the studies evaluated different markers of exercise capacity or fitness and analyzed them differently (as continuous, dichotomous, or multiple category variables). In two reports from the same study of women, lower METs achieved during exercise predicted CHD death when analyzed as a categorical variable (HR, 3.1 for <5 METs vs. >8 METs [95% CI, 2.1 to 4.8] and HR, 1.9 for 5–8 METs vs. >8 METs [95% CI, 1.3 to 2.9])105 or as a continuous variable (HR, 0.83 per 1 MET increase [95% CI, 0.78 to 0.89]).104 One study of men found that lower exercise capacity (based on highest workload during exercise) was associated with increased risk of CVD death and all-cause mortality when the lowest quartile (<162 W) was compared with the highest quartile (HR, 2.0 for CVD death [95% CI, 1.1 to 3.6] and HR, 2.5 for all-cause mortality [95% CI, 1.7 to 3.7]) or as a continuous variable (per 20 W increment; HR, 0.86 for CVD death [95% CI, 0.79 to 0.93] and HR, 0.85 for all-cause mortality [95% CI, 0.80 to 0.89]).113 Another study found that the number of METs predicted all-cause mortality when evaluated as a dichotomous variable (<9.5 METs for men or <7.5 for women vs. higher number of METs; HR, 3.0 [95% CI, 2.0 to 4.4]) after adjusting for traditional risk factors, or as a continuous variable (HR, 1.3 per 1 MET decrease [95% CI, 1.2 to 1.4]) after adjusting for traditional risk factors and exercise ECG variables.95 One study found that high fitness (defined as exercise time in the upper 2 quintiles) was associated with reduced risk of CVD events (MI, revascularization, or stroke) compared with low fitness (lowest quintile) in men (HR, 0.75 [95% CI, 0.64 to 0.87]).129 The estimate was similar in women, but did not reach statistical significance (HR, 0.78 [95% CI, 0.49 to 1.2]). An earlier report from the same study reported consistent results when subjects were categorized into two rather than three fitness levels (HR, 1.7 [95% CI, 1.3 to 2.2] for men and HR, 2.1 [95% CI, 1.4 to 3.3] for women).97 One study found that low work capacity (defined as <age-based median) was associated with increased risk of fatal or nonfatal MI (RR, 2.2 [95% CI, 1.1 to 4.7]).121 Two other studies evaluated continuous measures of exercise capacity. One study found that increased duration of exercise was associated with decreased risk of coronary events (HR, 0.87 beats/min [95% CI, 0.79 to 0.96]).125 Estimates were similar in women but did not reach statistical significance. The other study found that lower workload achieved at a heart rate of 100 beats/min was associated with increased risk of CHD death (HR, 1.9 per decrement of 31 W [95% CI, 1.3 to 2.8]).126

Table 13 Exercise Capacity or Fitness Level on Exercise ECG as a Predictor of Cardiovascular Events

Author, year Study | Sample size Demographics Duration of followup | Measure of exercise capacity or fitness Prevalence | Effect Size of ECG abnormality compared to no abnormality (95% CI)
Aktas et al, 2004^95^ Study not named | n=3,554 Mean age: 57 yrs (range, 50–75) 81% male Mean followup: 8 yrs | Impaired functional capacity (<9.5 METs for men, <7.5 for women): 25% Exercise capacity (number of METs): continuous variable | [underlined: All-cause mortality] Impaired functional capacity: HR, 3.0 (2.0–4.4) Exercise capacity (per 1 MET decrease): HR, 1.3 (1.2–1.4), adjusted for exercise ECG variables
Blair et al, 1996^97^ Aerobics Center Longitudinal Study Other publications: Wei et al, 1999^151^ | n=32,421 Mean age: 43 yrs (range, 20–88) 79% male Mean followup: 8.2 yrs | Low fitness level (based on treadmill time, least fit 20% of study population): 20% | [underlined: CVD death] Men: HR, 1.7 (1.3–2.2) Women: HR, 2.4 (0.99–5.9) [underlined: All-cause mortality] Men: HR, 1.5 (1.3–1.8) Women: HR, 2.1 (1.4–3.3)
Gulati et al, 2003^105^ St. James Women Take Heart | n=5,271 Mean age: 52 yrs (range NR [SD, 11]) 0% male Mean followup: 8.4 yrs | Exercise capacity (<5, 5–8, or >8 METs): NR | [underlined: All-cause mortality] <5 METs vs. >8 METs: HR, 3.1 (2.1–4.8) 5–8 METs vs. >8 METs: HR, 1.9 (1.3–2.9)
Gulati et al, 2005^104^ St. James Women Take Heart Same population as Gulati et al, 2003^105^ | n=5,636 Mean age: 52 yrs (range NR [SD, 11]) 0% male Mean followup: 8.4 yrs | Exercise capacity (number of METs): continuous variable | CHD death (per unit MET increase): HR, 0.83 (0.78–0.89) All-cause mortality (per unit MET increase): HR, 0.83 (0.78–0.89)
Laukkanen et al, 2008^113^ Kuopio Ischemic Heart Disease Risk Factor Study | n=1,639 Mean age: 52 yrs (range, 42–60 yrs) 100% male Mean followup: 16.6 yrs | Exercise capacity, based on highest workload achieved during exercise test, categorized into quartiles (<162 W [lowest quartile] vs. >230 W [highest quartile]) and per 20 W increment | [underlined: CVD death] <162 W vs. >230 W: HR, 2.0 (1.1–3.6) Per 20 W increment: HR, 0.86 (0.79–0.93) [underlined: Major CVD event] <162 W vs. >230 W: HR, 1.9 (1.4–2.7) Per 20 W increment: HR, 0.88 (0.84–0.93) [underlined: All-cause mortality] <162 W vs. >230 W: HR, 2.5 (1.7–3.7) Per 20 W increment: HR, 0.85 (0.80–0.89)
Peters et al, 1983^121^ Study not named | n=2,779 Median age: 41 yrs (range, 35–53) 100% male Mean followup: 4.8 yrs | Physical work capacity (maximum average power output during 5-min intervals of exercise testing) below median for age group | Fatal or nonfatal MI: RR, 2.2 (1.1–4.7)
Rywik et al, 2002^125^ Baltimore Longitudinal Study of Aging | n=1,083 Mean age: 52 yrs (range NR [SD, 18]) 57% male Mean followup: 7.9 yrs | Duration of exercise (minutes): continuous variable | Coronary events (angina, nonfatal MI, CHD death) (per minute): HR, 0.87 (0.79–0.96)
Savonen et al, 2007^126^ Kuopio Ischemic Heart Disease Risk Factor Study | n=1,314 Mean age: 52 yrs (range, 42–61) 100% male Mean followup: 11.5 yrs | Workload achieved at 100/bpm (WL_100_): continuous variable | CHD death (per decrement of 31 W): HR, 1.9 (1.3–2.8) CVD death (per decrement of 31 W): HR, 1.7 (1.3–2.4) All-cause mortality (per decrement of 31 W): NS (data NR)
Sui et al, 2007^129^ Aerobics Center Longitudinal Study | n=26,637 Mean age: NR (range, 18–83 yrs) 78% male Mean followup: 10 yrs | Fitness level, based on duration of maximal treadmill exercise test: low=lowest quintile; moderate=2nd and 3rd quintiles; high=upper 2 quintiles | [underlined: CVD event (MI, revascularization, stroke) vs. low fitness level group] Men Moderate fitness level: HR, 0.89 (0.78–1.0) High fitness level: HR, 0.75 (0.64–0.87) Women Moderate fitness level: HR, 0.83 (0.54–1.3) High fitness level: HR, 0.78 (0.49–1.2)

Abbreviations: bpm=beats per minute; CHD=coronary heart disease; CI=confidence interval; CVD=cardiovascular disease; ECG=electrocardiography; HR=hazard ratio; METs=metabolic equivalents; MI=myocardial Infarction; NR=not reported; NS=not significant; RR=relative risk; SD=standard deviation; yrs=years.

Other abnormalities on exercise ECG. Three studies evaluated other abnormalities, or combinations of abnormalities, on exercise ECG as predictors of subsequent cardiovascular events (Table 14).97,104,117,131 One study found that decreased peak oxygen pulse (defined as maximal oxygen uptake/peak heart rate) was associated with increased risk of CHD death (HR, 2.4 [95% CI, 1.1 to 5.4] for peak oxygen pulse <13.5 ml/beat vs. >17.8 ml/beat) and all-cause mortality (HR, 1.8 [95% CI, 1.2 to 2.6]).97 One study found that a Duke treadmill score (defined as exercise time − [5 × ST deviation] − [4 × angina score index]) <5 was associated with increased risk of CHD death (HR, 2.7 [95% CI, 1.6 to 4.8]) and all-cause mortality (HR, 2.2 [95% CI, 1.6 to 3.1]).104 The third study found that abnormal exercise ECG was associated with increased risk of CVD death and all-cause mortality, but did not define “abnormal.”97 One study found that presence of both low heart rate recovery and low METs (categorized as “low” or “high” based on sex-specific medians) was a stronger predictor of CVD death at 20 years than presence of either low heart rate recovery or low METs alone (vs. high heart rate recovery and high METs; HR for low heart rate recovery or low METs, 1.5 [95% CI, 0.83 to 2.7] for men and 3.1 [95% CI, 1.3 to 7.4] for women; HR for low heart rate recovery and low METs, 3.5 [95% CI, 2.0 to 6.2] for men and 8.3 [95% CI, 3.6 to 20]) for women.117

Table 14 Other Findings on Exercise ECG as Predictors of Cardiovascular Events

Author, year | Sample Size Demographics Duration of followup | Exercise ECG abnormality Prevalence | Effect size of ECG abnormality compared to no abnormality (95% CI)
Blair et al, 1996^97^ Aerobics Center Longitudinal Study Other publications: Wei et al, 1999^151^ | n=32,421 Mean age: 43 yrs (range, 20–88) 79% male Mean followup: 8.2 yrs | Nonspecific ECG changes at rest or with exercise: 6.8% | [underlined: CVD death] Men: HR, 3.0 (2.2–4.0) Women: HR, 5.0 (1.9–13) [underlined: All-cause mortality] Men: HR, 1.6 (1.3–2.0) Women: HR, 1.6 (0.87–2.8)
Gulati et al, 2005^104^ St. James Women Take Heart Same population as Gulati et al, 2003^105^ | n=5,636 Mean age: 52 yrs (range NR [SD, 11]) Mean followup: 9 yrs | Duke treadmill score (exercise time − [5 × ST deviation] − [4 × angina score index]) <5: NR (mean score, 8) | CHD death: HR, 2.7 (1.6–4.8) All-cause mortality: HR, 2.2 (1.6–3.1)
Laukkanen et al, 2006^112^ Kuopio Ischemic Heart Disease Risk Factor Study | n=1,596 Mean age: 52 yrs (range, 42–61) 100% male Mean followup: 14 yrs | Peak oxygen pulse (VO_2_ max/ maximum heart beat): continuous variable | [underlined: CHD death (reference: peak oxygen pulse >17.8 ml/beat)] Peak oxygen pulse <13.5: HR, 2.4 (1.1–5.4) Peak oxygen pulse 13.5–15.7: HR, 1.2 (0.52–2.8) Peak oxygen pulse 15.8–17.8: HR, 1.3 (0.59–3.0) [underlined: All-cause mortality (reference: peak oxygen pulse >17.8 ml/beat)] Peak oxygen pulse <13.5: HR, 1.8 (1.2–2.6) Peak oxygen pulse 13.5–15.7: HR, 1.2 (0.80–1.8) Peak oxygen pulse 15.8–17.8: HR, 1.2 (0.81–1.8)
Mora et al, 2005^117^ Lipid Research Clinics Prevalence Study | n=6,126 Mean age: 45 yrs (range NR [SD, 10]) 54% male 96% white (other races NR) Followup: 10 yrs and 20 yrs | [underlined: Heart rate recovery (based on peak exercise heart rate - heart rate 2 min after exercise) and exercise capacity (METs), categorized into high or low groups based on sex-specific medians] High heart rate recovery and high METs: 28% Low heart rate recovery or low METs: 41% Low heart rate recovery and low METs: 31% | [underlined: CVD death] 10-yr followup High heart rate recovery and high METs: HR, 1 (referent) Low heart rate recovery or low METs: HR, 1.1 (0.40–2.9) in men; HR, 1.4 (0.36–5.3) in women Low heart rate recovery and low METs: HR, 2.7 (1.1–6.6) in men; HR, 3.8 (1.1–13) in women 20-yr followup High heart rate recovery and high METs: HR, 1 (referent) Low heart rate recovery or low METs: HR, 1.5 (0.83–2.7) in men; HR, 3.1 (1.3–7.4) in women Low heart rate recovery and low METs: HR, 3.5 (2.0–6.2) in men; HR, 8.5 (3.6–20) in women
Okin et al, 1991^119^ Framingham Offspring Study | n=3,168 Mean age: 44 yrs (range, 17–70 [SD, 10]) 48% male Race NR Mean followup: 4.3 yrs | Heart rate adjusted ST segment depression index ≥1.6 μV bpm: 8.7% Abnormal rate-recovery loop: 6.0% | Abnormal heart rate adjusted ST segment depression index + abnormal rate-recovery loop (vs. both normal): HR, 2.7 (1.8–4.0) Abnormal heart rate adjusted ST segment depression index + normal rate-recovery loop, or normal heart rate adjusted ST segment depression index + abnormal rate-recovery loop (vs. both normal): HR, 1.6 (1.1–2.5)

Abbreviations: bpm=beats per minute; CHD=coronary heart disease; CI=confidence interval; CVD=cardiovascular disease; ECG=electrocardiography; HR=hazard ratio; METs=metabolic equivalents;NR=not reported; SD=standard deviation; yrs=years.

Stratification by sex. In studies that stratified results by sex, estimates of risk associated with various exercise ECG abnormalities in men and women were similar, or had overlapping confidence intervals (Table 15).

Table 15 Estimates of Risk Associated With Exercise ECG Abnormalities, Stratified By Sex

Author, year Study | Sample Size Demographics Duration of followup | Definition of abnormality Prevalence | Risk associated with abnormality compared to no abnormality in men (95% CI) | Risk associated with abnormality compared to no abnormality in women (95% CI)
Balady et al, 2004^96^ Framingham Heart Study | n=3,043 Mean age: 45 yrs (range, 30–70) 47% male Mean followup: 18 yrs | ≥1 mm horizontal or downsloping ST segment depression in 3 consecutive beats: 4.3% | Any CHD event: HR, 1.8 (1.2–2.9) | Any CHD event: HR, 1.9 (0.91–4.0)
Balady et al, 2004^96^ Framingham Heart Study Other publications: Framingham Study150 | n=3,043 Mean age: 45 yrs (range, 30–70) 47% male Mean followup: 18 yrs | Failure to reach 85% of predicted maximum heart rate: 9.0% | Any CHD event: HR, 1.8 (1.2–2.4) | Any CHD event: HR, 1.3 (0.74–2.4)
Blair et al, 1996^97^ Aerobics Center Longitudinal Study | n=32,421 Mean age: 43 yrs (range, 20–88) 79% male Mean followup: 8.2 yrs | Abnormal ECG (not defined): 6.8% | CVD death: HR, 3.0 (2.2–4.0) All-cause mortality: HR, 1.6 (1.3–2.0) | CVD death: HR, 5.0 (1.9–13) All-cause mortality: HR, 1.6 (0.87–2.8)
Blair et al, 1996^97^ Aerobics Center Longitudinal Study | n=32,421 Mean age: 43 yrs (range, 20–88) 79% male Mean followup: 8.2 yrs | Low fitness level (based on treadmill time, least fit 20% of study population): 20% | CVD death: HR, 1.7 (1.3–2.2) All-cause mortality: HR, 1.5 (1.3–1.8) | CVD death: HR, 2.4 (0.99–5.9) All-cause mortality: HR, 2.1 (1.4–3.3)
Sui et al, 2007^129^ Aerobics Center Longitudinal Study | n=26,637 Mean age: NR (range, 18–83) 78% male Mean followup: 10 yrs | Fitness level, based on duration of maximal treadmill exercise test: low=lowest quintile; moderate=2nd and 3rd quintiles; high=upper 2 quintiles | [underlined: CHD event (revascularization or MI)] Low fitness level: HR, 1 (referent) Moderate fitness level: HR, 0.87 (0.77–1.0) High fitness level: HR, 0.76 (0.63–0.89) | [underlined: CHD event (revascularization or MI)] Low fitness level: HR, 1 (referent) Moderate fitness level: HR, 0.93 (0.54–1.6) High fitness level: HR, 0.82 (0.45–1.5)
Mora et al, 2005^117^ Lipid Research Clinics Prevalence Study | n=6,126 Mean age: 45 yrs (range NR [SD, 10]) 54% male Mean followup: 20 yrs | [underlined: Abnormal heart rate recovery (peak exercise heart rate − heart rate 2 min after exercise) and low exercise capacity (based on METs); categorized into high or low groups based on sex-specific medians] High heart rate recovery and high METs: 28% Low heart rate recovery or low METs: 41% Low heart rate recovery and low METs: 31% | [underlined: CVD death] High heart rate recovery and high exercise capacity: HR, 1 (referent) Low heart rate recovery or low exercise capacity: HR, 1.5 (0.83–2.7) Low heart rate recovery and low exercise capacity: HR, 3.5 (2.0–6.2) | [underlined: CVD death] High heart rate recovery and high exercise capacity: HR, 1 (referent) Low heart rate recovery or low exercise capacity: HR, 3.1 (1.3–7.4) Low heart rate recovery and low exercise capacity: HR, 8.5 (3.6–20)

Abbreviations: CHD=coronary heart disease; CI=confidence interval; CVD=cardiovascular disease; ECG=electrocardiography; HR=hazard ratio; METs=metabolic equivalents; MI=myocardial infarction; NR=not reported; SD=standard deviation; yrs=years.

Studies of patients with diabetes. Two studies evaluated exercise ECG in persons with diabetes (Table 16).114,123 One study found that 1 mm of ST segment depression or elevation with exercise was associated with an increased risk of CHD death (HR, 2.1 [95% CI, 1.3 to 3.3]) after adjustment for traditional risk factors that was comparable to the risk observed in studies of persons without diabetes.114 The second study also found that exercise-induced ST depression was associated with increased risk of any CHD event (cardiac death, MI, or new-onset angina), but the sample size was small (n=86) and confidence intervals were very imprecise (HR, 21 [95% CI, 2 to 204]).123

Table 16 Abnormalities on Exercise ECG as Predictors of Cardiovascular Events in Persons With Diabetes

Author, year Study | Sample size Demographics Duration of followup | Exercise ECG abnormality Prevalence | Risk associated with ECG abnormality compared to no abnormality (95% CI)
Lyerly et al, 2008^114^ Aerobics Center Longitudinal Study | n=2,854 Mean age: 50 yrs (range, 21–84) 100% male All with diabetes Mean followup: 16 yrs | ST segment depression or elevation ≥1 mm ≥0.08 s from the J-point: 11% ST segment depression 0.5–1.0 mm ≥0.08 s: 11% | [underlined: CHD death] ST depression or elevation ≥1 mm: HR, 2.1 (1.3–3.3) ST segment depression 0.5–1.0 mm: HR, 1.7 (1.0–2.8) [underlined: CVD death] ST segment depression or elevation ≥1 mm: HR, 2.0 (1.4–2.8) ST segment depression 0.5–1.0 mm: HR, 1.6 (1.1–2.5) [underlined: All-cause mortality] ST segment depression or elevation ≥1 mm: HR, 1.4 (1.1–1.8) ST segment depression 0.5–1.0 mm: HR, 1.4 (1.1–1.9)
Lyerly et al, 2009^115^ Aerobics Center Longitudinal Study | n=3,044 Mean age: 47 yrs (range, 20–79) 100% female All with impaired glucose tolerance or undiagnosed diabetes Mean followup: 16 yrs | [underlined: Fitness level, based on age-specific maximal exercise duration and oxygen uptake in METs] Low fitness level: 17% Moderate fitness level: 34% High fitness level: 49% | [underlined: All-cause mortality] Low fitness level: HR, 1 (referent) Moderate fitness level: HR, 0.65 (0.45–0.94) High fitness level: HR, 0.64 (0.43–0.95)
Rutter et al, 2002^123^ Study not named Other publication: Rutter et al, 1999^153^ | n=86 Mean age: 62 yrs (range, 45–75) 72% male All with diabetes Mean followup: 2.8 yrs | ST segment depression (>1 mm horizontal or downsloping ST-segment depression at 80 ms after J-point for 3 consecutive beats): 52% | Any CHD event (cardiac death, MI, or new-onset angina): HR, 21 (2–204)

Abbreviations: CHD=coronary heart disease; CI=confidence interval; CVD=cardiovascular disease; ECG=electrocardiography; HR=hazard ratio; METs=metabolic equivalents; MI=myocardial infarction; yrs=years.

One other study evaluated exercise ECG in women with impaired fasting glucose (100 to 125.9 mg/dL) or undiagnosed diabetes (fasting glucose ≥126 mg/dL, no history of diabetes, and not taking hypoglycemia medication). It found that moderate or high fitness (based on age-specific maximal exercise duration and oxygen uptake in METs) was associated with decreased risk of all-cause mortality compared with low fitness (HR, ~0.65 for either moderate or high fitness).115

## Key Question 4 What Are the Harms of Screening With Resting or Exercise Electrocardiography?

### Summary

We identified no studies that reported harms directly associated with screening with resting ECG, though direct harms are likely to be minimal. One study reported no complications in 377 subjects who underwent exercise ECG. Evidence from populations that included symptomatic persons suggests that harms associated with exercise ECG are likely to be small.

No study evaluated harms associated with followup testing or interventions following resting or exercise ECG. Studies that reported rates of angiography and revascularization procedures following screening with exercise ECG did not meet formal inclusion criteria because they did not report harms associated with these interventions or compare results between screened and unscreened persons. However, such studies might provide some information about potential downstream harms based on known complications associated with these procedures. In 10 studies, the proportion of patients who underwent angiography following screening with exercise ECG ranged from 0.6 to 1.7 percent, after excluding an outlier study. In two studies, 0.5 percent or fewer of patients who underwent screening with exercise ECG subsequently underwent a revascularization procedure. No study evaluated harms associated with use of lipid-lowering therapy or aspirin to reduce cardiovascular risk following screening.

### Evidence

Direct harms. Because resting ECG is noninvasive and does not involve exercise, direct harms are likely to be minimal, but could include anxiety about the test or labeling effects. However, we identified no studies that reported harms directly associated with screening with resting ECG. For exercise ECG, potential direct harms include cardiovascular events associated with exercise, injuries associated with exercise, anxiety about the test, and labeling. One study included in the previous USPSTF review reported no complications in the study population (n=377) as a direct result of screening with exercise ECG.132 Based on survey data that included symptomatic patients, serious adverse events occurring as a result of exercise ECG, including arrhythmia (<0.2 percent), acute MI (0.04 percent), or sudden cardiac death (0.01 percent), are rare. The overall risk of experiencing either an event that requires hospitalization or sudden death has been estimated to be 1 per 10,000 tests.133

Harms associated with subsequent tests or interventions. Screening with resting or exercise ECG could also result in harms related to subsequent tests or interventions. Some patients with abnormalities on resting or exercise ECG might undergo further evaluation for presence of CHD, including use of exercise echocardiography, myocardial perfusion imaging, angiography, or CT angiography. Subsequent interventions might be related to use of lipid-lowering therapy, aspirin, or revascularization procedures.

We identified no studies on harms associated with followup testing or interventions after screening with resting or exercise ECG. We identified 11 studies that reported rates of angiography or revascularization procedures following screening with exercise ECG in asymptomatic persons.95,99,132,134–141 Although these studies did not directly measure harms associated with angiography or revascularization procedures and therefore do not meet formal inclusion criteria, they are discussed here because it might be possible to estimate harms based on the known rates of complications associated with these interventions.

Nine studies132, 34–141 reporting angiography rates were summarized in the previous USPSTF evidence review.8 In these studies, rates of subsequent angiography in primarily asymptomatic patients following an abnormal exercise ECG ranged from 0.6 to 13 percent. One outlier study (13 percent angiography rate)139 evaluated a cohort of veterans with hypertension. Exclusion of this study narrowed the range of observed angiography rates (0.6 to 2.9 percent). Two studies published since the previous USPSTF review (n=4605) reported rates of angiography following screening with exercise ECG as part of a routine, executive physical examination (Table 17).95,99 In these two studies, 8.5 and 10 percent of subjects had an abnormal ST segment response to exercise, and 0.6 and 1.7 percent of the total sample (or within the range from the studies included in the prior USPSTF review) underwent angiography following exercise ECG.95,99 Based on total study samples, 0.1 percent (4/3554) and 0.5 percent (5/1051) underwent a revascularization procedure (coronary artery bypass surgery or a percutaneous coronary intervention) following exercise ECG.95,99

Table 17 Prospective Cohort Studies Describing Downstream Results of Exercise Treadmill Test Screening in Asymptomatic Populations

Author, year | Population | Sample size Demographics | ETT abnormality and proportion with abnormality | Subsequent testing | CHD diagnosis following testing | Subsequent treatment following testing
Aktas et al, 2004^95^ | Asymptomatic members of a preventive executive health program | n=3,554 Mean age: 57 yrs (range, 50–75) 81% male 2% black (other races NR) | [underlined: Ischemic ST changes] 1 mm horizontal or down-sloping depression occurring 80 ms after the J-point in at least 3 consecutive beats and 2 contiguous leads: 10.4% (371/3554) | Nuclear or echocardiography stress imaging: 5.3% (190/3554) Angiography: 0.6% (21/3554) | Nuclear or echo-cardiography stress imaging: 0.5% (16/ 3554) had evidence of ischemia or scar Angiography: 0.06% (2/3554) stenosis | Angiography: 0.08% (3/3554) CABG: 0.03% (1/3554) revascularization
Blumenthal et al, 2003^134^ | Siblings with family history of CHD and no known CAD | n=734 Mean age: 49 yrs* 79% male 24% black (other races NR) *Age reported only for subset of patients with abnormal ETT and/or scintigram | [underlined: Abnormal ETT and/or scintigram] Presence of reversible ischemia: 20.8% | Angiography: 1.43% (105/743) | ≥1 coronary artery with ≥50% stenosis: 5.5% (41/743) ≥1 coronary artery with ≥70% stenosis: 3.2% (24/743) | NR
Boyle et al, 1987^135^ | Random, asymptomatic UK factory workers | n=1,194* Mean age: NR (range, 19–64 yrs) 95% male Race NR *20 participants excluded from analysis; 10 due to incomplete testing, 5 due to inadequate ECG data, 5 due to development of CHD symptoms | [underlined: ST segment/heart rate slope] >13 mm beats^−1^/min/10^−3^ twice within 1 month: 5.8% (68/1174) | Angiography: 2% (24/1174) Further assessment (undefined): 3.3% (39/1174) | Significant coronary narrowing: 0.77% (9/1174) | NR
Cournot et al, 2006^99^ | Asymptomatic, consecutively enrolled, self- and physician-referred from general population | n=1,051 Mean age: 52 yrs (range, 18–79) 64% male Race NR | [underlined: Positive ETT] ST segment depression ≥1.0 mm at 80 ms after the J-point in at least 2 leads: 8.5% (89/1051) | Angiography: 1.7% (18/1051) | NR | Revascularization: 0.48% (5/1051)
Davies et al, 1996^136^ | Asymptomatic, self- and physician-referred from general population | n=5,000 Mean age: 54 yrs (range, 30–65)* 100% male Race NR *Age reported only for subset of patients with positive stress test | [underlined: Positive ECG] Any of the following conditions: fatigue during test, dyspnea, angina, ST segment depression or elevation of ≥1 mm, significant arrythmia: 3.2% (162/5000) | Angiography: 1.7% (86/5000) | CAD (≥75% diameter narrowing of at least one major coronary artery): 1.3% (67/5000) | CABG: 0.5% (26/5000) Angioplasty: 0.1% (7/5000) Medical treatment: 0.7% (34/5000)
Dunn et al, 1991^137^ | Employee- and self-referred patients at a preventive medicine clinic; known CAD excluded | n=1,930 Mean age: NR (range, 22–85 yrs) Median age: 48 yrs in normal ETT group vs. 59 yrs in abnormal ETT group 85% male Race NR | [underlined: Abnormal ETT] ≥1 mm horizontal or downsloping ST segment depression 80 ms after the J-point: 8.5% (155/1930) (8.4% [137/1633] in men; 6% [18/297] in women) | Angiography: 1.2% (23/1930) (1.3% [22/1633] in men; 0.3% [1/297] in women) Thallium scan: 4% (77/1930) (4.3% [71/1633] in men; 2% [6/297] in women) | CAD (abnormal ETT + abnormal thallium scan or abnormal angiography): 1.3% (25/1930) (1.5% [24/1633] in men; 0.3% [1/297] in women) | CABG: 0.3% (6/1930) Percutaneous transluminal coronary angioplasty: 0.6% (11/1930) Medical treatment: 0.4% (8/1930)
Hollenberg et al, 1985^132^ | Asymptomatic, military officers | n=377 Mean age: 37 yrs (range, 31–48) 100% male Race NR | [underlined: Abnormal ETT] ≥1 mm horizontal or down-sloping ST segment depression 80 ms after the J-point (defined as conventional assessment): 12% (45/377) | Angiography: 2.7% (10/377) | Mild CAD (60% proximal obstruction and 70% distal obstruction of right coronary artery): 0.3% (1/377) | NR
Livschitz et al, 2000^138^ | Healthy, male soldiers age >39 yrs undergoing routine physical exam | n=4,900 Mean age: 43 yrs (range NR) 100% male Race NR | [underlined: Abnormal ETT] Exercise-induced chest pain and hypotension, horizontal or downsloping ST depression ≥1 mm, or 1.5 mm upsloping depression 80 ms after the J-point: 6.1% (299/ 4900) | Angiography: 0.8% (4/4900) Repeat study: 2.2% (106/4900) Thallium scan: 2% (78/4900) | CAD: 0.06% (3/4900) | CABG: 0.02% (1/4900) Percutaneous transluminal coronary angioplasty: 0.02% (1/4900)
Massie et al, 1993^139^ | Asymptomatic veterans with hypertension recruited at VA hypertension clinic | n=201 (completed ETT) Mean age: 61 yrs (range NR) 100% male 80% white or Asian (other races NR) | [underlined: Positive ETT] ≥1 μV horizontal or down-sloping ST-segment depression 80 ms after the J-point: 33% (67/201) (includes 180 definitive tests and 21 inconclusive tests) | Angiography: 12.9% (26/201) | CAD: 7% (14/201) | NR
Piepgrass et al, 1982^140^ | Asymptomatic, male Air Force personnel undergoing routine physical exam | n=771 Mean age: 42 yrs (range, 35–54) 100% male Race NR | [underlined: Abnormal ETT] ≥1 μV ST depression 80 ms from the J-point: 3.5% (27/771) | Angiography: 2.5% (19/771) | CAD: 0.5% (4/771) | Removal from duty: 1.1% (8/771) (4 due to CAD, 4 due to declining angiography)
Pilote et al, 1998^141^ | Asymptomatic, consecutively enrolled adults undergoing routine physical exam | n=4,334 Mean age: 52 yrs (median, 51; range NR) 83% male Race NR | [underlined: Abnormal ETT] Presence of ischemic ST-segment changes, drop in blood pressure of ≥10 mmHg, anginal chest pain, failure to reach 85% of maximum age-predicted target heart rate: 14.6% (633/4334) | Angiography: 2.9% (126/4334) Thallium scan: 2.4% (105/4334) | CAD: 1.6% (71/4334) (includes 19 cases [0.4%] of severe CAD) | CABG: 0.8% (34/4334) Percutaneous transluminal coronary angioplasty: 0.4% (16/4334)

Abbreviations: CABG=coronary artery bypass graft; CAD=coronary artery disease; CHD=coronary heart disease; ECG=electrocardiography; ETT=exercise treadmill test; NR=not reported; UK=United Kingdom; VA=U.S. Department of Veterans Affairs; yrs=years.

None of the studies described above estimated complications associated with angiography or revascularization procedures. Based on large, population-based registries, the risk of having any serious adverse event as a result of angiography is 1.7 percent; this includes risk of death (0.1 percent), MI (0.05 percent), stroke (0.07 percent), and arrhythmia (0.4 percent).142

Coronary angiography, CT angiography, and myocardial perfusion imaging are associated with radiation exposure that could increase cancer risk. Coronary angiography is associated with an average effective radiation dose of 7 mSv, accounting for an estimated 5 percent of the total effective dose from all medical imaging procedures.143 Myocardial perfusion imaging is associated with an average radiation dose of 15.6 mSv, accounting for 22 percent of the dose from all medical imaging procedures.143

Patients who have an abnormal screening test and undergo additional testing, but do not have coronary artery disease, are subjected to potential harms without the possibility of benefit. Understanding the false-positive rate for coronary artery disease among persons with abnormalities on resting or exercise ECG could help inform judgments regarding the balance of benefits and harms for screening. However, data on the prevalence of coronary artery disease among persons who underwent coronary angiography as a result of screening ECG (resting or exercise) are limited. One study included in the prior USPSTF review found “severe” coronary artery disease in 15 percent of patients who underwent angiography.141 Another study included in the prior USPSTF review found that 55 percent of patients who underwent angiography had at least 50 percent occlusion in at least one coronary artery, and 37 percent had at least 70 percent occlusion in at least one coronary artery.134 A recent, large (nearly 400,000 patients) study that evaluated a primarily symptomatic (70 percent) population who underwent angiography found that 39 percent of patients had no coronary artery disease (defined as <20 percent stenosis).144

Abnormal findings on resting or exercise ECG could also result in harms associated with increased use of treatments for reducing cardiovascular risk. We identified no studies that assessed harms associated with lipid-lowering therapy or aspirin following ECG screening. General harms associated with lipid-lowering therapy or aspirin for primary prevention of cardiovascular events have been reviewed in other USPSTF reports.33,34