# Methods

## Key Questions and Analytic Framework

The investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers developed the scope and key questions used to guide this review.24–26 The analytic framework shows the key questions used to guide the review (Figure 1).

- Key Question 1. What are the benefits of screening for abnormalities with resting or exercise ECG compared with no screening on CHD outcomes?
- Key Question 2. How does the identification of high-risk persons via resting or exercise ECG affect use of treatments to reduce cardiovascular risk?
- Key Question 3. What is the accuracy of resting or exercise ECG for stratifying persons into high-, intermediate-, and low-risk groups?
- Key Question 4. What are the harms of screening with resting or exercise ECG?

Figure 1 Analytic Framework and Key Questions

Figure 1 is an analytic framework for the key questions of this report that depicts the events that asymptomatic adults could experience while undergoing screening for coronary heart disease (CHD). The figure illustrates how consideration of known risk factors, including age at time of screening, sex, cholesterol, blood pressure, diabetic status, and smoking status can be considered to help determine who would benefit the most from screening for CHD. The figure shows how screening can be accomplished through the use of resting or exercise electrocardiography (ECG), with the potential for risk reclassification and risk-reducing treatments based on the results of ECG testing. The figure portrays the ultimate goal of screening as a reduction in CHD-based health outcomes. The figure also depicts the possibility of harms or adverse events occurring as a result of screening.

The target population for this review was adult women and men ages 18 years and older without symptoms of CHD. The intervention was resting or exercise (treadmill, bicycle, ergometer, or other method) ECG. To evaluate benefits of screening for asymptomatic CHD, we focused on (in order of preference) CHD death, cardiovascular disease (CVD) death, nonfatal MI, all-cause mortality, stroke, and other cardiovascular outcomes (such as CHF). We evaluated composite cardiovascular outcomes only if a study did not report more specific cardiovascular outcomes. To evaluate use of treatments for reducing cardiovascular risk, we focused on use of lipid-lowering therapy and aspirin, because use of these interventions varies depending on the assessed baseline risk.27,28 The use of other preventive cardiovascular interventions such as weight loss, smoking cessation, and blood pressure management are largely unaffected by estimated baseline risk.29–32 To evaluate the usefulness of resting or exercise ECG for risk stratification, we evaluated whether the addition of screening to traditional risk factor assessment resulted in more accurate prediction of persons who experienced subsequent cardiovascular events, or improved the classification of persons into high-, intermediate-, or low-risk groups compared with assessment based on traditional risk factors alone. We also evaluated how the presence of abnormalities on resting or exercise screening ECG affected risk for cardiovascular outcomes after adjustment for traditional risk factors, and likelihood of cardiovascular outcomes. We did not evaluate the accuracy of resting or exercise ECG for identifying the presence or degree of asymptomatic atherosclerosis because of its unclear clinical implications. To evaluate harms of screening, we evaluated rates and consequences of false-positive and false-negative tests, patient anxiety and other psychosocial effects, and unnecessary treatments. We did not review adverse outcomes associated with lipid-lowering therapy and aspirin, as these have been evaluated in other USPSTF reviews.33,34

## Search Strategies

We searched Ovid MEDLINE from January 2002 through January 2011 and the Cochrane Database of Systematic Reviews and the Cochrane Central Register of Controlled Trials through the fourth quarter of 2010 to identify relevant articles. The search of the Cochrane Database of Systematic Reviews failed to identify any publications directly relevant to this report. Complete search strategies are shown in Appendix B1. We identified additional studies from citations in relevant articles and experts, and included studies from the previous USPSTF review that met inclusion criteria.

## Study Selection

We selected studies based on inclusion and exclusion criteria developed for each key question (Appendix B2). All citations were independently reviewed by two investigators before final exclusion. Results of the search and selection process are described in Appendix B3.

We included randomized controlled trials and controlled observational studies that evaluated effects of screening with resting or exercise ECG compared with no screening on clinical outcomes (benefits or harms). We also included large uncontrolled studies that reported harms associated with screening resting or exercise ECG. We included studies that evaluated persons without symptoms of CHD, reported results separately for asymptomatic persons, or included persons with symptoms, if the proportion of patients was <10 percent of the total sample. For usefulness of screening for risk stratification, we included prospective cohort studies that reported rates of cardiovascular outcomes and controlled for at least five of the seven Framingham cardiovascular risk factors (male sex, older age, tobacco use, diabetes, hypertension, high total or LDL cholesterol, and low HDL cholesterol) through restriction (e.g., only enrolling male subjects) or adjustment. Many studies of the same cohort were described in multiple publications; a detailed listing of included studies and publications can be found in Appendix B4. We excluded a number of studies included in prior USPSTF reviews7, 8 because they did not adjust for five or more traditional risk factors35–53 or otherwise did not meet inclusion criteria (Appendixes B5 and B6).54,55

## Data Abstraction and Quality Rating

One investigator abstracted details about the patient population, study design, analysis, followup, and results; data abstraction was checked by a second investigator. We also recorded how many Framingham risk factors and other confounding factors were adjusted for in the model; whether the investigators reported model fit measures, discrimination measures, or model calibration statistics separately for models with and without resting or exercise ECG; and whether the study assessed the degree and accuracy of reclassification into different risk categories on the basis of ECG findings. Two investigators used criteria developed by the USPSTF26 to rate the quality of each study as good, fair, or poor. (Criteria used to rate prospective studies on ECG abnormalities and risk of subsequent cardiovascular events are shown in Appendix B7; criteria for randomized controlled trials of screening are not shown because no such study met inclusion criteria.) We rated studies as good quality if they met all quality criteria or had only minor methodological shortcomings. We rated studies as poor quality if they had multiple, important methodological shortcomings. Other studies were rated as fair quality. Discrepancies were resolved through a consensus process.

## Data Synthesis

We assessed the aggregate internal validity (quality) of the body of evidence for each key question (“good,” “fair,” “poor”) using methods developed by the USPSTF, based on the number, quality, and size of studies, consistency of results between studies, and directness of evidence.26

We used several methods to assess the incremental value of resting or exercise ECG over traditional Framingham risk factor assessment.56 We evaluated how the addition of screening with resting or exercise ECG to traditional risk factor assessment affects reclassification of subjects into high- (10-year risk for CHD or nonfatal MI >20 percent), intermediate- (10-year risk 10–20 percent), or low-risk (10-year risk <10 percent) categories compared with classification based on traditional risk factors alone.57 Reclassification has recently been emphasized in the literature57–60 because understanding the frequency and accuracy by which people are reclassified into different risk categories is important, and can have a significant effect on clinical decisions.6,61 Risk stratification tables are one method for comparing the proportion of patients correctly moved from intermediate to low- and high-risk categories using different risk assessment methods.57

We also evaluated the C statistic for resting or exercise ECG plus traditional risk factor assessment versus the C statistic based on traditional risk factor assessment alone with regard to prediction of subsequent cardiovascular events. The C statistic is a measure of discrimination, or how accurately a risk assessment method separates those individuals with a disease or outcome from those without it.62 It indicates the proportion of all pairs of patients (one with and one without the outcome) in which the patient with the outcome has the higher predicted probability of the outcome. We also evaluated whether adding screening ECG improves calibration, or the degree to which predicted and observed risk estimates are in agreement.59 Compared with measures of discrimination, measures of calibration provide additional information regarding how accurately a risk factor or risk assessment method predicts the likelihood of an outcome in an individual patient. However, measures of discrimination or calibration may be less useful than measures of reclassification for understanding the value of different risk assessment methods, because the former do not necessarily indicate how frequently and accurately people are classified into different risk categories or provide information about the actual predicted risks in an individual patient, which can have important effects on clinical decisions.6,61

Most studies did not provide data to estimate the degree and accuracy of reclassification or report measures of discrimination or calibration. Rather, they provided an estimate of the risk of subsequent cardiovascular events associated with resting or exercise ECG abnormalities after adjusting for traditional risk factors. We conducted meta-analysis for ECG abnormalities on adjusted estimates of risk using the DerSimonian-Laird random effects model with Stata 11.1 software (StataCorp, College Station, TX).63 We focused on CHD death as the preferred outcome, but evaluated other outcomes (CVD death, nonfatal MI, all-cause mortality, or composite cardiovascular outcomes, in order of preference) if CHD death was not available. We performed meta-analyses for resting or exercise ECG abnormalities that were evaluated by at least three studies. For resting ECG, these abnormalities were ST segment changes, T wave changes, ST segment or T wave changes, LVH, bundle branch block, and left axis deviation. For exercise ECG, these were ST depression with exercise and failure to reach target heart rate. We assessed the presence of statistical heterogeneity using standard chi-square tests and estimated the magnitude of heterogeneity using the I^2^ statistic.64 If at least five studies evaluated an outcome, we evaluated potential sources of heterogeneity by performing pooled analyses and meta-regression on studies stratified according to the outcome evaluated (CHD death or another outcome), study quality (good or fair), and use of different definitions for the abnormality being evaluated. We performed sensitivity analyses, excluding outlier studies if they were present. We also performed meta-regression on the proportion of male subjects enrolled in the study, the number of traditional risk factors that the study adjusted for (ranging from five to seven), and the duration of followup.

## External Review

A draft report was reviewed by outside experts, USPSTF members, AHRQ Medical Officers, and federal partners, and was revised based on comments.