# Quality Tables

Appendix C1 Quality Ratings: Cohort Studies of Resting ECG

Author, year | Cohort assembled at a uniform point | Enrolled consecutive patients or a random sample | Described baseline demographic characteristics | Loss to followup was low (<20%) and similar | Outcomes measured using equal, reliable, and valid methods | Described screening test and methods for classifying results | Analyzed outcomes in patients with uninterpretable screening test results | Adjusted analysis | Number of Framingham risk score variables adjusted | Quality rating
Bodegard et al, 2004^66^ | Yes | Yes | No (race not reported) | Low overall: Yes Differential: Yes | Yes | Yes | No (22/2014 excluded) | Yes | 5 | Good
Brown, et al, 2000^67^ | Yes | Yes | Yes | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 6 | Fair
Crow, et al, 2003^68^ | Yes | Yes | Yes | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 7 | Fair
Cuddy et al, 2006^69^ Other sources: www.mfus.ca | Unclear | Unclear | Yes | Low overall: Unclear Differential: Unclear | Unclear | Yes | Unclear | Yes | 5 | Fair
Daviglus et al, 1999^70^ Other publications: Oglesby, 1963^146^ | Yes | Unclear | No (race not reported) | Low overall: Yes Differential: Yes | Yes | Yes | Unclear | Yes | 5 | Fair
De Bacquer et al, 1998^71^ | Yes | Yes | No (race not reported) | Low overall: Yes Differential: Yes | Yes | Yes | Unclear | Yes | 7 | Good
Denes et al, 2007^72^ | Yes | Yes | Yes | Low overall: Yes Differential: Unclear | Yes | Yes | No | Yes | 6 | Good
Dhingra et al, 2006^73^ | Yes | Yes | No (race not reported) | Low overall: Unclear Differential: Unclear | Yes | Yes | Yes | Yes | 7 | Good
Diercks et al, 2002^74^ | Yes | Yes | No (race not reported) | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 6 | Fair
Gottdiener et al, 2000^75^ Other publications: Furberg et al, 1992^147^ | Yes | Yes | Yes | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 7 | Good
Greenland et al, 2003^76^ | Yes | Unclear | Yes | Low overall: Yes Differential: Yes | Yes | Yes | Unclear | Yes | 6 | Fair
Jouven et al, 2005^78^ | Yes | Yes | No (race not reported) | Low overall: Yes Differential: Yes | Yes | Yes | Unclear | Yes | 6 | Good
Kahn et al, 1996^79^ | Yes | Unclear (recruited volunteers) | Yes | Low overall: Yes Differential: Unclear | Unclear | Yes | Unclear | Yes | 5 | Fair
Larsen et al, 2002^80^ | Yes | Yes | Yes | Low overall: Yes Differential: Yes | Yes | Yes | Unclear | Yes | 6 | Good
Liao et al, 1988^81^ | Yes | Yes | Yes (blacks excluded from analysis) | Low overall: Yes Differential: Yes | Yes | Yes | Unclear | Yes | 5 | Fair
Macfarlane et al, 2007^77^ | Yes | Yes | No (race not reported) | Low overall: Yes (12%) Differential: Yes | Yes | Yes | Unclear | Yes | 4 | Fair
Machado et al, 2006^82^ Other publications: ARIC Investigators, 1989^148^ | Yes | Yes | Yes | Low overall: Unclear Differential: Unclear | Yes | Yes | No | Yes | 7 | Fair
Massing et al, 2006^83^ | Yes | Yes | Yes | Low overall: Unclear Differential: Unclear | Yes | Yes | No | Yes | 7 | Fair
Menotti et al, 1997^84^ Other publications: RIFLE Research Group, 1993^149^ | Yes | Yes | Yes | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 5 | Fair
Menotti et al, 2001^85^ Other publications: Menotti et al, 1996^156^ | Yes | Yes | Yes | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 5 | Fair
Moller et al, 2007^86^ | Yes | Yes | No (race not reported) | Low overall: No (27%) Differential: Unclear | Yes | Yes | Unclear | Yes | 7 | Fair
Prineas et al, 2001^87^ | Yes | Yes | Yes | Low overall: Yes Differential: Unclear | Yes | Yes | Unclear | Yes | 5 | Good
Prineas et al, 2002^88^ | Yes | Yes | Yes | Low overall: Yes Differential: Yes | Yes | Yes | Unclear | Yes | 7 | Good
Rautaharju et al, 2006a and 2006b89,90 | Yes | Yes | Yes | Low overall: Unclear Differential: Unclear | Unclear | Yes | No (excluded at baseline) | Yes | 5 | Fair
Rautaharju et al, 2006c91 | Yes | Yes | Yes | Low overall: Unclear Differential: Unclear | Yes | Yes | No (excluded at baseline) | Yes | 5 | Fair
Sigurdsson et al, 1996^92^ | Yes | Yes | No (race not reported) | Low overall: No Differential: Unclear | Unclear | Yes | Unclear | Yes | 6 | Fair
Sutherland et al, 1993^93^ | Yes | Yes | Yes | Low overall: Yes Differential: Yes | Yes | Yes | Unclear | Yes | 6 | Good

Appendix C2 Quality Ratings: Cohort Studies of Exercise ECG

Author, year | Cohort assembled at a uniform point | Enrolled consecutive patients or a random sample | Described baseline demographic characteristics | Loss to followup was low (<20%) and similar | Outcomes measured using equal, reliable, and valid methods | Described screening test and methods for classifying results | Analyzed outcomes in patients with uninterpretable screening test results | Adjusted analysis | Number of Framingham risk score variables adjusted | Quality rating
Aktas et al, 2004^95^ | Yes | Yes | No (race not reported) | Low overall: Unclear Differential: Unclear | Yes | Yes | No | Yes | 7 | Fair
Adabag et al, 2008^94^ | Yes | Yes | Yes | Low overall: Yes Differential: Yes | Yes | Yes | Unclear | Yes | 7 | Good
Balady et al, 2004^96^ Other publications: Framingham Study150 | Yes | Yes | No (race not reported) | Low overall: Yes Differential: Yes | Yes | Yes | Unclear | Yes | 7 | Good
Blair et al, 1996^97^ Other publications: Wei et al, 1999^151^ | Unclear | Unclear | No (race not reported) | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 5 | Fair
Bodegard et al, 2004^66^ | Yes | Yes | No (race not reported) | Low overall: Yes Differential: Yes | Yes | Yes | No (22/2014 excluded) | Yes | 5 | Good
Cole et al, 2000^98^ | Yes | No | Yes | Low overall: Yes Differential: Yes | Yes | Yes | Unclear | Yes | 6 | Good
Cournot et al, 2006^99^ | Yes | Yes | No (race not reported) | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 7 | Good
Ekelund et al, 1989^100^ | Yes | Yes | No (race not reported) | Low overall: Yes Differential: Yes | Yes | Yes | Yes | Yes | 6 | Good
Fleg et al, 1990^101^ | Yes | Yes | Yes | Low overall: Yes Differential: Yes | Yes | Yes | No | Yes | 6 | Good
Giagnoni et al, 1983^102^ | Yes | Yes | No (race not reported) | Low overall: Yes Differential: Yes | Yes | Yes | Unclear | Yes | 5 | Good
Gordon et al, 1986^103^ | Yes | Yes | Yes | Low overall: Yes Differential: Yes | Unclear | Yes | No | Yes | 7 | Fair
Gulati et al, 2003^105^ | Yes | Yes | Yes | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 7 | Fair
Gulati et al, 2005^104^ Same population as Gulati et al, 2003^105^ | Yes | Yes | Yes | Low overall: Unclear Differential: Unclear | Yes | Yes | No (excluded) | Yes | 7 | Good
Josephson et al, 1990^106^ | No | Yes | No (race not reported) | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 5 | Fair
Jouven et al, 2000^107^ Other publications: Filipovsky et al 1992^152^ | Yes | Yes | No (race not reported) | Low overall: Yes Differential: Yes | Yes | Yes | Unclear | Yes | 6 | Good
Jouven et al, 2005^78^ | Yes | Yes | No (race not reported) | Low overall: Yes Differential: Yes | Yes | Yes | Unclear | Yes | 6 | Good
Kurl et al, 2003^108^ | Yes | Yes | No (race not reported) | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 6 | Fair
Kurl et al, 2009^109^ | Yes | Yes | No (race not reported) | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 7 | Fair
Lauer et al, 1996^110^ | Yes | Yes | No (race not reported) | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 5 | Fair
Laukkanen et al, 2001^111^ | Yes | Yes | Yes | Low overall: Yes Differential: Yes | Yes | Yes | Unclear | Yes | 6 | Good
Laukkanen et al, 2006^112^ | Yes | Yes | No (race not reported) | Low overall: Yes Differential: Yes | Yes | Yes | No | Yes | 7 | Good
Lyerly et al, 2008^114^ | Yes | Unclear | No (race not reported) | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 6 | Fair
Lyerly et al, 2009^115^ | Yes | Unclear | No (race not reported) | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 6 | Fair
Mora et al, 2003^116^ | Yes | No (mixed population; 15% random selection) | Yes | Low overall: Yes Differential: Yes | Yes | Yes | Unclear | Yes | 6 | Good
Mora et al, 2005^117^ | Yes | Yes | Yes | Low overall: Unclear Differential: Unclear | Yes | Yes | No | Yes | 6 | Fair
Morshedi-Meibodi et al, 2002^118^ | Yes | Yes | No (race not reported) | Low overall: Unclear Differential: Unclear | Unclear | Yes | Unclear | Yes | 7 | Fair
Okin et al, 1991^119^ | Yes | Yes | Yes | Low overall: Yes Differential: Yes | Yes | Yes | No | Yes | 6 | Good
Okin et al, 1996^120^ | Yes | Yes | No (race not reported) | Low overall: Unclear Differential: Unclear | Yes | Yes | No | Yes | 5 | Fair
Rautaharju et al, 1986^122^ | Yes | Yes | Yes | Low overall: Yes Differential: Yes | Yes | Yes | Unclear | Yes | 5 | Good
Rutter et al, 2002^123^ Other publications: Rutter et al, 1999^153^ | Yes | Yes | No (race not reported) | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 7 | Fair
Rywik et al, 1998^124^ | No | Yes | No (race not reported) | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 6 | Good
Rywik et al, 2002^125^ | Yes | Yes | No (race not reported) | Low overall: Unclear Differential: Unclear | Yes | Yes | No (those unable to achieve ≥85% of max predicted HR on exercise and MN code 11.3 excluded) | Yes | 5 | Fair
Savonen et al, 2007^126^ | Yes | Yes | No (race not reported) | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 7 | Fair
Siscovick et al, 1991^127^ Other publications: Lipid Research Clinics Program 1984^154^ | Yes | Unclear (all patients had high cholesterol | Yes | Low overall: Yes Differential: Yes | Yes | Yes | Yes (included with negative test results) | Yes | 5 | Good
Sui et al, 2007^129^ | Yes | Unclear | No (race not reported) | Low overall: Unclear Differential: Unclear | Yes | Yes | Unclear | Yes | 5 | Fair