# Detailed Methods

## Appendix B1 Search Strategies

### Database: Ovid MEDLINE

#### Key Question 1 Screening

1 | Electrocardiography, ambulatory/ or electrocardiography/ or electrocardiography.mp.
2 | (ekg or ecg).mp.
3 | 1 or 2
4 | Exercise test/
5 | (treadmill adj2 test).mp.
6 | (treadmill and ett).mp.
7 | or/4–6
8 | 3 or 7
9 | Myocardial ischemia/
10 | 8 and 9
11 | Mass screening/
12 | 10 and 11
13 | limit 12 to yr=“2002–2009”
14 | limit 13 to humans
15 | from 14 keep 1–11

#### Key Questions 2 & 3 Risk stratification and diagnostic accuracy

1 | Electrocardiography, ambulatory/ or electrocardiography/ or electrocardiography.mp.
2 | (ekg or ecg).mp.
3 | 1 or 2
4 | Exercise test/
5 | (treadmill adj2 test).mp.
6 | (treadmill and ett).mp.
7 | or/4–6
8 | 3 or 7
9 | Myocardial ischemia/th, mo, di, ep, pc
10 | (coronary heart disease or chd).mp.
11 | 9 or 10
12 | 8 and 11
13 | exp risk/
14 | 12 and 13
15 | limit 14 to yr=“2002–2009”
16 | limit 15 to humans
17 | limit 15 to English language
18 | 16 and 17
19 | limit 18 to “all adult (19 plus years)”
20 | from 19 keep 1–406

#### Key Question 4 Harms

1 | Electrocardiography, ambulatory/ or electrocardiography/ or electrocardiography.mp.
2 | (ekg or ecg).mp.
3 | 1 or 2
4 | Exercise test/
5 | (treadmill adj2 test).mp.
6 | (treadmill and ett).mp.
7 | or/4–6
8 | 3 or 7
9 | (medical errors or iatrogenic disease or false positive reactions).sh.
10 | 8 and 9
11 | limit 10 to (English language and humans)
12 | 11 and (comparative study or clinical trial or controlled clinical trial or randomized controlled trial).pt.
13 | from 12 keep 1–134

### Database: Cochrane Central Register of Controlled Trials

1 | Electrocardiography, ambulatory/ or electrocardiography/ or electrocardiography.mp.
2 | (ekg or ecg).mp.
3 | 1 or 2
4 | Exercise test/
5 | (treadmill adj2 test).mp.
6 | (treadmill and ett).mp.
7 | or/4–6
8 | 3 or 7
9 | Myocardial ischemia/th, mo, di, ep, pc
10 | (coronary heart disease or chd).mp.
11 | 9 or 10
12 | 8 and 11
13 | exp risk/
14 | 12 and 13
15 | limit 14 to yr=“2002–2009”

## Appendix B2 Inclusion and Exclusion Criteria

| Inclusion criteria | Exclusion criteria
Settings | Studies performed in settings generalizable to primary care Studies performed in United States, Canada, and Europe | Studies performed in specialty settings Studies of patients undergoing preoperative evaluation
Populations | Adults ages >18 years without symptoms of coronary heart disease (accepted studies with mixed populations of asymptomatic and symptomatic persons if results were reported separately for asymptomatic persons or <10% of the sample was symptomatic) | Persons with a history of atherosclerotic disease or symptoms suggesting coronary heart disease
Interventions | Resting electrocardiography Exercise electrocardiography | Radiological tests (e.g., thallium scans, scintigraphy, and computed tomography) Echocardiography Vectorcardiography
Outcomes | Coronary heart disease death Cardiovascular disease death Myocardial infarction Angina Stroke Congestive heart failure Composite cardiovascular outcomes All-cause mortality Anxiety, labeling Complications of procedures or treatments initiated as a result of screening | Radiographic progression of coronary artery disease
Study types
Benefits (KQ 1) and use of interventions to reduce cardiovascular risk (KQ 2) | Randomized controlled trials involving resting or exercise electrocardiography in asymptomatic people Controlled observational studies | Non-systematic reviews Case-control studies Cross-sectional studies Hybrid designs that do not clearly stipulate followup and ascertainment procedures Case reports and other uncontrolled studies
Diagnostic accuracy and risk prediction (KQ 3) | Prospective cohort studies that controlled for at least 5 of 7 Framingham cardiovascular risk factors and reported rates of subsequent cardiovascular events
Harms (KQ 4) | Randomized controlled trials involving resting or exercise electrocardiography in asymptomatic people Controlled observational studies Large uncontrolled studies | Case reports Cross-sectional studies

## Appendix B3 Literature Flow Diagram

*Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

† Identified from reference lists, suggested by experts.

Abbreviations: ECG=electrocardiography.

Appendix B3 displays an accounting of studies reviewed for the evidence report. 979 studies were identified through searches of online databases as being potentially relevant to the evidence report. Of those, 662 were excluded at the title or abstract level for not meeting inclusion criteria. The full text of 317 studies were reviewed for inclusion in the evidence report. Of those, 252 were excluded for not meeting inclusion criteria. The remaining 65 studies were included in the final evidence report. Of those, no studies were included for Key Questions 1 and 2, 63 studies were included for Key Question 3, and 2 studies were included for Key Question 4.

## Appendix B4 Included Studies and Companion Papers

Primary publication | Other publications | Name of study/data source
Resting ECG studies
Bodegard et al, 2004^66^ | None | Government employees in Oslo, Norway
Brown, Giles, and Croft, 2000^67^ | None | National Health and Nutrition Examination Survey II
Crow, Hannah, and Folsom, 2003^68^ | None | Atherosclerosis Risk in Community Study
Cuddy and Tate, 2006^69^ | Mathewson FA, Varnam GS. Abnormal electrocardiograms in apparently healthy people, II: the electrocardiogram in the diagnosis of subclinical myocardial disease—serial records of 32 people. Circulation. 1960;21:204–13. Tate RB, Lah L, Cuddy TE, et al. Definition of successful aging by elderly Canadian males: the Manitoba Follow-up Study. Gerontologist. 2003;43(5):735–44. | Manitoba Follow-Up Study
Daviglus et al, 1999^70^ | Paul O, Lepper MH, Phelan WH, et al. A longitudinal study of coronary heart disease. Circulation. 1963;28:20–31. | Chicago Western Electric Study
De Bacquer et al, 1998^71^ | Regional differences in dietary habits, coronary risk factors and mortality rates in Belgium, 1: design and methodology. Acta Cardiol. 1984;39(4):285–92. Kornitzer M, Dramaix M. The Belgian Inter-university Research on Nutrition and Health (BIRNH.) study. Acta Cardiol. 1989;94:89–99. | Belgian Inter-University Research on Nutrition and Health Study
Denes et al, 2007^72^ | Manson JE, Hsia J, Johnson KC, et al. Estrogen plus progestin and the risk of coronary heart disease. N Engl J Med. 2003;349(6):523–34. | Women’s Health Initiative
Dhingra et al, 2006^73^ | None | Framingham Heart Study
Diercks et al, 2002^74^ | Hillege HL, Janssen WM, Bak AA, et al. Microalbuminuria is common, also in a nondiabetic, nonhypertensive population, and an independent indicator of cardiovascular risk factors and cardiovascular morbidity. J Intern Med. 2001;249(6):519–26. Diercks GF, van Boven AJ, Hillege HL, et al. Microalbuminuria is independently associated with ischaemic electrocardiographic abnormalities in a large non-diabetic population: the PREVEND (Prevention of Renal and Vascular Endstage Disease) study. Eur Heart J. 2000;21(23):1922–7. | Prevention of Renal and Vascular End-stage Disease Study
Gottdiener et al, 2000^75^ | Robbins J, Nelson JC, Rautaharju PM, Gottdiener JS. The association between the length of the QT interval and mortality in the Cardiovascular Health Study. Am J Med. 2003;115(9):689–94. | Cardiovascular Health Study
Greenland et al, 2003^76^ | Stamler J, Rhomberg P, Schoenberger JA, et al. Multivariate analysis of the relationship of seven variables to blood pressure: findings of the Chicago Heart Association Detection Project in Industry, 1967–1972. J Chronic Dis. 1975;28(10):527–48. | Chicago Heart Association Detection Project in Industry
Kahn et al, 1996^79^ | Nadelmann J, Frishman W, Ooi W. Prevalence, incidence and prognosis of recognized and unrecognized myocardial infarction in persons aged 75 years or older: the Bronx Aging Study. Am J Cardiol. 1990;66(5):533–7. | Bronx Aging Study
Larsen et al, 2002^80^ | None | Copenhagen City Heart Study
Liao et al, 1988^81^ | Stamler J, Rhomberg P, Schoenberger JA, et al. Multivariate analysis of the relationship of seven variables to blood pressure: findings of the Chicago Heart Association Detection Project in Industry, 1967–1972. J Chronic Dis. 1975;28(10):527–48. | Chicago Heart Association Detection Project in Industry
Macfarlane et al, 2007^77^ | Shepherd J, Cobbe SM, Ford I, et al. Prevention of coronary heart disease with pravastatin in men with hypercholesterolemia. N Engl J Med. 1995;333(20):1301–7. WOSCOPS Study Group. A coronary primary prevention study of Scottish men aged 45–64 years: trial design. J Clin Epidemiol. 1992;45(8):849–60. | West of Scotland Coronary Prevention Study
Machado et al, 2006^82^ | Vitelli LL, Crow RS, Shahar E, et al. Electrocardiographic findings in a healthy biracial population. Am J Cardiol. 1998;81:453–9. | Atherosclerosis Risk in Community Study
Massing et al, 2006^83^ | The Atherosclerosis Risk in Communities (ARIC) study: design and objectives. Am J Epidemiol. 1989;129(4):687–702. | Atherosclerosis Risk in Community Study
Menotti et al, 1997^84^ | Presentation of the RIFLE project risk factors and life expectancy. Eur J Epidemiol. 1993;9(5):459–76. Menotti A, Keys A, Kromhout D, et al. Inter-cohort differences in coronary heart disease mortality in the 25-year follow-up of the seven countries study. Eur J Epidemiol. 1993;9(5):527–36. | Risk Factors and Life Expectancy Project
Menotti et al, 2001^85^ | None | FINE (Finland, Italy, and the Netherlands) Study
Moller et al, 2007^86^ | Hedstrand H. A study of middle-aged men with particular reference to risk factors for cardiovascular disease. Ups J Med Sci Suppl. 1975;19:1–61. | Uppsala Longitudinal Study of Adult Men
Prineas et al, 2002^88^ | Multiple Risk Factor Intervention Trial: risk factor changes and mortality results. JAMA. 1982;248(12):1465–77. | Multiple Risk Factor Intervention Trial
Rautaharju et al, 2006^89^ | Design of the Women’s Health Initiative clinical trial and observational study. Control Clin Trials. 1998;19(1):61–109. Rossouw JE, Anderson GL, Prentice RL, et al. Risks and benefits of estrogen plus progestin in healthy postmenopausal women: principal results from the Women’s Health Initiative randomized controlled trial. JAMA. 2002;288(3):321–33. Manson JE, Hsia J, Johnson KC, et al. Estrogen plus progestin and the risk of coronary heart disease. N Engl J Med. 2003;349(6):523–34. | Women’s Health Initiative
Rautaharju et al, 2006^90^ | Ives DG, Fitzpatrick AL, Bild DE, et al. Surveillance and ascertainment of cardiovascular events: the Cardiovascular Health Study. Ann Epidemiol. 1995;5(4):278–85. Rautaharju PM, Park LP, Chaitman BR, Rautaharju F, Zhang ZM. The Novacode criteria for classification of ECG abnormalities and their clinically significant progression and regression. J Electrocardiol. 1998;31(3):157–87. | Cardiovascular Health Study
Sigurdsson et al, 1996^92^ | Sigurdsson E, Sigfusson N, Agnarsson U, et al. Long-term prognonsis of different forms of coronary heart disease: the Reykjavik study. Int J Epidemiol. 1995;24(1):58–68. Sigurdsson E, Thorgeirsson G, Sigvaldason H, Sigfusson N. Prevalence of coronary heart disease in Icelandic men 1968–1986. Eur Heart J. 1993;14:584–91. Sigurdsson E, Thorgeirsson G, Sigvaldason H, Sigfusson N. Unrecognized myocardial infarction: epidemiology, clinical characteristics, and the prognostic role of angina pectoris. Ann Intern Med. 1995;122(2):96–102. | Reykjavik Study
Sutherland et al, 1993^93^ | Boyle E, Griffey WP, Nichaman MZ, Talbert CR. An epidemiologic study of hypertension among racial groups of Charleston County, SC: the Charleston Heart Study, phase II. In: The Epidemiology of Hypertension. New York: Grune & Stratton; 1967:193–203. | Charleston Heart Study
Exercise treadmill test studies
Adabag et al, 2008^94^ | Coronary heart disease death, nonfatal acute myocardial infarction and other clinical outcomes in the Multiple Risk Factor Intervention Trial. Am J Cardiol. 1986;58(1):1–13. | Multiple Risk Factor Intervention Trial
Aktas et al, 2004^95^ | None | Unamed Clevland Clinic study
Balady et al, 2004^96^ | Kannel WB, Feinleib M, McNamara PM, et al. An investigation of coronary heart disease in families: the Framingham Offspring Study. Am J Epidemiol. 1979;110(3):281–90. | Framingham Heart Study
Blair et al, 1996^97^ | None | Aerobics Center Longitudinal Study
Bodegard et al, 2004^66^ | None | Government employees in Oslo, Norway
Cole et al, 2000^98^ | Plasma lipid distributions in selected North American populations: the Lipid Research Clinics Program Prevalence Study. Circulation. 1979;60(2):427–39. Williams OD, Mowery RL, Waldman GT. Common methods, different populations: the Lipid Research Clinics Program Prevalence Study. Circulation. 1980;62(4 Pt 2):iv18–23. Criqui MH, Haskell WL, Heiss G, et al. Predictors of systolic blood pressure response to treadmill exercise: the Lipid Research Clinics Program Prevalence Study. Circulation. 1983;68(2):225–33. Ekelund LG, Haskell WL, Johnson JL, et al. Physical fitness as a predictor of cardiovascular mortality in asymptomatic North American men: the Lipid Research Clinics Mortality Follow-up Study. N Engl J Med. 1988;319(21):1379–84. | Lipid Research Clinics Program Prevalence Study
Cournot et al, 2006^99^ | None | French general population (self- or physician-referred)
Ekelund et al, 1989^100^ | The Coronary Primary Prevention Trial: design and implementation. J Chronic Dis. 1979;32(9–10):609–31. The Lipid Research Clinics Coronary Primary Prevention Trial results, I: reduction in incidence of coronary heart disease. JAMA. 1984;251(3):351–64. Gordon DJ, Ekelund LG, Karon JM, et al. Predictive value of the exercise tolerance test for mortality in North American men: the Lipid Research Clinics Mortality Follow-up Study. Circulation. 1986;74(2):252–61. | Lipid Research Clinics Program Prevalence Study
Fleg et al, 1990^101^ | Shock NW, Greulich RC, Andres RA, et al. Normal Human Aging: The Baltimore Study of Aging. Bethesda, MD: National Institutes of Health; 1984. | Baltimore Longitudinal Study on Aging
Giagnoni et al, 1983^102^ | None | Unamed Lombard, Italy study
Gordon et al, 1986^103^ | Plasma lipid distributions in selected North American populations: the Lipid Research Clinics Program Prevalence Study. Circulation. 1979;60(2):427–39. Heiss G, Tamir I, Davis CE, et al. Lipoprotein-cholesterol distributions in selected North American populations: the Lipid Research Clinics Program Prevalence Study. Circulation. 1980;61(2):302–15. | Lipid Research Clinics Program Prevalence Study
Gulati et al, 2003^105^ | None | St. James Women Take Heart Project
Gulati et al, 2005^104^ | None | St. James Women Take Heart Project
Josephson et al, 1990^106^ | Shock NW, Greulich RC, Andres RA, et al. Normal Human Aging: The Baltimore Study of Aging. Bethesda, MD: National Institutes of Health; 1984. | Baltimore Longitudinal Study of Aging
Jouven and Ducimetiere, 2000^107^ | Filipovsky J, Ducimetiere P, Safar M. Prognostic significance of exercise blood pressure and heart rate in middle-aged men. Hypertension. 1992;20(3):333–9. | Paris Prospective Study
Kurl et al, 2003^108^ | None | Kuopio Ischemic Heart Disease Risk Factor Study
Kurl et al, 2009^109^ | None | Kuopio Ischemic Heart Disease Risk Factor Study
Lauer et al, 1996^110^ | Dawber TR, Meadors GF, Moore FE Jr. Epidemiological approaches to heart disease: the Framingham Study. Am J Public Health Nations Health. 1951;41(3):279–81. Dawber TR, Kannel WB, Lyell LP. An approach to longitudinal studies in a community: the Framingham Study. Ann N Y Acad Sci. 1963;107:539–56. Kannel WB, Feinleib M, McNamara PM, et al. An investigation of coronary heart disease in families: the Framingham Offspring Study. Am J Epidemiol. 1979;110(3):281–90. | Framingham Heart Study
Laukkanen et al, 2001^111^ | Salonen JT. Is there a continuing need for longitudinal epidemiologic research? The Kuopio Ischaemic Heart Disease Risk Factor Study. Ann Clin Res. 1988;20(1–2):46–50. | Kuopio Ischemic Heart Disease Risk Factor Study
Laukkanen et al, 2006^112^ | None | Kuopio Ischemic Heart Disease Risk Factor Study
Lyerly et al, 2008^114^ | None | Aerobic Center Longitudinal Study
Morshedi-Meibodi et al, 2002^118^ | Kannel WB, Feinleib M, McNamara PM, et al. An investigation of coronary heart disease in families. the Framingham Offspring Study. Am J Epidemiol. 1979;110(3):281–90. | Framingham Heart Study
Okin et al, 1991^119^ | Feinleib M, Kannel WB, Garrison RJ, et al. The Framingham Offspring Study: design and preliminary data. Prev Med. 1975;4(4):518–25. | Framingham Heart Study
Okin et al, 1996^120^ | Rautaharju PM, Prineas RJ, Eifler WJ, et al. Prognostic value of exercise electrocardiogram in men at high risk of future coronary heart disease: Multiple Risk Factor Intervention Trial experience. J Am Coll Cardiol. 1986;8(1):1–10. Statistical design considerations in the NHLI Multiple Risk Factor Intervention Trial (MRFIT). J Chronic Dis. 1977;30(5):261–75. Multiple Risk Factor Intervention Trial: risk factor changes and mortality results. JAMA. 1982;248(12):1465–77. Baseline rest electrocardiographic abnormalities, antihypertensive treatment, and mortality in the Multiple Risk Factor Intervention Trial. Am J Cardiol. 1985;55(1):1–15. Multiple Risk Factor Intervention Trial Research Group. Exercise electrocardiogram and coronary heart disease mortality in the Multiple Risk Factor Intervention Trial. Am J Cardiol. 1985;55:16–24. | Multiple Risk Factor Intervention Trial
Rautaharju et al, 1986^122^ | Multiple Risk Factor Intervention Trial: risk factor changes and mortality results. JAMA. 1982;248(12):1465–77. Baseline rest electrocardiographic abnormalities, antihypertensive treatment, and mortality in the Multiple Risk Factor Intervention Trial. Am J Cardiol. 1985;55(1):1–15. Exercise electrocardiogram and coronary heart disease mortality in the Multiple Risk Factor Intervention Trial. Am J Cardiol. 1985;55:16–24. | Multiple Risk Factor Intervention Trial
Rutter et al, 2002^123^ | Rutter MK, McComb JM, Brady S, Marshall SM. Silent myocardial ischemia and microalbuminuria in asymptomatic subjects with non-insulin-dependent diabetes mellitus. Am J Cardiol. 1999;83(1):27–31. | Clinic patients in England
Rywik et al, 1998^124^ | Shock NW, Greulich RC, Andres RA, et al. Normal Human Aging: The Baltimore Study of Aging. Bethesda, MD: National Institutes of Health; 1984. | Baltimore Longitudinal Study of Aging
Savonen et al, 2007^126^ | None | Kuopio Ischemic Heart Disease Risk Factor Study
Siscovick et al, 1991^127^ | The Coronary Primary Prevention Trial: design and implementation. J Chronic Dis. 1979;32(9–10):609–31. The Lipid Research Clinics Coronary Primary Prevention Trial results, I: reduction in incidence of coronary heart disease. JAMA. 1984;251(3):351–64. | Lipid Research Clinics Program Coronary Primary Prevention Trial
Special populations – diabetes
Lyerly et al, 2008^114^ | None | Aerobic Center Longitudinal Study
Rutter et al, 2002^123^ | Rutter MK, McComb JM, Brady S, Marshall SM. Silent myocardial ischemia and microalbuminuria in asymptomatic subjects with non-insulin-dependent diabetes mellitus. Am J Cardiol. 1999;83(1):27–31. | Clinic patients in England

## Appendix B5 Excluded Studies From Prior USPSTF Evidence Reviews

Author, year | Source | Reason for exclusion
Allen et al, 1980^1^ | 2004 report | Did not adjust for ≥5 Framingham risk factors
Blumenthal et al, 1996^2^ | Annals | Did not adjust for ≥5 Framingham risk factors
Cullen et al, 1982^3^ | 2004 report | Did not adjust for ≥5 Framingham risk factors
Cumming et al, 1975^4^ | 2004 report | Did not adjust for ≥5 Framingham risk factors
Dunn et al, 1990^5^ | 2004 report | Did not adjust for ≥5 Framingham risk factors
Froelicher et al, 1974^6^ | 2004 report | Did not adjust for ≥5 Framingham risk factors
Frolkis et al, 2003^7^ | Annals | >15% of patients with history of CHD at baseline
Gibbons et al, 2000^8^ | Annals | Did not adjust for ≥5 Framingham risk factors
Hames et al, 1993^9^ | 2004 report | Adjusted hazard ratios not reported
Jones et al, 2002^10^ | 2004 report | Did not adjust for ≥5 Framingham risk factors
Kannel and Abbott, 1986^11^ | 2004 report | Did not adjust for ≥5 Framingham risk factors
Kannel et al, 1987^12^ | 2004 report | Did not adjust for ≥5 Framingham risk factors
Kannel and Cobb, 1992^11^ | 2004 report | Did not adjust for ≥5 Framingham risk factors
Katzel et al, 1999^13^ | Annals | Did not adjust for ≥5 Framingham risk factors
Knutsen et al, 1988^14^ | 2004 report | Did not adjust for ≥5 Framingham risk factors
McHenry et al, 1984^15^ | 2004 report | Did not adjust for ≥5 Framingham risk factors
Pedoe, 1978^16^ | 2004 report | Did not adjust for ≥5 Framingham risk factors
Rabkin et al, 1982^17^ | 2004 report | Did not adjust for ≥5 Framingham risk factors
Reunanen et al, 1978^18^ | 2004 report | Did not adjust for ≥5 Framingham risk factors
Rose et al, 1978^19^ | 2004 report | Did not adjust for ≥5 Framingham risk factors
Sullivan et al, 1993^20^ | 2004 report | Did not adjust for ≥5 Framingham risk factors
Verdecchia et al, 2000^21^ | 2004 report | Did not adjust for ≥5 Framingham risk factors

### References

1 Allen WH, Aronow WS, Goodman P, Stinson P. Five-year follow-up of maximal treadmill stress test in asymptomatic men and women. Circulation. 1980;62(3):522-7. [pmid: 7398012].
2 Blumenthal RS, Becker DM, Moy TF, et al. Exercise thallium tomography predicts future clinically manifest coronary heart disease in high-risk asymptomatic men. Am J Cardiol. 1996;93:915-23.
3 Cullen K, Stenhouse NS, Wearne KL, Cumpston GN. Electrocardiograms and 13 year cardiovascular mortality in Busselton study. Brit Heart J. 1982;47(3):209-12. [pmid: 6174132].
4 Cumming GR, Samm J, Borysyk L, Kich L. Electrocardiographic changes during exercise in asymptomatic men: 3-year follow-up. Can Med Assoc J. 1975;112(5):578-81. [pmid: 1116087].
5 Dunn FG, McLenachan J, Isles CG, et al. Left ventricular hypertrophy and mortality in hypertension: an analysis of data from the Glasgow Blood Pressure Clinic. J Hypertens. 1990;8(8):775-82. [pmid: 2170517].
6 Froelicher VF Jr, Thomas MM, Pillow C, Lancaster MC. Epidemiologic study of asymptomatic men screened by maximal treadmill testing for latent coronary artery disease. Am J Cardiol. 12. 1974;34(7):770-6. [pmid: 4432807].
7 Frolkis JP, Pothier CE, Blackstone EH, Lauer MS. Frequent ventricular ectopy after exercise as a predictor of death. N Engl J Med. 2003;348(9):781-90. [pmid: 12606732].
8 Gibbons LW, Mitchell TL, Wei M, et al. Maximal exercise test as a predictor of risk for mortality from coronary heart disease in asymptomatic men. Am J Cardiol. 2000;86(1):53-8. [pmid: 10867092].
9 Hames CG, Rose K, Knowles M, et al. Black-white comparisons of 20-year coronary heart disease mortality in the Evans County Heart Study. Cardiology. 1993;82(2–3):122-36. [pmid: 8324775].
10 Jones DW, Chambless LE, Folsom AR, et al. Risk factors for coronary heart disease in African Americans: the Atherosclerosis Risk in Communities study, 1987–1997. Arch Intern Med. 2002;162(22):2565-71. [pmid: 12456228].
11 Kannel WB, Abbott RD. A prognostic comparison of asymptomatic left ventricular hypertrophy and unrecognized myocardial infarction: the Framingham Study. Am Heart J. 1986;111(2):391-7. [pmid: 2936230].
12 Kannel WB, Anderson K, McGee DL, et al. Nonspecific electrocardiographic abnormality as a predictor of coronary heart disease: the Framingham Study. Am Heart J. 1987;113(2 Pt 1):370-6. [pmid: 3812192].
13 Katzel LI, Sorkin JD, Goldberg AP. Exercise-induced silent myocardial ischemia and future cardiac events in healthy, sedentary, middle-aged and older men. J Am Geriatr Soc. 1999;47(8):923-9. [pmid: 10443851].
14 Knutsen R, Knutsen SF, Curb JD, et al. The predictive value of resting electrocardiograms for 12-year incidence of coronary heart disease in the Honolulu Heart Program. J Clin Epidemiol. 1988;41(3):293-302. [pmid: 3339383].
15 McHenry PL, O’Donnell J, Morris SN, Jordan JJ. The abnormal exercise electrocardiogram in apparently healthy men: a predictor of angina pectoris as an initial coronary event during long-term follow-up. Circulation. 1984;70(4):547-51. [pmid: 6478560].
16 Pedoe HD. Predictability of sudden death from resting electrocardiogram: effect of previous manifestations of coronary heart disease. Brit Heart J. 1978;40(6):630-5. [pmid: 656237].
17 Rabkin SW, Mathewson FL, Tate RB. The electrocardiogram in apparently healthy men and the risk of sudden death. Brit Heart J. 1982;47(6):546-52. [pmid: 6177327].
18 Reunanen A, Pyorala K, Punsar S, Aromaa A. Predictive value of ECG findings with respect to coronary heart disease mortality. Adv Cardiol. 1978;21:310-2. [pmid: 619560].
19 Rose G, Baxter PJ, Reid DD, McCartney P. Prevalence and prognosis of electrocardiographic findings in middle-aged men. Brit Heart J. 1978;40(6):636-43. [pmid: 656238].
20 Sullivan JM, Vander Zwaag RV, el-Zeky F, et al. Left ventricular hypertrophy: effect on survival. J Am Coll Cardiol. 1993;22(2):508-13. [pmid: 8335822].
21 Verdecchia P, Dovellini EV, Gorini M, et al. Comparison of electrocardiographic criteria for diagnosis of left ventricular hypertrophy in hypertension: the MAVI study. Ital Heart J. 2000;1(3):207-15. [pmid: 10806988].

## Appendix B6 Excluded Studies List

### Contextual Only

Cushman WC, Evans GW, et al. Accord Study Group. Effects of intensive blood-pressure control in type 2 diabetes mellitus. N Engl J Med. 2010;362(17):1575-85. [pmid: 20228401].
American College of Sports Medicine. ACSM’s Guidelines for Exercise Testing and Prescription. 6. Philadelphia. Lippincott Williams & Wilkins. 2000.
Blumenthal RS, Becker DM, Yanek LR, et al. Detecting occult coronary disease in a high-risk asymptomatic population. Circulation. 2003;107(5):702-7. [pmid: 12578872].
Chobanian AV, Bakris GL, Black HR, et al. The Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report. JAMA. 2003;289(19):2560-72. [pmid: 12748199].
Cook NR. Statistical evaluation of prognostic versus diagnostic models: beyond the ROC curve. Clin Chem. 2008;54(1):17-23. [pmid: 18024533].
Filipovsky J, Ducimetiere P, Safar M. Prognostic significance of exercise blood pressure and heart rate in middle-aged men. Hypertension. 1992;20(3):333-9. [pmid: 1387630].
Grundy SM, Cleeman JI, Merz CN, et al. Implications of recent clinical trials for the National Cholesterol Education Program Adult Treatment Panel III guidelines. Circulation. 2004;110(2):227-39. [pmid: 15249516].
Johnson RL, Bungo MW. The diagnostic accuracy of exercise electrocardiography—a review. Aviat Space Envir Md. 1983;54(2):150-7.
Lauer M, Sivarajan Froelicher E, Williams M, et al. Exercise testing in asymptomatic adults: a statement for professionals from the American Heart Association Council on Clinical Cardiology, Subcommittee on Exercise, Cardiac Rehabilitation and Prevention. Circ J. 2005;112:771-6.
Lloyd-Jones DM. Prediction of lifetime risk for cardiovascular disease by risk factor burden at 50 years of age. Circulation. 2005;113:791-8. [pmid: 16461820].
McTigue KM, Harris R, Hemphill B, et al. Screening and interventions for obesity in adults: summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2003;139(11):933-49. [pmid: 14644897].
Ohman EM, Granger CB, Harrington RA, et al. Risk stratification and therapeutic decision making in acute coronary syndromes. JAMA. 2000;284(7):876-8. [pmid: 10938178].
Okin PM, Devereux RB, Kors JA, et al. Computerized ST depression analysis improves prediction of all-cause and cardiovascular mortality: the Strong Heart Study. Ann Noninvas Electrol. 2001;6(2):107-16.
Pilote L, Pashkow F, Thomas JD, et al. Clinical yield and cost of exercise treadmill testing to screen for coronary artery disease in asymptomatic adults. Am J Cardiol. 1998;81(2):219-24. [pmid: 9591907].
Redberg RF, Benjamin EJ, Bittner V, et al. ACCF/AHA 2009 performance measures for primary prevention of cardiovascular disease in adults: a report of the American College of Cardiology Foundation/American Heart Association Task Force on Performance Measures. Circulation. 2009;120(13):1296-336. [pmid: 19770388].
Sox HC Jr, Garber AM, Littenberg B. The resting electrocardiogram as a screening test. Ann Intern Med. 1989;111:489-502. [pmid: 2528311].
Sox HC Jr, Littenberg B, Garber AM. The role of exercise testing in screening for coronary artery disease. Ann Intern Med. 1989;110(6):456-69. [pmid: 2493211].
Stern RH. Evaluating new cardiovascular risk factors for risk stratification. J Clin Hypertens. 2008;10(6):485-8.
U.S. Preventive Services Task Force. Counseling and interventions to prevent tobacco use and tobacco-caused disease in adults and pregnant women: U.S. Preventive Services Task Force reaffirmation recommendation statement. Ann Intern Med. 2009;150(8):551-5. [pmid: 19380855].
U.S. Preventive Services Task Force. Aspirin for the prevention of cardiovascular disease: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2009;150(6):396-404. [pmid: 19293072].
Vasan RS, Sullivan LM, Wilson PW, et al. Relative importance of boderline and elevated levels of coronary heart disease risk factors. Ann Intern Med. 2005;142:393-402. [pmid: 15767617].
Women’s Health Initiative Study Group. Design of the Women’s Health Initiative clinical trial and observational study. Control Clin Trials. 1998;19(1):61-109. [pmid: 9492970].

### Wrong Population

Achenbach S, Ropers D, Kallert L, et al. Transradial versus transfemoral approach for coronary angiography and intervention in patients above 75 years of age. Catheter Cardio Int. 2008;72(5):629-35.
Aijaz B, Babuin L, Squires RW, et al. Long-term mortality with multiple treadmill exercise test abnormalities: comparison between patients with and without cardiovascular disease. Am Heart J. 2008;156(4):783-9. [pmid: 18926161].
Amini M, Salarifar M, Amirbaigloo A, et al. N-acetylcysteine does not prevent contrast-induced nephropathy after cardiac catheterization in patients with diabetes mellitus and chronic kidney disease: a randomized clinical trial. Trials. 2009;10:45. [pmid: 19563648].
Bacci S, Villella M, Villella A, et al. Screening for silent myocardial ischaemia in type 2 diabetic patients with additional atherogenic risk factors: applicability and accuracy of the exercise stress test. Eur J Endocrinol. 2002;147(5):649-54. [pmid: 12444897].
Batty GD, Shipley MJ, Marmot M, et al. Leisure time physical activity and coronary heart disease mortality in men symptomatic or asymptomatic for ischaemia: evidence from the Whitehall study. J Public Health Med. 2003;25(3):190-6. [pmid: 14575192].
Bhatt DL, Lee BI, Casterella PJ, et al. Safety of concomitant therapy with eptifibatide and enoxaparin in patients undergoing percutaneous coronary intervention: results of the Coronary Revascularization Using Integrilin and Single bolus Enoxaparin Study. J Am Coll Cardiol. 2003;41(1):20-5. [pmid: 12570939].
Bilchick KC, Fetics B, Djoukeng R, et al. Prognostic value of heart rate variability in chronic congestive heart failure (Veterans Affairs’ Survival Trial of Antiarrhythmic Therapy in Congestive Heart Failure). Am J Cardiol. 2002;90(1):24-8. [pmid: 12088774].
Briguori C, Colombo A, Airoldi F, et al. N-Acetylcysteine versus fenoldopam mesylate to prevent contrast agent-associated nephrotoxicity. J Am Coll Cardiol. 2004;44(4):762-5. [pmid: 15312855].
de Ruijter W, Westendorp RG, Macfarlane PW, et al. The routine electrocardiogram for cardiovascular risk stratification in old age: the Leiden 85-plus study. J Am Geriatr Soc. 2007;55(6):872-7. [pmid: 17537087].
Elhendy A, Mahoney DW, Khandheria BK, et al. Prognostic significance of impairment of heart rate response to exercise: impact of left ventricular function and myocardial ischemia. J Am Coll Cardiol. 2003;42(5):823-30. [pmid: 12957427].
El-Jack SS, Ruygrok PN, Webster MW, et al. Effectiveness of manual pressure hemostasis following transfemoral coronary angiography in patients on therapeutic warfarin anticoagulation. Am J Cardiol. 2006;97(4):485-8. [pmid: 16461042].
Falcone C, Nespoli L, Geroldi D, et al. Silent myocardial ischemia in diabetic and nondiabetic patients with coronary artery disease. Int J Cardiol. 2003;90(2–3):219-27. [pmid: 12957755].
Frolkis JP, Pothier CE, Blackstone EH, et al. Frequent ventricular ectopy after exercise as a predictor of death. N Engl J Med. 2003;348(9):781-90. [pmid: 12606732].
Garcia S, McFalls EO, Goldman S, et al. Diagnostic coronary angiography in patients with peripheral arterial disease: a sub-study of the Coronary Artery Revascularization Prophylaxis Trial. J Interv Cardiol. 2008;21(5):369-74. [pmid: 18761563].
Gare M, Haviv YS, Ben-Yehuda A, et al. The renal effect of low-dose dopamine in high-risk patients undergoing coronary angiography. J Am Coll Cardiol. 1999;34(6):1682-8. [pmid: 10577557].
Gates PC, Eliasziw M, Algra A, et al. Identifying patients with symptomatic carotid artery disease at high and low risk of severe myocardial infarction and cardiac death. Stroke. 2002;33(10):2413-6. [pmid: 12364730].
Georgoulias P, Demakopoulos N, Valotassiou V, et al. Long-term prognostic value of heart-rate recovery after treadmill testing in patients with diabetes mellitus. Int J Cardiol. 2009;134(1):67-74. [pmid: 18499284].
Goldberg A, Zinder O, Zdorovyak A, et al. Diagnostic coronary angiography induces a systemic inflammatory response in patients with stable angina. Am Heart J. 2003;146(5):819-23. [pmid: 14597930].
Goldenberg I, Shechter M, Matetzky S, et al. Oral acetylcysteine as an adjunct to saline hydration for the prevention of contrast-induced nephropathy following coronary angiography: a randomized controlled trial and review of the current literature. Eur Heart J. 2004;25(3):212-8. [pmid: 14972421].
Gulel O, Keles T, Eraslan H, et al. Prophylactic acetylcysteine usage for prevention of contrast nephropathy after coronary angiography. J Cardiovasc Pharml. 2005;46(4):464-7.
Holscher B, Heitmeyer C, Fobker M, et al. Predictors for contrast media-induced nephropathy and long-term survival: prospectively assessed data from the randomized controlled Dialysis-Versus-Diuresis (DVD) trial. Can J Cardiol. 2008;24(11):845-50. [pmid: 18987758].
Huang CL, Su TC, Chen WJ, et al. Usefulness of paradoxical systolic blood pressure increase after exercise as a predictor of cardiovascular mortality. Am J Cardiol. 2008;102(5):518-23. [pmid: 18721505].
Kardys I, Kors JA, van der Meer IM, et al. Spatial QRS-T angle predicts cardiac death in a general population. Eur Heart J. 2003;24(14):1357-64. [pmid: 12871693].
Kim SH, Kim EJ, Cheon WS, et al. Comparative study of nicorandil and a spasmolytic cocktail in preventing radial artery spasm during transradial coronary angiography. Int J Cardiol. 2007;120(3):325-30. [pmid: 17196682].
Lee PT, Chou KJ, Liu CP, et al. Renal protection for coronary angiography in advanced renal failure patients by prophylactic hemodialysis: a randomized controlled trial. J Am Coll Cardiol. 2007;50(11):1015-20. [pmid: 17825709].
MacKinlay N, Taper J, Renisson F, et al. Cardiac surgery and catheterization in patients with haemophilia. Haemophilia. 2000;6(2):84-8. [pmid: 10781193].
Marenzi G, Marana I, Lauri G, et al. The prevention of radiocontrast-agent-induced nephropathy by hemofiltration. N Engl J Med. 2003;349(14):1333-40. [pmid: 14523141].
Miller HI, Dascalu A, Rassin TA, et al. Effects of an acute dose of L-arginine during coronary angiography in patients with chronic renal failure: a randomized, parallel, double-blind clinical trial. Am J Nephrol. 2003;23(2):91-5. [pmid: 12481147].
Miner SE, Dzavik V, Nguyen-Ho P, et al. N-acetylcysteine reduces contrast-associated nephropathy but not clinical events during long-term follow-up. Am Heart J. 2004;148(4):690-5. [pmid: 15459602].
Misra D, Leibowitz K, Gowda RM, et al. Role of N-acetylcysteine in prevention of contrast-induced nephropathy after cardiovascular procedures: a meta-analysis. Clin Cardiol. 2004;27(11):607-10. [pmid: 15562929].
Mueller C, Buerkle G, Buettner HJ, et al. Prevention of contrast media-associated nephropathy: randomized comparison of 2 hydration regimens in 1620 patients undergoing coronary angioplasty. Arch Intern Med. 2002;162(3):329-36. [pmid: 11822926].
Myers J, Prakash M, Froelicher V, et al. Exercise capacity and mortality among men referred for exercise testing. N Engl J Med. 2002;346(11):793-801. [pmid: 11893790].
Nie B, Cheng WJ, Li YF, et al. A prospective, double-blind, randomized, controlled trial on the efficacy and cardiorenal safety of iodixanol vs. iopromide in patients with chronic kidney disease undergoing coronary angiography with or without percutaneous coronary intervention. Catheter Cardio Inte. 2008;72(7):958-65.
Nishime EO, Cole CR, Blackstone EH, et al. Heart rate recovery and treadmill exercise score as predictors of mortality in patients referred for exercise ECG. JAMA. 2000;284(11):1392-8. [pmid: 10989401].
Noto TJ Jr, Johnson LW, Krone R, et al. Cardiac catheterization 1990: a report of the Registry of the Society for Cardiac Angiography and Interventions (SCA&I). Cathet Cardio Diag. 1991;24(2):75-83.
Okin PM, Devereux RB, Lee ET, et al. Electrocardiographic repolarization complexity and abnormality predict all-cause and cardiovascular mortality in diabetes: the Strong Heart Study. Diabetes. 2004;53(2):434-40. [pmid: 14747295].
Oldemeyer JB, Biddle WP, Wurdeman RL, et al. Acetylcysteine in the prevention of contrast-induced nephropathy after coronary angiography. Am Heart J. 2003;146(6):1089-94.
Patel MR, Peterson ED, Dai D, et al. Low diagnostic yield of elective coronary angiography. N Engl J Med. 2010;362(10):886-95. [pmid: 20220183].
Pearte CA, Furberg CD, O’Meara ES, et al. Characteristics and baseline clinical predictors of future fatal versus nonfatal coronary heart disease events in older adults: the Cardiovascular Health Study. Circulation. 2006;113(18):2177-85. [pmid: 16651468].
Pigozzi F, Spataro A, Alabiso A, et al. Role of exercise stress test in master athletes. Br J Sports Med. 2005;39(8):527-31. [pmid: 16046336].
Prior JO, Monbaron D, Koehli M, et al. Prevalence of symptomatic and silent stress-induced perfusion defects in diabetic patients with suspected coronary artery disease referred for myocardial perfusion scintigraphy. Eur J Nucl Med Mol I. 2005;32(1):60-9.
Spin JM, Prakash M, Froelicher VF, et al. The prognostic value of exercise testing in elderly men. Am J Med. 2002;112(6):453-9. [pmid: 11959055].
Ugur-Altun B, Altun A, Guldiken S, et al. Silent myocardial ischemia in middle-aged asymptomatic patients with type 2 diabetes in Turkish population. Angiology. 2007;58(5):535-42. [pmid: 18024935].
Widimsky P, Motovska Z, Simek S, et al. Clopidogrel pre-treatment in stable angina: for all patients >6 h before elective coronary angiography or only for angiographically selected patients a few minutes before PCI? A randomized multicentre trial PRAGUE-8. Eur Heart J. 2008;29(12):1495-503. [pmid: 18441320].
Zhang ZM, Prineas RJ, Case D, et al. Comparison of the prognostic significance of the electrocardiographic QRS/T angles in predicting incident coronary heart disease and total mortality (from the Atherosclerosis Risk in Communities study). Am J Cardiol. 2007;100(5):844-9. [pmid: 17719331].

### Wrong Intervention

Agarwal SK, Heiss G, Rautaharju PM, et al. Premature ventricular complexes and the risk of incident stroke: the Atherosclerosis Risk in Communities (ARIC) study. Stroke. 2010;41(4):588-93. [pmid: 20167922].
Anttila I, Nikus K, Nieminen T, et al. Prevalence and prognostic value of poor R-wave progression in standard resting electrocardiogram in a general adult population: the Health 2000 Survey. Ann Med. 2010;42(2):123-30. [pmid: 20166814].
Bartel A, Heyden S, Tyroler HA, et al. Electrocardiographic predictors of coronary heart disease. Arch Intern Med. 1971;128(6):929-37. [pmid: 5132451].
Bodegard J, Erikssen G, Bjornholt JV, et al. Possible angina detected by the WHO angina questionnaire in apparently healthy men with a normal exercise ECG: coronary heart disease or not? A 26 year follow up study. Heart. 2004;90(6):627-32. [pmid: 15145862].
Botti M, Williamson B, Steen K, et al. The effect of pressure bandaging on complications and comfort in patients undergoing coronary angiography: a multicenter randomized trial. Heart Lung. 1998;27(6):360-73. [pmid: 9835668].
Boyle E, Griffey WP, Nichaman MZ, Talbert CR. An epidemiologic study of hypertension among racial groups of Charleston County, SC: the Charleston Heart Study, phase II, The Epidemiology of Hypertension. New York. Grune & Stratton. 1967:193-203.
Boyle RM, Adlakha HL, Mary DA. Diagnostic value of the maximal ST segment/heart rate slope in asymptomatic factory populations. J Electrocardiol. 1987;20(Suppl):128-34. [pmid: 3320257].
Chaumeil A, Beygui F, Collet JP, et al. Feasibility of outpatient coronary angiography with “ad hoc” angioplasty. Arch Cardiovasc Dis. 2008;101(6):383-90. [pmid: 18809151].
Cosson E, Paycha F, Paries J, et al. Detecting silent coronary stenoses and stratifying cardiac risk in patients with diabetes: ECG stress test or exercise myocardial scintigraphy?. Diabet Med. 2004;21(4):342-8. [pmid: 15049936].
de Azevedo MJ, Neto AFR, Caramori ML, et al. Value of diagnostic tools for myocardial ischemia used in routine clinical practice to predict cardiac events in patients with type 2 diabetes mellitus: a prospective study. Arq Bras Endocrinol Metabol. 2006;50(1):46-52. [pmid: 16628274].
Duong MH, MacKenzie TA, Malenka DJ. N-acetylcysteine prophylaxis significantly reduces the risk of radiocontrast-induced nephropathy: comprehensive meta-analysis. Catheter Cardio Inte. 2005;64(4):471-9.
Durham JD, Caputo C, Dokko J, et al. A randomized controlled trial of N-acetylcysteine to prevent contrast nephropathy in cardiac angiography. Kidney Int. 2002;62(6):2202-7. [pmid: 12427146].
Fransson SG, Stenport G, Andersson M. Immediate and late adverse reactions in coronary angiography: a comparison between iodixanol and ioxaglate. Acta Radiol. 1996;37(2):218-22. [pmid: 8600966].
Georgoulias P, Orfanakis A, Demakopoulos N, et al. Abnormal heart rate recovery immediately after treadmill testing: correlation with clinical, exercise testing, and myocardial perfusion parameters. J Nucl Cardiol. 2003;10(5):498-505. [pmid: 14569243].
Gera N, Taillon LA, Ward RP. Usefulness of abnormal heart rate recovery on exercise stress testing to predict high-risk findings on single-photon emission computed tomography myocardial perfusion imaging in men. Am J Cardiol. 2009;103(5):611-4. [pmid: 19231321].
Janerot-Sjoberg B, Broqvist M, Fransson SG. Femoral artery haemostasis with a pneumatic compression device versus a clamp after coronary angiography. Scand Cardiovasc J. 1998;32(5):281-4. [pmid: 9835002].
Jensen J, Saleh N, Jensen U, et al. The inflammatory response to femoral arterial closure devices: a randomized comparison among FemoStop, AngioSeal, and Perclose. Cardiovasc Inter Rad. 2008;31(4):751-5.
Kimmel M, Butscheid M, Brenner S, et al. Improved estimation of glomerular filtration rate by serum cystatin C in preventing contrast induced nephropathy by N-acetylcysteine or zinc—preliminary results. Nephrol Dial Transpl. 2008;23(4):1241-5.
Lauer MS, Pothier CE, Chernyak YB, et al. Exercise-induced QT/R-R-interval hysteresis as a predictor of myocardial ischemia. J Electrocardiol. 2006;39(3):315-23. [pmid: 16777519].
Laukkanen JA, Kurl S, Salonen JT, et al. Peak oxygen pulse during exercise as a predictor for coronary heart disease and all cause death. Heart. 2006;92(9):1219-24. [pmid: 16467459].
Lee CD, Sui X, Blair SN. Combined effects of cardiorespiratory fitness, not smoking, and normal waist girth on morbidity and mortality in men. Arch Intern Med. 2009;169(22):2096-101. [pmid: 20008693].
The Coronary Primary Prevention Trial: design and implementation. The Lipid Research Clinics Program. J Chronic Dis. 1979;32(9–10):609-31. [pmid: 489702].
Lipid Research Clinics Program Epidemiology Committee. Plasma lipid distributions in selected North American populations: the Lipid Research Clinics Program Prevalence Study. Circulation. 1979;60(2):427-39. [pmid: 312704].
Louvard Y, Lefevre T, Allain A, et al. Coronary angiography through the radial or the femoral approach: the CARAFE study. Catheter Cardio Inte. 2001;52(2):181-7.
Mehta H, Chatterjee T, Windecker S, et al. Four French catheters for diagnostic coronary angiography. Catheter Cardio Inte. 2003;58(3):275-80.
Michalis LK, Rees MR, Patsouras D, et al. A prospective randomized trial comparing the safety and efficacy of three commercially available closure devices (Angioseal, Vasoseal and Duett). Cardiovasc Inter Rad. 2002;25(5):423-9.
Multiple Risk Factor Intervention Trial Research Group. Exercise electrocardiogram and coronary heart disease mortality in the Multiple Risk Factor Intervention Trial. Am J Cardiol. 1985;55(1):16-24. [pmid: 2857061].
Salles GF, Cardoso CR, Fiszman R, et al. Prognostic impact of baseline and serial changes in electrocardiographic left ventricular hypertrophy in resistant hypertension. Am Heart J. 2010;159(5):833-40. [pmid: 20435193].
Schrader R, Esch I, Ensslen R, et al. A randomized trial comparing the impact of a nonionic (Iomeprol) versus an ionic (Ioxaglate) low osmolar contrast medium on abrupt vessel closure and ischemic complications after coronary angioplasty. J Am Coll Cardiol. 1999;33(2):395-402. [pmid: 9973019].
Shammas NW, Rajendran VR, Alldredge SG, et al. Randomized comparison of Vasoseal and Angioseal closure devices in patients undergoing coronary angiography and angioplasty. Catheter Cardio Int. 2002;55(4):421-5.
Shephard RJ. Prognostic value of exercise testing for ischaemic heart disease. Br J Sports Med. 1982;16(4):220-9. [pmid: 7159814].
Stone GW, Tumlin JA, Madyoon H, et al. Design and rationale of CONTRAST—a prospective, randomized, placebo-controlled trial of fenoldopam mesylate for the prevention of radiocontrast nephropathy. Rev Cardiovasc Med. 2001;2(Suppl 1):S31-6. [pmid: 12439366].

### Wrong Outcome

Regional differences in dietary habits, coronary risk factors and mortality rates in Belgium, 1: design and methodology. Nutrition and health: an interuniversity study. Acta Cardiol. 1984;39(4):285-92. [pmid: 6333125].
ARIC Investigators. The Atherosclerosis Risk in Communities (ARIC) study: design and objectives. Am J Epidemiol. 1989;129(4):687-702. [pmid: 2646917].
Bartolucci AA, Howard G. Meta-analysis of data from the six primary prevention trials of cardiovascular events using aspirin. Am J Cardiol. 2006;98(6):746-50. [pmid: 16950176].
Beddoes L, Botti M, Duke MM. Patients’ experiences of cardiology procedures using minimal conscious sedation. Heart Lung. 2008;37(3):196-204. [pmid: 18482631].
Bischoff B, Hein F, Meyer T, et al. Impact of a reduced tube voltage on CT angiography and radiation dose: results of the PROTECTION I study. JACC Cardiovasc Imaging. 2009;2(8):940-6. [pmid: 19679281].
Cameron JD, Jennings GL, Kay S, et al. A self-administered questionnaire for detection of unrecognised coronary heart disease. Aust N Z J Public Health. 1997;21(5):545-7. [pmid: 9343902].
Chair SY, Taylor-Piliae RE, Lam G, et al. Effect of positioning on back pain after coronary angiography. J Adv Nurs. 2003;42(5):470-8. [pmid: 12752867].
Chatelain P, Arceo A, Rombaut E, et al. New device for compression of the radial artery after diagnostic and interventional cardiac procedures. Cathet Cardio Diag. 1997;40(3):297-300.
Chico A, Tomas A, Novials A. Silent myocardial ischemia is associated with autonomic neuropathy and other cardiovascular risk factors in type 1 and type 2 diabetic subjects, especially in those with microalbuminuria. Endocrine. 2005;27(3):213-7. [pmid: 16230776].
Chrapko B, Kowalczyk M, Nocun A, et al. Evaluation of the left ventricular hemodynamic function and myocardial perfusion by gated single photon emission tomography, in patients with type 1 diabetes mellitus; prodromal signs of cardiovascular disease after four years. Hell J Nucl Med. 2006;9(2):90-3. [pmid: 16894411].
Correia LC, Rocha MS, Esteves JP. HDL-cholesterol level provides additional prognosis in acute coronary syndromes. Int J Cardiol. 2009;136(3):307-14. [pmid: 18706714].
Daugherty SL, Peterson PN, Magid DJ, et al. The relationship between gender and clinical management after exercise stress testing. Am Heart J. 2008;156(2):301-7. [pmid: 18657660].
Davies B, Ashton WD, Rowlands DJ, et al. Association of conventional and exertional coronary heart disease risk factors in 5,000 apparently healthy men. Clin Cardiol. 1996;19(4):303-8. [pmid: 8706370].
Eggers KM, Kempf T, Allhoff T, et al. Growth-differentiation factor-15 for early risk stratification in patients with acute chest pain. Eur Heart J. 2008;29(19):2327-35. [pmid: 18664460].
Ereth MH, Nuttall GA, Orszulak TA, et al. Blood loss from coronary angiography increases transfusion requirements for coronary artery bypass graft surgery. J Cardiothor Vasc An. 2000;14(2):177-81.
Farah R, Shurtz-Swirski R, Bolotin Y, et al. Oxidative stress and inflammation due to peripheral polymorphonuclear leukocytes after coronary angiography vs percutaneous coronary intervention. Minerva Cardioangiol. 2008;56(2):189-95. [pmid: 18319697].
Farrell SW, Cheng YJ, Blair SN. Prevalence of the metabolic syndrome across cardiorespiratory fitness levels in women. Obes Res. 2004;12(5):824-30. [pmid: 15166303].
Fazel R, Krumholz HM, Wang Y, et al. Exposure to low-dose ionizing radiation from medical imaging procedures. N Engl J Med. 2009;361(9):849-57. [pmid: 19710483].
From AM, Kane G, Bruce C, et al. Characteristics and outcomes of patients with abnormal stress echocardiograms and angiographically mild coronary artery disease (<50% stenoses) or normal coronary arteries. J Am Soc Echocardiog. 2010;23(2):207-14.
Furberg CD, Manolio TA, Psaty BM, et al. Major electrocardiographic abnormalities in persons aged 65 years and older (the Cardiovascular Health Study). Am J Cardiol. 1992;69(16):1329-35. [pmid: 1585868].
Hames CG, Rose K, Knowles M, et al. Black-white comparisons of 20-year coronary heart disease mortality in the Evans County Heart Study. Cardiology. 1993;82(2–3):122-36. [pmid: 8324775].
Hedstrand H. A study of middle-aged men with particular reference to risk factors for cardiovascular disease. Uppsala J Med Sci Suppl. 1975;19:1-61.
Hennekens CH, Schneider WR. The need for wider and appropriate utilization of aspirin and statins in the treatment and prevention of cardiovascular disease. Expert Rev Cardiovasc Ther. 2008;6(1):95-107. [pmid: 18095910].
Ives DG, Fitzpatrick AL, Bild DE, et al. Surveillance and ascertainment of cardiovascular events: the Cardiovascular Health Study. Ann Epidemiol. 1995;5(4):278-85. [pmid: 8520709].
Jo SH, Koo BK, Park JS, et al. Prevention of radiocontrast medium-induced nephropathy using short-term high-dose simvastatin in patients with renal insufficiency undergoing coronary angiography (PROMISS) trial—a randomized controlled study. Am Heart J. 2008;155(3):e491-8.
Kannel WB. Prevalence and natural history of electrocardiographic left ventricular hypertrophy. Am J Med. 1983;75(3 Part 1):4-11. [pmid: 6226193].
Kannel WB, Feinleib M, McNamara PM, et al. An investigation of coronary heart disease in families: the Framingham Offspring Study. Am J Epidemiol. 1979;110(3):281-90. [pmid: 474565].
King NA, Philpott SJ, Leary A. A randomized controlled trial assessing the use of compression versus vasoconstriction in the treatment of femoral hematoma occurring after percutaneous coronary intervention. Heart Lung. 2008;37(3):205-10. [pmid: 18482632].
Kini AA, Sharma SK. Managing the high-risk patient: experience with fenoldopam, a selective dopamine receptor agonist, in prevention of radiocontrast nephropathy during percutaneous coronary intervention. Rev Cardiovasc Med. 2001;2(Suppl 1):S19-25. [pmid: 12439364].
Kornitzer M, Dramaix M. The Belgian Inter-university Research on Nutrition and Health (BIRNH) study. Acta Cardiol. 1989;94:89-99. [pmid: 2750419].
Kumar A, Lloyd-Jones DM. Clinical significance of minor nonspecific ST-segment and T-wave abnormalities in asymptomatic subjects: a systematic review. Cardiol Rev. 2007;15(3):133-42. [pmid: 17438379].
Leotta G, Maule S, Rabbia F, et al. Relationship between QT interval and cardiovascular risk factors in healthy young subjects. J Hum Hypertens. 2005;19(8):623-7. [pmid: 15905890].
Ling W, Zhaohui N, Ben H, et al. Urinary IL-18 and NGAL as early predictive biomarkers in contrast-induced nephropathy after coronary angiography. Nephron. 2008;108(3):c176-81. [pmid: 18287807].
Liuzzo G, Buffon A, Biasucci LM, et al. Enhanced inflammatory response to coronary angioplasty in patients with severe unstable angina. Circulation. 1998;98(22):2370-6. [pmid: 9832480].
May O, Schlosser H, Skytte L. A randomized trial assessing the influence of lying still or being allowed to move in the observation period following coronary angiography using the femoral approach. J Interv Cardiol. 2008;21(4):347-9. [pmid: 18513345].
McConahay DR, McCallister BD, Smith RE. Postexercise electrocardiography: correlations with coronary arteriography and left ventricular hemodynamics. Am J Cardiol. 1971;28(1):1-9. [pmid: 4103943].
Miller JM, Rochitte CE, Dewey M, et al. Diagnostic performance of coronary angiography by 64-row CT. N Engl J Med. 2008;359(22):2324-36. [pmid: 19038879].
Moller CS, Byberg L, Sundstrom J, et al. T wave abnormalities, high body mass index, current smoking and high lipoprotein(a) levels predict the development of major abnormal Q/QS patterns 20 years later: a population-based study. BMC Cardiovasc Disord. 2006;6:10. [pmid: 16519804].
Morales-Ballejo H, Greenberg PS, Ellestad MH, et al. Septal Q wave in exercise testing: angiographic correlation. Am J Cardiol. 1981;48(2):247-51. [pmid: 7270434].
Multiple Risk Factor Intervention Trial Research Group. Baseline rest electrocardiographic abnormalities, antihypertensive treatment, and mortality in the Multiple Risk Factor Intervention Trial. Am J Cardiol. 1985;55(1):1-15. [pmid: 3880997].
Multiple Risk Factor Intervention Trial Research Group. Exercise electrocardiogram and coronary heart disease mortality in the Multiple Risk Factor Intervention Trial. Am J Cardiol. 1985;55:16-24. [pmid: 2857061].
Multiple Risk Factor Intervention Trial Research Group. Coronary heart disease death, nonfatal acute myocardial infarction and other clinical outcomes in the Multiple Risk Factor Intervention Trial. Am J Cardiol. 1986;58(1):1-13. [pmid: 2873741].
Murphy ML, Thenabadu PN, Blue LR, et al. Descriptive characteristics of the electrocardiogram from autopsied men free of cardiopulmonary disease—a basis for evaluating criteria for ventricular hypertrophy. Am J Cardiol. 1983;52(10):1275-80. [pmid: 6228133].
Nadelmann J, Frishman W, Ooi W. Prevalence, incidence and prognosis of recognized and unrecognized myocardial infarction in persons aged 75 years or older: the Bronx Aging Study. Am J Cardiol. 1990;66(5):533-7. [pmid: 2392974].
Namazi MH, Motamedi MR, Safi M, et al. Efficacy of folic acid therapy for prevention of in-stent restenosis: a randomized clinical trial. Arch Iran Med. 2006;9(2):108-10. [pmid: 16649350].
Neyt M, De Laet C, Van Brabandt H, et al. Cost-effectiveness of statins in the primary prevention of cardiovascular disease: a systematic review and economic analysis for Belgium. Acta Cardiol. 2009;64(1):1-10. [pmid: 19317290].
Richter WO, Donner MG, Hofling B, et al. Long-term effect of low-density lipoprotein apheresis on plasma lipoproteins and coronary heart disease in native vessels and coronary bypass in severe heterozygous familial hypercholesterolemia. Metabolism. 1998;47(7):863-8. [pmid: 9667236].
Robbins J, Nelson JC, Rautaharju PM, et al. The association between the length of the QT interval and mortality in the Cardiovascular Health Study. Am J Med. 2003;115(9):689-94. [pmid: 14693320].
Sapin PM, Koch G, Blauwet MB, et al. Identification of false positive exercise tests with use of electrocardiographic criteria: a possible role for atrial repolarization waves. J Am Coll Cardiol. 1991;18(1):127-35. [pmid: 2050915].
Savonen KP, Lakka TA, Laukkanen JA, et al. Heart rate response during exercise test and cardiovascular mortality in middle-aged men. Eur Heart J. 2006;27(5):582-8. [pmid: 16399774].
Seyon RA, Jensen LA, Ferguson IA, et al. Efficacy of N-acetylcysteine and hydration versus placebo and hydration in decreasing contrast-induced renal dysfunction in patients undergoing coronary angiography with or without concomitant percutaneous coronary intervention. Heart Lung. 2007;36(3):195-204. [pmid: 17509426].
Sigurdsson E, Sigfusson N, Agnarsson U, et al. Long-term prognonsis of different forms of coronary heart disease: the Reykjavik Study. Int J Epidemiol. 1995;24(1):58-68. [pmid: 7797357].
Sigurdsson E, Thorgeirsson G, Sigvaldason H, et al. Prevalence of coronary heart disease in Icelandic men 1968–1986. Eur Heart J. 1993;14:584-91. [pmid: 8508850].
Southard J, Baker L, Schaefer S. In search of the false-negative exercise treadmill testing evidence-based use of exercise echocardiography. Clin Cardiol. 2008;31(1):35-40. [pmid: 18203117].
Stansfeld SA, Fuhrer R, Shipley MJ, et al. Psychological distress as a risk factor for coronary heart disease in the Whitehall II Study. Int J Epidemiol. 2002;31(1):248-55. [pmid: 11914328].
Taylor AJ, Sackett MC, Beller GA. The degree of ST-segment depression on symptom-limited exercise testing: relation to the myocardial ischemic burden as determined by thallium-201 scintigraphy. Am J Cardiol. 1995;75(4):228-31. [pmid: 7832128].
van Tellingen C, Ascoop CA, Rijneke RD. On the clinical value of conventional and new exercise electrocardiographic criteria: a comparative study. Int J Cardiol. 1984;5(6):689-705. [pmid: 6746123].
Ward S, Lloyd-Jones M, Pandor A, et al. A systematic review and economic evaluation of statins for the prevention of coronary events. Health Technol Assess. 2007;11(14):1-160.
Wei M, Kampert JB, Barlow CE, et al. Relationship between low cardiorespiratory fitness and mortality in normal weight, overweight and obese men. JAMA. 1999;282:1547-53. [pmid: 10546694].
Wolff T, Miller T, Ko S. Aspirin for the primary prevention of cardiovascular events: an update of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2009;150(6):405-10. [pmid: 19293073].
WOSCOPS Study Group. A coronary primary prevention study of Scottish men aged 45–64 years: trial design. J Clin Epidemiol. 1992;45(8):849-60. [pmid: 1624967].
Yilmaz E, Gurgun C, Dramali A. Minimizing short-term complications in patients who have undergone cardiac invasive procedure: a randomized controlled trial involving position change and sandbag. Anadolu Kardiyol Der. 2007;7(4):390-6.

### Wrong Study Design for Key Question

Baggish AL, Hutter AM Jr, Wang F, et al. Cardiovascular screening in college athletes with and without electrocardiography: a cross-sectional study. Ann Intern Med. 2010;152(5):269-75. [pmid: 20194232].
Blankenship JC, Haldis T, Feit F, et al. Angiographic adverse events, creatine kinase-MB elevation, and ischemic end points complicating percutaneous coronary intervention (a REPLACE-2 substudy). Am J Cardiol. 2006;97(11):1591-6. [pmid: 16728220].
Deedwania PC. Should asymptomatic subjects with silent ischemia undergo further evaluation and follow-up?. Int J Cardiol. 1994;44(1):101-3. [pmid: 8021044].
Dunn RL, Matzen RN, VanderBrug-Medendorp S. Screening for the detection of coronary artery disease by using the exercise tolerance test in a preventive medicine population. Am J Prev Med. 1991;7(5):255-62. [pmid: 1790029].
Erikssen G, Bodegard J, Bjornholt JV, et al. Exercise testing of healthy men in a new perspective: from diagnosis to prognosis. Eur Heart J. 2004;25(11):978-86. [pmid: 15172470].
Faglia E, Manuela M, Antonella Q, et al. Risk reduction of cardiac events by screening of unknown asymptomatic coronary artery disease in subjects with type 2 diabetes mellitus at high cardiovascular risk: an open-label randomized pilot study. Am Heart J. 2005;149(2):e1-6. [pmid: 15846252].
Ghani AA, Tohamy KY. Risk score for contrast induced nephropathy following percutaneous coronary intervention. Saudi J Kidney Dis Transpl. 2009;20(2):240-5. [pmid: 19237811].
Greenland P, Gaziano JM. Clinical practice: selecting asymptomatic patients for coronary computed tomography or electrocardiographic exercise testing. N Engl J Med. 2003;349(5):465-73. [pmid: 12890846].
Hayashi T, Nomura H, Esaki T, et al. The treadmill exercise-tolerance test is useful for the prediction and prevention of ischemic coronary events in elderly diabetics. J Diabetes Complications. 2005;19(5):264-8. [pmid: 16112501].
Hiyoshi Y, Omae T, Hirota Y, et al. Clinicopathological study of the heart and coronary arteries of autopsied cases from the community of Hisayama during a 10-year period, part V: comparison of autopsy findings with electrocardiograms—Q.QS items of the Minnesota code. Am J Epidemiol. 1985;121(6):906-13. [pmid: 4014182].
Juneja R, Wasir HS. Abnormal exercise electrocardiogram in an asymptomatic person—what next?. Int J Cardiol. 1994;43(1):1-9. [pmid: 8175210].
Kwok JM, Miller TD, Hodge DO, et al. Prognostic value of the Duke treadmill score in the elderly. J Am Coll Cardiol. 2002;39(9):1475-81. [pmid: 11985910].
Kwok OH, Prpic R, Gaspar J, et al. Angiographic outcome after intracoronary X-Sizer helical atherectomy and thrombectomy: first use in humans. Catheter Cardio Inter. 2002;55(2):133-9.
Lim R, Anderson H, Walters MI, et al. Femoral complications and bed rest duration after coronary arteriography. Am J Cardiol. 1997;80(2):222-3. [pmid: 9230168].
Massie BM, Szlachcic Y, Tubau JF, et al. Scintigraphic and electrocardiographic evidence of silent coronary artery disease in asymptomatic hypertension: a case-control study. J Am Coll Cardiol. 1993;22(6):1598-1606. [pmid: 8227826].
Mehran R, Aymong ED, Nikolsky E, et al. A simple risk score for prediction of contrast-induced nephropathy after percutaneous coronary intervention: development and initial validation. J Am Coll Cardiol. 2004;44(7):1393-9. [pmid: 15464318].
Mills EJ, Rachlis B, Wu P, et al. Primary prevention of cardiovascular mortality and events with statin treatments: a network meta-analysis involving more than 65,000 patients. J Am Coll Cardiol. 2008;52(22):1769-81. [pmid: 19022156].
Okin PM, Kligfield P, Milner MR, et al. Heart rate adjustment of ST-segment depression for reduction of false positive electrocardiographic responses to exercise in asymptomatic men screened for coronary artery disease. Am J Cardiol. 1988;62(16):1043-7. [pmid: 3189166].
Otom A, Hourani F, Hatter E. Ischaemic spinal cord injury following a coronary angiogram: a case report. Spinal Cord. 1996;34(5):308-10. [pmid: 8963982].
Perez MV, Yaw TS, Myers J, et al. Prognostic value of the computerized ECG in Hispanics. Clin Cardiol. 2007;30(4):189-94. [pmid: 17443659].
Piepgrass SR, Uhl GS, Hickman JR Jr, et al. Limitations of the exercise stress test in the detection of coronary artery disease in apparently healthy men. Aviat Space Envir Md. 1982;53(4):379-82.
Sheehan J, Perry IJ, Reilly M, et al. QT dispersion, QT maximum and risk of cardiac death in the Caerphilly Heart Study. Eur J Cardiovasc Prev Rehabil. 2004;11(1):63-8. [pmid: 15167208].
Sumanen M, Mattila K. A negative finding in an exercise test is reliable among elderly people: a follow-up study. Gerontology. 2007;53(3):159-64. [pmid: 17192713].
Zaidat OO, Slivka AP, Mohammad Y, et al. Intra-arterial thrombolytic therapy in peri-coronary angiography ischemic stroke. Stroke. 2005;36(5):1083-4. [pmid: 15817892].

### Wrong Publication Type

Alp BN, Bozbuga N, Tuncer MA, et al. Transient cortical blindness after coronary angiography. J Int Med Res. 2009;37(4):1246-51. [pmid: 19761711].
Chair SY. Minimizing short-term complications in patients who have undergone cardiac invasive procedure: a randomized controlled trial involving position change and sandbag. Anadolu Kardiyol Der. 2008;8(1):81.
Criqui MH, Haskell WL, Heiss G, et al. Predictors of systolic blood pressure response to treadmill exercise: the Lipid Research Clinics Program Prevalence Study. Circulation. 1983;68(2):225-33. [pmid: 6861301].
Dawber TR, Kannel WB, Lyell LP. An approach to longitudinal studies in a community: the Framingham Study. Ann N Y Acad Sci. 1963;107:539-56. [pmid: 14025561].
Dawber TR, Meadors GF, Moore FE Jr. Epidemiological approaches to heart disease: the Framingham Study. Am J Public Health Nations Health. 1951;41(3):279-81. [pmid: 14819398].
Ekelund LG, Haskell WL, Johnson JL, et al. Physical fitness as a predictor of cardiovascular mortality in asymptomatic North American men: the Lipid Research Clinics Mortality Follow-up Study. N Engl J Med. 1988;319(21):1379-84. [pmid: 3185648].
Feinleib M, Kannel WB, Garrison RJ, et al. The Framingham Offspring Study: design and preliminary data. Prev Med. 1975;4(4):518-25. [pmid: 1208363].
Islam MA, Blankenship JC, Balog C, et al. Effect of abciximab on angiographic complications during percutaneous coronary stenting in the Evaluation of Platelet IIb/IIIa Inhibition in Stenting Trial (EPISTENT). Am J Cardiol. 2002;90(9):916-21. [pmid: 12398954].
Lipid Research Clinics Program: the prevalence study, The Lipid Research Clinics Population Studies Data Book. Bethesda, MD. U.S. Department of Health and Human Services. 1980;1.
Manson JE, Hsia J, Johnson KC, et al. Estrogen plus progestin and the risk of coronary heart disease. N Engl J Med. 2003;349(6):523-34. [pmid: 12904517].
Mathewson FA, Varnam GS. Abnormal electrocardiograms in apparently healthy people, II: the electrocardiogram in the diagnosis of subclinical myocardial disease—serial records of 32 people. Circulation. 1960;21:204-13. [pmid: 14422281].
Multiple Risk Factor Intervention Trial Group. Statistical design considerations in the NHLI Multiple Risk Factor Intervention Trial (MRFIT). J Chronic Dis. 1977;30(5):261-75. [pmid: 863996].
Rathore S, Morris JL. The radial approach: is this the route to take?. J Interv Cardiol. 2008;21(5):375-9. [pmid: 18705638].
Rautaharju PM, Park LP, Chaitman BR, et al. The Novacode criteria for classification of ECG abnormalities and their clinically significant progression and regression. J Electrocardiol. 1998;31(3):157-87. [pmid: 9682893].
RIFLE Research Group. Presentation of the RIFLE project risk factors and life expectancy. Eur J Epidemiol. 1993;9(5):459-76. [pmid: 8307130].
Rossouw JE, Anderson GL, Prentice RL, et al. Risks and benefits of estrogen plus progestin in healthy postmenopausal women: principal results from the Women’s Health Initiative randomized controlled trial. JAMA. 2002;288(3):321-33. [pmid: 12117397].
Salonen JT. Is there a continuing need for longitudinal epidemiologic research? The Kuopio Ischaemic Heart Disease Risk Factor Study. Ann Clin Res. 1988;20(1–2):46-50. [pmid: 3408213].
Shepherd J, Cobbe SM, Ford I, et al. Prevention of coronary heart disease with pravastatin in men with hypercholesterolemia. N Engl J Med. 1995;333(20):1301-7. [pmid: 7566020].
Shock NW, Greulich RC, Andres RA. Normal Human Aging: The Baltimore Study of Aging. Bethesda, MD. National Institutes of Health. 1984.
Tate RB, Lah L, Cuddy TE, et al. Definition of successful aging by elderly Canadian males: the Manitoba Follow-up Study. Gerontologist. 2003;43(5):735-44. [pmid: 14570969].
Williams OD, Mowery RL, Waldman GT. Common methods, different populations: the Lipid Research Clinics Program Prevalence Study. Circulation. 18. 1980;62(4 Pt 2):iv-23. [pmid: 7418145].

### Not English Language but Otherwise Relevant

Ballout J, Andre F, Cottin Y, et al. Randomized comparison of 4F and 6F catheters for diagnostic coronary angiographies via the femoral approach [in French]. Arch Mal Coeur Vaiss. 2000;93(1):35-9. [pmid: 11227716].
Fernandez-Portales J, Valdesuso R, Carreras R, et al. Right versus left radial artery approach for coronary angiography: differences observed and the learning curve [in Spanish]. Rev Esp Cardiol. 2006;59(10):1071-4. [pmid: 17125718].
Guillard N, Lefevre T, Spaulding C, et al. Coronary angiography by left radial approach: a bi-center prospective pilot study [in French]. Arch Mal Coeur Vaiss. 1997;90(10):1349-55. [pmid: 9539834].

### Statistical Adjustment for <5 Framingham Risk Factors

Al-Attar AT, Mahussain SA, Sadanandan S. Cardiac tests in asymptomatic type 2 diabetics. Med Princ Pract. 2002;11(4):171-5. [pmid: 12424409].
Allen WH, Aronow WS, Goodman P, et al. Five-year follow-up of maximal treadmill stress test in asymptomatic men and women. Circulation. 1980;62(3):522-7. [pmid: 7398012].
Arauz A, Calleja J, Vallejo E, et al. Prevalence of silent myocardial ischemia in single and multiple lacunar infarcts and large vessel disease stroke. Clin Neurol Neurosurg. 1992;112(8):658-61. [pmid: 20510499].
Blumenthal RS, Becker DM, Moy TF, et al. Exercise thallium tomography predicts future clinically manifest coronary heart disease in high-risk asymptomatic men. Am J Cardiol. 1996;93:915-23.
Bruce RA, DeRouen TA, Hossack KF. Value of maximal exercise tests in risk assessment of primary coronary heart disease events in healthy men: five years’ experience of the Seattle Heart Watch Study. Am J Cardiol. 1980;46(3):371-8. [pmid: 7415981].
Cullen K, Stenhouse NS, Wearne KL, et al. Electrocardiograms and 13 year cardiovascular mortality in Busselton study. Br Heart J. 1982;47(3):209-12. [pmid: 6174132].
Cumming GR, Samm J, Borysyk L, et al. Electrocardiographic changes during exercise in asymptomatic men: 3-year follow-up. Can Med Assoc J. 1975;112(5):578-81. [pmid: 1116087].
Dunder K, Lind L, Zethelius B, et al. A new Q/QS pattern on the resting electrocardiogram is associated with impaired insulin secretion and a poor prognosis in elderly men independently of history of myocardial infarction. J Intern Med. 2004;255(2):221-8. [pmid: 14746559].
Dunn FG, McLenachan J, Isles CG, et al. Left ventricular hypertrophy and mortality in hypertension: an analysis of data from the Glasgow Blood Pressure Clinic. J Hypertens. 1990;8(8):775-82. [pmid: 2170517].
Erikssen G, Liestol K, Bjornholt J, et al. Changes in physical fitness and changes in mortality. Lancet. 1998;352(9130):759-62. [pmid: 9737279].
Froelicher VF Jr, Thomas MM, Pillow C, et al. Epidemiologic study of asymptomatic men screened by maximal treadmill testing for latent coronary artery disease. Am J Cardiol. 1974;34(7):770-6. [pmid: 4432807].
Gulati M, Black HR, Shaw LJ, et al. The prognostic value of a nomogram for exercise capacity in women. N Engl J Med. 2005;353(5):468-75. [pmid: 16079370].
Gyntelberg F, Lauridsen L, Schubell K. Physical fitness and risk of myocardial infarction in Copenhagen males aged 40–59: a five- and seven-year follow-up study. Scand J Work Environ Health. 1980;6(3):170-8. [pmid: 6937821].
Hein HO, Suadicani P, Gyntelberg F. Physical fitness or physical activity as a predictor of ischaemic heart disease? A 17-year follow-up in the Copenhagen Male Study. J Intern Med. 1992;232(6):471-9. [pmid: 1474346].
Jimenez-Corona A, Nelson RG, Sievers ML, et al. Electrocardiographic abnormalities predict deaths from cardiovascular disease and ischemic heart disease in Pima Indians with type 2 diabetes. Am Heart J. 2006;151(5):1080-6. [pmid: 16644339].
Jones DW, Chambless LE, Folsom AR, et al. Risk factors for coronary heart disease in African Americans: the Atherosclerosis Risk in Communities study, 1987–1997. Arch Intern Med. 2002;162(22):2565-71. [pmid: 12456228].
Kampert JB, Blair SN, Barlow CE, et al. Physical activity, physical fitness, and all-cause and cancer mortality: a prospective study of men and women. Ann Epidemiol. 1996;6(5):452-7. [pmid: 8915477].
Kannel WB, Abbott RD. A prognostic comparison of asymptomatic left ventricular hypertrophy and unrecognized myocardial infarction: the Framingham Study. Am Heart J. 1986;111(2):391-7. [pmid: 2936230].
Kannel WB, Anderson K, McGee DL, et al. Nonspecific electrocardiographic abnormality as a predictor of coronary heart disease: the Framingham Study. Am Heart J. 1987;113(2 Pt 1):370-6. [pmid: 3812192].
Kannel WB, Cobb J. Left ventricular hypertrophy and mortality—results from the Framingham Study. Cardiology. 1992;81(4–5):291-8. [pmid: 1301257].
Katzel LI, Sorkin JD, Goldberg AP. Exercise-induced silent myocardial ischemia and future cardiac events in healthy, sedentary, middle-aged and older men. J Am Geriatr Soc. 1999;47(8):923-9. [pmid: 10443851].
Katzmarzyk PT, Church TS, Janssen I, et al. Metabolic syndrome, obesity, and mortality: impact of cardiorespiratory fitness. Diabetes Care. 2005;28(2):391-7. [pmid: 15677798].
Knutsen R, Knutsen SF, Curb JD, et al. The predictive value of resting electrocardiograms for 12-year incidence of coronary heart disease in the Honolulu Heart Program. J Clin Epidemiol. 1988;41(3):293-302. [pmid: 3339383].
Laukkanen JA, Rauramaa R, Salonen JT, et al. The predictive value of cardiorespiratory fitness combined with coronary risk evaluation and the risk of cardiovascular and all-cause death. J Intern Med. 2007;262(2):263-72. [pmid: 17645594].
McHenry PL, O’Donnell J, Morris SN, et al. The abnormal exercise electrocardiogram in apparently healthy men: a predictor of angina pectoris as an initial coronary event during long-term follow-up. Circulation. 1984;70(4):547-51. [pmid: 6478560].
Miller GJ, Cooper JA, Beckles GL. Cardiorespiratory fitness, all-cause mortality, and risk of cardiovascular disease in Trinidadian men—the St James Survey. Int J Epidemiol. 2005;34(6):1387-94. [pmid: 16169888].
Moller CS, Zethelius B, Sundstrom J, et al. Impact of follow-up time and re-measurement of the electrocardiogram and conventional cardiovascular risk factors on their predictive value for myocardial infarction. J Intern Med. 2006;260(1):22-30. [pmid: 16789975].
Parikh NI, Gona P, Larson MG, et al. Long-term trends in myocardial infarction incidence and case fatality in the National Heart, Lung, and Blood Institute’s Framingham Heart Study. Circulation. 2009;119(9):1203-10. [pmid: 19237656].
Pedoe HD. Predictability of sudden death from resting electrocardiogram: effect of previous manifestations of coronary heart disease. Br Heart J. 1978;40(6):630-5. [pmid: 656237].
Rabkin SW, Mathewson FL, Tate RB. The electrocardiogram in apparently healthy men and the risk of sudden death. Br Heart J. 1982;47(6):546-52. [pmid: 6177327].
Reunanen A, Pyorala K, Punsar S, et al. Predictive value of ECG findings with respect to coronary heart disease mortality. Adv Cardiol. 1978;21:310-2. [pmid: 619560].
Rose G, Baxter PJ, Reid DD, et al. Prevalence and prognosis of electrocardiographic findings in middle-aged men. Br Heart J. 1978;40(6):636-43. [pmid: 656238].
Sandvik L, Erikssen J, Thaulow E, et al. Physical fitness as a predictor of mortality among healthy, middle-aged Norwegian men. N Engl J Med. 1993;328(8):533-7. [pmid: 8426620].
Sobolski J, Kornitzer M, De Backer G, et al. Protection against ischemic heart disease in the Belgian Physical Fitness Study: physical fitness rather than physical activity?. Am J Epidemiol. 1987;125(4):601-10. [pmid: 3826040].
Stevens J, Cai J, Evenson KR, et al. Fitness and fatness as predictors of mortality from all causes and from cardiovascular disease in men and women in the Lipid Research Clinics Study. Am J Epidemiol. 2002;156(9):832-41. [pmid: 12397001].
Stevens J, Evenson KR, Thomas O, et al. Associations of fitness and fatness with mortality in Russian and American men in the Lipids Research Clinics Study. Int J Obes Relat Metab Disord. 2004;28(11):1463-70. [pmid: 15365584].
Sullivan JM, Vander Zwaag RV, el-Zeky F, et al. Left ventricular hypertrophy: effect on survival. J Am Coll Cardiol. 1993;22(2):508-13. [pmid: 8335822].
Verdecchia P, Dovellini EV, Gorini M, et al. Comparison of electrocardiographic criteria for diagnosis of left ventricular hypertrophy in hypertension: the MAVI study. Ital Heart J. 2000;1(3):207-15. [pmid: 10806988].
Villeneuve PJ, Morrison HI, Craig CL, et al. Physical activity, physical fitness, and risk of dying. Epidemiology. 1998;9(6):626-31. [pmid: 9799172].

## Appendix B7 Quality Rating Criteria for Studies Assessing ECG Abnormalities and Risk of Subsequent Cardiovascular Events^*^ * Adapted from Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21–35.

### Criteria

- Was the cohort assembled at a uniform point (inception)?
- Did the study attempt to enroll consecutive patients or a random sample?
- Did the study adequately describe baseline demographic characteristics (at least age, sex, and race)?
- Was loss to followup low (<20%) and similar?
- Were outcomes measured using equal, reliable, and valid methods?
- Did the study clearly describe the screening test and methods for classifying results?
- Did the study analyze outcomes in patients with uninterruptable screening test results?
- Was the analysis adjusted for potential confounders?