# Abbreviations and Acronyms

Abbreviation/Acronym: Definition
AAFP: American Academy of Family Physicians
ABI: Ankle-brachial index
ACC: American College of Cardiology
ACCF: American College of Cardiology Foundation
ACP: American College of Physicians
ACPM: American College of Preventive Medicine
ACSM: American College of Sports Medicine
AHA: American Heart Association
AHRQ: Agency for Healthcare Research and Quality
ARIC: Atherosclerosis Risk in Community
AVR: Aortic valve replacement
BIRNH: Belgian Inter-University Research on Nutrition and Health
BP: Blood pressure
bpm: Beats per minute
CABG: Coronary artery bypass graft
CAD: Coronary artery disease
CAS: Coronary artery stenosis
CHD: Coronary heart disease
CHF: Congestive heart failure
CI: Confidence interval
CT: Computed tomography
CVA: Cerebral vascular accident
CVD: Cardiovascular disease
DBP: Diastolic blood pressure
EBCT: Electron-beam computed tomography
ECG: Electrocardiography
ETT: Exercise treadmill test
HDL: High-density lipoprotein
HR: Hazard ratio
HRV: Heart rate variability
KQ: Key question
LDL: Low-density lipoprotein
LVH: Left ventricular hypertrophy
LVM: Left ventricular mass
MET: Metabolic equivalent
MI: Myocardial infarction
MN: Minnesota
MRFIT: Multiple Risk Factor Intervention Trial
NHANES: National Health and Nutrition Examination Survey
NR: Not reported
NS: Not significant
OR: Odds ratio
PCI: Percutaneous coronary intervention
PVD: Premature ventricular depolarization
RCT: Randomized controlled trial
RIFLE: Risk Factors and Life Expectancy
RR: Relative risk
SBP: Systolic blood pressure
SCORE: Systematic Coronary Risk Evaluation
SD: Standard deviation
USPSTF: U.S. Preventive Services Task Force
VA: U.S. Department of Veteran Affairs
VD: Ventricular depolarization
VPC: Ventricular premature complex
WHI: Women’s Health Initiative
WOSCOPS: West of Scotland Coronary Prevention Study