# Appendixes

Appendix A Abbreviations and Acronyms

Appendix B Detailed Methods

Appendix C Quality Tables