# References and Included Studies

(Note: This set of references is different from those in Appendix E.)

1 Inouye SK, Studenski S, Tinetti ME, et al. Geriatric syndromes: clinical, research, and policy implications of a core geriatric concept. J Am Geriatr Soc. 2007;55(5):780-91. [pmid: 17493201].
2 Fried LP, Walston JD, Ferrucci L. Frailty. Halter JB, Ouslander JG, Tinetti ME, Studenski S, High KP, Asthana S, editors. Hazzard’s Geriatric Medicine and Gerontology. 6. New York. McGraw Hill. 2009:631-45.
3 Tinetti ME, Inouye SK, Gill TM, Doucette JT. Shared risk factors for falls, incontinence, and functional dependence: unifying the approach to geriatric syndromes. JAMA. 1995;273(17):1348-53. [pmid: 7715059].
4 Inouye SK, Bogardus ST Jr, Vitagliano G, et al. Burden of illness score for elderly persons: risk adjustment incorporating the cumulative impact of diseases, physiologic abnormalities, and functional impairments. Med Care. 2003;41(1):70-83. [pmid: 12544545].
5 Rakowski W, Fleishman JA, Mor V, Bryant SA. Self-assessments of health and mortality among older persons: do questions other then global self-rated health predict mortality?. Res Aging. 1993;15(1):92-116.
6 Wolinsky FD, Johnson RJ. Perceived health status and mortality among older men and women. J Gerontol. 1992;47(6):S304-12. [pmid: 1430868].
7 Wolinsky FD, Callahan CM, Fitzgerald JF, et al. Changes in functional status and the risks of subsequent nursing home placement and death. J Gerontol. 1993;48(3):S94-101. [pmid: 8482831].
8 Steinbach U. Social networks, institutionalization, and mortality among elderly people in the United States. J Gerontol. 1992;47(4):S183-90. [pmid: 1624713].
9 Johnston CB, Harper GM, Landefeld CS. Geriatric disorders. McPhee SJ, Papadakis MA, editors. Current Medical Diagnosis & Treatment 2011. 50. New York. McGraw Hill. 2011:61-75.
10 Reuben DB, Rosen S. Principles of geriatric assessment. Halter JB, Ouslander JG, Tinetti ME, Studenski S, High KP, Asthana S, editors. Hazzard’s Geriatric Medicine and Gerontology. 6. New York. McGraw Hill. 2009:141-52.
11 Bourdel-Marchasson I, Berrut G. Caring the elderly diabetic patient with respect to concepts of successful aging and frailty. Diabetes Metab. 2005;31(2):5S13-9. [pmid: 16415761].
12 Rockwood K, Song X, MacKnight C, et al. A global clinical measure of fitness and frailty in elderly people. CMAJ. 2005;173(5):489-95. [pmid: 16129869].
13 Rockwood K, Mitnitski A, Song X, et al. Long-term risks of death and institutionalization of elderly people in relation to deficit accumulation at age 70. J Am Geriatr Soc. 2006;54(6):975-9. [pmid: 16776795].
14 Avila-Funes JA, Amieva H, Barberger-Gateau P, et al. Cognitive impairment improves the predictive validity of the phenotype of frailty for adverse health outcomes: the three-city study. J Am Geriatr Soc. 2009;57(3):453-61. [pmid: 19245415].
15 Idler EL, Benyamini Y. Self-rated health and mortality: a review of twenty-seven community studies. J Health Soc Behav. 1997;38(1):21-37. [pmid: 9097506].
16 Branch LG, Katz S, Kniepmann K, et al. A prospective study of functional status among community elders. Am J Public Health. 1984;74(3):266-8. [pmid: 6696160].
17 Manton KG. Recent declines in chronic disability in the elderly U.S. population: risk factors and future dynamics. Annu Rev Public Health. 2008;29:91-113. [pmid: 18031222].
18 Fried LP, Ferrucci L, Darer J, et al. Untangling the concepts of disability, frailty, and comorbidity: implications for improved targeting and care. J Gerontol A Biol Sci Med Sci. 2004;59(3):255-63. [pmid: 15031310].
19 Markle-Reid M, Browne G. Conceptualizations of frailty in relation to older adults. J Adv Nurs. 2003;44(1):58-68. [pmid: 12956670].
20 Brown I, Renwick R, Raphael D. Frailty: constructing a common meaning, definition, and conceptual framework. Int J Rehabil Res. 1995;18(2):93-102. [pmid: 7665266].
21 Bortz WM 2nd. A conceptual framework of frailty: a review. J Gerontol A Biol Sci Med Sci. 2002;57(5):M283-8. [pmid: 11983721].
22 Rockwood K, Andrew M, Mitnitski A. A comparison of two approaches to measuring frailty in elderly people. J Gerontol A Biol Sci Med Sci. 2007;62(7):738-43. [pmid: 17634321].
23 Fried LP, Tangen CM, Walston J, et al. Frailty in older adults: evidence for a phenotype. J Gerontol A Biol Sci Med Sci. 2001;56(3):M146-56. [pmid: 11253156].
24 Ensrud KE, Ewing SK, Taylor BC, et al. Comparison of 2 frailty indexes for prediction of falls, disability, fractures, and death in older women. Arch Intern Med. 2008;168(4):382-9. [pmid: 18299493].
25 Winograd CH, Gerety MB, Chung M, et al. Screening for frailty: criteria and predictors of outcomes. J Am Geriatr Soc. 1991;39(8):778-84. [pmid: 1906492].
26 Drame M, Novella JL, Lang PO, et al. Derivation and validation of a mortality-risk index from a cohort of frail elderly patients hospitalised in medical wards via emergencies: the SAFES study. Eur J Epidemiol. 2008;23(12):783-91. [pmid: 18941907].
27 Fried LP, Kronmal RA, Newman AB, et al. Risk factors for 5-year mortality in older adults: the Cardiovascular Health Study. JAMA. 1998;279(8):585-92. [pmid: 9486752].
28 Avila-Funes JA, Helmer C, Amieva H, et al. Frailty among community-dwelling elderly people in France: the three-city study. J Gerontol A Biol Sci Med Sci. 2008;63(10):1089-96. [pmid: 18948560].
29 Vanitallie TB. Frailty in the elderly: contributions of sarcopenia and visceral protein depletion. Metabolism. 2003;52(10 Suppl 2):22-6. [pmid: 14577059].
30 Kinney JM. Nutritional frailty, sarcopenia and falls in the elderly. Curr Opin Clin Nutr Metab Care. 2004;7(1):15-20. [pmid: 15090898].
31 Bauer JM, Sieber CC. Sarcopenia and frailty: a clinician’s controversial point of view. Exp Gerontol. 2008;43(7):674-8. [pmid: 18440743].
32 Rockwood K, Hogan DB, MacKnight C. Conceptualisation and measurement of frailty in elderly people. Drugs Aging. 2000;17(4):295-302. [pmid: 11087007].
33 Topinkova E. Aging, disability and frailty. Ann Nutr Metab. 2008;52(Suppl 1):6-11. [pmid: 18382070].
34 Cigolle CT, Langa KM, Kabeto MU, et al. Geriatric conditions and disability: the Health and Retirement Study. Ann Intern Med. 2007;147(3):156-64. [pmid: 17679703].
35 Murray MD, Callahan CM. Improving medication use for older adults: an integrated research agenda. Ann Intern Med. 2003;139(5 Pt 2):425-9. [pmid: 12965970].
36 Bruunsgaard H, Pedersen BK. Age-related inflammatory cytokines and disease. Immunol Allergy Clin North Am. 2003;23(1):15-39. [pmid: 12645876].
37 Petersen RC, Smith GE, Waring SC, et al. Mild cognitive impairment: clinical characterization and outcome. Arch Neurol. 1999;56(3):303-8. [pmid: 10190820].
38 Petersen RC, Stevens JC, Ganguli M, et al. Practice parameter: early detection of dementia: mild cognitive impairment (an evidence-based review). Report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. 2001;56(9):1133-42. [pmid: 11342677].
39 Kelman HR, Thomas C, Kennedy GJ, et al. Cognitive impairment and mortality in older community residents. Am J Pub Health. 1994;84(8):1255-60. [pmid: 8059881].
40 Gallo JJ, Schoen R, Jones R. Cognitive impairment and syndromal depression in estimates of active life expectancy: the 13-year follow-up of the Baltimore Epidemiologic Catchment Area sample. Acta Psychiatra Scand. 2000;101(4):265-73.
41 Raji MA, Al Snih S, Ray LA, et al. Cognitive status and incident disability in older Mexican Americans: findings from the Hispanic Established Population for the Epidemiological Study of the Elderly. Ethn Dis. 2004;14(1):26-31. [pmid: 15002920].
42 Rait G, Fletcher A, Smeeth L, et al. Prevalence of cognitive impairment: results from the MRC trial of assessment and management of older people in the community. Age Ageing. 2005;34(3):242-8. [pmid: 15863409].
43 Zanetti M, Ballabio C, Abbate C, et al. Mild cognitive impairment subtypes and vascular dementia in community-dwelling elderly people: a 3-year follow-up study. J Am Geriatr Soc. 2006;54(4):580-6. [pmid: 16686866].
44 Guehne U, Luck T, Busse A, et al. Mortality in individuals with mild cognitive impairment: results of the Leipzig Longitudinal Study of the Aged (LEILA75+). Neuroepidemiology. 2007;29(3–4):226-34. [pmid: 18073495].
45 Plassman BL, Langa KM, Fisher GG, et al. Prevalence of cognitive impairment without dementia in the United States. Ann Intern Med. 2008;148(6):427-34. [pmid: 18347351].
46 Stookey JD, Purser JL, Pieper CF, et al. Plasma hypertonicity: another marker of frailty?. J Am Geriatr Soc. 2004;52(8):1313-20. [pmid: 15271119].
47 Bassuk SS, Berkman LF, Wypij D. Depressive symptomatology and incident cognitive decline in an elderly community sample. Arch Gen Psychiatry. 1998;55(12):1073-81. [pmid: 9862549].
48 Purser JL, Fillenbaum GG, Pieper CF, et al. Mild cognitive impairment and 10-year trajectories of disability in the Iowa Established Population for Epidemiologic Studies of the Elderly cohort. J Am Geriatr Soc. 2005;53(11):1966-72. [pmid: 16274380].
49 Pratt LA, Weeks JD, Goulding MR. Measures of cognitive functioning in the 1994–2000 Second Longitudinal Study of Aging. Natl Health Stat Report. 2008;(2):1-15. [pmid: 18839800].
50 Stephan BC, Matthews FE, McKeith IG, et al. Early cognitive change in the general population: how do different definitions work?. J Am Geriatr Soc. 2007;55(10):1534-40. [pmid: 17908056].
51 Goggins WB, Woo J, Sham A, et al. Frailty index as a measure of biological age in a Chinese population. J Gerontol A Biol Sci Med Sci. 2005;60(8):1046-51. [pmid: 16127111].
52 Searle SD, Mitnitski A, Gahbauer EA, et al. A standard procedure for creating a frailty index. BMC Geriatr. 2008;8:24. [pmid: 18826625].
53 Lee SJ, Lindquist K, Segal MR, et al. Development and validation of a prognostic index for 4-year mortality in older adults. JAMA. 2006;295(7):801-8. [pmid: 16478903].
54 Ganguli M, Dodge HH, Mulsant BH. Rates and predictors of mortality in an aging, rural, community-based cohort: the role of depression. Arch Gen Psychiatry. 2002;59(11):1046-52. [pmid: 12418938].
55 Tabbarah M, Mihelic A, Crimmins E. Disability: the demographics of physical functioning and home environments of older Americans. J Archit Plann Res. 2001;18(3):183-93.
56 Chen PC, Wilmoth JM. The effects of residential mobility on ADL and IADL limitations among the very old living in the community. J Gerontol B Psychol Sci Soc Sci. 2004;59(3):S164-72. [pmid: 15118022].
57 Hanlon JT, Fillenbaum GG, Kuchibhatla M, et al. Impact of inappropriate drug use on mortality and functional status in representative community dwelling elders. Med Care. 2002;40(2):166-76. [pmid: 11802089].
58 Wiener JM, Hanley RJ, Clark R, et al. Measuring the activities of daily living: comparisons across national surveys. J Gerontol. 1990;45(6):S229-37. [pmid: 2146312].
59 Newman AB, Arnold AM, Sachs MC, et al. Long-term function in an older cohort—the Cardiovascular Health Study All Stars Study. J Am Geriatr Soc. 2009;57(3):432-40. [pmid: 19187412].
60 Fuller-Thomson E, Nuru-Jeter A, Minkler M, et al. Black-white disparities in disability among older Americans: further untangling the role of race and socioeconomic status. J Aging Health. 2009;21(5):677-98. [pmid: 19584411].
61 Fuller-Thomson E, Yu B, Nuru-Jeter A, et al. Basic ADL disability and functional limitation rates among older Americans from 2000–2005: the end of the decline?. J Gerontol A Biol Sci Med Sci. 2009;64(12):1333-6. [pmid: 19723771].
62 Goins RT, Moss M, Buchwald D, et al. Disability among older American Indians and Alaska Natives: an analysis of the 2000 Census Public Use Microdata Sample. Gerontologist. 2007;47(5):690-6. [pmid: 17989411].
63 Bannerman E, Miller MD, Daniels LA, et al. Anthropometric indices predict physical function and mobility in older Australians: the Australian Longitudinal Study of Ageing. Public Health Nutr. 2002;5(5):655-62. [pmid: 12372159].
64 Corti MC, Guralnik JM, Salive ME, et al. Serum albumin level and physical disability as predictors of mortality in older persons. JAMA. 1994;272(13):1036-42. [pmid: 8089886].
65 Jette AM, Branch LG, Berlin J. Musculoskeletal impairments and physical disablement among the aged. J Gerontol. 1990;45(6):M203-8. [pmid: 2229943].
66 Nakasato YR, Carnes BA. Myopathy, polymyalgia rheumatica, and temporal arteritis. Halter JB, Ouslander JG, Tinetti ME, Studenski S, High KP, Asthana S, editors. Hazzard’s Geriatric Medicine and Gerontology. 6. New York. McGraw Hill. 2009:1445-52.
67 Gallagher D, Visser M, De Meersman RE, et al. Appendicular skeletal muscle mass: effects of age, gender, and ethnicity. J Appl Physiol. 1997;83(1):229-39. [pmid: 9216968].
68 Baumgartner RN, Koehler KM, Gallagher D, et al. Epidemiology of sarcopenia among the elderly in New Mexico. Am J Epidemiol. 1998;147(8):755-63. [pmid: 9554417].
69 Cruz-Jentoft AJ, Baeyens JP, Bauer JM, et al. Sarcopenia: European consensus on definition and diagnosis. Report of the European Working Group on Sarcopenia in Older People. Age Ageing. 2010;39(4):412-23. [pmid: 20392703].
70 Beck AM, Ovesen L, Osler M. ‘The Mini Nutritional Assessment’ (MNA) and the ‘Determine Your Nutritional Health’ checklist (NSI checklist) as predictors of morbidity and mortality in an elderly Danish population. Br J Nutr. 1999;81(1):31-6. [pmid: 10341673].
71 Newman AB, Yanez D, Harris T, et al. Weight change in old age and its association with mortality. J Am Geriatr Soc. 2001;49(10):1309-18. [pmid: 11890489].
72 Marshall JA, Lopez TK, Shetterly SM, et al. Indicators of nutritional risk in a rural elderly Hispanic and non-Hispanic white population: San Luis Valley Health and Aging Study. J Am Diet Assoc. 1999;99(3):315-22. [pmid: 10076583].
73 Onder G, Landi F, Volpato S, et al. Serum cholesterol levels and in-hospital mortality in the elderly. Am J Med. 2003;115(4):265-71. [pmid: 12967690].
74 Shannon J, Shikany JM, Barrett-Connor E, et al. Demographic factors associated with the diet quality of older US men: baseline data from the Osteoporotic Fractures in Men (MrOS) Study. Public Health Nutr. 2007;10(8):810-8. [pmid: 17381915].
75 Martin CT, Kayser-Jones J, Stotts NA, et al. Risk for low weight in community-dwelling, older adults. Clin Nurse Spec. 2007;21(4):203-11. [pmid: 17622809].
76 Ledikwe JH, Smiciklas-Wright H, Mitchell DC, et al. Dietary patterns of rural older adults are associated with weight and nutritional status. J Am Geriatr Soc. 2004;52(4):589-95. [pmid: 15066076].
77 Lesourd B, Decarli B, Dirren H. Longitudinal changes in iron and protein status of elderly Europeans. Eur J Clin Nutr. 1996;50(Suppl 2):S16-24. [pmid: 8841781].
78 Dallman PR, Yip R, Johnson C. Prevalence and causes of anemia in the United States, 1976 to 1980. Am J Clin Nutr. 1984;39(3):437-45. [pmid: 6695843].
79 Patel KV, Semba RD, Ferrucci L, et al. Red cell distribution width and mortality in older adults: a meta-analysis. J Gerontol A Biol Sci Med Sci. 2010;65(3):258-65. [pmid: 19880817].
80 Visser M, Deeg DJ, Puts MT, et al. Low serum concentrations of 25-hydroxyvitamin D in older persons and the risk of nursing home admission. Am J Clin Nutr. 2006;84(3):616-22. [pmid: 16960177].
81 Johnson MA, Fischer JG, Park S. Vitamin D deficiency and insufficiency in the Georgia Older Americans Nutrition Program. J Nutr Elder. 2008;27(1–2):29-46. [pmid: 18928189].
82 de Groot LC, Beck AM, Schroll M, et al. Evaluating the Determine Your Nutritional Health Checklist and the Mini Nutritional Assessment as tools to identify nutritional problems in elderly Europeans. Eur J Clin Nutr. 1998;52(12):877-83. [pmid: 9881882].
83 Visvanathan R, Macintosh C, Callary M, et al. The nutritional status of 250 older Australian recipients of domiciliary care services and its association with outcomes at 12 months. J Am Geriatr Soc. 2003;51(7):1007-11. [pmid: 12834523].
84 Weatherspoon LJ, Worthen HD, Handu D. Nutrition risk and associated factors in congregate meal participants in northern Florida: role of Elder Care Services (ECS). J Nutr Elder. 2004;24(2):37-54. [pmid: 15778156].
85 Yap KB, Niti M, Ng TP. Nutrition screening among community-dwelling older adults in Singapore. Singapore Med J. 2007;48(10):911-6. [pmid: 17909675].
86 Nelson KM, Reiber G, Kohler T, et al. Peripheral arterial disease in a multiethnic national sample: the role of conventional risk factors and allostatic load. Ethn Dis. 2007;17(4):669-75. [pmid: 18072377].
87 Cao JJ, Arnold AM, Manolio TA, et al. Association of carotid artery intima-media thickness, plaques, and C-reactive protein with future cardiovascular disease and all-cause mortality: the Cardiovascular Health Study. Circulation. 2007;116(1):32-8. [pmid: 17576871].
88 Visser M, Pahor M, Taaffe DR, et al. Relationship of interleukin-6 and tumor necrosis factor-alpha with muscle mass and muscle strength in elderly men and women: the Health ABC Study. J Gerontol A Biol Sci Med Sci. 2002;57(5):M326-32. [pmid: 11983728].
89 Szanton SL, Allen JK, Seplaki CL, et al. Allostatic load and frailty in the Women’s Health and Aging Studies. Biol Res Nurs. 2009;10(3):248-56. [pmid: 18829589].
90 Lopez OL, Jagust WJ, DeKosky ST, et al. Prevalence and classification of mild cognitive impairment in the Cardiovascular Health Study Cognition Study: part 1. Arch Neurol. 2003;60(10):1385-9. [pmid: 14568808].
91 Kravitz BA, Corrada MM, Kawas CH. High levels of serum C-reactive protein are associated with greater risk of all-cause mortality, but not dementia, in the oldest-old: results from the 90+ Study. J Am Geriatr Soc. 2009;57(4):641-6. [pmid: 19245412].
92 Evans DA, Funkenstein HH, Albert MS, et al. Prevalence of Alzheimer’s disease in a community population of older persons: higher than previously reported. JAMA. 1989;262(18):2551-6. [pmid: 2810583].
93 Ritchie K, Kildea D. Is senile dementia “age-related” or “ageing-related”?—evidence from meta-analysis of dementia prevalence in the oldest old. Lancet. 1995;346(8980):931-4. [pmid: 7564727].
94 Helmer C, Barberger-Gateau P, Letenneur L, et al. Subjective health and mortality in French elderly women and men. J Gerontol B Psychol Sci Soc Sci. 1999;54(2):S84-92. [pmid: 10097778].
95 Graham JE, Rockwood K, Beattie BL, et al. Prevalence and severity of cognitive impairment with and without dementia in an elderly population. Lancet. 1997;349:1793-6. [pmid: 9269213].
96 Pearson JM, Schlettwein-Gsell D, Brzozowska A, et al. Life style characteristics associated with nutritional risk in elderly subjects aged 80–85 years. J Nutr Health Aging. 2001;5(4):278-83. [pmid: 11753495].
97 Rocca WA, Hofman A, Brayne C, et al. The prevalence of vascular dementia in Europe: facts and fragments from 1980–1990 studies. Ann Neurol. 1991;30(6):817-24. [pmid: 1838681].
98 Tuokko H, Frerichs RJ. Cognitive impairment with no dementia (CIND): longitudinal studies, the findings, and the issues. Clin Neuropsychol. 2000;14(4):504-25. [pmid: 11262720].
99 Aggarwal NT, Wilson RS, Beck TL, et al. Mild cognitive impairment in different functional domains and incident Alzheimer’s disease. J Neurol Neurosurg Psychiatry. 2005;76(11):1479-84. [pmid: 16227534].
100 Jessen F, Wiese B, Bachmann C, et al. Prediction of dementia by subjective memory impairment: effects of severity and temporal association with cognitive impairment. Arch Gen Psychiatry. 2010;67(4):414-22. [pmid: 20368517].
101 Brody KK, Johnson RE, Douglas Ried L. Evaluation of a self-report screening instrument to predict frailty outcomes in aging populations. Gerontologist. 1997;37(2):182-91. [pmid: 9127974].
102 Kang HG, Costa MD, Priplata AA, et al. Frailty and the degradation of complex balance dynamics during a dual-task protocol. J Gerontol A Biol Sci Med Sci. 2009;64(12):1304-11. [pmid: 19679739].
103 Gutman GM, Stark A, Donald A, et al. Contribution of self-reported health ratings to predicting frailty, institutionalization, and death over a 5-year period. Int Psychogeriatr. 2001;13(Supp 1):223-31. [pmid: 11892970].
104 Cigolle CT, Ofstedal MB, Tian Z, et al. Comparing models of frailty: the Health and Retirement Study. J Am Geriatr Soc. 2009;57(5):830-9. [pmid: 19453306].
105 Peterson MJ, Giuliani C, Morey MC, et al. Physical activity as a preventative factor for frailty: the Health, Aging, and Body Composition Study. J Gerontol A Biol Sci Med Sci. 2009;64(1):61-8. [pmid: 19164276].
106 Bowles J, Brooks T, Hayes-Reams P, et al. Frailty, family, and church support among urban African American elderly. J Health Care Poor Underserved. 2000;11(1):87-99. [pmid: 10778045].
107 Hardy SE, Dubin JA, Holford TR, et al. Transitions between states of disability and independence among older persons. Am J Epidemiol. 2005;161(6):575-84. [pmid: 15746474].
108 Ottenbacher KJ, Graham JE, Al Snih S, et al. Mexican Americans and frailty: findings from the Hispanic Established Populations Epidemiologic Studies of the Elderly. Am J Public Health. 2009;99(4):673-9. [pmid: 19197079].
109 Kiely DK, Cupples LA, Lipsitz LA. Validation and comparison of two frailty indexes: the MOBILIZE Boston Study. J Am Geriatr Soc. 2009;57(9):1532-9. [pmid: 19682112].
110 Santos-Eggimann B, Cuenoud P, Spagnoli J, et al. Prevalence of frailty in middle-aged and older community-dwelling Europeans living in 10 countries. J Gerontol A Biol Sci Med Sci. 2009;64(6):675-81. [pmid: 19276189].
111 Klein BE, Klein R, Knudtson MD, et al. Frailty, morbidity and survival. Arch Gerontol Geriatr. 2005;41(2):141-9. [pmid: 16085065].
112 Kenny AM, Waynik IY, Smith J, et al. Association between level of frailty and bone mineral density in community-dwelling men. J Clin Densitom. 2006;9(3):309-14. [pmid: 16931349].
113 Cawthon PM, Marshall LM, Michael Y, et al. Frailty in older men: prevalence, progression, and relationship with mortality. J Am Geriatr Soc. 2007;55(8):1216-23. [pmid: 17661960].
114 Ensrud KE, Ewing SK, Cawthon PM, et al. A comparison of frailty indexes for the prediction of falls, disability, fractures, and mortality in older men. J Am Geriatr Soc. 2009;57(3):492-8. [pmid: 19245414].
115 Song X, Mitnitski A, Rockwood K. Prevalence and 10-year outcomes of frailty in older adults in relation to deficit accumulation. J Am Geriatr Soc. 2010;58(4):681-7. [pmid: 20345864].
116 Ottenbacher KJ, Ostir GV, Peek MK, et al. Frailty in older Mexican Americans. J Am Geriatr Soc. 2005;53(9):1524-31. [pmid: 16137282].
117 Chang SS, Weiss CO, Xue QL, et al. Patterns of comorbid inflammatory diseases in frail older women: the Women’s Health and Aging Studies I and II. J Gerontol A Biol Sci Med Sci. 2010;65(4):407-13. [pmid: 19933749].
118 Gardener EA, Huppert FA, Guralnik JM, et al. Middle-aged and mobility-limited: prevalence of disability and symptom attributions in a national survey. J Gen Intern Med. 2006;21(10):1091-6. [pmid: 16970558].
119 Hays JC, Keller HH, Ostbye T. The effects of nutrition-related factors on four-year mortality among a biracial sample of community-dwelling elders in the North Carolina Piedmont. J Nutr Elder. 2005;25(2):41-67. [pmid: 17182466].
120 Murtagh KN, Hubert HB. Gender differences in physical disability among an elderly cohort. Am J Public Health. 2004;94(8):1406-11. [pmid: 15284051].
121 Crimmins EM, Saito Y, Reynolds SL. Further evidence on recent trends in the prevalence and incidence of disability among older Americans from two sources: the LSOA and the NHIS. J Gerontol B Psychol Sci Soc Sci. 1997;52(2):S59-71. [pmid: 9060986].
122 Albert SM, Alam M, Nizamuddin M, et al. Comparative study of functional limitation and disability in old age: Delhi and New York City. J Cross Cult Gerontol. 2005;20(3):231-41. [pmid: 17013664].
123 Newman AB, Kupelian V, Visser M, et al. Sarcopenia: alternative definitions and associations with lower extremity function. J Am Geriatr Soc. 2003;51(11):1602-9. [pmid: 14687390].
124 Seeman TE, Crimmins E, Huang MH, et al. Cumulative biological risk and socio-economic differences in mortality: MacArthur Studies of Successful Aging. Soc Sci Med. 2004;58(10):1985-97. [pmid: 15020014].
125 Schultz-Larsen K, Avlund K. Tiredness in daily activities: a subjective measure for the identification of frailty among non-disabled community-living older adults. Arch Gerontol Geriatr. 2007;44(1):83-93. [pmid: 17095107].
126 Dorr DA, Jones SS, Burns L, et al. Use of health-related, quality-of-life metrics to predict mortality and hospitalizations in community-dwelling seniors. J Am Geriatr Soc. 2006;54(4):667-73. [pmid: 16686880].
127 Long SK, Liu K, Black K, et al. Getting by in the community: lessons from frail elders. J Aging Soc Policy. 2005;17(1):19-44. [pmid: 15760799].
128 Mor V, Wilcox V, Rakowski W, et al. Functional transitions among the elderly: patterns, predictors, and related hospital use. Am J Public Health. 1994;84(8):1274-80. [pmid: 8059885].
129 Tilvis RS, Kahonen-Vare MH, Jolkkonen J, et al. Predictors of cognitive decline and mortality of aged people over a 10-year period. J Gerontol A Biol Sci Med Sci. 2004;59(3):268-74. [pmid: 15031312].
130 Ahmad R, Bath PA. Identification of risk factors for 15-year mortality among community-dwelling older people using Cox regression and a genetic algorithm. J Gerontol A Biol Sci Med Sci. 2005;60(8):1052-8. [pmid: 16127112].
131 Onawola RS, LaVeist TA. Subjective health status as a determinant of mortality among African-American elders. J Natl Med Assoc. 1998;90(12):754-8. [pmid: 9884495].
132 Kersting RC. Impact of social support, diversity, and poverty on nursing home utilization in a nationally representative sample of older Americans. Soc Work Health Care. 2001;33(2):67-87. [pmid: 11760116].
133 Shelton P, Sager MA, Schraeder C. The Community Assessment Risk Screen (CARS): identifying elderly persons at risk for hospitalization or emergency department visit. Am J Manag Care. 2000;6(8):925-33. [pmid: 11186504].
134 Mazzaglia G, Roti L, Corsini G, et al. Screening of older community-dwelling people at risk for death and hospitalization: the Assistenza Socio-Sanitaria in Italia project. J Am Geriatr Soc. 2007;55(12):1955-60. [pmid: 17944891].
135 Wolinsky FD, Culler SD, Callahan CM, et al. Hospital resource consumption among older adults: a prospective analysis of episodes, length of stay, and charges over a seven-year period. J Gerontol. 1994;49(5):S240-52. [pmid: 8056953].
136 Aliyu MH, Adediran AS, Obisesan TO. Predictors of hospital admissions in the elderly: analysis of data from the Longitudinal Study on Aging. J Natl Med Assoc. 2003;95(12):1158-67. [pmid: 14717472].
137 Laditka JN. Hazards of hospitalization for ambulatory care sensitive conditions among older women: evidence of greater risks for African Americans and Hispanics. Med Care Res Rev. 2003;60(4):468-95. [pmid: 14677221].
138 Wolinsky FD, Stump TE, Johnson RJ. Hospital utilization profiles among older adults over time: consistency and volume among survivors and decedents. J Gerontol B Psychol Sci Soc Sci. 1995;50(2):S88-100. [pmid: 7757844].
139 Stearns SC, Kovar MG, Hayes K, et al. Risk indicators for hospitalization during the last year of life. Health Serv Res. 1996;31(1):49-69. [pmid: 8617609].
140 Boult C, Dowd B, McCaffrey D, et al. Screening elders for risk of hospital admission. J Am Geriatr Soc. 1993;41(8):811-7. [pmid: 8340558].
141 Ostbye T, Hill G, Steenhuis R. Mortality in elderly Canadians with and without dementia: a 5-year follow-up. Neurology. 1999;53(3):521-6. [pmid: 10449114].
142 Ostbye T, Steenhuis R, Wolfson C, et al. Predictors of five-year mortality in older Canadians: the Canadian Study of Health and Aging. J Am Geriatr Soc. 1999;47(10):1249-54. [pmid: 10522960].
143 Royall DR, Chiodo LK, Mouton C, et al. Cognitive predictors of mortality in elderly retirees: results from the Freedom House Study. Am J Geriatr Psychiatry. 2007;15(3):243-51. [pmid: 17322135].
144 Keller BK, Potter JF. Predictors of mortality in outpatient geriatric evaluation and management clinic patients. J Gerontol. 1994;49(6):M246-51. [pmid: 7963276].
145 St John PD, Montgomery PR, Kristjansson B, et al. Cognitive scores, even within the normal range, predict death and institutionalization. Age Ageing. 2002;31(5):373-8. [pmid: 12242200].
146 Wikby A, Ferguson F, Forsey R, et al. An immune risk phenotype, cognitive impairment, and survival in very late life: impact of allostatic load in Swedish octogenarian and nonagenarian humans. J Gerontol A Biol Sci Med Sci. 2005;60(5):556-65. [pmid: 15972602].
147 Rothman MD, Leo-Summers L, Gill TM. Prognostic significance of potential frailty criteria. J Am Geriatr Soc. 2008;56(12):2211-6. [pmid: 19093920].
148 Graham JE, Snih SA, Berges IM, et al. Frailty and 10-year mortality in community-living Mexican American older adults. Gerontology. 2009;55(6):644-51. [pmid: 19690395].
149 Dewey ME, Saz P. Dementia, cognitive impairment and mortality in persons aged 65 and over living in the community: a systematic review of the literature. Int J Geriatr Psychiatry. 2001;16(8):751-61. [pmid: 11536341].
150 Goodlin S, Boult C, Bubolz T, et al. Who will need long-term care? Creation and validation of an instrument that identifies older people at risk. Dis Manag. 2004;7(4):267-74. [pmid: 15671784].
151 Rockwood K, Stolee P, McDowell I. Factors associated with institutionalization of older people in Canada: testing a multifactorial definition of frailty. J Am Geriatr Soc. 1996;44(5):578-82. [pmid: 8617909].
152 Eaker ED, Vierkant RA, Mickel SF. Predictors of nursing home admission and/or death in incident Alzheimer’s disease and other dementia cases compared to controls: a population-based study. J Clin Epidemiol. 2002;55(5):462-8. [pmid: 12007549].
153 Jones DM, Song X, Rockwood K. Operationalizing a frailty index from a standardized comprehensive geriatric assessment. J Am Geriatr Soc. 2004;52(11):1929-33. [pmid: 15507074].
154 Mitnitski A, Song X, Skoog I, et al. Relative fitness and frailty of elderly men and women in developed countries and their relationship with mortality. J Am Geriatr Soc. 2005;53(12):2184-9. [pmid: 16398907].
155 Jones D, Song X, Mitnitski A, et al. Evaluation of a frailty index based on a comprehensive geriatric assessment in a population based study of elderly Canadians. Aging Clin Exp Res. 2005;17(6):465-71. [pmid: 16485864].
156 Kulminski AM, Ukraintseva SV, Kulminskaya IV, et al. Cumulative deficits better characterize susceptibility to death in elderly people than phenotypic frailty: lessons from the Cardiovascular Health Study. J Am Geriatr Soc. 2008;56(5):898-903. [pmid: 18363679].
157 Hastings SN, Purser JL, Johnson KS, et al. Frailty predicts some but not all adverse outcomes in older adults discharged from the emergency department. J Am Geriatr Soc. 2008;56(9):1651-7. [pmid: 18691282].
158 Puts MT, Lips P, Deeg DJ. Sex differences in the risk of frailty for mortality independent of disability and chronic diseases. J Am Geriatr Soc. 2005;53(1):40-7. [pmid: 15667374].
159 Gu D, Dupre ME, Sautter J, et al. Frailty and mortality among Chinese at advanced ages. J Gerontol B Psychol Sci Soc Sci. 2009;64(2):279-89. [pmid: 19196691].
160 Bandeen-Roche K, Xue QL, Ferrucci L, et al. Phenotype of frailty: characterization in the Women’s Health and Aging Studies. J Gerontol A Biol Sci Med Sci. 2006;61(3):262-6. [pmid: 16567375].
161 Dukers DF, Vermeer MH, Jaspars LH, et al. Expression of killer cell inhibitory receptors is restricted to true NK cell lymphomas and a subset of intestinal enteropathy-type T cell lymphomas with a cytotoxic phenotype. J Clin Pathol. 2001;54(3):224-8. [pmid: 11253136].
162 Harris T, Kovar MG, Suzman R, et al. Longitudinal study of physical ability in the oldest-old. Am J Public Health. 1989;79(6):698-702. [pmid: 2729466].
163 Ferrucci L, Guralnik JM, Pahor M, et al. Hospital diagnoses, Medicare charges, and nursing home admissions in the year when older persons become severely disabled. JAMA. 1997;277(9):728-34. [pmid: 9042845].
164 Anderson RT, James MK, Miller ME, et al. The timing of change: patterns in transitions in functional status among elderly persons. J Gerontol B Psychol Sci Soc Sci. 1998;53:S17-27. [pmid: 9469176].
165 Cesari M, Pahor M, Lauretani F, et al. Skeletal muscle and mortality results from the InCHIANTI Study. J Gerontol A Biol Sci Med Sci. 2009;64(3):377-84. [pmid: 19181709].
166 Volpato S, Guralnik JM, Ferrucci L, et al. Cardiovascular disease, interleukin-6, and risk of mortality in older women: the Women’s Health and Aging Study. Circulation. 2001;103(7):947-53. [pmid: 11181468].
167 Raynaud-Simon A, Lafont S, Berr C, et al. Orosomucoid: a mortality risk factor in elderly people living in the community?. Clin Nutr. 2002;21(1):45-50. [pmid: 11884012].
168 Zakai NA, Katz R, Hirsch C, et al. A prospective study of anemia status, hemoglobin concentration, and mortality in an elderly cohort: the Cardiovascular Health Study. Arch Intern Med. 2005;165(19):2214-20. [pmid: 16246985].
169 Semba RD, Ricks MO, Ferrucci L, et al. Types of anemia and mortality among older disabled women living in the community: the Women’s Health and Aging Study I. Aging Clin Exp Res. 2007;19(4):259-64. [pmid: 17726354].
170 Carriere I, Dupuy AM, Lacroux A, et al. Biomarkers of inflammation and malnutrition associated with early death in healthy elderly people. J Am Geriatr Soc. 2008;56(5):840-6. [pmid: 18410327].
171 Zoppini G, Verlato G, Targher G, et al. Variability of body weight, pulse pressure and glycaemia strongly predict total mortality in elderly type 2 diabetic patients: the Verona Diabetes Study. Diabetes Metab Res Rev. 2008;24(8):624-8. [pmid: 18802932].
172 Seeman TE, McEwen BS, Rowe JW, et al. Allostatic load as a marker of cumulative biological risk: MacArthur Studies of Successful Aging. Proc Natl Acad Sci U S A. 2001;98(8):4770-5. [pmid: 11287659].
173 Karlamangla AS, Singer BH, Seeman TE. Reduction in allostatic load in older adults is associated with lower all-cause mortality risk: MacArthur Studies of Successful Aging. Psychosom Med. 2006;68(3):500-7. [pmid: 16738085].
174 Harris TB, Ferrucci L, Tracy RP, et al. Associations of elevated interleukin-6 and C-reactive protein levels with mortality in the elderly. Am J Med. 1999;106(5):506-12. [pmid: 10335721].
175 Cohen HJ, Harris T, Pieper CF. Coagulation and activation of inflammatory pathways in the development of functional decline and mortality in the elderly. Am J Med. 2003;114(3):180-7. [pmid: 12637131].
176 Bruunsgaard H, Andersen-Ranberg K, Hjelmborg JB, et al. Elevated levels of tumor necrosis factor alpha and mortality in centenarians. Am J Med. 2003;115(4):278-83. [pmid: 12967692].
177 Alley DE, Crimmins E, Bandeen-Roche K, et al. Three-year change in inflammatory markers in elderly people and mortality: the Invecchiare in Chianti Study. J Am Geriatr Soc. 2007;55(11):1801-7. [pmid: 17727645].
178 Jenny NS, Yanez ND, Psaty BM, et al. Inflammation biomarkers and near-term death in older men. Am J Epidemiol. 2007;165(6):684-95. [pmid: 17215383].
179 Jylha M, Paavilainen P, Lehtimaki T, et al. Interleukin-1 receptor antagonist, interleukin-6, and C-reactive protein as predictors of mortality in nonagenarians: the Vitality 90+ Study. J Gerontol A Biol Sci Med Sci. 2007;62(9):1016-21. [pmid: 17895441].
180 Pilotto A, Ferrucci L, Franceschi M, et al. Development and validation of a multidimensional prognostic index for one-year mortality from comprehensive geriatric assessment in hospitalized older patients. Rejuvenation Res. 2008;11(1):151-61. [pmid: 18173367].
181 Walter LC, Brand RJ, Counsell SR, et al. Development and validation of a prognostic index for 1-year mortality in older adults after hospitalization. JAMA. 2001;285(23):2987-94. [pmid: 11410097].
182 Levine SK, Sachs GA, Jin L, et al. A prognostic model for 1-year mortality in older adults after hospital discharge. Am J Med. 2007;120(5):455-60. [pmid: 17466658].
183 Purser JL, Kuchibhatla MN, Fillenbaum GG, et al. Identifying frailty in hospitalized older adults with significant coronary artery disease. J Am Geriatr Soc. 2006;54(11):1674-81. [pmid: 17087693].
184 Carey EC, Covinsky KE, Lui LY, et al. Prediction of mortality in community-living frail elderly people with long-term care needs. J Am Geriatr Soc. 2008;56(1):68-75. [pmid: 18031487].
185 Melzer D, Lan TY, Guralnik JM. The predictive validity for mortality of the index of mobility-related limitation—results from the EPESE Study. Age Ageing. 2003;32(6):619-25. [pmid: 14600003].
186 Schonberg MA, Davis RB, McCarthy EP, et al. Index to predict 5-year mortality of community-dwelling adults aged 65 and older using data from the National Health Interview Survey. J Gen Intern Med. 2009;24(10):1115-22. [pmid: 19649678].
187 Carey EC, Walter LC, Lindquist K, et al. Development and validation of a functional morbidity index to predict mortality in community-dwelling elders. J Gen Intern Med. 2004;19(10):1027-33. [pmid: 15482555].
188 Gill TM, Gahbauer EA, Allore HG, et al. Transitions between frailty states among community-living older persons. Arch Intern Med. 2006;166(4):418-23. [pmid: 16505261].
189 Pijpers E, Ferreira I, van de Laar RJ, et al. Predicting mortality of psychogeriatric patients: a simple prognostic frailty risk score. Postgrad Med J. 2009;85(1007):464-9. [pmid: 19734513].
190 Garcia-González JJ, Garcia-Peña C, Franco-Marina F, Gutiérrez-Robledo LM. A frailty index to predict the mortality risk in a population of senior Mexican adults. BMC Geriatr. 2009;9:47. [pmid: 19887005].
191 Ravaglia G, Forti P, Lucicesare A, et al. Development of an easy prognostic score for frailty outcomes in the aged. Age Ageing. 2008;37(2):161-6. [pmid: 18238805].
192 Albertsson DM, Mellstrom D, Petersson C, et al. Validation of a 4-item score predicting hip fracture and mortality risk among elderly women. Ann Fam Med. 2007;5(1):48-56. [pmid: 17261864].
193 Song X, Mitnitski A, MacKnight C, et al. Assessment of individual risk of death using self-report data: an artificial neural network compared with a frailty index. J Am Geriatr Soc. 2004;52(7):1180-4. [pmid: 15209659].
194 Mitnitski AB, Graham JE, Mogilner AJ, Rockwood K. Frailty, fitness and late-life mortality in relation to chronological and biological age. BMC Geriatr. 2002;2:1. [pmid: 11897015].
195 Woloshin S, Schwartz LM, Welch HG. The risk of death by age, sex, and smoking status in the United States: putting health risks in context. J Natl Cancer Inst. 2008;100(12):845-53. [pmid: 18544745].
196 Fried LP, Kronmal RA, Newman AB, et al. Risk factors for 5-year mortality in older adults: the Cardiovascular Health Study. JAMA. 1998;279(8):585-92. [pmid: 9486752].
197 Lee HB, Kasper JD, Shore AD, et al. Level of cognitive impairment predicts mortality in high-risk community samples: the Memory and Medical Care Study. J Neuropsychiatry Clin Neurosci. 2006;18(4):543-6. [pmid: 17135381].
198 Saletti A, Johansson L, Yifter-Lindgren E, et al. Nutritional status and a 3-year follow-up in elderly receiving support at home. Gerontology. 2005;51(3):192-8. [pmid: 15832047].
199 Stump TE, Callahan CM, Hendrie HC. Cognitive impairment and mortality in older primary care patients. J Am Geriatr Soc. 2001;49(7):934-40. [pmid: 11527485].
200 Wallace BC, Schmid CH, Lau J, Trikalinos TA. Meta-Analyst: software for meta-analysis of binary, continuous and diagnostic data. BMC Med Res Methodol. 2009;9:80. [pmid: 19961608].
201 Kuchel GA. Aging and homeostatic regulation. Halter JB, Ouslander JG, Tinetti ME, Studenski S, High KP, Asthana S, editors. Hazzard’s Geriatric Medicine and Gerontology. 6. New York. McGraw Hill. 2009:621-31.
202 Pizzarelli F, Lauretani F, Bandinelli S, et al. Predictivity of survival according to different equations for estimating renal function in community-dwelling elderly subjects. Nephrol Dial Transplant. 2009;24(4):1197-205. [pmid: 18988669].
203 Yancik R, Ershler W, Satariano W, et al. Report of the National Institute on Aging Task Force on Comorbidity. J Gerontol A Biol Sci Med Sci. 2007;62(3):275-80. [pmid: 17389724].
204 Charlson ME, Pompei P, Ales KL, et al. A new method of classifying prognostic comorbidity in longitudinal studies: development and validation. J Chronic Dis. 1987;40(5):373-83. [pmid: 3558716].
205 Haider SI, Johnell K, Weitoft GR, et al. The influence of educational level on polypharmacy and inappropriate drug use: a register-based study of more than 600,000 older people. J Am Geriatr Soc. 2009;57(1):62-9. [pmid: 19054196].
206 Haider SI, Johnell K, Thorslund M, et al. Trends in polypharmacy and potential drug-drug interactions across educational groups in elderly patients in Sweden for the period 1992–2002. Int J Clin Pharmacol Ther. 2007;45(12):643-53. [pmid: 18184532].
207 Idler EL, Russell LB, Davis D. Survival, functional limitations, and self-rated health in the NHANES I Epidemiologic Follow-up Study, 1992. Am J Epidemiol. 2000;152(9):874-83. [pmid: 11085400].
208 Krause NM, Jay GM. What do global self-rated health items measure?. Med Care. 1994;32(9):930-42. [pmid: 8090045].
209 Ferrucci L, Guralnik JM, Studenski S, et al. Designing randomized, controlled trials aimed at preventing or delaying functional decline and disability in frail, older persons: a consensus report. J Am Geriatr Soc. 2004;52(4):625-34. [pmid: 15066083].
210 Higgins JP, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Chichester, England. Wiley-Blackwell. 2008.
211 Viechtbauer W. Confidence intervals for the amount of heterogeneity in meta-analysis. Stat Med. 2007;26(1):37-52. [pmid: 16463355].
212 Knapp G, Biggerstaff BJ, Hartung J. Assessing the amount of heterogeneity in random-effects meta-analysis. Biom J. 2006;48(2):271-85. [pmid: 16708778].
213 Drummond MF. Methods for the Economic Evaluation of Health Care Programmes. 2. Oxford, England. Oxford University Press. 1997.
214 Gerard K, Seymour J, Smoker I. A tool to improve quality of reporting published economic analyses. Int J Technol Assess Health Care. 2000;16(1):100-10. [pmid: 10815357].
215 Aschengrau A, Seage GR III. Essentials of Epidemiology in Public Health. Sudbury, MA. Jones and Bartlett. 2003.
216 Sawaya GF, Guirguis-Blake J, LeFevre M, et al. Update on the methods of the U.S. Preventive Services Task Force: estimating certainty and magnitude of net benefit. Ann Intern Med. 2007;147(12):871-5. [pmid: 18087058].
217 Methods Guide for Comparative Effectiveness Reviews, AHRQ Publication No 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2011. Accessed at http://www.effectivehealthcare.ahrq.gov/healthInfo.cfm?infotype=rr&ProcessID=60. 2 June 2011.
218 Bartali B, Frongillo EA, Guralnik JM, et al. Serum micronutrient concentrations and decline in physical function among older persons. JAMA. 2008;299(3):308-15. [pmid: 18212315].
219 van den Biggelaar AH, Huizinga TW, de Craen AJ, et al. Impaired innate immunity predicts frailty in old age: the Leiden 85-Plus Study. Exp Gerontol. 2004;39(9):1407-14. [pmid: 15489064].
220 Sarkisian CA, Gruenewald TL, John Boscardin W, et al. Preliminary evidence for subdimensions of geriatric frailty: the MacArthur Study of Successful Aging. J Am Geriatr Soc. 2008;56(12):2292-7. [pmid: 19016933].
221 Ory MG, Schechtman KB, Miller JP, et al. Frailty and injuries in later life: the FICSIT trials. J Am Geriatr Soc. 1993;41(3):283-96. [pmid: 8440853].
222 Brown M, Sinacore DR, Binder EF, et al. Physical and performance measures for the identification of mild to moderate frailty. J Gerontol A Biol Sci Med Sci. 2000;55(6):350-5.
223 Gill TM, Williams CS, Richardson ED, et al. Impairments in physical performance and cognitive status as predisposing factors for functional dependence among nondisabled older persons. J Gerontol A Biol Sci Med Sci. 1996;51(6):M283-8. [pmid: 8914500].
224 Winograd CH, Gerety MB, Brown E, et al. Targeting the hospitalized elderly for geriatric consultation. J Am Geriatr Soc. 1988;36(12):1113-9. [pmid: 3192889].
225 Strawbridge WJ, Shema SJ, Balfour JL, et al. Antecedents of frailty over three decades in an older cohort. J Gerontol B Psychol Sci Soc Sci. 1998;53(1):S9-16. [pmid: 9469175].
226 Saliba D, Elliott M, Rubenstein LZ, et al. The Vulnerable Elders Survey: a tool for identifying vulnerable older people in the community. J Am Geriatr Soc. 2001;49(12):1691-9. [pmid: 11844005].
227 Pendergast DR, Fisher NM, Calkins E. Cardiovascular, neuromuscular, and metabolic alterations with age leading to frailty. J Gerontol. 1993;48:61-7. [pmid: 8409243].
228 Campbell AJ, Buchner DM. Unstable disability and the fluctuations of frailty. Age Ageing. 1997;26(4):315-8. [pmid: 9271296].
229 Dayhoff NE, Suhrheinrich J, Wigglesworth J, et al. Balance and muscle strength as predictors of frailty among older adults. J Gerontol Nurs. 1998;24(7):18-27. [pmid: 9801527].
230 Vellas B, Gillette-Guyonnet S, Nourhashémi F, et al. Falls, frailty and osteoporosis in the elderly: a public health problem [in French]. Rev Med Interne. 2000;21(7):608-13. [pmid: 10942977].
231 Rockwood K, Fox RA, Stolee P, et al. Frailty in elderly people: an evolving concept. CMAJ. 1994;150(4):489-95. [pmid: 8313261].
232 Chin AP, Dekker JM, Feskens EJ, et al. How to select a frail elderly population? A comparison of three working definitions. J Clin Epidemiol. 1999;52(11):1015-21. [pmid: 10526994].
233 Friedman DS, Wolfs RC, O’Colmain BJ, et al. Prevalence of open-angle glaucoma among adults in the United States. Arch Ophthalmol. 2004;122(4):532-8. [pmid: 15078671].
234 Jefferson AL, Massaro JM, Wolf PA, et al. Inflammatory biomarkers are associated with total brain volume: the Framingham Heart Study. Neurology. 2007;68(13):1032-8. [pmid: 17389308].
235 Stewart R, Masaki K, Xue QL, et al. A 32-year prospective study of change in body weight and incident dementia: the Honolulu-Asia Aging Study. Arch Neurol. 2005;62(1):55-60. [pmid: 15642850].
236 Tyas SL, Salazar JC, Snowdon DA, et al. Transitions to mild cognitive impairments, dementia, and death: findings from the Nun Study. Am J Epidemiol. 2007;165(11):1231-8. [pmid: 17431012].
237 Ensrud KE, Ewing SK, Taylor BC, et al. Frailty and risk of falls, fracture, and mortality in older women: the study of osteoporotic fractures. J Gerontol A Biol Sci Med Sci. 2007;62(7):744-51. [pmid: 17634322].
238 Fried LP, Xue QL, Cappola AR, et al. Nonlinear multisystem physiological dysregulation associated with frailty in older women: implications for etiology and treatment. J Gerontol A Biol Sci Med Sci. 2009;64(10):1049-57. [pmid: 19567825].
239 Cappola AR, Xue QL, Ferrucci L, et al. Insulin-like growth factor I and interleukin-6 contribute synergistically to disability and mortality in older women. J Clin Endocrinol Metab. 2003;88(5):2019-25. [pmid: 12727948].
240 Walston J, Xue Q, Semba RD, et al. Serum antioxidants, inflammation, and total mortality in older women. Am J Epidemiol. 2006;163(1):18-26. [pmid: 16306311].
241 Semba RD, Houston DK, Ferrucci L, et al. Low serum 25-hydroxyvitamin D concentrations are associated with greater all-cause mortality in older community-dwelling women. Nutr Res. 2009;29(8):525-30. [pmid: 19761886].
242 Fried LP, Bandeen-Roche K, Kasper JD, et al. Association of comorbidity with disability in older women: the Women’s Health and Aging Study. J Clin Epidemiol. 1999;52(1):27-37. [pmid: 9973071].
243 Xue QL, Fried LP, Glass TA, et al. Life-space constriction, development of frailty, and the competing risk of mortality: the Women’s Health and Aging Study I. Am J Epidemiol. 2008;167(2):240-8. [pmid: 17906296].
244 Schmaltz HN, Fried LP, Xue QL, et al. Chronic cytomegalovirus infection and inflammation are associated with prevalent frailty in community-dwelling older women. J Am Geriatr Soc. 2005;53(5):747-54. [pmid: 15877548].
245 Boyd CM, Xue QL, Simpson CF, et al. Frailty, hospitalization, and progression of disability in a cohort of disabled older women. Am J Med. 2005;118(11):1225-31. [pmid: 16271906].
246 Blaum CS, Xue QL, Tian J, et al. Is hyperglycemia associated with frailty status in older women?. J Am Geriatr Soc. 2009;57(5):840-7. [pmid: 19484839].
247 Takahashi PY, Dyrbye LN, Thomas KG, et al. The association of transient ischemic attack symptoms with memory impairment among elderly participants of the third US National Health and Nutrition Examination Survey. J Geriatr Psychiatry Neurol. 2009;22(1):46-51. [pmid: 19073836].
248 Johnson TM 2nd, Bernard SL, Kincade JE, et al. Urinary incontinence and risk of death among community-living elderly people: results from the National Survey on Self-Care and Aging. J Aging Health. 2000;12(1):25-46. [pmid: 10848124].
249 Mathieson KM, Kronenfeld JJ, Keith VM. Maintaining functional independence in elderly adults: the roles of health status and financial resources in predicting home modifications and use of mobility equipment. Gerontologist. 2002;42(1):24-31. [pmid: 11815696].
250 Disability and frailty among elderly Canadians: a comparison of six surveys. Int Psychogeriatr. 2001;13(Supp 1):159-67. [pmid: 11892963].
251 Buurman BM, van Munster BC, Korevaar JC, et al. Prognostication in acutely admitted older patients by nurses and physicians. J Gen Intern Med. 2008;23(11):1883-9. [pmid: 18769983].
252 Solfrizzi V, Scafato E, Capurso C, et al. Metabolic syndrome, mild cognitive impairment, and progression to dementia: the Italian Longitudinal Study on Aging. Neurobiol Aging. 2009. 12. 30. [Epub ahead of print].
253 Wieland D, Lamb VL, Sutton SR, et al. Hospitalization in the Program of All-Inclusive Care for the Elderly (PACE): rates, concomitants, and predictors. J Am Geriatr Soc. 2000;48(11):1373-80. [pmid: 11083311].
254 de Groot LC, Verheijden MW, de Henauw S, et al. Lifestyle, nutritional status, health, and mortality in elderly people across Europe: a review of the longitudinal results of the SENECA study. J Gerontol A Biol Sci Med Sci. 2004;59(12):1277-84. [pmid: 15699526].
255 Perkins AJ, Kroenke K, Unutzer J, et al. Common comorbidity scales were similar in their ability to predict health care costs and mortality. J Clin Epidemiol. 2004;57(10):1040-8. [pmid: 15528055].
256 Zarowitz BJ, Stebelsky LA, Muma BK, et al. Reduction of high-risk polypharmacy drug combinations in patients in a managed care setting. Pharmacotherapy. 2005;25(11):1636-45. [pmid: 16232025].
257 Levy R. Aging-associated cognitive decline. Int Psychogeriatr. 1994;6(1):63-8. [pmid: 8054494].
258 Kral VA. Senescent memory decline and senile amnestic syndrome. Am J Psychiatry. 1958;115(4):361-2. [pmid: 13583231].
259 Ebly EM, Hogan DB, Parhad IM. Cognitive impairment in the nondemented elderly: results from the Canadian Study of Health and Aging. Arch Neurol. 1995;52(6):612-9. [pmid: 7763211].
260 Reisberg B, Ferris SH, de Leon MJ, et al. The Global Deterioration Scale for assessment of primary degenerative dementia. Am J Psychiatry. 1982;139(9):1136-9. [pmid: 7114305].
261 Raji MA, Kuo YF, Snih SA, et al. Cognitive status, muscle strength, and subsequent disability in older Mexican Americans. J Am Geriatr Soc. 2005;53(9):1462-8. [pmid: 16137273].
262 Ritchie K, Kildea D, Robine JM. The relationship between age and the prevalence of senile dementia: a meta-analysis of recent data. Int J Epidemiol. 1992;21(4):763-9. [pmid: 1387871].
263 Wolfson C, Wolfson DB, Asgharian M, et al. A reevaluation of the duration of survival after the onset of dementia. N Engl J Med. 2001;344(15):1111-6. [pmid: 11297701].
264 Tennstedt S, Cafferata GL, Sullivan L. Depression among caregivers of impaired elders. J Aging Health. 1992;4(1):58-76. [pmid: 10116446].
265 Xue QL, Bandeen-Roche K, Varadhan R, et al. Initial manifestations of frailty criteria and the development of frailty phenotype in the Women’s Health and Aging Study II. J Gerontol A Biol Sci Med Sci. 2008;63(9):984-90. [pmid: 18840805].
266 Espino DV, Bazaldua OV, Palmer RF, et al. Suboptimal medication use and mortality in an older adult community-based cohort: results from the Hispanic EPESE Study. J Gerontol A Biol Sci Med Sci. 2006;61(2):170-5. [pmid: 16510861].
267 Rolland Y, Lauwers-Cances V, Cesari M, et al. Physical performance measures as predictors of mortality in a cohort of community-dwelling older French women. Eur J Epidemiol. 2006;21(2):113-22. [pmid: 16518679].
268 Baumgartner RN, Stauber PM, McHugh D, et al. Cross-sectional age differences in body composition in persons 60+ years of age. J Gerontol A Biol Sci Med Sci. 1995;50(6):M307-16. [pmid: 7583802].
269 Veehof L, Stewart R, Haaijer-Ruskamp F, et al. The development of polypharmacy: a longitudinal study. Fam Pract. 2000;17(3):261-7. [pmid: 10846147].
270 Pressley JC, Patrick CH. Frailty bias in comorbidity risk adjustments of community-dwelling elderly populations. J Clin Epidemiol. 1999;52(8):753-60. [pmid: 10465320].
271 National Center for Health Statistics. Health, United States, 2007, DHHS Publication No 2007–1232. Hyattsville, MD. National Center for Health Statistics, Centers for Disease Control and Prevention. 2007. Accessed at http://www.cdc.gov/nchs/data/hus/hus07.pdf. 2 June 2011.
272 Gurland BJ, Dean LL, Copeland J, et al. Criteria for the diagnosis of dementia in the community elderly. Gerontologist. 1982;22(2):180-6. [pmid: 7084739].
273 Hughes CP, Berg L, Danziger WL, et al. A new clinical scale for the staging of dementia. Br J Psychiatry. 1982;140:566-72. [pmid: 7104545].
274 Morris JC, Edland S, Clark C, et al. The Consortium to Establish a Registry for Alzheimer’s Disease (CERAD), part IV: rates of cognitive change in the longitudinal assessment of probable Alzheimer’s disease. Neurology. 1993;43(12):2457-65. [pmid: 8255439].
275 Lichtman JH, Krumholz HM, Wang Y, et al. Risk and predictors of stroke after myocardial infarction among the elderly: results from the Cooperative Cardiovascular Project. Circulation. 2002;105(9):1082-7. [pmid: 11877359].
276 Lupon J, Gonzalez B, Santaeugenia S, et al. Prognostic implication of frailty and depressive symptoms in an outpatient population with heart failure. Rev Esp Cardiol. 2008;61(8):835-42. [pmid: 18684366].
277 Puts MT, Lips P, Deeg DJ. Static and dynamic measures of frailty predicted decline in performance-based and self-reported physical functioning. J Clin Epidemiol. 2005;58(11):1188-98. [pmid: 16223663].
278 Woo J, Tang NL, Suen E, et al. Telomeres and frailty. Mech Ageing Dev. 2008;129(11):642-8. [pmid: 18809425].
279 Boyle PA, Buchman AS, Wilson RS, et al. Physical frailty is associated with incident mild cognitive impairment in community-based older persons. J Am Geriatr Soc. 2010;58(2):248-55. [pmid: 20070417].
280 Grant MD, Piotrowski ZH, Chappell R. Self-reported health and survival in the Longitudinal Study of Aging, 1984 1986. J Clin Epidemiol. 1995;48(3):375-87. [pmid: 7897459].
281 Artero S, Ancelin ML, Portet F, et al. Risk profiles for mild cognitive impairment and progression to dementia are gender specific. J Neurol Neurosurg Psychiatry. 2008;79(9):979-84. [pmid: 18450788].
282 Fitzpatrick AL, Kuller LH, Ives DG, et al. Incidence and prevalence of dementia in the Cardiovascular Health Study. J Am Geriatr Soc. 2004;52(2):195-204. [pmid: 14728627].
283 Tuokko HA, Frerichs RJ, Kristjansson B. Cognitive impairment, no dementia: concepts and issues. Int Psychogeriatr. 2001;13(Supp 1):183-202. [pmid: 11892966].
284 Lee Y, Back JH, Kim J, et al. Systematic review of health behavioral risks and cognitive health in older adults. Int Psychogeriatr. 2010;22(2):174-87. [pmid: 19883522].
285 Kivipelto M, Rovio S, Ngandu T, et al. Apolipoprotein E ɛ4 magnifies lifestyle risks for dementia: a population-based study. J Cell Mol Med. 2008;12(6B):2762-71. [pmid: 18318693].
286 Taaffe DR, Irie F, Masaki KH, et al. Physical activity, physical function, and incident dementia in elderly men: the Honolulu-Asia Aging Study. J Gerontol A Biol Sci Med Sci. 2008;63(5):529-35. [pmid: 18511759].
287 Larson EB, Wang L, Bowen JD, et al. Exercise is associated with reduced risk for incident dementia among persons 65 years of age and older. Ann Intern Med. 2006;144(2):73-81. [pmid: 16418406].
288 Simons LA, Simons J, McCallum J, et al. Lifestyle factors and risk of dementia: Dubbo Study of the elderly. Med J Aust. 2006;184(2):68-70. [pmid: 16411871].
289 Podewils LJ, Guallar E, Kuller LH, et al. Physical activity, APOE genotype, and dementia risk: findings from the Cardiovascular Health Cognition Study. Am J Epidemiol. 2005;161(7):639-51. [pmid: 15781953].
290 Singh-Manoux A, Hillsdon M, Brunner E, et al. Effects of physical activity on cognitive functioning in middle age: evidence from the Whitehall II prospective cohort study. Am J Public Health. 2005;95(12):2252-8. [pmid: 16304136].
291 Abbott RD, White LR, Ross GW, et al. Walking and dementia in physically capable elderly men. JAMA. 2004;292(12):1447-53. [pmid: 15383515].
292 Weuve J, Kang JH, Manson JE, et al. Physical activity, including walking, and cognitive function in older women. JAMA. 2004;292(12):1454-61. [pmid: 15383516].
293 Reitz C, den Heijer T, van Duijn C, et al. Relation between smoking and risk of dementia and Alzheimer disease: the Rotterdam Study. Neurology. 2007;69(10):998-1005. [pmid: 17785668].
294 Tyas SL, White LR, Petrovitch H, et al. Mid-life smoking and late-life dementia: the Honolulu-Asia Aging Study. Neurobiol Aging. 2003;24(4):589-96. [pmid: 12714116].
295 Ott A, Slooter AJ, Hofman A, et al. Smoking and risk of dementia and Alzheimer’s disease in a population-based cohort study: the Rotterdam Study. Lancet. 1998;351(9119):1840-3. [pmid: 9652667].
296 Ngandu T, Helkala EL, Soininen H, et al. Alcohol drinking and cognitive functions: findings from the Cardiovascular Risk Factors Aging and Dementia (CAIDE) Study. Dement Geriatr Cogn Disord. 2007;23(3):140-9. [pmid: 17170526].
297 Ganguli M, Vander Bilt J, Saxton JA, et al. Alcohol consumption and cognitive function in late life: a longitudinal community study. Neurology. 2005;65(8):1210-7. [pmid: 16247047].
298 Anttila T, Helkala EL, Viitanen M, et al. Alcohol drinking in middle age and subsequent risk of mild cognitive impairment and dementia in old age: a prospective population based study. BMJ. 2004;329(7465):539. [pmid: 15304383].
299 Luchsinger JA, Tang MX, Siddiqui M, et al. Alcohol intake and risk of dementia. J Am Geriatr Soc. 2004;52(4):540-6. [pmid: 15066068].
300 Elias PK, Elias MF, D’Agostino RB, et al. Alcohol consumption and cognitive performance in the Framingham Heart Study. Am J Epidemiol. 1999;150(6):580-9. [pmid: 10489997].
301 Whitmer RA, Gunderson EP, Quesenberry CP Jr, et al. Body mass index in midlife and risk of Alzheimer disease and vascular dementia. Curr Alzheimer Res. 2007;4(2):103-9. [pmid: 17430231].
302 Elias MF, Elias PK, Sullivan LM, et al. Obesity, diabetes and cognitive deficit: the Framingham Heart Study. Neurobiol Aging. 2005;26(Suppl 1):11-6. [pmid: 16223549].
303 Rosengren A, Skoog I, Gustafson D, et al. Body mass index, other cardiovascular risk factors, and hospitalization for dementia. Arch Intern Med. 2005;165(3):321-6. [pmid: 15710796].
304 Gustafson D, Rothenberg E, Blennow K, et al. An 18-year follow-up of overweight and risk of Alzheimer disease. Arch Intern Med. 2003;163(13):1524-8. [pmid: 12860573].
305 Eskelinen MH, Ngandu T, Helkala EL, et al. Fat intake at midlife and cognitive impairment later in life: a population-based CAIDE study. Int J Geriatr Psychiatry. 2008;23(7):741-7. [pmid: 18188871].
306 Tschanz JT, Welsh-Bohmer KA, Lyketsos CG, et al. Conversion to dementia from mild cognitive disorder: the Cache County Study. Neurology. 2006;67(2):229-34. [pmid: 16864813].
307 Schoenborn CA, Marano M. Current estimates from the National Health Interview Survey. Vital Health Stat 10. 1988;(166):1-233.
308 Malmgren JA, Koepsell TD, Martin DP, et al. Mortality, health services use, and health behavior in a cohort of well older adults. J Am Geriatr Soc. 1999;47(1):51-9. [pmid: 9920229].
309 Wolinsky FD, Johnson RL, Stump TE. The risk of mortality among older adults over an eight-year period. Gerontologist. 1995;35(2):150-61. [pmid: 7750771].
310 Porell FW, Miltiades HB. Disability outcomes of older Medicare HMO enrollees and fee-for-service Medicare beneficiaries. J Am Geriatr Soc. 2001;49(5):615-31. [pmid: 11380756].
311 Belgrave LL, Bradsher JE. Health as a factor in institutionalization. Res Aging. 1994;16(2):115-41.
312 Davies HT, Crombie IK, Tavakoli M. When can odds ratios mislead?. BMJ. 1998;316(7136):989-91. [pmid: 9550961].
313 Fisk JD, Merry HR, Rockwood K. Variations in case definition affect prevalence but not outcomes of mild cognitive impairment. Neurology. 2003;61(9):1179-84. [pmid: 14610117].
314 Juva K, Sulkava R, Erkinjuntti T, et al. The prognosis of demented patients: one-year follow-up study of a population sample. Int J Geriatr Psychiatry. 1994;9:537-41.
315 Aevarsson O, Svanborg A, Skoog I. Seven-year survival rate after age 85 years: relation to Alzheimer disease and vascular dementia. Arch Neurol. 1998;55(9):1226-32. [pmid: 9740117].
316 Aguero-Torres H, Fratiglioni L, Winblad B. Natural history of Alzheimer’s disease and other dementias: review of the literature in the light of the findings from the Kungsholmen Project. Int J Geriatr Psychiatry. 1998;13(11):755-66. [pmid: 9850872].
317 Baldereschi M, Di Carlo A, Maggi S, et al. Dementia is a major predictor of death among the Italian elderly. Neurology. 1999;52(4):709-13. [pmid: 10078714].
318 Bonaiuto S, Mele M, Galluzzo L, et al. Survival and dementia: a 7-year follow-up of an Italian elderly population. Arch Gerontol Geriatr. 1995;20(1):105-13. [pmid: 15374264].
319 Banaszak-Holl J, Fendrick AM, Foster NL, et al. Predicting nursing home admission: estimates from a 7-year follow-up of a nationally representative sample of older Americans. Alzheimer Dis Assoc Disord. 2004;18(2):83-9. [pmid: 15249852].
320 Chodosh J, Seeman TE, Keeler E, et al. Cognitive decline in high-functioning older persons is associated with an increased risk of hospitalization. J Am Geriatr Soc. 2004;52(9):1456-62. [pmid: 15341546].
321 Weiner M, Powe NR, Weller WE, et al. Alzheimer’s disease under managed care: implications from Medicare utilization and expenditure patterns. J Am Geriatr Soc. 1998;46(6):762-70. [pmid: 9625195].
322 Cawthon PM, Fox KM, Gandra SR, et al. Do muscle mass, muscle density, strength, and physical function similarly influence risk of hospitalization in older adults?. J Am Geriatr Soc. 2009;57(8):1411-9. [pmid: 19682143].
323 Maggio M, Ceda GP, Lauretani F, et al. Relationship between higher estradiol levels and 9-year mortality in older women: the Invecchiare in Chianti study. J Am Geriatr Soc. 2009;57(10):1810-5. [pmid: 19737330].
324 Yaffe K, Lindquist K, Penninx BW, et al. Inflammatory markers and cognition in well-functioning African-American and white elders. Neurology. 2003;61(1):76-80. [pmid: 12847160].
325 Schaap LA, Pluijm SM, Deeg DJ, et al. Inflammatory markers and loss of muscle mass (sarcopenia) and strength. Am J Med. 2006;119(6):526. [pmid: 16750969].
326 Strandberg TE, Tilvis RS. C-reactive protein, cardiovascular risk factors, and mortality in a prospective study in the elderly. Arterioscler Thromb Vasc Biol. 2000;20(4):1057-60. [pmid: 10764673].
327 Speare A Jr, Avery R, Lawton L. Disability, residential mobility, and changes in living arrangements. J Gerontol. 1991;46(3):S133-42. [pmid: 2030283].
328 Kersting RC. Predictors of nursing home admission for older black Americans. J Gerontol Soc Work. 2001;35(3):33-50.
329 Naeim A, Keeler EB, Reuben D. Perceived causes of disability added prognostic value beyond medical conditions and functional status. J Clin Epidemiol. 2007;60(1):79-85. [pmid: 17161758].
330 Grabowski DC, Ellis JE. High body mass index does not predict mortality in older people: analysis of the Longitudinal Study of Aging. J Am Geriatr Soc. 2001;49(7):968-79. [pmid: 11527490].
331 Rakowski W, Hickey T. Mortality and the attribution of health problems to aging among older adults. Am J Public Health. 1992;82(8):1139-41. [pmid: 1636837].
332 Markides KS, Black SA, Ostir GV, et al. Lower body function and mortality in Mexican American elderly people. J Gerontol A Biol Sci Med Sci. 2001;56(4):M243-7. [pmid: 11283198].
333 Murphy TE, Han L, Allore HG, et al. Treatment of death in the analysis of longitudinal studies of gerontological outcomes. J Gerontol A Biol Sci Med Sci. 2011;66(1):109-14. [pmid: 21030467].
334 Leipzig RM, Whitlock EP, Wolff TA, et al. Reconsidering the approach to prevention recommendations for older adults. Ann Intern Med. 2010;153(12):809-14. [pmid: 21173415].