# Results

We retrieved 2,377 publications and excluded 1,865 that were ineligible for review (Figure 7). We included 509 publications of 123 studies. Results from the same studies have been published in more than one article. The articles could provide slightly different information about included and excluded subjects. For key questions 2 through 4 we identified four meta-analyses79,93,97,233 and 119 original studies (Appendix E Table 1). The majority of the studies were conducted in the United States (76 studies, 62 percent). The studies included 5,420,254 subjects. The majority of the subjects resided in the United States (5,287,278 or 98 percent of the total subjects). The majority of the studies were prospective cohorts, nationally representative surveys, or Medicare analyses. Retrospective analyses of the administrative data were presented in two studies.101,127 Randomized controlled clinical trials (RCTs) provided information relevant to our research questions and were included in the review.42,153 The majority of eligible studies enrolled adults older than age 65 years. Several cohorts enrolled centenarians, including the Danish Centenarian Study,176 the Vitality 90+ Study,179 an d the 90+ Study.91 Two cohort studies, including the Baltimore Epidemiologic Catchment Area Program40 and the Framingham Offspring Study,234 did not enroll exclusively older individuals but reported the outcomes in age categories eligible for our review. Three studies enrolled men exclusively, including the Osteoporotic Fractures in Men Study,113 the Honolulu-Asia Aging Study of the Honolulu Heart Program,235 and the University of Connecticut Center on Aging Osteoporosis in Men Study.112 Some studies enrolled women exclusively, including the Nun Study,236 the Study of Osteoporotic Fractures,237 and the Women’s Health and Aging Studies.89,117,160,166,169,238–246

Figure 7 Study Flow

Figure 7 depicts study flow. Squared corner rectangles contain the number of retrieved, included, and excluded studies. The investigators retrieved from Medline, the Centers of Diseases Control and Prevention, found by manual search of the reference lists, and received from different experts a total 2,374 studies, included 509 and excluded 1,865 studies because they examined not eligible for the report target population, exposure, or outcomes.

Almost all studies enrolled some race and ethnic subgroups, but very few reported the outcomes among them. NHANES III,247 the National Health Interview Survey,121 and the Cardiovascular Health Study (CHS)87 reported oversampling of minority populations. The Frailty Study of African Americans in South Central Los Angeles enrolled only African Americans.106 The National Survey of Self-Care and Aging248,249 oversampled the oldest old. The Precipitating Events Project107 oversampled persons who were physically frail. The majority of the eligible studies enrolled community-residing older persons. Several studies included residents of long-term care facilities.44,58,61,93,97,106,154,176,179,219,250–253

Internal validity of the majority of the studies was good. The studies provided multivariate adjusted estimates of the association between syndromes and outcomes. Adjustment varied across the studies. The majority of the studies adjusted for age, sex, socioeconomic status, comorbidities, and behavioral factors. Some studies adjusted for correlated syndromes, thus underestimating the strength of the association. Adjustment for components of the definition of frailty may also underestimate the association between frailty and mortality. Adjustment for a disability that is an outcome of several syndromes may also underestimate the association between syndromes and mortality. Therefore, we judged crude but not overadjusted estimates as poor quality.

## Key Question 1 What is the Definition and Prevalence of Common Syndromes/Conditions in Older Adults?

### Multiple Morbidities

The studies used a variety of definitions for multiple morbidities, including number of chronic diseases or conditions, high comorbidity score, polypharmacy, and self-perceived poor health. Prevalence estimates varied depending on definitions (Table 8).

Table 8 Prevalence of Multiple Morbidities in Older Persons

Number of Chronic Conditions (high level of evidence) | Polypharmacy (low level of evidence) | Self-Perceived Health (high level of evidence)
Suffer from chronic diseases: 77.4%^254^ | 2–3 drugs: 40.7%^269^ | Fair/poor: Pooled 28.24% (95% CI, 20.98–38.00)14,103,109,250
3–4: 18.7–30.7%^250,270^ | 4–5 drugs: 0.09%^269^ | Poor: Pooled 2.93% (95% CI, 1.90–4.51)14,103,109,250
≥3: 27.80–36.60%^*^ | 5–9 drugs: 21.8%^152^
≥4: 10.8%^270^ | >5 drugs: 29.0%^256^ to 56.6%^205^ >11 drugs: 17.7%^205^
5–6: 8.2–18.3%^250^
>5: 23%^176^
≥7: 1.9–13.9%^250^
8–10: 20.1%^152^
≥11: 23.7%^152^

* From the National Health Interview Survey.

A majority of older people suffered from chronic diseases;254 28 to 37 percent had more than three chronic conditions (Figure 8). Prevalence did not decrease in association with a greater number of diagnoses. More than 20 percent of older persons suffered from five or more chronic diseases, and the same number suffered from 11 or more (Appendix E Table 2).152 Population-based studies relied on self-reported medical diagnoses to define older people with multiple morbidities. The simple number of the self-reported diseases, however, may not reflect severity of the conditions.

Figure 8 Prevalence of Three or More Chronic Conditions Among Older Persons By Percent of Poverty Level: United States, 2005 (Good-Quality National Survey*)

*National Health Interview Survey.271

Figure 8 is a forest plot diagram depicting prevalence of three or more chronic conditions among elderly persons by percent of poverty level. The data came from good quality national surveys, the National Center for Health Statistics, National Health Interview Survey, United States, 2005. The plot has two columns. The left-hand column lists poverty levels in relation to the national average among elderly persons between 65–74 years or older than 75 years of age. The right-hand column is a plot of prevalence as percentage with 95% CI of three or more chronic conditions for each poverty level. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. Figure 8 demonstrates that elderly below 100% of an average poverty level have higher prevalence of three or more diseases than elderly 400% above an average poverty level.

Studies of community-dwelling older adults in clinical settings defined multimorbid conditions using medical examinations and documentation. Such studies were able to address clinical importance of multiple morbidities. Some analyzed severity and seriousness of multiple morbidities by analyzing major diagnoses among all listed; others calculated the weighted Charlson comorbidity index (Appendix E Table 2). Prevalence estimates differ depending on the population studied. A prospective cohort study of community-dwelling older adults attending a large primary care clinic reported that 9.3 percent had two or more serious diagnoses among six to nine listed.255 A prospective study that aimed to develop the Burden of Illness Score for Elderly Persons reported that 61 to 71 percent of patients had a Charlson comorbidity index score of ≥2.^4^ The Swedish Prescribed Drug Register analysis reported that 25 percent of older adults had a Charlson comorbidity index score of 1–2, 3 percent had a score of 3–4, and 0.4 percent had a score of >5.^205^

Several studies defined multiple comorbidity as polypharmacy because it reflected prevalence of diseases that required treatments.205,206 The prevalence of polypharmacy (defined as concurrent use of five or more drugs) varied from 22 percent in the United States152 to 29 percent in Europe256 and 57 percent in Sweden205 (Appendix E Table 3). Polypharmacy was also defined as the number of doctor visits in which at least one drug was prescribed on the patient record. Annual drug visits increased from an average of three per older patient in 1995–1996 to five per older patient in 2004–2005 (Figure 9). The number of drugs per patient increased from nine to 12 in 1995–1996 to 19–22 in 2004–2005 (Figure 10). The annual number of drug visits increased by 25–29 percent during the analyzed 10 years from 1995–2005 (Figure 11). During the same time period, the number of drugs per patient increased by 85–89 percent (Figure 11). Almost 18 percent of older people have taken more than 11 drugs.205 Prevalence of inappropriate polypharmacy, defined according to the Physicians’ Desk Reference, was as high as 34.6 percent in a study of more than 60,000 older patients.205

Figure 9 Increase in Drug Visits in Which at Least One Prescription or Nonprescription Drug Was Recorded on the Patient Record Form, per 100 Older Persons (Good-Quality National Surveys*)

*National Ambulatory Medical Care Survey and National Hospital Ambulatory Medical Care Survey.271

Vertical axis=number of drug visits.

Figure 9 is a bar graph that shows an increase in drug visits in which at least one prescription or nonprescription drug was recorded on the patient record form, per 100 elderly persons. The data came from good quality national surveys the Centers for Disease Control and Prevention, National Center for Health Statistics, National Ambulatory Medical Care Survey and National Hospital Ambulatory Medical Care Survey. Vertical axis shows number of drug visits in which at least one prescription or nonprescription drug was recorded on the patient record form, per 100 elderly persons. Horizontal axis shows paired bars for both genders, men, and women older than 65, between 65 and 75 years of age, and older than 75 years old. Black bars demonstrate the number of drug visits in 1995–1996. Grey bars demonstrate the number of drug visits in 2004–2005. Annual drug visits increased from an average three per elderly patient in 1995–1996 to five per elderly patient in 2004–2005.

Figure 10 Increase in the Number of Drugs per 100 Older Persons (Good-Quality National Surveys*)

*National Ambulatory Medical Care Survey and National Hospital Ambulatory Medical Care Survey.271

Vertical axis=total number of drugs.

Figure 10 is a bar graph that shows an increase in the number of drugs per 100 elderly persons. The data came from the Centers for Disease Control and Prevention, National Center for Health Statistics, good quality National Ambulatory Medical Care Survey and National Hospital Ambulatory Medical Care Survey. Vertical axis shows a total number of drugs. Horizontal axis shows paired bars for genders, men, and women older than 65, between 65 and 75 years of age, and older than 75 years old. White bars demonstrate the number of drugs per 100 elderly persons in 1995–1996. Black bars demonstrate drug number in 2004–2005. The number of drugs increased from 9–12 per elderly patient in 1995–1996 to 19–22 per elderly patient in 2004–2005. Almost 18 percent of elderly people have taken more than 11 drugs.

Figure 11 Percentage Increase in Drug Visits and the Number of Drugs per 100 Older Persons From 1994–1996 to 2004–2005 (Good-Quality National Surveys*)

*National Ambulatory Medical Care Survey and National Hospital Ambulatory Medical Care Survey.271

Vertical axis=percent increase in drug visits and the number of drugs.

Figure 11 is a bar graph that shows percentage increase in drug visits and the number of the drugs per 100 elderly persons from 1994–1996 to 2004–2005. Vertical axis shows percentage increase in drug visits (grey bars) and the number of drugs (black bars). Horizontal axis shows paired bars for genders, men, and women older than 65, between 65 and 75 years of age, and older than 75 years old. The annual number of drug visits increased by 25–29 percent during the analyzed 10 years from 1995–2005. The number of drugs increased by 85–89 percent at the same time.

Poor self-perceived health reflected a person’s morbidity, physical functioning, and well-being.15,207,208 The prevalence of fair health in older people was 28.24 percent (Figure 12).14,103,109,250 Poor health was reported by 3 percent of older persons.14,103,109,250

Figure 12 Prevalence of Fair/Poor Health Status in Older Persons (High Level of Evidence)14,103,109,250

Figure 12 is a forest plot diagram depicting prevalence of fair/poor health status in elderly persons (high level of evidence from 4 studies). The plot has two columns. The left-hand column lists population based studies that examined prevalence of self perceived fair or poor health in elderly persons. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The diamond represents a pooled estimate from random effects model with 95% CI. The pooled prevalence of fair health in elderly people was 28.24 percent. The pooled prevalence of poor health was 3 percent. There was a statistically significant heterogeneity across four studies that reported prevalence of fair health and across three studies that reported prevalence of poor health.

In conclusion, more than 20 percent of older persons suffer from multiple chronic conditions. One-third to one-half take more than five drugs, with inappropriate polypharmacy in 35 percent of cases. One-third of older people report fair or poor health.

### Cognitive Impairment

Definitions of cognitive impairment varied in the studies categorizing pathophysiological classification of the condition, prevalence, or association estimates (Table 9).50 Some studies defined age-associated cognitive decline257 as part of the normal aging process.50,258 Several studies defined it as memory impairment and absence of dementia259 or absence of neurological, psychiatric, or systemic illnesses that could explain the presence of cognitive deficits.90 The definitions can also be categorized as self-reported memory complaints50 or memory impairment diagnosed with validated tools.37,38,90 Operational definitions varied depending on inclusion of impaired ADLs and social functions. Some studies defined cognitive decline as objective memory deficit resulting in decreased performance in employment or social situations.38,260 The most common definition of cognitive impairment required subjective complaint of memory impairment with objective memory impairment, normal general cognitive function, and intact cognitive ADLs and IADLs.37,38 Prevalence estimates varied substantially depending on the definitions.

Table 9 Components of Systems Classifying Cognitive Impairment in Older Persons50

System, Reference | Criteria
Age-associated cognitive decline257 | Impairments (below age- and education-matched norms) in memory, learning, attention, thinking, language, or visuospatial functioning. Onset of decline is described as gradual and has been present for at least 6 months, which is confirmed by an informant.
Age-associated memory impairment50 | Gradual decline in memory (below young healthy norms), with other cognitive functions unimpaired. Adequate intellectual functioning.
Age-consistent memory impairment50 | Decline in memory is observed as expected for age. Performance ±1 SD of the mean established for age on 75% or more of memory tests administered.
Age-related cognitive decline | Objective decline from premorbid level (within normal limits for the person’s age) in cognitive function on a comprehensive neuropsychological assessment, not otherwise specified.
Benign senescent forgetfulness258 | Inability to recall relatively unimportant data and parts of experiences belonging to remote rather than the recent past; use of compensatory strategies.
Cognitive impairment, no dementia259 | Cognitively impaired but no evidence of dementia, as diagnosed according to the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition; cognitive impairment can be in one or multiple domains and have a variety of aetiologies. This category is therefore more inclusive than age-associated memory impairment and age-related cognitive decline.
Limited cognitive disturbance272 | Referred to in the Comprehensive Assessment and Referral Evaluation and contrasts with pervasive cognitive disturbance and dementia.
Mild cognitive decline260 | Stage 3 of the Global Deterioration Scale, the earliest stage of clinical decline. Objective evidence of a memory deficit resulting in decreased performance in demanding employment and social situations.
Moderate cognitive decline260 | Stage 4 of the Global Deterioration Scale, a late confusional phase in which a clear cut deficit is apparent. Patients almost always make three or more errors on the Mental Status Questionnaire.
Mild cognitive disorder50 | Decline in cognitive performance, including memory impairment and learning or concentration difficulties. Cognitive tests must corroborate complaint. The disorder may precede, accompany, or follow a wide variety of infections.
Mild cognitive impairment (amnestic)37,38 | Subjective complaint of memory impairment with objective memory impairment adjusted for age. Normal general cognitive function. Intact activities of daily living/instrumental activities of daily living.
Mild cognitive impairment37 (multiple)38 | Deterioration in at least one nonmemory cognitive domain in addition to memory impairment without sufficiently severe functional impairment or loss of instrumental activities of daily living to constitute dementia. Normal general cognitive function.
Mild cognitive impairment (nonamnestic) 50 | Objective impairment in one or more nonmemory domains. Memory performance is not impaired. No functional impairment or loss of instrumental activities of daily living. Normal general cognitive function.
Probable mild cognitive impairment90 | Meeting the following criteria: 1) participants or their families reported cognitive problems and 2) there were no neurological, psychiatric, or systemic illnesses that could explain the presence of cognitive deficits.
Possible mild cognitive impairment90 | Meeting the following criteria: 1) neither participants nor their families reported cognitive problems; or 2) there were neurological, psychiatric, or systemic illnesses that might explain the presence of cognitive deficits; or 3) there was an incomplete evaluation.
Minimal dementia50 | Corresponds closely to “questionable dementia” (CDR score of 0.5).16 Deficits in memory and minor and variable errors in orientation. No evident impairment in occupational functioning.
Mild neurocognitive disorder50 | Impairment arising as a consequence of a general medical condition.
Self-reported memory complaint50 | Complaints of memory loss in the absence of formal testing. When formal testing indicates no impairment, an individual would be classified as “worried well.”
Questionable dementia273,274 | The worst end of the mild cognitive impairment spectrum; associated with a CDR score of 0.5, indicative of cognitive impairment 2 SDs below the mean in one cognitive domain. Objective evidence of cognitive impairment not satisfying criteria for dementia.

The Medical Research Council Cognitive Function and Aging Study used 17 different definitions of cognitive impairment in the same sample of 2,053 older people (Appendix E Table 4).50 Prevalence estimates varied from 42 percent having self-reported memory complaints to less than 1 percent having mild or moderate cognitive impairment or questionable dementia.50 Interestingly, the authors found little overlap (concordance from 0 to 24 percent) in different definitions of cognitive impairment. First, this means that each definition identified a unique group of older people. Therefore, prevalence estimation of cognitive impairment in the population requires using several definitions to distinguish different types of impairment. Second, overall prevalence of cognitive impairment without dementia may exceed half of older individuals residing in the community.50

Prevalence of cognitive impairment in other studies was lower, probably because the studies used fewer definitions (Appendix E Table 5). From the individual studies, the Canadian Study of Health and Aging reported the highest prevalence of positivity on the Modified Mini-Mental State Examination (3MSE) for cognitive functioning (41.0^250^ to 46.3 percent95 had a 3MSE score of <78). The CHS Cognition Study demonstrated a much lower prevalence of amnestic cognitive impairment (Figure 13).90 Prevalence of probable mild cognitive impairment-amnestic type was less than 3 percent.90 Prevalence of probable mild cognitive impairment-multiple cognitive deficit type was slightly higher but still less than 6 percent.90 NHANES III found prevalence of amnestic cognitive impairment (6.6 percent) similar to that found in CHS.247

Figure 13 Prevalence of Amnestic or Multiple-Deficit Mild Cognitive Impairment in Age Categories (Low Level of Evidence)90,247

CHS=Cardiovascular Health Study (CHS) Cognition Study.

Figure 13 is a forest plot diagram depicting prevalence of amnestic or multiple deficit mild cognitive impairment in age categories (low level of evidence from 2 studies). The plot has two columns. The left-hand column lists population based studies that examined prevalence of amnestic cognitive impairment, probable milder cognitive impairment amnesic type, possible multiple cognitive deficit type amnesic type, probable milder cognitive impairment multiple cognitive deficit type, and possible milder cognitive impairment multiple cognitive deficit type in different age categories of elderly persons. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. From the individual studies, the Canadian Study of Health and Aging reported the highest prevalence of positivity on the Modified Mini-Mental State Examination (3MSE) for cognitive functioning (41.0 percent to 46.3 percent had a 3MSE score of <78). The Cardiovascular Health Study (CHS) Cognition Study demonstrated a much lower prevalence of amnestic cognitive impairment. Prevalence of probable mild cognitive impairment-amnestic type was less than 3 percent. Prevalence of probable mild cognitive impairment-multiple cognitive deficit-type was slightly higher but still less than 6 percent. The Third U.S. National Health and Nutrition Examination Survey found prevalence of amnestic cognitive impairment (6.6 percent) that was similar to the CHS.

Prevalence varied depending on the diagnostic methods used to identify cognitive impairment. Prevalence of cognitive impairment (defined as a score of <24 on the Mini-Mental State Examination [MMSE]) varied from 10.6 to 33.1 percent (Figure 14).14,39–45 Prevalence of severe cognitive impairment (defined as an MMSE score of <15) was lower and varied between 1.3 and 9.3 percent (Figure 15).39,44,261 The second Longitudinal Study of Aging obtained self-reported responses to the Telephone Interview of Cognitive Status (TICS) instrument.49 This study found cognitive impairment in 2.8 to 13.2 percent of older individuals (Figure 16).49 Studies of the Established Populations for Epidemiologic Studies of the Elderly used the 10-item Short Portable Mental Status Questionnaire and demonstrated that, on average, 7.1 percent of those tested met criteria of cognitive impairment (Figure 17).46–48

Figure 14 Prevalence of Cognitive Impairment in Older Persons Defined as an MMSE Score of <24 (Moderate Level of Evidence)14,39–45

Figure 14 is a forest plot diagram depicting prevalence of cognitive impairment in elderly persons defined as Mini-Mental State Examination <24 (moderate level of evidence from 8 studies). The plot has two columns. The left-hand column lists population based studies that examined prevalence of cognitive impairment in different age subgroups. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The diamond represents a pooled estimate from random effects model with 95% CI. Prevalence of cognitive impairment (defined as <24 scores in the Mini-Mental State Examination) varied from 10.6 to 33.10%. The prevalence of cognitive impairment, pooled from five studies, was 16.9% (95% CI 10.4, 27.3) in older than 65 years of age. The pooled from three studies prevalence of cognitive impairment was 12.2% (95% CI 4.0, 36.8) in people older than 70 years of age. The prevalence of cognitive impairment, pooled from three studies, was 22.9% (95% CI 8.0, 65.7) in those older than 90 years of age. There was a statistically significant heterogeneity for all pooled estimates.

Figure 15 Prevalence of Severe Cognitive Impairment in Older Persons Defined as an MMSE Score of <15 (Low Level of Evidence)39,44,261

Figure 15 is a forest plot diagram depicting prevalence of severe cognitive impairment defined as Mini-Mental State Examination <15 in elderly persons (low level of evidence from three studies). The plot has two columns. The left-hand column lists population based studies that examined prevalence of severe cognitive impairment. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. Prevalence of severe cognitive impairment varied between 1.30 percent and 9.30 percent.

Figure 16 Prevalence of Cognitive Impairment in Age Categories of Self-Respondents (High Level of Evidence)49

Figure 16 is a forest plot diagram depicting prevalence of cognitive impairment in age categories of self-respondents (high level of evidence from systematic review and meta-analyses). The plot has two columns. The left-hand column lists population based studies that examined prevalence of cognitive impairment in different age categories. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The diamond represents a pooled estimate from random effects model with 95% CI. Pooled from four studies prevalence of cognitive impairment was 3.38% (95% CI 1.29; 8.87) in people 70-74 years old. Pooled from two studies prevalence of cognitive impairment was 4.02% (95% CI 3.43; 4.70) in people 75-79 years old. Pooled from four studies prevalence of cognitive impairment was 8.42% (95% CI 5.02; 14.12) in those 75-84 years old. Pooled from five studies prevalence of cognitive impairment was the highest in very old (19.56%, 95% CI 10.93; 35.01). There was a statistically significant heterogeneity for all pooled estimates.

Figure 17 Prevalence of Cognitive Impairment Using the 10-Item Short Portable Mental Status Questionnaire (High Level of Evidence)46–48

Figure 17 is a forest plot diagram depicting prevalence of cognitive impairment defined using 10-item Short Portable Mental Status Questionnaire (SPMSQ) (high level of evidence from three studies). The plot has two columns. The left-hand column lists population based studies that examined prevalence of cognitive impairment. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The diamond represents a pooled estimate from random effects model with 95% CI. Pooled prevalence of cognitive impairment defined using 10-item Short Portable Mental Status Questionnaire was 7.13% (95% CI 3.94; 12.91). There was a statistically significant heterogeneity.

Prevalence of dementia was less variable across the studies because of standardized consensus definitions (Figure 18).262 Prevalence of senile dementia diagnosed using Diagnostic and Statistical Manual of Mental Disorders, Third Edition criteria varied from 3.6 percent in France to 6.7 percent in Finland.262 Prevalence of senile dementia diagnosed using the Geriatric Mental Status Examination in England was 4.6 to 5.2 percent.262 Prevalence of probable Alzheimer’s disease in older people was 14 percent (Figure 19).92,93 Prevalence of definitive Alzheimer’s disease was much less at 3.1 percent.92,93 The Canadian Study of Health and Aging reported the highest prevalence, with 31.6 percent scoring positive for dementia on the 3MSE (Appendix E Table 6).95 The same study identified 5.1 percent of older patients with Alzheimer’s disease and 8 percent with all types of dementia combined.95 Prevalence of severe dementia was 2.6 percent95 or 42 percent of all dementia cases.263

Figure 18 Prevalence of Senile Dementia in Older Persons According to Definition (High Level of Evidence)262

Figure 18 is a forest plot diagram depicting prevalence of senile dementia in elderly persons depending on definitions (high level of evidence from a systematic review). The plot has two columns. The left-hand column lists countries and methods for diagnosis of senile dementia. The right-hand column is a plot of prevalence (%) with 95% CI for each methods of diagnosis. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. Prevalence of dementia was less variable across the studies because of standardized consensus definitions. Prevalence of senile dementia diagnosed with Diagnostic and Statistical Manual (DSM-III) criteria varied from 3.6 percent in France to 6.7 percent in Finland. Prevalence of senile dementia diagnosed with Geriatric Mental Status Examination (GMS) in England was 4.6 to 5.2 percent.

Figure 19 Prevalence of Dementia in Age Groups: Results From the East Boston Study and Meta-Analysis of 13 Epidemiological Studies of Senile Dementia (High Level of Evidence)92,262

Figure 19 is a forest plot diagram depicting prevalence of dementia in age groups (high level of evidence from the East Boston Study and meta-analysis of 13 epidemiological studies ). The plot has two columns. The left-hand column lists definitions of dementia and age categories. The right-hand column is a plot of prevalence (%) with 95% CI for each definition and age category. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The diamond represents a pooled estimate from random effects model with 95% CI. Pooled prevalence of probable Alzheimer's disease in elderly people was 13.97% (95% CI 5.86, 33.31). Pooled prevalence of definitive Alzheimer's disease was much less at 3.06 percent. (95% CI 1.57, 5.99). Pooled prevalence of senile dementia was 6.28% (95% CI 3.33, 11.85). Prevalence evidently increased with age. There was a statistically significant heterogeneity for all pooled estimates.

In conclusion, prevalence of cognitive impairment is estimated at around 30 percent in older people across different studies and definitions. Prevalence of amnestic cognitive impairment was around 7 percent. Prevalence of dementia did not exceed 8 percent in elderly persons older than age 65 years, but this estimate can be misleading because of substantial variation in prevalence across age subgroups.

### Frailty

Definitions of frailty vary widely, and the nature of the definition affects the prevalence of reported frailty. Table 10 arrays a number of studies on frailty in order of the reported prevalence and shows the components used to determine frailty. There is no clear relationship between the number or type of components and the prevalence of frailty. Accumulation deficit indices included up to 75 components. Phenotype indices typically included five criteria. Self-reported mobility limitations were included in the phenotype definition. Disability in ADLs was included in the accumulation deficit definition. Separation of the two types of definitions and estimation of disability in frail persons was somewhat artificial.

Table 10 Definitions and Prevalence of Frailty

Study | Prevalence (%) | Mobility impairment | Weakness | Weight loss/poor nutritional status | Low Physical Activity | Fatigue | Bowel and Bladder Incontinence | Cognitive impairment | Visual impairment | ADL/IADL impairment | Lung Function | Chronic/Terminal Illness
Cardiovascular Health Study Fried, 2001^23^ | 6.9 | ✓ | ✓ | ✓ | ✓ | ✓
Canadian Study of Health and Aging Gutman, 2001^103^ | 21.2 | ✓ | | | | | ✓ | ✓ | | ✓
Women’s Health and Aging Studies Bandeen-Roche, 2006^160^ | 11.3 | ✓ | ✓ | ✓ | ✓ | ✓
PAVAMC Frailty Study Winograd, 1991^25^ (hospital based) | 27 | ✓ | | ✓ | | | ✓ | ✓ | | ✓ | | ✓
Cooperative Cardiovascular Project Lichtman, 2009^275^ (hospital based) | 27.5 | ✓ | | | | | ✓ | ✓
Heart Failure Cohort Lupon, 2008^276^ (among diseases) | 39.9 | | | | | | | ✓ | | | ✓
Beaver Dam Eye Study Cohort Klein et al, 2005^111^ | 44.7 | ✓ | ✓ | | | | | | ✓ | ✓
Precipitating Events Project Hardy, 2005^107^ | 42.7 | ✓
Chinese Longitudinal Healthy Longevity Survey Gu, 2009^159^ | NR | | | | | | | ✓ | ✓ | | ✓ | ✓
Study of Osteoporotic Fractures Ensrud, 2008^24^ | 17 | ✓ | | ✓ | | ✓
Osteoporotic Fractures in Men Cawthon, 2007^113^ | 4 | ✓ | ✓ | ✓ | ✓ | ✓
Longitudinal Aging Study Amsterdam Puts, 2005^277^ | 5.8 | | | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓
Three-City Study Avila-Funes, 2008^28^ | 7 | ✓ | ✓ | ✓ | ✓ | ✓
MacArthur Study Sarkisian, 2008^220^ | 6.7 | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓
Depression Among Caregivers of Impaired Elders Study Tennstedt, 1992^264^ | 18.9 | ✓ | | | ✓ | | | ✓ | | | ✓
Hispanic Established Populations for Epidemiologic Studies of the Elderly Ottenbacher, 2009^108^ | 7.6 | ✓ | ✓ | ✓ | ✓ | ✓
Chinese University of Hong Kong Aging Study Woo, 2008^278^ | NR | ✓ | | | | | | ✓ | | | ✓
Rush Memory and Aging Project Boyle, 2010^279^ | NR | ✓ | ✓ | ✓ | | ✓
Health and Retirement Study Cigolle, 2009^104^ | 21.3 | | ✓ | ✓ | | | | ✓ | ✓
National Population Health Survey of Canada Song, 2010^115^ | 22.7 | ✓ | | ✓ | ✓ | ✓ | ✓ | | ✓ | | ✓
Health, Aging and Body Composition Study Peterson, 2009^105^ | 2.7 | ✓

NR=prevalence estimate not reported; study defined frailty and examined association between frailty and outcome.

Table 11 summarizes these arrays slightly differently, by showing the effect of including a specific component on the prevalence of frailty. Lung function, chronic or terminal illness, visual or cognitive impairment, and incontinence are all strong influences.

Table 11 Number of Studies and Prevalence Estimates By Each Criterion of the Definition of Frailty

Prevalence Category | Mobility Impairment | Weakness | Weight Loss/Poor Nutritional Status | Low Physical Activity | Fatigue | Bowel and Bladder Incontinence | Cognitive Impairment | Visual Impairment | ADL/IADL Impairment | Lung Function | Chronic/Terminal Illness
0–5% | 2 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0
10–20% | 3 | 1 | 2 | 2 | 2 | 0 | 1 | 0 | 0 | 1 | 0
20–30% | 4 | 1 | 3 | 1 | 1 | 4 | 4 | 2 | 2 | 1 | 1
5–10% | 4 | 4 | 5 | 5 | 4 | 1 | 2 | 1 | 1 | 0 | 0
>30% | 2 | 1 | 0 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 0
Total | 15 | 8 | 11 | 9 | 8 | 5 | 8 | 4 | 4 | 3 | 1
Average prevalence of frailty in studies when component is included in the definition of frailty
Mean | 17.9 | 13.7 | 12.5 | 10.1 | 10.4 | 20.8 | 21.0 | 23.6 | 24.7 | 27.2 | 27.0
Standard deviation | 13.3 | 13.6 | 8.1 | 6.4 | 6.3 | 8.8 | 11.2 | 16.0 | 16.1 | 11.2

Another way of synthesizing this complex array is to contrast the measures that use various phenotypic measures, such as low physical activity or fatigue, as compared to specific deficits. Figure 20 shows the odds of having a frailty prevalence higher than 20 percent for these two types of indicators. The studies that used accumulation deficit components reported higher prevalence estimates more often. Figure 21 graphs the prevalence of frailty from various studies according to the type of measure used; again, the prevalence is higher when using accumulation of deficits.23,101,103,104,107,109,111,115,229,264

Figure 20 Odds of Higher Frailty Prevalence Estimates (>20%) in Studies That Included Components in the Definition of Frailty Compared to Those That Did Not

Figure 20 is a forest plot diagram depicting odds of higher frailty prevalence estimates (>20%) in studies that included exact components in the definition of frailty compared to those that did not (studies that used accumulation deficit components reported higher prevalence estimates more often). The plot has two columns. The left-hand column lists diagnostic criteria of phenotype definition or accumulation deficit definition of frailty. The right-hand column is a plot of odds ratios with 95% CI of having prevalence higher than 20% when each diagnostic criteria was included in the definition of frailty. Mean estimate is presented by a square incorporating confidence intervals represented by horizontal lines. Phenotype definition included low physical activity, fatigue, weight loss/poor nutritional status, weakness, mobility impairment. Accumulation of the deficits included lung function, cognitive impairment, chronic/terminal illness, visual impairment, impairment in activities of daily living and instrumental activities of daily living, and bowel and bladder incontinence. The studies that used accumulation deficit components reported higher prevalence estimates more often.

Figure 21 Prevalence of Frailty in Older Persons (High Level of Evidence)23,101,103,104,107,109,111,115,229,264

Figure 21 is a forest plot diagram depicting prevalence of frailty in elderly persons (high level of evidence from 10 studies). The plot has two columns. The left-hand column lists population based studies that examined prevalence of frailty using phenotype definition or accumulation deficit definition. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The diamond represents a pooled estimate from random effects model with 95% CI. Pooled from 8 studies prevalence of frailty defined as accumulation deficit was 23.5 % (95% CI 17.95; 30.94). Pooled from 3 studies prevalence of frailty defined as phenotype was 14.35% (95% CI 3.80, 54.18). The prevalence is higher when using accumulation of deficits. Overall, pooled prevalence of frailty was 20.56% (95% CI 15.50; 27.28). There was a statistically significant heterogeneity for all pooled estimates.

The initial manifestations of frailty criteria in association to the development of frailty was examined in the Women’s Health and Aging Study II.265 Weakness was the most common first manifestation that could predict development of frailty during 7.5 years of followup.265 Other studies did not analyze temporality in different frailty criteria.

Variability in prevalence estimates was substantial within the same study and across different studies. The Health and Retirement Study examined prevalence of frailty using different definitions, including phenotype and accumulation deficit, and found that 30 percent of older people were frail according to at least one definition, but only 3 percent according to all three definitions (Figure 22).104 Such a small overlap indicates that each definition distinguished unique groups, and population-based studies should use all definitions to detect frailty.

Figure 22 Differences in Prevalence of Frailty in the Same Population According to Definition: Results From the Health and Retirement Study (Good-Quality Study)104

Figure 22 is a forest plot diagram depicting differences in prevalence of frailty in the same population depending on definition (results from the Health and Retirement Study). The plot has two columns. The left-hand column has different definitions of frailty. The right-hand column is a plot of prevalence (%) with 95% CI for each definition. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The Health and Retirement Study examined prevalence of frailty using different definitions, including phenotype and accumulation deficit, and found that 30 percent of elderly people were frail according to at least one definition, but only 3 percent according to all three definitions.

Appendix E Table 7 summarizes the prevalence rates from various studies, showing the measure used. The same study may generate a different prevalence depending on the measure used or severity of the condition (Appendix E Table 8).

In conclusion, prevalence of frailty varied depending on definitions. Prevalence of frailty, defined as accumulation deficit, was 24 percent. Prevalence of frailty, defined as phenotype, was 14 percent. The overlap in definitions was small. Thus, according to at least one definition, around 30 percent of older people were frail.

### Disability

#### Definition and prevalence of BADL disability in older people

Any BADL disability. The prevalence of any BADL disability was reported in 12 studies (Table 12).41,53,55–64 The percentage of older people with any BADL disability ranged from 5.0 to 25.6 percent (Appendix E Table 9). The prevalence was lowest (5.0 to 9.1 percent) in national surveys that included people of all ages, but reported those aged 65 years and older separately (i.e., the National Health Interview Survey,58 the American Community Survey,60 the Survey on Income and Program Participation,58 and the Census Public Use Microdata Files62), higher (11.0 to 18.3 percent) in studies exclusively targeting older adults (i.e., Established Populations for Epidemiologic Studies of the Elderly,41,57,64 Longitudinal Studies of Aging56,63), and highest (13.9 to 25.6 percent) in studies targeting the oldest of the old (i.e., Survey of Assets and Health Dynamics of the Oldest Old,55 CHS All Stars59) (Figure 23).

Table 12 Prevalence of Basic ADL Disability (Evidence From Good-Quality Studies)

Disability Definition | Range of Older Persons With Disability (%)
Any BADL disability | 5.0–18.3^41,53,55–64^ 25.6 (CHS All Stars)59
Moderate BADL disability | 16.1–20.5^5,118^
Severe BADL disability | 6.0–7.8 (3–4 BADLs)5,118 4.8 (5–7 BADLs)5
Bathing disability | 3.9–9.0^53,55,65,122,248^
Dressing/hygiene disability | 0.8–11.0^53,55,65,120,248^ 9.2 (Alumni Health Study)120
Eating disability | 0.4–4.5^53,55,58,65,119,120,248^ 7.3 (Alumni Health Study)120
Toileting disability | 2.4–6.0^53,55,58^
Transferring disability | 0.4–9.0^53,55,58,65^ 21.1 (Alumni Health Study)120
Walking disability | 0.8–13.0^53,55,65,120^ 20.6 (Alumni Health Study)120

Figure 23 Prevalence of Any ADL Disability (Good-Quality Studies)41,53,55–64

Figure 23 is a forest plot showing the prevalence of any ADL disability from good quality studies. Any ADL disability was defined as having one or more ADL limitation. The left column groups the study names by the number of ADL items included in the disability survey. The right column reports the prevalence and 95% confidence interval for each study. The prevelance of any ADL disability for surveys with five items ranged from 5 to 25.6%. The prevalence for surveys with four items was 5.8%. The prevalance for surveys with three items ranged from 5.4 to 9.1%. The prevalence for seven item surveys ranged from 11 to 12%. The prevalence for six item surveys ranged from 13.9 to 18%. Two studies did not report the number of items in their survey and their prevalence ranged from 11.9 to 12.2%. In general the forest plots shows that the prevalence of any ADL disability increases as the number of items in the survey increases.

Moderate BADL disability. The prevalence of moderate BADL disability (defined as having one to two BADL disabilities) was reported in two studies, and ranged from 16.1 to 20.5 percent (Figure 24).5,118

Figure 24 Prevalence of Moderate or Severe ADL Disability (Good-Quality Studies)5,118

Figure 24 is a forest plot reporting the prevalence of moderate or severe ADL disability in good quality studies. Moderate ADL disability was defined as having one to two ADL limitations, and severe disability was defined as having three or more ADL limitations. The left column groups the study names by the type of disability (either moderate or severe) and by gender. The right column reports the prevalence and 95% confidence interval for each study. The prevalence of moderate ADL disability for men and women was reported in two studies and ranged from 16.1 to 20.5%. The prevalence of severe ADL disability for men and women was reported in two studies and ranged from 4.8 to 6%. One study (the English Longitudinal Study of Aging) reported the prevalence of moderate and severe disability by gender. For women the prevalence of moderate BADL disability was 21.7% and for severe disability it was 7%. For men, the prevalence of moderate BADL disability was 28%, and for severe disability it was 17%. In general the prevalence for moderate disability was higher than the prevalence for severe disability.

Severe BADL disability. The lowest rates were reported for severe BADL disability, which ranged from 6.0 to 7.8 percent5,118 when it was measured as having three to four BADL disabilities and 4.8 percent5 when it was measured as having five to seven BADL disabilities (Figure 24).

Bathing disability. The percentage of older people with bathing disabilities ranged from 3.9 to 9.0 percent (Figure 25).53,55,65,122,248 In the Massachusetts Health Care Panel Study, the percentage of older adults who had a bathing disability increased from 3.9 to 14.7 percent over 5 years.65

Figure 25 Prevalence of Bathing ADL Disability (High Level of Evidence)53,55,58,65,122,248

Figure 25 is a forest plot reporting the prevalence of bathing disabilities reported in studies with a high level of evidence. The left column lists the studies and the right column reports the prevalence and 95% confidence interval for bathing disability for both genders. The prevalence of bathing disabilities for both genders ranged from 3.9 to 14.7% The Sources of independence in the Elderly study reported a higher prevalence for women (7.7%) than men (4.4%).

Dressing/hygiene disability. The percentage of older people with dressing or hygiene disabilities ranged from 0.8 to 11.0 percent (Figure 26).53,55,65,120,248 In the Massachusetts Health Care Panel Study, the percentage of older adults who had a dressing disability increased from 0.8 to 9.3 percent over 5 years.65

Figure 26 Prevalence of Dressing/Hygiene ADL Disability (High Level of Evidence)53,55,58,65,248

Figure 26 is a forest plot reporting the prevalence of dressing and hygiene disability in studies with a high level of evidence. The left column lists the study names and the right column lists the prevalence and 95% confidence intervals. The prevalence of dressing and hygiene disabilities ranged from 0.8% to 11% for both genders. The Alumni Health Study reported the prevalence of hygiene and dressing disabilities by gender. Women had a higher prevalence of hygiene (12.8%) and dressing (17.1%) disabilities than men, whose prevalence was 8.1% for hygiene disability and 13.2% for dressing disabilities.

Eating disability. The percentage of older people with eating disabilities ranged from 0.4 to 4.5 percent (Figure 27).53,55,58,65,119,120,248 In the Massachusetts Health Care Panel Study, the percentage of older adults who had an eating disability increased from 0.4 to 2.2 percent over 5 years.65

Figure 27 Prevalence of Eating ADL Disability (High Level of Evidence)53,55,58,65,119,248

Figure 27 is a forest plot reporting the prevalence of eating disabilities in studies with a high level of evidence. The left column lists the studies and the right column lists the prevalence and 95% confidence intervals. The prevalence of eating disabilities reported in nine studies ranged from 0.4% to 7.3% for both genders. Two studies reported the prevalence of eating disabilities by gender. The prevalence of eating disabilities ranged from 1.2% to 11.8% for women and ranged from 6% to 1.5% for men.

Toileting disability. The percentage of older people with toileting disabilities ranged from 2.4 to 6.0 percent (Figure 28).53,55,58

Figure 28 Prevalence of Individual ADL Disability (High Level of Evidence)53,55,58,65,120

Figure 28 is a forest plot reporting the prevalence of toileting, transferring, and walking disabilities reported is studies with a high level of evidence. The left column lists the studies by type of disability (toileting, transferring, and walking) and the right column lists the prevalence and 95% confidence interval. The prevalence of toileting disabilities was reported in four samples and range from 2.4% to 6%. Transferring disabilities were reported in eight samples and the prevalence ranged from 0.4% to 21%. Walking disabilities were reported in seven samples and the prevalence ranged from 0.8% to 27.3%. The Alumni Health Study reported that 27.6% of women had a transferring disability compared to 19.2% of men. In general, the chart shows that walking disabilities are more prevalent than transferring and toileting disabilities. Toileting disabilities were the least prevalent.

Transferring disability. The percentage of older people with transferring disabilities ranged from 0.4 to 21.1 percent (Figure 28).53,55,58,65,120 In the Massachusetts Health Care Panel Study, the percentage of older adults who had a transferring disability increased from 0.4 to 5.8 percent over 5 years.65

Walking disability. Between 0.8 and 27.3 percent of older people reported walking disabilities (Figure 28).53,55,65,120 In the Massachusetts Health Care Panel Study, the percentage of older adults who had a walking disability increased from 0.8 to 7.7 percent over 5 years.65

Summary. The prevalence of any BADL disability was quite variable and depended on the target population of the study. It was lower in national surveys and highest in studies targeting the oldest old. Moderate BADL disability was the most common, and severe BADL disability was the least common. In terms of individual BADL disabilities, the hierarchy of most to least common disability was walking, bathing, dressing, transferring, toileting, and eating (Table 12). Over a period of 5 years, more older people developed individual BADL disabilities (Table 13).

Table 13 Increase in Individual Basic ADL Disability Over 5 Years65

Individual BADL Disability | Year
Individual BADL Disability | 1980 | 1985
Bathing disability | 3.9 | 14.7
Dressing/hygiene disability | 0.8 | 11.0
Eating disability | 0.4 | 2.2
Transferring disability | 0.4 | 5.8
Walking disability | 0.8 | 7.7

#### Definition and prevalence of IADL disability in older people

Any IADL disability. The percentage of older people reporting any IADL disability ranged from 12.0 to 46.7 percent (Figure 29 and Table 14).53–57,266

Figure 29 Prevalence of Instrumental ADL Disability (High Level of Evidence)5,53–57,248,266,267

Figure 29 is a forest plot reporting the prevalence of disabilities in Instrumental Activities of Daily Living (IADLs) in studies with a high level of evidence. The left column groups the studies by the definitions of IADL disability. Any IADL disability was defined as reporting one or more limitations with IADLs. Moderate IADL disability was defined as having one to two limitations with IADLs. Severe IADL disability was defined as having limitations with three or more IADLs. Each survey included a different number of items to assess IADL disability. The number of items for each survey is listed next to the study name. Surveys included three to eight IADL items. The prevalence of any IADL disability ranged from 12% to 46.7% in the seven studies reported. The prevalence of moderate IADL disability ranged from 7.2 to 31% in the four studies reported. The prevalence of severe IADL disability ranged from 4.5 to 21.2% in the five studies reported. In general, the forest plots show a higher prevalence when any IADL disability is reported and the lowest prevalance for severe IADL disability.

Table 14 Prevalence of Instrumental ADL Disability (Moderate to High Level of Evidence)

Disability Definition | Range of Older Persons With Disability (%)
Any IADL disability | 12.0–46.7^53–57^
Moderate IADL disability | 7.2–31.0^5,248,267^
Severe IADL disability | 4.5–21.2^5,54,267^
Finance disability | 8.0–19.3^53,55,65^
Housekeeping disability | 7.5–35.8^65,122^
Meal preparation disability | 7.1–32.4^53,65,119^
Medication management disability | 3.0–4.7^53,55^
Shopping disability | 11.0–32.9^53,65,119^
Telephone disability | 4.0–6.0^53,55^
Transportation disability | 54.3^65^

Moderate IADL disability. The percentage of older people reporting a moderate IADL disability ranged from 7.2 to 31.0 percent (Figure 29).5,248,267

Severe IADL disability. The percentage of older people reporting a severe IADL disability ranged from 4.5 to 21.2 percent (Figure 29).5,54,267 The prevalence was lowest when severe IADL disability was defined as having difficulty with four or more IADLs (4.5 to 5.7 percent)5,54 and higher when it was defined as having difficulty with three or more IADLs (6.2 to 21.2 percent) (Appendix E Table 10).5,267

Financial disability. The percentage of older people reporting a financial disability ranged from 8.0 to 19.3 percent (Figure 30).53,55,65 The percentage of older people with difficulty managing finances increased from 19.3 to 36.7 percent over a 5-year period in the Massachusetts Health Care Panel Study.65

Figure 30 Prevalence of Individual Instrumental ADL Disability (High Level of Evidence)53,55,65,119,122

Figure 30 is a foest plot reporting the prevalence of individual IADL disabilities from studies with a high level of evidence. The left column lists the study grouped by the type of IADL disability (i.e., trouble with managing finances, housekeeping, meal preparation, medications, and shopping. The right column lists the prevalence and 95% confidence intervals. The prevalence for disabilities with managing finances ranged from 8% to 36.7% in the six samples reported. The prevalence housekeeping disabilities ranged from 35.8% to 48% in the two samples reported. The prevalence for meal preparation disabilities ranged from 10% to 34.1% in the five samples reported. The prevalence for medication management disabilities ranged from 3% to 4.7% in the three samples reported. The prevalence for shopping disabilities ranged from 11% to 32.9% in the five samples reported. In general, the forest plots show similar prevalances for finance, meal preparation, and shopping disabilities. The highest prevalence was for housekeeping disabilities and the lowest prevalence was for medication management disabilities.

Housekeeping disability. The percentage of older people reporting a housekeeping disability ranged from 7.5 to 35.8 percent (Figure 30).65,122 The percentage of older people with difficulty doing housework increased from 35.8 to 48.0 percent over a 5-year period in the Massachusetts Health Care Panel Study.65

Meal preparation disability. The percentage of older people reporting difficulty with meal preparation ranged from 7.1 to 32.4 percent (Figure 30).53,65,119 The percentage of older people with difficulty preparing meals increased from 32.4 to 34.1 percent over a 5-year period in the Massachusetts Health Care Panel Study.65

Medication management disability. The percentage of older people reporting difficulty with medication management ranged from 3.0 to 4.7 percent (Figure 30).53,55

Shopping disability. The percentage of older people reporting difficulty with shopping ranged from 11.0 to 32.9 percent (Figure 30).53,65,119 The percentage of older people with difficulty shopping increased from 32.9 to 41.3 percent over a 5-year period in the Massachusetts Health Care Panel Study.65

Telephone disability. The percentage of older people reporting difficulty using the telephone ranged from 4 to 6 percent (Figure 31).53,55

Figure 31 Prevalence of Telephone and Transportation Instrumental ADL Disability (Low to Moderate Level of Evidence)53,55,65

Figure 31 is a forest plot reporting the prevalence of telephone and transportation IADL disabilities from studies with a high level of evidence. The left column lists the study grouped by the type of IADL disability (i.e., trouble using the telephone or trouble using transportation). The right column lists the prevalence and 95% confidence interval. The prevalence for telephone IADL disabilities ranged from 4% to 6% in the three studies reported. The prevalence for transportation disabilities ranged from 54.3 to 67.6%. The forest plots clearly show that trouble using transportation was the most prevalent disability with over half of older adults reporting this IADL disability.

Transportation disability. The percentage of older people requiring assistance with transportation increased from 54.3 to 67.6 percent over a 5-year period in the Massachusetts Health Care Panel Study (Figure 31).65

Summary. Prevalence was highest when any IADL disability was reported, lower when moderate IADL disability was reported, and lowest for severe IADL disability. The order of individual IADL disabilities from most to least common was needing assistance with or having difficulty with driving, housekeeping, personal finances, shopping, meal preparation, using the telephone, and medication management. Over a 5-year period the percentage of older people with IADL disabilities increased (Table 15).

Table 15 Increase in Individual Instrumental ADL Disability Over 5 Years (Good-Quality Study)65

Individual IADL Disability | Year
Individual IADL Disability | 1980 | 1985
Finance disability | 19.3 | 36.7
Housekeeping disability | 35.8 | 48.0
Meal preparation disability | 32.4 | 34.1
Shopping disability | 32.9 | 41.3
Transportation disability | 54.3 | 67.6

### Sarcopenia

Sarcopenia was defined as a loss of skeletal muscle mass owing to any disease or condition.66 Operational definitions were based on lean body mass relative to skeletal size and total body mass.66 Relative indices were calculated using dual energy x-ray absorptiometry. Sarcopenia was defined as index values of less than 2 standard deviations below the sex-specific mean in a healthy, younger population.67,68 Using this definition, sarcopenia was identified when relative skeletal muscle index or appendicular skeletal muscle mass index (kg/m^2^) was less than 7.3 kg/m^2^ for men and 5.5 kg/m^2^ for women.67,68 The recently published recommendations from the European Working Group on Sarcopenia in Older People defined sarcopenia as the presence of both low muscle mass and low muscle function (strength or performance).69

The Rosseta study,67 Aging Process Study,268 and the New Mexico Elder Health Survey68 defined sarcopenia using a relative skeletal muscle index. This definition, however, does not take into account individuals with increased fat mass who will not be diagnosed with sarcopenia despite inadequate low muscle mass. The investigators of the Health Aging and Body Composition (Health ABC) Study proposed adjusting relative skeletal muscle indices for body fat mass and height to determine the expected total lean mass.123 Total lean mass was measured relative to height squared and relative to height and total fat mass.123 Sarcopenia was defined as lean mass/height^2^ in the lowest 20 percent of the sex-specific distribution of the index using cutoff points of 7.2 kg/m^2^ (men) and 5.7 kg/m^2^ (women).123 A second definition of sarcopenia was based on linear regression modeling the relationship between lean mass and height (meters) and fat mass (kilograms). Individuals below the 20th percentile of the distribution of residuals were diagnosed with sarcopenia.123

Prevalence estimates varied depending on definitions. The studies provided sex-specific estimates only. The New Mexico Elder Health Survey68 reported sarcopenia in 13.5 percent of non-Hispanic white men younger than age 70 years and in 53 percent of Caucasian men older than age 80 years.68 Prevalence of sarcopenia was slightly higher in Hispanic men, ranging from 17 percent in men younger than age 70 years to 58 percent in those older than age 80 years.68 Prevalence of sarcopenia was greater in older women and varied from 23.1 percent in non-Hispanic white women to 24 percent in Hispanic women younger than age 70 years.68 Hispanic women older than age 80 years had the highest prevalence of sarcopenia (60 percent).68 The Health ABC Study found sarcopenia in 50.4 percent of men with a body mass index (BMI) of <25 kg/m^2^ using a lean mass index and in 32.8 percent of men using definitions adjusted for fat mass (Figure 32).123 The same study found sarcopenia in 51.9 percent of women with a BMI of <25 kg/m^2^ using a lean mass index and in 23 percent of women using definitions adjusted for fat mass. Prevalence of sarcopenia using the residual method was identified in 11.5 percent of obese older men and in 21 percent of obese older women.123 Using the unadjusted lean mass index, no obese individuals with relatively low lean mass were found to have sarcopenia.123

Figure 32 Prevalence of Sarcopenia in Participants of the Health, Aging, and Body Composition Study (Good-Quality Study)123

Sarcopenia was defined using relative lean mass index (<7.23 kg/m^2^ for men and <5.67 kg/m^2^ for women) and negative residuals that were derived by adjusting for fat mass in addition to height.

Figure 32 is a forest plot diagram depicting prevalence of sarcopenia in elderly men and women, participants of the Health Aging and Body Composition (Health ABC) study. The plot has two columns. The left-hand column has different definitions of sarcopenia including relative lean mass index or residual definition of sarcopenia in gender and body mass index category. The right-hand column is a plot of prevalence (%) with 95% CI for each definition and each gender and body mass index category. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The Health ABC Study found sarcopenia in 50.4 percent of men with BMI <25kg/m2 using a lean mass index and in 32.8 percent of men using definitions adjusted for fat mass. This figure also shows that sarcopenia was detected in 51.9 percent of women with BMI <25kg/m2 using a lean mass index and in 23 percent using definitions adjusted for fat mass. Prevalence of sarcopenia using the residual method was identified in 11.5 percent of obese elderly men and in 21 percent of obese elderly women. Using the unadjusted lean mass index, no obese elderly individuals with relatively low lean mass were found to be sarcopenic. This figure thus demonstrates that simple relative skeletal muscle index can underestimate sarcopenia in obese elderly patients. Residual methods adjusting for fat mass may be a better method to identify sarcopenia in overweight and obese elderly people.

In conclusion, prevalence of sarcopenia in older individuals varied from 14 to 60 percent, depending on age, sex, and ethnicity. Simple relative skeletal muscle index can underestimate sarcopenia in obese patients. Residual methods adjusting for fat mass may more effectively identify sarcopenia in overweight and obese patients.

### Malnutrition

The studies defined malnutrition as abnormal categories of individual biomarkers or composite measures of poor nutritional status. Among individual anthropometric markers, unintended weight loss70–72 and low BMI46,72–76 defined individuals with malnutrition. Among biochemical markers, low blood albumin levels,73,75,77 anemia,77,78 and deficit of micronutrients79–81 identified people with poor nutritional status. Several studies used composite nutritional scores based on self-reported dietary intake and habits to identify people with malnutrition.70,72,82–85 Prevalence estimates varied across the definitions.

Anthropometric definitions of malnutrition. Unexpected weight loss of more than 5 percent of baseline body weight was reported by 21 percent of individuals in the Danish part of a large survey of European older adults (Appendix E Table 11).70 Low BMI was defined as <18.5 kg/m^2^,46,73,76,121 <19 kg/m^2^,75 or <22 kg/m^2^.72 The highest prevalence of malnutrition according to low BMI (15 percent) was found among older American veterans.75 A European study found that 5.8 percent of older individuals had low BMI.73 The prevalence of low BMI in older people from the general American population was as low as 2.3 percent.46 The Geisinger Rural Aging Study did not find any rural older Americans with a BMI of <18.5 kg/m^2^ (0 percent prevalence) (Appendix E Table 11).76

Biochemical definitions of malnutrition. Low albumin levels were found in 3.1 percent of American veterans (Appendix E Table 11).75 Prevalence was remarkably higher in studies that recruited older people in clinical settings. The Italian Group of Pharmacoepidemiology in the Elderly study found that 38.1 percent of individuals had albumin levels <35 g/L.73 American studies developing the High-Risk Diagnoses for the Elderly Scale found that 24 to 49 percent of older patients in clinical settings had albumin levels <3.5 mg/dL.4

A micronutrient deficit was more common in older Europeans (18.2 percent) than in older Americans (6.4 percent) (Appendix E Table 12).79 On average, 5.3 percent of older people had a folate deficit (Figure 33).80,81 Older Europeans also had a higher prevalence of vitamin B12 deficiency (11.7 percent) compared to Americans (5.4 percent).79 On average, 7.5 percent had a vitamin B12 deficiency (Figure 33). Prevalence of iron deficiency was similar in older Europeans (6.1 percent) and Americans (5.6 percent) (Appendix E Table 12).79 On average, 4.7 percent of older adults had an iron deficiency (Figure 33). Prevalence of vitamin D insufficiency was the same (36.7 percent) in older Europeans80 and Americans.81 On average, 9.9 percent of older adults had a vitamin D deficiency (Figure 33).

Figure 33 Prevalence of Micronutrient Deficiency in Older Persons (High Level of Evidence)80,81

Figure 33 is a forest plot diagram depicting prevalence of micronutrient deficiency in elderly persons (high level of evidence from two systematic reviews and meta-analyses). The plot has two columns. The left-hand column has different definitions of malnutrition including folate deficiency, Iron deficiency , Vitamin B12 deficiency, or Vitamin D deficiency that were examined in population based studies. The right-hand column is a plot of prevalence (%) with 95% CI for each definition and each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The diamond represents a pooled estimate from random effects model with 95% CI. Pooled from three studies prevalence of folate deficiency was 5.31% (95% CI 2.04; 13.83) with significant heterogeneity across the studies. Pooled from three studies prevalence of iron deficiency was 4.74% (95% CI 3.35; 6.71) with significant heterogeneity across the studies. Pooled from three studies prevalence of Vitamin B12 deficiency was 7.47% (95% CI 4.41; 12.67) with significant heterogeneity across the studies. Pooled from two studies prevalence of Vitamin D deficiency was 9.92% (95% CI 8.49, 11.58). Heterogeneity was not significant. the figure demonstrates that European elderly people had a higher prevalence of Vitamin B12 deficiency (11.7 percent) compared to American elderly people (5.4 percent). Prevalence of iron deficiency was similar in European (6.1 percent) and American (5.6 percent) elderly people . Prevalence of Vitamin D insufficiency was the same (36.7 percent) in European and American elderly people.

Composite nutritional score. Prevalence of malnutrition in older adults varied from 1 percent82 in eight European countries to 5 percent in Australia (Appendix E Table 13).83 According to the Nutrition Screening Initiative, 21 percent of older adults in the United States had a high nutritional risk.84 Half of the American older adults with poor perceived health were at high risk of malnutrition.84 Overall, 33 percent of older individuals had a high nutritional risk (Figure 34).70,72,82–85

Figure 34 Prevalence of Malnutrition Using the Composite Nutritional Score (High Level of Evidence)70,72,82–85

Figure 34 is a forest plot diagram depicting prevalence of malnutrition defined as composite nutritional score (high level of evidence from 6 studies). The plot has two columns. The left-hand column has different studies that examined prevalence of malnutrition defined as composite nutritional score in gender and race categories. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The diamond represents a pooled estimate from random effects model with 95% CI. Pooled from three studies prevalence was 32.27% (95% CI 22.65; 45.98) with significant heterogeneity across the studies. Pooled from two studies prevalence in men was 18.27% (95% CI 10.77; 30.98) with significant heterogeneity across the studies. Pooled from two studies prevalence in women was 24.02% (95% CI 12.18; 47.38) with significant heterogeneity across the studies. The figure demonstrates that according to the Nutrition Screening Initiative, 21 percent of elderly people in the United States had a high nutritional risk. Half of the American elderly people with poor perceived health were at high risk of malnutrition. Overall, 33 percent of elderly individuals had a high nutritional risk.

In conclusion, the prevalence of malnutrition depended on definitions. The chance of having low BMI was less than 3 percent, around 6 to 10 percent for having a vitamin and micronutrient deficit, and 1 to 5 percent for having a low composite nutritional score. The prevalence of low BMI and blood albumin level was highest in older American veterans.75

### Homeostenosis (Impaired Homeostasis)

Very few studies examined the prevalence of impaired homeostasis (Appendix E Table 14). NHANES I and II defined impaired homeostasis in older persons using an allostatic load score.86 The total score was based on elevated CRP level of >0.5 mg/dL, low albumin level of <4.5 g/dL, creatinine clearance of <78.5 mL/min/1.73 m^2^, and increased blood pressure, hemoglobin A_1C_, homocysteine, total cholesterol, and triglycerides. The surveys found that 1.4 percent of the elderly population in the United States had an allostatic load score of >4.^86^ The Duke Established Populations for Epidemiologic Studies of the Elderly analyzed plasma tonicity as a marker of impaired homeostasis that can predict frailty and disability.46 Plasma tonicity was estimated from plasma glucose, sodium, and potassium measures and was used to classify subjects as normotonic (285–294 mOsm/L) or hypertonic (>300 mOsm/L). This study found that 10 percent of individuals had increased plasma tonicity.

In conclusion, existing evidence was insufficient to estimate the prevalence of homeostenosis.

### Chronic Inflammation

Few studies provided prevalence of unspecified chronic inflammation (Appendix E Figure 1).87,88,146 CHS found that 24.4 percent of older adults had elevated CRP.87 The Health ABC Study reported that 5 percent of older adults had elevated IL6 and 5 percent had elevated tumor necrosis factor-alpha.88 The Swedish NONA Immune Study demonstrated that 15.3 percent of all older adults and 18.4 percent of frail older persons had an inverted CD4/CD8 ratio.146

In conclusion, existing evidence was insufficient to estimate a prevalence of chronic inflammation.

## Key Question 2 What is the Prevalence of Common Syndromes/Conditions in Older Adults in Sex, Age, Race, Ethnicity, and Other Subgroups?

### Multiple Morbidities

Prevalence of three or more chronic diseases increased from 28 percent in adults ages 65–74 years to 37 percent in adults older than age 75 years (Figure 8). Older persons living below the poverty level had a higher prevalence of multiple morbidities. The prevalence of polypharmacy also increased from 50 percent in adults ages 75–79 years to 63 percent in those older than age 85 years (Table 16).205

Table 16 Prevalence of Multiple Morbidities in Older Subgroups

Subgroup | Number of Chronic Conditions (low to moderate level of evidence) | Polypharmacy (insufficient level of evidence) | Self-Perceived Health (high level of evidence)
65–74 years | ≥3 diseases: 27.80%^307^
>75 years >100 years | ≥3 diseases: 36.60%^307^ >5 diseases: 23%^176^ | 75–79 years: 50.3% 80–84 years: 57.2% 85–89 years: 63.1%^205^
Men | 2 diseases: 16%^125^ 4–6 diseases: 5%^125^ | ≥5 drugs: 35.6%^94^ >11 drugs: 15.5%^205^ | Fair Pooled: 27.61% (95% CI,16.77–45.47)94,280 Fair/poor 14.20% (95% CI,13.30–15.10)74 Poor Pooled: 6.94% (95% CI, 3.00–16.10)94,103,280
Women | 2 diseases: 16%^125^ 3 diseases: 23.0%^242^ ≥3 diseases: 16–18.4%^89,117^ 4 diseases: 16.0%^242^ >4 diseases: 8.6%^117^ 5 diseases: 9.0%^242^ >5 diseases: 1.6%^117^ 6 diseases: 4.5%^242^ 7 diseases: 2.0%^242^ 8 diseases: 0.5%^242^ | ≥5 drugs: 43.0%^94^ >11 drugs: 19.1%^205^ | Fair Pooled: 31.64% (95% CI, 14.31–69.93) Poor Pooled: 6.71% (95% CI, 3.04–14.81)94,103,280
African Americans | ≥3 diseases in women: 13.4%^89^
Caucasians | ≥3 diseases in women: 9.5%^89^

Prevalence of comorbidities in older men varied from 16 percent having two chronic diseases to 5 percent having four to six chronic diseases (Appendix E Table 2).125 More than one-third of older men took more than five drugs,94 while 16 percent took more than 11 drugs (Appendix E Table 3).205 On average, an older man took 9.6 to 12 drugs in 1995–1996 but 18 to 21 drugs in 2004–2005 (Figure 10). The increase in annual drug visits (35 percent) and drugs taken (102 percent) in men ages 65–74 years during the decade from 1996 to 2005 was largest when compared to other sex and age categories (Figure 11). Poor health was reported by 7 percent of older men (Figure 35).94,103,280

Figure 35 Prevalence of Fair/Poor Health Status in Older Men (Moderate Level of Evidence)74,94,103,280

Figure 35 is a forest plot diagram depicting prevalence of fair/poor health status in elderly men (moderate level of evidence from four studies). The plot has two columns. The left-hand column has different studies that examined prevalence of fair, fair/poor, or poor self perceived health. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The diamond represents a pooled estimate from random effects model with 95% CI. Pooled from two studies prevalence of fair health was 27.61% (95% CI 16.77, 45.47). Pooled from three studies prevalence of poor health was 6.94% (95%CI 3.00, 16.10). Heterogeneity across the studies was significant for both pooled estimates.

The prevalence of more than three comorbidities in older women varied from 16.0 to 18.4 percent (Table 16).89,117 The prevalence of five, six, or more diseases was lower among older women who participated in the Women’s Health and Aging Studies.117,242 Thus, the majority of older women reported three or four comorbidities.

The prevalence of polypharmacy was greater in older women than in men; 43 percent had taken more than five drugs94 and 19 percent took more than 11 drugs.205 From 1996–2005, women older than age 75 years experienced a 32 percent increase in annual drug visits and a 94 percent increase in the number of prescribed drugs (Figure 11). Poor health was reported by 7 percent of older women (Figure 36).94,103,280

Figure 36 Prevalence of Fair/Poor Health Status in Older Women (Moderate Level of Evidence)94,103,280

Figure 36 is a forest plot diagram depicting prevalence of fair/poor health status in elderly women (moderate level of evidence from three studies). The plot has two columns. The left-hand column has different studies that examined prevalence of fair or poor self perceived health. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The diamond represents a pooled estimate from random effects model with 95% CI. Pooled from two studies prevalence of fair health was 31.64% (95% CI 14.31, 69.93). Pooled from three studies prevalence of poor health was 6.71% (95% CI 3.04, 14.81). Heterogeneity across the studies was significant for both pooled estimates.

Prevalence of more than three chronic diseases was higher in African American women (13.4 percent) than in Caucasian women (9.5 percent).89 A comparison of the estimates was difficult because there were inconsistent definitions of the outcomes and older subgroups across the studies.

In conclusion, prevalence of multimorbid conditions increased with age. Women tended to have a higher prevalence of comorbidities, polypharmacy, and poor health. African American women had a higher prevalence of comorbidities than Caucasian women.

### Cognitive Impairment

Age. Prevalence of cognitive impairment increased with age across all definitions and studies. Prevalence of mild cognitive impairment identified using the 3MSE increased from 18.8 percent in individuals older than age 75 years to 44.1 percent among those older than age 90 years (Figure 37).90,91,146,281 Prevalence of cognitive impairment in elderly persons defined as an MMSE score of <24 increased from 16.9 percent among those older than age 65 years to 22.9 percent in centenarians older than age 90 years (Figure 14).14,39–45 The prevalence of cognitive impairment identified through the TICS instrument increased from 3.38 percent in persons ages 70–74 years to 19.6 percent among those older than age 85 years (Figure 16).49

Figure 37 Prevalence of Mild Cognitive Impairment in Different Race and Age Categories Using the 3MSE Questionnaire for Cognitive Functioning (High Level of Evidence)90,91,146,281

Figure 37 is a forest plot diagram depicting prevalence of mild cognitive impairment in different race and age categories defined using the Modified Mini-Mental State Examination (3MSE) for cognitive functioning (high level of evidence from four studies). The plot has two columns. The left-hand column has different studies that examined prevalence of mild cognitive impairment in race and age categories. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. Prevalence of mild cognitive impairment identified with the 3MSE increased from 18.8 percent in elderly individuals over 75 years to 44.1 percent among those over than 90 years of age. Limited evidence from the CHS Cognition Study indicated that elderly individuals of African American descent had a higher prevalence of mild cognitive impairment (45.5%) compared to Caucasians (14%).

Prevalence of dementia increased with age in all studies. Prevalence of senile dementia increased from 1.6 percent in individuals age 67.5 years to 36.7 percent in those older than age 95 years (Figure 19).92,93 The prevalence of Alzheimer’s disease increased from 0.4 percent in individuals age 67.5 years to 37.4 percent in those older than age 95 years.92,93 Prevalence of severe dementia increased dramatically from 3.2 percent in individuals ages 75–84 years to 14.6 percent in those older than age 85 years.95 A meta-analysis of nine studies concluded that the highest prevalence of dementia was among individuals ages 80–85 years, with a minimal increase after age 90 years.93

Race. Limited evidence from the CHS Cognition Study indicates that older individuals of African American descent had a higher prevalence of mild cognitive impairment (45.5 percent) compared to Caucasians (14 percent) (Figure 37).90

Sex. Prevalence of cognitive impairment in men varied from 16 percent in the Canadian Study of Health and Aging250 and PAQUID (Personnes Agées QUID) Research Program94 to 36 percent in the CHS All Stars Study (Appendix E Table 15).59 No age-associated increase was evident. For instance, the Survey in Europe on Nutrition and the Elderly reported that 14 percent of men ages 80–85 years had cognitive impairment.96 The prevalence was 10.3^42^ to 14.9 percent59 in men older than age 89 years.

Prevalence of dementia in older men was consistent across different countries, with an evident increase with age (Figure 38).97 The EURODEM-Prevalence Research Group reported that 3.25 percent of older men had vascular or mixed dementia.97 Prevalence increased from 1.04 percent in men ages 65–69 years to 5.8 percent in those older than age 85 years.97 CHS identified dementia in 9 percent of men younger than age 75 years and in 43 percent of those older than age 85 years (Figure 39).282 The Canadian Study of Health and Aging demonstrated an evident increase in severe dementia in aging men, from 0.4 percent in those ages 65–74 years to 8.8 percent in those older than age 85 years.95

Figure 38 Prevalence of Vascular and Mixed Dementia in Older Men: Results From the EURODEM Prevalence Research Group (High Level of Evidence)97

Figure 38 is a forest plot diagram depicting prevalence of vascular and mixed dementia in elderly men (high level of evidence from the EURODEM-Prevalence Research Group). The plot has two columns. The left-hand column has age categories and countries. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The diamond represents a pooled estimate from random effects model with 95% CI. Prevalence of dementia in elderly men was consistent across different countries with an evident increase with aging. An average prevalence of vascular and mixed dementia in men 65-69 years old was 1.04% (95% CI 0.29, 3.68). An average prevalence of vascular and mixed dementia in men 70-79 years old was 3.22% (95% CI 2.09, 4.98). An average prevalence of vascular and mixed dementia in men older than 80 years of age was 5.83% (95% CI 2.30, 14.76). Pooled across age group prevalence was 3.25% (95% CI 1.93, 5.46) with significant heterogeneity across age subgroups.

Figure 39 Prevalence of Dementia in Older Men in Age and Severity Categories (Moderate Level of Evidence)95,282

Figure 39 is a forest plot diagram depicting prevalence of dementia in elderly men in age and severity categories (moderate level of evidence from two studies). The plot has two columns. The left-hand column has definitions of any, mild, moderate, and severe dementia. The right-hand column is a plot of prevalence (%) with 95% CI for each diagnostic and age category. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The diamond represents a pooled estimate from random effects model with 95% CI. The Cardiovascular Health Study identified dementia in 31.63% (95% CI 30.81, 32.47) of men. Prevalence increased from 9 percent in men below 75 years of age to 43 percent in those older than 85 years. The Canadian Study of Health and Aging demonstrated an evident increase in severe dementia in aging men from 0.4 percent in those 65-74 years of age to 8.8% in those older than 85 years of age. Mild dementia was diagnosed in 3.54% (95% CI 2.74, 4.58) of men, moderate dementia in 4.87% (95% CI 3.93, 6.04), and severe dementia in 2.73% (95% CI 2.04, 3.65) of men.

The prevalence of cognitive impairment in women varied depending on definitions and age. Cognitive impairment detected with the 3MSE questionnaire varied from 10.4 to 11.5 percent in older women (Figure 40).59,95 Functional cognitive impairment was identified with the 3MSE questionnaire in 35 to 59 percent of older women.59 Cognitive and physical impairment were identified with the same instrument in 6.3 to 24.3 percent of older women.59 The prevalence of cognitive impairment defined as an MMSE score of <24 was 24 percent in women older than age 65 years (Figure 41).42,90,94,96

Figure 40 Prevalence of Cognitive Impairment in Older Women in Age Categories Using Definitions Derived From the 3MSE Questionnaire (Moderate Level of Evidence)59,95

CHS=Cardiovascular Health Study All Stars; CSA=Canadian Study of Aging.

Figure 40 is a forest plot diagram depicting prevalence of cognitive impairment in elderly women in age categories depending on definitions derived using the Modified Mini-Mental State Examination 3MSE questionnaire (moderate level of evidence from two studies). The plot has two columns. The left-hand column has definitions of cognitive impairment, functional cognitive impairment, cognitive impairment, no dementia, or cognitive and physical impairment in different age categories. The right-hand column is a plot of prevalence (%) with 95% CI for each definition and age category. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The prevalence of cognitive impairment in elderly women varied depending on definitions and age. Cognitive impairment detected with the 3MSE questionnaire varied from 10.4 percent to 11.5 percent in elderly women. Functional cognitive impairment was identified with the 3MSE questionnaire in 35 to 59 percent of elderly women. Cognitive and physical impairment were identified with the same instrument in 6.30 to 24.3 percent of elderly women.

Figure 41 Prevalence of Cognitive Impairment in Older Women Defined as an MMSE Score <24 (High Level of Evidence)42,90,94,96

Figure 41 is a forest plot diagram depicting prevalence of cognitive impairment in elderly women defined as <24 in the Mini-Mental State Examination 20-item questionnaire (high level of evidence from four studies). The plot has two columns. The left-hand column has studies that examined cognitive impairment in different age categories. The right-hand column is a plot of prevalence (%) with 95% CI for each definition and age category. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The diamond represents a pooled estimate from random effects model with 95% CI. Pooled from three studies prevalence of cognitive impairment in elderly women older than 65 years of age was 23.98% (95% CI 22.89, 25.13) with significant heterogeneity across the studies. Averaged prevalence in women 80-85 years old was 31.83% (95% CI 30.53, 33.20). The prevalence was lower (14.2 %) in those older than 90 years. Since prevalence of dementia increases with age, a decrease in prevalence of cognitive impairment may reflect a competing risk issue.

Prevalence did not increase substantially with age. Pooled prevalence of cognitive impairment in women ages 80 to 85 years was 31.8 percent but was reduced to 14.2 percent in those older than age 90 years.42,90,94,96 Since prevalence of dementia increases with age, a decrease in prevalence of cognitive impairment may reflect a competing risk issue.

The prevalence of cognitive impairment was lower in the Longitudinal Study of Aging that used the TICS instrument (Figure 42).49 The Longitudinal Study of Aging found an increase in prevalence with age, from 8.6 percent in women ages 70–74 years to 33 percent in those older than age 85 years.49

Figure 42 Prevalence of Cognitive Impairment in Older Women in the Cardiovascular Health Study Using the 3MSE Questionnaire and in the Second Longitudinal Study of Aging Using the Telephone Interview of Cognitive Status Instrument (Good-Quality Study)49

Figure 42 is a forest plot diagram depicting prevalence of cognitive impairment in elderly women defined using the Modified Mini-Mental State Examination (3MSE) in the Cardiovascular Health Study and using the Telephone Interview of Cognitive Status (TICS) instrument in the Second Longitudinal Study of Aging (LSOA II). The plot has two columns. The left-hand column has studies that examined cognitive impairment in different age categories. The right-hand column is a plot of prevalence (%) with 95% CI for each definition and age category. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The prevalence of cognitive impairment was lower in the Longitudinal Study of Aging that used the TICS instrument. The Longitudinal Study of Aging found an increase in prevalence with aging from 8.6 percent in women 70-74 years of age to 33 percent in those older than 85 years.

The prevalence of dementia in older women was consistent across different countries, with evident increases with age (Figure 43).97 The EURODEM-Prevalence Research Group found vascular or mixed dementia in 2.3 percent of older women.97 Prevalence increased from 0.3 percent in those ages 65–69 years to 5.4 percent in those older than age 80 years.97 Prevalence of any dementia increased from 8.8 percent in women younger than age 75 years to 51 percent in those older than age 85 years, and to 56 percent in centenarians (Figure 44).95,176,236,282 Severe dementia increased from 0.6 percent in women ages 65–74 years to 17.2 percent in those older than age 85 years.95,176,236,282

Figure 43 Prevalence of Vascular or Mixed Dementia in Older Women From the EURODEM Prevalence Research Group (High Level of Evidence)97

Figure 43 is a forest plot diagram depicting prevalence of vascular or mixed dementia in elderly women, EURODEM-Prevalence Research Group. The plot has two columns. The left-hand column has studies that examined cognitive impairment in different age categories. The right-hand column is a plot of prevalence (%) with 95% CI for each age category. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The prevalence of dementia in elderly women was consistent across different countries with evident increases with aging. The EURODEM-Prevalence Research Group found vascular or mixed dementia in 2.33 percent of elderly women (95% CI 1.45, 3.74). Prevalence increased from 0.25 percent (95% CI 0.08, 0.80) in those 65-69 years old to 5.4 percent in those older than 80 years of age (95% CI 2.98, 9.84).

Figure 44 Prevalence of Dementia in Older Women in Age and Severity Categories (High Level of Evidence)95,176,236,282

Figure 44 is a forest plot diagram depicting prevalence of dementia in age and severity categories in elderly women (high level of evidence from four studies). The plot has two columns. The left-hand column has studies that examined prevalence of global impairment, any dementia, and mild, moderate, or severe dementia in different age categories. The right-hand column is a plot of prevalence (%) with 95% CI for each definition and age category. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. Prevalence of any dementia increased from 8.8 percent in women less than 75 years of age to 51 percent in those older than 85 and to 56 percent in centenarians. Severe dementia increased from 0.6 percent in women 65–74 years of age to 17.2 percent in those over 85 years old.

Other factors. Several factors have been associated with the development of cognitive impairment and dementia in healthy aging people (Appendix E Table 16).283,284 Sedentary lifestyle was associated with dementia in several studies.285–292 Several cohort studies demonstrated an increased risk of dementia among smokers (Appendix E Table 16).284,285,293–295 The association with alcohol intake was not linear, with an increased risk of dementia among both nondrinkers and heavy drinkers.285,288,296–300 Obesity301–304 and increased saturated fat intake in older adults was also associated with a higher risk of cognitive impairment.285,305

Several studies showed that cognitive impairment was associated with a greater risk of dementia. More than 20 percent of older people with cognitive impairment developed dementia during 2 to 5 years of followup (Appendix E Table 17).98 The Cache County Study on Memory, Health, and Aging demonstrated that 46 percent of older individuals with mild cognitive impairment developed dementia during 3 years of followup.306 The Religious Orders Study99 and the German Study on Aging, Cognition, and Dementia in Primary Care Patients Study Group100 demonstrated a significant risk of any dementia and Alzheimer’s disease in older individuals with cognitive impairment (Appendix E Table 18). Several cognitive tests have been shown to predict dementia in older people with cognitive impairment, including the Selective Reminding Test, Benton Visual Retention Test, Wechsler Memory Scale, Paired Associate Learning, Mattis Dementia Rating Scale, Rey Auditory Verbal Learning Test, Cambridge Mental Disorders in the Elderly Examination, Wechsler Adult Intelligence, Fuld Object Memory Test, Boston Naming Test, and California Verbal Learning Test (Appendix E Table 19).98,283 The differences in the magnitude of the association between different definitions of cognitive impairment and dementia have not been documented in large population-based studies.

In conclusion, prevalence of cognitive impairment and dementia increased with age, with the highest prevalence among community-dwelling persons ages 80–85 years. Older African Americans had a higher prevalence of cognitive impairment. Older men and women had comparable prevalence of cognitive impairment and dementia. Older persons with cognitive impairment were at a higher risk of developing dementia.

### Frailty

Prevalence of frailty increased with age but differed within age subgroups, depending on definitions (Appendix E Table 20). Prevalence in those between the ages of 65 and 70 years ranged from 3–6 percent, using the phenotype definition, to 5–15 percent using the accumulation deficit definition (Figure 45).23,101–104 Prevalence of frailty in adults between the ages of 70 and 80 years varied from 5–12 percent, according to the phenotype definition, to 8–17 percent according to the accumulation deficit definition (Figure 46).22,23,101,104,105 Prevalence of frailty according to any definition was more than 16 percent in those older than age 80 years (Figure 47).23,101–104 Prevalence according to the phenotype definition increased from 16 percent in those ages 80–84 years to 26 percent in those ages 85–89 years, without further increase with age. Prevalence of frailty according to the accumulation deficit definition continued increasing with age. More than half (50 to 56 percent) of people older than age 85 years were frail according to the accumulation deficit definition.

Figure 45 Differences in Prevalence of Frailty in Older Persons Ages 65 to 70 Years According to Definition of Frailty (Moderate Level of Evidence)23,101–104

Figure 45 is a forest plot diagram depicting differences in prevalence estimates in elderly between 65 and 70 years of age depending on different definitions of frailty (moderate level of evidence from five studies). The plot has two columns. The left-hand column has studies that examined prevalence of frailty using different definitions. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. Prevalence of frailty in elderly people between 65 and 70 years of age ranged from 3 to 6 percent, using phenotype definition, to 5-15 percent using accumulation deficit definition.

Figure 46 Differences in Prevalence of Frailty in Older Persons Ages 70 to 80 Years According to Definition of Frailty (Moderate Level of Evidence)22,23,101,104,105

Figure 46 is a forest plot diagram depicting differences in prevalence estimates in elderly individuals between 70 and 80 years of age depending on different definitions of frailty (moderate level of evidence from five studies). The plot has two columns. The left-hand column has studies that examined prevalence of frailty using different definitions in different age categories. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. Prevalence of frailty in adults between 70 and 80 years of age varied from 5 to 12 percent, according to the phenotype definition, to 8 to 17 percent according to accumulation deficit.

Figure 47 Differences in Prevalence of Frailty in Persons Older Than Age 80 Years According to Definition of Frailty (Moderate Level of Evidence)23,101–104

Figure 47 is a forest plot diagram depicting differences in prevalence estimates in elderly individuals older than 80 years of age depending on different definitions of frailty (moderate level of evidence in five studies). The plot has two columns. The left-hand column has studies that examined prevalence of frailty using different definitions in different age categories. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. Prevalence was more than 16 percent in elderly people older than 80 years of age according to any definition. Prevalence according to phenotype definition increased from 16 percent in those 80-84 years old to 26 percent in elderly individuals between 85-89 years of age without further increase with aging. Prevalence of frailty according to accumulation deficit continued increasing with aging. More than half (50 to 56 percent) of elderly people over 85 years were frail according to accumulation deficit definition.

Among race groups, older African Americans had the highest prevalence of frailty across different definitions (Appendix E Table 21). More than half of older African Americans were frail according to two studies (Precipitating Events Project and Frailty Study of African Americans in South Central Los Angeles) (Figure 48).23,104,106,107 Two studies examined prevalence of frailty in older Hispanics and reported that 8–20 percent met different frailty criteria (Figure 49).104,108 Prevalence of frailty in older Caucasians varied from 6–12 percent, using the phenotype definition, to 15–40 percent using the accumulation deficit definition (Figure 50).23,104,107,109 The large cohort studies of predominantly Caucasian participants in the Survey of Health, Aging and Retirement in Europe demonstrated that, according to phenotype criteria, 17 percent of older people were frail.110

Figure 48 Prevalence of Frailty in Older African Americans According to Definition of Frailty (Moderate Level of Evidence)23,104,106,107

Figure 48 is a forest plot diagram depicting prevalence of frailty in African American elderly persons depending on definitions of frailty (moderate level of evidence from four studies). The plot has two columns. The left-hand column has studies that examined prevalence of frailty using different definitions. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. More than half of elderly African American individuals were frail according to two studies (Precipitating Events Project and Frailty Study of African Americans in South Central Los Angeles). The Health and Retirement Study found that 20.18% of African American elderly persons were frail according to accumulation deficits definitions and 30% according to phenotype definition.

Figure 49 Prevalence of Frailty in Older Hispanics According to Definition of Frailty (Low Level of Evidence)104,108

Figure 49 is a forest plot diagram depicting prevalence of frailty in Hispanic elderly individuals depending on definitions of frailty (low level of evidence from two studies). The plot has two columns. The left-hand column has studies that examined prevalence of frailty using different definitions. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. Prevalence varied from 8 to 20 percent depending on frailty criteria that were included in definitions.

Figure 50 Prevalence of Frailty in Older Caucasians According to Definition of Frailty (Low Level of Evidence)23,104,107,109

Figure 50 is a forest plot diagram depicting prevalence of frailty in Caucasian elderly persons depending on definitions of frailty (low level of evidence from four studies). The plot has two columns. The left-hand column has studies that examined prevalence of frailty using different definitions. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. Prevalence of frailty in Caucasian elderly persons varied from 6 to 12%, using the phenotype definition, to 15 to 40%, using the accumulation deficit definition.

Among sex groups, prevalence of frailty was somewhat higher in women than in men. Estimates varied depending on studies, definitions, and age subgroups. In older men, prevalence of phenotype frailty was 7 percent, and accumulation deficit frailty was 24 percent (Figure 51).23,103–105,107,109,111–115 Prevalence of phenotype frailty increased from 2–37 percent in higher age subgroups (Figure 52).23,101,111,113,115 Prevalence of accumulation deficit frailty increased from 3 percent in men ages 65–69 years to 55 percent in those older than age 90 years. Prevalence was higher in aging African American and Hispanic men compared to Asian or Caucasian men (Figure 53).23,113,116 Prevalence of phenotype frailty was 13 percent in women, and accumulation deficit frailty was 26 percent (Figure 54).23,24,103–105,107,109,111,115–117 Prevalence of phenotype frailty increased from 3–13 percent in higher age subgroups (Figure 55).23,101,104,111,115 Prevalence of accumulation deficit frailty increased from 6–57 percent in higher age subgroups. African American women had the highest prevalence of frailty, with 60 percent of those older than age 85 years being frail (Figure 56).23,116

Figure 51 Prevalence of Frailty in Older Men (Moderate Level of Evidence)23,103–105,107,109,111–115

Figure 51 is a forest plot diagram depicting prevalence of frailty in elderly men (moderate level of evidence from 11 studies). The plot has two columns. The left-hand column has studies that examined prevalence of frailty using accumulation deficit or phenotype definition. The right-hand column is a plot of prevalence (%) with 95% CI for each study. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The diamond represents a pooled estimate from random effects model with 95% CI. Overall, 10.28% of elderly men were frail (95% CI 5.96, 17.75). Pooled from three studies prevalence of frailty defined as accumulation deficit was 24.39% (95% CI 11.34, 52.44) with significant heterogeneity across the studies. Pooled from eight studies prevalence of frailty defined as phenotype was 7.41% (95% CI 3.91, 14.05) with significant heterogeneity across the studies.

Figure 52 Prevalence of Frailty in Older Men By Definition and Age Group, Sorted By Increasing Age (High Level of Evidence)23,101,111,113,115

Figure 52 is a forest plot diagram depicting prevalence of frailty in elderly men by definition and age groups (high level of evidence from five studies). The plot has two columns. The left-hand column has studies that examined prevalence of frailty using accumulation deficit or phenotype definition in different age categories. The right-hand column is a plot of prevalence (%) with 95% CI for each definition and age category. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. Prevalence of phenotype frailty increased from 2 to 37% in subgroups with higher ages. Prevalence of accumulation deficit frailty increased from 3% in men 65-69 years of age to 55% in those older than 90 years of age.

Figure 53 Prevalence of Frailty in Men Using Phenotype Definition in Race and Age Subgroups, Sorted By Increasing Age (High Level of Evidence)23,113,116

Figure 53 is a forest plot diagram depicting prevalence of frailty in men using phenotype definition in race and age subgroups (sorted by increasing age) (high level of evidence from three studies). The plot has two columns. The left-hand column has studies that examined prevalence of frailty using phenotype definition in different race and age categories. The right-hand column is a plot of prevalence (%) with 95% CI for each race and age category. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. Prevalence was higher in aging African American (prevalence ranged 3-25%) and Hispanic (prevalence ranged 2-17%) men compared to Asian (prevalence 6%) or Caucasian elderly men (prevalence 4%).

Figure 54 Prevalence of Frailty in Older Women According to Definition (High Level of Evidence)23,24,103–105,107,109,111,115–117

Figure 54 is a forest plot diagram depicting prevalence of frailty in elderly women depending on definitions (high level of evidence from 11 studies). The plot has two columns. The left-hand column has studies that examined prevalence of frailty using phenotype or accumulation deficits definitions. The right-hand column is a plot of prevalence (%) with 95% CI for each definition. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. The diamond represents a pooled estimate from random effects model with 95% CI. Pooled from four studies prevalence of frailty defined as accumulation deficit was 26.41% (95% CI 17.93, 38.90) with significant heterogeneity across the studies. Pooled from eight studies prevalence of frailty defined as phenotype was 12.94% (95% CI 7.81, 21.44).This figure demonstrates that prevalence depends of definition being higher when frailty was defined as accumulation deficit.

Figure 55 Prevalence of Frailty in Older Women By Definition and Age Group, Sorted By Increasing Age (High Level of Evidence)23,101,104,111,115

Figure 55 is a forest plot diagram depicting prevalence of frailty in elderly women depending on definition and age categories (sorted by increasing age) (high level of evidence from five studies). The plot has two columns. The left-hand column has studies that examined prevalence of frailty using phenotype or accumulation deficits definitions in different age categories. The right-hand column is a plot of prevalence (%) with 95% CI for each definition and age category. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. Prevalence increased with age using either definition. Prevalence of phenotype frailty increased from 3 to 13% in higher age subgroups. Prevalence of accumulation deficit increased from 6 to 57% in higher age subgroups. This figure demonstrates that prevalence depends of definition being higher when frailty was defined as accumulation deficit.

Figure 56 Prevalence of Frailty in Older Women Using Phenotype Definition in Race and Age Subgroups, Sorted By Increasing Age (Moderate Level of Evidence)23,116

Figure 56 is a forest plot diagram depicting prevalence of frailty according to phenotype model in elderly women by race and age categories (sorted by increasing age) (moderate level of evidence from two studies). The plot has two columns. The left-hand column has studies that examined prevalence of frailty in different race and age categories. The right-hand column is a plot of prevalence (%) with 95% CI for each race and age category. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. African American women had the highest prevalence of frailty with 60% of elderly individuals over 85 years of age being frail. One study, Hispanic Established Populations for Epidemiologic Study of the Elderly (65+), found that 22% of elderly Hispanic women were frail according to phenotype definition.

In conclusion, prevalence of frailty varied depending on studies, definitions, and age subgroups. Prevalence increased with age and was higher when accumulation deficit definitions were used. Older African Americans and Hispanics had a higher prevalence of frailty.

### Disability

#### Prevalence of BADL disability by sex

Any BADL disability. Four studies reported prevalence for any BADL disability by sex, and women had a higher prevalence of any BADL disability (8.1–14.0 percent) than men (6.5–10.3 percent) (Figures 57–60).61,63,64,121

Figure 57 Prevalence of Any Basic ADL Disability in Women and Men (Moderate Level of Evidence)61,63,64

Figure 57 is a forest plot reporting the prevalence of disabilities with any Basic Activities of Daily Living by gender in studies with a moderate level of evidence. Any BADL disability was defined as reporting one or more limitations with BADLs. The number of BADL items used in each study ranged from three to seven items. The left column groups the study name by gender and the right column reports the prevalence and 95% confidence interval. The prevalence of any BADL disability for women ranged from 8.1% to 14% and for men it ranged from 6.5% to 10.3%. The forest plots clearly show a higher prevalence of any BADL disability in women.

Figure 58 Prevalence of Any Basic ADL Disability in Women Increases With Older Age (Good-Quality Study)59

Figure 58 is a bar graph demonstrating that BADL disabilities increase with older age in women from a good quality study. The graph has four vertical bars. The first bar represents women age 82 or younger and shows a prevalence of less than 25%. The second bar represents women age 83 to 84 and shows a prevalence of over 27%. The third bar represents women age 85 to 88 and shows a prevalence of less than 25%. The fourth bar represents women age 89 and older and reports a prevalence of over 29%.

Figure 59 Prevalence of Any ADL Disability in the Cardiovascular Health Study Increases With Older Age (Good-Quality Study)59

Figure 59 is a bar graph from the Cardiovascular Health Study demonstrating that any ADL disability increases with age. The graph contains four vertical bars. The first bar represents men and women age 82 and younger and shows a prevalence of about 16%. The second bar represents men and women age 83–84 and shows a prevalence of about 12.5%. The third bar represents men and women age 85–88 and shows a prevalence of about 22.5%. The fourth bar represents men and women age 89 and older and shows a prevalence of about 24%. The bar graph shows a higher prevalence in men and women age 85 and older.

Figure 60 Differences in Prevalence of Any Basic ADL Disability By Age and Sex (Good-Quality Study)59

Figure 60 is a bar graph demonstrating the difference in prevalance of any BADL disability by age and gender from a good quality study. The graph contains eight vertical bars with the x axis categorized into four age categories for men and women. The y axis reports the prevalence. The first vertical bar represents men age 82 and less and reports a prevalence close to 16%. The second vertical bar represents men age 83–84 and reports a prevalence near 12%. The third vertical bar represents men age 85–88 and reports a prevalence near 22.5%. The fourth vertical bar represents men age 89 and older and reports a prevalence near 24%. The fifth vertical bar represents women age 82 and less and reports a prevalence just under 25%. The sixth vertical bar represents women age 83–84 and reports a prevalence just under 25%. The seventh vertical bar represents women age 85–88 and reports a prevalence near 27%. The eighth vertical bar represents women age 89 and older and reports a prevalence near 30%. The bar graph clearly demonstrates the the prevalence for women of any age is greater than that for even the oldest men.

Moderate BADL disability. Women (21.7 percent) had a higher prevalence of moderate BADL disability than men (19.1 percent) in the one study that reported this outcome (Figure 61).118

Figure 61 Prevalence of Moderate ADL Disability By Age (Good-Quality Study)118

Figure 61 is a bar graph demonstrating differences in the prevalence of moderate ADL disability by age and gender from a good quality study. Moderate ADL disability is defined as having limitations in one to two basic activities of daily living. The graph contains four vertical bars. The x-axis reports the four age and gender categories and the y-axis reports the prevalence in percentages. The first vertical bar represents women age 65 to 79 and shows a prevalence near 17%. The second vertical bar represents women age 80 and older and shows a prevalence near 32%. The third vertical bar represents men age 65 to 79 and shows a prevalence slightly under 14%. The fourth vertical bar represents men age 80 and over and shows a prevalence near 27%. The chart shows that women age 65 to 79 have a slightly higher prevalence of moderate ADL disability than men the same age. The oldest women those age 80 and over had a higher prevalance than men the same age.

Severe BADL disability. The prevalence of severe BADL disability was the same in older men and women (6 percent) (Figure 62).118

Figure 62 Prevalence of Severe ADL Disability By Age (Good-Quality Study)118

Figure 62 is a bar graph reporting the prevalence of severe ADL disability by age and gender from a good quality study. Severe ADL disability is defined as having limitation with three or more basic activities of daily living. The x-axis reports the age and gender categories and the y-axis reports the prevalence in percentages. There are four vertical bars on the graph. The first vertical bar represents women age 65–79 and reports a prevalence of 6%. The second vertical bar represents women age 80 and over and reports a prevalence of 11%. The third vertical bar represents men age 65–70 and reports a prevalence of 6%. The fourth vertical bar represents men age 80 and older and reports a prevalence of 10%. In general, the graph shows that the prevalence of severe ADL disability is similar among men and women.

Individual BADL disabilities. Women had a higher prevalence of disabilities in bathing, dressing/hygiene, transferring, and walking than men (Table 17). The prevalence was equal between men and women for eating disabilities, and no study reported on differences in toileting disabilities.

Table 17 Prevalence of Basic ADL Disability in Women and Men

Disability Definition | Range of Older Persons With Disability (%)
Disability Definition | Women | Men
Any BADL disability | 8.1–14.0^61,63,64,121^ (high level of evidence) | 6.1–10.3^61,63,64,121^ (high level of evidence)
Moderate BADL disability | 21.7^118^ | 19.1^118^
Severe BADL disability | 7.0^118^ | 7.0^118^
Bathing disability | 7.7^122^ | 4.4^122^
Dressing/hygiene disability | 17.1 (Alumni Health Study)120 | 13.2 (Alumni Health Study)120
Eating disability | 1.2^119^ to 11.8 (Alumni Health Study)120 | 1.2^119^ to 6.0 (Alumni Health Study)120
Toileting disability | None | None
Transferring disability | 27.6 (Alumni Health Study)120 | 19.2 (Alumni Health Study)120
Walking disability | 27.3 (Alumni Health Study)120 | 18.6 (Alumni Health Study)120

Summary. In general, women had higher rates for all types of BADL disabilities, except for eating disabilities, which had an equal prevalence. The highest prevalence reported for BADL disability occurred when it was measured as moderate BADL disability, then as any BADL disability, and finally as severe BADL disability.

#### Prevalence of IADL disability by sex

Few studies reported differences by sex in IADL disabilities (Table 18).

Table 18 Differences in Instrumental ADL Disability Prevalence By Sex (Good-Quality Individual Studies)

IADL Disability | Men | Women
Any IADL | 9.2^121^ | 12.7^121^
Housekeeping | 23.6^120^ | 40.1^120^
Meal Preparation | 9.8^119^ | 10.2^119^
Shopping | 20.5^119^ | 10.4^119^

The prevalence of any IADL disability was higher in women than men (Table 18).121 One study described changes in the prevalence of any IADL disability over 6 years between men and women.121 More women reported an IADL disability than men at any time period, but showed less change over time (Figure 63). In terms of individual IADL disabilities, more women had more difficulty with housekeeping and meal preparation than men, but less difficulty with shopping (Figures 64 and 65).119,122

Figure 63 Time Trend and Differences in Prevalence of One or More Instrumental ADL Disabilities By Sex (Good-Quality Study)121

Figure 63 is a line graph showing a time trend and gender differences in the prevalence of any IADL disability from a good quality study. Any IADL disability is defined as having one or more limitations with instrumental activities of daily living (IADL). The x-axis categories represent the years 1984, 1986, 1988, and 1990 for women and men. The first line represents the prevalence of any IADL disability for women by year. The prevalence for women remains fairly constant at just under 13% for the years 1984, 1986, and 1988 and it drops to under 12% in 1990. The second line represents the prevalence of any IADL disability for men by year. The prevalence increases dramatically from 9% in 1984 to 12.5% in 1986, then decreases to 11% in 1988 and 10.5% in 1990. In general, the graph shows that the prevalence of any IADL disability is higher and more constant than that for men.

Figure 64 Difference in Prevalence of Meal Preparation and Shopping Disability By Sex (Good-Quality Study)122

Figure 64 is a bar graph reporting gender differences in the prevalence of meal preparation and shopping disabilities from a good quality study. The graph contains four vertical bars. The first vertical bar shows that just under 10% of men have difficulty with meal preparation. The second vertical bar shows that just over 10% of women have difficulty with meal preparation. The third vertical bar shows that over 20% of men have difficulty with shopping. The fourth vertical bar shows that just over 10% of women have difficulty shopping. The graph clearly shows that men have greater difficulty with shopping than women.

Figure 65 Prevalence of Housekeeping Disability By Sex and Age (Good-Quality Study)122

Figure 65 is a bar graph reporting the prevalence of housekeeping disabilities by gender and age from a good quality study. There are four vertical bars. The first vertical bar shows that about 2.5% of men age less than 75 years have a housekeeping disability. The second vertical bar shows that about 5.2% of men age 75 or older have a housekeeping disability. The third vertical bar shows that 8.1% of women less than age 75 have a housekeeping disability. The fourth vertical bar shows that over 9% of women over the age of 75 have a housekeeping disability. In general the graph shows that women are twice as likely to have a housekeeping disability than men of similar age.

#### Prevalence of BADL disability by ethnicity

Any BADL disability. Two studies reported prevalence of any BADL disability by ethnic group and one study enrolled only older Hispanic Americans (Table 19).41,60,62 Prevalence of any BADL disability, in order of highest to lowest, was African Americans (13.6 percent), American Indians (11.6 percent), Hispanic Americans (11.0 percent),41 and Caucasian Americans (8.1 percent) (Figure 66).62 Racial differences persisted after accounting for sex. Older African American women had the highest prevalence of having any BADL disability (10.7 percent), followed by African American men (7.5 percent), Caucasian women (5.2 percent), and Caucasian men (4.7 percent) (Figure 67).60

Table 19 Prevalence of Basic ADL Disability By Ethnic Group (Good-Quality Individual Studies)

Disability Definition | Prevalence (%)
Disability Definition | African American Older Persons With Disability | American Indian Older Persons With Disability | White Older Persons With Disability
Any BADL disability | 13.6^62^ Men: 7.5^60^ Women:10.7^60^ | 11.6^62^ | 8.7^62^ Men: 4.7^60^ Women: 5.2^60^
Moderate BADL disability
Severe BADL disability
Bathing disability
Dressing/hygiene disability
Eating disability | 1.2^119^ | | 1.2^119^
Toileting disability
Transferring disability
Walking disability

Figure 66 Differences in Prevalence of Any ADL Disability By Race and Ethnicity in the Census Public Use Microdata Sample (Good-Quality Study)62

Figure 66 is a bar graph reporting race and ethnic differences in the prevalence of any ADL disability from a good quality study. Any ADL disability is defined as having one or more limitations in basic activities of daily living. The graph contains three horizontal bars. The x-axis list the prevalence of any ADL disability, while the y-axis lists the racial or ethnic group. The first horizontal bar shows that about 13% of African Americans report an ADL disability. The second horizontal bar shows that about 11.5% of American Indian and Alaska Natives report an ADL disability. The third horizontal bar shows that less than 9% of white Americans report an ADL disability.

Figure 67 Differences in Prevalence of Any Basic ADL Disability By Sex and Race (Good-Quality Study)60

Figure 67 is a bar graph reporting gender and race differences in the prevalence of any BADL disability from a good quality study. Any BADL disability is defined as having one or more limitations in basic activities of daily living (BADL). The graph contains four horizontal bars. The first horizontal bar shows that 11% of African American women age 65–74 report any BADL disability. The second horizontal bar shows that 7.5% of African American men age 65–74 report any BADL disability. The third horizontal bar shows that 5.5% of white American women age 65–74 report any BADL disability. The fourth horizontal bar shows that less than 5% of white American men age 65–74 report any BADL disability. The graph clearly shows that Older African American women have the highest prevalence of reporting any BADL disability followed by African American men, white women, and then white men.

Eating disability. One study reported the prevalence of eating disabilities by ethnic group and found that African American and Caucasian older adults had the same prevalence (1.2 percent) (Figure 68).119

Figure 68 Differences in Prevalence of Eating Disability By Race and Sex (Good-Quality Study)119

Figure 68 is a bar graph reporting race and gender differences in eating disabilities from a good quality study. The bar graph contains four horizontal bars. The first bar shows that 1.1% of white women have an eating disability. The second bar shows that 1.5% of African American women have an eating disability. The third bar shows that 1.3% of white men have an eating disability. The fourth bar shows that 0.6% of African American men have an eating disability. African American women have the highest prevalence of eating disabilities followed by white men, white women, and then African American men.

Summary. The prevalence of BADL disabilities was highest in African American older people, followed by American Indian older people and Hispanic older people, and was lowest in Caucasian older Americans. African American women had the highest prevalence of BADL disability, followed by African American men, Caucasian women, and Caucasian men. There were no racial differences in eating disabilities.

#### Prevalence of IADL disability by ethnicity

Only one study reported differences in the prevalence of IADL disabilities by race.119 Older African Americans had a higher percentage of individuals having difficulty with meal preparation and shopping than Caucasian older adults. Older African American women had the highest prevalence (Figures 69 and 70).

Figure 69 Prevalence of Shopping Disability By Race and Sex (Good-Quality Study)119

Figure 69 is a bar graph reporting differences in the prevalence of shopping disabilities by race and gender from a good quality study. The graph has six vertical bars. The first bar shows that about 24.6% of African American women have a shopping disability. The second bar shows that about 15.6% of white women have a shopping disability. The third bar shows that about 12.1% of African American men have shopping disabilities. The fourth bar shows that about 8.3% of white men have a shopping disability. The fifth column pools the prevalence for African American men and women and shows a prevalence of just over 16%. The sixth column pools the prevalence for white men and women and shows a prevalence of just over 10%.

Figure 70 Prevalence of Meal Preparation Disability By Race and Sex (Good-Quality Study)119

Figure 70 is a bar graph reporting differences in the prevalence of meal preparation disabilities by race and gender from a good quality study. The graph has six vertical bars. The first bar shows that about 9% of African American men have difficulty preparing meals. The second bar shows that about 11% of white men have difficulty preparing meals. The third bar shows that about 12% of African American women have difficulty preparing meals. The fourth bar shows that about 7% of white women have difficulty preparing meals. The fifth column pools the prevalence for African American men and women and shows a prevalence of just over 10%. The sixth column pools the prevalence for white men and women and shows a prevalance of just under 10%. The graph illustrates how important it is to look at gender differences in prevalence. Pooling the prevalences show similar results, whereas the individual prevalences clearly show that African American women and white men have higher prevalences of meal preparation disabilities.

Summary. Very little is known about racial differences in the prevalence of IADL disability in older people. African American women appear to have more IADL disability.

#### Prevalence of BADL disability by age groups

Any BADL disability. One study reported differences in the prevalence of any BADL disability by sex and age group.59 In general, the prevalence of any BADL disability increased with age and was higher in women (Table 20).

Table 20 Differences in Prevalence of Moderate Basic ADL Disability By Age and Sex Groups (Good-Quality Study)118

| Ages 65–74 | Ages 80+
Women | 18.0% | 33.0%
Men | 17.0% | 28.0%

Moderate BADL disability. One study reported differences in the prevalence of moderate BADL disability by sex and age group.118 In general, prevalence of moderate BADL disability was higher in women and in the oldest age groups. Women older than age 80 years had the highest prevalence of moderate BADL disability.

Severe BADL disability. One study reported differences in the prevalence of severe BADL disability by sex and age group.118 Prevalence of severe BADL disability ranged from 10–11 percent in people ages 80 years and older, was 6 percent in those ages 65–74 years, and did not differ significantly by sex (Table 21).

Table 21 Differences in Prevalence of Severe Basic ADL Disability By Age and Sex Groups (Good-Quality Study)118

| Ages 65–74 | Ages 80+
Women | 6.0% | 10.0%
Men | 6.0% | 11.0%

Summary. BADL disability was highest in the oldest age groups, and in older women.

### Sarcopenia

Prevalence of sarcopenia increased with age.68,123 However, the association was strong and consistent only in men.68,123 The association was significant in women in the New Mexico Elder Health Survey68 but random in female participants in the Health Aging and Body Composition Study.123

Older African Americans had significantly lower odds of sarcopenia when compared to Caucasians (OR, 0.2 [95% CI, 0.1–0.3]).123 The odds of sarcopenia did not differ among Hispanic and non-Hispanic whites.68

Prevalence of sarcopenia did not demonstrate a consistent association with comorbidity across the studies. Older men with more than three diseases had significantly higher odds of sarcopenia in the Health Aging and Body Composition Study123 but not in the New Mexico Elder Health Survey.68 Sarcopenia was not associated with multimorbid conditions in women in both studies.68,123

### Malnutrition

Prevalence of poor nutritional scores did not demonstrate a linear association with age in the Nutrition Screening Initiative.84 Prevalence was highest in those ages 65–74 years (46 percent) but decreased to 31 percent in those older than age 85 years.84 Sex differences in prevalence of malnutrition were evident for some but not all definitions of malnutrition (Appendix E Figure 2).96

Prevalence of poor nutritional scores was the same in men and women in the Nutrition Screening Initiative (Figure 71).84 The pooled prevalence of poor nutritional scores was 18.27 percent in older men and 24 percent in older women (Figure 34). Prevalence of unintentional weight loss also did not differ by sex (Figure 72).71,72 Women, however, had a lower prevalence of decreased albumin levels77 but a higher prevalence of low BMI (Appendix E Table 10).72

Figure 71 Factors Associated With Malnutrition Defined as High Nutritional Score, Low Body Mass Index, or Unintentional Weight Loss (Good-Quality Individual Studies)79–81

Figure 71 is a forest plot diagram depicting factors associated with malnutrition that was defined as high nutritional score, low body mass index, or not intentional weight loss (good quality three individual studies). The plot has two columns. The left-hand column has studies that examined prevalence of different definitions of malnutrition in race and age categories. The right-hand column is a plot of the measure of effect with 95% confidence limits in each category. Means of the relative measure of the association are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between age, race, gender, or definition of malnutrition is also plotted. If the confidence intervals for individual studies do not overlap with this line, it demonstrates a significant association between examined factors and prevalence of malnutrition. This figure demonstrated that prevalence of poor nutritional scores was the same in men and women in the Nutrition Screening Initiative. Elderly African Americans individuals had a significantly higher risk of malnutrition defined as unintentional weight loss when compared to elderly Caucasian individuals (relative risk 6.05 95% CI 1.66, 22.06). Elderly persons with disability had higher odds of malnutrition when compared to able elderly persons (odds ratio 4.00 95% CI 1.40, 11.30).

Figure 72 Prevalence of Malnutrition Defined as Low Body Mass Index, Low Serum Albumin Level, or Unintentional Weight Loss (Good-Quality Individual Studies)46,70–77

Figure 72 is a forest plot diagram depicting prevalence of malnutrition defined as low body mass index, serum albumin level, or unintentional weight loss (9 good quality individual studies). The plot has two columns. The left-hand column has studies that examined prevalence of malnutrition using different definitions. The right-hand column is a plot of prevalence (%) with 95% CI for each definition. Mean prevalence is presented by a square incorporating confidence intervals represented by horizontal lines. Women had slightly higher prevalence of low albumin and low body mass index. Prevalence of unintentional weight loss did not differ by gender. Prevalence of low body mass index varied across four studies from the lowest (0.10%) in the Geisinger Rural Aging Study to the highest in the American veterans (15.00%).

Older African Americans had a significantly higher risk of malnutrition defined as unintentional weight loss when compared to Caucasians (Figure 71).71 According to NHANES II, prevalence of anemia did not differ among older Caucasians and non-Caucasians (Appendix E Table 11).78

Prevalence of unintentional weight loss did not differ in older Hispanics and non-Hispanics.72 Older Hispanic women had a higher prevalence of poor nutritional scores when compared to non-Hispanic women (30 percent vs. 17 percent, respectively).72

In conclusion, age and sex differences in malnutrition were not consistent across the studies. Older African Americans had a higher prevalence of unintentional weight loss. Older Hispanic women had a higher prevalence of poor nutritional scores.

### Homeostenosis (Impaired Homeostasis)

We could not identify studies that reported prevalence of homeostenosis in age subgroups.

### Chronic Inflammation

We could not identify studies that reported prevalence of chronic inflammation in age, sex, or race subgroups. Older women with higher blood levels of carotene, lycopene, lutein, b-cryptoxanthin, and selenium had a lower prevalence of elevated IL6 (Appendix E Table 22).240

In conclusion, evidence was insufficient about prevalence of unspecified chronic inflammation in older subpopulations.

## Key Question 3 What is the Association Between These Common Syndromes/Conditions and Mortality, Institutionalization, Hospitalization, and Activities of Daily Living?

We analyzed the association of outcomes with each syndrome and across all syndromes. The estimates of the association varied depending on definitions of comorbidities, population subgroups, definitions of the outcomes, and adjustment for correlated contributing factors. Some analyses did not address the multifactorial nature of geriatric syndromes and the role of baseline diseases. For example, disability was an outcome but also a part of the definition of frailty. Adjustment for correlated multifactorial syndromes that ignored definitive primary cause of disability or death may give invalid estimation of the association between syndromes and mortality. Age and specific disease contributions were not separately examined in the studies.

### Multiple Morbidities

The estimates of the association varied depending on definitions of comorbidities, population subgroups, definitions of the outcomes, and adjustment for correlated contributing factors. The Women’s Health and Aging Studies I and II demonstrated increased odds of frailty in women with more than three chronic diseases (OR, 1.5 [95% CI, 1.3–1.7])89 or more than eight inflammatory diseases (OR, 1.8 [95% CI, 1.5–2.3]) (Appendix E Table 23).117 The Health ABC Study found an increased risk of sarcopenia in older men (RR, 2.8 [95% CI, 1.7–4.8]) but not in women.123

The positive significant association between multiple morbidities and mortality was consistent across the studies. Older persons with comorbidities had a 32–112 percent relative increase in death (Table 22).39,124–129 The magnitude of the association decreased during the time of followup, from a 100 percent relative increase at 10 years (OR, 2 [95% CI, 1.4–2.8)] to a 59 percent increase at 15 years (OR, 1.59 [95% CI, 1.1–2.3]).125 The association between comorbidity and mortality attenuated dramatically during the longer time of followup in another cohort, from a 471 percent relative increase at 1 year to a 120 percent increase at 10 years.129 Attenuation in association may be a statistical reflection of a greater denominator as outcomes accrue over time. The magnitude of the association was dose responsive, with an 85 percent relative increase in mortality for older persons with four to five diseases and a 112 percent relative increase among those with six or more chronic conditions.126

Table 22 Association Between Multiple Morbidities and Clinical Outcomes

Population | Number of Chronic Diseases | Charlson Score | Polypharmacy | Poor Health
Relative increase in risk of death
| High level of evidence | Good-quality individual study | Moderate level of evidence | High level of evidence
All sexes | 32–112%^39,124,125–129^ | | 13–16% per drug54,130 | Pooled: 104%^27,103,131^
Women | 18%^243^ | 89–154%^308^ | Not significant94 | Pooled: 235%^94,280^
Men | | 127%^308^ | Not significant94 | Pooled: 233%^94,280^
Relative increase in risk of institutionalization
| Low-quality individual study | | | Moderate level of evidence
All sexes | 20%^128^ | | | 10–80%^8,103,132^ Dose response: 20% per score (0–5)327
African Americans | | | | Not significant311,328
Caucasians | | | | 10–12%^311,328^
Relative increase in risk of hospitalization
| Low-quality individual study | Low-quality individual study | Moderate level of evidence | Low level of evidence
All sexes | 70%^133^ | 37–94%^126^ | 124–190%^133,134^ | 7–179%^135–140^

A prospective cohort from a large health maintenance organization demonstrated a significant increase in mortality in older women (OR, 2.5 [95% CI, 1.1–6.0]) and men (OR, 2.3 [95% CI, 1.3–4.1]) who had a Charlson comorbidity index score of 2–4 versus 0.^308^

Polypharmacy was significantly associated with mortality in two studies with evidence of a dose response.54,130 One European cohort, the PAQUID study, did not find a significant association between polypharmacy and death in older men and women.94

Older persons with poor health had an increased risk of death in all studies that examined the association (Figure 73).27,103,131 Older women with poor health had a 235 percent relative increase in mortality94,280 and older men had a 233 percent increase.94,280 The magnitude of the association decreased over the time of followup in women (Appendix E Table 24). Women with poor health had a 280 percent increase in risk of death at 5 months of followup in the Longitudinal Study of Aging (HR, 3.8 [95% CI, 2.0–7.1]), a 100 percent increase at 23 months (HR, 2.0 [95% CI, 1.3–3.0]), but no significant association at 32 months.309 Among other population subgroups, older Medicare beneficiaries with functional dependency and poor health had an increased risk of death of 99–124 percent.310

Figure 73 Association Between Mortality and Poor Self-Perceived Health (High Level of Evidence)27,94,103,131,280

Figure 73 is a forest plot diagram depicting the association between mortality and poor self perceived health (high level of evidence from five studies ). The plot has two columns. The left-hand column has studies that examined mortality in gender categories. The right-hand column is a plot of relative risks with 95% confidence limits. Means of relative risk are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between poor self perceived health and mortality is also plotted. If the confidence intervals for individual studies do not overlap with this line, it demonstrates a significant association between poor self perceived health and mortality. The diamond represents a pooled estimate from random effects model with 95% CI. Elderly persons with poor health had an increased risk of death in all studies that examined the association (pooled relative risk 2.04 95% CI 1.81, 2.31). Elderly women with poor health had an increased risk of death (pooled relative risk 3.35 95% CI 2.56, 4.40). Heterogeneity was not significant. Elderly men with poor health had an increased risk of death (pooled relative risk 3.33 95% CI 1.77, 6.25).

The Longitudinal Study of Aging demonstrated a positive significant association between multiple morbidities and institutionalization (Appendix E Table 25).128 Older persons with poor health had a 10–80 percent relative increase in institutionalization (Appendix E Table 26).8,103,132 The Longitudinal Study of Aging reported a significant risk of first admission ever to a nursing home (HR, 1.2 [95% CI, 1.1–1.2]) and overall nursing home placement (HR, 1.1 [95% CI, 1.1–1.2]) in older Caucasians with poor health.132,311 The association was not significant among older African Americans.

Older persons with multiple morbidities had increased odds of hospitalization (OR, 1.7 [95% CI, 1.1–2.9]) (Appendix E Table 27).133 The association with hospitalization was dose responsive.126 The relative increase in odds of hospitalization was 37 percent in persons with comorbidity scores of 3 versus ≤ 2, 46 percent in those with scores of 4–5 versus ≤5, and 94 percent in those with scores of ≥6 versus ≤2.^126^

Polypharmacy was significantly associated with hospitalization.133,134 The Medicare Risk Demonstration cohort reported a 190 percent increase (OR, 2.9 [95% CI, 2.2–4.1]) in odds of hospitalization among older persons with more than five prescriptions when compared to those with less than five concurrent drugs.133 The Assistenza Socio-Sanitaria Italian cohort found a 124 percent relative increase in odds of hospitalization among older persons with more than five prescription medications (OR, 2.2 [95% CI, 1.8–2.8]).134

The Longitudinal Study of Aging reported a significant increase in the risk of hospitalization among older persons with poor health (Appendix E Table 28).135–140 Older persons with poor health had increased odds of any hospital admission (OR, 2.8),136 any Medicare-reimbursed hospital episode (OR, 2.1),135 hospitalization for ambulatory care-sensitive conditions (OR, 1.5),137 and repeated admissions (OR, 2.2).140

In conclusion, among different definitions of multimorbid conditions, comorbidity scores and poor perceived health demonstrated a strong association with mortality in older people. Poor perceived health was a strong predictor for institutionalization. The number of chronic conditions, comorbidity scores, polypharmacy, and poor perceived health were associated with hospitalization.

### Cognitive Impairment

Cognitive impairment was associated with a significantly higher risk of mortality in all studies that examined this association (Appendix E Table 29).149 The magnitude of the association varied depending on the definition of cognitive impairment, country of study, and adjustment for other contributing factors (Appendix E Table 30). The largest relative increase of 250 percent in women and 280 percent in men was found in the Canadian Study of Health and Aging, which defined cognitive impairment as a score of <78 on the 3MSE scale.141,142 The association was dose responsive, with a 4 percent relative increase in mortality for each one-point decrease in MMSE score (Figure 74).39,44,54,143–148 The magnitude of the association was highest in studies that estimated the association with odds ratios (pooled OR, 4.2 [95% CI, 2.6–6.8]).144,146 The studies that estimated relative risk of hazard rate ratios found a 37 percent39,54 and a 61 percent44,147 relative increase in risk of death, respectively (Figure 74). Odds ratios may overestimate relative risk when baseline event rates are higher than 30 percent.312 Estimation of relative risk from the reported odds ratio was not feasible because of inconsistent reporting of baseline rates.

Figure 74 Association Between Cognitive Impairment and Mortality (High Level of Evidence)39,44,54,143–148

Figure 74 is a forest plot diagram depicting the association between cognitive impairment and mortality (high level of evidence from nine studies). The plot has two columns. The left-hand column has studies that examined mortality and reported dose response association, odds ratio, relative risk of hazard rate ratio. The right-hand column is a plot of relative measures of the association with 95% confidence limits. Means of the effects are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between cognitive impairment and mortality is also plotted. If the confidence intervals for individual studies do not overlap with this line, it demonstrates a significant association between cognitive impairment and mortality. The diamond represents a pooled estimate from random effects model with 95% CI. Heterogeneity was not significant for all associations. Reduction by one score in Mini-Mental Examination was association with a significant increase in mortality (pooled relative risk 1.04 95% CI 1.01, 1.06). The magnitude of the association was the highest for studies that estimated the association with odds ratios (pooled odds ratio 4.15, 95% CI 2.55, 6.75). The studies that estimated relative risk of hazard rate ratios found a 37% and a 61% relative increase in risk of death, respectively.

Fewer studies analyzed the association between different definitions of cognitive impairment. The Canadian Study of Health and Aging examined different case definitions of mild cognitive impairment313 and did not demonstrate a significant increase in risk of mortality (Figure 75).39,94,313

Figure 75 Association Between Cognitive Impairment and Mortality in Older Persons According to Measurement and Severity (Moderate Level of Evidence)39,94,313

Figure 75 is a forest plot diagram depicting the association between cognitive impairment and mortality in elderly persons depending on measurements and severity (moderate level of evidence from three studies). The plot has two columns. The left-hand column has studies that examined the association between cognitive impairment and mortality in gender categories using different definitions of cognitive impairment. The right-hand column is a plot of relative measures of the association with 95% confidence limits. Means of the effect are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between cognitive impairment and mortality is also plotted. If the confidence intervals for individual studies do not overlap with this line, it demonstrates a significant association between cognitive impairment and mortality. The diamond represents a pooled estimate from random effects model with 95% CI. The Canadian Study of Health and Aging examined different case definitions of mild cognitive impairment and did not demonstrate a significant increase in risk of mortality. Among gender groups, elderly women (pooled RR 1.37, 95% CI 1.11; 1.69) but not men (pooled RR 1.20, 95% CI 0.79; 1.82) with MMSE scores <24 had a significant risk of mortality. Both, elderly men and women with severe cognitive impairment defined as MMSE <18 were at a higher risk of death.

Among sex groups, older women (pooled RR, 1.37 [95% CI, 1.11–1.69]) but not men (pooled RR, 1.2 [95% CI, 0.8–1.8]) with an MMSE score of <24 had a significant risk of mortality (Figure 75).39,94 Both men and women with severe cognitive impairment, defined as an MMSE score of <18, were at a higher risk of death.

Dementia was associated with a significantly higher risk of mortality in the majority of the studies that examined this association (Appendix E Table 31).149 Overall, dementia was associated with a 163 percent relative increase in the odds of death (pooled OR, 2.6 [95% CI, 2.2–3.2]).149 The highest risk of death was found in the North Manhattan Aging Project, among three ethnoracial groups (Latinos, African Americans, and non-Latino whites) with dementia. Several European cohorts, including the Helsinki Aging Study,314 the Longitudinal Gerontological and Geriatric Population Studies in Gothenburg,315 the Swedish Kungsholmen Study,316 the Italian Longitudinal Study on Aging,317 and the Appignano Study318 demonstrated more than a 100 percent relative increase in mortality in older individuals with dementia.

Cognitive impairment was associated with a significant risk of institutionalization in the majority of the studies that examined this association (Appendix E Table 32). For cognitive function measured with MMSE, the association was dose responsive and significant even within the normal ranges of the scale. Older individuals had a higher relative increase in institutionalization of 9 percent per each one-point decrease in MMSE score.145 The magnitude of the association varied substantially across the studies. Studies that reported odds ratios tended to overestimate the magnitude of the association. The Canadian Study of Health and Aging demonstrated that older persons with age-associated memory impairment (OR, 17.5 [95% CI, 14.0–22.0]) or mild cognitive impairment with an MMSE score of <23 (OR, 29.1 [95% CI, 25.1–33.8]) had a substantial increase in the odds of nursing home placement.151 The Asset and Health Dynamics Among the Oldest Old Study demonstrated a smaller but still highly significant risk of institutionalization in older people with mild/moderate (HR, 2.3 [95% CI, 1.8–2.8]) or severe cognitive impairment.319 Older persons with dementia had a significant risk of institutionalization in several large studies, including the Medicare Current Beneficiary Survey (OR, 34.9),150 the Canadian Study of Health and Aging (OR, 36.3),151 and the Marshfield Epidemiologic Study Area (HR, 5.1) (Appendix E Table 32).152 The magnitude of the association was higher in the studies that reported odds ratios rather than relative risk.

Cognitive impairment was associated with a significant risk of hospitalization in one study of three that examined this association (Appendix E Table 33). The MacArthur Research Network on Successful Aging Community Study demonstrated 680 percent higher odds of hospitalization in older people with a decline in the Short Portable Mental Status Questionnaire (OR, 7.8 [95% CI, 2.0–30.8]).320 The Longitudinal Study of Aging137,140 and the Medicare Current Beneficiary Survey321 did not find a significant association between cognitive impairment and dementia.

In conclusion, older individuals with cognitive impairment had a higher risk of mortality and institutionalization. The magnitude of the association varied depending on the country, age, and sex of the participants, definitions of the cognitive impairment, and statistical estimates.

### Frailty

Frailty was associated with cognitive impairment, comorbidities, and disability. The prevalence of frailty demonstrated a dose response association with a larger number of comorbidities or ADL disability (Appendix E Table 34).23,104

Frailty was associated with mortality (Appendix E Table 35). Figure 76 summarizes the overall association between frailty and mortality across a number of varying studies, organized by the general definitional approach to frailty.14,23,111,115,148,153–156 Although there is substantial heterogeneity across the studies, there is a positive relationship. The relationship is stronger when accumulated deficits are employed as the basis for the definition.

Figure 76 Association Between Frailty and Mortality in Older Persons: Effect of the Definition (Moderate Level of Evidence)14,23,111,115,148,153–156

Figure 76 is a forest plot diagram depicting the association between frailty and mortality in elderly persons. This figure shows the effect of the definition on prevalence (moderate level of evidence from nine studies). The plot has two columns. The left-hand column has studies that examined the association between frailty and mortality defining frailty as phenotype or accumulation deficit.. The right-hand column is a plot of relative measures of the association with 95% confidence limits. Means of the effect are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between frailty and mortality is also plotted. If the confidence intervals for individual studies do not overlap with this line, it demonstrates a significant association between frailty and mortality. The diamond represents a pooled estimate from random effects model with 95% CI. The relationship is stronger when accumulated deficits are employed as the basis for the definition. Frail elderly had an increased risk of death by 15% (pooled relative risk 1.15 95% CI 1.10, 1.20) for accumulation deficit definition and by 50% (pooled relative risk 1.50 95% CI 1.05, 2.16) for phenotype definition. Heterogeneity was significant.

The strength of the association was cumulative. Figure 77 uses data from an analysis of the Medicare Current Beneficiary Survey to show that more deficits were associated with a higher risk of bad events.157 Figure 78 shows how increasing numbers of phenotypic frailty components were associated with a greater risk of mortality.14,156 As shown in Figure 79, this effect generally persisted over longer followup periods.23,156 The strongest association between frailty and mortality was demonstrated at 4 years of followup. The relative increase in mortality was less at 11 years but remained significant.

Figure 77 Dose Response Association Between Accumulation Deficits and Mortality or Treatment Utilization Among Medicare Beneficiaries (Good-Quality Study)157

*From the Medicare Current Beneficiary Survey; adjusted for age, sex, race, income, living alone, insurance status, previous emergency department (ED) visits, and previous hospitalizations.

Figure 77 is a forest plot diagram depicting dose response association between accumulation deficits with mortality and treatment utilization among Medicare beneficiaries. This figure presents hazard ratios from the Medicare Current Beneficiary Survey that were adjusted for age, sex, race, income, living alone, insurance status, previous emergency department visits, previous hospitalizations. The plot has two columns. The left-hand column has the number of the detected accumulation deficits and patient outcomes. The right-hand column is a plot of relative measures of the association with 95% confidence limits. Means of the effect are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between frailty and patient outcomes is also plotted. If the confidence intervals for individual studies do not overlap with this line, it demonstrates a significant association between frailty and treatment utilization. This figure demonstrated that more deficits are associated with a higher risk of bad events.

Figure 78 Dose Response Association Between Mortality and Frailty Definitions in Older Persons (Good-Quality Individual Study)14,156

Figure 78 is a forest plot diagram depicting dose response association between mortality and frailty definitions in elderly persons. The plot has two columns. The left-hand column has different definitions of frailty and the number of the detected phenotype criteria. The right-hand column is a plot of relative measures of the association with 95% confidence limits. Means of the effect are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between frailty and mortality is also plotted. If the confidence intervals for individual studies do not overlap with this line, it demonstrates a significant association between frailty and mortality. Figure 78 shows how increasing numbers of phenotypic frailty components are associated with a greater risk of mortality.

Figure 79 Dose Response Association Between Phenotypic Frailty Components and Mortality According to Time of Followup: Results From the Cardiovascular Health Study (Good-Quality Individual Study)23,156

Figure 79 is a forest plot diagram depicting dose response association between phenotypic frailty components and mortality depending on time of followup from the Cardiovascular Health Study. The plot has two columns. The left-hand column has the number of the detected phenotype criteria at 3, 4, 7, and 11 years of followu . The right-hand column is a plot of relative risk with 95% confidence limits. Means of relative risk are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between frailty and mortality is also plotted. If the confidence intervals for individual studies do not overlap with this line, it demonstrates a significant association between frailty and mortality. As shown in Figure 79, the significant positive association generally persists over longer followup periods. The strongest association between frailty and mortality was demonstrated at 4 years of followup. The relative increase in mortality was less at 7 years but remained significant (relative risk 3.47 95% CI 2.55, 4.74 for those with 4 phenotypic criteria of frailty).

The association was significant in men and women. Older frail men had a relatively greater risk of death of 105 to 251 percent, according to the phenotype definition, and 65 to 356 percent according to the accumulation deficit definition (Appendix E Figure 3).113,114,158,159 The dose response association between the increasing value of the frailty accumulation deficit index and mortality was significant in Chinese men ages 80–99 years but random in those ages 65–80 years or older than age 100 years (Appendix E Figure 4).159 Frail older women had increased mortality across different studies and definitions of frailty (Appendix E Figure 5).158–160 The dose response association between the increasing value of the frailty accumulation deficit index and mortality was significant in all age categories of Chinese women (Appendix E Figure 6).159

Frailty was associated with an increased risk of institutionalization (Appendix E Table 36). The magnitude of association was higher in studies of disabled older persons, including the Women’s Health and Aging Studies160 and the Canadian Study of Health and Aging.155 Different frailty criteria were also associated with increased risk of institutionalization in the Precipitating Events Project.147 Slow gait speed and cognitive impairment were the strongest predictors. Frailty was also associated with an increased risk of hospitalization (Appendix E Table 37).14,28,161 The studies demonstrated a 29 percent relative increase in risk161 and a 41–345 percent relative increase in odds of hospitalization.14,161

Two studies examined the association between frailty and emergency department (ED) visits (Appendix E Table 38). The MOBILIZE Boston Study found that the relative increase in odds of ED visits was 210–254 percent in frail older persons compared to nonfrail older persons.109 Secondary analysis of data from the Medicare Current Beneficiary Survey that adjusted for previous ED visits and previous hospitalizations did not find a significant association between frailty and ED visits.157

In conclusion, frail older adults had an increased risk of disability, mortality, and institutionalization. The association was consistent across the studies, persisted with more years of followup, and demonstrated a dose response association with the number of criteria met.

### Disability

#### Disability and hospitalization

The results of studies examining the association between disability and risk of hospitalization are summarized in Table 23. A more detailed accounting of the results appears in Appendix E Table 39. The statistically significant association between disability and hospitalization was demonstrated in four studies (adjusted relative measures of association ranged from 1.8 to 16.0).136,137,162,163 The risk of hospitalization depended on the definition of disability, and in general this risk increased with the severity of disability. Older people who had any BADL disability (defined as having one or more BADL dependencies) had the lowest risk of hospitalization. Older individuals with severe BADL disability (defined as having three or more BADL dependencies) had the highest risk. The risk for women was also greater than the risk for men. The manner in which BADL disability develops appears to influence the risk for hospitalization. Older people who experienced catastrophic severe disability (defined as the sudden onset of three or more BADL disabilities when none existed before) were 16 times more likely to be hospitalized than those who had moderate ADL disability.163 When ADL disability was measured on a continuous scale, the risk for hospitalization was not statistically significant, nor was it significant when it was measured as having any ADL or IADL dependencies.

Table 23 Association Between Disability and Risk of Hospitalization (Moderate-Quality Individual Studies)

Disability Definition | Estimate (95% CI)
Any BADL disability | 1.8 (1.6–2.0)136 2.0 (1.1–3.4)162 3.3 (1.9–5.5)162
Severe BADL disability | Progressive disability^*^ Men: 2.8 (1.6–5.2)163 Women: 3.8 (2.2–4.9)163
Severe BADL disability | Catastrophic disability^**^ Men: 15.8 (9.1–27.5)163 Women: 16.0 (11.1–23)163
BADL disability, continuous variable | 1.31^137^ (NS)
Any IADL disability | 2.5 (1.4–4.5)162
Any IADL/BADL disability | 1.2 (0.8–1.8)140
Other disability definitions | Not physically able^***^ 2.1 (1.2–3.5)162
Other disability definitions | Number of restricted-activity bed days 1.7 (0.86–2.9)133 (NS)
Other disability definitions | Uses cane, walker, wheelchair 1.16^253^ (p=0.006)

NS=statistically nonsignificant result.

* Progressive disability is defined as the development of an additional ADL dependency after having 1–2 ADL disabilities.

** Catastrophic disability is defined as the onset of 3 or more ADL dependencies when none existed before.

*** Physically able is defined as having no difficulty in walking 1/4 of a mile, stooping, crouching or kneeling, lifting 10 pounds, or walking up 10 steps without resting.

Disability measures not measured as ADLs also predicted hospitalization. The greatest risk was a two-fold increase for older people who were not physically able (difficulty in walking 1/4 of a mile; stooping, crouching, or kneeling; lifting 10 pounds; or walking up 10 steps without resting).162

The majority of the studies that examined the association between disability and institutionalization found that disabled elderly adults had a significantly higher risk of placement in nursing homes (Appendix E Table 40).

#### Disability and mortality

Risk of death for older people with BADL disabilities. Several studies reported the odds ratio or hazard ratio associated with different definitions of disability and the risk of death during different time periods (Appendix E Table 41).

Table 24 summarizes the studies that reported these relationships. In general, older people with BADL disabilities were at higher risk for death (OR range, 1.9–86.8) than those with IADL disabilities (OR range, 1.5–6.6) compared to elderly adults without disabilities (Figures 80 and 81). Those with more BADL disabilities had a higher risk of death than those with fewer BADL disabilities (Figure 80). Severe BADL disabilities were associated with the highest risk of death at 72 months (OR, 30.0 [95% CI, 18.0–51.0])128 and 24 months (OR, 86.8 [95% CI, 39.4–190.8]).164 Moderate BADL disabilities were associated with greater odds of death at 72 months (OR, 8.6 [95% CI, 6.6–11.0])128 and 24 months (OR, 14.1 [95% CI, 9.2–21.6]).164 The lowest risk of death occurred when any BADL disability was reported (OR, 1.9 [95% CI, 1.2–2.7]).162 The risk of death associated with individual BADL disabilities was not reported in the studies, with one exception. The risk for death at 48 months doubled for older people with bathing disabilities.53

Table 24 Association Between Disability and Risk of Death (Good-Quality Individual Studies)

Disability Definition | Time to Mortality (Months) | Estimated Subpopulation (95% CI)
BADL disability continuous | 48 | 1.1 (1.04–1.16)329
BADL disability continuous | 6 | 1.4 (NR); p<0.01^127^ – Frail
BADL disability continuous | 1.5 | 1.11 (1.06–1.15)251 – Hospitalized
Any BADL disability | 24 | 1.9 (1.3–2.7)162
Moderate BADL disability | 24 | 14.1 (9.2–21.6)164
Moderate BADL disability | 48 | 2.0 (1.2–3.3)164
Moderate BADL disability | 72 | 8.6 (6.6–11.0)128
Moderate BADL disability | 12 | 2.1 (1.6–2.8)181 – Hospitalized
Severe BADL disability | 24 | 86.8 (39.4–190.8)164
Severe BADL disability | 48 | 3.4 (1.6–7.5)164
Severe BADL disability | 72 | 30.0 (18.0–51.0)128
Severe BADL disability | 96 | 1.13 (1.07–1.19) Hispanic elders266
Dressing | 30 ±19.2 | 1.6 (1.3–2.1) fully dependent184 – Frail
Dressing | 30 ±19.2 | 1.2 (1.0–1.4) partially dependent184 – Frail
Toileting | 30 ±19.2 | 1.3 (1.1–1.5) fully dependent184 – Frail
Walking | 6 | 1.7 (NS)127 – Frail
Bathing | 48 | 2.0 (1.6–2.4)53
IADL continuous | 48 | 1.12 (1.08–1.17)53
IADL continuous | 6 | 0.88 (NS)127 – Frail
Any IADL disability | 24 | 4.14 (3.20–5.36)164
Any IADL disability | 48 | 1.86 (1.4–2.46)164
Any IADL disability | 72 | 6.6 (5.0–8.6)128
Moderate IADL disability | 36 | 1.54 (NR); p=0.05^54^
Moderate IADL disability | 60 | 1.72 (NR); p=0.001^54^
Moderate IADL disability | 120 | 1.62 (NR); p<0.001^54^
Moderate IADL disability | 60 | 1.46 (1.20–1.78)27
Severe IADL disability | 36 | 2.49 (NR); p=0.02^54^
Severe IADL disability | 60 | 1.64 (1.26–2.14)27
Severe IADL disability | 60 | 2.09 (NR); p=0.03^54^
Severe IADL disability | 120 | 2.2 (NR); p=0.001^54^
Meal preparation | 6 | 2.42 (NS)127 – Frail
Medication management | 6 | 1.15 (NS)127
Financial management | 48 | 1.9 (1.6–2.3)53
BADL/IADL continuous | 96 | 1.10 (1.08–1.12)330
Any BADL/IADL disability | Variable death or institutionalization | 1.84 (1.04–3.24)153 – Frail

NS=not significant; NR=not reported.

Figure 80 Different Definitions of Basic ADL Disability and Risk of Death in the General Older Adult Population27,53,54,128,162,164,329,330

Figure 80 is a bar graph reporting different definitions of BADL disability and risk of death in the general older population. The graph contains eight horizontal bars. The y-axis reports the type of BADL disability (for example, severe, moderate, any BADL disability and bathing) and length of followup (72, 48 or 24 months). The x-axis reports the risk of death. Starting at the top of the graph the first horizontal bar shows that the severe disability accounted for a 30 times increase in the risk of death over 72 months. The second bar shows the risk of death was 8.6 for moderate disability over 72 months. The third bar showed a 3.4 increased risk of death over 48 months for severe disability. The fourth bar shows twice the risk for death over 48 months for moderate disability. The fifth bar shows that those with bathing disabilities had twice the risk of death over 48 months. The sixth bar shows that those with severe disability were 86.6 times more likely to die over 24 months. The seventh bar shows that those with moderate disability were 14.1 times more likely to die over 24 months. The eighth bar shows that those with any BADL disability were 1.9 times more likely to die over 24 months. In general, the risk of death range from 1.9 to 86.8. The greatest risk was associated with severe BADL disability and then moderate BADL disability. The length of followup did not appear to influence the risk of death.

Figure 81 Different Definitions of Instrumental ADL Disability and Risk of Death in the General Older Adult Population27,53,54,128,162,164,329,330

Figure 81 is a bar graph reporting different definitions of IADL disability and risk of death in the general older population. The x-axis reports the increased risk for death and the y-axis lists the type of IADL disability (severe, moderate, any, financial) and length of followup (120, 72, 60, 48, 36, 24 months). There are 12 horizontal bars. The top bar reports a 2.2 times increased risk of death for severe IADL disability over 120 months. The second bar shows a 1.6 times increased risk of death for moderate disability over 120 months. The third bar shows a 6.6 times increased risk for death for any IADL disability over 72 months. The fourth and fifth bars show increased risks of 2.09 and 1.6 for severe IADL disability over 60 months. The sixth and seventh bars show increased risk of 1.72 and 1.46 for moderate IADL disability reported over 60 months. The eightth bar shows a 1.9 increase risk for financial management disabilities over 48 months. The ninth bar shows a 1.86 increased risk for any IADL disability over 48 months. The tenth bar shows a 2.49 increased risk for severe disability over 36 months. The eleventh bar shows a 1.54 increased risk for moderate disability over 36 months and the final bar shows an increased risk of 4.14 for any IADL disability over 24 months. The definitions with the highest risk of death were with any IADL disabilty over 72 months (6.6 increased risk) and any IADL disability over 24 months (4.14 increased risk). All the other defintitions and followup times had similar prevalences ranging from 1.46 to 2.49.

Risk of death for older people with IADL disabilities. The risk of death associated with IADL disabilities was highest when any IADL disability was reported. Older adults reporting any IADL disability were 6.6 times more likely to die at 72 months128 and 4.1 times more likely to die at 24 months.164 Those with severe IADL disability had slightly higher odds of death (OR range, 1.6–2.2) than those with moderate IADL disabilities (OR range, 1.5–1.7) (Figure 81). The risk of death associated with individual IADL disabilities was only reported in one study. Those with difficulty managing personal finances were twice as likely to die as those without this disability.53

When disability was measured on a continuous scale, the per one-point increase in disability score and the risk of death were the same whether the scale measured BADL, IADL, or BADL/IADL disability (Figure 82).

Figure 82 Risk of Death per 1-Point Increase in Disability Score27,53,54,128,162,164,329,330

Figure 82 is a bar graph reporting the risk of death per one-unit increase in disability scores. This bar graph contains three horizontal bars. The first bar shows there was a 1.1 unit increased risk for death over 96 months for a continuous measure of disability that combined an index of both basic and instrumental activities of daily living. The second bar shows a 1.1 unit increase in the risk of death over 48 months for a continuous measure of basic activities of daily living. The third bar shows a 1.12 unit increase in the risk of death over 48 months for a continuous measure of instrumental activities of daily living. In general the graph shows a similar increase risk of death associated with a 1-unit increase in continuous measures of BADL and IADL disability.

Difference in risk of death and disability by sex and race. Men with BADL disabilities had slightly higher risks of death than women.64 One study looked at risk disparities in race subgroups of older people with IADL disabilities.119 White men and women who were unable to prepare a meal had higher risks of death than African American men and women with this disability (Figure 83).

Figure 83 Association Between Disability and Mortality in Older Persons in Race and Sex Subgroups (Good-Quality Individual Studies)64,119

LASA=Longitudinal Study on Aging – Amsterdam; EPESE=Established Populations for Epidemiologic Studies of the Elderly.

Figure 83 is a forest plot reporting the association between disability and mortality in gender and race catergories of older persons from good quality studies. The left column groups the studies by disability measure and the right column reports the relative measure of association and 95% confidence intervals. The association with mortality was similar between men and women (1.06 and 1.05 respectively) when ADL disabilities were measured on a continuous scale. The association with mortality was similar between men and women (1.9 and 1.7 respectively) when disability was measured with ADLs and the Rosow-Breslau mobility questionnarie. The association with mortality was also similar between men and women (2.6 and 2.5 respectively) when disability was measured with the Rosow-Breslau ADL measure. Black men had the lowest association with mortality (2.69) when they had a meal preparation disability. The associated risk for white men was 6.53, for white women 6.1, and for black women 5.61. In general the force plot show no gender disparities with the relative association with death.

Life expectancy. One study reported differences in life expectancy by age and sex for older people with and without BADL/IADL disabilities (Figure 84).40 Women suffered greater discrepancies in years of expected active life remaining if they had a BADL/IADL disability. Women age 78 years who have a disability had a 49 percent reduction in expected active life remaining compared to women the same age without a disability; this reduction was 34 percent for women age 65 years, 38 percent for men age 78 years, and 25 percent for men age 65 years.40

Figure 84 Years of Expected Active Life Remaining in Older Persons With and Without Disability: Results From the Baltimore Epidemiologic Catchment Area (Good-Quality Individual Study)40

Vertical axis=years of life.

Figure 84 is a bar graph reporting years of expected active life remaining in older persons with and without disability from a good quality study (the Baltimore Epidemiologic Catchment Area). There are eight vertical bars. The x-axis contains the categories men age 65, men age 78, women age 65, and women age 78. There are two vertical bars above each category. The white bars represent healthy older adults, and the black bars represent those with ADL/IADL limitations. The first bar reports 13 years of expected active life remaining for healthy men age 65, The second bar reports 9.8 years of expected active life remaining for disabiled men age 65. The third bar reports 7.1 years of expected active life remaining for healthy men age 78. The fourth bar reports 4.4 years of expected active life remaining for disabled men age 78. The fifth bar reports 15.2 years of expected active life remaining for healthy women age 65. The sixth bar reports 10 years of expected active life remaining for disabled women age 54. The seventh bar reports 9 years of expected active life remaining for healthy women age 78. The eighth bar reports 4.6 years of expected active life remaining for disabled women age 78. In general the graph shows that older men and women with disabilities have similar years of expected active life remaining, but it is significantly less than those without disabilities.

Summary. In general, older people with the most severe BADL disabilities had the highest risks of death. There is basically no research on how individual BADL and IADL disabilities increase the risk of death. Men with BADL disabilities had slightly higher death rates than women with BADL disabilities. There are few studies reporting race or ethnic differences in death rates among disabled older men and women.

### Sarcopenia

Sarcopenia was associated with significantly higher odds of multiple disabilities.68 The relative increase in odds of having more than three disabilities was 266 percent in older men with sarcopenia and 308 percent in women with sarcopenia.68 The association with impaired lower extremity function depended on the definitions of sarcopenia. A significant increase in the odds of mobility disability was demonstrated among older patients with sarcopenia who were diagnosed using a lean mass index adjusted for fat mass (Appendix E Table 42).123 The unadjusted relative lean mass index was positively associated with mobility disability in men but not in women.123

The association between sarcopenia and mortality was examined in one study (the Invecchiare in Chianti Study).165 Even though older people with greater muscle density had a lower risk of death, sarcopenia was not associated with mortality.165

The association between sarcopenia and hospitalization was examined in one study, the Health ABC Study.322 The study demonstrated a significant positive association between low muscle density (RR, 1.5 [95% CI, 1.2–1.7]) or weak grip strength (RR, 1.5 [95% CI, 1.3–1.8]) and hospitalization. Lean mass or sarcopenia was not associated with hospitalization.322 The authors concluded that poor function and low muscle density are better predictors for treatment utilization in older individuals and should be measured in population-based studies.

In conclusion, limited evidence suggests that sarcopenia was associated with disability but not mortality in older people. Mobility disability and low muscle density may predict hospitalization better than simple lean mass index.

### Malnutrition

The association between mortality and malnutrition was consistent across the studies and different definitions of malnutrition (Figure 85).70,71,83,166–169

Figure 85 Association Between Different Definitions of Malnutrition and Mortality (Good-Quality Individual Studies)70,71,83,166–169,331

Figure 85 is a forest plot diagram depicting the association between different definitions of malnutrition and mortality (eight good quality individual studies). The plot has two columns. The left-hand column lists the studies that examined different definitions of malnutrition including low albumin levels, anemia, and low body mass index, not intentional weight loss of 5% or more, or low scores from the Mini Nutritional Assessment or Nutritional Health Checklist. The right-hand column is a plot of relative measures of the association with 95% confidence limits. Means of the effect are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between malnutrition and mortality is also plotted. If the confidence intervals for individual studies do not overlap with this line, it demonstrates a significant association between malnutrition and mortality. The association between mortality and malnutrition was consistent across the studies and different definitions of malnutrition. Elderly adults with low albumin level had 110% relative increase in mortality (relative risk 2.10 95% CI 1.10, 3.90). Elderly adults with anemia had 33% relative increase in mortality (relative risk 1.33 95% CI 1.15, 1.54). Two studies found that elderly adults with not intentional weight loss had 100% relative increase in mortality. Elderly adults with low score from the Mini Nutritional Assessment had 186% relative increase in mortality (relative risk 2.86 95% CI 1.52, 5.56).

Low BMI166,167 and malnutrition identified using the Mini Nutritional Assessment70 were the strongest predictors for mortality.

In addition, several biological markers related to malnutrition have been shown to be strong and significant predictors of mortality (Appendix E Table 43). Red cell distribution width is typically elevated in older persons with malnutrition, iron deficiency, or vitamin B12 or folate deficiency.79 Meta-analysis of individual subject data from seven community-based studies of 11,827 older adults demonstrated a strong and significant association with mortality in all examined age, sex, and race subgroups.79 Red cell distribution width was associated with mortality in older adults with and without iron, folate, and/or vitamin B12 deficiencies (adjusted HR for a 1 percent increment in RDW, 1.2 [95% CI, 1.1–1.2]), as well as in those without these deficiencies (adjusted HR for a 1 percent increment in RDW, 1.2 [95% CI, 1.2–1.3]).79 Routinely measured as a part of the complete blood count, red cell distribution width >15 percent was associated with a 151 percent relative increase in risk of death (HR, 2.5 [95% CI, 2.2–2.9]).79 Very low albumin levels and very high prealbumin levels (transthyretin >316mg/L or <258mg/L) were associated with increased mortality (Figure 86).167,170 Low albumin level predicted a higher risk of early death in older men but not women (Appendix E Table 44).170 Low vitamin D levels were associated with higher mortality in older women participating in the Women’s Health and Aging Studies241 but not in the Longitudinal Aging Study Amsterdam when men and women were combined in one model.80

Figure 86 Association Between Mortality and Biomarkers of Malnutrition and Inflammation in Older Participants of the Pathologies Oculaires Liées à l'Age Cohort (Good-Quality Individual Study)170

Figure 86 is a forest plot diagram depicting the association between mortality and biomarkers of malnutrition and inflammation in elderly participants of the Pathologies Oculaires Liées à l’Age cohort (POLA). The plot has two columns. The left-hand column lists the definitions of malnutrition including low albumin level, increased alpha 1-acid glycoprotein and decreased transthyretin levels in categories of gender and length of followup. The right-hand column is a plot of hazard ratios with 95% confidence limits. Means of the effect are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between malnutrition and mortality is also plotted. If the confidence intervals for individual studies do not overlap with this line, it demonstrates a significant association between malnutrition and mortality. Very low albumin levels in men was associated with increased risk of death (hazard ratio 2.72 95% CI 1.44, 5.14). Elderly men (hazard ratio 6.86 95% CI 3.20, 14.71) and women (hazard ratio 4.64 95% CI 1.79, 12.05) with increased alpha 1-acid glycoprotein and reduced transthyretin levels had greater risk of death.

Several studies analyzed composite measures of malnutrition and chronic inflammation in older people and found a significant positive association with mortality. For instance, elevated levels of inflammatory globulin, orosomucoid (alpha-1-acid glycoprotein), was associated with increased mortality.167 The relative increase in mortality was 126 percent in older men and 161 percent in women (Appendix E Table 44).170 Elevated alpha-1-acid glycoprotein levels predicted followup mortality of 5 years, but not longer (Figure 86).170 Older people with the highest levels of alpha-1-acid glycoprotein and the lowest levels of transthyretin had the highest risk of death, with a 364 percent relative increase in women and 586 percent relative increase in men (Appendix E Table 44).170 An elevated composite measure of chronic inflammation and poor nutrition was associated with increased risk of death in older men but not women (Figure 87).170

Figure 87 Association Between the Prognostic Inflammatory and Nutritional Index* and Mortality in Older Participants of the Pathologies Oculaires Liées à l'Age Cohort (Good-Quality Individual Study)170

*The Prognostic Inflammatory and Nutritional Index is defined as (C-reactive protein * alpha 1-acid glycoprotein)/(albumin * transthyretin).

Figure 87 is a forest plot diagram depicting the association between the prognostic inflammatory and nutritional index and mortality in elderly participants of the Pathologies Oculaires Liées à l'Age cohort (POLA). The prognostic inflammatory and nutritional index (PINI) was defined as (high sensitive C Reactive Protein multiplied by alpha 1-acid glycoprotein) and divided by (albumin multiplied by transthyretin). The plot has two columns. The left-hand column lists the definitions of the diagnostic categories of prognostic inflammatory and nutritional index in gender subgroups during different length of followup. The right-hand column is a plot of hazard ratios with 95% confidence limits. Means of the effects are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between prognostic inflammatory and nutritional index and mortality is also plotted. If the confidence intervals for individual studies do not overlap with this line, it demonstrates a significant association between prognostic inflammatory and nutritional index and mortality. Elderly men with prognostic inflammatory and nutritional index >0.27 vs. 0.05–0.27 had greater risk of death (hazard ratio 2.50 95% CI 1.44, 4.36). The association was not significant for women.

Women with nutritional deficit or multiple definitions of malnutrition, however, had a higher prevalence of frailty (Figure 88).238 The evidence about treatment utilization in older people with malnutrition is limited to one study of domiciliary care services for older people with moderate or severe functional limitations that found an increased risk of ED admissions and hospitalizations in those with undernutrition and malnutrition (Appendix E Table 43).83

Figure 88 Association Between Nutritional and Metabolic Abnormalities and Frailty in Older Women: Results From the Women’s Health and Aging Studies I and II (Good-Quality Individual Studies)238

Figure 88 is a forest plot diagram depicting the association between nutritional and metabolic abnormalities and frailty in elderly women (results from the Women’s Health and Aging Studies I and II). The plot has two columns. The left-hand column lists the definitions of the nutritional and metabolic abnormalities including anemia; inflammation; endocrine; micronutrient; body composition; fine motor speed, lower dehydroepiandrosterone sulfate levels, or nutritional deficit. The right-hand column is a plot of relative measures of the association with 95% confidence limits. Means of the effects are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between nutritional and metabolic abnormalities and frailty is also plotted. If the confidence intervals for individual studies do not overlap with this line, it demonstrates a significant association between nutritional and metabolic abnormalities and frailty. Elderly women with abnormal levels in >5 physiological measures had increased risk of frailty (relative risk 26.00 95% CI 3.70, 183.30) .Elderly women with >2 nutritional deficits had increased risk of frailty (relative risk 2.60 95% CI 1.30, 5.00).

In conclusion, low BMI, nutritional risk identified with the Mini Nutritional Assessment, and increased red cell distribution width were strong and consistent predictors of mortality in older individuals. Other biomarkers and their combinations need further examination.

### Homeostenosis (Impaired Homeostasis)

The association of impaired homeostasis with clinical outcomes varied depending on the definitions of the exposure and study populations (Appendix E Table 44). Older women with increased allostatic load had significantly greater odds of frailty (OR, 1.2 [95% CI, 1.0–1.3]), with a 16 percent relative increase per each one-point increase in score in the Women’s Health and Aging Studies.89 Older persons with high plasma tonicity had a significantly higher risk of impaired ADLs (RR, 2.7 [95% CI, 1.3–5.6]), impaired IADLs (RR, 2.3 [95% CI, 1.2–4.3]), and overall disability (RR, 2.1 [95% CI, 1.2–3.6]) in the Duke Established Populations for Epidemiologic Studies of the Elderly.46

The association between mortality and homeostenosis was examined in several studies that used different definitions of homeostenosis (Appendix E Table 44). Unstable BMI (HR, 1.3 [95% CI, 1.0–1.8]), pulse pressure (HR, 1.3 [95% CI, 1.0–1.7]), and fasting plasma glucose (HR, 1.6 [95% CI, 1.2–2.1]) were associated with greater risk of mortality in an older Italian cohort.171 The MacArthur Studies of Successful Aging demonstrated a significant association between increased allostatic load and mortality.124,172,173 The same study found a 27 percent relative increase in odds of death (OR, 1.3 [95% CI, 1.0–1.5]) in older people with an elevated stress hormone index.124 The Invecchiare in Chianti Study demonstrated a relative increase of death of 472 percent in older people with elevated free estrogen levels (OR, 5.7 [95% CI, 1.7–19.4]).323

In conclusion, individual studies demonstrated a significant association between disability, mortality, and indicators of impaired homeostasis in elderly people. Consensus operational definition of homeostenosis and its biomarkers is necessary for better interpretation of the results.

### Chronic Inflammation

The studies consistently found positive significant association between chronic inflammation and disability and mortality, despite different markers of inflammation and study populations. Older people with three elevated markers of chronic inflammation had increased odds of cognitive decline (OR, 1.5 [95% CI, 1.0–2.3]) (Appendix E Figure 7).324 The Framingham study demonstrated decreasing brain volume among elderly individuals with elevated markers of chronic inflammation.234 Older individuals with increased levels of IL6 (OR, 3.7 [95% CI, 1.9–6.9]) or CRP (OR, 1.9 [95% CI, 1.1–3.4]) had significantly higher odds of sarcopenia (Appendix E Figure 8).325 The highest relative increase in odds of sarcopenia of 627 percent was demonstrated among those with elevated IL6 and alpha 1-antichymotrypsin.325 Older women with elevated IL6 and decreased insulin-like growth factor had increased odds of disability in ADLs (OR, 2.5 [95% CI, 1.0–6.3]) and IADLs (OR, 3.7 [95% CI, 1.1–12.2]) (Appendix E Figure 9).239 Older women with elevated IL6 had increased odds of frailty (OR, 2.0 [95% CI, 1.1–3.6]) (Appendix E Figure 10).238,244

The association between chronic inflammation and mortality differed across the studies depending on the markers and populations. Older women with elevated levels of two markers, IL6 and CRP, did not have a higher risk of death in a pooled analysis among women (Appendix E Figure 11).124,174,219,220 However, older men with chronic inflammation had a higher risk of death (RR, 2.8 [95% CI, 1.4–5.5]).174 A composite inflammatory index was not associated with mortality in the MacArthur Studies of Successful Aging and in the Leiden 85-Plus Study (Appendix E Figure 12).124,219 Only older people with low levels of proinflammatory markers (IL-1Ra) and anti-inflammatory markers (IL10) had higher risk of death (RR, 2.2 [95% CI, 1.3–3.8]).219

Among common definitions of chronic inflammation, elevated IL6 and CRP were associated with higher mortality in older people. Elderly individuals with elevated IL6 levels had a 42 percent relative increase in death (pooled RR, 1.4 [95% CI, 1.2–1.7]) (Figure 89).124,174–177 Older people with elevated CRP had a 42 percent relative increase in death (pooled RR, 1.4 [95% CI, 1.3–1.6]) (Figure 90).87,124,129,166,167,170,174,177–179

Figure 89 Association Between Increased Interleukin-6 and Mortality in Older Persons (High Level of Evidence)124,174–177

Figure 89 is a forest plot diagram depicting the association between increased Interleukin 6 and mortality in elderly individuals (high level of evidence from five studies). The plot has two columns. The left-hand column lists the studies that examined increased levels of Interleukin 6. The right-hand column is a plot of relative measures of the association with 95% confidence limits. Means of the effect are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between increased Interleukin 6 and mortality is also plotted. If the confidence intervals for individual studies do not overlap with this line, it demonstrates a significant association between increased Interleukin 6 and mortality. The diamond represents a pooled estimate from random effects model with 95% CI. Elderly adults with increased Interleukin 6 had a greater risk of death (pooled relative risk 1.42 95% CI 1.16, 1.74). Heterogeneity was not significant. Elderly adults with increased Interleukin 6 had a greater risk of death with a dose response increase in mortality by 12% (pooled relative risk 1.12 95% CI 0.92, 1.36) corresponding to an increase in Interleukin 6 in logarithmic scale. Heterogeneity was not significant.

Figure 90 Association Between Elevated Levels of C-Reactive Protein and Mortality in Older Persons (High Level of Evidence)87,124,129,166,167,170,174,177–179

Figure 90 is a forest plot diagram depicting the association between elevated levels of C-reactive protein and mortality in elderly individuals (high level of evidence from 10 studies). The plot has two columns. The left-hand column lists the studies that examined increased levels of C-reactive protein in gender categories. The right-hand column is a plot of relative measures of the association with 95% confidence limits. Means of the effect are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between increased C-reactive protein and mortality is also plotted. If the confidence intervals for individual studies do not overlap with this line, it demonstrates a significant association between increased C-reactive protein and mortality. The diamond represents a pooled estimate from random effects model with 95% CI. Elderly adults with elevated levels of C-reactive protein had a greater risk of death (pooled relative risk 1.42 95% CI 1.29, 1.55). Heterogeneity was not significant. Elderly men with elevated levels of C-reactive protein had greater risk of death (pooled relative risk 1.61 95% CI 1.19, 2.19). Heterogeneity was not significant. The association was not significant for elderly women.

The association differed among men and women. Elevated IL6 was associated with increased mortality in women but not men (Appendix E Figure 13).166,174,239 In contrast, elevated CRP was associated with increased mortality in men (pooled RR, 1.6 [95% CI, 1.2–2.2]) but not women (pooled RR, 1.1 [95% CI, 0.8–1.7]) (Figure 90).87,124,166,167,170,174,176,177,202

The studies reported different times of followup to analyze the association between mortality and different cut-off points for elevated CRP (Appendix E Table 45). The association attenuated with longer time of followup in CHS.178 Older men with elevated CRP had a 300 percent relative increase in early 3-year mortality (HR, 4.1 [95% CI, 2.7–6.3]) but only a 42 percent relative increase in 8-year mortality (HR, 1.4 [95% CI, 1.1–1.8]).178 Older women with elevated CRP had a 134 percent relative increase in 3-year mortality (HR, 2.3 [95% CI, 1.4–3.9]) and no significant association at 8 years of followup (HR, 1.2 [95% CI, 0.9–1.7]). The attenuation during longer followup was not evident when the association was compared at 5 and 9 years of followup in the Pathologies Oculaires Liées à l’Age Study.170 Older men with elevated CRP had a significantly higher risk of death at 5 and 9 years while women did not.170 One cohort (the Invecchiare in Chianti Study) demonstrated that an increase in CRP during the time of followup was the best predictor of mortality when compared to baseline or followup absolute CRP levels.177 In a study in which CRP increased during followup, older subjects had a 210 percent relative increase in mortality (HR, 3.1 [95% CI, 1.3–7.7]).177 Meta-regression analyses did not find a significant modification in association by the time of followup across all studies.

The studies reported different cut-off points for elevated CRP (Appendix E Table 45). The studies categorized older people by a single cut-off point for CRP, ranging from 3 mg/L87,174,177 to 15 mg/L.167 CHS178 and the Iowa 65+ Rural Health Study174 analyzed mortality in quartiles, while the Vitality 90+ Study179 and the Women’s Health and Aging Study 166 analyzed mortality in tertiles of CRP levels. All studies reported a greater risk of death in larger categories of CRP. Few studies analyzed the dose response association between CRP levels and mortality. The Helsinki Ageing Study found a 20 percent increase in death per 10 mg/L increase in CRP.326 The Danish Centenarian Study found a significant 26 percent increase in mortality (crude HR, 1.3 [95% CI, 1.0–1.5]) per increase in 1 standard deviation of CRP levels in logarithmic scales.176 Meta-regression analyses did not find a significant modification in association by cut-off point of CRP across all studies.

Individual studies reported other markers of chronic inflammation. Among them, elevated levels of tumor necrosis factor-alpha,176 D-dimer,175 fibrinogen,178 and IL1 receptor antagonist179 levels were associated with mortality (Appendix E Table 46). The strongest association with mortality was demonstrated for elevated CRP combined with low albumin (HR, 5.0 [95% CI, 2.3–11.0])170 or elevated fibrinogen levels (HR, 9.6 [95% CI, 4.3–21.1]).178 Significant association was found for early mortality and in men.

We could not find studies that examined the association between chronic inflammation and institutionalization or hospitalization.

In conclusion, chronic inflammation was associated with increased risk of frailty, disability, and mortality in older people. The risk was higher for early mortality and attenuated during longer time of followup. The risk was dose responsive for IL6 and CRP. The association was consistent for men but not for women. The strongest predictor of early mortality was elevated CRP combined with low albumin or increased fibrinogen.

## Key Question 4 What Statistical and Decisionmaking Models Report Mortality Based on These Common Geriatric Syndromes/Conditions?

Models reporting mortality vary by complexity, by selection of predictors, and by time course. Some models strive for simplicity, with few predictors that are easily measured, much or all of which could be gained by culling administrative data. Others are much more complex, with data gathered from clinician and/or patient assessments. While a simpler approach is more appealing from a cost and operational perspective, the question remains as to the marginal benefit of more complex models. The basic relationship holds regardless of the measure used.

To provide an overview of overall effects of different syndromes on mortality in adults older than age 65 years, we estimated the number of deaths per 1,000 older persons from individual studies that provided death rates among those with and without different syndromes (Table 1). We estimated that among frail older persons, 459 older persons per 1,000 died within 1–2 years of followup.182,187

Within 3 years, 500–600 older persons with malnutrition, 351 with cognitive impairment, and 534 with severe dementia died per 1,000.^189,197,198^ Disability in basic ADLs and IADLs were associated with the highest risk of mortality.196

Within 5 years, 490 older persons with malnutrition, 513 with frailty, 530 with elevated CRP, and 827–941 with vascular dementia died per 1,000.^70,91,141,186^ Frailty and cognitive impairment were associated with 400–800 deaths per 1,000 during more than 5 years of followup.23,148,199 Such estimations may not reflect mortality in age, sex, or race subgroups but demonstrate a burden of geriatric syndromes.

We also estimated population risk of mortality attributable to geriatric syndromes (Table 2). When population prevalence and multivariate adjusted relative risks were taken into account, more than 7 percent of deaths were attributable to multiple morbidities and elevated CRP. We estimated that 3–5 percent of deaths among elderly persons could be delayed if frailty was prevented. Prevention of mild cognitive impairment could result in delaying 5–6 percent of deaths among elderly persons. Overall, around 26 percent of deaths in elderly persons can be attributed to geriatric syndromes. Conversely, having the syndrome may affect the likelihood of benefitting from other interventions, such as prevention.

The prevalence and risk of mortality and institutionalization were almost inversely related. The prevalence of accumulation deficit frailty (which uses many components) was higher than phenotype frailty (which uses only a few components). The relative risk of mortality and institutionalization was higher for phenotype frailty (Figure 1). The same negative association was seen for more severe forms of the same syndrome. Prevalence of severe cognitive impairment and dementia were lower, but risk of mortality was higher when compared to mild cognitive impairment (Figure 2). A negative association between the prevalence of a syndrome and its effect on mortality was evident across those syndromes in which the more restricted definition defines a more severe state (Figure 3).

The remaining life expectancy of individuals with syndromes was estimated using the CDC United States Life Tables and the relative risk of death from pooled analyses and individual studies. Increased levels of allostatic load (impaired homeostasis) and dementia were associated with the lowest survival among older persons when compared to the general population in the United States. The data shown in Figure 4 represent a merger of several data sets to yield general trends. The influence on survival of some factors was much greater than others when we compared them across studies. Poor health, malnutrition, and allostatic load (impaired homeostasis) exerted twice the influence of factors such as comorbidity and frailty. Since not a single study measured and compared all syndromes in association with mortality, indirect comparisons may be erroneous. The size of the effect differed by age (and thus expected life expectancy) (Table 3). For the purposes of informing prevention decisions, relative risk is likely more useful than population attributable risk. In the young-old, ages 65–74 years, only the very few who were very ill or frail (e.g., homeostenosis, poor health, or advanced dementia) suffered significant alterations in predicted life expectancy. From ages 75–90 years there was maximal heterogeneity of disease and geriatric syndromic states, resulting in larger mortality deviations from unafflicted individuals than in other age groups. In the old-old, particularly past age 90 years, the added value of factoring in conditions and syndromes to predict mortality beyond 1 year was minimal.

### Statistical Models

We found 28 studies that described prognostic indices that report mortality in elderly people. Since previous indices are complex, time consuming, or have a lack of clinical applicability, recent studies have been designed to develop and validate easy-to-use indices using information readily available from administrative data, laboratory data, diagnoses, or self-reported health status data (Appendix E Table 47). Some indices were created for certain segments of the population (e.g., hospitalized elderly,26,180–183 community dwellers,4,23,27,148,155,184–188 or older people with acquired mental disorders).189 Others have been developed with the use of nationally representative samples.53,186,187,190 Most studies have been conducted in the U.S. population ages 50 years and older, but a few have been done in European countries14,134,180,189,191,192 and Canada.155,193,194

To assess the predictive accuracy of the final logistic model used to derive the frailty index, calibration (i.e., the degree of similarity between predicted and actual risk) and discrimination (i.e., the ability of a risk score to correctly assign a higher mortality risk value to a person who died than to one who survived) were largely evaluated in many models (Appendix E Table 48).4,24,26,27,53,114,134,155,181,182,184,187,193 The point scoring system created in the development (or derivation) cohort was applied to the validation cohort to determine risk scores for all of the population in the validation cohort. Then, the mean predicted mortality from the development cohort and the observed mortality in the validation cohort were compared in each quartile, quintile, or other groups of risk score. To determine the discrimination of the index, the area under the receiver operating characteristic curve (AUC) was calculated in both cohorts and compared. In general, studies chose to report number of deaths versus number at risk and AUC for both cohorts.4,26,27,53,134,181,182,184,187 Validation procedures and results were not reported in the articles in a consistent manner. Variability in design, validation, and reporting of the models hampered comparison to conclude which models are better than others. The studies did not validate predictive models against actual life expectancies in the general population of older adults.

We believe that there are at least four areas to consider when evaluating prognostic instruments: simplicity, geriatric syndromes or disease approach, frailty or mortality indices, and short- or long-term estimate of the risk of mortality. We recognize an overlap between different categories of models.

Simplicity of the models. In simple models, all the variables should be either readily available or straightforward to measure (without the aid of any instrument) or found in medical records (Appendix E Table 49). The scoring system should be easy to follow and reproduce in clinical settings. Unless complex indices can be hard-wired into an electronic medical record, clinicians are unlikely to use them.

Some of the models were complex in terms of the number of index components, measurement of each component, weight method, and design of risk scoring systems.27,180,186,190,191,193 These indices are time consuming and rely heavily on availability of clinical data or the clinician’s experience. Therefore, they are not easy to use and are of limited clinical use, but they can be useful for research purposes (Appendix E Table 50).

Diseases versus geriatric syndromes. In an attempt to evaluate the added benefit of incorporating more functional and multidimensional predictors, we calculated the relative risk and attributable risk of different syndromes on mortality (Table 2). Some of the indices were oriented toward diseases as predictors, and some incorporated more geriatric principles such as geriatric syndromes and functionality. While disease-oriented methods are more pragmatic and easy to capture with administrative data, more gerocentric indices are more conceptually appealing and do appear to add predictive value.

Frailty or mortality indices. Among geriatric syndromes, frailty was examined to predict mortality with different composite indices. Fried et al23 considers frailty as a unique clinical syndrome that differs from comorbidity or disability. According to Fried, an individual who is frail presents three of the following criteria: unintentional weight loss (10 pounds in past year), self-reported exhaustion, weakness (grip strength), slow walking speed, and low physical activity. Quite a few studies followed this approach, either adopting or improving their indices based upon Fried’s model (Appendix E Table 51).14,23,24,109,114,148,183,188

The other widely accepted approach considers frailty as the accumulation of symptoms, diseases, and disabilities and combines all of them in one frailty index score (Appendix E Table 52).4,26,27,53,155,180–182,184,186,187,189–191,193,194,332

Short- or long-term mortality risk. Some of the indices were validated using a continuous mortality outcome variable, while others used categorical variables. Published models offer a range of 1–10 years for mortality prediction. Selection of how far one wants to assess mortality risk varies by clinical and policy considerations. A 1-year mortality risk would be important for revisiting patient preferences for care at the end of life (Appendix E Table 53). An assessment of 3-year mortality could be useful for health care providers in heightening awareness of the transition from a chronic disease to a frail state, and for patients in estate planning and putting other affairs in order. Five-year mortality risk is an important consideration for decisions regarding cancer screening, given that many cancer screening tests require 5 or more years to realize a benefit (Appendix E Table 54).181 Whereas 6- to 10-year mortality risk might be useful for policy issues, shorter time spans are much more useful for individual patient care.

A few summary statements are possible:

- Simple disease-based measures, such as number of comorbid illnesses or measures of inflammation, add modestly to the relative risk of mortality but account for more population-based mortality burden due to their high prevalence.
- Advanced dementia is one specific condition that confers significantly added mortality risk.
- More complex syndromic measures, such as those assessing frailty or incorporating functional status (e.g., allostatic load), better capture increased mortality risk (indicated by higher relative risk) than simpler measures, as they more selectively identify the relatively few (indicated by lower population attributable risk) sickest patients most likely to experience deterioration in health and death.
- Simpler measures that reflect the severity of individual diseases, such as indicators of advanced dementia, or the overall impact of multiple conditions, such as assessments of overall health, also identify the fewer and sicker patients at higher risk of mortality.

In conclusion, complex mortality models added comparatively little understanding to more simply measured and calculated models. Measures of the impact of conditions and syndromes on overall health and functioning provided greater discrimination among individual patients for assessing mortality risk. Mortality predictors appeared to be relatively consistent across short- and long-range models. The greatest added advantage of mortality models over simple remaining life expectancy was observed among patients ages 75–90 years. Decisionmaking models that are based on various assumptions and simulation techniques need careful sensitivity analysis and validation.