# Evidence Tables

Appendix E Table 1 Epidemiologic Studies in Older Persons

Study, Reference | Country Quality | Sample Size | Oversampling | Minority Present | Inclusion Age | Inclusion | Exclusion | Women Included | Nursing Home Residents
Aging, Demographics, and Memory Study(ADAMS) sample from the Health and Retirement Study1 | USA good | 856 | No | Yes | >71 | Drawn from the larger HRS(Health and Retirement Study) | Not reported | Yes | No
AHEAD-Survey of Asset and Health Dynamics of the Oldest Old (AHEAD)2 | USA good | 7,447 | No | Yes | >70 | Older Americans who resided in the community at the time of the baseline interview | Under age 70, who did not fall into Black or White racial categories, and who responded that they did not perform an ADL or had missing information for any of the covariates used in this analysis | Yes | No
American Community Survey (US Census)3,4 | USA good | 202,956 | American Indian/AlaskaNative/NativeAmericans are oversampled | Yes | >55 | Community-dwelling Americans | Nursing home residents | Yes | No
Baltimore Epidemiologic Catchment Area Program5 | USA good | 3,481 | No | Yes | >18 | Persons aged 18 years and older in Baltimore | Not reported | Yes | No
Beaver Dam Eye Study cohort6 | USA good | 2,515 | No | Not reported | >53 | Adults 43–86 years of age living in Beaver Dam, Wisconsin | Deaths within one year of examination | Yes | No
Census Public Use 5% Microdata sample7 | USA Census | 2,944,755 | No | Yes | >55 | Representative sample of housing units and their residents as well as individuals living in group quarters. The sample is a stratified subsample drawn from the full Census enumeration; housing units and individuals were randomly selected to receive the long form questionnaire. | Nursing home residents | Yes | No
Duke Established Populations for Epidemiologic Studies of the Elderly, 1992; Third In-Person Survey Wilson, 2003 #1390}8,9 | USA good | 1,752 | No | Yes | >65 | 65 years or older who were selected in a random household sample of a five-county area including and adjacent to Durham, North Carolina, in 1986. Blacks were oversampled to allow for comparison by race | Disability at baseline, did not give blood to study in 1992 | Yes | No
EPESE Established Populations for Epidemiologic Studies of the Elderly -East Boston & New Haven Communities10–17 | USA good | 6,640 | No | Not reported | >65 | Community-living persons aged 65 years or older living in East Boston, 2 Iowa communities, New Haven, Connecticut | Not reported | Yes | No
Freedom House Study18 | USA good | 546 and 242 in analysis | No | Yes | >70 | Initially non- institutionalized elderly CCRC (Continuing-Care Retirement Community) residents over the age of 70. CLOX was introduced in the second FHS wave and collected on 242 residents and these form the basis of the analysis’ | No exclusions | Yes | No
Kaiser Permanente Inter-regional Committee on Aging Study19 | USA good | 5,810 | No | Not reported | >65 | The study population was drawn from the 1990 HSF (Health Status Form) respondents. | Nursing home residents | Yes | No
MacArthur Research Network on Successful Aging Community Study20 | USA good | 598 | No | Yes | >65 | Men and women were subsampled on the basis of age (70–79) and physical and cognitive functioning at the time of their 1988 EPESE interview, a score of 6 or more correct on the 9-point Pfeiffer Short Portable Mental-Status Questionnaire (SPMSQ), the ability to remember three or more of six elements of a delayed recall of a short story, no disability on the Katz activities of daily living scale, no more than one disability on an eight-item measure of gross mobility and physical performance based on items from two studies, the ability to maintain a semi- tandem balance for at least 10 seconds, and the ability to stand from a seated position five times within 20 seconds, agreed to participate in the MacArthur study and provided informed consent | Medicare data were not available | Yes | No
MacArthur Studies of Successful Aging20–25 | USA | 657 | No | Not reported | >70 | High functioning men and women, aged 70–79 years community- based cohorts in Durham, NC, East Boston, MA, and New Haven, CT that were part of the Established Populations for Epidemiological Studies of the Elderly (EPESE). | Not reported | Yes | No
MOBILIZE26,27 | USA good | 765 | No | Yes | >70 | Aged 70 and older, ability to speak and understand English, ability to walk across a room, visual ability to read written material, and the expectation that the participant would be living in the area for at least 3 years | | Yes | No
MROS - Osteoporotic Fractures in Men Study28,29 | USA good | | No | Not reported | >65 | Men must be able to provide consent; be able to walk without assistance from another person or aid; be age 65 years and older; and not have had bilateral hip replacements. | Not reported | No | No
National Long- Term Care Survey30 | USA good | 17,658 | No | Yes | >65 | People >65 years of age drawn from national Medicare enrollment files. Both elderly in the community (including those not impaired) and those residing in institutions are represented in the samples | Not reported | Yes | Yes
National Survey on Self- Care and Aging31 | USA good | 3,485 | Oversampling of the oldest old and males | Yes | >65 | Community dwelling Medicare beneficiaries who were 65 years of age or older in 1990. | Not reported | Yes | No
Precipitating Events Project32–44 | USA good | 754 | Persons who were physically frail were oversampled | Yes | >70 | Members of an ongoing longitudinal study of 754 community-dwelling persons, aged 70 years or older, who were initially nondisabled in four key ADLs—bathing, dressing, walking inside the house, and transferring from a chair. Potential participants were members of a large health plan in greater New Haven, Connecticut. | Life expectancy of less than 12 months, planned to move out of the New Haven area, or were unable to speak English. Participants with significant cognitive impairment were excluded only if they had no available proxy. | Yes | No
NHANES III (National Health and Nutrition Examination Survey III) 45,46 | USA good | 4,617 | African American/Mexican American/Persons aged 60+,etc. | Yes | >60 | Respondents aged ≥60 years who completed both the AHS(Adult Household Survey) and MEC(Mobile Examination Center) | Self-reported history of stroke. | Yes | No
Norwood - Montefiore Aging Study(NMAS) 47 | USA good | 1,855 | No | Yes | >65 | At least 65 years of age, randomly selected from a list of Medicare beneficiaries living in a neighborhood in the Bronx. | Not reported | Yes | No
SITE Sources of Independence in the Elderly48 | USA good | 361 | No | Yes | >70 | Mild to moderate disability, as defined by self-reported difficulty with at least one but no more than three of four different domains of function: upper extremity, lower extremity, instrumental activities of daily living (IADL), or basic activities of daily living (BADL). | Those meeting criteria for depression or dementia, reported impairment in vision as a source of disability, were residing in a skilled nursing facility, were receiving hospice services, required a wheelchair for indoor mobility, or planned to move out of the community within the year. | Yes | No
Study of osteoporotic fractures49–51 | USA good | 6,724 | No | No | >65 | Women at least 65 years old from population-based listings in four areas of the United States | Black women were originally excluded from SOF because of their low incidence of hip fracture. In addition, women were excluded if they were unable to walk without assistance or had a history of bilateral hip replacement. | Yes | No
The 90+Study52 | USA good | 227 | No | Not reported | >90 | People aged 90 years and older. Cognitive diagnosis of no dementia (normal or CIND) from an in-person examination, serum CRP measurement from baseline examination, and cognitive diagnosis obtained at a followup in-person examination. | Subjects with less than one year of follow-up time were excluded | Yes | No
The Bronx Aging Study53 | USA good | 488 | No | Yes | >75 | Healthy, nondemented, community-dwelling individuals aged 75–85 years | Previous diagnoses of idiopathic Parkinson’s disease, liver disease, alcoholism, or known terminal illness; severe visual and hearing impairment interfering with completion of neuropsychological tests; and the presence of dementia. | Yes | No
The Cardiovascular Health Study54–64 | USA good | 5,888 | Supplemental African- American cohort recruited | Yes | >65 | Potential participants were identified from a random sample stratified by age group (65–74, 75–84,>=85 years) from the Health Care Financing Administration (HCFA) Medicare Enrollment lists in 4 U.S. communities (Sacramento County, California; Washington County, Maryland, Forsyth County, North Carolina; and Allegheny County, (Pittsburgh), Pennsylvania); willing to reside in the community for at least 3 years. | Wheel-chair bound in the home, unable to participate in the examination at the field center, or undergoing active treatment for cancer. | Yes | No
The Cache County Study on Memory in Aging65 | USA good | 4683 | No | Yes | >=65 years | All elderly residents aged 65 and older of Cache County, Utah. | Those who did not complete procedures sufficient for definitive classification or because they had developed dementia at a subsequent visit and may thus have had prodromal dementia when enrolled. | Yes | Yes
The Chicago Health and Aging Project66t | USA good | 4,392 | | Yes | >65 | All households in a geographically defined area on the south side of Chicago; persons aged 65 years and older | Not reported
The Framingham Offspring Study67 | USA good | 1,926 | No | Not reported | >35 | Not reported | Neurologic condition that could substantively alter brain MRI measures | Yes | No
The Geisinger Rural Aging Study (GRAS) 68 | USA good | 179 | No | Not reported | >65 | Rural Pennsylvanians aged 65 and older enrolled in a managed- risk Medicare program at Geisinger Health System. | Six were excluded because of depression, two as BMI outliers, and one because of poor cognitive function | Yes | No
The General Medicine Practice of the Regenstrief Health Center69 | USA fair | 3,861 | No | Yes | >60 | All patients aged 60 and older were screened for cognitive impairment, depression, and problem drinking during their regularly scheduled visits | Prisoners, patients residing in a nursing home, patients unable to speak English, and patients who had hearing impairment | Yes | No
The Geriatric Evaluation and Management( GEM) 70 | USA poor | | No | Yes | 78.4 | Approximately 20% of subjects were physician- referred to the GEM clinic. An additional 22% were referred by either a social agency, home health service, or day care program. The remaining individuals were referred by family members who had heard about the program via word of mouth, brochures, or newspaper articles. Individuals with one or more of the following concerns were scheduled for evaluation: memory loss, depression, behavioral problems, paranoia, functional decline, weight loss, falls, incontinence, and concerns about overall health and safety. | Not reported | Yes | No
The Health and Retirement Study71,72 | USA good | 11,701 | No | Yes | >50 | Community dwelling adults aged 50 and older, representative of entire US | Nursing home residents | Yes | No
The Health, Aging and Body Composition(Health ABC) Study73–79 | USA good | 3,075(analytic sample:2984) | No | Yes | >70 | 3075 well-functioning men and women aged 70 to 79 recruited from a random sample of Medicare enrollees in Pittsburgh, Pennsylvania, and Memphis, Tennessee. Eligible participants had self-reported no difficulty walking one- quarter of a mile, climbing 10 steps, and performing activities of daily living (ADL); did not report a walking aid; and were free of cancer under active treatment. Analysis was conducted on 2984 participants who had complete data on body composition and physical function. | Not reported | Yes | No
The Honolulu-Asia Aging Study of the Honolulu Heart Program80,81 | USA good | 1,890(analytic sample) | No | Yes | >77 | Japanese and American men, identified from selective service records, who were born between 1900 and 1919 and were living on the island of Oahu, Hawaii, in 1965. | Not reported | No | No
The Iowa 65+ Rural Health Study82 | USA good | 1,293 | No | Not reported | >65 | Healthy, nondisabled elderly | 647 persons who needed help walking a half mile, climbing a flight of steps, moving from bed to chair, using a toilet, bathing, or walking across a small room. | Yes | No
The Marshfield Epidemiologic Study Area (MESA) system83 | USA fair | 811 | No | Not reported | Not reported | New cases of Alzheimer’s disease and dementia were defined to first occur between 7/1/92 and 6/30/97by the ICD-9 code, people who did not receive a diagnosis of AD/OD were frequency- matched to cases by age. | Permanent residence in a nursing home at the time of diagnosis, a history of AD/OD prior to 7/1/92, no mention of a memory problem in the medical record, receiving less than 75% of their care through the Marshfield Clinic system, or death on the date of diagnosis | Yes | No
The Medical Expenditure Panel Survey(MEPS) 84 | USA good | 35200 | Oversampling of minorities | Yes | NR | US civilian non- institutionalized population | Individuals missing data on one or more responses are excluded from analyses. | Yes | No
The Monongahela Valley Independent Elders Survey85 | USA good | 1,064 | No | Not reported | >67 | Registered voters in Washington & Westmoreland Counties in PA, community residence (i.e., not already being in long-term care), 65 years or older, fluency in English, and at least sixth grade education | Not reported | Yes | No
The National Health Interview Survey86 | USA good | approx 9,000 | African- American and Hispanic | Yes | >70 | Civilian non- institutionalized population of the United States | Not reported | Yes | No
The National Long-Term Care Survey (NLTCS) 87 | USA good | 5,934 | No | Yes | >65 | Community-dwelling elderly | Not reported | Yes | No
The National Survey of Self- Care and Aging88 | USA good | 3,485 | Oversampling of the oldest old (85 years and older) | Yes | >65 | A stratified random sample of non- institutionalized Medicare beneficiaries 65 years of age and older, drawn from 50 primary sampling units | Not reported | Yes | No
The New England Centenarian Study89 | USA poor | 36 | No | Not Reported | 100–107 years | 86% of all centenarians living within an eight-town area. | Not Reported | Yes | Yes
The New Mexico Elder Health Survey90 | USA good | 808 | No | No | >65 years | Equal numbers of Hispanic and non- Hispanic white men and women were selected randomly from the Health Care Financing Administration’s Medicare listings for Bernalillo County, New Mexico. | 73 subjects were deleted because of missing anthropometric data. Two subjects with artificial limbs whose estimates of muscle mass had doubtful validity were also excluded. | Yes | No
The Northern Manhattan Aging Project91 | USA good | 2,130 | | Yes | >65 | A random sample of Medicare beneficiaries, 65 years old or older, living in a bounded target geographic area | Not reported | Yes | No
The Nutrition Screening Initiative92e | USA good | 324 | No | Yes | >60 | Participants >60 years in six congregate meal sites in a north Florida county | Not reported | Yes | No
The Older Americans Act Nutrition Program (OAANP) in northeast Georgia93 | USA fair | 158 | No | Yes | >65 | Low-income older adults receiving home- delivered or congregate meals in the OAANP (Older Americans Act Nutrition Program) in the Northeast Georgia Area Agency on Aging. | Not reported | Yes | No
The Religious Orders Study94 | USA good | 816 | No | Not reported | >70 | Older Catholic nuns, priests, and brothers. Participants without known dementia. | Not reported | Yes | No
The Rush Memory and Aging Project95 | USA good | 832 | No | Yes | Mean age: 80.4years | Absence of clinical dementia based on the baseline clinical evaluation with a valid baseline and at least one follow-up composite frailty score. | Participants without valid follow-up data including: 24 persons who died before their first follow-up examination, 120 who have not been in the study long enough for their first follow-up examination and 36 with missing follow-up data. | Yes | No
The San Antonio Longitudinal Study of Aging96 | USA good | 749 | No | Yes | 65–80 years | Subjects were randomly sampled from low-, middle-, and high- income neighborhoods to provide a cohort with comparable numbers of Mexican-Americans and European-Americans and to maximize socio- cultural variation among Mexican-Americans in the study. Aged 65–80 years. Community- dwelling. | Not Reported | Yes | No
The Survey of Health, Aging and Retirement in Europe(SHARE) 97 | Multinational good | 18227 | No | Not Reported | >=50 years | Randomly selected community-dwelling individuals 50 years of age and older | 674 spouses younger than 50 years, 295 individuals living in institutions, 61 with insufficient information on sampling characteristics, and 2 non-evaluable individuals | Yes | No
The Women’s Health and Aging Study98–111 | USA good | 3,481 | No | Yes | >65 | The sampling frame was obtained from the Health Care Financing Administration Medicare Enrollment files for the eastern half of Baltimore City and County, consisting of 12 zip code areas. A random sample of older women was drawn, stratified by age (65–74, 75–84, and 85 and older). | Not reported | Yes | No
University of Connecticut Center on Aging Osteoporosis in Men Study112 | USA good | 392 | No | Yes | >58 | Community-dwelling elderly men | Men younger than 58 years of age; those receiving prescription medication for osteoporosis, were on testosterone or dihydroepiandosterone, had a history of elevated prostate specific antigen (PSA) level, had a history of prostate cancer, had sleep apnea, or had elevated hematocrit. | No | No
2-year longitudinal study of independent residents of a continuing care retirement community113 | USA fair | 152 | No | Not reported | 82.3 | Alert, oriented, ambulatory, able to socialize appropriately with other members of the community, and have no acute or chronic medical problems which interfere with ability to function or require daily nursing supervision | Not reported | Yes | No
411 patients who participated as control patients in the Generalist Physician Initiative at the Carle Clinic site, Urbana, Illinois114 | USA poor | 411 | No | Yes | >65 | 65 years of age or older, survived for 12 months after enrollment, had Medicare Part A and B coverage, were not enrolled in a Medicare risk product, were community dwelling, and had 1 or more of the following characteristics: hospitalized in the previous 6 months before entering the study, lived alone, lacked a caregiver, were taking 4 or more prescription medications, had difficulty walking, had limitations in activities of daily living (ADLs), had memory difficulties, were incontinent of urine or stool, or had multiple illnesses or disabilities | Not reported | Yes | No
7076 community-dwelling elderly patients with at least one chronic disease were surveyed115 | USA poor | 1,899 | No | Not reported | >65 | Had seen their primary care provider within 14 months, had a comorbidity score of 1 or higher, were enrolled in Medicare, and were living outside of an institution as of September 2002 | Returned with incomplete survey forms | Yes | No
A prospective cohort from a large health maintenance organization of (Group Health Cooperative (GHC) in Seattle, Washington)116 | USA good | 1,129 | No | Yes | >65 | Randomly from Group Health enrollees, aged 65 and over | Physical limitations, limited ability to perform certain activities of daily living at baseline, and incomplete responses or data | Yes | No
Ambulatory Care Groups (ACGs)117 | USA fair | 3,496 | No | Yes | >60 | Community-dwelling patients at least 60 years of age with a scheduled primary care appointment between July 15, 1999, and August 31, 2001, were eligible for the study. | Not reported | Yes | No
Applicants to the home-and community-based care (HCBC) programs118 | USA fair | 1,690 | No | Yes | 79.7 | Individuals who satisfied the level of care criteria for the program (regardless of whether they met the financial eligibility criteria or “cost cap” of the program) and remained in the community following their HCBC assessment | Not reported | Yes | No
Consecutive patients were screened and recruited from primary care clinics of a Veteran’s Affairs network site and a Medicare Health119 Management Organization serving a common geographic area | USA poor | 316 | No | Yes | >65 | 65 years or older, lived within 20 miles of the provider site, had received care in the system for at least 1 year, were living in the community, and met screening criteria for mental status and mobility. Participants had to score 24 on the Folstein Mini-Mental State Examination (MMSE) to assure that they could independently maintain a utilization diary; subjects with MMSE scores between 16 and 24 could participate if they had a caregiver who could maintain the diary | MMSE scores less than 16, persons who were unable to walk at least 12 feet or who were felt to be extremely fit (gait speed over 1.3 m/s) or extremely fragile | Yes | No
Depression Among Caregivers of Impaired Elders Study120 | USA good | 4,185 | No | Not reported | >70 | A geographically stratified sample of older people was drawn in 2 stages, using town/cities of eastern Massachusetts as the primary sampling unit, and then randomly selecting individuals within these units from local census lists. | Not reported | Yes | No
Effects of Two Exercise Interventions Among Community-residing Older Adults Study121 | USA good | 84 | No | Not reported | >60 | 60 years of age or older, living independently in the community, able to speak and read English, and sufficient vision to read large print. | Diagnosis of neurological diseases, arthritis with severe pain that prevented activity, or presence of major symptoms suggestive of cardiopulmonary or metabolic disease unless physician approval was obtained. | Yes | No
For the validation study: Pneumonia Pathways project of Qualidigm, Connecticut Peer Review Organization and Connecticut Thoracic Society. For the Development cohort: NR122 | USA poor | Development cohort:525 and validation cohort:1,246 | No | Yes | >70 | In the development cohort: subjects aged ≥70 years admitted consecutively to the medicine service at Yale New Haven Hospital that serves a large community and referral population. The validation cohort was selected from discharges from 27 acute care hospitals in Connecticut, patients aged>=65 years with a principal discharge diagnosis of pneumonia. | In the development cohort: inability to be interviewed as a result of intubation, coma, aphasia, severe dementia, or terminal condition; prior enrollment. In the validation cohort: prior admission within 10 days; transfer from another hospital; immunosuppressive therapy; and discharge or transfer to ICU within 24 h of admission | Yes | No
Frailty Study of African Americans in South Central Los Angeles123 | USA good | 507 | No | Yes | >60 | African-American residents 60 years or older of South Central Los Angeles and adjacent communities. | Not reported | Yes | Yes
Henry Ford Medical Group124 | USA fair | 195,971 | No | Not reported | Not reported | Patients who received prescription and medical care coverage through the Health Alliance Plan and who were treated by physicians in the Henry Ford Medical Group. | Not reported | Yes | No
Individuals enrolled in 2 randomized trials of an intervention to improve functional outcomes of hospitalized older adults125 | USA good | 1,495 | No | Yes | >70 | Aged 70 years or older and who were admitted to the general medical service | Patients admitted to intensive care units (ICUs) or subspecialty services or elective admissions and patients with lengths of stay fewer than 2 days | Yes | Yes
Massachusetts Health Care Panel Study (MHCPS) 126 | USA good | Not specified; approx 540 | No | Yes | >70 | Age 70+ in 1980, living in community | Anyone lost to follow-up, dead, or in a nursing home at Wave 4 | Yes | No
Randomized trial of in-home comprehensive geriatric assessment and preventive care127 | USA fair | 202 | No | Not reported | >75 | Randomly selected from a voter-registration list, community-dwelling, non-institutionalized, living in Santa Monica CA | Not reported | Yes | No
PACE-Program of All-Inclusive Care for the Elderly128,129 | USA good | 5,478 | No | Yes | >55 | Enrollment in PACE was limited to older persons aged >=55, who lived within the sites’ service areas and who met the state’s nursing home eligibility requirements, and were eligible for Medicaid | Not reported | Yes | Yes
Pooled analysis130 | USA good | 5,308 | No | Yes | >65 | Studies had to contribute data believed to be directly applicable to the US population and the determination of glaucoma was made using both visual field and photographically obtained optic nerve head data. | Not reported | Yes | No
Practices providing services to Medicare beneficiaries in the U.S. 131 | USA good | 1,221,615 | No | Yes | >65 | Medicare beneficiaries, aged 65 years or older, living in the US, with fee-for-service coverage, who had both Medicare part A and part B coverage in fiscal year (FY) 1992 | Beneficiaries enrolled in HMOs | Yes | No
The San Luis Valley Health and Aging Study132 | USA good | 1,006 | No | Yes | >65 | A geographically-based sample of rural, community-dwelling residents was identified from a household enumeration of 97.2% of all occupied residential structures in Alamosa and Conejos counties in southern Colorado. | Subjects who were unable to complete the full protocol by themselves (scores <18 on the Folstein Mini-Mental Status Examination, a measure of cognitive functioning; extreme frailty; or any other reason necessitating proxy responses: n=184) and those without complete diet data (n=8) were excluded. | Yes | No
The Medicare Current Beneficiary Survey133,134 | USA good | 20,227 | No | Yes | >65 | People living in the United States who were 65 years of age or older and who were solely community-based | Respondents who died during the calendar year, individuals who did not have any type of physician encounter (i.e., in any type of inpatient or outpatient setting) during the calendar year | Yes | No
The Nun Study135 | USA good | 470 | No | Not reported | >75 | From 1991 to 1993, all members of the School Sisters of Notre Dame born before 1917 and living in communities in the Midwestern, eastern, and southern United States. | Not reported | Yes | No
Two cohorts, each composed of approximately 3000 randomly selected members of Kaiser Foundation Health Plan of Northern California136 | USA fair | 5,986 | No | Yes | >65 | Had been KFHP members for at least 5 years | Not reported | Yes | No
Urban, working-class community in East Boston, Massachusetts137 | USA good | 467 | No | Not reported | >65 | All non-institutionalized residents over the age of 65 years in East Boston, Mass., a geographically defined, urban, working-class community of approximately 32, 000 persons. | Participation through proxy respondents or refusal to respond to the memory test items. | Yes | No
Veterans Administrative (VA) outpatient clinics138 | USA fair | 130 | No | Yes | >65 | Community-dwelling older adults (n = 130), age 65 years and older, with a BMI <24 kg/m^2^ residing in 3 rural counties in the Western United States | The diagnosis of dementia (Folstein Mini-Mental Examination score of 23 or less), congestive heart failure, or cancer; bedridden or unable to stand for measurement of height; currently hospitalized; hospitalized in the past 30 days; or residing in a skilled nursing facility and non-English speaking | Yes | No
American Community Survey (US Census) and National Nursing Home Survey3,4 | USA good | 512,768 | American Indian/Alaska Native/Native American are oversampled in the ACS Survey | Yes | >65 | ACS: community - living men and women 65 years and older. NNHS: nursing home residents | ACS: no nursing home residents. NNHS: community-dwelling residents | Yes | Yes
Australian Longitudinal study on aging139 | Australia good | 1,272 | No | Not reported | >70 | Randomly selected from State electoral database age 70+, community-dwelling | Not reported | Yes | No
All consecutive non-elective admissions of patients aged 75 yrs and above to the Rapid assessment medical unit (RAMU) under the General Internal Medicine unit140 | Australia poor | 110 | No | Not reported | >75 | All consecutive non-elective admissions of patients aged 75 yrs and above to the Rapid assessment medical unit (RAMU) under the General Internal Medicine unit | Patients from nursing homes, patients who were transferred to other units or hospitals, patients who were considered for palliative care on admission, patients not conversant in English and those who were discharged from hospital within 48 hours | Yes | No
Domiciliary care services for elderly people with moderate or severe functional limitations141 | Australia poor | 250 | No | Not reported | >67 | Those registered with the Eastern Domiciliary Care Service in Adelaide between July 1999 and February 2000. | Subjects younger than 65 (16.2%), non-English speaking (7.9%), or with the diagnosis of dementia (11.2%) were excluded. | Yes | No
National Population Health Survey142 | Canada good | 2,740 | No | Not reported | >65 | Adults 65 – 102 years old at baseline | | Yes | No
The Canadian Study of Health and Aging(CSHA) 143–152 | Canada good | 8,949 | No | Not reported | >65 | CSHA-1 (Canadian Study of Health and Aging-wave 1) included people aged 65 and over on October 31, 1990 from 39 urban and surrounding rural areas in the ten Canadian provinces. The community sampling frame was based on the Canadian provincial universal health insurance plans, with the exception of Ontario where technical limitations with the health insurance plan list at the time prevented its use. In Ontario, the Enumeration Composite Record was used that was based on a composite list of all citizens in Ontario based on electoral lists. | Reasons for non-inclusion in analyses are: loss to follow up, refusal to participate, unable to participate, or missing data. Those who were excluded had lower Time 1 MMSE scores. | Yes | Yes
The MGAT study153 | Canada fair | 170 | No | Not reported | Not reported | Be frail, which was defined as “a vulnerable state of health, arising from the complex interaction of medical and social problems, resulting in a decreased ability to respond to stress, and associated with a decline in functional performance” | Not reported | Yes | No
Prospective cohort study of community-living, medical patients age 75 or over154 admitted to acute care for elders units (ACE) at a teaching hospital | Canada poor | 150 | No | Not reported | >75 | ACE patients who consented to participate. They were eligible if they were 75 years or over (our hospital used this age cut-off as a surrogate marker to determine ACE eligibility), lived in the community pre-hospitalization, and could comprehend simple three-step commands in English. We also included ACE patients who transitioned through a separate sub-acute medical (SAM) unit after their initial stay in ACE. | If they were transferred from/to critical care or palliative care because these populations are not normally serviced by ACE; residing at a long term care facility prior to hospitalization; residing outside the catchment of the hospital (greater than 100 km distance); or deemed medically unstable | Yes | No
Study participants were recruited at a preadmission clinic for preoperative assessment, at a tertiary care teaching hospital155 | Canada poor | 125 | No | Not reported | >70 | (i) age 70 years or older; (ii) referred for medical preoperative assessment for medical clearance; (iii) undergoing a single elective non-cardiac operation | (i) day surgical procedures; (ii) active cancer (defined as having surgery for a possible malignancy or receiving treatment for cancer); (iii) undecided as to whether they would have surgery; (iv) no working understanding of English; (v) not cleared for surgery for unstable medical reasons; (vi) enrolled in randomized controlled trials of new (i.e. investigational) pharmacologic agents | Yes | No
The Chinese Longitudinal Health Longevity Survey156 | China good | 15,919 | No | Not reported | >65 | Randomly selected counties/cities in 22 out of 31 provinces in China. Adults aged 65 to 109 years. For every centenarian with a pre-designated random code, interviews were conducted for nearby adults with a pre-designated age and sex who were randomly selected from the following age ranges: 65–79, 80–89, and 90–99. | Not reported | Yes | No
The Danish part of the ‘Survey in Europe of Nutrition in the Elderly, a Concerted Action’(SENEC A) 157 | Denmark good | 202 | No | Not reported | >73 | 74-to-79 years old elderly European men and women | | Yes | No
The Danish Centenarian Study Centenarian Study158 | Denmark good | 126 | No | Not reported | >100 | 276 persons living in Denmark who celebrated their 100th birthday from April 1, 1995, to May 31, 1996 | Not reported | Yes | Yes
The Glostrup Aging Study159 | Denmark good | 705 | No | Not reported | >70 | 70 -year old adults of the 1914 birth cohort in Glostrup, Denmark | 31 persons who were disabled at baseline. | Yes | No
ELSA - English Longitudinal Study of Aging160 | England good | 5,432 | No | Not reported | >50 | Individuals were eligible if they were living in a responding HSE (Health Survey for England) household in 1998, 1999, or 2001, were born on or before 29 February 1952, and were, at ELSA interview, still living at a private residential address in England. | Not reported | Yes | No
The Helsinki Aging Study161,162 | Finland good | 650 | No | Not reported | >75 | A random sample of persons born in 1904, 1909, and 1914 were selected from the census register in 1989. | Not reported | Yes | No
The second wave of the Tampere Longitudinal Study on Ageing (TamELSA) 163 | Finland good | 775 | No | Not reported | >60 | Persons aged 60–99 years were eligible to be interviewed face to face | Subjects already living in institutions and 3 subjects without data on urinary symptoms | Yes | No
The Vitality 90+ Study164 | Finland good | 285 | No | Not reported | >90 | People aged 90 or older in Tampere, Finland. Included both community-dwelling and institutionalized persons. | Not reported | Yes | Yes
EPIDOS Epidémiologie de l’ostéoporose study165 | France good | 7,250 | No | Not reported | >75 | Community-dwelling French women | Inability to walk independently, institutionalized, previous history of hip fracture or bilateral hip replacement, inability to understand or answer study questionnaire, confined to bed for at least 2 months during past year, motor impairment i.e. stroke sequelae, disease leading to hospitalization during past year (stroke, HTN, DM, CHD, Parkinson’s | Yes | No
The PAQUID(Perso nnes Agees QUID) Research Program166,167 | France good | 3,660 | No | Not reported | >65 | Community residents aged 65 years and older living in Southwestern France. Baseline data were collected in 1988–89 in Gironde and 1989–1990 in Dordogne. Three criteria had to meet for inclusion: participant had to be at least 65 years of age, to live at home at baseline time, and to give written informed consent. | Not reported | Yes | No
The Pathologies Oculaires Liées à l’Age Study168 | France good | 1,441 | No | Not reported | >60 | Subjects aged 60 and older were recruited from the population of Sète, a harbor on the French Mediterranean. | A history of the following diseases was excluded: diabetes mellitus; coronary heart disease; or self- reported history of stroke, lower limb arterial disease, cancer, asthma, or respiratory disease. Subjects treated with non-steroidal anti- inflammatory drugs or with oral corticosteroid treatment were also excluded. | Yes | No
The Three City Study169–171 | France good | 6,030 | No | Not reported | >65 | 65 years old or older, initially non- institutionalized, random sample obtained from the electoral rolls of two French cities— Bordeaux (southwest) and Dijon (central east) | Those with conditions that could be a consequence of a single disease and not of generalized frailty as already proposed, or frailty status could not be determined (missing data) | Yes | No
The German Study on Aging, Cognition and Dementia in Primary Care Patients Study Group172 | Germany good | 2,415 | No | Not reported | >75 | Age 75 years or older, absence of dementia according to judgment of GP, and at least 1 contact with the GP within the last 12 months. | GP consultation by home visits only, residence in a nursing home, severe illness with an anticipated fatal outcome within 3 months, German- language insufficiency, deafness or blindness, and lack of ability to provide informed consent. | Yes | No
The Leipzig Longitudinal Study of the Aged(LEILA75 +)173 | Germany good | 1,045 | No | Not reported | >75 | Community-dwelling individuals aged 75 and over residing in the Leipzig-South district of Germany were identified by systematic random sampling from an age- ordered list provided by the local registry office. 192 institutionalized individuals (60 residential home residents and 132 nursing home residents) were included in the study by proportion. | Study subjects with Parkinson’s disease, mental retardation, known brain cancer, and severe weakness or severe sensory impairment leading to invalid cognitive testing. | Yes | Yes
A family study sample: Patients with Alzheimer’s disease and/or major depression (according to DSM-III-R criteria, APA 1987 39) over 60 years had been recruited from the Inpatient Departments of Psychiatry of the University of Mainz (recruitment from 1992 to 1995) and of the University of Bonn (recruitment from 1996 to 1998). Control subjects who were group- matched to the patient sample for age, gender, and educational background had been recruited with the support of the cities’ census agencies. 174 | Germany fair | 757 | No | Not reported | >55 | All non-demented subjects(defined by the absence of dementia according to DSM-III-R criteria (American Psychiatric Association 1987) above the age of 55 years, who had been carefully examined for possible initial signs of dementia and for the presence of possible risk factors during a previous comprehensive family study. | Subjects with a MMSE score below 24, a Hachinski Ischemic score above 2, a history of dementia or other major medical disorder possible to cause depression, or depression.18 subjects who developed other dementing disorders according to personal or family history information were excluded | Yes | No
ilSIRENTE Aging and Longevity in the Sirente Geographic Area175 | Italy good | 364 | No | Not reported | >80 | Community-dwelling Italian older adults | Not reported | Yes | No
InCHIANTI176–181 | Italy good | 1,020 | No | Not reported | >65 | Participants aged between 65 and 102 years, randomly selected from residents in two towns of the Chianti geographic area (Greve in Chianti and Bagno a Ripoli, Tuscany, Italy), using a multistage stratified sampling method. | Participants in whom inflammatory markers, physical performance tests, or hand-grip strength were not tested. | Yes | No
The Conselice Study of Brain Aging182 | Italy good | 804 | No | Not reported | >65 | In 1999–2000, 1016 of the 1353 individuals aged 65 years and older residing in the Italian municipality of Conselice (Emilia Romagna region) participated in the prevalence study. | Not reported | Yes | No
The European Challenge for Healthy Aging183 | Italy good | 211 | No | Not reported | >65 | Born in Calabria and their ancestry in the region had been ascertained up to the grandparents generation | Not reported | Yes | No
The Italian Group of Pharmacoepid emiology in the Elderly (GIFA) 184 | Italy good | 6,984 | No | Not reported | >65 | All patients admitted to 81 clinical centers in Italy were enrolled and followed until discharge. | Those younger than 65 years and those with cancer. Subsequently excluded were patients for whom body mass index had not been collected. | Yes | No
The Italian Longitudinal Study on Aging185 | Italy good | 2,097 | No | Not reported | >65 | 5,632 subjects, aged 65–84 years, independent or institutionalized. Randomly selected from the electoral rolls of eight Italian municipalities, after stratification for age and gender. | Not reported | Yes | Yes
The Verona Diabetes Study186 | Italy good | 754 | No | Not reported | >65 | Type 2 diabetic outpatients, who regularly attended the Diabetes Clinic of Verona main hospital, dedicated to the cure of diabetes and endocrinologic diseases, and who had at least one determination of BMI, BP and fasting plasma glucose per year during an observation period of 3 years | Not reported | Yes | No
ASSI, a prospective cohort study of persons aged 65 and older randomly abstracted from the rosters of 98 PCPs in Florence, Italy187 | Italy good | 5,396 | No | Not reported | >65 | Persons aged 65 and older randomly abstracted from the rosters of 98 PCPs in Florence, Italy | Not reported | Yes | No
Community- dwelling elderly people188 | Italy poor | 65 | No | Not reported | >65 | Community-dwelling elderly people who freely chose to come to a geriatric unit for general clinical evaluation as part of a comprehensive geriatric assessment program. 400 subjects aged 65 years and older were evaluated at the geriatric unit of the Ospedale Maggiore Instituto do Ricovero e Cura a Carattere Scientifico, Milan, Italy, to study memory impairment and other cognitive disorders. | Known or suspected history of alcohol abuse, head injury, depression, or other major medical illness. | Yes | No
Survey in Europe on Nutrition and the Elderly: a Concerted Action(SENECA) 189 | Multinational good | 989 | No | Not reported | Not reported | Approximately 2,600 elderly people born between 1913 and 1918 living in 19 “traditional” towns in 12 countries were included. | People living in psychogeriatric nursing homes, who were not fluent in the country’s language, or who were not able to answer questions independently. | Yes | No
The Australian Longitudinal Study of Aging, the Canadian Study of Health and Aging screening(CSH A-screen) and community clinical examination(C SHA- examination), the Canadian National Population Health Survey, the U.S. National Health and Nutrition Examination Survey, the Sydney Older Persons Studies, CSHA institutional (CSHA- institute), the U.S. National Long-Term Care Survey institutional sample(NLTC- institute), the Improving Cardiac Outcomes in Nova Scotia(ICONS) Study in Canada, a breast cancer study in Canada, and the Gothenberg Study in Sweden. 190 | Multinational good | 2,087 in The Australian Longitudinal Study of Aging, 8,547 in the Canadian Study of Health and Aging screening (CSHA- screen) and 1,585 in community clinical examination(C SHA- examination), 16,481 in the Canadian National Population Health Survey, 3,639 in the U.S. National Health and Nutrition Examination Survey, 547 in the Sydney Older Persons Studies, 720 in CSHA institutional (CSHA- institute),1,036 in the U.S. National Long-Term Care Survey institutional sample(NLTC -institute), 687 in the Improving Cardiac Outcomes in Nova Scotia (ICONS) Study in Canada,130 in the breast cancer study in Canada, and 965 in the Gothenberg Study in Sweden. | No | Yes | >65 | Not reported | Not reported | Yes | Yes
Singapore Longitudinal Aging Study, SLAS191 | Singapore good | 1,407 | No | Yes | >55 | Elderly residents in five southeast districts of Singapore, aged 55 years and above identified from a door- to-door census. | Not reported | Yes | No
NONA Immune Study192 | Sweden fair | 138 | No | Not reported | >85 | Population-based sample of oldest-old individuals | Not reported | Yes | No
The Leiden 85 plus study193 | The Netherlands good | 551 | No | Not reported | >85 | All inhabitants of Leiden born between 1912 and 1914 | Not reported | Yes | Yes
The Longitudinal Aging Study Amsterdam194–197 | The Netherlands good | 2,257 | No | Not reported | 72 | Population registers of 11 municipalities | Not living independently at baseline, not providing a blood sample or had no measurement of serum 25(OH)D, missing contact information. | Yes | No
Patients 65 years or older acutely admitted from November 1, 2002, through July 1, 2005, to a 1024-bed tertiary university teaching hospital198 | The Netherlands good | 463 | No | Not reported | >65 | All consecutive patients aged 65 years or older acutely admitted to the Department of Internal Medicine | Inability to speak or understand Dutch, transferring from or to non medical ward, discharge from the hospital within 48 hours after admission | Yes | Yes
H-EPESE Hispanic Established Populations for Epidemiologic Studies of the Elderly199–205 | USA | 3,050 | No | Yes | >65 | Community-dwelling Mexican Americans | Refused to be re- interviewed or were lost to followup, or were confirmed dead through the National Death Index and reports from relatives | Yes | No
The Hertfordshire Cohort Study206 | UK good | 638 | No | Not reported | >64 | Community-dwelling young-old men and women | Not reported | Yes | No
The Medical Research Council Cognitive Function and Aging Study207 | UK good | 2,640 | No | Not reported | >65 | Participants aged 65 and older randomly selected from the Family Health Service Authority lists in five areas of England and Wales (two rural: Cambridgeshire and Gwynedd; and three urban: Newcastle, Nottingham, and Oxford). | Not reported | Yes | No
The Medical Research Council (MRC) Trial of the Assessment and Management of Older People in the Community208 | UK good | 14,621 | No | Not reported | >75 | Community-based cluster randomized controlled trial, comparing different methods of multidimensional screening of older people. One hundred and six general practices were selected from the MRC General Practice Framework in England, Scotland and Wales. The study population was all patients aged 75 years and over registered with the practice. | Anyone in long-stay hospitals, nursing homes or with terminal illness. | Yes | No
The Nottingham Longitudinal Study of Activity and Ageing (NLSAA) 209 | UK good | 1,042 | No | Not reported | >65 | Community-dwelling people aged 65 years and older in Nottingham, U.K. | Not reported | Yes | No
Systematic reviews and meta analyses
EURODEM-Prevalence Research Group210 | Multi-national good | 23 | No | Not reported | >65 | Inclusion criteria were: (1) studies conducted in Europe; (2) studies completed or published after 1979 (1980–1990); (3) minimum sample of 300 subjects 65 years or older; (4) case finding through direct individual examination; (5) inclusion of institutionalized individuals; and (6) clinical diagnosis of dementia based on (DSM-III), or equivalent criteria. | Prevalence estimates for subjects over the age of 89 years were discarded. | Yes | Yes
A meta-analysis of 13 epidemiological studies of senile dementia211 | Multi-national good | 0 | No | Not reported | >80 | Only studies that used internationally recognized diagnostic methods for senile dementia were included. Data available over age 80 and sampling procedures from both community-dwelling and institutionalized population. | Of the 12 studies, three were rejected because information on the numbers of people in each age-group was incomplete. | Yes | Yes
Seven community-based studies46 | Multi-national good | 11,827 | No | Yes | >65 | The InCHIANTI Study, NHANES III, and WHAS I; the Health ABC Study; the East Boston, Iowa, and New Haven sites of the EPESE | Not reported | Yes | No

Appendix E Table 2 Prevalence of Comorbidities in Older Persons According to Definition

Reference | Study | Sample | Definition | Prevalence (95% CI)
Number of chronic diseases in elderly
Schultz-Larsen, 2007^159^ | The Glostrup Aging Study | 705 | Comorbidity in nondisabled 70-year old - hypertension, diabetes, bronchitis, osteoarthritis in lower limbs, arteriosclerosis in lower limbs, and an ankle/arm index below 90% | 8.9 (7.0; 11.3)
Pressley, 1999^87^ | National Long-Term Care Survey (NLTCS) | 5,934 | 3 | 18.7 (17.7; 19.7)
2001^152^ | Canadian Study of Health and Aging (CSHA) | 8,949 | 3 or 4 in the GSS91 survey (General Social Surveys, 1991) | 30.5 (29.6; 31.5)
2001^152^ | Canadian Study of Health and Aging (CSHA) | 8,949 | 3 or 4 in the CSHA-1 survey (Canadian Study of Health and Aging) | 30.7 (29.8; 31.7)
Pressley, 1999^87^ | National Long-Term Care Survey (NLTCS) | 5,934 | ≥4 | 10.8 (10.0; 11.6)
2001^152^ | Canadian Study of Health and Aging (CSHA) | 8,949 | 5 or 6 in the GSS91 survey (General Social Surveys, 1991) | 8.2 (7.6; 8.8)
2001^152^ | Canadian Study of Health and Aging (CSHA) | 8,949 | 5 or 6 in the CSHA-1 survey (Canadian Study of Health and Aging) | 18.3 (17.5; 19.1)
2001^152^ | Canadian Study of Health and Aging (CSHA) | 8,949 | ≥ 7 in the GSS91 survey (General Social Surveys, 1991) | 1.9 (1.6; 2.2)
2001^152^ | Canadian Study of Health and Aging (CSHA) | 8,949 | ≥ 7 or more in the CSHA-1 survey (Canadian Study of Health and Aging) | 13.9 (13.2; 14.6)
Bruunsgaard, 2003^158^ | Danish Centenarian Study | 126 | >5 diagnoses | 23 (16.5; 31.1)
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) | 811 | 8–10 | 20.1 (17.5; 23.0)
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) | 811 | 11+ | 23.7 (20.9; 26.7)
de Groot, 2004^189^ | Survey in Europe on Nutrition and the Elderly: a Concerted Action (SENECA) | 989 | Suffering from chronic diseases | 77.4 (74.6; 79.9)
Ambulatory Care Groups (ACGs)
Perkins, 2004^117^ | Ambulatory Care Groups(ACGs) | 3,496 | 10 ADG combinations with ≥2 major ACG | 0.7 (0.5; 1.0)
Perkins, 2004^117^ | Ambulatory Care Groups(ACGs) | 3,496 | 4–5 ADG combinations with ≥2 major ACG | 4.5 (3.9; 5.2)
Perkins, 2004^117^ | Ambulatory Care Groups(ACGs) | 3,496 | 6–9 ADG combinations with ≥2 major ADGs | 9.3 (8.4; 10.3)
Charlson Score
Inouye, 2003^122^ | Validation study | 525 | Charlson score ≥2 in development cohort | 71.0 (67.0; 74.7)
Inouye, 2003^122^ | Validation study | 525 | Charlson score ≥2 in validation cohort | 60.8 (56.6; 64.9)
Number of chronic diseases in elderly women
Schultz-Larsen, 2007^159^ | Glostrup Aging Study | 705 | 2 diseases | 16.0 (13.5; 18.9)
Schultz-Larsen, 2007^159^ | Glostrup Aging Study | 705 | 4–6 diseases | 5.0 (3.6; 6.9)
Szanton, 2009^103^ | Women's Health and Aging Studies | 728 | 3 or more chronic diseases | 16 (13.5; 18.8)
Fried, 1999^106^ | Women's Health and Aging Study | 3,481 | 3 chronic diseases and conditions | 23.0 (21.6; 24.4)
Fried, 1999^106^ | Women's Health and Aging Study | 3,481 | 4 chronic diseases and conditions | 16.0 (14.8; 17.3)
Fried, 1999^106^ | Women's Health and Aging Study | 3,481 | 5 chronic diseases and conditions | 9.0 (8.1; 10.0)
Fried, 1999^106^ | Women's Health and Aging Study | 3,481 | 6 chronic diseases and conditions | 4.5 (3.9; 5.2)
Fried, 1999^106^ | Women's Health and Aging Study | 3,481 | 7 chronic diseases and conditions | 2.0 (1.6; 2.5)
Fried, 1999^106^ | Women's Health and Aging Study | 3,481 | 8 chronic diseases and conditions | 0.5 (0.3; 0.8)
Chang, 2010^104^ | Women's Health and Aging Studies I and II and complementary cohorts | 620 | ≥ 3 diseases | 18.4 (15.5; 21.6)
Chang, 2010^104^ | Women's Health and Aging Studies I and II and complementary cohorts | 620 | ≥ 4 diseases | 8.6 (6.6; 11.1)
Chang, 2010^104^ | Women's Health and Aging Studies I and II and complementary cohorts | 620 | ≥ 5 diseases | 1.6 (0.9; 3.0)
Szanton, 2009^103^ | Women's Health and Aging Studies | 728 | ≥ 3 diseases in African Americans | 13.4 (11.1; 16.1)
Szanton, 2009^103^ | Women's Health and Aging Studies | | ≥ 3 diseases in Caucasians | 9.5 (7.6; 11.9)
Number of chronic diseases in elderly men
Schultz-Larsen, 2007^159^ | Glostrup Aging Study | 705 | 2 diseases | 16.0 (13.5; 18.9)
Schultz-Larsen, 2007^159^ | Glostrup Aging Study | 705 | 4–6 diseases | 5.0 (3.6; 6.9)

Appendix E Table 3 Prevalence of Polypharmacy in Older Persons

Reference | Study | Sample | Definition of the Outcome | Prevalence (95% CI)
Zarowitz, 2005^124^ | Henry Ford Medical Group | 195,971 | Overall polypharmacy - 5 or more different drugs concurrently for long-term use, rate/1,000 patients | 29.0 (28.8; 29.2)
Veehof, 2000^212^ | Registration Network of Groningen (RNG) | 1,544 | 2–3 drugs, long-term drug use | 40.7 (38.3; 43.2)
Veehof, 2000^212^ | Registration Network of Groningen (RNG) | 1,544 | 4–5 drugs, long-term drug use | 0.09 (0; 0.5)
Veehof, 2000^212^ | Registration Network of Groningen (RNG) | 1,544 | >5 drugs, long-term drug use | 0.04 (0; 0.5)
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) | 811 | 5–9 prescription medicines | 21.8 (19.1; 24.8)
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) | 811 | 10+ prescription medicines | 23.4 (20.6; 26.4)
Helmer, 1999^166^ | PAQUID (Personnes Agees QUID) Research Program | 3660 | ≥ 5 Number of medications in women at baseline | 43.0 (41.4; 44.6)
Helmer, 1999^166^ | PAQUID (Personnes Agees QUID) Research Program | 3660 | ≥ 5 Number of medications in men at baseline | 35.6 (34.1; 37.2)

Appendix E Table 4 Prevalence of Cognitive Impairment in Older Persons According to Definition: Medical Research Council Cognitive Function and Aging Study207

Definitions of Cognitive Impairment (Measure with Mini-Mental State Examination) | Prevalence (95% CI)
Moderate cognitive decline (a score of 7 or less of 10 on the 10-Item Mental Status Questionnaire from the Global Deterioration Scale) | 0.10 (0.0; 0.2)
Mild cognitive decline (a score of at least 8 of 10 on the 10-Item Mental Status Questionnaire from the Global Deterioration Scale) | 0.30 (0.1; 0.7)
Questionable dementia (dementia was defined as an AGECAT organic symptom level of 3 or greater (i.e., 03–05) which corresponds to a diagnosis of dementia as defined according to the DSM-III-R) | 0.70 (0.5; 1.0)
Age-associated cognitive decline (self-report of a gradual decline in memory present for at least 6 months) | 1.40 (1.0; 1.9)
Mild neurocognitive disorder | 1.40 (1.0; 1.8)
Age-related cognitive decline | 1.80 (1.3; 2.6)
Mild cognitive disorder | 1.80 (1.4; 2.2)
Age-associated memory impairment | 2.00 (1.3; 3.3)
Mild cognitive impairment (amnestic) | 2.50 (1.7; 3.6)
Mild cognitive impairment (multiple) | 2.60 (1.8; 3.5)
Limited cognitive disturbance | 4.90 (3.9; 6.1)
Mild cognitive impairment (nonamnestic) | 5.30 (4.2; 6.8)
Benign senescent forgetfulness (long-term memory score ≥16 centile) | 8.20 (7.0; 9.5)
Age-consistent memory impairment | 12.70 (10.8; 14.9)
Cognitive impairment no dementia | 16.20 (14.4; 18.3)
Minimal dementia | 16.70 (14.8; 18.7)
Mini-Mental State Examination | 35.20 (32.6; 37.9)
Self-reported memory complaint | 42.00 (39.3; 44.8)

Appendix E Table 5 Prevalence of Cognitive Impairment in Older Persons By Age Group and Definition

Study | Reference | Definition | Prevalence (95% CI)
| >65
Canadian Study of Health and Aging | Graham, 1997^148^ | Circumscribed memory impairment (3MSE <78) | 9.4 (8.4; 10.5)
Canadian Study of Health and Aging | Graham, 1997^148^ | Positive on 3MSE (3MSE <78) | 46.3 (43.9; 48.7)
Canadian Study of Health and Aging | Graham, 1997^148^ | Cognitive impairment, no dementia (3MSE <78) | 16.8 (15.1; 18.7)
Canadian Study of Health and Aging | Graham, 1997^148^ | Various categories of impairment (3MSE <78) | 16.8 (15.5; 18.1)
Canadian Study of Health and Aging | Fisk, 2003^151^ | Mild cognitive impairment (3MSE <78), all amnestic MCI criteria met | 1.0 (0.66; 1.40)
Canadian Study of Health and Aging | Fisk, 2003^151^ | Mild cognitive impairment (3MSE <78), IADL impairment allowed | 1.5 (1.04; 1.92)
Canadian Study of Health and Aging | Fisk, 2003^151^ | Mild cognitive impairment (3MSE <78), no subjective memory complaints required | 2.4 (1.84; 2.96)
Canadian Study of Health and Aging | Fisk, 2003^151^ | Mild cognitive impairment (3MSE <78), neither memory complaints nor intact IADL required | 3.0 (2.40; 3.640
Cardiovascular Health Study All Stars Study | Newman, 2009^60^ | African, 3MSE <80 | 17.0 (15.3; 18.90
| 65–74
Canadian Study of Health and Aging | Graham, 1997^148^ | Various categories of impairment (3MSE <78) | 11.0 (9.0; 13.0)
Canadian Study of Health and Aging | No author listed, 2001^152^ | Cognitive loss (3MSE <78) | 9.0 (8.4; 9.6)
| >70
Religious Orders Study | Aggarwal, 2006^94^ | Mild CI | 24.3 (21.4; 27.3)
| >74
Canadian Study of Health and Aging | Rockwood, 1996^147^ | Age associated memory impairment (3MSE <77) | 1.6 (1.4; 1.9)
Canadian Study of Health and Aging | Rockwood, 1996^147^ | Any cognitive impairment (3MSE <77) | 10.0 (9.4; 10.6)
Canadian Study of Health and Aging | Rockwood, 1996^147^ | Any cognitive impairment, without dementia (3MSE <77) | 5.7 (5.2; 6.2)
Canadian Study of Health and Aging | Rockwood, 1996^147^ | Other types of CIND | 4.1 (3.7; 4.5)
Canadian Study of Health and Aging | 75–84
Canadian Study of Health and Aging | Graham, 1997^148^ | Various categories of impairment (3MSE <78) | 24.0 (21.7; 26.3)
Canadian Study of Health and Aging | No author listed, 2001^152^ | Cognitive loss 93MSE <78) | 20.0 (19.2; 20.8)
Canadian Study of Health and Aging | 85+
Canadian Study of Health and Aging | Graham, 1997^148^ | Various categories of impairment (3MSE <78) | 30.3 (27.0; 33.6)
Canadian Study of Health and Aging | No author listed, 2001^152^ | Cognitive loss (3MSE <78) | 41.0 (40.0; 42.0)

Appendix E Table 6 Prevalence of Dementia in Older Persons By Age Group and According to Definition and Severity

Reference | Study | Diagnosis | Prevalence (95% CI)
>65
Graham, 1997^148^ | Canadian Study of Health and Aging | Positive for dementia in 3MSE | 31.6 (29.4; 33.9)
No author listed, 1994^146^ | | Alzheimer’s Disease | 5.1 (4.7; 5.5)
Graham, 1997^148^ | | All types of dementia combined | 8.0 (6.8; 9.4)
No author listed, 1994^146^ | | Dementia | 8.0 (7.5; 8.5)
Fitzpatrick, 2004^57^ | Cardiovascular Health Study | Dementia at baseline | 6.3 (5.6; 7.1)
Graham, 1997^148^ | Canadian Study of Health and Aging | Mild dementia | 2.3 (1.8; 2.8)
Wolfson, 2001^149^ | Among all demented | Mild dementia | 18.8 (16.3; 21.6)
Graham, 1997^148^ | | Moderate dementia | 3.1 (2.5; 3.7)
Wolfson, 2001^149^ | Among all demented | Moderate dementia | 39.3 (36.0; 42.7)
Graham, 1997^148^ | | Severe dementia | 2.6 (2.0; 3.2)
Wolfson, 2001^149^ | Among all demented | Severe dementia | 41.9 (38.6; 45.3)
No author listed, 1994^146^ | | Vascular dementia | 1.5 (1.3; 1.8)
65–74
Graham, 1997^148^ | | Mild dementia | 1.0 (0.4; 1.6)
Graham, 1997^148^ | | Moderate dementia | 0.9 (0.3; 1.5)
Graham, 1997^148^ | | Severe dementia | 0.5 (0.0; 1.0)
>70
Aggarwal, 2006^94^ | Religious Orders Study | Alzheimer’s Disease | 7.35 (5.8; 9.4)
>74
Rockwood, 1996^147^ | Canadian Study of Health and Aging | Alzheimer’s Disease | 3.0 (2.7; 3.4)
Rockwood, 1995^147^ | | Any dementia | 4.6 (4.2; 5)
Rockwood, 1996^147^ | | Vascular dementia | 0.9 (0.7; 1.1)
75–84
Graham, 1997^148^ | Canadian Study of Health and Aging | Mild dementia | 3.4 (2.4; 4.4)
Graham, 1997^148^ | | Moderate dementia | 4.6 (3.5; 5.7)
Graham, 1997^148^ | | Severe dementia | 3.2 (2.2; 4.2)
>85
Wikby, 2005^192^ | NONA Immune Study | Dementia | 14.5 (9.6; 21.4)
Graham, 1997^148^ | Canadian Study of Health and Aging | Mild dementia | 7.2 (5.3; 9.1)
Graham, 1997^148^ | | Moderate dementia | 12.9 (10.5; 15.3)
Graham, 1997^148^ | | Severe dementia | 14.6 (12.1; 17.1)
>90
Kravitz, 2009^52^ | The 90+ Study | All cause dementia | 36.1 (30.1; 42.6)

Appendix E Table 7 Differences in Prevalence of Frailty in Older Persons According to Definition of Frailty

Reference | Sample | Definition of Frailty | Mean (95% CI)
Alameda County Study
Cigolle, 2009^72^ | 574 | Frail according to functional domain model (>2 domains with deficiencies) | 26.0 (22.6; 29.7)
Beaver Dam Eye Study Cohort
Klein, 2005^6^ | 2,515 | Frailty markers: gait time, handgrip strength, peak respiratory flow rate, ability to stand from a sitting position without using arms, best corrected visual acuity. Mild 1–2 markers, moderate 3 markers, severe 4–5 markers | 44.7 (42.8; 46.7)
Canadian Study of Health and Aging
Rockwood, 2007^145^ | 2,305 | Frailty index based on; wt loss >10lbs or greater than 5% of body wt, subjective exhaustion, impaired walking, Timed Up and Go Test > 19s, abnormal strength on physical examination | 16.5 (15.0; 18.1)
Gutman, 2001^143^ | 5,987 | Rockwood frailty index: 1 - Healthy, 2 - Bladder incontinence, 3 - Mild/moderate frailty, 4 - severe frailty | 21.2 (20.2; 22.3)
Gutman, 2001^143^ | 3,925 | Frail: mild/moderate, severe | 8.9 (8.0; 9.8)
Gutman, 2001^143^ | 8,914 | Frail: mild/moderate, severe | 21.2 (20.4; 22.1)
Cardiovascular Health Study
Fried, 2001^55^ | 5,317 | 3 or more of criteria list | 6.9 (6.2; 7.6)
Walston, 2002^56^ | 4,735 | 3 or more of criteria list | 6.3 (5.6; 7.0)
Cigolle, 2009^72^ | 5,317 | Frail according to Biologic Syndrome Model( >3 frailty defining criteria) | 7.0 (6.3; 7.7)
Depression Among Caregivers of Impaired Elders Study
Tennstedt, 1992^120^ | 4,185 | HRCA vulnerability index | 18.9 (17.7; 20.1)
Effects of Two Exercise Interventions Among Community-residing Older Adults Study
Dayhott, 1998^121^ | 84 | Frailty measurement based on two measures: WHOAFC and self-reported health status | 17.9 (11.1; 27.6)
Kaiser Permanente Inter-regional Committee on Aging Study
Brody, 1997^19^ | 5,810 | Eligibility for nursing home placement or long-term placement | 14.6 (13.7;15.5)
National Population Health Survey
Song, 2010^142^ | 2,740 | Frailty index based on the number of deficits divided by the number of variables considered (36). People with nine or more deficits were considered frail. | 22.7 (21.0; 24.3)
New Haven Older Americans Independence Center Study
Hardy, 2005^37^ | 754 | Frail: a timed score of greater than 10 seconds on the rapid gait test (i.e., walking back and forth over a 10-foot (3.048-m) course as quickly as possible) | 42.7 (39.2; 46.3)
The Health and Retirement Study
Cigolle, 2009^72^ | 11,113 | Frail according to at least one model (Functional Domains Model, Burden, or biologic syndrome model) | 30.2 (29.4; 31.1)
Cigolle, 2009^72^ | 11,113 | Frail according to all three models (Functional Domains Model, Burden, or biologic syndrome model) | 3.1 (2.8; 3.4)
Cigolle, 2009^72^ | 11,113 | Frail - >2 domains with deficiencies | 29.0 (28.2; 29.90
Cigolle, 2009^72^ | 11,113 | Frail according to Burden model | 15.4 (14.7; 16.1)
Cigolle, 2009^72^ | 11,113 | Frail according to functional domain model | 20.3 (19.6; 21.1)
Cigolle, 2009^72^ | 11,113 | Frail according to biologic syndrome model | 10.9 (10.3; 11.5)
Cigolle, 2009^72^ | 11,113 | Frail according to an Index of Deficit Accumulation (>0.2) | 32.0 (31.1; 32.9)
Cigolle, 2009^72^ | 11,113 | Frail according to Biologic Syndrome Model(>3 frailty defining criteria) | 11.0 (10.4; 11.6)
Cigolle, 2009^72^ | 1,657 | Frail according to functional domains (weighted for nonresponse percentages) | 21.3 (19.4; 23.3)
Cigolle, 2009^72^ | 1,657 | Frail according to Burden model (weighted (weighted for nonresponse percentages) | 14.8 (13.2; 16.6)
Cigolle, 2009^72^ | 1,657 | Frail according to Biologic Syndrome Model (weighted (weighted for nonresponse percentages) | 13.3 (11.7; 15.0)
The MOBILIZE (Maintenance of Balance, Independent Living, Intellect, And Zest in the Elderly) Boston Study
Kiely, 2009^26^ | 765 | Frailty index based on; weight loss >10 pounds or greater than 5% of body weight, subjective exhaustion, impaired walking, Timed Up and Go Test >19 seconds, abnormal strength on physical examination | 10.0 (8.1; 12.3)
Kiely, 2009^26^ | 765 | Cardiovascular Health Study Frailty Index | 76.0 (72.8; 78.9)

Appendix E Table 8 Prevalence of Frailty in Older Persons According to Severity

Reference | Study | Definition | Prevalence (95% CI)
Passarino, 2007^183^ | The European research program European Challenge for Healthy Aging (ECHA project http:/biologia.unical.it/echa/) | Very frail with no ADL disability (Katz' Index of ADL) | 12.5 (7.6; 19.8)
Passarino, 2007^183^ | The European research program European Challenge for Healthy Aging (ECHA project http:/biologia.unical.it/echa/) | Very frail with at least one ADL disability (Katz' Index of ADL) | 87.5 (80.2; 92.4)
Passarino, 2007^183^ | The European research program European Challenge for Healthy Aging (ECHA project http:/biologia.unical.it/echa/) | Very frail with ≥2 diseases | 70.8 (61.9; 78.3)
Gutman, 2001^143^ | The Canadian Study of Health and Aging | Severe frailty in males (Rockwood scale with >2 totally dependent in transfers or one or more ADLs, incontinent of bowel and bladder, diagnosed with dementia) | 4.4 (4; 4.8)
Gutman, 2001^143^ | The Canadian Study of Health and Aging | Severe frailty in females (Rockwood sale with >2 totally dependent in transfers or one or more ADLs, incontinent of bowel and bladder, diagnosed with dementia) | 5.9 (5.4; 6.4)
Gutman, 2001^143^ | The Canadian Study of Health and Aging | Severe frailty in total sample (Rockwood sale with >2 totally dependent in transfers or one or more ADLs, incontinent of bowel and bladder, diagnosed with dementia) | 5.3 (4.9; 5.8)
Gutman, 2001^143^ | The Canadian Study of Health and Aging | Mild/moderate frailty in 65–74 age group (Rockwood index that includes one of the following: assistance with mobility or one or more ADLs, cognitive impairment without dementia, bowel or bladder incontinence) | 7.5 (7; 8.1)
Gutman, 2001^143^ | The Canadian Study of Health and Aging | Mild/moderate frailty in 75–84 age group | 18.4 (17.6; 19.2)
Gutman, 2001^143^ | The Canadian Study of Health and Aging | Mild/moderate frailty in 85+ age group | 34.5 (33.5; 35.5)
Gutman, 2001^143^ | The Canadian Study of Health and Aging | Mild/moderate frailty in total sample | 15.9 (15.2; 16.7)
Gutman, 2001^143^ | The Canadian Study of Health and Aging | Severe frailty in 65–74 age group | 1.4 (1.2; 1.7)
Gutman, 2001^143^ | The Canadian Study of Health and Aging | Severe frailty in 75–84 age group | 6.1 (5.6; 6.6)
Gutman, 2001^143^ | The Canadian Study of Health and Aging | Severe frailty in 85+ age group | 14.7 (14; 15.5)

Appendix E Table 9 Prevalence of ADL Disability in Older Persons

Reference | Country | Study | Year of Study | Sample Size | Disability Type 2 | Prevalence (95% CI) | Sub-Population
Prevalence of Any ADL Disability
Wiener, 1990^30^ | USA | National Health Interview Survey, Supplement on Aging | 1984 | 11,425 | ≥1 ADL (5 items) | 5.0 4.6 (5.4) | Age 65+
Fuller-Thompson, 2009^3^ | USA | American Community Survey (US Census) | 2003 | 202,956 | ≥ 1 ADL (3 items) | 5.4 (5.3; 5.5)
Wiener, 1990^30^ | USA | Survey on Income and Program Participation | 1984 | 5,900 | ≥ 1 ADL (4 items) | 5.8 (5.2; 6.4) | Age 65+
Fuller-Thompson, 2009^4^ | USA | American Community Survey (US Census) | 2000 | 512,768 | ≥ 1 ADL (3 items) | 8.8 (8.8; 8.9)
Goins, 2007^7^ | USA | Census Public Use 5% Microdata sample | 2000 | 2,944,755 | ≥ 1 ADL (3 items) | 9.1%
Raji, 2004^199^ | USA | H-EPESE | 1993–2001 | 2,731 | ≥ 1 ADL (7 items) | 11.0 (9.9; 12.2)
Bannerman, 2002^139^ | Australia | Australian Longitudinal study on aging | 1992–1994 | 1,272 | ≥ 1 ADL (# items not specified) | 11.9%
Chen, 2004^213^ | USA | Longitudinal Study on Aging | 1984 | 7,512 | ≥ 1 ADL (7 items) | 12.1 (11.4; 12.8) | Age 70+
Corti, 1994^12^ | USA | EPESE Boston, New Haven, Iowa sites Established Populations for Epidemiologic Studies of the Elderly | 1987–1992 | 4,116 | ≥ 1 ADL (2 items) | 12.2
Tabbarah, 2001^2^ | USA | Survey of Asset and Health Dynamics of the Oldest Old (AHEAD) | 1994 | 7,447 | ≥ 1 ADL (6 items) “Receive help performing activity” | 13.9 (13.1; 14.7)
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 11,701 | ≥ 1 ADL (6 items) | 16.0 (15.3; 16.7) | Development cohort
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 8,009 | ≥1 ADL (6 items) | 18.0 (17.2; 18.9) | Validation cohort
Hanlon, 2002^11^ | USA - North Carolina | EPESE - New Haven Site Established Populations for Epidemiologic Studies of the Elderly | 1989/90 & 1992/93 | 3,234 | ≥ 1 ADL (5 items) | 18.3 (17; 19.7)
Newman, 2009^60^ | USA | Cardiovascular Health Study All Star | 1992–2006 | 1,677 | ≥ 1 ADL (5 items) | 25.6%
Prevalence of Moderate ADL Disability
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5,432 | 1–2 ADL (6 items) | 20.5
Rakowski, 1993^214^ | USA | Longitudinal Study on Aging | 1984 | 7,469 | 1–2 ADLs (7 items) | 16.1 (15.3; 16.9)
Prevalence of Severe ADL Disability
Rakowski, 1993^214^ | USA | Longitudinal Study on Aging | 1984 | 7,469 | 3–4 ADLS (7 items) | 6.0 (5.5; 6.6)
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5,432 | ≥ 3 ADLs (6 items) | 7.8%
Rakowski, 1993^214^ | USA | Longitudinal Study on Aging | 1984 | 7,469 | 5–7 ADLS (7 items) | 4.8 (4.3; 5.3)
Prevalence of Bathing ADL Disability
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1980 | 535 | Bathing | 3.9 (2.6; 5.9)
Wiener, 1990^30^ | USA | National Health Interview Survey, Supplement on Aging | 1984 | 11,425 | Bathing | 4.6 (4.2; 5) | Age 65+
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 11,701 | Bathing | 6.0 (5.6; 6.4) | Development cohort
Albert, 2006^48^ | USA - NYC | SITE Sources of Independence in the Elderly | 1999–2001 | 361 | Bathing | 6.7% | Total population
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 8,009 | Bathing | 8.0 (7.4; 8.6) | Validation cohort
Tabbarah, 2001^2^ | USA | Survey of Asset and Health Dynamics of the Oldest Old (AHEAD) | 1994 | 7,447 | Bathing “Receive help performing activity” | 8.8 (8.2; 9.5)
Johnson, 2000^31^ | USA | National Survey on Self-Care and Aging | 1990–1991 | 3,485 | Bathing | 9.0 (8.1; 10)
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1985 | 535 | Bathing | 14.7 (11.9; 18)
Prevalence of Dressing/Hygeine ADL Disability
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1980 | 535 | Dressing | 0.8 (0.3; 2)
Wiener, 1990^30^ | USA | National Health Interview Survey, Supplement on Aging | 1984 | 11,425 | Dressing | 2.9 (2.6; 3.2) | Age 65+
Johnson, 2000^31^ | USA | National Survey on Self-Care and Aging | 1990–1991 | 3,485 | Dressing | 5.0 (4.3; 5.8)
Tabbarah, 2001^2^ | USA | Survey of Asset and Health Dynamics of the Oldest Old (AHEAD) | 1994 | 7,447 | Dressing “Receive help performing activity” | 7.7 (7.1; 8.3)
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 11,701 | Dressing | 9.0 (8.5; 9.5) | Development cohort
Murtogh, 2004^215^ | USA | Alumni Health Study | 1999 | 1,348 | Hygiene | 9.2 | Sample Age 73+ Mean age 79
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1985 | 535 | Dressing | 9.3 (7.1; 12.1)
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 8,009 | Dressing | 11.0 (10.3; 11.7) | Validation cohort
Prevalence of Eating ADL Disability
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1980 | 533 | Eating | 0.4 (0.1; 1.5)
Wiener, 1990^30^ | USA | National Health Interview Survey, Supplement on Aging | 1984 | 11,425 | Eating | 0.7 (0.6; 0.9) | Age 65+
Johnson, 2000^31^ | USA | National Survey on Self-Care and Aging | 1990/1991 | 3,485 | Eating | 1.0 (0.7; 1.4)
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1,920 | Eating | 1.1 (0.7; 1.7) | White women
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1,920 | Eating | 1.3 (0.9; 1.9) | White men
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1,920 | Eating | 1.5 (1; 2.2) | Black women
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1985 | 533 | Eating | 2.2 (1.2; 3.9)
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 11,701 | Eating | 3.0 (2.7; 3.3) | Development cohort
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 8,009 | Eating | 4.0 (3.6; 4.5) | Validation cohort
Tabbarah, 2001^2^ | USA | Survey of Asset and Health Dynamics of the Oldest Old (AHEAD) | 1994 | 7,447 | Eating “Receive help performing activity” | 4.5 (4.1; 5)
Murtogh, 2004^215^ | USA | Alumni Health Study | 1999 | 1,348 | Eating | 7.3 | Sample Age 73+ Mean age 79
Prevalence of Toileting ADL Disability
Wiener, 1990^30^ | USA | National Health Interview Survey, Supplement on Aging | 1984 | 11,425 | Toileting | 2.4 (2.1; 2.7) | Age 65+
Tabbarah, 2001^2^ | USA | Survey of Asset and Health Dynamics of the Oldest Old (AHEAD) | 1994 | 7,447 | Toileting “Receive help performing activity” | 2.5 (2.2; 2.9)
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 11,701 | Toileting | 5.0 (4.6; 5.4) | Development cohort
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 8,009 | Toileting | 6.0 (5.5; 6.5) | Validation cohort
Prevalence of Transferring ADL Disability
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1980 | 536 | Transferring | 0.4 (0.1; 1.5)
Wiener, 1990^30^ | USA | National Health Interview Survey, Supplement on Aging | 1984 | 11,425 | Transferring | 2.6 (2.3; 2.9) | Age 65+
Wiener, 1990^30^ | USA | National Health Interview Survey, Supplement on Aging | 1984 | 5,900 | Transferring | 2.6 (2.2; 3) | Age 65+
Tabbarah, 2001^2^ | USA | Survey of Asset and Health Dynamics of the Oldest Old (AHEAD) | 1994 | 7,447 | Transferring “Receive help performing activity” | 3.3 (2.9; 3.7)
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1985 | 536 | Transferring | 5.8 (4.1; 8.1)
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 11,701 | Transferring | 7.0 (6.6; 7.5) | Development cohort
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 8,009 | Transferring | 9.0 (8.4; 9.6) | Validation cohort
Murtogh, 2004^215^ | USA | Alumni Health Study | 1999 | 1,348 | Transferring | 21.1 | Sample Age 73+ Mean age 79
Prevalence of Walking ADL Disability
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1980 | 535 | Walking | 0.8 (0.3; 2)
Tabbarah, 2001^2^ | USA | Survey of Asset and Health Dynamics of the Oldest Old (AHEAD) | 1994 | 7,447 | Walking “Receive help performing activity” | 5.9 (5.4; 6.5)
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1985 | 535 | Walking | 7.7 (5.7; 10.3)
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 11,701 | Walking | 11.0 (10.4; 11.6) | Development cohort
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 8,009 | Walking | 13.0 (12.3; 13.8) | Validation cohort
Murtogh, 2004^215^ | USA | Alumni Health Study | 1999 | 1,348 | Walking | 20.6 | Sample Age 73+ Mean age 79
Prevalence of ADL Disability in Women
Crimmins, 1997^86^ | USA | Longitudinal Study on Aging | 1984 | 3,081 | ≥ 1 ADL (7 items) | 8.1 (7.2; 9.1) | Women age 76+
Crimmins, 1997^86^ | USA | Longitudinal Study on Aging | 1988 | 2,842 | ≥ 1 ADL (7 items) | 9.6 (8.6; 10.7) | Women age 76+
Fuller-Thompson, 2009^4^ | USA | American Community Survey (US Census) | 2000 | 512,768 | ≥ 1 ADL (3 items) | 10.2 (10.1; 10.2) | Women
Crimmins, 1997^86^ | USA | Longitudinal Study on Aging | 1990 | 2,782 | ≥ 1 ADL (7 items) | 10.2 (9.1; 11.4) | Women age 76+
Crimmins, 1997^86^ | USA | Longitudinal Study on Aging | 1986 | 2,904 | ≥ 1 ADL (7 items) | 10.6 (9.5; 11.8) | Women age 76+
Corti, 1994^12^ | USA | EPESE Boston, New Haven, Iowa sites Established Populations for Epidemiologic Studies of the Elderly | 1987–1992 | 4,116 | ≥ 1 ADL (# items not specified) | 13.2 (12.2; 14.3) | Women
Bannerman, 2002^139^ | Australia | Australian Longitudinal study on aging | 1992–1994 | 1,272 | ≥ 1 ADL (# items not specified) | 14.0 (12.2; 16)
Newman, 2009^60^ | USA | Cardiovascular Health Study All Stars | 1992–2006 | 1,677 | ≥ 1 ADL (5 items) | 24.7 (22.7; 26.8) | Women age 85–88
Newman, 2009^60^ | USA | Cardiovascular Health Study All Stars | 1992–2006 | 1,677 | ≥ 1 ADL (5 items) | 24.8 (22.8; 26.9) | Women age ≤ 82
Newman, 2009^60^ | USA | Cardiovascular Health Study All Stars | 1992–2006 | 1,677 | ≥ 1 ADL (5 items) | 27.3 (25.2; 29.5) | Women age 83–84
Newman, 2009^60^ | USA | Cardiovascular Health Study All Stars | 1992–2006 | 1,677 | ≥ 1 ADL (5 items) | 29.4% 27.3 31.6 | Women age 89+
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5432 | 1–2 ADLs (6 items) | 21.7 | All women
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5432 | 1–2 ADLs (6 items) | 33.0 (31.8; 34.3) | Women age ≥ 80
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5432 | 1–2 ADLs (6 items) | 18.0 (17; 19) | Women age 65–79
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5432 | ≥ 3 ADLs (6 items) | 7.0% | All women
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5432 | ≥ 3 ADLs (6 items) | 10.0 (9.2; 10.8) | Women age ≥ 80
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5432 | ≥ 3 ADLs (6 items) | 6.0 (5.4; 6.7) | Women age 65–79
Albert, 2006^48^ | USA - NYC | SITE Sources of Independence in the Elderly | 1999–2001 | 361 | Bathing | 6.9 (4.7; 10) | Women age <75
Albert, 2006^48^ | USA - NYC | SITE Sources of Independence in the Elderly | 1999–2001 | 361 | Bathing | 7.7 | All women
Albert, 2006^48^ | USA - NYC | SITE Sources of Independence in the Elderly | 1999–2001 | 361 | Bathing | 8.0 (5.6; 11.3) | Women age ≥ 75
Murtogh, 2004^215^ | USA | Alumni Health Study | 1999 | 1,348 | Dressing/grooming | 17.1 (15.2; 19.2) | Sample Age 73+ Mean age 79 Women
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1,920 | Eating | 1.1 (0.7; 1.7) | White women
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1,920 | Eating | 1.2 | All women
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1,920 | Eating | 1.5 (1; 2.2) | Black women
Murtogh, 2004^215^ | USA | Alumni Health Study | 1999 | 1,348 | Eating | 11.8 (10.2; 13.6) | Sample Age 73+ Mean age 79 Women
Murtogh, 2004^215^ | USA | Alumni Health Study | 1999 | 1,348 | Hygiene | 12.8 (11.1; 14.7) | Sample Age 73+ Mean age 79 Women
Murtogh, 2004^215^ | USA | Alumni Health Study | 1999 | 1,348 | Transferring | 27.6 (25.3; 30) | Sample Age 73+ Mean age 79 Women
Murtogh, 2004^215^ | USA | Alumni Health Study | 1999 | 1,348 | Walking | 27.3 (25; 29.7) | Sample Age 73+ Mean age 79 Women
Prevalence of ADL Disability in Men
Crimmins, 1997^86^ | USA | Longitudinal Study on Aging | 1984 | 3,081 | ≥ 1 ADL (7 items) | 6.1 (5.3; 7) | Men age 76+
Crimmins, 1997^86^ | USA | Longitudinal Study on Aging | 1986 | 2,904 | ≥ 1 ADL (7 items) | 6.5 (5.7; 7.5) | Men age 76+
Fuller-Thompson, 2009^4^ | USA | American Community Survey (US Census) | 2000 | 512,768 | ≥ 1 ADL (3 items) | 7.1 (7; 7.1) | Men
Crimmins, 1997^86^ | USA | Longitudinal Study on Aging | 1990 | 2,782 | ≥ 1 ADL (7 items) | 7.5 (6.6; 8.5) | Men age 76+
Crimmins, 1997^86^ | USA | Longitudinal Study on Aging | 1988 | 2,842 | ≥ 1 ADL (7 items) | 7.9 (7; 9) | Men age 76+
Bannerman, 2002^139^ | Australia | Australian Longitudinal study on aging | 1992–1994 | 1,272 | ≥ 1 ADL (# items not specified) | 10.0 (8.5; 11.8)
Corti, 1994^12^ | USA | EPESE Boston, New Haven, Iowa sites Established Populations for Epidemiologic Studies of the Elderly | 1987–1992 | 4,116 | ≥ 1 ADL (2 items) | 10.3 (9.4; 11.3) | Men
Newman, 2009^60^ | USA | Cardiovascular Health Study All Stars | 1992–2006 | 1,677 | ≥ 1 ADL (5 items) | 12.8% 11.3 14.5 | Men age 83–84
Newman, 2009^60^ | USA | Cardiovascular Health Study All Stars | 1992–2006 | 1,677 | ≥ 1 ADL (5 items) | 16.7 (15; 18.6) | Men age ≤ 82
Newman, 2009^60^ | USA | Cardiovascular Health Study All Stars | 1992–2006 | 1,677 | ≥ 1 ADL (5 items) | 22.8 (20.9; 24.9) | Men age 85–88
Newman, 2009^60^ | USA | Cardiovascular Health Study All Stars | 1992–2006 | 1,677 | ≥ 1 ADL (5 items) | 23.7 (21.7; 25.8) | Men age 89+
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5,432 | 1–2 ADL (6 items) | 19.1 | All men
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5,432 | 1–2 ADL (6 items) | 28.0 (26.8; 29.2) | Men age ≥ 80
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5,432 | 1–2 ADL (6 items) | 17.0 (16; 18) | Men age 65–79
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5,432 | 3+ ADLs (6 items) | 7.0 | All men
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5,432 | 3+ ADLs (6 items) | 11.0 (10.2; 11.9) | Men age ≥ 80
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5,432 | 3+ ADLs (6 items) | 6.0 (5.4; 6.7) | Men age 65–79
Albert, 2006^48^ | USA - NYC | SITE Sources of Independence in the Elderly | 1999–2001 | 361 | Bathing | 0.0 (0; 2.2) | Men age <75
Albert, 2006^48^ | USA - NYC | SITE Sources of Independence in the Elderly | 1999–2001 | 361 | Bathing | 4.4 | Sample age 73+ Mean age 79 All men
Albert, 2006^48^ | USA - NYC | SITE Sources of Independence in the Elderly | 1999–2001 | 361 | Bathing | 6.7 (4.5; 9.80) | Men age ≥ 75
Murtogh, 2004^215^ | USA | Alumni Health Study | 1999 | 1,348 | Dressing/grooming | 13.2 (11.5; 15.1) | Sample age 73+ Mean age 79 men
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1,920 | Eating | .60 | Black men
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1,920 | Eating | 1.2 | All men
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1,920 | Eating | 1.3 (0.9; 1.9) | White men
Murtogh, 2004^215^ | USA | Alumni Health Study | 1999 | 1,348 | Eating | 6.0 (4.9; 7.4) | Sample age 73+ Mean age 79 Men
Murtogh, 2004^215^ | USA | Alumni Health Study | 1999 | 1,348 | Hygiene | 8.1 (6.8; 9.7) | Sample age 73+ Mean age 79 Men
Murtogh, 2004^215^ | USA | Alumni Health Study | 1999 | 1,348 | Transferring | 19.2 (17.2; 21.4) | Men
Murtogh, 2004^215^ | USA | Alumni Health Study | 1999 | 1,348 | Walking | 18.6 (16.6; 20.8) | Sample age 73+ Mean age 79 Men
Prevalence of ADL Disability by Ethnicity
Fuller-Thompson, 2009^3^ | USA | American Community Survey (US Census) | 2003 | 202,956 | ≥ 1 ADL (3 items) | 7.5 (7.4; 7.6) | Black men age 65–74
Fuller-Thompson, 2009^3^ | USA | American Community Survey (US Census) | 2003 | 202,956 | ≥ 1 ADL (3 items) | 4.7 (4.6; 4.8) | White men age 65–74
Fuller-Thompson, 2009^3^ | USA | American Community Survey (US Census) | 2003 | 202,956 | ≥ 1 ADL (3 items) | 10.7 (10.6; 10.8) | Black women age 65–74
Fuller-Thompson, 2009^3^ | USA | American Community Survey (US Census) | 2003 | 202,956 | ≥ 1 ADL (3 items) | 5.2% (5.1; 5.3) | White women age 65–74
Goins, 2007^7^ | USA | Census Public Use 5% Microdata sample | 2000 | 2,944,755 | ≥ 1 ADL (3 items) | 13.6 (13.6; 13.6) | African American
Goins, 2007^7^ | USA | Census Public Use 5% Microdata sample | 2000 | 2,944,755 | ≥ 1 ADL (3 items) | 11.6 (11.6; 11.6) | American Indian
Goins, 2007^7^ | USA | Census Public Use 5% Microdata sample | 2000 | 2,944,755 | ≥ 1 ADL (3 items) | 8.7 (8.7; 8.7) | White
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1,920 | Eating | .60 | Black men
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1,920 | Eating | 1.1 (0.7; 1.7) | White men
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1,920 | Eating | 1.2 | Black men & women
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1,920 | Eating | 1.2 | White men & women
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1,920 | Eating | 1.3 (0.9; 1.9) | White women
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1,920 | Eating | 1.5 (1; 2.2) | Black women
Prevalence of ADL Disability by Age
Newman, 2009^60^ | USA | Cardiovascular Health Study All Star | 1992–2006 | 1,677 | ≥ 1 ADL (5 items) | 16.7 (15; 18.6) | Men age ≤ 82
Newman, 2009^60^ | USA | Cardiovascular Health Study All Star | 1992–2006 | 1,677 | ≥ 1 ADL (5 items) | 12.8 (11.3; 14.5) | Men age 83–84
Newman, 2009^60^ | USA | Cardiovascular Health Study All Star | 1992–2006 | 1,677 | ≥ 1 ADL (5 items) | 22.8 (20.9; 24.9) | Men age 85–88
Newman, 2009^60^ | USA | Cardiovascular Health Study All Star | 1992–2006 | 1,677 | ≥ 1 ADL (5 items) | 23.7 (21.7; 25.8) | Men age 89+
Newman, 2009^60^ | USA | Cardiovascular Health Study All Star | 1992–2006 | 1,677 | ≥ 1 ADL (5 items) | 24.8 (22.8; 26.9) | Women age ≤ 82
Newman, 2009^60^ | USA | Cardiovascular Health Study All Star | 1992–2006 | 1,677 | ≥ 1 ADL (5 items) | 27.3 (25.2; 29.5) | Women age 83–84
Newman, 2009^60^ | USA | Cardiovascular Health Study All Star | 1992–2006 | 1,677 | ≥ 1 ADL (5 items) | 24.7 (22.7; 26.8) | Women age 85–88
Newman, 2009^60^ | USA | Cardiovascular Health Study All Star | 1992–2006 | 1,677 | ≥ 1 ADL (5 items) | 29.4 (27.3; 31.6) | Women age 89+
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5,432 | 1–2 ADLs (6 items) | 33.0 (31.8; 34.3) | Women age ≥ 80
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5,432 | 1–2 ADLs (6 items) | 18.0 (17; 19) | Women age 65–79
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5,432 | 1–2 ADL (6 items) | 28.0 (26.8; 29.2) | Men age ≥ 80
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5,432 | 1–2 ADL (6 items) | 17.0 (16; 18) | Men age 65–79
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5,432 | ≥ 3 ADLs (6 items) | 10.0 (9.2; 10.8) | Women age ≥ 80
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5,432 | ≥ 3 ADLs (6 items) | 6.0 (5.4; 6.7) | Women age 65–79
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5,432 | ≥ 3 ADLs (6 items) | 11.0(10.2; 11.9) | Men age ≥ 80
Gardener, 2006^160^ | England | ELSA - English Longitudinal Study of Aging | 2002 | 5,432 | ≥ 3 ADLs (6 items) | 6.0 (5.4; 6.7) | Men age 65–79
Albert, 2006^48^ | USA - NYC | SITE Sources of Independence in the Elderly | 1999–2001 | 361 | Bathing | 0.0 (0; 2.2) | Men age <75
Wiener, 1990^30^ | USA | National Health Interview Survey, Supplement on Aging | 1984 | 7,054 | Bathing | 2.5 (2.2; 2.9) | Age 65–74
Wiener, 1990^30^ | USA | National Health Interview Survey, Supplement on Aging | 1984 | 11,425 | Bathing | 4.6(4.2; 5) | Age 65+
Albert, 2006^48^ | USA - NYC | SITE Sources of Independence in the Elderly | 1999–2001 | 361 | Bathing | 6.7 (4.5; 9.8) | Men age ≥ 75
Albert, 2006^48^ | USA - NYC | SITE Sources of Independence in the Elderly | 1999–2001 | 361 | Bathing | 6.9 (4.7; 10) | Women age < 75
Albert, 2006^48^ | USA - NYC | SITE Sources of Independence in the Elderly | 1999–2001 | 361 | Bathing | 8.0 (5.6; 11.3) | Women age ≥ 75
Wiener, 1990^30^ | USA | National Health Interview Survey, Supplement on Aging | 1984 | 7,054 | Dressing | 1.8 (1.5; 2.1) | Age 65–74
Wiener, 1990^30^ | USA | National Health Interview Survey, Supplement on Aging | 1984 | 11,425 | Dressing | 2.9 (2.6; 3.2) | Age 65+
Wiener, 1990^30^ | USA | National Health Interview Survey, Supplement on Aging | 1984 | 7,054 | Eating | 0.4 (0.3; 0.6) | Age 65–74
Wiener, 1990^30^ | USA | National Health Interview Survey, Supplement on Aging | 1984 | 11,425 | Eating | 0.7 (0.6; 0.9) | Age 65+
Wiener, 1990^30^ | USA | National Health Interview Survey, Supplement on Aging | 1984 | 7,054 | Toileting | 1.3 (1.1; 1.6) | Age 65–74
Wiener, 1990^30^ | USA | National Health Interview Survey, Supplement on Aging | 1984 | 11,425 | Toileting | 2.4 (2.1; 2.7) | Age 65+
Wiener, 1990^30^ | USA | National Health Interview Survey, Supplement on Aging | 1984 | 7,054 | Transferring | 1.5 (1.2; 1.8) | Age 65–74
Wiener, 1990^30^ | USA | National Health Interview Survey, Supplement on Aging | 1984 | 11,425 | Transferring | 2.6 (2.3; 2.9) | Age 65+
ADL Disability in Frail Population
Wiener, 1990^30^ | USA | National Long-Term Care Survey | 1982 | 17,658 | ≥ 1 ADL (5 items) | 7.8 (7.4; 8.2) | Age 65+
Wiener, 1990^30^ | USA | National Long-Term Care Survey | 1982 | 17,658 | ADL bathing | 6.3 (6; 6.7) | Age 65+
Wiener, 1990^30^ | USA | National Long-Term Care Survey | 1982 | 10,439 | ADL bathing | 4.0 (3.6; 4.4) | Age 65–74
Wiener, 1990^30^ | USA | National Long-Term Care Survey | 1982 | 17,658 | Bathing | 6.3 (6; 6.7) | Age 65+
Wiener, 1990^30^ | USA | National Long-Term Care Survey | 1982 | 17,658 | Dressing | 4.2 (3.9; 4.5) | Age 65+
Wiener, 1990^30^ | USA | National Long-Term Care Survey | 1982 | 17,658 | Eating | 2.5 (2.3; 2.7) | Age 65+
Wiener, 1990^30^ | USA | National Long-Term Care Survey | 1982 | 17,658 | Toileting | 3.4 (3.1; 3.7) | Age 65+
Wiener, 1990^30^ | USA | National Long-Term Care Survey | 1982 | 17,658 | Transferring | 4.2 (3.9; 4.5) | Age 65+
Wiener, 1990^30^ | USA | National Long-Term Care Survey | 1984 | 12,687 | ≥ 1 ADL (5 items) | 4.9 (4.5; 5.3) | Age 65+
Wiener, 1990^30^ | USA | National Long-Term Care Survey | 1984 | 19,720 | ADL bathing | 6.3 (6; 6.6) | Age 65+
Wiener, 1990^30^ | USA | National Long-Term Care Survey | 1984 | 12,687 | ADL bathing | 3.8 (3.5; 4.1) | Age 65–74
Wiener, 1990^30^ | USA | National Long-Term Care Survey | 1984 | 19,720 | Bathing | 6.3 (6; 6.6) | Age 65+
Wiener, 1990^30^ | USA | National Long-Term Care Survey | 1984 | 19,720 | Dressing | 4.0 (3.7; 4.3) | Age 65+
Wiener, 1990^30^ | USA | National Long-Term Care Survey | 1984 | 19,720 | Eating | 2.3 (2.1; 2.5) | Age 65+
Wiener, 1990^30^ | USA | National Long-Term Care Survey | 1984 | 19,720 | Toileting | 3.3 (3.1; 3.6) | Age 65+
Wiener, 1990^30^ | USA | National Long-Term Care Survey | 1984 | 19,720 | Transferring | 4.0 (3.7; 4.3) | Age 65+
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 2,232 | ≥ 3 ADLs (6 items) | 50.0 (47.9; 52.1) | Frail group development cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 1,667 | ≥ 3 ADLs (6 items) | 52.0 (49.6; 54.4) | Frail group validation cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 1,667 | Bathing | 86.4 (84.7; 88) | Validation cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 2,232 | Bathing | 81.7 (80; 83.2) | Development cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 1,667 | Dressing | 69.8 (67.6; 72) | Validation cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 2,232 | Dressing | 62.6 (60.6; 64.6) | Development cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 2,232 | Eating | 21.4 (19.7; 23.2) | Development cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 1,667 | Eating | 28.9 (26.8; 31.1 | Validation cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 2,232 | Finances | 58.1 (56.00; 60.10) | Development cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 1,667 | Finances | 68.5 (66.20; 70.70) | Validation cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 2,232 | Heavy chores | 94.6 (93.60; 95.50) | Development cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 1,667 | Heavy chores | 97.0 (96.10; 97.70) | Validation cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 2,232 | Housework | 79.3 (77.60; 80.90) | Development cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 1,667 | Housework | 74.8 (72.70; 76.80) | Validation cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 2,232 | Laundry | 83.0 (81.40; 84.50) | Development cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 1,667 | Laundry | 85.6 (83.80; 87.20) | Validation cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 2,232 | Meal prep | 74.8 (73.00; 76.60) | Development cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 1,667 | Meal prep | 65.7 (63.40; 67.90) | Validation cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 2,232 | Medication management | 37.3 (35.30; 39.30) | Development cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 1,667 | Medication management | 39.0 (36.70; 41.40) | Validation cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 2,232 | Shopping | 83.2 (81.60; 84.70) | Development cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 1,667 | Shopping | 85.9 (84.10; 87.50) | Validation cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 2,232 | Toileting | 46.3 (44.2; 48.4) | Development cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 1,667 | Toileting | 45.9 (43.5; 48.3) | Validation cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 1,667 | Transferring | 39.8 (37.5; 42.2) | Validation cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 2,232 | Transferring | 45.6 (43.5; 47.7) | Development cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 2,232 | Transportation | 79.6 (77.90; 81.20) | Development cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 1,667 | Transportation | 74.2 (72.00; 76.20) | Validation cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 1,667 | Walking | 42.0 (39.7; 44.4) | Validation cohort
Carey, 2008^129^ | USA | PACE Program of All- Inclusive Care for the Elderly | 1988–1996 | 2,232 | Walking | 53.6 (51.5; 55.7) | Development cohort
Gill, 2008^43^ | USA - New Haven CT | Precipitating Events Project | 1998–2004 | 491 | ≥ 1 ADL (4 items) | 31.2 (27.3; 35.4)

Appendix E Table 10 Prevalence of IADL Disability in Older Persons

Reference | Country | Study | Year of Study | Sample Size | Disability Type 2 | Prevalence (95% CI) | Sub-Population
Prevalence of Any IADL Disability
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 11,701 | ≥ 1 IADL (5 items) | 12.0 (11.40; 12.60) | Development cohort
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 8,009 | ≥ 1 IADL (5 items) | 16.0 (15.20; 16.80) | Validation cohort
Ganguli, 2002^85^ | USA | Monongahela Valley Independent Elders Survey | 1987–1999 | 1,064 | 1–3 IADL (# items not specified OARS) | 23.8 (21.30; 26.50)
Tabbarah, 2001^2^ | USA | Survey of Asset and Health Dynamics of the Oldest Old (AHEAD) | 1994 | 7,447 | ≥ 1 IADL (5 items) “Need help performing activity” | 26.5 (25.50; 27.50)
Chen, 2004^213^ | USA | Longitudinal Study on Aging | 1984 | 7,512 | ≥ 1 IADL (6 items) | 26.90 (25.90; 27.90)
Hanlon, 2002^11^ | USA | EPESE - New Haven Site Established Populations for Epidemiologic Studies of the Elderly | 1989/90 & 1992/93 | 3,234 | ≥ 1 IADL (3 items) | 35.5 (33.90; 37.20)
Espino, 2006^200^ | USA | H-EPESE Hispanic Established Populations for Epidemiologic Studies of the Elderly | 1993–2001 | 3,050 | ≥ 1 IADL (# items not specified) | 46.7 (44.90; 48.50)
Prevalence of Moderate IADL Disability
Rolland, 2006^165^ | France | EPIDOS Epidemiologie de l'osteoporose study | 1992–1998 | 7,250 | 2 IADL (8 items) | 7.2 (6.60; 7.80)
Rolland, 2006^165^ | France | EPIDOS Epidemiologie de l'osteoporose study | 1992–1998 | 7,250 | 1 IADL (8 items) | 15.1 (14.30; 15.90)
Rakowski, 1993^214^ | USA | Longitudinal Study on Aging | 1984 | 7,474 | 1–2 IADL (6 items) | 21.3 (20.40; 22.20)
Johnson, 2000^31^ | USA | National Survey on Self-Care and Aging | 1990/1991 | 3,485 | ≥ 2 IADL (6 items) | 31.0 (29.50; 32.60)
Prevalence of Severe IADL Disability
Rakowski, 1993^214^ | USA | Longitudinal Study on Aging | 1984 | 7,474 | 5–6 IADL (6 items) | 4.5 (4.00; 5.00)
Ganguli, 2002^85^ | USA - Washington & Westmorel and Counties in PA | Monongahela Valley Independent Elders Survey | 1987–1999 | 1,064 | ≥ 4 IADL (# items not specified OARS) | 5.7 (4.50; 7.30)
Rakowski, 1993^214^ | USA | Longitudinal Study on Aging | 1984 | 7474 | 3–4 IADL (6 items) | 6.2 (5.70; 6.80)
Rolland, 2006^165^ | France | EPIDOS Epidemiologie de l'osteoporose study | 1992–1998 | 7250 | ≥ 3 IADL (8 items) | 8.5 (7.90; 9.20)
Kiely, 2009^26^ | USA | MOBILIZE (Maintenance of Balance, Independent Living, Intellect, and Zest in the Elderly) Boston Study (MBS) | Not reported | 765 | 3–4 IADL (3 items) | 21.2 (18.40; 24.20)
Prevalence of Finance IADL Disability
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 11701 | Finances | 8.0 (7.50; 8.50) | Development cohort
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 8009 | Finances | 9.0 (8.40; 9.60) | Validation cohort
Tabbarah, 2001^2^ | USA | Survey of Asset and Health Dynamics of the Oldest Old (AHEAD) | 1994 | 7,447 | Finances “Need help performing activity” | 17.9 (17.00; 18.80)
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1980 | 523 | Finances | 19.3 (16.10; 22.90)
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1985 | 523 | Finances | 36.7 (32.70; 40.90)
Prevalence of Housekeeping IADL Disability
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1980 | 500 | Housekeeping | 35.8 (31.70; 40.10)
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1985 | 500 | Housekeeping | 48.0 (43.60; 52.40)
Albert, 2006^48^ | USA - NYC | SITE Sources of Independence in the Elderly | 1999–2001 | 361 | Housekeeping | 7.5
Prevalence of Meal Preparation IADL Disability
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Meal prep | 10.1
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 11701 | Meal prep | 10.0 (9.50; 10.60) | Development cohort
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 8009 | Meal prep | 12.0 (11.30; 12.70) | Validation cohort
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1980 | 530 | Meal prep | 32.4 (28.50; 36.50)
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1985 | 530 | Meal prep | 34.1 (30.20; 38.20)
Tabbarah, 2001^2^ | USA | Survey of Asset and Health Dynamics of the Oldest Old (AHEAD) | 1994 | 7,447 | Meal prep “Need help performing activity” | 7.1 (6.50; 7.70)
Prevalence of Medication IADL Disability
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 11701 | Medication management | 3.0 (2.70; 3.30) | Development cohort
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 8009 | Medication management | 3.0 (2.60; 3.40) | Validation cohort
Tabbarah, 2001^2^ | USA | Survey of Asset and Health Dynamics of the Oldest Old (AHEAD) | 1994 | 7,447 | Medication management “Need help performing activity” | 4.7 (4.20; 5.20)
Prevalence of Shopping IADL Disability
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Shopping | 13.8
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 11701 | Shopping | 11.0 (10.40; 11.60) | Development cohort
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 8009 | Shopping | 14.0 (13.30; 14.80) | Validation cohort
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1980 | 522 | Shopping | 32.9 (29.00; 37.00)
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1985 | 522 | Shopping | 41.3 (37.10; 45.60)
Tabbarah, 2001^2^ | USA | Survey of Asset and Health Dynamics of the Oldest Old (AHEAD) | 1994 | 7,447 | Shopping “Need help performing activity” | 14.6 (13.80; 15.40)
Prevalence of Telephone IADL Disability
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 11701 | Telephone | 4.0 (3.70; 4.40) | Development cohort
Lee, 2006^71^ | USA | Health and Retirement Study | 1998 | 8009 | Telephone | 6.0 (5.50; 6.50) | Validation cohort
Tabbarah, 2001^2^ | USA | Survey of Asset and Health Dynamics of the Oldest Old (AHEAD) | 1994 | 7,447 | Telephone “Need help performing activity” | 4.5 (4.10; 5.00)
Prevalence of Transportation IADL Disability
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1980 | 513 | Driving | 54.3 (50.00; 58.60)
Jette, 1990^126^ | USA | Massachusetts Health Care Panel Study (MHCPS) | 1985 | 513 | Driving | 67.6 (63.40; 71.50)
Prevalence of IADL Disability by Frailty Status
Cawthon, 2007^28^ | USA | MROS - Osteoporotic Fractures in Men Study | 2000–2002 | 5993 | ≥ 1 IADL (3 items) | 7.4 (6.80; 8.10) | Robust
Cawthon, 2007^28^ | USA | MROS - Osteoporotic Fractures in Men Study | 2000–2002 | 5993 | ≥ 1 IADL (3 items) | 19.6 (18.60; 20.60) | Pre-frail
Cawthon, 2007^28^ | USA | MROS - Osteoporotic Fractures in Men Study | 2000–2002 | 5993 | ≥ 1 IADL (3 items) | 55.7 (54.40; 57.00) | Frail
Gender Difference
Murtogh, 2004^215^ | USA | Alumni Health Study | 1999 | 1348 | Chore | 40.1 (37.50; 42.70) | Sample Age 73+
Murtogh, 2004^215^ | USA | Alumni Health Study | 1999 | 1348 | Chore | 40.1 (37.50; 42.70) | Mean age 79
Crimmins, 1997^86^ | USA | Longitudinal Study on Aging | 1984 | 3081 | ≥ 1 IADL (6 items) | 12.7 (11.60; 13.90) | Women age 76+
Crimmins, 1997^86^ | USA | Longitudinal Study on Aging | 1986 | 2904 | ≥ 1 IADL (6 items) | 12.6 (11.40; 13.90) | Women age 76+
Crimmins, 1997^86^ | USA | Longitudinal Study on Aging | 1988 | 2842 | ≥ 1 IADL (6 items) | 12.8 (11.60; 14.10) | Women age 76+
Crimmins, 1997^86^ | USA | Longitudinal Study on Aging | 1990 | 2782 | ≥ 1 IADL (6 items) | 11.6 (10.50; 12.80) | Women age 76+
Murtogh, 2004^215^ | USA | Alumni Health Study | 1999 | 1348 | Chore | 23.6 (21.40; 25.90) | Sample Age 73+ Mean age 79
Crimmins, 1997^86^ | USA | Longitudinal Study on Aging | 1984 | 3081 | ≥ 1 IADL (6 items) | 9.2 (8.20; 10.30) | Men age 76+
Crimmins, 1997^86^ | USA | Longitudinal Study on Aging | 1986 | 2904 | ≥ 1 IADL (6 items) | 12.5 (11.30; 13.80) | Men age 76+
Crimmins, 1997^86^ | USA | Longitudinal Study on Aging | 1988 | 2842 | ≥ 1 IADL (6 items) | 11.2 (10.10; 12.40) | Men age 76+
Crimmins, 1997^86^ | USA | Longitudinal Study on Aging | 1990 | 2782 | ≥ 1 IADL (6 items) | 10.7 (9.60; 11.90) | Men age 76+
Albert, 2006^48^ | USA - NYC | SITE Sources of Independence in the Elderly | 1999–2001 | 361 | Housekeeping | 2.6 (1.40; 4.90) | Men age <75
Albert, 2006^48^ | USA - NYC | SITE Sources of Independence in the Elderly | 1999–2001 | 361 | Housekeeping | 5.3 (3.40; 8.10) | Men age ≥ 75
Albert, 2006^48^ | USA - NYC | SITE Sources of Independence in the Elderly | 1999–2001 | 361 | Housekeeping | 8.3 (5.90; 11.60) | Women age <75
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Meal prep | 10.2 | Women
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Meal prep | 9.8 | Men
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Meal prep | 11.9 (10.50; 13.40) | Black women
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Meal prep | 7.5 (6.40; 8.80) | White women
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Meal prep | 9.7 (8.50; 11.10) | Black men
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Meal prep | 10.9 (9.60; 12.40) | White men
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Shopping | 10.4 | Women
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Shopping | 20.5 | Men
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Shopping | 24.8 (22.90; 26.80) | Black women
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Shopping | 15.6 (14.00; 17.30) | White women
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Shopping | 12.1 (10.70; 13.60) | Black men
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Shopping | 8.3 (7.10; 9.60) | White men
Albert, 2006^48^ | USA - NYC | SITE Sources of Independence in the Elderly | 1999–2001 | 361 | Housekeeping | 9.1 (6.50; 12.50) | Women age ≥ 75
Racial Difference
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Meal prep | 10.4 | Black
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Meal prep | 9.7 | White
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Meal prep | 11.9 (10.50; 13.40) | Black women
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Meal prep | 7.5 (6.40; 8.80) | White women
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Meal prep | 9.7 (8.50; 11.10) | Black men
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Meal prep | 10.9 (9.60; 12.40) | White men
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Shopping | 16.2 | Black
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Shopping | 10.9 | White
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Shopping | 24.8 (22.90; 26.80) | Black women
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Shopping | 15.6 (14.00; 17.30) | White women
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Shopping | 12.1 (10.70; 13.60) | Black men
Hays, 2005^13^ | USA | EPESE-Duke Site- Established Populations for Epidemiologic Studies of the Elderly | 1992–1993 | 1920 | Shopping | 8.3 (7.10; 9.60) | White men

Appendix E Table 11 Prevalence of Malnutrition in Older Persons Defined as Low Albumin Level, Low BMI, or Unintentional Weight Loss

Reference | Study | Country | Sample size | Age | Gender | Definition | Subgroup | Prevalence (95% CI)
Albumin
Onder, 2003^184^ | Italian Group of Pharmacoepidemiology in the Elderly (GIFA) | Italy | 6984 | >65 | Total | Serum albumin level <35 g/L | | 38.1 (37.0; 39.3)
Martin, 2007^138^ | Veterans Administrative (VA) outpatient clinics | USA | 130 | >65 | Total | Serum albumin <35 g/L | BMI <24 kg/m2 | 3.1 (1.2; 7.9)
Lesourd, 1996^216^ | SENECA: Survey in Europe on Nutrition and the Elderly, a Concerted Action | 8 European countries | 1701 | >73 | Male | Albumin <35g/l | | 1.8 (1.3; 2.6)
Lesourd, 1996^216^ | SENECA: Survey in Europe on Nutrition and the Elderly, a Concerted Action | 8 European countries | 1701 | >73 | Female | Albumin <30g/l | | 0.2 (0.1; 0.6)
Lesourd, 1996^216^ | SENECA: Survey in Europe on Nutrition and the Elderly, a Concerted Action | 8 European countries | 1701 | >73 | Male | Albumin <35g/l | | 2.5 (1.9; 3.4)
Lesourd, 1996^216^ | SENECA: Survey in Europe on Nutrition and the Elderly, a Concerted Action | 8 European countries | 1701 | >73 | Female | Albumin <30g/l | | 0.7 (0.4; 1.2)
Anemia
Lesourd, 1996^216^ | SENECA: Survey in Europe on Nutrition and the Elderly, a Concerted Action | 8 European countries | 1701 | >73 | Male | Anemia, WHO criteria <130g/L | | 5.6 (4.6; 6.8)
Lesourd, 1996^216^ | SENECA: Survey in Europe on Nutrition and the Elderly, a Concerted Action | 8 European countries | 1701 | >73 | Female | Anemia, WHO criteria <120g/L | | 5.5 (4.5; 6.7)
Lesourd, 1996^216^ | SENECA: Survey in Europe on Nutrition and the Elderly, a Concerted Action | 8 European countries | 1701 | >73 | Male | Anemia, NHANES II criteria <126g/L | | 4.1 (3.3; 5.2)
Lesourd, 1996^216^ | SENECA: Survey in Europe on Nutrition and the Elderly, a Concerted Action | 8 European countries | 1701 | >73 | Female | Anemia, NHANES II criteria <117g/L | | 4.2 (3.3; 5.3)
Dallman, 1984^217^ | Second National Health and Nutrition Examination Survey (NHANES II, 1976 to 1980) | USA | 1013 | >65 | Male | Anemia, 126g/L | | 4.4 (3.3; 5.9)
Dallman, 1984^217^ | Second National Health and Nutrition Examination Survey (NHANES II, 1976 to 1980) | USA | 1013 | >65 | Male | Anemia, 126g/L | Caucasian | 4.5 (3.4; 6.0)
Dallman, 1984^217^ | Second National Health and Nutrition Examination Survey (NHANES II, 1976 to 1980) | USA | 1682 | >65 | Female | Anemia, 117g/L | | 3.9 (3.1; 4.9)
Dallman, 1984^217^ | Second National Health and Nutrition Examination Survey (NHANES II, 1976 to 1980) | USA | 1682 | >65 | Female | Anemia, 117g/L | Caucasian | 3.5 (2.7; 4.5)
Body mass index, kg/m2
Onder, 2003^184^ | Italian Group of Pharmacoepidemiology in the Elderly (GIFA) | Italy | 6984 | >65 | Total | BMI < 18.5 | | 5.8 (5.3; 6.4)
Shannon, 2007^29^ | Osteoporotic Fractures in Men (MrOS) | USA | 5928 | >65 | Male | BMI<20 | | 1.0 (0.8; 1.3)
Stookey, 2004^8^ | Duke Established Populations for Epidemiologic Studies of the Elderly | USA | 705 | >70 | Total | BMI< 18.5 | | 2.3 (1.4; 3.7)
Marshall, 1999^132^ | San Luis Valley Health and Aging Study | USA | 1,006 | >65 | Male | BMI<22 | Hispanic | 10.4 (8.7; 12.4)^*^
Marshall, 1999^132^ | San Luis Valley Health and Aging Study | USA | 1,006 | >65 | Male | BMI<22 | non Hispanic | 5.9 (4.6; 7.5)^*^
Marshall, 1999^132^ | San Luis Valley Health and Aging Study | USA | 1,006 | >65 | Female | BMI<22 | Hispanic | 9.8 (8.1; 11.8)^*^
Marshall, 1999^132^ | San Luis Valley Health and Aging Study | USA | 1,006 | >65 | Female | BMI<22 | non Hispanic | 13.0 (11.1; 15.2)^*^
Martin, 2007^138^ | Veterans Administrative (VA) outpatient clinics | USA | 130 | >65 | Total | BMI <19 | | 15.0 (9.8; 22.2)
Ledikwe, 2004^68^ | Geisinger Rural Aging Study (GRAS) | USA | 179 | >65 | Total | BMI <18.5 | | 0.0 (0.0; 4.3)
Cesari, 2004^176^ | InCHIANTI | Italy | 1020 | >65 | Total | BMI<20 | | 1.8 (1.1; 2.8)
de Groot, 2004^189^ | Survey in Europe on Nutrition and the Elderly: a Concerted Action (SENECA) | Europe | 989 | >65 | Female | BMI<20 | | 10 (8.3;12)
de Groot, 2004^189^ | Survey in Europe on Nutrition and the Elderly: a Concerted Action (SENECA) | Europe | 989 | >65 | Men | BMI<20 | | 0.1 (0;0.8)
Weight loss
Beck, 1999^157^ | Danish part of the ‘Survey in Europe of Nutrition in the Elderly, a Concerted Action’ (SENECA) | Denmark | 202 | >73 | Total | Weight loss >5% | High Nutritional risk, NSI Score >6 | 21.0 (15.9; 27.2)
Beck, 1999^157^ | Danish part of the ‘Survey in Europe of Nutrition in the Elderly, a Concerted Action’ (SENECA) | Denmark | 202 | >73 | Total | Weight loss >5% | Risk of malnutrition by MNA 17–23.5 | 58.0 (51.1; 64.6)
Newman, 2001^64^ | Cardiovascular Study Research Group | USA | 4718 | >65 | Male | Weight loss of 5% in a 3-year | | 16.2 (15.2; 17.3)
Newman, 2001^64^ | Cardiovascular Study Research Group | USA | 4718 | >65 | Male | Weight loss of 10% in a 3-year | | 4.1 (3.6; 4.7)
Newman, 2001^64^ | Cardiovascular Study Research Group | USA | 4718 | >65 | Female | Weight loss of 5% in a 3-year | | 18.7 (17.6; 19.8)
Newman, 2001^64^ | Cardiovascular Study Research Group | USA | 4718 | >65 | Female | Weight loss of 10% in a 3-year | | 6.3 (5.6; 7.0)
Kulminski, 2008^62^ | Cardiovascular Health Study | USA | 4721 | >65 | | Weight loss (component of Phenotypic Frailty Index) | | 4.5 (3.9;5.1)
Marshall, 1999^132^ | San Luis Valley Health and Aging Study | USA | 1,006 | >65 | Male | Weight loss >10% in 6 months | Hispanic | 6.6 (5.2; 8.3)^*^
Marshall, 1999^132^ | San Luis Valley Health and Aging Study | USA | 1,006 | >65 | Male | Weight loss >10% in 6 months | Non Hispanic | 7.2 (5.8; 9.0)^*^
Marshall, 1999^132^ | San Luis Valley Health and Aging Study | USA | 1,006 | >65 | Female | Weight loss >10% in 6 months | Hispanic | 8.3 (6.7; 10.2)^*^
Marshall, 1999^132^ | San Luis Valley Health and Aging Study | USA | 1,006 | >65 | Female | Weight loss >10% in 6 months | Non Hispanic | 8.9 (7.3; 10.8)^*^
Ensrud, 2009^51^ | The Osteoporotic Fractures in Men Research Group | USA | 3132 | >65 | Male | Weight loss | | 19.6 (18.2;21)
Graham, 2009^202^ | Hispanic Established Population for the Epidemiological Study of the Elderly | USA | 1996 | >65 | Total | Weight loss | Hispanic | 18.8 (17.1;20.6)
Syddall, 2010^206^ | Hertfordshire Cohort Study | UK | 638 | >65 | Male | Weight loss (>10 pounds over the past year) | | 5.3 (3.8;7.3)
Syddall, 2010^206^ | Hertfordshire Cohort Study | UK | 638 | >65 | Female | | | 3.5 (2.3;5.2)

* age adjusted prevalence

Appendix E Table 12 Prevalence of Malnutrition in Older Persons Defined as Micronutrients Deficit

Reference | Study | Country | Sample size | Age | Gender | Subgroup | Definition | Prevalence (95% CI)
Patel, 2010^46^ | NHANES III | USA | 4,198 | >65 | Total | | Folate deficient | 6.4 (5.7; 7.2)
Patel, 2010^46^ | Women’s Health and Aging Study I | USA | 742 | >70 | Total | | Folate deficient | 1.0 (0.5; 2.0)
Patel, 2010^46^ | InCHIANTI | USA | 1,036 | >65 | Total | | Folate deficient | 18.2 (16.0; 20.7)
Patel, 2010^46^ | NHANES III | USA | 4,198 | >65 | Total | | Iron deficient | 5.6 (4.9; 6.3)
Patel, 2010^46^ | Women’s Health and Aging Study I | USA | 742 | >70 | Total | | Iron deficient | 2.6 (1.7; 4.0)
Patel, 2010^46^ | InCHIANTI | USA | 1,036 | >65 | Total | | Iron deficient | 6.1 (4.8; 7.7)
Patel, 2010^46^ | NHANES III | USA | 4,198 | >65 | Total | | Vitamin B12 deficient | 5.4 (4.8; 6.1)
Patel, 2010^46^ | Women’s Health and Aging Study I | USA | 742 | >70 | Total | | Vitamin B12 deficient | 6.6 (5.0; 8.6)
Patel, 2010^46^ | InCHIANTI | USA | 1,036 | >65 | Total | | Vitamin B12 deficient | 11.7 (9.9; 13.8)
Visser, 2006^196^ | Longitudinal Aging Study Amsterdam (1995–1996) | The Netherlands | 1260 | >65 | Total | | Vitamin D deficiency [25 (OH)D < 25 nmol/L] | 10.1 (8.6; 11.9)
Visser, 2006^196^ | Longitudinal Aging Study Amsterdam (1995–1996) | The Netherlands | | >65 | Total | | Vitamin D insufficiency [25 (OH)D 25–49.9 nmol/L] | 36.7 (34.1; 39.4)
Johnson, 2008^93^ | Older Americans Act Nutrition Program (OAANP) in northeast Georgia | USA | 158 | >65 | Total | | Vitamin D insufficiency (25 (OH)D 25–<50nmol/l) | 36.7 (29.6; 44.5)
Johnson, 2008^93^ | Older Americans Act Nutrition Program (OAANP) in northeast Georgia | USA | 158 | >65 | Total | | Vitamin D deficiency | 8.2 (4.8; 13.6)
Johnson, 2008^93^ | Older Americans Act Nutrition Program (OAANP) in northeast Georgia | USA | 158 | >65 | Male | | Vitamin D deficiency | 10.0 (6.2; 15.7)
Johnson, 2008^93^ | Older Americans Act Nutrition Program (OAANP) in northeast Georgia | USA | 158 | >65 | Female | | Vitamin D deficiency | 8.0 (4.7; 13.4)
Johnson, 2008^93^ | Older Americans Act Nutrition Program (OAANP) in northeast Georgia | USA | 158 | >65 | Total | Caucasian | Vitamin D deficiency | 8.0 (4.7; 13.4)
Johnson, 2008^93^ | Older Americans Act Nutrition Program (OAANP) in northeast Georgia | USA | 158 | >65 | Total | African American | Vitamin D deficiency | 8.0 (4.7; 13.4)

Appendix E Table 13 Prevalence of Malnutrition in Older Persons Using Composite Nutritional Score

Reference | Study | Country | Sample size | Age | Gender | Definition | Subgroup | Prevalence (95% CI)
High nutritional risk
de Groot, 1998^218^ | SENECA: Survey in Europe on Nutrition and the Elderly, a Concerted Action | 8 European countries | 1701 | >73 | Total | High risk by Nutritional Health Checklist | | 48.0 (45.6; 50.4)
Marshall, 1999^132^ | San Luis Valley Health and Aging Study | USA | 1,006 | >65 | Male | High risk by Nutritional Health Checklist | Hispanic | 19.1 (16.8; 21.6)*
Marshall, 1999^132^ | San Luis Valley Health and Aging Study | USA | 1,006 | >65 | Male | High risk by Nutritional Health Checklist | Non Hispanic | 14.0 (12.0; 16.3)*
Marshall, 1999^132^ | San Luis Valley Health and Aging Study | USA | 1,006 | >65 | Female | High risk by Nutritional Health Checklist | Hispanic | 30.0 (27.2; 32.9)*
Marshall, 1999^132^ | San Luis Valley Health and Aging Study | USA | 1,006 | >65 | Female | High risk by Nutritional Health Checklist | Non Hispanic | 17.0 (14.8; 19.4)*
Beck, 1999^157^ | Danish part of ‘Survey in Europe of Nutrition in the Elderly, a Concerted Action’ (SENECA) | Denmark | 202 | >73 | Total | High risk by Nutritional Health Checklist | | 19.3 (14.4; 25.3)
Yap, 2007^191^ | Singapore Longitudinal Aging Study, SLAS | Singapore | 1407 | 65–74 years | Total | High risk score (>3) | | 33.1 (30.7; 35.6)
Yap, 2007^191^ | Singapore Longitudinal Aging Study, SLAS | Singapore | 1407 | 75+ years | Total | High risk score (>3) | | 40.9 (38.4; 43.5)
Weatherspoon, 2004^92^ | Nutrition Screening Initiative | USA | 324 | >60 | Total | High risk score | Rural | 29.0 (24.3; 34.2)
Weatherspoon, 2004^92^ | Nutrition Screening Initiative | USA | 324 | | Total | High risk score | Urban | 33.0 (28.1; 38.3)
Weatherspoon, 2004^92^ | Nutrition Screening Initiative | USA | 324 | | Male | High risk score | | 24.0 (19.7; 29.0)
Weatherspoon, 2004^92^ | Nutrition Screening Initiative | USA | 324 | | Female | High risk score | | 34.0 (29.0; 39.3)
Weatherspoon, 2004^92^ | Nutrition Screening Initiative | USA | 324 | 60–64 | Total | High risk score | 60–64 | 21.0 (16.9; 25.8)
Weatherspoon, 2004^92^ | Nutrition Screening Initiative | USA | 324 | 65–74 | Total | High risk score | 65–74 | 46.0 (40.6; 51.5)
Weatherspoon, 2004^92^ | Nutrition Screening Initiative | USA | 324 | 75–84 | Total | High risk score | 75–84 | 25.0 (20.6; 30.0)
Weatherspoon, 2004^92^ | Nutrition Screening Initiative | USA | 324 | >85 | Total | High risk score | >85 | 31.0 (26.2; 36.2)
Weatherspoon, 2004^92^ | Nutrition Screening Initiative | USA | 324 | >60 | Total | High risk score | Caucasian | 24.0 (19.7; 29.0)
Weatherspoon, 2004^92^ | Nutrition Screening Initiative | USA | 324 | >60 | Total | High risk score | African American | 38.0 (32.9; 43.4)
Weatherspoon, 2004^92^ | Nutrition Screening Initiative | USA | 324 | >60 | Total | High risk score | Others/Hispanics | 34.0 (29.0; 39.3)
High risk nutritional score by health perception
Weatherspoon, 2004^92^ | | USA | 324 | >60 | Total | | Health perception: Excellent | 16.0 (12.4; 20.4)
Weatherspoon, 2004^92^ | | USA | 324 | >60 | Total | | Health perception: Good | 22.0 (17.8; 26.8)
Weatherspoon, 2004^92^ | | USA | 324 | >60 | Total | | Health perception: Fair | 44.0 (38.7; 49.5)
Weatherspoon, 2004^92^ | | USA | 324 | >60 | Total | | Health perception: Poor | 53.0 (47.6; 58.4)
Moderate risk nutritional score
de Groot, 1998^218^ | SENECA: Survey in Europe on Nutrition and the Elderly, a Concerted Action | 8 European countries | 1701 | >73 | Total | Moderate risk by Nutritional Health Checklist | | 41.0 (38.7; 43.4)
Beck, 1999^157^ | Danish part of ‘Survey in Europe of Nutrition in the Elderly, a Concerted Action’ (SENECA) | Denmark | 202 | >73 | Total | | | 51.0 (44.1; 57.8)
Weatherspoon, 200^92^ | Nutrition Screening Initiative | USA | 324 | >60 | Total | Moderate risk l score | | 60.0 (54.6; 65.2)
Weatherspoon, 200^92^ | Nutrition Screening Initiative | USA | 324 | | Total | Moderate risk l score | | 39.0 (33.8; 44.4)
Weatherspoon, 200^92^ | Nutrition Screening Initiative | USA | 324 | | Male | Moderate risk l score | | 57.0 (51.5; 62.3)
Weatherspoon, 200^92^ | Nutrition Screening Initiative | USA | 324 | | Female | Moderate risk l score | | 42.0 (36.7; 47.4)
Weatherspoon, 200^92^ | Nutrition Screening Initiative | USA | 324 | 60–64 | Total | Moderate risk l score | 60–64 | 50.0 (44.6; 55.4)
Weatherspoon, 200^92^ | Nutrition Screening Initiative | USA | 324 | 65–74 | Total | Moderate risk l score | 65–74 | 43.0 (37.7; 48.5)
Weatherspoon, 200^92^ | Nutrition Screening Initiative | USA | 324 | 75–84 | Total | Moderate risk l score | 75–84 | 51.0 (45.6; 56.4)
Weatherspoon, 200^92^ | Nutrition Screening Initiative | USA | 324 | >85 | Total | Moderate risk l score | >85 | 39.0 (33.8; 44.4)
Weatherspoon, 200^92^ | Nutrition Screening Initiative | USA | 324 | >60 | Total | Moderate risk l score | Caucasian | 47.0 (41.6; 52.4)
Weatherspoon, 200^92^ | Nutrition Screening Initiative | USA | 324 | >60 | Total | Moderate risk l score | African American | 48.0 (42.6; 53.4)
Weatherspoon, 200^92^ | Nutrition Screening Initiative | USA | 324 | >60 | Total | Moderate risk l score | Others/Hispanics | 42.0 (36.7; 47.4)
Moderate risk nutritional score by health perception
Weatherspoon, 200^92^ | | | | >60 | Total | | Health perception: Excellent | 49.0 (43.6; 54.4)
Weatherspoon, 200^92^ | | | | >60 | Total | | Health perception: Good | 50.0 (44.6; 55.4)
Weatherspoon, 200^92^ | | | | >60 | Total | | Health perception: Fair | 40.0 (34.8; 45.4)
Weatherspoon, 200^92^ | | | | >60 | Total | | Health perception: Poor | 38.0 (32.9; 43.4)
Risk of malnutrition
de Groot, 1998^218^ | SENECA: Survey in Europe on Nutrition and the Elderly, a Concerted Action | 8 European countries | 1701 | >73 | Total | Risk of malnutrition by The Mini Nutritional Assessment | | 44.0 (41.7; 46.4)
de Groot, 1998^218^ | SENECA: Survey in Europe on Nutrition and the Elderly, a Concerted Action | 8 European countries | 1701 | >73 | Total | Malnutrition by The Mini Nutritional Assessment | | 1.0 (0.6; 1.6)
Beck, 1999^157^ | Danish part of ‘Survey in Europe of Nutrition in the Elderly, a Concerted Action’ (SENECA) | Denmark | 202 | >73 | Total | Risk of malnutrition by The Mini Nutritional Assessment | | 21.6 (16.5; 27.8)
Visvanathan, 2003^141^ | Domiciliary care services for elderly people with moderate or severe functional limitations | Australia | 250 | >67 | Total | Risk of malnutrition | Moderate or severe functional limitations | 38.4 (32.6; 44.6)
Visvanathan, 2003^141^ | Domiciliary care services for elderly people with moderate or severe functional limitations | Australia | 250 | >67 | Total | Malnutrition | | 4.8 (2.7; 8.3)

Appendix E Table 14 Prevalence of Impaired Homeostasis in Older Persons

Reference | Study | Measure of Impaired Homeostasis | Sample | Definition | Prevalence (95% CI)
Nelson, 2007^219^ | National Health and Nutrition Examination Surveys (NHANES) 1999–2000 and 2001–2002 | Allostatic load score (0–10) for high-risk systolic blood pressure (>138 mm Hg), diastolic blood pressure (>81 mm Hg, BMI 31.2 kg/m2), hemoglobin A1C >5.6%, albumin <4.47 g/dL, creatinine clearance <78.5 mL/min/1.73 m2, triglycerides >189.5 mg/dL, C-reactive protein >0.49 mg/dL, homocysteine >10.1 mmol/L, and total cholesterol >233.9 mg/dL. | 5,083 | Allostatic load score >4 | 1.4 (1.1; 1.8)
Stookey, 2004^8^ | Duke Established Populations for Epidemiologic Studies of the Elderly | Plasma tonicity was estimated from plasma glucose, sodium, and potassium measures and used to classify subjects as normo- (285–294 mOsm/L) or hypertonic (>300 mOsm/L) | 705 | hypertonic plasma, >300 mOsm/L | 10 (8; 12.4)

Appendix E Figure 1 Prevalence of Biomarkers of Chronic Inflammation in Older Persons58,76,192

Appendix E Table 15 Prevalence of Cognitive Impairment in Older Men According to Age and Measurement

Reference | Study | Method | Prevalence (95% CI)
>65
Newman, 2009^60^ | Cardiovascular Health Study All Stars Study | 3MSE | 36.0 (33.7; 38.3)
Helmer, 1999^166^ | PAQUID (Personnes Agees QUID) Research Program | MMSE | 16.9 (15.7; 18.1)
No author listed, 2001^152^ | Canadian Study of Health and Aging (CSHA) | 3MSE | 16.0 (15.3; 16.8)
65–74
Graham, 1997^148^ | Canadian Study of Health and Aging | 3MSE | 16.1 (12.6; 19.6)
>70
Pratt, 2008^220^ | Health and Retirement Survey (HRS) | TICS | 5.2 (4.4; 6.2)
>75
Rait, 2005^208^ | Medical Research Council (MRC) Trial of the Assessment and Management of Older People in the Community | MMSE | 2.4 (1.9; 3.0)
75–79
Pratt, 2008^220^ | Cardiovascular Health Study | TICS | 15.4 (14.6; 16.3)
Rait, 2005^208^ | Medical Research Council (MRC) Trial of the Assessment and Management of Older People in the Community | MMSE | 1.4 (1.0; 2.0)
75–84
Graham, 1997^148^ | Canadian Study of Health and Aging | 3MSE | 29.5 (25.6; 33.4)
80–84
Pratt, 2008^220^ | Cardiovascular Health Study | TICS | 33.3 (32.2; 34.4)
<82
Newman, 2009^60^ | Cardiovascular Health Study All Stars Study | 3MSE | 10.8 (9.4; 12.4)
80–84
Rait, 2005^208^ | Medical Research Council (MRC) Trial of the Assessment and Management of Older People in the Community | MMSE | 2.5 (1.8; 3.6)
80–85 | SENECA study
Pearson, 2001^221^ | Hamme, Belgium | MMSE | 31.0 (27.5; 34.7)
Pearson, 2001^221^ | Denmark | MMSE | 10.0 (7.9; 12.6)
Pearson, 2001^221^ | Haguenau, France | MMSE | 4.0 (2.7; 5.8)
Pearson, 2001^221^ | Romans, France | MMSE | 10.0 (7.9; 12.6)
Pearson, 2001^221^ | Italy | MMSE | 10.0 (7.9; 12.6)
Pearson, 2001^221^ | The Netherlands | MMSE | 4.0 (2.7; 5.8)
Pearson, 2001^221^ | Portugal | MMSE | 27.0 (23.7; 30.6)
Pearson, 2001^221^ | Spain | MMSE | 15.0 (12.4; 18.0)
Pearson, 2001^221^ | Switzerland | MMSE | 9.0 (7.0; 11.5)
Pearson, 2001^221^ | Poland | MMSE | 20.0 (17.1; 23.3)
Pearson, 2001^221^ | SENECA study, total sample | MMSE | 14.0 (11.5; 16.9)
83–84
Newman, 2009^60^ | Cardiovascular Health Study All Stars Study | 3MSE | 9.2 (7.9; 10.7)
>85
Pratt, 2008^220^ | Cardiovascular Health Study | TICS | 42.9 (41.7; 44.1)
Graham, 1997^148^ | Canadian Study of Health and Aging | 3MSE | 35.8 (29.5; 42.1)
85–88
Newman, 2009^60^ | Cardiovascular Health Study All Stars Study | 3MSE | 9.1 (7.8; 10.6)
Rait, 2005^208^ | Medical Research Council (MRC) Trial of the Assessment and Management of Older People in the Community | MMSE | 4.4 (3.0; 6.4)
>89
Newman, 2009^60^ | Cardiovascular Health Study All Stars Study | 3MSE | 14.9 (13.3; 16.7)
Rait, 2005^208^ | Medical Research Council (MRC) Trial of the Assessment and Management of Older People in the Community | MMSE | 10.3 (6.4; 16.2)

TICS=Telephone Interview of Cognitive Status; MMSE=Mini-Mental State Examination; 3MSE=Modified Mini-Mental Status Examination.

Appendix E Table E16 Association Between Cognitive and Behavioral Factors and Dementia in Healthy Older Persons222,223

Study | Reference | Comparison Groups | Sample Size | Predictors of Dementia
Demographic and cognitive factors
Bronx Aging Study | Masur, 1994^224^ | Normal vs. dementia | n=317 | Selective Reminding Test delayed recall, Fuld Object Memory Test recall, category fluency, Wechsler Adult Intelligence Scale Digit Symbol
Prospective epidemiologic study of dementia | Jacobs, 1995^225^ | Normal vs. Alzheimer’s Disease | n=443 | Gender (female), Boston Naming Test, Wechsler Adult Intelligence Scale-Revised Similarities, Selective Reminding Test immediate recall.
Framingham Study | Linn, 1995^226^ | Normal vs. Alzheimer’s Disease | n=1,045 | Wechsler Memory Scale logical memory and Paired Associate Learning (but not Similarities or letter fluency), Digit Span(Alzheimer’s Disease scoring higher)
Random sample of nondemented persons aged 75 years and older | Braekhus, 1995^227^ | Normal vs. dementia | n=215 | MMSE score of 24 or 25 (predictive at 3 years but not at 6 years)
Amsterdam Study of the Elderly (AMSTEL) | Schmand, 1996^228^ | Normal vs. dementia | n=203 | Age and Cambridge Mental Disorders in the Elderly Examination Cognitive subtest memory subscale
Bronx Aging Study | Crystal, 1996^229^ | Normal vs. Alzheimer’s Disease (Autopsy) | n=22 | Greater rate of decline on neuropsychological tests
Canadian Study of Health and Aging (CSHA) | O'Rourke, 1997^230^ | Nondemented vs. dementia | n=59 | Deficits on one or more subsets of the Clock Test
Canadian Study of Health and Aging (CSHA) | Small, 1997^231^ | Nondemented vs. dementia | n=205 | MMSE, word recall (organized list), face recognition test, letter fluency/Clock Test
Canadian Study of Health and Aging (CSHA) | Fox, 1998^232^ | Nondemented with familial history vs. Alzheimer’s Disease | n=63 | Recognition Memory Test-Words
Canadian Study of Health and Aging (CSHA) | Katzman, 1989^233^ | Normal vs. dementia | n=406 | Age, gender (female), and baseline score on the Blessed Information Memory Concentration
Canadian Study of Health and Aging (CSHA) | Fuld, 1990^234^ | Normal vs. dementia | n=474 | Fuld Object Memory Test immediate recall
Canadian Study of Health and Aging (CSHA) | Masur, 1990^235^ | | n=422 | Selective Reminding Test sum of recall and delayed recall
Canadian Study of Health and Aging (CSHA) | Tuokko, 1991^236^ | Nondemented vs. Alzheimer’s Disease | n=45 | Free recall from Buschke's cued recall paradigm
Canadian Study of Health and Aging (CSHA) | Flicker, 1991^237^ | Global Deterioration Scale ≤3 vs. Global Deterioration Scale>4 | n=32 | Memory (visual, verbal)receptive language
Canadian Study of Health and Aging (CSHA) | Flicker, 1993^238^ | Global Deterioration Scale<=2 vs. Global Deterioration Scale>3 | n=50 | Memory measures, object function recall
Behavioral risk factors
| Physical activity
Cardiovascular Risk Factors, Aging and Dementia Study (CAIDE) | Kivipelto, 2008^239^ | Sedentary (<2 times/week) vs. Active (≥2) | n=1,449 | Sedentary life style increased dementia and Alzheimer’s Disease
Honolulu-Asia Aging Study (HAAS) | Taafe, 2008^240^ | Moderate (gardening, carpentry) vs. high (lifting, shoveling) | n=2,263 men | Moderate and high usual 24-hour activity levels reduced Alzheimer’s Disease but not vascular dementia
Cardiovascular Risk Factors, Aging and Dementia Study (CAIDE) | Rovio, 2007^241^ | Occupational physical activity vs. total daily commuting physical activity | n=1,449 | No association
Adult Changes in Thought Study (ACT) | Larson, 2006^242^ | ≥3 times/week | n=1,619 | Regular exercise reduced dementia but not Alzheimer’s Disease
Dubbo Study | Simons, 2006^243^ | Walking, gardening | n=2,805 | Walking, gardening in men reduced dementia
Cardiovascular Health Cognition Study (CHCS) | Podewils, 2005^244^ | | n=3,375 | >4 activities in the past two weeks reduced dementia and Alzheimer’s Disease but not vascular Alzheimer’s Disease
Whitehall II | Singh-Manoux, 2005^245^ | High level (≥2.5 hours/week of moderate or ≥1 hour/week of vigorous activity) vs. low level (<2 hours/week of moderate, <1 hour/week of vigorous activity) | n=6.236 | Low weekly activity increased dementia and Alzheimer’s Disease
Honolulu-Asia Aging Study (HAAS) | Abbott, 2004^246^ | Distance walked/day | n=1,495 | Walking <0.25miles/day increased risk of dementia and Alzheimer’s Disease but not vascular Alzheimer’s Disease
Nurses' Health Study | Weuve, 2004^247^ | Leisure time activity vs. Metabolic Equivalent- hours/week | n=16,466 | High energy expenditure associated with better cognitive function
| Smoking | | | Risk Factor
Cardiovascular Risk Factors, Aging and Dementia Study (CAIDE) | Kivipelto, 2008^239^ | Ever vs. never | n=1,449 | Smoking was associated with increased risk of dementia and Alzheimer’s Disease in apoE □4 carriers
Rotterdam Study | Reitz, 2007^248^ | Current vs. past vs. never vs. pack years | n=6,868 | Smoking was associated with increased risk of dementia and Alzheimer’s Disease but not vascular dementia
Honolulu Heart Program (HHP), Honolulu-Asia Aging Study (HAAS) | Tyas, 2003^249^ | Current vs. past vs. never vs. pack years [Light (≤26.7) vs. medium (>26.7–40.5) vs. heavy (>40.5–55.5) vs. very heavy (>55.5–156) | n=3,734 | Smoking was associated with increased risk of dementia but not vascular dementia
Rotterdam Study | Ott, 1998^250^ | Current vs. past vs. never | n=6,870 | Smoking was associated with increased risk of dementia but not vascular dementia
| Alcohol drinking | | | Risk Factor
Cardiovascular Risk Factors, Aging and Dementia Study (CAIDE) | Kivipelto, 2008^239^ | Frequent (≥once/month) vs. infrequent (<once/month) vs. never | n=1,449 | Frequent alcohol drinking in apoE □4 carriers
Cardiovascular Risk Factors, Aging and Dementia Study (CAIDE) | Ngandu, 2007^251^ | Frequent (≥once/month) vs. infrequent (<once/month) vs. never | n=1,341 | Non drinkers had poorer cognitive performance
Kame Project | Dai, 2006^252^ | Wine (sake)1–2 times/week vs. <once/week | n=1,589 | No association
Dubbo Study | Simons, 2006^243^ | Drinks/week | n=2,805 | 8–28 drinks/week vs. non reduced risk of dementia
Monongahela Valley Independent Elders Survey (MoVIES) | Ganguli, 2005^253^ | None vs. minimal (≤once/month) vs. moderate (>once/month) | n=1,098 | Alcohol drinking
Cardiovascular Risk Factors, Aging and Dementia Study (CAIDE) | Anttila, 2004^254^ | Frequent (several times/month) vs. infrequent (<once/month) vs. never | n=1,018 | Lesser decline in cognitive function in minimal and moderate drinkers
Washington Heights-Inwood Columbia Aging Project (WHICAP) | Luchsinger, 2004^255^ | Beer, liquor, wine none vs. light (1 serving/month - 6 servings/week) vs. moderate (1–3 servings/day vs. heavy (>3 servings/day) | n=980 | Light-moderate wine drinking reduced risk of dementia
Framingham Heart Study (FHS) | Elias, 1999^256^ | Mean oz/week | n=1,940 | Better cognitive functions in light drinkers
| Obesity
Kaiser Permanente | Whitemer, 2007^257^ | Underweight (<18.5) vs. normal (18.5–24.9) vs. overweight (25–29.9) vs. obese (≥30) | n=10,136 | Over weight and obesity increased risk of dementia, vascular dementia, and Alzheimer’s Disease
Framingham Heart Study (FHS) | Elias, 2005^258^ | Non-obese (normal: 18.5–24.9, overweight: 25–29.9) vs. obese (>30) | n=2,000 | Obese men had worse cognitive function
Cardiovascular Risk Factors, Aging and Dementia Study (CAIDE) | Kivipelto, 2005^259^ | Normal (≤25) vs. overweight (25–30) vs. obese (>30) | n=1,449 | No association
Multifactor Primary Prevention Study (MPPS) | Rosengren, 2005^260^ | 20–22.4 (reference) vs. 25–27.4 vs. 27.5–29.9 vs. ≥30 | n=7,402 | Dose response positive association with dementia
Göteborg | Gustafson, 2003^261^ | Continuous | n=382 | Dose response positive association with dementia and Alzheimer’s Disease in women (36% for additional 1 kg/m2 after 70 years of age)
Adult Health Study (AHS) | Yamada, 2003^262^ | Continuous | n=1,774 | No association
| Dietary factors
Cardiovascular Risk Factors, Aging and Dementia Study (CAIDE) | Eskelinen, 2008^263^ | Fat intake from milk, sour milk, and spreads (saturated fatty acids, polyunsaturated fatty acids, monounsaturated fatty acids), fish (≥2/week vs. <2/week) | n=1,449 | High saturated fatty acids intake was associated with mild cognitive impairment
Cardiovascular Risk Factors Aging and Dementia Study (CAIDE) | Kivipelto, 2008^239^ | Polyunsaturated fatty acids, saturated fatty acids (g/day) from spreads | n=1,449 | High saturated fatty acids intake was associated with mild cognitive impairment in apoE □4 carriers
Conselice Study of Brain Ageing (CSBA) | Ravaglia, 2008^264^ | Mediterranean diet score (0–10) | n=615 | Dose response reduction in dementia by increase tocopherols (plasma)
Kame Project | Dai, 2006^252^ | Fruit & vegetable juices, Vitamin E, Vitamin C,- carotene | n=1,589 | Negative association with juice, no association with tea, Vitamin E,C, beta-carotene
Cardiovascular Risk Factors, Aging and Dementia Study (CAIDE) | Laitenen, 2006^265^ | Fat intake from milk, sour milk, and spreads (Polyunsaturated fatty acids, Saturated fatty acids, Monounsaturated fatty acids) | n=1,449 | High polyunsaturated fatty acid intake reduced risk of dementia, high saturated fatty acid intakes increased risk of Alzheimer’s Disease
Chicago Health and Aging Project (CHAP) | Morris, 2006^266^ | Vegetables, fruits (servings/day) | n=3,718 | Slower cognitive decline after vegetables, no association with fruits
Cardiovascular Health Cognition Study (CHCS) | Huang, 2005^267^ | Fish Servings/week | n=2,233 | High intake reduced dementia and Alzheimer’s Disease
Chicago Health and Aging Project (CHAP) | Morris, 2005^268^ | Fish Servings/week | n=3,718 | Fish reduced speed of cognitive decline
Conselice Study of Brain Ageing (CSBA) | Ravaglia, 2005^269^ | Folate, Vitamin B_12_ (serum) | n=816 | Low folate increased risk of dementia
Honolulu-Asia Aging Study (HAAS) | Laurin, 2004^270^ | β-carotene (μg/day), flavonoids, Vitamin E, Vitamin C (mg/day) | n=2,459 | No association
Chicago Health and Aging Project (CHAP) | Morris, 2004^271^ | Niacin (mg/day) | n=3,718 | Niacin administration slowed cognitive decline
Nurses' Health Study | Grodstein, 2003^272^ | Vitamin E, Vitamin C (mg/day) | n=14,968 | Better cognitive function with higher intake
Washington Heights-Inwood Columbia Aging Project (WHICAP) | Luchsinger, 2003^273^ | Carotenes (IU/day), Vitamin C (mg/day), Vitamin E (IU/day) | n=980 | No association
Rotterdam Study | Englehart, 2002^274^ | β-carotene, flavonoids, Vitamin C, Vitamin E (mg/day) | n=5,395 | Vitamin E reduced risk of Alzheimer’s Disease
Canadian Study of Health and Aging (CSHA) | Maxwell, 2002^275^ | Folate (serum) | n=369 | No association

BIMC=Blessed Information Memory Concentration; FOME=Fuld Object Memory Test; CLT=California Verbal Learning Test; MMSE=Mini-Mental State Examination; MDRS=Mattis Dementia Rating Scale; WAIS=Wechsler Adult Intelligence Scale; WMS-R=Wechsler Memory Scale-Revised; LM=logical memory; SRT=Selective Reminding Test; BNT=Boston Naming Test; WAIS-R=Wechsler Adult Intelligence Scale-Revised; WMS=Wechsler Memory Scale; PAL=Paired Associate Learning; CAMCOG=Cambridge Mental Disorders in the Elderly Examination Cognitive subtest; FH=familial history of AD.

Appendix E Table 17 Proportion of Older Persons With Cognitive Impairment Who Developed Dementia276

Reference | Inclusion Criteria | Sample Size | Followup, Years | % Developing Dementia
O’Connor, 1990^277^ | Cambridge Mental Disorders in the Elderly Examination rating of minimal dementia; age 75 years; excluded: none | 44 community-dwelling volunteers recruited from a general medical practice | 1.1 years | 20.7% progressed to Cambridge Mental Disorders in the Elderly Examination mild or moderate dementia (6/29)
Petersen, 1995^278^ | Clinical Dementia Rating = 0.5; cognitive complaint reported by the individual, informant or physician; normal score on cognitive screening measures; performance >1.5 SDs below age appropriate levels on measures of memory; excluded: persons with dementia using DSM-III-R criteria | 66 individuals from the Mayo Clinic Alzheimer’s Disease Center and Alzheimer’s Disease Patient Registry | 1.5 years | 24.2% progressed to probable Alzheimer’s Disease (16/66)
Tierney, 1996^279^ | Global Deterioration Scale = 2 or 3; MMSE 24 or DRS 123; 3 or more months of symptomatic memory problems that interfered with daily functioning; excluded: persons with dementia using DSM-III-R criteria and persons with neurologic, psychiatric, and medical disorders | 123 individuals referred by a family physician for memory problems | 2.0 years | 23.6% progressed to probable Alzheimer’s Disease (29/123)
Johansson, 1997^280^ | Mild impairment on cognitive measures and age between 84 and 90 years; excluded: persons with dementia using DSM-III-R criteria | 70 persons from a population- based sample in Sweden of the oldest-old | 2.0 years | 50.0% progressed to dementia (25/50)
Johnson, 1998^281^ | Clinical Dementia Rating = 0.5; excluded: persons with history of significant head trauma, neurologic disorder, psychiatric disorder, major medical disease, or use of medication with psychoactive properties | 45 volunteers recruited primarily through the print media | 2.0 years | 40.0% progressed to probable Alzheimer’s Disease (18/45)
Flicker, 1991^237^ | Global Deterioration Scale = 3; excluded: persons with past or current neurologic, psychiatric, or medical disorders | 32 memory-clinic patients | 2.1 years | 71.9% progressed to Global Deterioration Scale 4 (23/32)
Devanand, 1997^282^ | Clinical Dementia Rating = 0 or 0.5; age >40, impairment present between 6 months and 10 years; evidence of cognitive impairment on clinical or neuropsychological evaluation; modified Mini Mental Status score >30, excluded: persons with dementia using DSM-III-R criteria, current thought or affective disorder, recent electroconvulsive therapy, current or recent substance dependence, stroke, and current medications that affect cognition, mental retardation, or neurologic conditions | 127 memory-clinic outpatients including persons with prior history of major affective disorder, substance abuse, and small vascular subcortical lesions | 2.5 years | 41.3% progressed to dementia (31/75)
Jack, 1999^283^ | Clinical Dementia Rating = 0.5; age 60 to 89 years; memory complaint by patient or collateral source; normal general cognitive function; normal ADLs; objective memory impairment with performance >1.5 SDs below age- and education appropriate levels; excluded: persons with dementia using DSM-III-R criteria and National Institute of Neurological and Communicative Disorders and Stroke and the Alzheimer’s Disease and Related Disorders Association criteria for probable Alzheimer’s Disease | 80 persons from the Mayo Clinic Alzheimer’s Disease Center and Alzheimer’s Disease Patient Registry | 2.7 years | 33.8% progressed to probable Alzheimer’s Disease (27/80)
Herlitz, 1997^284^ | Impaired cognitive test performance and age 75 years; excluded: persons with dementia using DSM-III-R criteria | 22 community-dwelling individuals | 3.0 years | 71.4% progressed to dementia (10/14)
Christensen, 1997^285^ | History of cerebral dysfunction or presence of a physical disorder known to cause cerebral dysfunction; cognitive dysfunction reported by self or informant; abnormality on cognitive measures (i.e., >1.5 SDs below average); excluded: persons with drinking problems, DSM-III-R delirium or amnestic syndromes, and International Classification of Diseases-10^th^ edition dementia or probable dementia | 36 community-dwelling volunteers | 3.6 years | 12.0% progressed to dementia (3/25)
Clarke, 1996^286^ | Clifton Assessment Procedures for the Elderly Information/Orientation score = 8 or 9; age 65 years | 24 elderly individuals recruited from a representative community sample | 4.0 years | 100% evidenced “cognitive decline” (6/6)
Bowen, 1997^287^ | Isolated memory loss presumably based upon neuropsychological test performance (no specific criteria provided); excluded: persons with dementia using DSMIII- R criteria | 25 persons with complaints of cognitive impairment from an Alzheimer’s Disease registry | 4.0 years | 47.6% progressed to dementia (10/21)
Johansson, 1997^280^ | Mild impairment on cognitive measures and age between 84 and 90 years; excluded: persons with dementia using DSM-III-R criteria | 31 individuals with stable “mild dysfunction” in second wave of the study | 4.0 years | 43.8% progressed to dementia (7/16)
Petersen, 1995^278^ | Clinical Dementia Rating = 0.5; cognitive complaint reported by the individual, informant or physician; normal score on cognitive screening measures; performance >1.5 SDs below age appropriate levels on measures of memory; excluded: persons with dementia using DSM-III-R criteria | 66 individuals from the Mayo Clinic Alzheimer’s Disease Center and Alzheimer’s Disease Patient Registry | Every 1.5 years | 37.9% progressed to probable Alzheimer’s Disease (25/66)
Rubin, 1989^288^ | Clinical Dementia Rating = 0.5; age 64 and 81 years; excluded: persons with neurological, psychiatric, and serious medical disorders | 16 community-dwelling volunteers recruited through public ads and physician referrals | 5.4 years | 68.8% progressed to Clinical Dementia Rating = 1 or autopsy confirmed Alzheimer’s Disease (7/16)

Appendix E Table 18 Association Between Cognitive Impairment and Dementia in Older Persons

Reference | Study | Adjustment | Exposure | Type of Estimate | Mean (95% CI)
Alzheimer's Disease
Heun, 2006^174^ | Case control study: patients with Alzheimer’s disease and population based control subjects group-matched to the patient sample for age, gender, and educational background | Adjusted for duration of individual followup and source of information during the followup investigation (i.e., .personal interview vs. family history information only) | Cognitive impairment, MMSE | OR | 2.51 (1.08l 5.81
Aggarwal, 2005^289^ | Religious Orders Study | Adjusted for age, sex, and education | Cognitive impairment, MMSE | RR | 2.45 (1.53; 3.92)
Jessen, 2010^172^ | German Study on Aging, Cognition and Dementia in Primary Care Patients Study Group | Adjusted for age, sex, education, baseline SISCO score, Geriatric Depression Scale score, and ApoE4 genotype | Subjective memory impairment, no mild cognitive impairment | OR | 3.44 (0.97; 12.16)
Jessen, 2010^172^ | German Study on Aging, Cognition and Dementia in Primary Care Patients Study Group | Adjusted for age, sex, education, baseline SISCO score, Geriatric Depression Scale score, and ApoE4 genotype | Subjective memory impairment + mild cognitive impairment, MMSE | OR | 19.33 (5.29; 70.81)
Jessen, 2010^172^ | German Study on Aging, Cognition and Dementia in Primary Care Patients Study Group | Adjusted for age, sex, education, baseline SISCO score, Geriatric Depression Scale score, and ApoE4 genotype | Amnestic cognitive impairment (SISCO + MMSE) | OR | 60.28 (12.23; 297.1)
Jessen, 2010^172^ | German Study on Aging, Cognition and Dementia in Primary Care Patients Study Group | Adjusted for age, sex, education, baseline SISCO score, Geriatric Depression Scale score, and ApoE4 genotype | Nonamnestic cognitive impairment, MMSE | OR | 13.8 (3.53; 53.99)
Any dementia
Jessen, 2010^172^ | German Study on Aging, Cognition and Dementia in Primary Care Patients Study Group | Adjusted for age, sex, education, baseline SISCO score, Geriatric Depression Scale score, and ApoE4 genotype. | Subjective memory impairment, no mild cognitive impairment | OR | 2.22 (0.97; 4.97)
Jessen, 2010^172^ | German Study on Aging, Cognition and Dementia in Primary Care Patients Study Group | Adjusted for age, sex, education, baseline SISCO score, Geriatric Depression Scale score, and ApoE4 genotype. | Subjective memory impairment + mild cognitive impairment (MMSE) | OR | 8.92 (3.69; 21.6)
Jessen, 2010^172^ | German Study on Aging, Cognition and Dementia in Primary Care Patients Study Group | Adjusted for age, sex, education, baseline SISCO score, Geriatric Depression Scale score, and ApoE4 genotype. | Amnestic cognitive impairment (SISCO + MMSE) | OR | 29.24 (8.75; 97.78)
Vascular dementia
Jessen, 2010^172^ | German Study on Aging, Cognition and Dementia in Primary Care Patients Study Group | Adjusted for age, sex, education, baseline SISCO score, Geriatric Depression Scale score, and ApoE4 genotype. | Subjective memory impairment, no mild cognitive impairment | OR | 1.64 (0.41; 6.53)
Jessen, 2010^172^ | German Study on Aging, Cognition and Dementia in Primary Care Patients Study Group | Adjusted for age, sex, education, baseline SISCO score, Geriatric Depression Scale score, and ApoE4 genotype. | Subjective memory impairment + mild cognitive impairment (MMSE) | OR | 1.05 (0.1; 11.08)
| | | Nonamnestic cognitive impairment | OR | 6.26 (2.41; 16.28

Appendix E Table 19 Predictors of Dementia in Older Persons With Cognitive Impairment222,276

Author, year | Comparison Groups | Sample Size | Predictors of Dementia
Rubin, 1989^288^ | Clinical dementia rating=0.5 vs. Clinical dementia rating>=1 | n=16 | None (including Blessed, Short Portable Mental Status Questionnaire, aphasia battery)
Petersen, 1993^290^ | MCCI (stable) vs. Alzheimer’s Disease | n=73 | Selective Reminding Test learning and semantic cues
Haenninen, 1995^291^ | Age associated memory impairment vs. dementia | n=176 | Memory(Selective Reminding Test, BVRT, Wechsler Memory Scale VR+ Paired Associate Learning), and word fluency (letter and category)
Petersen, 1995^278^ | Mild cognitive impairment (stable) vs. dementia | n=66 | MMSE, Mattis Dementia Rating Scale, Selective Reminding Test learning and semantic cues
Tierney, 1996^292^ | Global Deterioration Scale-2–3 vs. dementia | n=107 | Rey Auditory Verbal Learning Test delayed recall (age- and-education-corrected)
Tierney, 1996^279^ | Global Deterioration Scale-2–3 vs. dementia | n=123 | Rey Auditory Verbal Learning Test delayed recall and Wechsler Memory Scale Mental Control (age-and-education corrected)
Tierney, 1996^293^ | Global Deterioration Scale-2–3 vs. dementia | n=120 | Rey Auditory Verbal Learning Test, Wechsler Memory Scale Mental Control and Informant perceptions (Cambridge Mental Disorders in the Elderly Examination)
Devanand, 1997^282^ | Clinical Dementia Rating 0–0.5 vs. dementia | n=62 | Wechsler Adult Intelligence Scale-Revised(Digit Symbol, Picture Arrangement, Block Design), Selective Reminding Test LRT, category fluency, memory items from modified MMSE, age
Bowen, 1997^287^ | Isolated memory loss vs. dementia | n=21 | None (including MMSE, Mattis Dementia Rating Scale, Fuld Object Memory Test, Boston Naming Test, Wechsler Adult Intelligence Scale- Revised, and Wechsler Adult Intelligence Scale Revised Logical Memory I, Logical Memory II, VR I, VR II)
Johansson, 1997^280^ | Mild dysfunction vs. dementia | n=70 | Lower baseline scores on more demanding tasks
Johnson, 1998^281^ | Clinical Dementia Rating=0.5 vs. dementia | n=45 | Single photon emission computed tomography, California Verbal Learning Test, Wechsler Memory Scale VR II, Trails B
Jack, 1999^283^ | Mild Cognitive Impairment (stable) vs. dementia | n=80 | Hippocampal volume (MRI), Mattis Dementia Rating Scale, Selective Reminding Test free recall and age(but not APOE, MMSE, Wechsler Memory Scale-Revised, Rey Auditory Verbal Learning Test, or letter fluency.
Flicker, 1991^237^ | Global Deterioration Scale ≤3 vs. Global Deterioration Scale ≥4 | n=32 | Shopping list verbal recall, misplaced object recall, object function recognition, and object identification

Appendix E Table 20 Differences in Prevalence of Frailty in Older Persons According to Definition of Frailty

Reference | Sample | Definition of Frailty | Mean (95% CI)
Alameda County Study
Cigolle, 2009^72^ | 574 | Frail according to functional domain model (>2 domains with deficiencies) | 26.0 (22.6; 29.7)
Beaver Dam Eye Study Cohort
Klein, 2005^6^ | 2,515 | Frailty markers: gait time, handgrip strength, peak respiratory flow rate, ability to stand from a sitting position without using arms, best corrected visual acuity. Mild 1–2 markers, moderate 3 markers, severe 4–5 markers | 44.7 (42.8; 46.7)
Canadian Study of Health and Aging
Rockwood, 2007^145^ | 2,305 | Frailty index based on; wt loss >10lbs or greater than 5% of body wt, subjective exhaustion, impaired walking, Timed Up and Go Test > 19s, abnormal strength on physical examination | 16.5 (15.0; 18.1)
Gutman, 2001^143^ | 5,987 | Rockwood frailty index: 1 - Healthy, 2 - Bladder incontinence, 3 - Mild/moderate frailty, 4 - severe frailty | 21.2 (20.2; 22.3)
Gutman, 2001^143^ | 3,925 | Frail: mild/moderate, severe | 8.9 (8.0; 9.8)
Gutman, 2001^143^ | 8,914 | Frail: mild/moderate, severe | 21.2 (20.4; 22.1)
Cardiovascular Health Study
Fried, 2001^55^ | 5,317 | 3 or more of criteria list | 6.9 (6.2; 7.6)
Walston, 2002^56^ | 4,735 | 3 or more of criteria list | 6.3 (5.6; 7.0)
Cigolle, 2009^72^ | 5,317 | Frail according to Biologic Syndrome Model( >3 frailty defining criteria) | 7.0 (6.3; 7.7)
Depression Among Caregivers of Impaired Elders Study
Tennstedt, 1992^120^ | 4,185 | HRCA vulnerability index | 18.9 (17.7; 20.1)
Effects of Two Exercise Interventions Among Community-residing Older Adults Study
Dayhott, 1998^121^ | 84 | Frailty measurement based on two measures: WHOAFC and self-reported health status | 17.9 (11.1; 27.6)
Kaiser Permanente Inter-regional Committee on Aging Study
Brody, 1997^19^ | 5,810 | Eligibility for nursing home placement or long-term placement | 14.6 (13.7;15.5)
National Population Health Survey
Song, 2010^142^ | 2,740 | Frailty index based on the number of deficits divided by the number of variables considered (36). People with nine or more deficits were considered frail. | 22.7 (21.0; 24.3)
New Haven Older Americans Independence Center Study
Hardy, 2005^37^ | 754 | Frail: a timed score of greater than 10 seconds on the rapid gait test (i.e., walking back and forth over a 10-foot (3.048-m) course as quickly as possible) | 42.7 (39.2; 46.3)
The Health and Retirement Study
Cigolle, 2009^72^ | 11,113 | Frail according to at least one model (Functional Domains Model, Burden, or biologic syndrome model) | 30.2 (29.4; 31.1)
Cigolle, 2009^72^ | 11,113 | Frail according to all three models (Functional Domains Model, Burden, or biologic syndrome model) | 3.1 (2.8; 3.4)
Cigolle, 2009^72^ | 11,113 | Frail - >2 domains with deficiencies | 29.0 (28.2; 29.90
Cigolle, 2009^72^ | 11,113 | Frail according to Burden model | 15.4 (14.7; 16.1)
Cigolle, 2009^72^ | 11,113 | Frail according to functional domain model | 20.3 (19.6; 21.1)
Cigolle, 2009^72^ | 11,113 | Frail according to biologic syndrome model | 10.9 (10.3; 11.5)
Cigolle, 2009^72^ | 11,113 | Frail according to an Index of Deficit Accumulation (>0.2) | 32.0 (31.1; 32.9)
Cigolle, 2009^72^ | 11,113 | Frail according to Biologic Syndrome Model(>3 frailty defining criteria) | 11.0 (10.4; 11.6)
Cigolle, 2009^72^ | 1,657 | Frail according to functional domains (weighted for nonresponse percentages) | 21.3 (19.4; 23.3)
Cigolle, 2009^72^ | 1,657 | Frail according to Burden model (weighted (weighted for nonresponse percentages) | 14.8 (13.2; 16.6)
Cigolle, 2009^72^ | 1,657 | Frail according to Biologic Syndrome Model (weighted (weighted for nonresponse percentages) | 13.3 (11.7; 15.0)
The MOBILIZE (Maintenance of Balance, Independent Living, Intellect, And Zest in the Elderly) Boston Study
Kiely, 2009^26^ | 765 | Frailty index based on; weight loss >10 pounds or greater than 5% of body weight, subjective exhaustion, impaired walking, Timed Up and Go Test >19 seconds, abnormal strength on physical examination | 10.0 (8.1; 12.3)
Kiely, 2009^26^ | 765 | Cardiovascular Health Study Frailty Index | 76.0 (72.8; 78.9)

Appendix E Table 21 Differences in Prevalence of Frailty in Older Persons By Race

Reference | Study | Race | Definition | Estimate | Prevalence (95% CI)
Accumulation deficit
Bowles, 2000^123^ | Frailty Study of African Americans in South Central Los Angeles | African American | Any of four: functional impairment, depression, urinary incontinence, falls | crude | 66.9 (62.7; 70.9)
Cigolle, 2009^72^ | Health and Retirement Study | African American | Frail according to Functional Domains Model | * | 34.0 (31.7; 36.3)
Cigolle, 2009^72^ | Health and Retirement Study | African American | Frail according to Burden Model | * | 20.2 (18.3; 22.2)
Cigolle, 2009^72^ | Health and Retirement Study | Caucasian | Frail according to Functional Domains Model | * | 20.2 (18.3; 22.2)
Cigolle, 2009^72^ | Health and Retirement Study | Caucasian | Frail according to Burden Model | * | 14.4 (12.8; 16.2)
Cigolle, 2009^72^ | Health and Retirement Study | Hispanic | Frail according to Functional Domains Model | * | 22.3 (20.3; 24.3)
Cigolle, 2009^72^ | Health and Retirement Study | Hispanic | Frail according to Burden Model | * | 12.8 (11.3; 14.5)
Phenotype
Fried, 2001^55^ | Cardiovascular Health Study | African American | Three or more of criteria list | crude | 12.9 (12.0; 13.8)
Fried, 2001^55^ | Cardiovascular Health Study | Caucasian | Three or more of criteria list | crude | 5.9 (5.3; 6.5)
Hardy, 2005^37^ | New Haven Older Americans Independence Center Study | African American | Rapid gait test >10 seconds | crude | 54.2 (50.6; 57.7)
Hardy, 2005^37^ | New Haven Older Americans Independence Center Study | Caucasian | Rapid gait test >10 seconds | crude | 41.5 (38.0; 45.1)
Ottenbacher, 2005^204^ | Hispanic Established Populations Epidemiologic Studies of the Elderly | Hispanic | Modified Frailty Index: Scale of 0–4 for weight loss, exhaustion, walking speed, and grip strength | crude | 20.0 (17.0; 23.3)
Ottenbacher, 2009^203^ | Hispanic Established Populations Epidemiologic Studies of the Elderly | Hispanic | Frailty index based on weight loss, exhaustion, walking speed, grip strength, and physical activity | crude | 7.6 (6.5; 8.8)
Cigolle, 2009^72^ | Health and Retirement Study | African American | Frail according to Biologic Syndrome Model | * | 30.0 (27.8; 32.2)
Cigolle, 2009^72^ | Health and Retirement Study | Caucasian | Frail according to Biologic Syndrome Model | * | 11.8 (10.3; 13.4)
Cigolle, 2009^72^ | Health and Retirement Study | Hispanic | Frail according to Biologic Syndrome Model | * | 15.0 (13.4; 16.9)
Kiely, 2009^26^ | MOBILIZE | Caucasian | Frailty index based on; weight loss >10 pounds or greater than 5% of body weight, subjective exhaustion, impaired walking, Timed Up and Go Test >19 seconds, abnormal strength on physical examination | crude | 8.6 (6.8; 10.8)

* Weighted percentages were derived using Health and Retirement Study respondent population weights to adjust for differential probability of selection into the sample and differential nonresponse

Appendix E Figure 2 Differences in Prevalence of Nutritional Risk (Defined as a Mini-Nutritional Assessment Score of <24) in European Older Persons: SENECA Study221

Appendix E Table 22 Association Between Micronutrients and Chronic Inflammation in Older Disabled Women: Women’s Health and Aging Study I102

Definition of Micronutrient | Odds Ratio^*^ (95% CI)
Outcome - highest tertile of interleukin-6 level
a-Carotene (lmol/liter) — one-standard-deviation increase in log-transformed micronutrient level | 0.65 (0.53; 0.8)
b-Carotene (lmol/liter) — one-standard-deviation increase in log-transformed micronutrient level | 0.72 (0.59; 0.87)
Lycopene (lmol/liter) —one-standard-deviation increase in log-transformed micronutrient level | 0.75 (0.63; 0.91)
Lutein/zeaxanthin (lmol/liter) — one-standard-deviation increase in log-transformed micronutrient level | 0.72 (0.59; 0.89)
b-Cryptoxanthin (lmol/liter) — one-standard-deviation increase in log-transformed micronutrient level | 0.77 (0.63; 0.94)
Retinol (lmol/liter) — one-standard-deviation increase in log-transformed micronutrient level | 0.87 (0.72; 1.05)
a-Tocopherol (lmol/liter) — one-standard-deviation increase in log-transformed micronutrient level | 0.91 (0.74; 1.11)
a-Tocopherol:cholesterol ratio (mg/g) — one-standard-deviation increase in log-transformed micronutrient level | 1.01 (0.82; 1.24)
Total carotenoids (lmol/liter) — one-standard-deviation increase in log-transformed micronutrient level | 0.65 (0.53; 0.79)
Selenium (lg/liter) — one-standard-deviation increase in log-transformed micronutrient level | 0.65 (0.52; 0.8)
Zinc (lg/liter) — one-standard-deviation increase in log-transformed micronutrient level | 0.99 (0.82; 1.2)
Outcome - interleukin-6 level increase by >0.5 standard deviation (3.21 pg/ml)
a-Carotene (lmol/liter) — <0.039 vs. >0.094 | 7.99 (2.27; 28.21)
b-Carotene (lmol/liter — <0.23 vs. >0.45 | 4.09 (1.38; 12.11)
Lutein/zeaxanthin (lmol/liter) — <0.27 vs. >0.41 | 5.57 (1.74; 17.8)
Total carotenoids (lmol/liter) — < 1.17 vs. >1.80 | 3.98 (1.51; 10.49)
a-Carotene (lmol/liter) — <0.040 vs. >0.094 | 1.06 (0.7; 1.59)
a-Carotene (lmol/liter) — >0.040–0.094 vs. >0.094 | 1.19 (0.81; 1.74)

* After controlling for age, race, years of education, smoking status, body mass index, chronic obstructive pulmonary disease, peripheral arterial disease, angina, diabetes, physical activity, and incident cardiovascular disease.

Bold=significant association at 95% confidence level.

Appendix E Table 23 Association Between Multimorbid Conditions and Patient Outcomes in Older Persons

Reference | Study | Sample | Adjustment | Definition of Exposure | Gender | Estimate | Mean (95% CI or P Value)
Frailty
Xue, 2008^108^ | Women’s Health and Aging Study I | 599 | Adjusted for age, education, and race, number of chronic diseases, anxiety, personal mastery, depression, MMSE score, ADL, IADL, and mobility disability at baseline | Number of chronic diseases | Women | HR | 1.06 (1; 1.19)
Szanton, 2009^103^ | Women’s Health and Aging Studies | 728 | Adjusted for age, race, and education | Disease count (>3) | Women | OR | 1.47 (1.3; 1.71)
Chang, 2010^104^ | Women’s Health and Aging Studies I and II and complementary cohorts | 620 | Crude | Total inflammatory disease count (8) | Women | OR | 1.84 (1.5; 2.26
Sarcopenia (aLM/ht2)
Newman, 2003^75^ | Health Aging and Body Composition (Health ABC) Study | 3,075 (analytic sample: 2,984) | Adjusted for age, race, drinking, smoking, physical activity, and body mass index | ≥3 conditions | Men | OR | 2.8 (1.7; 4.8)
Newman, 2003^75^ | Health Aging and Body Composition (Health ABC) Study | 3,075 (analytic sample: 2,984) | Adjusted for age, race, drinking, smoking, physical activity, and body mass index | ≥3 conditions | Women | OR | 0.8 (0.4; 1.5)
Sarcopenia (residual)
Newman, 2003^75^ | Health Aging and Body Composition (Health ABC) Study | 3,075 (analytic sample: 2,984) | Adjusted for age, race, drinking, smoking, physical activity | ≥3 conditions | Men | OR | 1.5 (1; 2.3)
Newman, 2003^75^ | Health Aging and Body Composition (Health ABC) Study | 3,075 (analytic sample: 2,984) | Adjusted for age, race, drinking, smoking, physical activity | ≥3 conditions | Women | OR | 1.1 (0.7; 1.6)
Mortality
Xue, 2008^108^ | Women’s Health And Aging Study I | 599 | Adjusted for age, education, and race, number of chronic diseases, anxiety, personal mastery, depression, MMSE score, ADL, IADL, and mobility disability at baseline | Number of chronic diseases | Women | HR | 1.18 (1; 1.41)
Seeman, 2004^21^ | MacArthur Studies of Successful Aging | 657 | Adjusted for age, gender, ethnicity | Chronic conditions, comorbidity | Total | OR | 1.32 (1.1; 1.62)
Kelman, 1994^47^ | Norwood -Montefiore Aging Study (NMAS) | 1,855 | Adjusted for age, income, self- assessed health, receiving social support, sex, cognitive impairment, education, marital status, depression, problems in daily activities | Two or more cardiovascular conditions vs. not in persons with mild/moderate impairment | Total | RR | 1.5 (1.1; 2.18)
Schultz-Larsen, 2007^159^ | Glostrup Aging Study | 705 | Adjusted by sex, income, education, individual diseases, weight, and the maximal power | Comorbidity 2–6 vs. 0–1 at 5-year followup | Total | OR | 1.6 (1; 2.47)
Schultz-Larsen, 2007^159^ | Glostrup Aging Study | 705 | Adjusted by sex, income, education, individual diseases, weight, and the maximal power | 10-year followup | Total | OR | 2 (1.4; 2.82)
Schultz-Larsen, 2007^159^ | Glostrup Aging Study | 705 | Adjusted by sex, income, education, individual diseases, weight, and the maximal power | 15-year followup | Total | OR | 1.59 (1.1; 2.25)
Dorr, 2006^115^ | Community-dwelling elderly patients with at least one chronic disease | 2,166 | Adjusted for age, sex, PCS and MCS score (from SF-12) | 3 diseases vs. ≤2 | Total | OR | 1.3 (p= 0.2)
Dorr, 2006^115^ | Community-dwelling elderly patients with at least one chronic disease | 2,166 | Adjusted for age, sex, PCS and MCS score (from SF-12) | 4–5 vs. ≤2 | Total | OR | 1.85 (p = 0.001)
Dorr, 2006^115^ | Community-dwelling elderly patients with at least one chronic disease | 2,166 | Adjusted for age, sex, PCS and MCS score (from SF-12) | ≥6 vs. ≤2 | Total | OR | 2.12 (p <0.001)
Malmgren, 1999^116^ | A prospective cohort from a large health maintenance organization of (Group Health Cooperative (GHC) in Seattle, Washington) | 1,129 | Adjusted for age, education, widowhood, CDC intervention participation, co-morbid conditions, and self-reported health | Charlson Comorbidity Index 1 vs. 0 | Female | OR | 1.89 (1.05; 3.4)
Malmgren, 1999^116^ | A prospective cohort from a large health maintenance organization of (Group Health Cooperative (GHC) in Seattle, Washington) | 1,129 | Adjusted for age, education, widowhood, CDC intervention participation, co-morbid conditions, and self-reported health | Charlson Comorbidity Index 2–4 vs. 0 | Female | OR | 2.54 (1.08; 5.97)
Malmgren, 1999^116^ | A prospective cohort from a large health maintenance organization of (Group Health Cooperative (GHC) in Seattle, Washington) | 1,129 | Adjusted for age, education, widowhood, CDC intervention participation, co-morbid conditions, and self-reported health | Charlson Comorbidity Index 1 vs. 0 | Male | OR | 1.09 (0.63; 1.9)
Malmgren, 1999^116^ | A prospective cohort from a large health maintenance organization of (Group Health Cooperative (GHC) in Seattle, Washington) | 1,129 | Adjusted for age, education, widowhood, CDC intervention participation, co-morbid conditions, and self-reported health | Charlson Comorbidity Index 2–4 vs. 0 | Male | OR | 2.27 (1.27; 4.08)
Long, 2005^118^ | Medicaid program: applicants to the home-and community-based care (HCBC) | 1,690 | Adjusted for receiving HCBC services, age, race, gender, health status, did not have hospital stay or SNF, LTCH, rehab hospital stay in prior 6 months, 0 to 3 MSQ errors, needs supervision never/sometimes/unknown, does not need assistance with mobility, does not need help with medication or meal preparation, does not have a mental illness, Alzheimer’s or dementia, does not have medications with potential side effects in elderly, lives with spouse/child/other/unknown, primary caregiver is other relative/nonrelative/none/unknown, did not have Medicare home health use in prior 6 months, monthly income greater than $1,000. | Number of health conditions vs. no comorbidities | Total | OR | 1.193 (p <0.05)
Mor, 1994^294^ | Longitudinal Study on Aging | 7,407 | Adjusted for age, gender, self-rated health, number of medical conditions, baseline functional status, and interaction between age and gender | Number of illnesses | Total | OR | 1.3 (1.2; 1.3)
Tilvis, 2004^161^ | Helsinki Aging Study | 650 | Adjusted for age and gender | Comorbidity present vs. not present | 1 year | RR | 5.71 (1.72; 18.9)
Tilvis, 2004^161^ | Helsinki Aging Study | 650 | Adjusted for age and gender | Comorbidity present vs. not present | 5 year | RR | 1.92 (1.29; 2.86)
Tilvis, 2004^161^ | Helsinki Aging Study | 650 | Adjusted for age and gender | Comorbidity present vs. not present | 10 year | RR | 2.2 (1.51; 3.26)
Association between mortality and polypharmacy
Ganguli, 2002^85^ | Population-based dementia registry | 1,064 | Crude | Number of prescription drugs taken (per drug) | Total | RR | 1.16 (p <0.05)
Ahmad, 2005^209^ | Nottingham Longitudinal Study of Activity and Ageing (NLSAA) | 1,042 | Crude | Total number of prescribed drugs including hypnotics | Total | HR | 1.13 (1.1; 1.20)
Helmer, 1999^166^ | PAQUID (Personnes Agees QUID) Research Program | 3,660 | Adjusted for age, sociodemographic factors, physical and mental health, and disability | ≥5 medications versus None | Men | RR | 0.96 (0.7; 1.42)
Helmer, 1999^166^ | PAQUID (Personnes Agees QUID) Research Program | 3,660 | Adjusted for age, sociodemographic factors, physical and mental health, and disability | ≥5 medications versus None | Women | RR | 1.15 (0.7; 2.04)

HR=hazard ratio; OR=odds ratio; bold=statistically significant.

Appendix E Table 24 Association Between Poor Perceived Health and Mortality in Older Persons

Reference | Study | Sample Size | Adjustment | Subgroups | Estimate | Mean (95% CI or P Value)
Poor vs. excellent/very good
Grant, 1995^295^ | Longitudinal Study of Aging | 4,380 | Adjusted for self-reported health, age, race, marital status, education, ADL difficulties, BMI, self-reported disease, prior hospitalization, social contacts, and interaction self-reported health with time | Female, 5 months | Hazard Ratio | 3.8 (2; 7.1)
Grant, 1995^295^ | Longitudinal Study of Aging | 4,380 | | Female, 14 months | Hazard Ratio | 2.7 (1.8; 4.1)
Grant, 1995^295^ | Longitudinal Study of Aging | 4,380 | | Female, 23 months | Hazard Ratio | 2 (1.3; 3)
Grant, 1995^295^ | Longitudinal Study of Aging | 4,380 | | Female, 32 months | Hazard Ratio | 1.4 (0.7; 2.7)
Grant, 1995^295^ | Longitudinal Study of Aging | 4,380 | | Male | Hazard Ratio | 1.7 (1.1; 2.6)
Wolinsky, 1995^296^ | Longitudinal Study of Aging | 7,527 | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | Total | Odds Ratio | 1.32 (p = 0.0002)
Steinbach, 1992^297^ | Longitudinal Study of Aging | 5,151 | Adjusted for age, sex, race, family income, self-perceived health status, ADLs, hypertension, stroke or CVA, cancer, heart disease, arthritis, DM, fall, social network, social activities, and living arrangement | Total | Odds Ratio | 2.48 (1.93; 3.19)
Poor/fair health vs. good health
Porell, 2001^134^ | Medicare Current Beneficiary Survey | 17,299 | Adjusted for demographics, insurance coverage and access, health behaviors, and chronic conditions | Functional dependence | Odds Ratio | 2.24 (p <0.05)
Porell, 2001^134^ | Medicare Current Beneficiary Survey | 7,407 | Adjusted for demographics, insurance coverage and access, health behaviors, and chronic conditions | Functional limitations | Odds Ratio | 1.39 (p >0.05)
Porell, 2001^134^ | Medicare Current Beneficiary Survey | 6,488 | Adjusted for demographics, insurance coverage and access, health behaviors, and chronic conditions | IADL disability | Odds Ratio | 1.99 (p <0.01)
Porell, 2001^134^ | Medicare Current Beneficiary Survey | 9,595 | Adjusted for demographics, insurance coverage and access, health behaviors, and chronic conditions | 1+ ADL disability | Odds Ratio | 1.7 (p <0.05)
Porell, 2001^134^ | Medicare Current Beneficiary Survey | 3,976 | Adjusted for demographics, insurance coverage and access, health behaviors, and chronic conditions | 3+ ADL disability | Odds Ratio | 1.48 (p <0.05)
Gutman, 2001^143^ | Canadian Study of Health and Aging | 8,912 | Adjusted for age, sex, trouble, health, and interactions | Total | Hazard Ratio | 1.8 (1.45; 2.23)

Appendix E Table 25 Association Between Institutionalization and Comorbidity in Older Persons

Reference | Study | Sample | Adjustment | Estimate | Mean (95% CI or P Value)
Multiple comorbidities
Long, 2005^118^ | Medicaid program: applicants to the home- and community-based care (HCBC) | 1,690 | Adjusted age, race, sex, health status, hospital stay or SNF, LTCH, rehab hospital stay in prior 6 months, 0 to 3 MSQ errors, ADL and IADL, Alzheimer’s or dementia, does not have medications with potential side effects in elderly, lives with spouse/child/other/unknown, primary caregiver is other relative/nonrelative, did not have Medicare home health use in prior 6 months, monthly income greater than $1000. | Odds Ratio | 0.86 (p <0.05)
Mor, 1994^294^ | Longitudinal Study on Aging | 7,407 | Adjusted for age, sex, self-rated health, number of medical conditions, baseline functional status, and the interaction between age and sex | Odds Ratio | 1.2 (1.1; 1.3)
Falconer, 1992^113^ | 2-year longitudinal study of independent residents of a continuing care retirement community | 152 | Adjusted for age, sex, GERI-AIMS, disease severity, and Williams test | Relative Risk | 0.89 (p >0.05)
Previous hospitalization (SNF, LTCH, rehab hospital stay)
Long, 2005^118^ | Applicants to the home- and community-based care (HCBC) programs | 1,690 | Adjusted age, race, sex, health status, hospital stay or SNF, LTCH, rehab hospital stay in prior 6 months, 0 to 3 MSQ errors, ADL and IADL, Alzheimer’s or dementia, does not have medications with potential side effects in elderly, lives with spouse/child/other/unknown, primary caregiver is other relative/nonrelative, did not have Medicare home health use in prior 6 months, monthly income greater than $1000. | Odds Ratio | 3.848 (p <0.01)
Hospital admission, 12 months
Goodin, 2004^298^ | Secondary analysis of data from the Medicare Current Beneficiary Survey | 3,232 | Adjusted for sociodemographic characteristics, health status, functional ability, previous use of health services, insurance, income, and family composition | Odds Ratio | 2.01 (p = 0.001)
Miller, 1999^299^ | Longitudinal Study of Aging | 12,007 | Adjusted for sex, age, race, hospitalization, marital status, living, family income, home ownership, survey transition year | Odds Ratio | 1.65 (0.13; 2.12)
Wolinsky, 1992^300^ | Longitudinal Study of Aging | 5,151 | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | Odds Ratio | 1.463 (p = 0.0184)
Coward, 1996^301^ | Longitudinal Study of Aging | 7,527 | Adjusted for residence, sociodemographic characteristics, health status characteristic, and social support characteristics | Odds Ratio | 1.23 (p <0.01)

Appendix E Table 26 Association Between Institutionalization and Self-Perceived Health Status in Older Persons

Reference | Study | Sample Size of the Study | Adjustment | Estimate | Mean (95% CI or P Value)
Excellent vs. poor
Coward, 1996^301^ | Longitudinal Study of Aging | 7,527 | Adjusted for residence, socio-demographic characteristics, health status characteristic, and social support characteristics | Odds Ratio | 0.7 (0.5; 0.9)
Very good vs. poor
Coward, 1996^301^ | Longitudinal Study of Aging | 7,527 | Adjusted for residence, socio-demographic characteristics, health status characteristic, and social support characteristics | Odds Ratio | 1.0 (0.8; 1.3)
Good vs. excellent/very good
Mor, 1994^294^ | Longitudinal Study on Aging | 7,407 | Adjusted for age, gender, self-rated health, number of medical conditions, baseline functional status, and the interaction between age and gender | Odds Ratio | 1.8 (1.4; 2.3)
Good vs. poor
Coward, 1996^301^ | Longitudinal Study of Aging | 7,527 | Adjusted for residence, socio-demographic characteristics, health status characteristic, and social support characteristics | Odds Ratio | 1.0 (0.8; 1.2)
Good or very good vs. poor or very poor
St. John, 2002^150^ | Canadian Study of Health and Aging | 8,073 | Adjusted for age, gender, education, Time 1 MMSE, and self-rated health | Odds Ratio | 1.2 (1.0; 1.5)
Fair vs. poor
Coward, 1996^301^ | Longitudinal Study of Aging | 7,527 | adjusted for residence, socio-demographic characteristics, health status characteristic, and social support characteristics | Odds Ratio | 1.1 (0.9; 1.4)
Poor
Gutman, 2001^143^ | Canadian Study of Health and Aging | 8,912 | Adjusted for age, sex, trouble, health, and interactions | Hazard Ratio | 1.8 (1.3; 2.4)
Kersting, 2001^302^ | Longitudinal Study of Aging | 7,527 | Adjusted for social support, poverty, age, gender, race, ADL/IADL score, self-reported health status, and fall | Hazard Ratio | 1.1 (1.1; 1.2)
Steinbach, 1992^297^ | Longitudinal Study of Aging | 4,547 | Adjusted for age, sex, race, family income, self- perceived health status, ADLs, hypertension, stroke or CVA, cancer, heart disease, arthritis, DM, fall, social network, social activities, and living arrangement | Odds Ratio | 1.7 (1.1; 2.5)
Poor (dose response 1–5)
Speare, 1991^303^ | Longitudinal Study of Aging | 5,151 | Adjusted for disability, incontinence, blindness, deafness, limitation in major activities, social support, age, sex, income | Odds ratio | 1.2 (1.0; 1.4)
Poor, African American
Kersting, 2001^304^ | Longitudinal Study of Aging | 555 | Adjusted for social support, poverty, age, gender, race, ADL/IADL score, self-reported health status, and fall | Hazard Ratio | 1.2 (0.8; 1.7)
Belgrave, 1994^305^ | Longitudinal Study of Aging | 560 | Adjusted for ADL, IADL, self-health, activity limitations, confused, age, sex, living alone, education, income, and Medicaid | Odds Ratio | 1.1 (0.8; 1.5)
Poor, Caucasians
Kersting, 2001^304^ | Longitudinal Study of Aging | 6,986 | Adjusted for social support, poverty, age, gender, race, ADL/IADL score, self-reported health status, and fall | Hazard Ratio | 1.2 (1.1; 1.2)
Belgrave, 1994^305^ | Longitudinal Study of Aging | 6,880 | Adjusted for ADL, IADL, self-health, activity limitations, confused, age, sex, living alone, education, income, and Medicaid | Odds Ratio | 1.1 (1.1; 1.2)
Poor/fair
Long, 2005^118^ | Medicaid program- applicants to the home- and community- based care (HCBC) | 1,690 | Adjusted for age, race, gender, health status, did not have hospital stay or SNF, LTCH, rehab hospital stay in prior 6 months, 0 to 3 MSQ errors, ADL, IADL, Alzheimer’s or dementia, does not have medications with potential side effects in elderly, lives with spouse/child, primary caregiver is other relative/non-relative/none/unknown, did not have Medicare home health use in prior 6 months, monthly income greater than $1000. | Odds Ratio | 1.4 (p >0.05)
Mor, 1994^294^ | Longitudinal Study on Aging | 7,407 | Adjusted for age, gender, self-rated health, number of medical conditions, baseline functional status, and the interaction between age and gender | Odds Ratio | 2.7 (2.1; 3.5)

Bold=statistically significant.

Appendix E Table 27 Association Between Comorbidity and Hospitalization in Older Persons

Reference | Definition of Exposure | Definition of the Outcome | Study | Sample | Adjustment | Estimate | Mean (95% CI or P Value)
Multiple comorbidities
Shelton, 2000^114^ | 2 or more comorbidities vs. none | A hospitalization or ED visit during the first year of the study | Generalist Physician Initiative | 411 | Adjusted for age, female sex, living arrangement, race, marital status, less than a high school education, taking 5 or more prescription medications daily, comorbid illness category, restricted-activity bed days category (confined to bed for at least 1 day during the past 12 months), 5 health status measures of the HSQ, and the baseline indicator of any hospitalization or ED encounter | Odds Ratio | 1.7 (1.1; 2.9)
Comorbidity score
Dorr, 2006^115^ | 3 vs. ≤2 | Risk for hospitalization | 7,076 community- dwelling elderly patients | 1,899 | Adjusted for age, sex, PCS, and MCS score (from SF-12), and comorbidity score | Odds Ratio | 1.37 (p = 0.01)
Dorr, 2006^115^ | 4–5 vs. ≤2 | | | | | Odds Ratio | 1.46 (p = 0.004)
Dorr, 2006^115^ | ≥6 vs. ≤2 | | | | | Odds Ratio | 1.94 (p <0.001)
Numbers of medications
Shelton, 2000^114^ | 5+ prescription medications vs. not | A hospitalization or ED visit during the first year of the study | Generalist Physician Initiative | 411 | Adjusted for age, female sex, living arrangement, race, marital status, less than a high school education, taking 5 or more prescription medications daily, comorbid illness category, restricted-activity bed days category (confined to bed for at least 1 day during the past 12 months), 5 health status measures of the HSQ, and the baseline indicator of any hospitalization or ED encounter | Odds Ratio | 2.9 (2.2; 4.1)
Mazzaglia, 2007^187^ | ≥5 medications vs. not | Risk for hospitalization | ASSI, Florence, Italy | 5,396 | Not available | Odds Ratio | 2.24 (1.77; 2.84)
Previous hospitalization
Shelton, 2000^114^ | Any hospitalization or ED visit in prior year vs. not | A hospitalization or ED visit during the first year of the study | Generalist Physician Initiative | 411 | Adjusted for age, female sex, living arrangement, race, marital status, less than a high school education, taking 5 or more prescription medications daily, comorbid illness category, restricted-activity bed days category (confined to bed for at least 1 day during the past 12 months), 5 health status measures of the HSQ, and the baseline indicator of any hospitalization or ED encounter | Odds Ratio | 3.40 (2.70; 4.50)
Mazzaglia, 2007^187^ | Yes vs. no | Risk for hospitalization | ASSI in Florence, Italy | 5,396 | Not available | Odds Ratio | 3.60 (2.66; 4.87)
Chodosh, 2004^20^ | Yes vs. no in previous 2 years | Risk for hospitalization | MacArthur Research Network on Successful Aging Community Study | 598 | Adjusted for age, sex, race/ethnicity, and prior hospitalization | Odds Ratio | 2.40 (1.50; 4.00)
Boult, 1993^306^ | Hospital admission in last year | Repeated admission | Longitudinal Study on Aging | 5,876 | Adjusted for need variables, predisposing variables, and enabling variables | Odds Ratio | 1.70 (1.30; 2.30)
Stearns, 1996^307^ | Yes vs. no | Probability of nonterminal hospitalization | Longitudinal Study of Aging | 870 | Adjusted for cancer, heart disease, prior hospitalization, age, age square, insurance, and interaction between age and functional status | Odds Ratio | 1.70 (p <0.05)
Stearns, 1996^307^ | Yes vs. no | Number of nights of hospitalization | Longitudinal Study of Aging | 870 | Adjusted for cancer, heart disease, prior hospitalization, age, age square, insurance, and interaction between age and functional status | Odds Ratio | 1.33 (p <0.1)
Laditka, 2003^308^ | Number of previous admissions | Hospitalization for Ambulatory Care Sensitive Conditions | the Longitudinal Study of Aging | 3562 | Adjusted for age, education, insurance and marital status, health status, primary care access, self-rated health, comorbidities, physical impairments, and previous hospitalizations | Relative Risk | 12.11 (9.74; 14.48)
Laditka, 2003^308^ | Previous discharge within 90 days | | | | Adjusted for age, education, insurance and marital status, health status, primary care access, self-rated health, comorbidities, physical impairments, and previous hospitalizations | Relative Risk | 94.15 (93.92; 94.39)
Wolinsky, 1995^309^ | Hospital contact | Natural log of the mean annual number of hospital episodes (plus one) | Longitudinal Study of Aging | 2,538 | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | Odds Ratio in survivor with at least one hospital episode | 1.08 (p <0.001)
Wolinsky, 1995^309^ | Hospital contact | Natural log of the maximum absolute deviation (plus one) from the mean annual number of hospital episodes | Longitudinal Study of Aging | 2,538 | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | Odds Ratio in survivor with at least one hospital episode | 1.04 (p <0.01)
Wolinsky, 1995^309^ | Hospital contact | Natural log of the mean annual number of hospital episodes (plus one) | Longitudinal Study of Aging | 1,783 | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | Odds Ratio in decedents with at least one hospital episode | 1.16 (p <0.001)
Previous physician visits
Boult, 1993^306^ | >6 doctor visit in past year | Repeated admission | Longitudinal Study on Aging | 5,876 | Adjusted for need variables, predisposing variables, and enabling variables | Odds Ratio | 1.40 (1.10; 1.80)
Laditka, 2003^308^ | Physician visits ≥ 4 in previous 12 months | Hospitalization for Ambulatory Care Sensitive Conditions | Longitudinal Study of Aging | 3,562 | Adjusted for age, education, insurance and marital status, health status, primary care access, self-rated health, comorbidities, physical impairments, and previous hospitalizations | Relative Risk | 1.12 (1.00; 1.24)
Wolinsky, 1995^309^ | Physician visits | Natural log of the mean annual number of hospital episodes (plus one) | Longitudinal Study of Aging | 2,538 | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | Odds Ratio in survivor with at least one hospital episode | 1.01 (p <0.001)
Wolinsky, 1995^309^ | Physician visits | Natural log of the maximum absolute deviation (plus one) from the mean annual number of hospital episodes | Longitudinal Study of Aging | 2,538 | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | Odds Ratio in survivor with at least one hospital episode | 1.005 (p <0.01)
Wolinsky, 1995^309^ | Physician visits | Natural log of the mean annual number of hospital episodes (plus one) | Longitudinal Study of Aging | 1,783 | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | Odds Ratio in decedents with at least one hospital episode | 1.01 (p <0.001)
Wolinsky, 1995^309^ | Physician visits | Natural log of the maximum absolute deviation (plus one) from the mean annual number of hospital episodes | Longitudinal Study of Aging | 1,783 | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | Odds Ratio in decedents with at least one hospital episode | 1.00 (p>0.05)

Appendix E Table 28 Association Between Self-Perceived Health and Hospitalization in Older Persons

Reference | Study | Sample | Definition of the Outcome | Adjustment | Estimate | Mean (95% CI or P Value)
Health perception score
Shelton, 2000^114^ | Generalist Physician Initiative | 411 | A hospitalization or ED visit during the first year of the study | Adjusted for age, female sex, living arrangement, race, marital status, less than a high school education, taking 5 or more prescription medications daily, comorbid illness category, restricted- activity bed days category (confined to bed for at least 1 day during the past 12 months), 5 health status measures of the HSQ, and the baseline indicator of any hospitalization or ED encounter | Odds Ratio | 1 (0.98; 1)
Physical health score
Shelton, 2000^114^ | | | | Adjusted for age, female sex, living arrangement, race, marital status, less than a high school education, taking 5 or more prescription medications daily, comorbid illness category, restricted- activity bed days category (confined to bed for at least 1 day during the past 12 months), 5 health status measures of the HSQ, and the baseline indicator of any hospitalization or ED encounter | Odds Ratio | 0.99 (0.98; 1.1)
Mental health score
Shelton, 2000^114^ | | 411 | A hospitalization or ED visit during the first year of the study | Adjusted for age, female sex, living arrangement, race, marital status, less than a high school education, taking 5 or more prescription medications daily, comorbid illness category, restricted- activity bed days category (confined to bed for at least 1 day during the past 12 months), 5 health status measures of the HSQ, and the baseline indicator of any hospitalization or ED encounter | Odds Ratio | 1 (0.98; 1.1)
Pain score
Shelton, 2000^114^ | | 411 | A hospitalization or ED visit during the first year of the study | Adjusted for age, female sex, living arrangement, race, marital status, less than a high school education, taking 5 or more prescription medications daily, comorbid illness category, restricted- activity bed days category (confined to bed for at least 1 day during the past 12 months), 5 health status measures of the HSQ, and the baseline indicator of any hospitalization or ED encounter | Odds Ratio | 1 (0.97; 1.1)
<14 bed days in past year
Boult, 1993^306^ | Longitudinal Study on Aging | 5,876 | Repeated admission | Adjusted for need variables, predisposing variables, and enabling variables | Odds Ratio | 1 (0.7; 1.4)
Fair vs. excellent
Aliyu, 2003^310^ | Longitudinal Study of Aging | 7,541 | Hospital stay/admission | Adjusted for race, education, family relationship family income, health insurance coverage, social network involvement, perceived health status and activities of daily living (ADL) | Odds Ratio | 2.99 (2.15; 4.15)
Laditka, 2003^308^ | | 3,562 | Hospitalization for Ambulatory Care Sensitive Conditions | Adjusted for age, education, insurance and marital status, health status, primary care access, self-rated health, comorbidities, physical impairments, and previous hospitalizations | Relative Risk | 1.14 (0.38; 1.9)
Wolinsky, 1995^309^ | | 2,538 | Natural log of the mean annual number of hospital episodes (plus one) | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | Odds Ratio in survivor with at least one hospital episode | 1.03 (p <0.01)
Wolinsky, 1995^309^ | | 1,783 | Natural log of the mean annual number of hospital episodes (plus one) | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | Odds Ratio in decedents with at least one hospital episode | 1.06 (p <0.01)
Boult, 1993^306^ | | 5,876 | Repeated admission | Adjusted for need variables, predisposing variables, and enabling variables | Odds Ratio | 1.7 (1.2; 2.6)
Good vs. excellent
Aliyu, 2003^310^ | Longitudinal Study of Aging | 7,541 | Hospital stay/admission | Adjusted for race, education, family relationship family income, health insurance coverage, social network involvement, perceived health status and activities of daily living (ADL) | Odds Ratio | 1.59 (1.15; 2.18)
Boult, 1993^306^ | Longitudinal Study on Aging | 5,876 | Repeated admission | Adjusted for need variables, predisposing variables, and enabling variables | Odds Ratio | 1.4 (1; 2)
Poor vs. excellent
Wolinsky, 1994^311^ | Longitudinal Study of Aging | 7,527 | Any Medicare-reimbursed hospital episode occurring | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | Odds Ratio | 2.14 (p = 0.015)
Aliyu, 2003^310^ | Longitudinal Study of Aging | 7,541 | Hospital stay/admission | Adjusted for race, education, family relationship family income, health insurance coverage, social network involvement, perceived health status and activities of daily living (ADL) | Odds Ratio | 2.79 (1.92; 4.05)
Laditka, 2003^308^ | Longitudinal Study of Aging | 3,562 | Hospitalization for Ambulatory Care Sensitive Conditions | Adjusted for age, education, insurance and marital status, health status, primary care access, self-rated health, comorbidities, physical impairments, and previous hospitalizations | Relative Risk | 1.47 (1.26; 1.68)
Wolinsky, 1995^309^ | Longitudinal Study of Aging | 2,538 | Natural log of the maximum absolute deviation (plus one) from the mean annual number of hospital episodes | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | Odds Ratio in survivor with at least one hospital episode | 1.07 (p <0.01)
Wolinsky, 1995^309^ | Longitudinal Study of Aging | 2,538 | Natural log of the mean annual number of hospital episodes (plus one) | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | Odds Ratio in survivor with at least one hospital episode | 1.05 (p <0.01)
Wolinsky, 1995^309^ | Longitudinal Study of Aging | 1,783 | Natural log of the mean annual number of hospital episodes (plus one) | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | Odds Ratio in decedents with at least one hospital episode | 1.72 (p>0.05)
Stearns, 1996^307^ | Longitudinal Study of Aging | 870 | Number of nights of hospitalization | Adjusted for cancer, heart disease, prior hospitalization, prior health, age square, ADL, ADL square, insurance, and interaction between age and functional status | Odds Ratio | 1.76 (p <0.05)
Boult, 1993^306^ | Longitudinal Study on Aging | 5,876 | Repeated admission | Adjusted for need variables, predisposing variables, and enabling variables | Odds Ratio | 2.2 (1.3; 3.6)

Bold=statistically significant.

Appendix E Table 29 Association Between Cognitive Impairment and Mortality in Older Persons 312

Reference | Study | Country | Sample Size | Age | Followup, Years | Measure | Cut Off | Risk (95% CI) | Type | Adjustment
Ostbye, 1999^313^ | Canadian Study of Health and Aging | Canada | 10,263 | 65+ | 2, 5 | 3MS | Women <50 vs. 78–100 | 3.5 (2.1; 6) | Odds Ratio | Age, marital status, education, ADL, vision, hearing
Ostbye, 1999^313^ | Canadian Study of Health and Aging | Canada | 10,263 | 65+ | 2, 5 | 3MS | 50–77 | 1.6 (1.3; 1.9) | Odds Ratio | Age, marital status, education, ADL, vision, hearing
Ostbye, 1999^313^ | Canadian Study of Health and Aging | Canada | 10,263 | 65+ | 2, 5 | 3MS | Men <50 vs. 78–100 | 3.8 (1.8; 7.8) | Odds Ratio | Age, marital status, education, ADL, vision, hearing
Ostbye, 1999^313^ | Canadian Study of Health and Aging | Canada | 10,263 | 65+ | 2, 5 | 3MS | 50–77 | 1.7 (1.4; 2.1) | Odds Ratio | Age, marital status, education, ADL, vision, hearing
Saz, 1999^314^ | Zaragoza study | Spain | 1,080 | 65+ | 4.5 | Automated Geriatric Examination for Computer Assisted Taxonomy organic syndrome level | 4 and 5 vs. 0 | 4.3 (1.7; 10.6) | Odds Ratio | Age, sex, education
Saz, 1999^314^ | Zaragoza study | Spain | 1,080 | 65+ | 4.5 | Organic syndrome level | Level 3 vs. 0 | 2 (1; 3.8)
Saz, 1999^314^ | Zaragoza study | Spain | 1,080 | 65+ | 4.5 | Automated Geriatric Examination for Computer Assisted Taxonomy organic syndrome level | level 1 and 2 vs. 0 | 1.3 (0.8; 2.1)
Jagger, 1995^315^ | Community based study, Melton Mowbray, Leicestershire | England | 1,579 | 75+ | 5 | CAPE information sub-scale | ≤7 vs. 12 | 4.18 (2.73; 6.41) | Hazard Ratio | Age sex
Jagger, 1995^315^ | Community based study, Melton Mowbray, Leicestershire | England | 1,579 | 75+ | 5 | CAPE information sub-scale | 8–9 vs. 12 | 2.36 (1.56; 3.58)
Jagger, 1995^315^ | Community based study, Melton Mowbray, Leicestershire | England | 1,579 | 75+ | 5 | CAPE information sub-scale | 10–11 vs. 12 | 1.45 (1.15; 1.84)
Clarke, 1996^286^ | | England | 1,042 | 65+ | 4, 8 | CAPE information sub-scale | ≤7 vs. 10–12 | 3.61 (2.31; 4.37) | Odds Ratio | Age sex
Clarke, 1996^286^ | | England | 1,042 | 65+ | 4, 8 | CAPE information sub-scale | 8–9 vs. 10–12 | 2.28 (1.86; 4.37)
Liu, 1998^316^ | | Taiwan | 2,915 | 65+ | 1, 2 | Composite score | Lowest decile | 1.67 (1.18; 2.35) | Hazard Ratio | Age sex education
Liu, 1998^316^ | | Taiwan | 2,915 | 65+ | 1, 2 | Composite score | 26–75 percentile | 1 (0.76; 1.32)
Foley, 1999^317^ | Honolulu Heart Program cohort study | United States | 3,741 | 71+ | 3 | Composite score | <74 | 2.26 (1.64; 3.1) | Odds Ratio | Age, BMI, marital status, sleep vars, health
Gale, 1996^318^ | | Great Britain | 983 | 65+ | 20 | Hodkinson | ≤7 v 10 | 2.2 (1.6;2.9) | Hazard Ratio | Age, sex
Ho, 1991^319^ | | Hong Kong | 1,054 | 70+ | 2 | Mental score | <16 v 20 | 2.2 (1.2; 4.1) | Odds Ratio | Ag, sex
Ho, 1991^319^ | | Hong Kong | 1,054 | 70+ | 2 | Mental score | 16–19 v 20+ | 1.4 (0.7; 2.5)
Eagles, 1990^320^ | | Scotland | 1778 | 65+ | 3 | Mental Status Questionnaire | ≤8 | 3.5 (2.37; 5.17) | Relative Risk | Age, sex
Shapiro, 1991^321^ | | Canada | 722 | 65+ | 17 | Mental Status Questionnaire | 0–6 | 1.95 (1.35; 2.83) | Hazard Ratio | Age, sex
Shapiro, 1991^321^ | | Canada | 722 | 65+ | 17 | Mental Status Questionnaire | 7.0–8.0 | 1.04 (0.78; 1.36)
Salive, 1993^322^ | EPESE | United States | 10,269 | 65+ | 6 | Mental Status Questionnaire | 1 error vs. 0 men | 1.4 (1.1; 1.8) | Hazard Ratio | Age, health, BMI, smoking, exercise, ADL
Liang, 1996^323^ | | Japan | 1,506 | 65+ | 3 | Mental Status Questionnaire | 3 + errors | 3.48(p<0.05) | Relative Risk
Gussekoo, 1997^324^ | Leiden 85-plus study | Netherlands | 891 | 85+ | 4, 7 | Mini Mental State Examination | 0–18 | 2.8 (2.3; 3.4) | Hazard Ratio | Age, sex
Gussekloo, 1997^324^ | Leiden 85-plus study | Netherlands | 891 | 85+ | 4, 7 | Mini Mental State Examination | 19–23 | 2.5 (2; 3.1)
Gussekloo, 1997^324^ | Leiden 85-plus study | Netherlands | 891 | 85+ | 4, 7 | Mini Mental State Exam | 24–27 | 1.8 (1.1; 3)
Kelman, 1994^47^ | | United States | 1,855 | 65+ | 1.5 | Mini Mental State Examination | <18 | 2.2 (1.13; 2.69) | Hazard Ratio | Age, sex, ADL, health, soc support, education, marital status, depression
Arve, 1998^325^ | | Finland | 1,032 | 70+ | 5 | Mini Mental State Examination | <24 | 1.43 (0.78; 2.65) | Relative Risk
Arve, 1998^325^ | | Finland | 1,032 | 70+ | 5 | Mini Mental State Examination | 11–25 percentile | 1.3 (0.95; 1.8)
Korten, 1999^326^ | | Australia | 897 | 70+ | 3.5 | Mini Mental State Examination | <24 vs. 30 | 1.88 (1.05; 3.12) | Hazard Ratio | Age, sex, ADL, health, soc support, education, marstat, depression
Fredman, 1999^327^ | | United States | 806 | 65+ | 6 | Mini Mental State Examination | <24 vs. 24 + | 2 (1.33; 3) | Hazard Ratio | Age, health, ADL, depression
Nakanishi, 1998^328^ | | Japan | 1,083 | 65+ | 3.5 | Office of Population Censuses (OPCS) score | 1.0–2.0 | 1.19 (0.81; 1.74) | Hazard Ratio | age, sex, health, anxiety, depression
Nakanishi, 1998^328^ | | Japan | 1,083 | 65+ | 3.5 | Office of Population Censuses (OPCS) score | 3.5–4.5 | 1.12 (0.65; 1.9)
Nakanishi, 1998^328^ | | Japan | 1,083 | 65+ | 3.5 | Office of Population Censuses (OPCS) score | 6 + | 1.74 (1.05; 2.88)
Swan, 1995^329^ | Western Collaborative Group Study | United States | 1,118 | 60+ | 5 | Wechsler Adult Intelligence Scale | | 1.44 (1.12; 1.86) | Hazard Ratio | Age, education

Appendix E Table 30 Association Between Cognitive Status and Mortality in Older Persons: Studies of Treatment Utilization (Health Care-Based Samples)

Reference | Study | Sample | Adjustment | Estimate | Mean (95% CI or P Value)
Alzheimer's disease
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) system | 811 | Adjusted for age | HR | 2.18 (1.57; 3.03)
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) system | 811 | Adjusted for age, insurance, and number of comorbidities | HR | 1.9 (1.36; 2.65)
Long, 2005^118^ | Medicaid program: applicants to home- and community-based care (HCBC) | 1,690 | Adjusted age, race, gender, health status, did not have hospital stay or SNF, LTCH, rehab hospital stay in prior 6 months, 0 to 3 MSQ errors, needs supervision never/sometimes/unknown, does not need assistance with mobility, does not need help with medication or meal preparation, does not have a mental illness, Alzheimer’s or dementia, does not have medications with potential side effects in elderly, lives with spouse/child/other/unknown, primary caregiver is other relative/non-relative/none/unknown, did not have Medicare home health use in prior 6 months, monthly income greater than $1000. | OR | 0.72 ( p >0.05)
Wolinsky, 1995^296^ | Longitudinal Study of Aging | 7,527 | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | OR | 1.48 (p = 0.05)
Cognitive impairment
Buuman, 2008^198^ | Patients 65 years or older acutely admitted from November 1, 2002, through July 1, 2005, to a 1,024-bed tertiary university teaching hospital | 463 | Crude | OR | 1.16 (0.73; 1.84)
Jones, 2004^153^ | MGAT study | 170 | Adjusted for age, sex, marriage status, and status of intervention | HR | 1.75 (1.08; 2.84)
Dementia
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) system | 811 | Adjusted for age | HR | 2.69 (1.94; 3.74)
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) system | 811 | Adjusted for age, insurance, and number of comorbidities | HR | 2.27 (1.62; 3.18)
Inouye, 2003^122^ | Prospective developmental cohort from Yale New Haven hospital | 525 | Adjusted for age, Medicaid status, nursing home resident, lab, dementia, walking impairment, depression, and UI | HR | 1.5 (1.1; 2.2)
Inouye, 2003^122^ | Prospective developmental cohort from Yale New Haven hospital | 525 | Adjusted for high risk diagnoses, albumin, creatinine, dementia, and walking impairment | HR | 1.9 (1.3; 2.7)
Inouye, 2003^122^ | Prospective validation cohort from Yale New Haven hospital | 1,246 | Adjusted for high risk diagnoses, albumin, creatinine, dementia, and walking impairment | HR | 2.2 (1.7; 2.7)
Mild cognitive impairment
Stump, 2001^69^ | General Medicine Practice of the Regenstrief Health Center | 3,861 | Adjusted for cognitive impairment, age, gender, race, education, and comorbid health conditions | HR | 0.93 (0.74; 1.16)
Moderate to severe cognitive impairment
Stump, 2001^69^ | General Medicine Practice of the Regenstrief Health Center | 3,861 | Adjusted for cognitive impairment, age, gender, race, education, and comorbid health conditions | HR | 1.7 (1.32; 2.19)

Bold=significant association at 95% confidence level.

Appendix E Table 31 Association Between Dementia and Mortality in Older Persons312

Reference | Study | Country | Sample Size | Age | Followup, Years | Diagnosis | Population | Risk (95% CI) | Risk Type | Adjustment
Jorm, 1991^331^ | | Australia | 274 | 70+ | 5 | DSMIII dementia | | 2.24 | Risk Ratio
Snowdon, 1995^337^ | Longitudinal study of elderly people in Botany | Australia | 211 | 65+ | 2, 4, 6, 8 | DSMIII dementia | | 2.71 | Risk Ratio
Hill, 1997^338^ | Canadian Study of Health and Aging | Canada | 10,263 | 65+ | 2, 5 | DSMIII | Men | 2.84 (p<0.05) | Odds Ratio | Age
Hill, 1997^338^ | Canadian Study of Health and Aging | Canada | 10,263 | 65+ | 2, 5 | DSMIII | Women | 2.67 (p<0.05)
Ostbye, 1999^313^ | Canadian Study of Health and Aging | Canada | 10,263 | 65+ | 2, 5 | Men | Mild | 0.9 (0.3; 3.5) | Odds Ratio | Age, marital status, education, ADL, vision, hearing
Ostbye, 1999^313^ | Canadian Study of Health and Aging | Canada | 10,263 | 65+ | 2, 5 | Men | Moderate | 2.1 (0.8; 5.6)
Ostbye, 1999^313^ | Canadian Study of Health and Aging | Canada | 10,263 | 65+ | 2, 5 | Men | Severe | 2.9(0.7; 11.7)
Ostbye, 1999^339^ | Canadian Study of Health and Aging | Canada | 10,263 | 65+ | 2, 5 | Men | Mild | 0.9 (0.3; 3.5) | Odds Ratio | Age, marital status, education, ADL, vision, hearing
Ostbye, 1999^313^ | Canadian Study of Health and Aging | Canada | 10,263 | 65+ | 2, 5 | Women | Mild | 1 (0.5; 2)
Ostbye, 1999^339^ | Canadian Study of Health and Aging | Canada | 1,0263 | 65+ | 2, 5 | Women | Mild | 1 (0.5; 2)
Ostbye, 1999^313^ | Canadian Study of Health and Aging | Canada | 10,263 | 65+ | 2, 5 | | Moderate | 1.4 (0.8; 2.6)
Ostbye, 1999^313^ | Canadian Study of Health and Aging | Canada | 10,263 | 65+ | 2, 5 | | Severe | 1.9 (0.9; 4.1)
Ostbye, 1999^339^ | Canadian Study of Health and Aging | Canada | 10,263 | 65+ | 2, 5 | | Moderate | 2.1 (0.8; 5.6)
Ostbye, 1999^339^ | Canadian Study of Health and Aging | Canada | 10,263 | 65+ | 2, 5 | | Severe | 2.9 (0.7; 11.7)
Ostbye, 1999^339^ | Canadian Study of Health and Aging | Canada | 10,263 | 65+ | 2, 5 | | Moderate | 1.4 (0.8; 2.6)
Ostbye, 1999^339^ | Canadian Study of Health and Aging | Canada | 10,263 | 65+ | 2, 5 | | Severe | 1.9 (0.9; 4.1)
Li, 1991^330^ | | China | 1,090 | 60+ | 3 | Dementia (clinical) | | 2.95 | SMR
Katzman, 1994^340^ | | China | 3,531 | 65+ | 2, 5 | DSMIIIR dementia | AD | 2.65 | Risk Ratio | Age, sex
Jagger, 1995^315^ | | England | 1,579 | 75+ | 5 | Cambridge Mental Disorders in the Elderly Examination | | 1.53 (1.08; 2.16) | Risk Ratio | Age, sex
Juva, 1994^341^ | | Finland | 656 | 75+ | 1 | DSMIII-R dementia | | 3.2 (1.8; 5.6) | Risk Ratio | Age, sex
Meller, 1999^342^ | | Germany | 358 | 85+ | 4.7 | Clinical | Men | 2.47 (1.35; 4.5) | Odds Ratio | Age
Meller, 1999^342^ | | Germany | 358 | 85+ | 4.7 | Clinical | Women | 1.98 (1.43; 2.75)
Meller, 1999^342^ | | Germany | 358 | 85+ | 4.7 | Clinical | Total | 2.08 (1.56; 2.77)
Bonaiuto, 1995^343^ | Appignano study | Italy | 778 | 60+ | 7 | DSMIII dementia | | 3.78 | Risk Ratio
Baldereschi, 1999^344^ | Italian Longitudinal Study on Aging | Italy | 4,521 | 65+ | 2 | DSMIIIR | | 3.56 (2.52; 5.04) | Hazard Ratio | Age, sex, health
Tsuji, 1995^345^ | Sendai Longitudinal Study of Aging | Japan | 3,549 | 65+ | 3 | DSMIII-R dementia | | 2.81 (2.02; 3.9) | Hazard Ratio | Age, sex
Asada, 1996^346^ | | Japan | 38 | 100+ | 0.5 | DSMIII-R dementia | | No death occurred in non demented, risk difference 0.27 | Risk Ratio
Heeren, 1992^334^ | Leiden 85-plus study | Netherlands | 891 | 85+ | 4, 7 | DSMIII dementia | | 1.9 (1.7; 2.2) | Hazard Ratio | Age, sex
Engedal, 1996^347^ | Oslo study | Norway | 334 | 75+ | 3 | DSMIII dementia | | 2.01 | Risk Ratio
Saz, 1999^314^ | Zaragoza study | Spain | 1,080 | 65+ | 4.5 | Automated Geriatric Examination for Computer Assisted Taxonomy | | 3.7 (2; 6.7) | Odds Ratio | Age, sex, education
Aevarsson, 1998^336^ | Longitudinal Gerontological and Geriatric Population Studies in Gothenburg, Sweden | Sweden | 494 | 85 | 3, 7 | Alzheimer’s Disease | Men | 2.6 (1.5; 4.7) | Hazard Ratio | Health
Aevarsson, 1998^336^ | Longitudinal Gerontological and Geriatric Population Studies in Gothenburg, Sweden | Sweden | 494 | 85 | 3, 7 | Alzheimer’s Disease | Women | 2.9 (1.9; 4.3)
Aguero-Torres, 1998^348^ | Kungsholmen Project | Sweden | 989 | 75+ | 5 | DSMIII-R | | 2.7 (2.1; 3.4) | Risk Ratio | Age and sex
Skoog, 1993^335^ | Longitudinal Gerontological and Geriatric Population Studies in Gothenburg, Sweden | Sweden | 494 | 85 | 3, 7 | DSMIII-R dementia | | 2.39 | Risk Ratio
Johansson, 1995^349^ | OCTO study | Sweden | 324 | 84+ | 2, 4 | DSMIII-R dementia | | 2.86 (1.72; 4.75) | Risk Ratio | Age, sex
Aguero-Torres, 1998^348^ | Kungsholmen Project | Sweden | 989 | 75+ | 5 | Men | 77–84 | 3.6 (1.4; 9.1)
Aevarsson, 1998^336^ | Longitudinal Gerontological and Geriatric Population Studies in Gothenburg, Sweden | Sweden | 494 | 85 | 3, 7 | Vascular | Men | 2.9 (1.4; 6.2)
Aevarsson, 1998^336^ | Longitudinal Gerontological and Geriatric Population Studies in Gothenburg, Sweden | Sweden | 494 | 85 | 3, 7 | Vascular | Women | 3.6 (2.3; 5.9)
Aguero-Torres, 1998^348^ | Kungsholmen Project | Sweden | 989 | 75+ | 5 | Women | 77–84 | 4.5 (2.2; 8.9)
Aguero-Torres, 1998^348^ | Kungsholmen Project | Sweden | 989 | 75+ | 5 | Women | 85+ | 1.7 (0.8; 3.5)
Aguero-Torres, 1998^348^ | Kungsholmen Project | Sweden | 989 | 75+ | 5 | Women | 85+ | 2.4 (1.8; 3.2)
Liu, 1998^316^ | | Taiwan | 2,915 | 65+ | 1, 2 | Consortium to Establish a Registry of Alzheimer's Disease | | 2.7 (2.1; 3.4) | Risk Ratio
Gurland, 1999^350^ | North Manhattan Aging Project | United States | 2,162 | 65+ | 1.5 | African-American | 65–74 | 2.94
Gurland, 1999^350^ | North Manhattan Aging Project | United States | 2,162 | 65+ | 1.5 | Algorithmic | Latino 65–74 | 4.77 | Odds Ratio
Albert, 1999^351^ | Washington Heights-Inwood Columbia Aging Project (WHICAP) | United States | 2,334 | 65+ | 1.8 | Alzheimer's | | 2.57 | Risk Ratio
Aronson, 1991^332^ | Bronx Aging Study | United States | 488 | 75+ | 8 | DSMIII dementia | | 3 (2.1; 3.1) | Risk Ratio
Evans, 1991^333^ | | United States | 3,623 | 65+ | 4.9 | National Institute of Neurological and Communicative Disorders and Stroke and the – Alzheimer’s Disease and Related Disorders Association | Alzheimer’s | 1.4 (1.05; 1.96) | Hazard Ratio | Age, sex
Gurland, 1999^350^ | North Manhattan Aging Project | United States | 2,162 | 65+ | 1.5 | Non-Latino white | 65–74 | 6.7
Gurland, 1999^350^ | North Manhattan Aging Project | United States | 2,162 | 65+ | 1.5 | Non-Latino white | 75–84 | 1.91
Gurland, 1999^350^ | North Manhattan Aging Project | United States | 2,162 | 65+ | 1.5 | Non-Latino white | 85+ | 0.77
Gurland, 1999^350^ | North Manhattan Aging Project | United States | 2,162 | 65+ | 1.5 | Non-Latino white | 75–84 | 1.23
Gurland, 1999^350^ | North Manhattan Aging Project | United States | 2,162 | 65+ | 1.5 | Non-Latino white | 85+ | 2.83
Gurland, 1999^350^ | North Manhattan Aging Project | United States | 2,162 | 65+ | 1.5 | Non-Latino white | 75–84 | 1.44
Gurland, 1999^350^ | North Manhattan Aging Project | United States | 2,162 | 65+ | 1.5 | Non-Latino white | 85+ | 11

Appendix E Table 32 Institutionalization in Older Persons With Cognitive Impairment

Reference | Study | Country | Sample | Adjustment | Estimate | Mean (95% CI or P Value)
Alzheimer’s disease
Long, 2005^118^ | Medicaid program: applicants to the home- and community-based care (HCBC) | USA | 1,690 | Adjusted for receiving HCBC services, age, race, gender, health status, did not have hospital stay or SNF, LTCH, rehab hospital stay in prior 6 months, 0 to 3 MSQ errors, ADL and IADL, lives with spouse/child/other/unknown, primary caregiver is other relative/non-relative/none/unknown, did not have Medicare home health use in prior 6 months, monthly income greater than $1,000. | Odds Ratio | 1.72 (p <0.05)
Rockwood, 1996^147^ | Canadian Study of Health and Aging | Canada | 9,113 | Adjusted for age, gender, race, married status, absence of a caregiver, non-spouse caregiver, IADL-dependence in finances, dependence in shopping, ADL-dependence in dressing, dependence in feeding, bladder incontinence, bowel incontinence, cardiovascular disease, hypertension, diabetes mellitus, stroke, Parkinson’s disease, hearing impairment, visual impairment, age-associated memory impairment (AAMI), Alzheimer’s disease, vascular dementia, and other dementia | Odds Ratio | 14.60 (12.10; 17.60)
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) system | USA | 811 | Adjusted for age | Hazard Ratio | 5.84 (3.96; 8.61)
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) system | USA | 811
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) system | USA | 811 | Adjusted for age, insurance, and stroke | Hazard Ratio | 5.44 (3.68; 8.05)
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) system | USA | 811
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) system | USA | 811 | Adjusted for age, insurance, stroke, and number of comorbidity | Hazard Ratio | 3.01 (2.35; 3.87)
Dementia
Goodlin, 2004^298^ | Secondary analysis of data from the Medicare Current Beneficiary Survey | USA | 3232 | adjusted for socio-demographic characteristics, health status, functional ability, previous use of health services, insurance, income, and family composition | Odds Ratio | 34.87 (p <0.001)
Rockwood, 1996^147^ | Canadian Study of Health and Aging | Canada | 9,113 | Adjusted for age, gender, race, married status, absence of a caregiver, non-spouse caregiver, IADL-dependence in finances, dependence in shopping, ADL-dependence in dressing, dependence in feeding, bladder incontinence, bowel incontinence, cardiovascular disease, hypertension, diabetes mellitus, stroke, Parkinson’s disease, hearing impairment, visual impairment, age-associated memory impairment (AAMI), Alzheimer’s disease, vascular dementia, and other dementia | Odds Ratio | 36.30 (27.10; 48.70)
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) system | USA | 811 | Adjusted for age | Hazard Ratio | 5.91 (3.97; 8.80)
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) system | USA | 811
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) system | USA | 811 | Adjusted for age, insurance, and stroke | Hazard Ratio | 5.08 (3.38; 7.63)
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) system | USA | 811
Eaker, 2002^83^ | Marshfield Epidemiologic Study Area (MESA) system | USA | 811 | Adjusted for age, insurance, stroke, and number of comorbidity | Hazard Ratio | 3.10 (2.39; 4.03)
Vascular dementia
Rockwood, 1996^147^ | Canadian Study of Health and Aging | Canada | 9,113 | Adjusted for age, gender, race, married status, absence of a caregiver, non-spouse caregiver, IADL-dependence in finances, dependence in shopping, ADL-dependence in dressing, dependence in feeding, bladder incontinence, bowel incontinence, cardiovascular disease, hypertension, diabetes mellitus, stroke, Parkinson’s disease, hearing impairment, visual impairment, age-associated memory impairment (AAMI), Alzheimer’s disease, vascular dementia, and other dementia | Odds Ratio | 13.80 (10.20; 18.70)
Confusion, sometimes
Speare, 1991^303^ | Longitudinal Study of Aging | USA | 5,151 | Adjusted for disability, incontinence, blindness, deafness, limitation in major activities, social support, age, sex, income | Odds Ratio | 1.08 (0.82; 1.43)
Confusion, frequently
Speare, 1991^303^ | Longitudinal Study of Aging | USA | 5,151 | Adjusted for disability, incontinence, blindness, deafness, limitation in major activities, social support, age, sex, income | Odds Ratio | 1.39 (1.03; 1.87)
Confusion, African Americans
Belgrave, 1994^305^ | Longitudinal Study of Aging | USA | 560 | Adjusted for ADL, IADL, self-health, activity limitations, confused, age, sex, living alone, education, income, and Medicaid | Odds Ratio | 1.45 (0.71; 2.93)
Confusion, Caucasians
Belgrave, 1994^305^ | Longitudinal Study of Aging | USA | 6,880 | Adjusted for ADL, IADL, self-health, activity limitations, confused, age, sex, living alone, education, income, and Medicaid | Odds Ratio | 1.21 (0.99; 1.47)
Cognitive impairment, Short Portable Mental Status Questionnaire (MSQ)
Long, 2005^118^ | Applicants to the home- and community-based care (HCBC) programs | USA | 1,690 | Adjusted for receiving HCBC services, age, race, gender, health status, did not have hospital stay or SNF, LTCH, rehab hospital stay in prior 6 months, 0 to 3 MSQ errors, ADL and IADL, lives with spouse/child/other/unknown, primary caregiver is other relative/non-relative/none/unknown, did not have Medicare home health use in prior 6 months, monthly income greater than $1,000. | Odds Ratio | 1.32 (>0.05)
Cognitive impairment, MMSE
Rockwood, 1996^147^ | Canadian Study of Health and Aging | Canada | 9,113 | Adjusted for age, gender, race, married status, absence of a caregiver, non-spouse caregiver, IADL-dependence in finances, dependence in shopping, ADL-dependence in dressing, dependence in feeding, bladder incontinence, bowel incontinence, cardiovascular disease, hypertension, diabetes mellitus, stroke, Parkinson’s disease, hearing impairment, visual impairment, age-associated memory impairment (AAMI), Alzheimer’s disease, vascular dementia, and other dementia | Odds Ratio | 29.10 (25.10; 33.80)
Cognitive impairment, increase in MMSE
St John, 2002^150^ | Canadian Study of Health and Aging | Canada | 8,073 | Adjusted for age, gender, education, Time 1 MMSE, and self-rated health | Odds Ratio | 0.91 (0.90; 0.94)
Cognitive impairment, normal MMSE vs. <23
St John, 2002^150^ | Canadian Study of Health and Aging | Canada | 6,934 | Adjusted for age, gender, education, Time 1 MMSE, and self-rated health | Odds Ratio | 0.88 (0.83; 0.93)
Age-associated memory impairment
Rockwood, 1996^147^ | Canadian Study of Health and Aging | Canada | 9,113 | Adjusted for age, gender, race, married status, absence of a caregiver, non-spouse caregiver, IADL-dependence in finances, dependence in shopping, ADL-dependence in dressing, dependence in feeding, bladder incontinence, bowel incontinence, cardiovascular disease, hypertension, diabetes mellitus, stroke, Parkinson’s disease, hearing impairment, visual impairment, age-associated memory impairment (AAMI), Alzheimer’s disease, vascular dementia, and other dementia | Odds Ratio | 17.50 (14.00; 22.00)
Mild/moderate cognitive impairment
Banaszak-Holl, 2004^352^ | Asset and Health Dynamics Among the Oldest Old (AHEAD) Study | USA | 6,676 | Adjusted for socio-demographic measures, potential caregiver network, geographic region, medical conditions, and ADL and IADL impairments | Hazard Ratio | 2.30 (1.80; 2.80)
Severe cognitive impairment
Banaszak-Holl, 2004^352^ | Asset and Health Dynamics Among the Oldest Old (AHEAD) Study | USA | 6,676 | Adjusted for socio-demographic measures, potential caregiver network, geographic region, medical conditions, and ADL and IADL impairments | Hazard Ratio | 1.80 (1.50; 2.20)

Bold=statistically significant.

Appendix E Table 33 Association Between Hospitalization and Cognitive Impairment in Older Persons

Reference | Study | Sample | Adjustment | Estimate | Mean (95% CI)
Alzheimer’s disease
Weiner, 1998^131^ | Practices providing services to Medicare beneficiaries in the U.S. | 1,221,615 | Crude | Ratio of Per Capita Expenditures of Medicare Beneficiaries | 2.2
Laditka, 2003^308^ | Longitudinal Study of Aging | 3,562 | Adjusted for age, education, insurance and marital status, health status, primary care access, self-rated health, comorbidities, physical impairments, and previous hospitalizations | Relative Risk | 1.19 (0.91; 1.46)
Cognitive impairment, frequent or increasing trouble remembering things or getting confused
Boult, 1993^306^ | Longitudinal Study on Aging | 5,876 | Adjusted for need variables, predisposing variables, and enabling variables | Odds Ratio | 0.9 (0.8; 1.2)
Decline in SPMSQ in 1991 (>2 points) vs. no for age >75
Chodosh, 2004^20^ | MacArthur Research Network on Successful Aging Community Study | 598 | Adjusted for age, sex, race/ethnicity, and prior hospitalization | Odds Ratio | 7.8 (2; 30.8)

Bold=statistically significant.

Appendix E Table 34 Prevalence of Frailty in Older Persons With Cognitive Impairment, Comorbidity, and Disability, According to Definition of Frailty

Reference | Study | Sample Size | Prevalence Subgroups | Mean (95% CI)
Cognitive Impairment
Accumulation deficit, functional domains model
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | Cognitive impairment, mild | 82.8 (81.0; 84.6)
Accumulation deficit, burden model
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | Cognitive impairment, mild | 48.5 (46.1; 50.9)
Phenotype model
Fried, 2001^55^ | Cardiovascular Health Study | 5,317 | Cognitive function: MMSE >23 84.9 | 6.3 (5.7; 7.0)
Fried, 2001^55^ | Cardiovascular Health Study | | Cognitive function: MMSE 18 – 23 | 16.6 (15.6; 17.60)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | Cognitive impairment, mild | 30.2 (28.1; 32.5)
Comorbidity
Accumulation deficit, functional domain model
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >3 chronic diseases | 33.9 (31.6; 36.20)
Accumulation deficit, burden model
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >3 chronic diseases | 41.7 (39.3; 44.01)
Phenotype model
Fried, 2001^55^ | Cardiovascular Health Study | 5,317 | Number of chronic diseases: 0 | 2.7 (2.3; 3.2)
Fried, 2001^55^ | Cardiovascular Health Study | 5,317 | Number of chronic diseases: 1 | 5.1 (4.6; 5.80)
Fried, 2001^55^ | Cardiovascular Health Study | 5,317 | Number of chronic diseases: 2 | 7.3 (6.6; 8.0)
Fried, 2001^55^ | Cardiovascular Health Study | 5,317 | Two or more comorbidities | 9.7 (8.9; 10.5)
Fried, 2001^55^ | Cardiovascular Health Study | 5,317 | Number of chronic diseases: 3–4 | 11.5 910.7; 12.4)
Fried, 2001^55^ | Cardiovascular Health Study | 5,317 | Number of chronic diseases: ≥5 | 19.6 (18.5; 20.7)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >3 chronic diseases | 24.3 (22.3; 26.4)
Phenotype model, women
Ensrud, 2008^50^ | Study of osteoporotic fractures | 6,701 | No medical conditions | 10.7 (10.0; 11.5)
Ensrud, 2008^50^ | Study of osteoporotic fractures | 6,701 | ≥3 medical conditions | 39.0 (37.8; 40.2)
Ensrud, 2008^50^ | Study of osteoporotic fractures | 6,701 | 1–2 medical conditions | 17.8 (16.9; 18.7)
Disability
Phenotype model, women
Ensrud, 2008^50^ | Study of osteoporotic fractures | 6,701 | ≥1 new IADL impairment | 6.6 (6.0; 7.2)
Phenotype model, men
Cawthon, 2007^28^ | Osteoporotic Fractures in Men (MrOS) Study | 5,993 | Unable to complete chair stands | 35.2 (34.0; 36.4)
Cawthon, 2007^28^ | Osteoporotic Fractures in Men (MrOS) Study | 5,993 | Unable to complete narrow walk | 19.0 (18.0; 20.0)
Cawthon, 2007^28^ | Osteoporotic Fractures in Men (MrOS) Study | 5,993 | At least one IADL limitation | 15.2 (14.3; 16.1)
Cawthon, 2007^28^ | Osteoporotic Fractures in Men (MrOS) Study | 5,993 | At least one mobility limitation | 16.1 (15.2; 17.1)
Accumulation deficit model, functional domains model, both genders
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >1 ADL dependency | 67.9 (65.6; 70.1)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >2 ADL dependencies | 60.2 (57.8; 62.5)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >3 ADL dependencies | 53.3 (50.9; 55.7)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >1 IADL dependency | 57.6 (55.2; 59.9)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >2 IADL dependencies | 77.5 (75.4; 79.4)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >3 IADL dependencies | 100.0 (99.5; 100.0)
Accumulation deficit model, burden model, both genders
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >1 ADL dependency | 78.9 (76.8; 80.8)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >2 ADL dependencies | 92.2 (90.8; 93.4)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >3 ADL dependencies | 91.2 (89.7; 92.5)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >1 IADL dependency | 62.7 (60.4; 65.0)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >2 IADL dependencies | 75.3 (73.1; 77.3)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >3 IADL dependencies | 82.8 (80.9; 84.5)
Gutman, 2001^143^ | Canadian Study of Health and Aging - 1 | 5,987 | Trouble rating: not at all | 10.2 (9.5; 11.0)
Gutman, 2001^143^ | Canadian Study of Health and Aging - 1 | 5,987 | Trouble rating: a little | 20.6 (19.6; 21.6)
Gutman, 2001^143^ | Canadian Study of Health and Aging - 1 | 5,987 | Trouble rating: a great deal | 51.0 (49.7; 52.3)
Phenotype model, both genders
Fried, 2001^55^ | Cardiovascular Health Study | 5,317 | ≥1 mobility task | 17.3 (16.3; 18.3)
Fried, 2001^55^ | Cardiovascular Health Study | 5,317 | ≥1 IADL task | 17.4 (16.4; 18.4)
Fried, 2001^55^ | Cardiovascular Health Study | 5,317 | ≥1 ADL task | 27.9 (26.7; 29.1)
Fried, 2001^55^ | Cardiovascular Health Study | 5,317 | Any disability | 14.4 (13.5; 15.3)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >1 ADL dependency | 56.7 (54.3; 59.1)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >2 ADL dependencies | 64.8 (62.5; 67.1)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >3 ADL dependencies | 55.3 (52.9; 57.7)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >1 IADL dependency | 43.4 (41.0; 45.8)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >2 IADL dependencies | 52.5 (50.1; 54.9)
Cigolle, 2009^72^ | The Health and Retirement Study | 1,657 | >3 IADL dependencies | 92.9 (91.6; 94.1)

Appendix E Table 35 Association Between Frailty and Mortality in Older Persons According to Definition of Frailty and Study Adjustment

Reference | Study | Age | Sample | Adjustment | Estimate | Mean | Lower 95%CI | Upper 95%CI
Frailty
Passarino, 2007^183^ | European Challenge for Healthy Aging | 65–85 | 209 | Crude | OR^*^ | 3.11
Dukers, 2001^353^ | Cardiovascular Health Study | >65 | 5,317 | Adjusted for age, gender, race, income, smoking, blood pressure, glucose, albumin, creatinine, carotid stenosis, CHF, cognitive function, major EKG abnormality, use of diuretics, problems of IADL, self-reported health measure, CES-D modified depression measure | HR | 2.24 | 1.51 | 3.33
Intermediate frailty
Passarino, 2007^183^ | European Challenge for Healthy Aging | 65–85 | 209 | Crude | OR^*^ | 1.5
Dukers, 2001^353^ | Cardiovascular Health Study | >65 | 5,317 | Adjusted for age, gender, race, income, smoking, blood pressure, glucose, albumin, creatinine, carotid stenosis, CHF, cognitive function, major EKG abnormality, use of diuretics, problems of IADL, self-reported health measure, CES-D modified depression measure | HR | 1.49 | 1.11 | 1.99
Very frail
Passarino, 2007^183^ | European Challenge for Healthy Aging | >90 | 117 | Crude | OR^*^ | 1.9375 | p value 0.128
Prefrail without cognitive impairment
Avila-Funes, 2009^169^ | Three-City Study | >65 | 5,423 | Adjusted for sex; education level; income; smoking status; drinker status; number of chronic diseases; self-reported health; Center for Epidemiologic Studies Depression Scale score (excluding the two questions used for the frailty definition); and mobility, instrumental activity of daily living, and activity of daily living disability at baseline | OR | 1.27 | 0.95 | 1.7
Prefrail with cognitive impairment
| | >65 | 5,423 | | OR | 1.59 | 0.98 | 2.57
Frail without cognitive impairment
| | >65 | 5,423 | | OR | 1.26 | 0.76 | 2.11
Frail with cognitive impairment
| | >65 | 5,423 | | OR | 1.91 | 1 | 3.68
Outcome: mortality, utilization, and institutionalization
FI-GGA
15507074 | The MGAT study | NA | 169 | Adjusted for age, sex, marriage status, and status of intervention | HR | 1.23 | 1.01 | 1.45
Outcome: Repeat outpatient ED visit, hospital admission, nursing home admission, or death, within 30 days of the index ED visit
Hastings, 2008^354^ | Medicare Current Beneficiary Survey | ≥65 | 1,581 | Adjusted for age, sex, race, income, living alone, insurance status, previous emergency department (ED) visits, previous hospitalizations. | HR DAI 2 VS. 1 | 1.2 | 0.91 | 1.6
Hastings, 2008^354^ | Medicare Current Beneficiary Survey | ≥65 | 1,581 | Adjusted for age, sex, race, income, living alone, insurance status, previous emergency department (ED) visits, previous hospitalizations. | HR DAI 3 vs. 1 | 1.33 | 1.02 | 1.77
Hastings, 2008^354^ | Medicare Current Beneficiary Survey | ≥65 | 1,581 | Adjusted for age, sex, race, income, living alone, insurance status, previous emergency department (ED) visits, previous hospitalizations. | HR DAI 4 vs. 1 | 1.44 | 1.06 | 1.96
Outcome: Hospital admission, nursing home admission, or death, within 30 days of the index ED visit
Hastings, 2008^354^ | Medicare Current Beneficiary Survey | ≥65 | 1,581 | Adjusted for age, sex, race, income, living alone, insurance status, previous emergency department (ED) visits, previous hospitalizations. | HR DAI 2 vs. 1 | 1.45 | 0.98 | 2.16
Hastings, 2008^354^ | Medicare Current Beneficiary Survey | ≥65 | 1,581 | Adjusted for age, sex, race, income, living alone, insurance status, previous emergency department (ED) visits, previous hospitalizations. | HR DAI 3 vs. 1 | 1.55 | 1.04 | 2.33
Hastings, 2008^354^ | Medicare Current Beneficiary Survey | ≥65 | 1,581 | Adjusted for age, sex, race, income, living alone, insurance status, previous emergency department (ED) visits, previous hospitalizations. | HR DAI 4 VS. 1 | 1.98 | 1.29 | 3.05

* OR is calculated from 2×2 table.

Appendix E Figure 3 Association Between Mortality and Frailty Definition in Older Men28,51,156,194

Appendix E Figure 4 Dose Response Association Between Accumulation Deficit Frailty Index and Mortality in Older Men: Chinese Longitudinal Health Longevity Survey156

Appendix E Figure 5 Association Between Mortality and Frailty Definition in Older Women99,156,194

Appendix E Figure 6 Dose Response Association Between Accumulation Deficit Frailty Index and Mortality in Older Women: Chinese Longitudinal Health Longevity Survey156

Appendix E Table 36 Association Between Frailty and Institutionalization in Older Persons

Reference | Study | Country | Sample | Adjustment | Estimate | Mean (95% CI)
Intermediate frailty vs. nonfrail
Bandeen-Roche, 2006^99^ | Women’s Health and Aging Studies (WHAS) | USA | 750 | Adjusted for age, race, grades completed, smoking, history of congestive heart failure, Mini-Mental State Examination score, Geriatric Depression Scale score (≥14), number of adjudicated diseases, ankle-arm blood pressure, use of diuretics | Hazard Ratio | 5.16 (0.81; 32.79)
Frailty
Bandeen-Roche, 2006^99^ | Women’s Health and Aging Studies (WHAS) | USA | 750 | Adjusted for age, race, grades completed, smoking, history of congestive heart failure, Mini-Mental State Examination score, Geriatric Depression Scale score (≥14), number of adjudicated diseases, ankle-arm blood pressure, use of diuretics | Hazard Ratio | 23.98 (4.45; 129.2)
Frailty- GGA
Jones, 2005^144^ | Canadian Study of Health and Aging | Canada | 2,305 | Adjusted for age, sex, and education | Hazard Ratio | 1.2 (1.1; 1.32)
Components of frailty
Slow gait speed
Rothman, 2008^44^ | Precipitating Events Project (PEP) | USA | 754 | Adjusted for age, sex, race, education, chronic conditions, and the presence of the other six frailty criteria | Hazard Ratio | 3.9 (2.2; 6.7)
Low physical activity
Rothman, 2008^44^ | Precipitating Events Project (PEP) | USA | 754 | Adjusted for age, sex, race, education, chronic conditions, and the presence of the other six frailty criteria | Hazard Ratio | 2.1 (1.3; 3.3)
Weight loss
Rothman, 2008^44^ | Precipitating Events Project (PEP) | USA | 754 | Adjusted for age, sex, race, education, chronic conditions, and the presence of the other six frailty criteria | Hazard Ratio | 1.7 (1.2; 2.4)
Self-reported exhaustion
Rothman, 2008^44^ | Precipitating Events Project (PEP) | USA | 754 | Adjusted for age, sex, race, education, chronic conditions, and the presence of the other six frailty criteria | Hazard Ratio | 1.1 (0.8; 1.7)
Weakness
Rothman, 2008 Rothman, 2008 #2899} | Precipitating Events Project (PEP) | USA | 754 | Adjusted for age, sex, race, education, chronic conditions, and the presence of the other six frailty criteria | Hazard Ratio | 1 (0.6; 1.6)
Cognitive impairment
Rothman, 2008^44^ | Precipitating Events Project (PEP) | USA | 754 | Adjusted for age, sex, race, education, chronic conditions, and the presence of the other six frailty criteria | Hazard Ratio | 2.6 (1.7; 4)
Depressive symptoms
Rothman, 2008^44^ | Precipitating Events Project (PEP) | USA | 754 | Adjusted for age, sex, race, education, chronic conditions, and the presence of the other six frailty criteria | Hazard Ratio | 1.4 (1; 2.1)

Bold=statistically significant.

Appendix E Table 37 Association Between Frailty and Hospitalization in Older Persons

Reference | Study | Sample | Adjustment | Estimate | Mean (95% CI)
Intermediate frailty
Bandeen-Roche, 2006^99^ | Women’s Health and Aging Studies (WHAS) | 715 | Adjusted for baseline age, race, grades completed, smoking (pack-years), disease- related variables—history of congestive heart failure, Mini-Mental State Examination score, Geriatric Depression Scale score (≥14), number of adjudicated diseases, ankle-arm blood pressure, use of diuretics without history of hypertension or congestive heart failure | Hazard Ratio | 0.99 (0.67; 1.47)
Avila-Funes, 2008^171^ | Three-City Study | 6,078 | Adjusted by age, sex, education level, income, smoking status, alcohol use, number of chronic diseases, self-reported health, Center for Epidemiologic Studies-Depression scale score, Mini-Mental State Examination score, and baseline disability | Odds Ratio | 1.14 (0.98; 1.31)
Avila-Funes, 2008^169^ | Three-City Study | 5,152 | Adjusted for age; sex; education level; income; smoking status; drinker status; number of chronic diseases; self-reported health; Center for Epidemiologic Studies Depression Scale score (excluding the two questions used for the frailty definition); and mobility, instrumental activity of daily living, and activity of daily living disability at baseline | Odds Ratio | 1.15 (0.99; 1.32)
Dukers, 2001^353^ | Cardiovascular Health Study | 5,317 | Adjusted for age, gender, indicator for minority cohort, income, smoking, blood pressure, glucose, albumin, creatinine, carotid stenosis, history of CHF, cognitive function, major EKG abnormality, use of diuretics, problems of IADL, self-reported health measure, CES-D modified depression measure | Hazard Ratio | 1.13 (1.03; 1.25)
Dukers, 2001^353^ | Cardiovascular Health Study | 5,317 | | Hazard Ratio, original cohort | 1.11 (1.03; 1.19)
Prefrail
Kiely, 2009^26^ | MOBILIZE Boston Study | 765 | Adjusted for age, gender, race, diabetes, stroke, hypertension, hyperlipidemia, education and income | Odds Ratio for accumulation deficit index | 2.64 (1.74; 4.01)
Kiely, 2009^26^ | MOBILIZE Boston Study | 765 | Adjusted for age, gender, race, diabetes, stroke, hypertension, hyperlipidemia, education and income | Odds Ratio for phenotype index | 1.97 (1.37; 2.84)
Avila-Funes, 2009^169^ | Three-City Study | 5,152 | Adjusted for age; sex; education level; income; smoking status; drinker status; number of chronic diseases; self-reported health; Center for Epidemiologic Studies Depression Scale score (excluding the two questions used for the frailty definition); and mobility, instrumental activity of daily living, and activity of daily living disability at baseline | Odds Ratio | 1.19 (1.03; 1.39)
Prefrail + cognitive impairment
Avila-Funes, 2009^169^ | Three-City Study | 5,152 | Adjusted for age; sex; education level; income; smoking status; drinker status; number of chronic diseases; self-reported health; Center for Epidemiologic Studies Depression Scale score (excluding the two questions used for the frailty definition); and mobility, instrumental activity of daily living, and activity of daily living disability at baseline | Odds Ratio | 0.95 (0.68; 1.31)
Frailty
Bandeen-Roche, 2006^99^ | Women’s Health and Aging Studies (WHAS) | 715 | Adjusted for baseline age, race, grades completed, smoking (pack-years), disease- related variables—history of congestive heart failure, Mini-Mental State Examination score, Geriatric Depression Scale score (≥14), number of adjudicated diseases, ankle-arm blood pressure, use of diuretics without history of hypertension or congestive heart failure | Hazard Ratio | 0.67 (0.33; 1.35)
Avila-Funes, 2008^171^ | Three-City Study | 6,078 | Adjusted by age, sex, education level, income, smoking status, alcohol use, number of chronic diseases, self-reported health, Center for Epidemiologic Studies-Depression scale score, Mini-Mental State Examination score, and baseline disability | Odds Ratio | 1.36 (1.01; 1.81)
Avila-Funes, 2009^169^ | Three-City Study | 5,152 | Adjusted for age; sex; education level; income; smoking status; drinker status; number of chronic diseases; self-reported health; Center for Epidemiologic Studies Depression Scale score (excluding the two questions used for the frailty definition); and mobility, instrumental activity of daily living, and activity of daily living disability at baseline | Odds Ratio | 1.41 (1.06; 1.87)
Kiely, 2009^26^ | MOBILIZE Boston Study | 765 | Adjusted for age, gender, race, diabetes, stroke, hypertension, hyperlipidemia, education and income | Odds Ratio for accumulation deficit index | 3.49 (1.53; 7.98)
Kiely, 2009^26^ | MOBILIZE Boston Study | 765 | Adjusted for age, gender, race, diabetes, stroke, hypertension, hyperlipidemia, education and income | Odds Ratio for phenotype | 4.45 (2.42; 8.18)
Dukers, 2001^353^ | Cardiovascular Health Study | 5,317 | Adjusted for age, gender, indicator for minority cohort, income, smoking, blood pressure, glucose, albumin, creatinine, carotid stenosis, history of CHF, cognitive function, major EKG abnormality, use of diuretics, problems of IADL, self-reported health measure, CES-D modified depression measure | Hazard Ratio | 1.29 (1.09; 11.54)
Dukers, 2001^353^ | Cardiovascular Health Study | 5,317 | | Hazard Ratio, original cohort | 1.27 (1.11; 1.46)
Avila-Funes, 2009^169^ | Three-City Study | 5,152 | Adjusted for age; sex; education level; income; smoking status; drinker status; number of chronic diseases; self-reported health; Center for Epidemiologic Studies Depression Scale score (excluding the two questions used for the frailty definition); and mobility, instrumental activity of daily living, and activity of daily living disability at baseline | Odds Ratio | 1.26 (0.91; 1.74)
Frailty +cognitive impairment
Avila-Funes, 2009^169^ | Three-City Study | 5,152 | Adjusted for age; sex; education level; income; smoking status; drinker status; number of chronic diseases; self-reported health; Center for Epidemiologic Studies Depression Scale score (excluding the two questions used for the frailty definition); and mobility, instrumental activity of daily living, and activity of daily living disability at baseline | Odds Ratio | 1.9 (1.09; 3.31)

Appendix E Table 38 Association Between Health Care Utilization and Frailty in Older Persons

Reference | Study | Sample | Definition of the Outcome | Definition of Exposure | Adjustment | Estimate | Mean (95% CI)
Hastings, 2008^354^ | Secondary analysis of data from the Medicare Current Beneficiary Survey | 1,581 | Repeat outpatient ED visit | DAI 2 vs. 1 | Adjusted for age, sex, race, income, living alone, insurance status, previous emergency department (ED) visits, and previous hospitalizations. | Hazard Ratio | 0.93 (0.62; 1.39)
Hastings, 2008^354^ | Secondary analysis of data from the Medicare Current Beneficiary Survey | 1,581 | Repeat outpatient ED visit | DAI 3 vs. 1 | | Hazard Ratio | 1.1 (0.74; 1.64)
Hastings, 2008^354^ | Secondary analysis of data from the Medicare Current Beneficiary Survey | 1,581 | Repeat outpatient ED visit | DAI 4 vs. 1 | | Hazard Ratio | 1.06 (0.73; 1.54)
Kiely, 2009^26^ | MOBILIZE Boston Study | 765 | Emergency Room Visits | SOF Frailty Index prefrail vs. robust | Adjusted for age, gender, race, diabetes, stroke, hypertension, hyperlipidemia, education and income | Odds Ratio | 2.19 (1.43; 3.33)
Kiely, 2009^26^ | MOBILIZE Boston Study | 765 | Emergency Room Visits | SOF Frailty Index frail vs. robust | | Odds Ratio | 3.54 (1.43; 8.79)
Kiely, 2009^26^ | MOBILIZE Boston Study | 765 | Emergency Room Visits | CHS Frailty Index prefrail vs. robust | | Odds Ratio | 1.34 (0.95; 1.89)
Kiely, 2009^26^ | MOBILIZE Boston Study | 765 | Emergency Room Visits | CHS Frailty Index frail vs. robust | | Odds Ratio | 3.1 (1.64; 5.86)

Appendix E Table 39 Association Between Hospitalization and Disability in Older Persons

Reference | Study | Country | Sample Size | Adjustment | Estimate | Mean (95% CI or P Value)
ADL ≥1 vs. 0
Aliyu, 2003^310^ | The Longitudinal Study of Aging | USA | 7,541 | Adjusted for race, education, family relationship family income, health insurance coverage, social network involvement, perceived health status, and activities of daily living (ADL) | Odds Ratio | 1.78 (1.64; 1.96)
Uses cane, walker, wheelchair vs. no
Wieland, 2000^128^ | Data from Program of All- Inclusive Care for the Elderly (PACE) | USA | 5,478 | Adjusted for age, Hispanic (vs. White) ethnicity, living at home with others, or other living arrangements (vs. home alone), widowed, and divorced/separated (vs. married), varying Medicare coverages, self-reported health, number of household and nonhousehold caregivers, informal meal preparation, housework, money management and transportation received, SPMSQ score, ADL/IADL status, use of dressing and feeding devices, visual, hearing, communication and behavioral impairments, bowel/bladder rehabilitation, ostomy care, parenteral medications, inhalation treatment, syphilis, tuberculosis, infectious disease other than TB or syphilis, neoplasms, hypo/hyperthyroidism, anemia, other blood disease, dementia, psychosis, depression/anxiety, other mental disorders, CVD, Parkinson’s, diseases of eye and ear, other nervous system diseases, hypertension, PVD, arteriosclerosis, bronchitis, COPD, bronchiectasis, bronchitis, other respiratory diseases, diverticulosis, colitis, chronic constipation, biliary tract disease, inguinal hernia, esophageal reflux, hepatic disease, UTI, skin infections, dermatitis, psoriasis, other skin diseases, arthritis, osteomyelitis, osteoporosis, other musculoskeletal disease, fracture, decubitus ulcer, amputation, and “other (unclassified) diseases.” | Hazard Ratio | 1.16 (p=0.006)
Dentures yes vs. no
Wieland, 2000^128^ | Data from Program of All- Inclusive Care for the Elderly (PACE) | USA | 5478 | Adjusted for age, Hispanic (vs. White) ethnicity, living at home with others, or other living arrangements (vs. home alone), widowed, and divorced/separated (vs. married), varying Medicare coverages, self-reported health, number of household and nonhousehold caregivers, informal meal preparation, housework, money management and transportation received, SPMSQ score, ADL/IADL status, use of dressing and feeding devices, visual, hearing, communication and behavioral impairments, bowel/bladder rehabilitation, ostomy care, parenteral medications, inhalation treatment, syphilis, tuberculosis, infectious disease other than TB or syphilis, neoplasms, hypo/hyperthyroidism, anemia, other blood disease, dementia, psychosis, depression/anxiety, other mental disorders, CVD, Parkinson’s, diseases of eye and ear, other nervous system diseases, hypertension, PVD, arteriosclerosis, bronchitis, COPD, bronchiectasis, bronchitis, other respiratory diseases, diverticulosis, colitis, chronic constipation, biliary tract disease, inguinal hernia, esophageal reflux, hepatic disease, UTI, skin infections, dermatitis, psoriasis, other skin diseases, arthritis, osteomyelitis, osteoporosis, other musculoskeletal disease, fracture, decubitus ulcer, amputation, and “other (unclassified) diseases.” | Hazard Ratio | 1.1 (p=0.02)
Number of ADLs (continuous variable 0–7) and hospitalization (defined as hospitalization for Ambulatory Care Sensitive Conditions)
Laditka, 2003^308^ | Longitudinal Study of Aging | USA | 3,562 | Adjusted for age, education, insurance and marital status, health status, primary care access, self-rated health, comorbidities, physical impairments, and previous hospitalizations | Relative Risk | 1.31 (-2.59; 5.21)
Number of restricted-activity bed days as continuous variables and hospitalization (defined as a hospitalization or ED visit during the first year)
Shelton, 2000^114^ | 411 patients who participated as control patients in the Generalist Physician Initiative at the Carle Clinic site, Urbana, Illinois | USA | 411 | Adjusted for age, female sex, living arrangement, race, marital status, less than a high school education, taking 5 or more prescription medications daily, comorbid illness category, restricted-activity bed days category (confined to bed for at least 1 day during the past 12 months), 5 health status measures of the HSQ, and the baseline indicator of any hospitalization or ED encounter | Odds Ratio | 1.7 (0.86; 2.9)
Male: disability in 3+ ADLs and disability in 1–2 ADLs in the 2 years prior to severe disability onset vs. disability in 1–2 ADLs in the 2 years prior to severe disability onset but final ADLs <3
Ferrucci, 1997^10^ | Established Populations for Epidemiologic Studies of the Elderly | USA | 6,070 | Adjusted for age and disability | Odds Ratio | 2.8 (1.6; 5.2)
Female: disability in 3+ ADLs and disability in 1–2 ADLs in the 2 years prior to severe disability onset vs. disability in 1–2 ADLs in the 2 years prior to severe disability onset but final ADLs <3
Ferrucci, 1997^10^ | Established Populations for Epidemiologic Studies of the Elderly | USA | 6,070 | Adjusted for age and disability | Odds Ratio | 3.8 (2.2; 4.9)
Unable to do one or more of five ADLs and four IADLs without other assistance and special device and hospitalization (defined as larger than 0.5 admission per year)
Boult, 1993^306^ | Longitudinal Study on Aging | USA | 5,876 | Adjusted for need variables, predisposing variables, and enabling variables | Odds Ratio | 1.2 (0.8; 1.8)
Male: ≥3 ADLs (used 6)--new onset after having no disabilities vs. additional ADL disability developed after having 1–2 ADL disabilities
Ferrucci, 1997^10^ | EPESE Boston, New Haven, Iowa sites Established Populations for Epidemiologic Studies of the Elderly | USA | 6,070 | Adjusted for socio-demographic characteristics, health status, functional ability, previous use of health services, insurance, income, and family composition | Odds Ratio | 15.9 (9.1; 27.5)
Female: ≥3 ADL (used 6)--new onset after having no disabilities vs. additional ADL disability developed after having 1–2 ADL disabilities
Ferrucci, 1997^10^ | EPESE Boston, New Haven, Iowa sites Established Populations for Epidemiologic Studies of the Elderly | USA | 6,070 | Adjusted for socio-demographic characteristics, health status, functional ability, previous use of health services, insurance, income, and family composition | Odds Ratio | 16 (11.1; 23)
Male: ≥3 ADL (used 6)--additional ADL disability developed after having 1–2 ADL disabilities vs. additional ADL disability developed after having 1–2 ADL disabilities
Ferrucci, 1997^10^ | EPESE Boston, New Haven, Iowa sites Established Populations for Epidemiologic Studies of the Elderly | USA | 6,070 | Adjusted for socio-demographic characteristics, health status, functional ability, previous use of health services, insurance, income, and family composition | Odds Ratio | 2.8 (1.6; 5.2)
Female: ≥3 ADL (used 6)--additional ADL disability developed after having 1–2 ADL disabilities vs. additional ADL disability developed after having 1–2 ADL disabilities
Ferrucci, 1997^10^ | EPESE Boston, New Haven, Iowa sites Established Populations for Epidemiologic Studies of the Elderly | USA | 6,070 | Adjusted for socio-demographic characteristics, health status, functional ability, previous use of health services, insurance, income, and family composition | Odds Ratio | 3.8 (2.2; 4.9)
≥1 ADL (used 7) assistance vs. no ADL or IADL difficulty, and physically able; and hospitalization (defined as two or more hospitalization in prior year)
Harris, 1989^355^ | Longitudinal Study on Aging | USA | 1,791 | Adjusted for age and sex | Odds Ratio | 3.3 (1.9; 5.5)
≥1 ADL (used 7) difficulty, no assistance vs. no ADL or IADL difficulty, and physically able; and hospitalization (defined as two or more hospitalization in prior year)
Harris, 1989^355^ | Longitudinal Study on Aging | USA | 1,791 | Adjusted for age and sex | Odds Ratio | 2 (1.1; 3.4)
≥1 IADL difficulty, no ADL difficulty vs. no ADL or IADL difficulty, and physically able; and hospitalization (defined as two or more hospitalization in prior year)
Harris, 1989^355^ | Longitudinal Study on Aging | USA | 1,791 | Adjusted for age and sex | Odds Ratio | 2.5 (1.4; 4.5)
No ADL or IADL difficulty, and not physically able vs. no ADL or IADL difficulty, and physically able; and hospitalization (defined as two or more hospitalization in prior year)
Harris, 1989^355^ | Longitudinal Study on Aging | USA | 1,791 | Adjusted for age and sex | Odds Ratio | 2.1 (1.2; 3.5)

Bold=statistically significant.

Physically able=having no difficulty in walking 1/4 of a mile, stooping, crouching or kneeling, lifting 10 pounds, or walking up 10 steps without resting.

Appendix E Table 40 Association Between Institutionalization and Disability in Older Persons

Reference | Study | Country | Sample Size | Adjustment | Estimate | Mean (95% CI or P Value)
ADLs >1 vs. 0
Miller, 1999Miller, 1999 #3016} | Longitudinal Study of Aging | USA | 12,007 | Adjusted for gender, age, race, hospitalization, marital status, living arrangements (alone/others), family income, home ownership, survey transition year, two- and three way interaction terms if they met either of two criterion: (1) if the overall test of the effect of the interaction across all outcome categories was significant at p <.05, or (2) if the overall test was not significant, but the component of the interaction term related to moves versus no transition was significant at p <.05, the assistance and functional status variables | Odds Ratio | 2.16 (1.41; 3.31)
ADL >1 vs. 0, male
Nuotio, 2003^163^ | The second wave of the Tampere Longitudinal Study on Ageing (TamELSA) | Finland | 775 | Adjusted for age, urge incontinence, living alone, neurological diseases, cardiovascular diseases, musculoskeletal diseases, other chronic diseases, ADL disability, depressive symptoms | Relative Risk | 1.39 (0.59; 3.28)
ADL >1 vs. 0, female
Nuotio, 2003^163^ | The second wave of the Tampere Longitudinal Study on Ageing (TamELSA) | Finland | 775 | Adjusted for age, urge incontinence, living alone, neurological diseases, cardiovascular diseases, musculoskeletal diseases, other chronic diseases, ADL disability, depressive symptoms | Relative Risk | 1.09 (0.63; 1.88)
ADL 1 vs. 0
Miller, 1999^299^ | Longitudinal Study of Aging | USA | 12,007 | Adjusted for gender, age, race, hospitalization, marital status, living arrangements (alone/others), family income, home ownership, survey transition year, two- and three way interaction terms if they met either of two criterion: (1) if the overall test of the effect of the interaction across all outcome categories was significant at p <.05, or (2) if the overall test was not significant, but the component of the interaction term related to moves versus no transition was significant at p <.05, the assistance and functional status variables | Odds Ratio | 1.61 (1.08; 2.39)
ADL 1–2 vs. 0
Mor, 1994^294^ | Longitudinal Study on Aging | USA | 7,407 | Adjusted for age, gender, self-rated health, number of medical conditions, baseline functional status, and the interaction between age and gender | Odds Ratio | 9.8 (6.8; 14)
Steinbach, 1992^297^ | Longitudinal Study of Aging | USA | 4,547 | Adjusted for age, sex, race, family income, self-perceived health status, ADLs, hypertension, stroke or CVA, cancer, heart disease, arthritis, DM, fall, social network, social activities, and living arrangement | Odds Ratio | 2.8 (1.78; 4.4)
ADL 1–3 vs. 0
Banaszak- Holl, 2004Banaszak-Holl, 2004 #2488} | Asset and Health Dynamics Among the Oldest Old (AHEAD) Study | USA | 6,676 | Adjusted for other variables: Model 1 included socio-demographic measures, potential caregiver network, geographic region, medical conditions, and ADL and IADL impairments | Hazard Ratio | 2.1 (1.8; 2.5)
ADL ≥3 vs. 0
Mor, 1994^294^ | Longitudinal Study on Aging | USA | 7,407 | Adjusted for age, gender, self-rated health, number of medical conditions, baseline functional status, and the interaction between age and gender | Odds Ratio | 17 (9.1; 32)
Steinbach, 1992^297^ | Longitudinal Study of Aging | USA | 4,547 | Adjusted for age, sex, race, family income, self-perceived health status, ADLs, hypertension, stroke or CVA, cancer, heart disease, arthritis, DM, fall, social network, social activities, and living arrangement | Odds Ratio | 4.53 (2.97; 6.9)
ADL 4–5 vs. 0
Banaszak- Holl, 2004^352^ | Asset and Health Dynamics Among the Oldest Old (AHEAD) Study | USA | 6,676 | Adjusted for other variables: Model 1 included socio-demographic measures, potential caregiver network, geographic region, medical conditions, and ADL and IADL impairments | Hazard Ratio | 2.1 (1.7; 2.6)
Number of ADLs (continuous variable 0–7)
Belgrave, 1994^305^ | Longitudinal Study of Aging | USA | 560 | Adjusted for ADL, IADL, self-health, activity limitations, confused, age, sex, living alone, education, income, and Medicaid in African American | Odds Ratio | 1.05 (p >0.1)
Belgrave, 1994^305^ | Longitudinal Study of Aging | USA | 6880 | Adjusted for ADL, IADL, self-health, activity limitations, confused, age, sex, living alone, education, income, and Medicaid in Whites | Odds Ratio | 1.04 (p >0.1)
Belgrave, 1994^305^ | Longitudinal Study of Aging | USA | 180 | Adjusted for ADL, IADL, self-health, activity limitations, confused, age, sex, living alone, education, income, and Medicaid in African American and with limitation of IADL | Odds Ratio | 1.29 (p >0.1)
Belgrave, 1994^305^ | Longitudinal Study of Aging | USA | 1,720 | Adjusted for ADL, IADL, self-health, activity limitations, confused, age, sex, living alone, education, income, and Medicaid | Odds Ratio | 1.17 (p <0.05)
Coward, 1996^301^ | Longitudinal Study of Aging | USA | 7,527 | Adjusted for residence, socio-demographic characteristics, health status characteristic, and social support characteristics | Odds Ratio | 1.15 (p <0.01)
St John, 2002^150^ | Canadian Study of Health and Aging | Canada | 8,073 | Adjusted for age, gender, education, Time 1 MMSE, and self- rated health | Odds Ratio | 1.07 (0.97; 1.67)
St John, 2002^150^ | Canadian Study of Health and Aging | Canada | 6,934 | Adjusted for age, gender, education, Time 1 MMSE, and self- rated health | Odds Ratio | 1.14 (1.01; 1.29)
Dependence in ADLs
Miller, 1999^299^ | Longitudinal Study of Aging | USA | 12,007 | Adjusted for gender, age, race, hospitalization, marital status, living arrangements (alone/others), family income, home ownership, survey transition year, two- and three way interaction terms if they met either of two criterion: (1) if the overall test of the effect of the interaction across all outcome categories was significant at p <.05, or (2) if the overall test was not significant, but the component of the interaction term related to moves vs. no transition was significant at p <.05, the assistance and functional status variables | Odds Ratio | 1.3 (0.92; 1.84)
Wolinsky, 1991^356^ | Longitudinal Study of Aging | USA | 5,151 | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics | Odds Ratio | 1 (p >0.05)
Wolinsky, 1993Wolinsky, 1993 #3083} | Longitudinal Study of Aging | USA | 3,646 | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, change in functional status measures | Odds Ratio | 1.29 (p = 0.02)
Dependence in walking
Long, 2005^118^ | Applicants to the home- and community-based care (HCBC) programs | USA | 1,690 | Adjusted for receiving HCBC services, age, race, gender, health status, did not have hospital stay or SNF, LTCH, rehab hospital stay in prior 6 months, 0 to 3 MSQ errors, needs supervision never/sometimes/unknown, does not need assistance with mobility, does not need help with medication or meal preparation, does not have a mental illness, Alzheimer’s or dementia, does not have medications with potential side effects in elderly, lives with spouse/child/other/unknown, primary caregiver is other relative/non-relative/none/unknown, did not have Medicare home health use in prior 6 months, monthly income greater than $1000. | Odds Ratio | 0.85 (p >0.05)
Goodlin, 2004^298^ | Secondary analysis of data from the Medicare Current Beneficiary Survey | USA | 3,232 | Adjusted for socio-demographic characteristics, health status, functional ability, previous use of health services, insurance, income, and family composition | Odds Ratio | 1.84 (p = 0.006)
Dependence in dressing
Rockwood, 1996^147^ | Canadian Study of Health and Aging | Canada | 9,113 | Adjusted for age, gender, race, married status, absence of a caregiver, non-spouse caregiver, IADL-dependence in finances, dependence in shopping, ADL-dependence in dressing, dependence in feeding, bladder incontinence, bowel incontinence, cardiovascular disease, hypertension, diabetes mellitus, stroke, Parkinson’s disease, hearing impairment, visual impairment, age-associated memory impairment (AAMI), Alzheimer’s disease, vascular dementia, and other dementia | Odds Ratio | 4.41 (3.6; 5.4)
Dependence in feeding
Rockwood, 1996^147^ | Canadian Study of Health and Aging | Canada | 9,113 | Adjusted for age, gender, race, married status, absence of a caregiver, non-spouse caregiver, IADL-dependence in finances, dependence in shopping, ADL-dependence in dressing, dependence in feeding, bladder incontinence, bowel incontinence, cardiovascular disease, hypertension, diabetes mellitus, stroke, Parkinson’s disease, hearing impairment, visual impairment, age-associated memory impairment (AAMI), Alzheimer’s disease, vascular dementia, and other dementia | Odds Ratio | 2.76 (2.16; 3.52)
Using equipment for bathing
Goodlin, 2004^298^ | Secondary analysis of data from the Medicare Current Beneficiary Survey | USA | 3,232 | Adjusted for socio-demographic characteristics, health status, functional ability, previous use of health services, insurance, income, and family composition | Odds Ratio | 1.92 (p = 0.019)
IADL ≥1 vs. 0
Mor, 1994^294^ | Longitudinal Study on Aging | USA | 7,407 | Adjusted for age, gender, self-rated health, number of medical conditions, baseline functional status, and the interaction between age and gender | Odds Ratio | 6.7 (4.6; 9.6)
IADL >1 vs. 0
Miller, 1999^299^ | Longitudinal Study of Aging | USA | 12,007 | Adjusted for gender, age, race, hospitalization, marital status, living arrangements (alone/others), family income, home ownership, survey transition year, two- and three way interaction terms if they met either of two criterion: (1) if the overall test of the effect of the interaction across all outcome categories was significant at p <.05, or (2) if the overall test was not significant, but the component of the interaction term related to moves versus no transition was significant at p <.05, the assistance and functional status variables | Odds Ratio | 1.36 (0.69; 2.68)
IADL 1 vs. 0
Miller, 1999^299^ | Longitudinal Study of Aging | USA | 12,007 | Adjusted for gender, age, race, hospitalization, marital status, living arrangements (alone/others), family income, home ownership, survey transition year, two- and three way interaction terms if they met either of two criterion: (1) if the overall test of the effect of the interaction across all outcome categories was significant at p <.05, or (2) if the overall test was not significant, but the component of the interaction term related to moves versus no transition was significant at p <.05, the assistance and functional status variables | Odds Ratio | 1.04 (0.6; 1.8)
IADL 1–3 vs. 0
Banaszak- Holl, 2004^352^ | Asset and Health Dynamics Among the Oldest Old (AHEAD) Study | USA | 6,676 | Adjusted for other variables: Model 1 included socio-demographic measures, potential caregiver network, geographic region, medical conditions, and ADL and IADL impairments | Hazar Ratio | 2 (1.7; 2.3)
IADL 4–5 vs. 0
Banaszak- Holl, 2004^352^ | Asset and Health Dynamics Among the Oldest Old (AHEAD) Study | USA | 6,676 | Adjusted for other variables: Model 1 included socio-demographic measures, potential caregiver network, geographic region, medical conditions, and ADL and IADL impairments | Hazard Ratio | 2.5 (2; 3.3)
Number of IADLs (continuous variable 0–4)
Wolinsky, 1992^300^ | Longitudinal Study of Aging | USA | 5,151 | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | Odds Ratio | 1.14 (p = 0.03)
Number of IADLs (continuous variable 0–6)
Belgrave, 1994^305^ | Longitudinal Study of Aging | USA | 560 | Adjusted for ADL, IADL, self-health, activity limitations, confused, age, sex, living alone, education, income, and Medicaid in African American | Odds Ratio | 1.21 (p >0.1)
Belgrave, 1994^305^ | Longitudinal Study of Aging | USA | 6,880 | Adjusted for ADL, IADL, self-health, activity limitations, confused, age, sex, living alone, education, income, and Medicaid in Whites | Odds Ratio | 1.1 (p >0.1)
Belgrave, 1994^305^ | Longitudinal Study of Aging | USA | 180 | Adjusted for ADL, IADL, self-health, activity limitations, confused, age, sex, living alone, education, income, and Medicaid in African American with IADL limitations | Odds Ratio | 1.1 (p >0.1)
Belgrave, 1994^305^ | Longitudinal Study of Aging | USA | 1,720 | Adjusted for ADL, IADL, self-health, activity limitations, confused, age, sex, living alone, education, income, and Medicaid | Odds Ratio | 1.03 (p >0.1)
Coward, 1996^301^ | Longitudinal Study of Aging | USA | ,7527 | Adjusted for residence, socio-demographic characteristics, health status characteristic, and social support characteristics | Odds Ratio | 1.16 (p <0.05)
Number of IADLs (continuous variable 0–7)
St John, 2002^150^ | Canadian Study of Health and Aging | Canada | 8,073 | Adjusted for age, gender, education, Time 1 MMSE, and self- rated health | Odds Ratio | 1.21 (1.15; 1.28)
Number of IADLs (continuous variable 0–7) in population with normal MMSE score
St John, 2002^150^ | Canadian Study of Health and Aging | Canada | 6,934 | Adjusted for age, gender, education, Time 1 MMSE, and self- rated health | Odds Ratio | 1.27 (1.19; 1.36)
Dependence in finances
Rockwood, 1996^147^ | Canadian Study of Health and Aging | Canada | 9,113 | Adjusted for Age, gender, race, married status, absence of a caregiver, non-spouse caregiver, IADL-dependence in finances, dependence in shopping, ADL-dependence in dressing, dependence in feeding, bladder incontinence, bowel incontinence, cardiovascular disease, hypertension, diabetes mellitus, stroke, Parkinson’s disease, hearing impairment, visual impairment, age-associated memory impairment (AAMI), Alzheimer’s disease, vascular dementia, and other dementia | Odds Ratio | 1.67 (1.41; 2)
Dependence in shopping
Goodlin, 2004^298^ | Secondary analysis of data from the Medicare Current Beneficiary Survey | USA | 3,232 | Adjusted for socio-demographic characteristics, health status, functional ability, previous use of health services, insurance, income, and family composition | Odds Ratio | 2.88 (p <0.001)
Rockwood, 1996^147^ | Canadian Study of Health and Aging | Canada | 9,113 | Adjusted for Age, gender, race, married status, absence of a caregiver, non-spouse caregiver, IADL-dependence in finances, dependence in shopping, ADL-dependence in dressing, dependence in feeding, bladder incontinence, bowel incontinence, cardiovascular disease, hypertension, diabetes mellitus, stroke, Parkinson’s disease, hearing impairment, visual impairment, age-associated memory impairment (AAMI), Alzheimer’s disease, vascular dementia, and other dementia | Odds Ratio | 0.88 (0.74; 1.03)
Needs help with medications vs. no
Long, 2005^118^ | Applicants to the home- and community-based care (HCBC) programs | USA | 1690 | Adjusted for receiving HCBC services, age, race, gender, health status, did not have hospital stay or SNF, LTCH, rehab hospital stay in prior 6 months, 0 to 3 MSQ errors, needs supervision never/sometimes/unknown, does not need assistance with mobility, does not need help with medication or meal preparation, does not have a mental illness, Alzheimer’s or dementia, does not have medications with potential side effects in elderly, lives with spouse/child/other/unknown, primary caregiver is other relative/non-relative/none/unknown, did not have Medicare home health use in prior 6 months, monthly income greater than $1000. | Odds Ratio | 1.34 (p >0.05)
Needs help with meal preparation vs. no
Long, 2005^118^ | Applicants to the home- and community-based care (HCBC) programs | USA | 1,690 | Adjusted for receiving HCBC services, age, race, gender, health status, did not have hospital stay or SNF, LTCH, rehab hospital stay in prior 6 months, 0 to 3 MSQ errors, needs supervision never/sometimes/unknown, does not need assistance with mobility, does not need help with medication or meal preparation, does not have a mental illness, Alzheimer’s or dementia, does not have medications with potential side effects in elderly, lives with spouse/child/other/unknown, primary caregiver is other relative/non-relative/none/unknown, did not have Medicare home health use in prior 6 months, monthly income greater than $1000. | Odds Ratio | 2.61 (p >0.05)
Number of ADLs and IADL (0–13)
Speare, 1991^303^ | Longitudinal Study of Aging | USA | 5,151 | Adjusted for disability, incontinence, blindness, deafness, limitation in major activities, social support, age, sex, income | Odds Ratio | 1.19 (p <0.01)
Kersting, 2001^302^ | Longitudinal Study of Aging | USA | 7,527 | Adjusted for social support, poverty, age, gender, race, ADL/IADL score, self-reported health status, and fall | Hazard Ratio | 1.17 (1.13; 1.2)
Kersting, 2001^302^ | Longitudinal Study of Aging | USA | 555 | Adjusted for social support, poverty, age, gender, race, ADL/IADL score, self-reported health status, and fall in African Americans | Hazard Ratio | 1.24 (1.13; 1.36)
304 | Longitudinal Study of Aging | USA | 6,986 | Adjusted for social support, poverty, age, and ADL/IADL score | Hazard Ratio | 1.19 (1.16; 1.21)
GERI-AIMS scale
Falconer, 1992^113^ | 2-year longitudinal study of independent residents of a continuing care retirement community | USA | 152 | Adjusted for age, sex, GERI-AIMS, disease severity, and Williams test | Relative Risk | 1.14 (p ≤0.01)
Williams test for hand function
Falconer, 1992^113^ | 2-year longitudinal study of independent residents of a continuing care retirement community | USA | 152 | Adjusted for age, sex, GERI-AIMS, disease severity, and Williams test | Relative Risk | 2.42 (p >0.05)
LBL
Miller, 1999^299^ | Longitudinal Study of Aging | USA | 12,007 | Adjusted for gender, age, race, hospitalization, marital status, living arrangements (alone/others), family income, home ownership, survey transition year, two- and three way interaction terms if they met either of two criterion: (1) if the overall test of the effect of the interaction across all outcome categories was significant at p <.05, or (2) if the overall test was not significant, but the component of the interaction term related to moves versus no transition was significant at p <.05, the assistance and functional status variables | Odds Ratio | 1.09 (0.99; 1.2)
Wolinsky, 1992^300^ | Longitudinal Study of Aging | USA | 5,151 | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, health services utilization, and change in functional status measures | Odds Ratio | 1.08 (p = 0.0417)
Change in lower body function
Wolinsky, 1993^357^ | Longitudinal Study of Aging | USA | 3,646 | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, change in functional status measures | Odds Ratio | 1.179 (p = 0.01)
Change in advanced ADLs
Wolinsky, 1993^357^ | Longitudinal Study of Aging | USA | 3,646 | Adjusted for baseline predisposing characteristics, enabling characteristics, need characteristics, change in functional status measures | Odds Ratio | 1.48 (p = 0.001)
≥ 3ADL (used 6)--new onset after having no disabilities vs. additional ADL disability developed after having 1–2 ADL disabilities
Ferrucci, 1997^10^ | EPESE Boston, New Haven, Iowa sites Established Populations for Epidemiologic Studies of the Elderly | USA | 6,070 | Adjusted for socio-demographic characteristics, health status, functional ability, previous use of health services, insurance, income, and family composition | Odds Ratio | 2.8 (1.7; 4.5)
Female: ≥3 ADL (used 6)--new onset after having no disabilities vs. additional ADL disability developed after having 1–2 ADL disabilities
Ferrucci, 1997^10^ | EPESE Established Populations for Epidemiologic Studies of the Elderly - East Boston & New Haven Communities | USA | 6,640 | Adjusted for socio-demographic characteristics, health status, functional ability, previous use of health services, insurance, income, and family composition | Odds Ratio | 2.3 (1.6; 3.2)
Male: ≥3 ADL (used 6)--new onset after having no disabilities vs. additional ADL disability developed after having 1–2 ADL disabilities
Ferrucci, 1997^10^ | EPESE Established Populations for Epidemiologic Studies of the Elderly - East Boston & New Haven Communities | USA | 6,640 | Adjusted for socio-demographic characteristics, health status, functional ability, previous use of health services, insurance, income, and family composition | Odds Ratio | 1.3 (0.8; 2.1)
1–2 ADLs (used 7) vs. 0, 4 year prior
Anderson, 1998^358^ | Longitudinal Study on Aging | USA | 5,079 | Adjusted odds ratio predicting being institutionalized relative to being independent (defined as no IADL or ADL limitations) | Odds Ratio | 2.63 (1.49; 4.66)
≥3 ADLs (used 7) vs. 0, 4 year prior
Anderson, 1998^358^ | Longitudinal Study on Aging | USA | 5,079 | Adjusted odds ratio predicting being institutionalized relative to being independent (defined as no IADL or ADL limitations) | Odds Ratio | 3.43 (1.48; 7.95)
≥1 IADL (used 6) AND no ADL (used 7) vs. 0, 4 year prior
Anderson, 1998^358^ | Longitudinal Study on Aging | USA | 5,079 | Adjusted odds ratio predicting being institutionalized relative to being independent (defined as no IADL or ADL limitations) | Odds Ratio | 2.38 (1.61; 3.51)
1–2 ADLs (used 7) vs. 0, 2 year prior
Anderson, 1998^358^ | Longitudinal Study on Aging | USA | 5,079 | Adjusted odds ratio predicting being institutionalized relative to being independent (defined as no IADL or ADL limitations) | Odds Ratio | 15.57 (9.12; 26.58)
≥3 ADLs (used 7) vs. 0, 2 year prior
Anderson, 1998^358^ | Longitudinal Study on Aging | USA | 5,079 | Adjusted odds ratio predicting being institutionalized relative to being independent (defined as no IADL or ADL limitations) | Odds Ratio | 83.22 (33.28; 208.1)
≥1 IADL (used 6) AND no ADL (used 7) vs. 0, 2 year prior
Anderson, 1998^358^ | Longitudinal Study on Aging | USA | 5,079 | Adjusted odds ratio predicting being institutionalized relative to being independent (defined as no IADL or ADL limitations) | Odds Ratio | 3.53 (2.27; 5.49)
≥1 ADL (used 7) assistance vs. no ADL or IADL difficulty, and physically able
Harris, 1989^355^ | Longitudinal Study on Aging | USA | 1,791 | Adjusted for age and sex | Odds Ratio | 6.7 (3.8; 12.8)
≥1 ADL (used 7) difficulty, no assistance vs. no ADL or IADL difficulty, and physically able
Harris, 1989^355^ | Longitudinal Study on Aging | USA | 1,791 | Adjusted for age and sex | Odds Ratio | 3.7 (2; 7.4)
≥1 IADL difficulty, no ADL difficulty vs. no ADL or IADL difficulty, and physically able
Harris, 1989^355^ | Longitudinal Study on Aging | USA | 1,791 | Adjusted for age and sex | Odds Ratio | 2.8 (1.4; 5.6)
No ADL or IADL difficulty, and not physically able vs. no ADL or IADL difficulty, and physically able
Harris, 1989^355^ | Longitudinal Study on Aging | USA | 1,791 | Adjusted for age and sex | Odds Ratio | 2.2 (1.1; 4.1)
Restricted activity
Gill, 2004^36^ | Precipitating Events Project | USA | 754 | Adjusted for age, sex, race/ethnicity, living alone, years of education, chronic conditions, cognitive impairment, depressive symptoms, and prior intervening events | Hazard Ratio | 3.51 (1.72; 7.19)
Restricted activity in population with physically frail at baseline
Gill, 2004^36^ | Precipitating Events Project | USA | 754 | Adjusted for age, sex, race/ethnicity, living alone, years of education, chronic conditions, cognitive impairment, depressive symptoms, and prior intervening events | Hazard Ratio | 4.52 (1.95; 10.5)
Restricted activity in population without physically frail at baseline
Gill, 2004^36^ | Precipitating Events Project | USA | 754 | Adjusted for age, sex, race/ethnicity, living alone, years of education, chronic conditions, cognitive impairment, depressive symptoms, and prior intervening events | Hazard Ratio | 1.71 (0.35; 8.29)

Bold=statistically significant.

Lower Body Limitations (LBL)=any difficulty with walking 1/4 of a mile, walking up 10 steps without rest, standing or being on the feet for 2 hours, stooping, crouching or kneeling, or lifting or carrying 25 pounds; Restricted activity=cut down on usual activities or stayed in bed for at least half a day due to an illness; Physically able=having no difficulty in walking 1/4 of a mile, stooping, crouching or kneeling, lifting 10 pounds, or walking up 10 steps without resting.

Appendix E Table 41 Association Between Disability and Mortality in Older Persons

Disability Definition | Reference | Study | Sample Size | Followup | Adjustment | Estimate (95% CI)
ADL continuous- per increase in 1 score
Number of ADL limits (used 7) | Naeim, 2007^359^ | Second Longitudinal Study on Aging (LSOAII) | 8,838 | Mortality at 4-yr followup | * | OR 1.1 (1.04; 1.16)
Increase by 1 score in Barthel index (range 0 to 20 [higher score is better], includes 10 ADLs) | Buurman, 2008^198^ | Tertiary university teaching hospital | 463 | 90-day survival after hospital admission | * | OR 0.9 (0.87; 0.94)
Number of “other” ADLs (used 5--bathe, dress, transfer, toilet, eat) | Long, 2005^118^ | Medicaid applicants to the home- and community-based care (HCBC) programs | 1,690 | Mortality 6-months following application for services | * | OR 1.44 p < 0.01
ADL/IADL per increase in 1 score
Number of Functional Limits (unclear in this write-up, but assumed to include 13 total: 7 ADLs and 6 IADLs) | Grabowski, 2001^360^ | Longitudinal Study of Aging | 7,459 | Cox regression to calculate proportional hazards ratios for mortality over 96 months | * | HR 1.10 (1.08; 1.12)
IADL continuous
Number of IADL limits (used 8) | Naeim, 2007^359^ | Second Longitudinal Study on Aging (LSOAII) | ,8838 | Mortality at 4-eayr followup | * | OR 1.12 (1.08; 1.17)
Number of “other” IADLs (used 6--housework, laundry, telephone, finances, travel, shopping) | Long, 2005^118^ | Medicaid applicants to the home- and community-based care (HCBC) programs | 1,690 | Mortality 6-months following application for services | * | OR 0.88 NS
IADL
≥1 IADL (used 3) AND no ADL | Mor, 1994^294^ | Longitudinal Study on Aging | 7,407 | Mortality at 6-year followup | * | OR 6.6 (5.1; 8.6)
≥1 IADL (used 6) AND no ADL (used 7) | Anderson, 1998^358^ | Longitudinal Study on Aging | 5,079 | 4-years prior IADL | | OR 1.86 (1.4; 2.46)
≥1 IADL (used 6) AND no ADL (used 7) | | | | 2-years prior IADL | | OR 4.14 (3.2; 5.36)
≥1 IADL difficulty, no ADL difficulty | Harris, 1989^355^ | Longitudinal Study on Aging | 1,791 | Mortality at 2-year followup | | OR 2.2 (1.4; 3.3)
1–3 IADLs (used OARS-- number of items not given) | Ganguli, 2002^85^ | Monongahela Valley Independent Elders Survey | 1,064 | 3 year mortality | * | RR 1.54 (p=0.05)
1–3 IADLs (used OARS-- number of items not given) | Ganguli, 2002^85^ | Monongahela Valley Independent Elders Survey | 1,064 | 5 year mortality | * | RR 1.72 (p=0.001)
1–3 IADLs (used OARS-- number of items not given) | Ganguli, 2002^85^ | Monongahela Valley Independent Elders Survey | 1,064 | 10 year mortality | * | RR 1.62 (p<0.001)
2 IADL (used 6) | Fried, 1998^54^ | Cardiovascular Health Study | 5,201 | 5 year mortality | * | RR 1.46 (1.2; 1.78)
≥ 3 IADL (used 6) | Fried, 1998^54^ | Cardiovascular Health Study | 5,201 | 5 year mortality | * | RR 1.64 (1.26; 2.14)
≥4 IADLs (used OARS-- number of items not given) | Ganguli, 2002^85^ | Monongahela Valley Independent Elders Survey | 1,064 | 3 year mortality | * | RR 2.49 (p=0.02)
≥4 IADLs (used OARS-- number of items not given) | | | | 5 year mortality | * | RR 2.09 (p=0.03)
≥4 IADLs (used OARS-- number of items not given) | | | | 10 year mortality | * | RR 2.20 (p=0.001
IADL individual
meal preparation | Long, 2005^118^ | Applicants to home- and community-based care (HCBC) programs | 1,690 | Mortality 6-months following application for services | * | OR 2.421 NS
Medication management | | | | Mortality 6-months following application for services | * | OR 1.149 NS
Manage finances | Lee, 2006^71^ | Health and Retirement Study | 11,701 | 4 year mortality | * | OR 1.9 (1.6; 2.3)
IADL/ADL
No issues, IADL issues only, ADL issues only (does not specify number of IADLs and ADLs used. | Jones, 2004^153^ | The MGAT study | 171 | Death or institutionalization | * | HR 1.84 (1.04; 3.24)
ADL
≥1 ADL (used 7) difficulty, no assistance | Harris, 1989^355^ | Longitudinal Study on Aging | 1,791 | Mortality at 2-year followup | | OR 1.9 (1.3; 2.7)
1–2 ADLs (used 5) | Walter, 2001^125^ | Individuals enrolled in 2 randomized trials of an intervention to improve functional outcomes of hospitalized older adults | 1,495 | 1 year after hospital discharge | * | OR 2.1 (1.6; 2.8)
5 ADLs (used 5) | | | | 1 year after hospital discharge | * | OR 5.7 (4.2; 7.7)
Used 7 ADLs | Espino, 2006^200^ | H-EPESE Hispanic Established Populations for Epidemiologic Studies of the Elderly | 3,050 | 8 year mortality | * | HR 1.13 (1.07; 1.19)
ADL individual
“Mobility” disability [definition of ADL/IADLs used is not very clear; is this referring to the “walking across the room” ADL?] | Long, 2005^118^ | Applicants to the home- and community-based care (HCBC) programs | 1,690 | Mortality 6-months following application for services | * | OR 1.75 (p < 0.05)
Bathe | Lee, 2006^71^ | Health and Retirement Study | 11,701 | 4 year mortality | * | OR 2 (1.6; 2.4)
Dress: fully dependent | Carey, 2008^129^ | PACE Program of All-Inclusive Care for the Elderly | 3,899 | 1-year or 3-year mortality | | HR 1.6 (1.3; 2.1)
Dress: partially dependent | Carey, 2008^129^ | PACE Program of All-Inclusive Care for the Elderly | 3,899 | | | HR 1.2 (1; 1.4)
Toilet: fully dependent | Carey, 2008^129^ | PACE Program of All-Inclusive Care for the Elderly | 3,899 | | | HR 1.3 (1.1; 1.5)
ADL moderate
1–2 ADLs (used 7) | Anderson, 1998^358^ | Longitudinal Study on Aging | 5,079 | 4-years prior mod ADL | | OR 2 (1.22; 3.27)
1–2 ADLs (used 7) | Anderson, 1998^358^ | Longitudinal Study on Aging | 5,079 | 2-years prior mod ADL | | OR 14.06 (9.15; 21.61)
1–2 ADLs (used 6) | Mor, 1994^294^ | Longitudinal Study on Aging | 7,407 | Mortality at 6-year follow-up | * | OR 8.6 (6.6; 11)
ADL severe
≥3 ADLs (used 7) | Anderson, 1998^358^ | Longitudinal Study on Aging | 5,079 | 2-years prior severe ADL | | OR 3.43 (1.57; 7.51)
≥ 3 ADLs (used 7) | Anderson, 1998^358^ | Longitudinal Study on Aging | 5,079 | 2-years prior severe ADL | | OR 86.75 (39.44; 190.8)
≥3 ADLs (used 6) | Mor, 1994^294^ | Longitudinal Study on Aging | 7,407 | Mortality at 6-year followup | * | OR 30 (18; 51)
Rosow-Breslau individual
Walk 1/2 mile | Melzer, 2003^14^ | EPESE East Boston & New Haven Site Established Populations for Epidemiologic Studies of the Elderly | 3,040 | 4 year mortality | * | HR 2.95 (2.48; 3.5)
Walk several blocks | Lee, 2006^71^ | Health and Retirement Study | 11,701 | 4 year mortality | * | OR 2.1 (1.8; 2.4)
SPPB
0–6 score on SPPB (0 to 12) | Rolland, 2006^165^ | EPIDOS Epidemiologie de l’osteoporose study | 7,250 | NR | * | HR 1.34 (1.04; 1.73)
7–9 score on SPPB (0 to 12) | Rolland, 2006^165^ | EPIDOS Epidemiologie de l’osteoporose study | 7250 | | * | HR 1.24 (1.01; 1.53)
Mobility
Assessed using CGA, rated at highest level of independence, with aid where used. | Jones, 2004^153^ | MGAT study | 170 | Death or institutionalization | * | HR 1.21 (0.73; 2)
MOBLI score
< 0.2021 | Melzer, 2003^14^ | EPESE East Boston & New Haven Site Established Populations for Epidemiologic Studies of the Elderly | 3,040 | 4 year mortality | * | HR 2.71 (2.28; 3.21)
Nagi individual
Push/pull heavy objects | Lee, 2006^71^ | Health and Retirement Study | 11,701 | 4 year mortality | * | OR 1.5 (1.3; 1.8)

* Multivariate adjusted estimates.

Bold= significant at 95% confidence limits.

Appendix E Table 42 Association Between Sarcopenia and Clinical Outcomes in Older Persons

Reference | Study | Adjustment | Definition of Exposure | Measure of the Association | Mean (95% CI)
EPESE score of less than 10(Impaired lower extremity function was defined as a total score less than 10)
Newman, 2003^75^ | Health Aging and Body Composition (Health ABC) Study | Adjusted for age, race, drinking, smoking, physical activity and comorbidity | Men who are sarcopenic (aLM/ht2) | OR | 1.5 (1.1; 2.1)
Newman, 2003^75^ | Health Aging and Body Composition (Health ABC) Study | Adjusted for age, race, drinking, smoking, physical activity and comorbidity | Women who are sarcopenic (aLM/ht2) | OR | 0.9 (0.7; 1.2)
Newman, 2003^75^ | Health Aging and Body Composition (Health ABC) Study | Adjusted for age, race, drinking, smoking, physical activity and comorbidity | Men who are sarcopenic (residual) | OR | 1.8 (1.3; 2.5)
Newman, 2003^75^ | Health Aging and Body Composition (Health ABC) Study | Adjusted for age, race, drinking, smoking, physical activity and comorbidity | Women who are sarcopenic (residual) | OR | 1.9 (1.4; 2.5)
Mortality
Cesari, 2009^180^ | Invecchiare in Chianti Study | Adjusted for age, gender, site, education, Mini-Mental State Examination score, Center for Epidemiological Studies-Depression scale score, physical activity, congestive heart failure, coronary artery disease, hypertension, peripheral artery disease, respiratory disease, osteoarthritis, stroke, interleukin-6 (log value), C-reactive protein, and tumor necrosis factor-α (log value) | Sarcopenia in BMI <25 | HR | 1.25 (0.69; 2.25)
Cesari, 2009^180^ | Invecchiare in Chianti Study | | Sarcopenia in BMI 25–29.9 | HR | 1.24 (0.65; 2.37)
Cesari, 2009^180^ | Invecchiare in Chianti Study | | Sarcopenia in BMI ≥30 | HR | 1.18 (0.46; 3.02)
Cesari, 2009^180^ | Invecchiare in Chianti Study | Unadjusted | Muscle density (in mg/cm3) | HR | 0.78 (0.69; 0.88)
Cesari, 2009^180^ | Invecchiare in Chianti Study | Unadjusted | Muscle area (in cm2) | HR | 0.75 (0.66; 0.86)

Bold=statistically significant.

Appendix E Table 43 Association Between Frailty, Mortality, and Malnutrition Definition in Older Persons

Reference | Study | Age | Sample | Definition of Exposure | Adjustment | Relative Measure of Association with 95% CI
Frailty
Abnormalities: Anemia; Inflammation; Endocrine; Micronutrient; Body composition; Fine motor speed
Fried, 2009^98^ | Women‘s Health and Aging Studies I and II | >70 | 1,438 | Multiple vs. isolated abnormalities | Adjusted for age, race, education, and number of chronic diseases | OR 2.59 (1.22; 5.52)
Fried, 2009^98^ | Women‘s Health and Aging Studies I and II | >70 | 1,438 | Abnormal levels in 3–4 physiological measures | Adjusted for age, race, education, and number of chronic diseases | OR 11 (2.5; 47.9)
Fried, 2009^98^ | Women‘s Health and Aging Studies I and II | >70 | 1,438 | Abnormal levels in >5 physiological measures | Adjusted for age, race, education, and number of chronic diseases | OR 26 (3.7; 183.3)
Fried, 2009^98^ | Women‘s Health and Aging Studies I and II | >70 | 1,438 | Anemia | Adjusted for age, race, education, and number of chronic diseases | OR 1.5 (0.7; 3.4)
Fried, 2009^98^ | Women‘s Health and Aging Studies I and II | >70 | 1,438 | Dehydroepiandrosterone sulfate DHEA-S <0.215 mcg/mL | Adjusted for age, race, education, and number of chronic diseases | OR 1.4 (0.7; 2.8)
Fried, 2009^98^ | Women‘s Health and Aging Studies I and II | >70 | 1,438 | ≥2 nutritional deficits | Adjusted for age, race, education, and number of chronic diseases | OR 2.6 (1.3; 5)
Fried, 2009^98^ | Women‘s Health and Aging Studies I and II | >70 | 1,438 | Skinfold thickness <17 mm | Adjusted for age, race, education, and number of chronic diseases | OR 2.6 (1.3; 5.2)
Bartali, 2008^177^ | Invecchiare in Chianti (InCHIANTI) | >65 | 698 | Vitamin E, 1.1 μg/mL, lowest vs. the highest quartile | Adjusted for age, sex, educational achievement, marital status, household composition, smoking, physical activity, number of diseases, BMI, Depression Scale, and Mini-Mental State Examination | OR 1.62 (1.11; 2.36)
Bartali, 2008^177^ | Invecchiare in Chianti (InCHIANTI) | >65 | 698 | Vitamin B12, 275 pg/mL, lowest vs. the highest quartile | Adjusted for age, sex, educational achievement, marital status, household composition, smoking, physical activity, number of diseases, BMI, Depression Scale, and Mini-Mental State Examination | OR 1.03 (0.71; 1.5)
Bartali, 2008^177^ | Invecchiare in Chianti (InCHIANTI) | >65 | 698 | Vitamin B6, 4.35 ng/mL, lowest vs. the highest quartile | Adjusted for age, sex, educational achievement, marital status, household composition, smoking, physical activity, number of diseases, BMI, Depression Scale, and Mini-Mental State Examination | OR 1.04 (0.71; 1.53)
Bartali, 2008^177^ | Invecchiare in Chianti (InCHIANTI) | >65 | 698 | Folic acid, 1.9 ng/mL, lowest vs. the highest quartile | Adjusted for age, sex, educational achievement, marital status, household composition, smoking, physical activity, number of diseases, BMI, Depression Scale, and Mini-Mental State Examination | OR 0.72 (0.49; 1.03)
Bartali, 2008^177^ | Invecchiare in Chianti (InCHIANTI) | >65 | 698 | Vitamin D, 305 ng/mL, lowest vs. the highest quartile | Adjusted for age, sex, educational achievement, marital status, household composition, smoking, physical activity, number of diseases, BMI, Depression Scale, and Mini-Mental State Examination | OR 0.92 (0.63; 1.36)
Bartali, 2008^177^ | Invecchiare in Chianti (InCHIANTI) | >65 | 698 | Iron, 55 μg/dL, lowest vs. the highest quartile | Adjusted for age, sex, educational achievement, marital status, household composition, smoking, physical activity, number of diseases, BMI, Depression Scale, and Mini-Mental State Examination | OR 1.1 (0.77; 1.59)
Mortality
Albumin levels (g/L)
Raynaud-Simon, 2002^167^ | PAQUID research program | >65 | 245 | <44.8 vs. 44.8–48.0 | Adjusted for Transthyretin, CRP, Orosomucoid, and BMI | RR 5.3 (0.2; 5.7), 2 years
Raynaud-Simon, 2002^167^ | PAQUID research program | >65 | 245 | <44.8 vs. 44.8–48.0 | Adjusted for Transthyretin, CRP, Orosomucoid, and BMI | RR 2.1 (1.1; 3.9), 6 years
Anemia
Semba, 2007^107^ | Women’s Health and Aging Study I | >65 | 688 | Anemia with nutritional deficiencies | Adjusted for age | HR 0.79 (0.29; 2.14)
Zakai, 2005^61^ | Cardiovascular Health Study | >65 | 5888 | Anemia | Adjusted for age, sex, and race, baseline cardiovascular disease, congestive heart failure, diabetes mellitus, pre-baseline cancer, ankle-arm index, self-reported health status (fair or poor), history of cigarette use, and forced vital capacity | RR 1.33 (1.15; 1.54)
BMI
Volpato, 2001^100^ | Women’s Health and Aging Study | ≥65 | 620 | <21.45 vs. 21.45–31.58 | Adjustment for age, smoking history, BMI, inflammatory markers and albumin | RR 2.03 (1.09; 3.77)
Raynaud-Simon, 2002^167^ | PAQUID research program | >65 | 245 | <22.8 vs. 22.8–27.3 | Adjusted for Transthyretin, CRP, Orosomucoid, and BMI | RR 0.7 (0.1; 3) 2 years
Raynaud-Simon, 2002^167^ | PAQUID research program | >65 | 245 | <22.8 vs. 22.8–27.3 | Adjusted for Transthyretin, CRP, Orosomucoid, and BMI | RR 2.3 (1.3; 4.4) 6 years
Rakowski, 1992^361^ | Longitudinal Study of Aging | >70 | 1391 | lowest vs. highest quintile | Crude | OR 2.17 (1.03; 4.55)
Not intentional weight loss
Newman, 2001^64^ | Cardiovascular Study Research Group | >65 | 4718 | Weight loss of 5% | Adjusted for age in years, gender, race, digital symbol score, number of medications, gastrointestinal disease, log of pack years of smoking, waist circumference, and mobility-impairment | HR 1.67 (1.29; 2.15)
Composite nutritional score
Beck, 1999^157^ | Danish part of ‘Survey in Europe of Nutrition in the Elderly, a Concerted Action’ (SENECA) | >73 | 202 | MNA nutritional score (<23.5 vs. >24) | Adjusted for age and smoking status | RR 2.86 (1.52; 5.56)
Visvanathan, 2003^141^ | Domiciliary care services for elderly people with moderate or severe functional limitations | >67 | 250 | MNA <24 | Adjusted for age and living status | RR 1.02 (0.44; 2.38) 1 year
Beck, 1999^157^ | Danish part of ‘Survey in Europe of Nutrition in the Elderly, a Concerted Action’ (SENECA) | >73 | 202 | High nutritional risk by NSI Checklist score | Adjusted for age and smoking status | RR 1.45 (0.78; 2.71)
Transthyretin, mg/L
Raynaud-Simon, 2002^167^ | PAQUID research program | >65 | 245 | <258 vs. 258–316 | Adjusted for Transthyretin, CRP, Orosomucoid, and BMI | RR 2.8 (0.7; 10.7) 2 years
Raynaud-Simon, 2002^167^ | PAQUID research program | >65 | 245 | >316 vs. 258–316 | Adjusted for Transthyretin, CRP, Orosomucoid, and BMI | RR 6.6 (1.7; 25.9) 2 years
Raynaud-Simon, 2002^167^ | PAQUID research program | >65 | 245 | <258 vs. 258–316 | Adjusted for Transthyretin, CRP, Orosomucoid, and BMI | RR 1.4 (0.7; 2.6) 6 years
Raynaud-Simon, 2002^167^ | PAQUID research program | >65 | 245 | >316 vs. 258–316 | Adjusted for Transthyretin, CRP, Orosomucoid, and BMI | RR 2.6 (1.4; 5) 6 years
Orosomucoid, g/L
Raynaud-Simon, 2002^167^ | The PAQUID research program | >65 | 245 | <0.68 vs. 0.68–0.88 | Adjusted for Transthyretin, CRP, | RR 0.6 (0.1; 3.9) 2 years; RR 0.5 (0.2; 1.1) 6 years
Raynaud-Simon, 2002^167^ | The PAQUID research program | >65 | 245 | >0.88 vs. 0.68–0.88 | Orosomucoid, and BMI | RR 7.4 (2.2; 24.6) 2 years; RR 2.9 (1; 3.4) 6 years
Raynaud-Simon, 2002^167^ | The PAQUID research program | >65 | 245 | >0.88 vs. 0.68–0.88 | Adjusted for Transthyretin, CRP, Orosomucoid, and BMI, functional status (ADL and IADL), cognitive function (MMSE), and depression (CES-D) | RR 6.1 (1.7; 22.2) 2 years
Raynaud-Simon, 2002^167^ | The PAQUID research program | >65 | 245 | >0.88 vs. 0.68–0.88 | Adjusted for Transthyretin, CRP, Orosomucoid, and BMI, functional status (ADL and IADL), cognitive function (MMSE), and depression (CES-D) | RR 1.7 (0.9; 3.2) 6 years
Raynaud-Simon, 2002^167^ | The PAQUID research program | >65 | 245 | >1 g/L | Adjusted for Transthyretin, CRP, Orosomucoid, and BMI, functional status (ADL and IADL), cognitive function (MMSE), and depression (CES-D) | RR 12.3 (4.3; 35) 2 years
Raynaud-Simon, 2002^167^ | The PAQUID research program | >65 | 245 | >1 g/L | Adjusted for Transthyretin, CRP, Orosomucoid, and BMI, functional status (ADL and IADL), cognitive function (MMSE), and depression (CES-D) | RR 4.4 (2.3; 8.5) 6 years
Vitamin D
Semba, 2009^105^ | Women’s Health and Aging Studies (WHAS) I and II, 2 | >70 | 714 | 25 (OH)D <15.3 vs. >27 | Age, race, education, season, BMI, smoking, supplement use, physical activity, total cholesterol, HDL cholesterol, and chronic diseases | HR 2.45 (1.12; 5.36)
Visser, 2006^196^ | Longitudinal Aging Study Amsterdam (1995–1996) | >65 | 1260 | 25 (OH)D: <25 nmol/L vs. >75 nmol/L | Adjusted for sex, age, and education; model, for chronic diseases, serum creatinine concentration, cognitive status, and depressive symptoms, BMI, smoking status, alcohol consumption, and physical activity, mobility performance, low serum albumin concentration, and low serum total cholesterol concentration | HR 1.28 (0.85; 1.92)
Visser, 2006^196^ | Longitudinal Aging Study Amsterdam (1995–1996) | >65 | 1260 | 25 (OH)D: 25–49.9 nmol/L vs. >75 nmol/L | | HR 1 (0.72; 1.4)
Red cell distribution width
Patel, 2010^46^ | InCHIANTI Study, NHANES III, and WHAS I;the Health ABC Study; the East Boston, Iowa, and New Haven sites of the EPESE | >65 | 11,827 | Red cell distribution width, 1% increment | Adjusted for age, sex, race, education level, smoking history, and body mass index, age-associated medical conditions (cancer, diabetes, heart attack, hypertension, and stroke | HR 1.14 (1.11; 1.17)
Patel, 2010^46^ | InCHIANTI Study, NHANES III, and WHAS I;the Health ABC Study; the East Boston, Iowa, and New Haven sites of the EPESE | No major age-associated diseases | 11,827 | Red cell distribution width, 1% increment | Adjusted for age, sex, race, education level, smoking history, and body mass index, age-associated medical conditions (cancer, diabetes, heart attack, hypertension, and stroke | HR 1.32 (1.21; 1.44)
Patel, 2010^46^ | InCHIANTI Study, NHANES III, and WHAS I;the Health ABC Study; the East Boston, Iowa, and New Haven sites of the EPESE | Iron, folate, and/or vitamin B12 deficiencies | 11,827 | Red cell distribution width, 1% increment | Adjusted for age, sex, race, education level, smoking history, and body mass index, age-associated medical conditions (cancer, diabetes, heart attack, hypertension, and stroke | HR 1.16 (1.09; 1.24)
Patel, 2010^46^ | InCHIANTI Study, NHANES III, and WHAS I;the Health ABC Study; the East Boston, Iowa, and New Haven sites of the EPESE | | 11,827 | RDW of 14.0%–14.9% | Adjusted for age, sex, race, education level, smoking history, and body mass index, age-associated medical conditions (cancer, diabetes, heart attack, hypertension, and stroke | HR 1.77 (1.53; 2.04)
Patel, 2010^46^ | InCHIANTI Study, NHANES III, and WHAS I;the Health ABC Study; the East Boston, Iowa, and New Haven sites of the EPESE | | 11,827 | RDW >14.9% | Adjusted for age, sex, race, education level, smoking history, and body mass index, age-associated medical conditions (cancer, diabetes, heart attack, hypertension, and stroke | HR 2.51 (2.16; 2.91)
Patel, 2010^46^ | InCHIANTI Study, NHANES III, and WHAS I;the Health ABC Study; the East Boston, Iowa, and New Haven sites of the EPESE | 65–74 | 11,827 | Red cell distribution width, 1% increment | Adjusted for age, sex, race, education level, smoking history, and body mass index, age-associated medical conditions (cancer, diabetes, heart attack, hypertension, and stroke | HR 1.25 (1.22; 1.3)
Patel, 2010^46^ | InCHIANTI Study, NHANES III, and WHAS I;the Health ABC Study; the East Boston, Iowa, and New Haven sites of the EPESE | 75–84 | 11,827 | Red cell distribution width, 1% increment | Adjusted for age, sex, race, education level, smoking history, and body mass index, age-associated medical conditions (cancer, diabetes, heart attack, hypertension, and stroke | HR 1.16 (1.13; 1.19)
Patel, 2010^46^ | InCHIANTI Study, NHANES III, and WHAS I;the Health ABC Study; the East Boston, Iowa, and New Haven sites of the EPESE | >85 | 11,827 | Red cell distribution width, 1% increment | Adjusted for age, sex, race, education level, smoking history, and body mass index, age-associated medical conditions (cancer, diabetes, heart attack, hypertension, and stroke | HR 1.16 (1.112; 1.21)
Patel, 2010^46^ | InCHIANTI Study, NHANES III, and WHAS I;the Health ABC Study; the East Boston, Iowa, and New Haven sites of the EPESE | male | 11,827 | Red cell distribution width, 1% increment | Adjusted for age, sex, race, education level, smoking history, and body mass index, age-associated medical conditions (cancer, diabetes, heart attack, hypertension, and stroke | HR 1.21 (1.175; 1.24)
Patel, 2010^46^ | InCHIANTI Study, NHANES III, and WHAS I;the Health ABC Study; the East Boston, Iowa, and New Haven sites of the EPESE | female | 11,827 | Red cell distribution width, 1% increment | Adjusted for age, sex, race, education level, smoking history, and body mass index, age-associated medical conditions (cancer, diabetes, heart attack, hypertension, and stroke | HR 1.16 (1.13; 1.19)
Patel, 2010^46^ | InCHIANTI Study, NHANES III, and WHAS I;the Health ABC Study; the East Boston, Iowa, and New Haven sites of the EPESE | African American | 11,827 | Red cell distribution width, 1% increment | Adjusted for age, sex, race, education level, smoking history, and body mass index, age-associated medical conditions (cancer, diabetes, heart attack, hypertension, and stroke | HR 1.13 (1.1; 1.18)
Patel, 2010^46^ | InCHIANTI Study, NHANES III, and WHAS I;the Health ABC Study; the East Boston, Iowa, and New Haven sites of the EPESE | Caucasian | 11,827 | Red cell distribution width, 1% increment | Adjusted for age, sex, race, education level, smoking history, and body mass index, age-associated medical conditions (cancer, diabetes, heart attack, hypertension, and stroke | HR 1.19 (1.16; 1.212)
Patel, 2010^46^ | InCHIANTI Study, NHANES III, and WHAS I;the Health ABC Study; the East Boston, Iowa, and New Haven sites of the EPESE | BMI <18.5 | 11,827 | Red cell distribution width, 1% increment | Adjusted for age, sex, race, education level, smoking history, and body mass index, age-associated medical conditions (cancer, diabetes, heart attack, hypertension, and stroke | HR 1.15 (1.035; 1.23)
Treatment utilization among those with high risk of undernutrition and malnutrition MNA <26
Visvanathan, 2003^141^ | Domiciliary care services for elderly people with moderate or severe functional limitations | >67, 250 elderly | Needing any form of admission | | Adjusted for Age and Living Status | RR 1.51 (1.07; 2.14)
Visvanathan, 2003^141^ | Domiciliary care services for elderly people with moderate or severe functional limitations | >67, 250 elderly | Needing emergency admission | | Adjusted for Age and Living Status | RR 1.94 (1.24; 3.03)
Visvanathan, 2003^141^ | Domiciliary care services for elderly people with moderate or severe functional limitations | >67, 250 elderly | Requiring >2 admissions | | Adjusted for Age and Living Status | RR 2.17 (1.05; 4.44)
Visvanathan, 2003^141^ | Domiciliary care services for elderly people with moderate or severe functional limitations | >67, 250 elderly | Requiring >2 emergency admissions | | Adjusted for Age and Living Status | RR 2.96 (1.15; 7.59)
Visvanathan, 2003^141^ | Domiciliary care services for elderly people with moderate or severe functional limitations | >67, 250 elderly | Spending >4 weeks in the hospital | | Adjusted for Age and Living Status | RR 3.22 (1.29; 8.07)

Bold=significant association at 95% confidence limit.

Appendix E Table 44 Association Between Sex-Specific Early and Late Mortality and Malnutrition and Inflammation Biomarkers in Older Persons: Pathologies Oculaires Liées à l’Age Cohort168

Reference | Study | Age, Sample, Adjustment | Gender | Mortality | Exposure Definition | Hazard Ratio (95% CI)
Albumin, g/L
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Males | Early Death (5 years after baseline) | <39.44 vs. 39.44–44.77 | 2.72 (1.44; 5.14)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Females | | <39.44 vs. 39.44–44.77 | 1.37 (0.7; 2.7)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Males | Late Death (Between 5 and 9 years after baseline) | <39.44 vs. 39.44–44.77 | 1.13 (0.61; 2.11)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Females | Late Death (Between 5 and 9 years after baseline) | <39.44 vs. 39.44–44.77 | 0.84 (0.48; 1.48)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Alpha 1-acid glycoprotein, g/L
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Males | Early Death | highest quartile and Transthyretin, lowest quartile | 6.86 (3.2; 14.71)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Females | Early Death | highest quartile and Transthyretin, lowest quartile | 4.64 (1.79; 12.05)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Males | Early Death | <0.64 vs. 0.64–0.89 | 1.03 (0.47; 2.28)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Females | | <0.64 vs. 0.64–0.89 | 1.99 (0.95; 4.16)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Males | Late Death | <0.64 vs. 0.64–0.89 | 0.38 (0.16; 0.92)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Females | | <0.64 vs. 0.64–0.89 | 0.68 (0.36; 1.29)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Males | Early Death | >0.90 vs. 0.64–0.90 | 2.26 (1.19; 4.31)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Females | Early Death | >0.90 vs. 0.64–0.90 | 2.61 (1.27; 5.35)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Males | Late Death | >0.90 vs. 0.64–0.90 | 1.44 (0.82; 2.53)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Females | Late Death | >0.90 vs. 0.64–0.90 | 1.1 (0.6; 2.02)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Transthyretin, g/L
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Males | Early Death | <0.24 vs. 0.24–0.29 | 2.23 (1.21; 4.13)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Females | Early Death | <0.24 vs. 0.24–0.29 | 2.39 (1.24; 4.58)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Males | Late Death | <0.24 vs. 0.24–0.29 | 1.17 (0.64; 2.17)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Females | Late Death | <0.24 vs. 0.24–0.29 | 1.36 (0.77; 2.38)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Males | Early Death | >0.30 vs. 0.24–0.30 | 0.39 (0.13; 1.16)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Females | Early Death | >0.30 vs. 0.24–0.30 | 0.97 (0.41; 2.33)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Males | Late Death | >0.30 vs. 0.24–0.30 | 0.89 (0.47; 1.68)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Females | Late Death | >0.30 vs. 0.24–0.30 | 1.04 (0.52; 2.1)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Prognostic inflammatory and nutritional index
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Males | Early Death | <0.052 vs. 0.052–0.265 | 0.66 (0.27; 1.58)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Females | Early Death | <0.052 vs. 0.052–0.265 | 1.28 (0.61; 2.68)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Males | Late Death | <0.052 vs. 0.052–0.265 | 0.53 (0.23; 1.23)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Females | Late Death | <0.052 vs. 0.052–0.265 | 0.78 (0.39; 1.56)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Males | Early Death | >0.266 vs. 0.052–0.266 | 2.13 (1.15; 3.95)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Females | Early Death | >0.266 vs. 0.052–0.266 | 1.33 (0.66; 2.68)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | >60, 1,441 Adjusted for age, educational level, perceived health, and smoking | Males | Late Death | >0.266 vs. 0.052–0.266 | 2.5 (1.44; 4.36)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | | Females | Late Death | >0.266 vs. 0.052–0.266 | 1.25 (0.72; 2.18)

Bold=significant association at 95% confidence limit.

Appendix E Figure 7 Association Between Chronic Inflammation Biomarkers and Cognitive Decline in Older Persons: Health, Aging, and Body Composition Study77

*After adjustment for age, education, race, sex, smoking, alcohol use, body mass index, self-reported health, CES-D score (depression), comorbidities (myocardial infarction, diabetes mellitus, hypertension, and stroke), use of NSAIDs, use of estrogen for women, and baseline cognitive test score.

Appendix E Figure 8 Association Between Chronic Inflammation and Sarcopenia (Muscle Strength Loss) in in Older Persons: Longitudinal Aging Study Amsterdam195

*After controlling for age, sex, education level, smoking status, number of chronic diseases, alcohol use, physical activity, anti-inflammatory drug use, body mass index (or total body fat when available), cognitive impairment, and depressive symptoms.

Appendix E Figure 9 Association Between Chronic Inflammation and Disability in Older Women: Women’s Health and Aging Study I101

*After controlling for age, education, race, smoking status, BMI, estrogen use, corticosteroid use, and chronic conditions.

Appendix E Figure 10 Association Between Chronic Inflammation and Frailty in Older Women: Women’s Health and Aging Studies I and II98,109

*After controlling for age, history of smoking, BMI >25 kg/m^2^, number of chronic diseases, and markers for socioeconomic status.

Appendix Figure E10 is a forest plot diagram depicting the association between chronic inflammation and frailty in older women after controlling for age, history of smoking, body mass index greater than 25 kg/m2, number of chronic diseases, and markers for socioeconomic status as reported in the Women’s Health and Aging Studies I and II. The plot has two columns. The left-hand column lists the definitions of increased biomarkers of chronic inflammation in prefrail or frail older women. The right-hand column is a plot of odds ratios of frailty with 95% CI. Means of odds ratios are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between elevated levels of biomarkers and frailty is also plotted. If the confidence intervals do not overlap with this line, it demonstrates a significant association between inflammation and frailty. Older women with elevated IL6 had increased odds of frailty (OR 2.0, 95 percent CI 1.1; 3.6).

Appendix E Figure 11 Association Between Elevated Inflammatory Biomarkers (CRP and IL6) and Mortality in Older Persons21,24,82,193

Appendix Figure E11 is a forest plot diagram depicting the association between elevated inflammatory markers (CRP and IL 6) and mortality in older adults. The plot has two columns. The left-hand column lists the individual studies that examined the association between elevated inflammatory markers (CRP and IL 6) and mortality in older adults. The right-hand column is a plot of relative measures of the association between inflammation and mortality with 95% CI. Means of the effect are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between elevated levels of biomarkers and mortality is also plotted. If the confidence intervals do not overlap with this line, it demonstrates a significant association between inflammation and mortality. The diamond represents a pooled estimate from random effects model with 95%CI. Older females with elevated levels of two markers, IL6 and CRP, did not have a higher risk of death. However, older males with chronic inflammation had a higher risk of death (RR 2.8, 95 percent CI 1.4; 5.5).

Appendix E Figure 12 Association Between Inflammatory Indexes and Mortality in Older Persons21,193

Appendix Figure E12 is a forest plot diagram depicting the association between inflammatory indexes and mortality in older adults. The plot has two columns. The left-hand column lists the definitions of elevated inflammatory indexes in older adults. The right-hand column is a plot of relative measures of the association between inflammation indexes mortality with 95%CI. Means of the effect are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between elevated levels inflammatory indexes and mortality is also plotted. If the confidence intervals do not overlap with this line, it demonstrates a significant association between inflammation and mortality. The association between chronic inflammation and mortality differed across studies depending on the markers and populations. A composite inflammatory index was not associated with morality in the MacArthur Studies of Successful Aging or in the Leiden 85-Plus Study. Only older people with a low proinflammatory marker (IL-1) and a low anti-inflammatory marker (IL10) had a higher risk of death (RR 2.2, 95% CI 1.3; 3.8).

Appendix E Figure 13 Association Between Elevated Interleukin-6 and Mortality in Older Persons82,100,101

Appendix Figure E13 is a forest plot diagram depicting the association between elevated interleukin 6 (IL6) and mortality in elderly men or women. The plot has two columns. The left-hand column lists individual studies and the definitions of elevated inflammatory markers in older adults. The right-hand column is a plot of relative measures of the association between elevated inflammatory markers and mortality with 95% CI. Means of the effect are presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect between elevated levels inflammatory markers and mortality is also plotted. If the confidence intervals do not overlap with this line, it demonstrates a significant association between inflammatory markers and mortality. The association differed among men and women. Elevated IL6 was associated with increased mortality in women but not in men.

Appendix E Table 45 Association Between C-Reactive Protein and Mortality in Older Persons

Reference | Study | Adjustment | Age | Definition of exposure | Estimate | Mean (95% CI)
Women
Harris, 1999^82^ | Iowa 65+ Rural Health Study | Adjusted for age, sex, prevalent cardiovascular disease, diabetes, BMI | >65 | High C-reactive protein levels only (C-reactive protein >2.78 mg/L and interleukin-6<3.19 pg/mL) | Relative Risk | 0.3 (0.1; 1.2)
Volpato, 2001^100^ | Women’s Health and Aging Study | Adjusted for age, smoking history, BMI, inflammatory markers and albumin | ≥65 | CRP, mg/L 2.1–7.4 vs. <2 | Relative Risk | 1.16 (0.64; 2.1)
Volpato, 2001^100^ | Women’s Health and Aging Study | Adjusted for age, smoking history, BMI, inflammatory markers and albumin | ≥65 | CRP, mg/L >7.5 vs. <2 | Relative Risk | 1.65 (0.93; 2.9)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | Adjusted for age, educational level, perceived health, and smoking | >60 | C-reactive protein, mg/L < 0.86 vs. 0.86–3.30 | Hazard Ratio | 1.45 (0.7; 3.04)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | Adjusted for age, educational level, perceived health, and smoking | >60 | C-reactive protein, mg/L >3.31 vs. 0.86–3.30 | Hazard Ratio | 1.32 (0.65; 2.69)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | Adjusted for age, educational level, perceived health, and smoking | >60 | C-reactive protein, mg/L 0.86 vs. 0.86–3.30 | Hazard Ratio | 0.82 (0.42; 1.59)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | Adjusted for age, educational level, perceived health, and smoking | >60 | C-reactive protein, mg/L 3.31 vs. 0.86–3.30 | Hazard Ratio | 1.05 (0.6; 1.85)
Men
Harris, 1999^82^ | Iowa 65+ Rural Health Study | Adjusted for age, sex, prevalent cardiovascular disease, diabetes, body mass index | >65 | High C-reactive protein levels (C- reactive protein >2.78 mg/L) | Relative Risk | 1.5 (0.7; 3.2)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | Adjusted for age, educational level, perceived health, and smoking | >60 | C-reactive protein, mg/L <0.86 vs. 0.86–3.30 | Hazard Ratio | 0.7 (0.31; 1.63)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | Adjusted for age, educational level, perceived health, and smoking | >60 | C-reactive protein, mg/L >3.31 vs. 0.86–3.30 | Hazard Ratio | 2.15 (1.14; 4.02)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | Adjusted for age, educational level, perceived health, and smoking | >60 | C-reactive protein, mg/L <0.86 vs. 0.86–3.30 | Hazard Ratio | 0.6 (0.27; 1.33)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | Adjusted for age, educational level, perceived health, and smoking | >60 | C-reactive protein, mg/L >3.31 vs. 0.86–3.30 | Hazard Ratio | 2.37 (1.36; 4.15)
All elderly
Raynaud-Simon, 2002^167^ | PAQUID research program | Adjusted for Transthyretin, CRP, Orosomucoid, and BMI | >65 | CRP (mg/L) >15 vs. <15 | Relative Risk | 0.2 (0.1; 9.2)
Bruunsgaard, 2003^158^ | Danish Centenarian Study | Crude | >100 | C-reactive protein increase by SD in log scale | Hazard Ratio | 1.26 (1.03; 1.53)
Cao, 2007^58^ | Cardiovascular Health Study | Adjusted for age, sex, race, systolic and diastolic blood pressure, use of antihypertensive medications, BMI, smoking (never, former, current), and amount smoked (in pack-years), high-density lipoprotein and low-density lipoprotein cholesterol, diabetes (none, impaired fasting glucose, diabetes), plaque risk group, and carotid wall thickness | >95 | CRP >3 mg/L | Hazard Ratio | 1.38 (1.25; 1.53)
Seeman, 2004^21^ | MacArthur Studies of Successful Aging | Adjusted for age, gender, ethnicity | >70 | High C-reactive protein | Odds Ratio | 1.67 (1.1; 2.55)
Harris, 1999^82^ | Iowa 65+ Rural Health Study | Adjustment for age, sex, BMI, and history of smoking, diabetes, and cardiovascular disease, as well as known indicators of inflammation including fibrinogen and albumin levels and white blood cell count | >65 | C-reactive protein-the highest quartile ≥2.78 mg/L) vs. the lowest quartile | Relative Risk | 1.6 (1; 2.6)
Alley, 2007^178^ | Invecchiare in Chianti Study | Adjusted for inflammatory markers, age, sex, education, and health behaviors (alcohol intake, smoking in pack-years, low physical activity) at baseline, and covariates at follow-up: high waist circumference, high blood pressure, low high-density lipoprotein cholesterol, high low-density lipoprotein cholesterol, high triglycerides, hospital stay in previous year, liver disease, coronary heart disease, diabetes mellitus, depression, cancer | >65 | baseline CRP >3.0 mg/L | Odds Ratio | 1.98 (0.8; 4.86)
Alley, 2007^178^ | Invecchiare in Chianti Study | | >65 | Followup CRP >3.0 mg/L | Odds Ratio | 2.06 (0.81; 5.23)
Alley, 2007^178^ | Invecchiare in Chianti Study | | >65 | CRP increase | Odds Ratio | 3.1 (1.25; 7.68)
Pizzarelli, 2009^179^ | Invecchiare in Chianti Study | Adjusted for age, gender, cholesterol, physical activity, stroke, congestive heart failure, and renal function | >65 | CRP increase | Hazard Ratio | 1.01 (1; 1.02)

Appendix E Table 46 Association Between Inflammatory Biomarkers and Mortality in Older Persons

Reference | Study | Adjustment | Age | Outcome | Exposure | Estimate | Mean (95% CI)
Seeman, 2004^21^ | MacArthur Studies of Successful Aging | Adjusted for age, gender, ethnicity | >70 | 7.5-year mortality | High fibrinogen | Odds Ratio | 1.28 (0.83; 1.99)
Wikby, 2005^192^ | NONA Immune Study | Crude | >85 | Mortality | CD4/CD8 ratio > vs. <1 | Odds Ratio
Cohen, 2003^9^ | Duke Established Populations for Epidemiologic Studies of the Elderly | Adjusted for age; sex; race; current and past smoking; BMI; baseline cancer, stroke, diabetes, or myocardial infarction; and baseline functional status | >65 | 5-year Mortality | High D-dimer levels only | Relative Risk | 1.53 (1.18; 1.97)
Cohen, 2003^9^ | Duke Established Populations for Epidemiologic Studies of the Elderly | Adjusted for age; sex; race; current and past smoking; BMI; baseline cancer, stroke, diabetes, or myocardial infarction; and baseline functional status | >65 | 5-year Mortality | Log D-dimer | Relative Risk | 1.74 (1.31; 2.31)
Bruunsgaard, 2003^158^ | Danish Centenarian Study | Adjusted for dementia, cardiovascular diseases, and an interaction between soluble TNF receptor-II and dementia | >100 | Mortality | Soluble TNF receptor-II ng/mL per SD | Hazard Ratio | 1.36 (1.1; 1.67)
Bruunsgaard, 2003^158^ | Danish Centenarian Study | Adjusted for dementia, cardiovascular diseases, and an interaction between soluble TNF receptor-II and dementia | >100 | Mortality | Soluble TNF receptor-II | Hazard Ratio | 1.41 (1.06; 1.88)
Bruunsgaard, 2003^158^ | Danish Centenarian Study | Adjusted for dementia, cardiovascular diseases, and an interaction between soluble TNF receptor-II and dementia | >100 | Mortality | TNF-alpha pg/mL (per SD) | Hazard Ratio | 1.54 (1.04; 2.27)
Bruunsgaard, 2003^158^ | Danish Centenarian Study | Adjusted for dementia, cardiovascular diseases, and an interaction between soluble TNF receptor-II and dementia | >100 | Mortality | TNF-alpha increase by SD in log scale | Hazard Ratio | 1.34 (1.12; 1.6)
Cohen, 2003^9^ | Duke Established Populations for Epidemiologic Studies of the Elderly | Adjusted for age; sex; race; current and past smoking; BMI; baseline cancer, stroke, diabetes, or myocardial infarction; and baseline functional status | >65 | 5-year Mortality | High interleukin-6 and D-dimer levels | Relative Risk | 2 (1.53; 2.62)
Carriere, 2008^168^ | Pathologies Oculaires Liées à l’Age Study | Adjusted for age, educational level, perceived health, and smoking | >60 | Early Death (5 years after baseline) | CRP, the highest quartile and albumin, the lowest quartile | Hazard Ratio | 4.98 (2.25; 11.01)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Early death | Highest quartile of fibrinogen and CRP in men (4th quartile for CRP: ≥3.42μg/ml and for fibrinogen ≥362mg/dl) compared to those in lowest quartile | Hazard Ratio | 9.56 (4.34; 21.1)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Early death | Highest quartile of fibrinogen and CRP in men aged 65–73 years at baseline(4th quartile for CRP: ≥3.42μg/ml and for fibrinogen ≥362mg/dl) compared to those in lowest quartile | | 4.82 (1.6; 14.5)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Early death | Highest quartile of fibrinogen and CRP in men aged ≥74 years at baseline (4th quartile for CRP: ≥3.42μg/ml and for fibrinogen ≥362mg/dl) compared to those in lowest quartile | | 14.33 (4.42; 46.52)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Early death | Highest quartile of fibrinogen and CRP in women (4th quartile for CRP: ≥3.42μg/ml and for fibrinogen ≥362mg/dl) compared to those in lowest quartile | | 1.5 (0.73; 3.1)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Early death | Highest quartile of fibrinogen and CRP in women aged ≤73 years at baseline (4th quartile for CRP: ≥3.42μg/ml and for fibrinogen ≥362mg/dl) compared to those in lowest quartile | | 1.31 (0.4; 4.34)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Early death | Highest quartile of fibrinogen and CRP in women aged ≥74 years at baseline (4th quartile for CRP: ≥3.42μg/ml and for fibrinogen ≥362mg/dl) compared to those in lowest quartile | | 1.25 (0.52; 3.02)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Early death | Fibrinogen in men: 1st Quartile (1st Quartile: ≤281mg/dl) | | 1
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Early death | Fibrinogen in men: 2nd Quartile (2nd Quartile: 282–311 mg/dl) | | 2.05 (1.27; 3.3)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Early death | Fibrinogen in men: 3rd Quartile (3rd quartile: 312–361 mg/dl) | | 2.76 (1.75; 4.35)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Early death | Fibrinogen in men: 4th Quartile (4th quartile:≥362mg/dl) | | 4.11 (2.66; 6.35)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Early death | Fibrinogen in women: 1st Quartile (1st Quartile: ≤281mg/dl) | | 1
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Early death | Fibrinogen in women: 2nd Quartile (2nd Quartile: 282–311 mg/dl) | | 0.95 (0.56; 1.61)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Early death | Fibrinogen in women: 3rd Quartile (3rd quartile: 312–361 mg/dl) | | 1.19 (0.73; 1.94)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Early death | Fibrinogen in women: 4th Quartile (4th quartile: ≥362mg/dl) | | 1.31 (0.79; 2.15)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Late death | Fibrinogen in men: 1st Quartile (1st Quartile: ≤281mg/dl) | | 1
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Late death | Fibrinogen in men: 2nd Quartile (2nd Quartile: 282–311 mg/dl) | | 1.01 (0.78; 1.3)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Late death | Fibrinogen in men: 3rd Quartile (3rd quartile: 312–361 mg/dl) | | 1.02 (0.79; 1.31)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Late death | Fibrinogen in men: 4th Quartile (4th quartile:≥362mg/dl) | | 1.39 (1.09; 1.77)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Late death | Fibrinogen in women: 1st Quartile (1st Quartile: ≤281mg/dl) | | 1
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Late death | Fibrinogen in women: 2nd Quartile (2nd Quartile: 282–311 mg/dl) | | 1.07 (0.81; 1.41)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Late death | Fibrinogen in women: 3rd Quartile (3rd quartile: 312–361 mg/dl) | | 0.86 (0.65; 1.15)
Jenny, 2007^63^ | Cardiovascular Health Study | Adjusted for age, cholesterol, BMI, systolic blood pressure, smoking, diabetes, race, and clinical and subclinical cardiovascular disease | ≥65 | Late death | Fibrinogen in women: 4th Quartile (4th quartile:≥362mg/dl) | | 1.14 (0.86; 1.51)
Jylha, 2007^164^ | Vitality 90+ Study | Adjusted for sex, CVD, diabetes, cancer, infections, HDL Cholesterol, MMSE Score, smoking, status, exercise, and education. | ≥90 years | 4-year mortality | IL-1ra tertiles(pg/mL): <312 | Hazard Ratio | 1
Jylha, 2007^164^ | Vitality 90+ Study | Adjusted for sex, CVD, diabetes, cancer, infections, HDL Cholesterol, MMSE Score, smoking, status, exercise, and education. | ≥90 years | 4-year mortality | IL-1ra tertiles (pg/mL): 312–454 | Hazard Ratio | 1.58 (0.95; 2.63)
Jylha, 2007^164^ | Vitality 90+ Study | Adjusted for sex, CVD, diabetes, cancer, infections, HDL Cholesterol, MMSE Score, smoking, status, exercise, and education. | ≥90 years | 4-year mortality | IL-1ra tertiles (pg/mL): >454 | Hazard Ratio | 2.12 (1.24; 3.62)
Jylha, 2007^164^ | Vitality 90+ Study | Adjusted for sex, CVD, diabetes, cancer, infections, HDL Cholesterol, MMSE Score, smoking, status, exercise, and education. | ≥90 years | 4-year mortality | IL-6 tertiles (pg/mL): <1.97 | Hazard Ratio | 1
Jylha, 2007^164^ | Vitality 90+ Study | Adjusted for sex, CVD, diabetes, cancer, infections, HDL Cholesterol, MMSE Score, smoking, status, exercise, and education. | ≥90 years | 4-year mortality | IL-6 tertiles (pg/mL): 1.97–3.8 | Hazard Ratio | 1.13 (0.7; 1.18)
Jylha, 2007^164^ | Vitality 90+ Study | Adjusted for sex, CVD, diabetes, cancer, infections, HDL Cholesterol, MMSE Score, smoking, status, exercise, and education. | ≥90 years | 4-year mortality | IL-6 tertiles (pg/mL): >3.8 | Hazard Ratio | 1.2 (0.74; 1.19)

Appendix E Table 47 Statistical Models That Predict Mortality in Older Persons Based on Geriatric Syndromes or Nonsyndromic Conditions

Reference Purpose | Predictor Name | Category | Index/Measurement Used
Drame, 2008{Drame, 2008 #2310; 1. for baseline descriptive analysis of all the patients in both derivation and validation cohorts;; 2. enter into bivariable model to study the association between each predictor and mortality in the derivation cohort;; 3. enter into multivariable model if they are significant (p<0.2) to identify components of the mortality risk index | Drame, 2008{Drame, 2008 #2310 Age | 75–84; 85 and over
| Gender | Female; Male
| Living location | Private home; Institution
| Education level | Primary; Secondary; University
| Dependence on the ADL | No; Yes | Katz’s index
| Delirium | No; Yes | DSM-IV criteria: Disturbance of consciousness (defined by Folstein’s Mini-Mental State Examination score of 24 or less); change in cognition; development over a short period of time.
| Malnutrition risk | No ; Yes | Mini Nutritional Assessment short form score of less than 12.
| Pressure sore risk | No ; Yes | Norton’s scale score of 14 or less
| Walking difficulties | No ; Yes | Timed Get-up and Go Test
| Mood disorders or depression risk | No ; Yes | Schwab and Gilleard’s scale of score greater than 14
| Gait and balance difficulties | No ; Yes | One-Leg Standing Balance Test
| Comorbidity level | Low (0 or 1) | Charlson comorbidity index
| Comorbidity level | Medium (2 to 4)
| Comorbidity level | High 5 or more)
| Recent hospitalization (within 3 months) | No ; Yes
| Day of admission | Weekday; Weekend
Ensrud, 2008^50^; 1. to compare characteristics of participants at the 4^th^ examination by category of frailty according to the Study of Osteoporotic Fractures (SOF) index;; 2. to identify components of the Study of Osteoporotic Fractures index | Age | By year
| Health status | Excellent or good; | Self reported
| | Fair
| | Poor or very poor
| Smoking status | Current; former; never
| Current estrogen use
| Fracture since age 50
| Falls in previous year
| Intent to lose weight
| Educational achievement
| Selected medical conditions | None | Stroke; cancer(except skin cancer); dementia; hypertension; parkinsonism; Diabetes mellitus; coronary heart disease; chronic obstructive lung disease
| Selected medical conditions | 1–2 | Stroke; cancer(except skin cancer); dementia; hypertension; parkinsonism; Diabetes mellitus; coronary heart disease; chronic obstructive lung disease
| Selected medical conditions | >=3 | Stroke; cancer(except skin cancer); dementia; hypertension; parkinsonism; Diabetes mellitus; coronary heart disease; chronic obstructive lung disease
| Physical activity | Weighted score of kilocalories | Modified version of Harvard Alumni Questionnaire
| Physical activity | Expended per week
| Depressive symptoms | | 15-item Geriatric Depression Scale score 0–15
| Cognitive function | | Modified Mini-Mental State Examination score 0–26
| Functional disability | | Any of 5 instrumental activities of daily living
| Physical function | Grip strength | Handheld dynamometer
| Physical function | Walking speed | Time in seconds to walk 6 m at usual pace
| Physical function | One’s ability to rise from a chair 5
| Physical function | Times without using her arms
| Body weight | | Recorded by a balanced beam scale
| Height | | By a standard held-expiration technique with a wall-mounted stadiometer
| Bone mineral density of the femoral neck | | By dual-energy x-ray absorptiometry
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Age | <80
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Age | ≥80
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Gender | Women
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Gender | Men
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Education | >3 years
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Education | ≤3 years
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Living alone | No
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Living alone | Yes
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Current or former smoking | No
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Current or former smoking | Yes
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Physical inactivity | No | Defined as lack of adherence to the current exercise recommendation for older People (<4 hour/week of moderate intensity activity)
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Physical inactivity | Yes | Defined as lack of adherence to the current exercise recommendation for older People (<4 hour/week of moderate intensity activity)
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | ≥2 medical conditions | No | Hypertension; cardiovascular disease (history of myocardial infarct and congestive
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | ≥2 medical conditions | Yes | Heart failure); cerebrovascular disease (history of stroke or transient ischemic attack); Diabetes; chronic pulmonary disease; cancer and dementia
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Daily use of ≥3 drugs | No
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Daily use of ≥3 drugs | Yes
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Sensory deficits | No | Blindness or deafness
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Sensory deficits | Yes
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Calf circumference | <31cm;
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Calf circumference | ≥31cm
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Body mass index | ≥25
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Body mass index | <25
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Activity of daily living | No difficulty | Any difficulty with bathing, dressing, toileting, transferring, continence and feeding
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Activity of daily living | Any difficulty
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Instrumental activity of daily living | No difficulty | Any difficulty with using telephone, taking medicine, travelling and managing money
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Instrumental activity of daily living | Any difficulty
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Gait and balance | >24 | Tinetti gait and balance test score ≤24
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Gait and balance | ≤24
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Abnormal cognition | <24 | Mini Mental State Examination score<24
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Abnormal cognition | ≥24
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Depressive symptom | ≥10 | Geriatric depression scale score >=10
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Depressive symptom | <10
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Pessimism about one’s health | No; | Subjects were asked if they felt ’their health was worse than others’
Ravaglia, 2008^362^ Develop a frailty score including only self-reported information and easy-to-perform standardized measurements recommended in routine geriatric practice | Pessimism about one’s health | Yes | Subjects were asked if they felt ’their health was worse than others’
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Age | <75;
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Age | 75–79;
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Age | 80–84;
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Age | ≥85
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Female
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Ethnicity | White;
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Ethnicity | Black;
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Ethnicity | Hispanic;
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Ethnicity | Asian;
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Ethnicity | Other
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Education | <12 years;
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Education | ≥12 years
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Married
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Medical eligible
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Received caregiving assistance at home | Formal
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Received caregiving assistance at home | informal
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Activities of daily living (ADL) | Independent | ADL includes: bathing; toileting; transferring; eating; dressing; walking across a room;
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Activities of daily living (ADL) | Partially independent | Defined as independent if entire activity is performed without supervision all of the
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Activities of daily living (ADL) | Fully dependent | Time; defined as partially independent if patients required assistance from another. Person only some of the time or with only part of the task; defined as fully dependent if they required assistance for the entire activity all of the time.
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Instrumental activity of daily living (IADL) | Independent; | IADL includes: meal preparation; shopping; housework; laundry; heavy chores; managing money; taking medications; using transportation.
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Instrumental activity of daily living (IADL) | Dependent | Defined as dependence if requiring another person to complete every component of the task for the patient
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Impaired vision
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Impaired hearing
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Receptive or expressive
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Communication impairment
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Cognitive impairment | Moderate or severe | 10-points short portable mental status questionnaire (SPMSQ) of 6 or more errors is defined as moderate or severe cognitive impairment
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | | Other | 10-points short portable mental status questionnaire (SPMSQ) of 6 or more errors is defined as moderate or severe cognitive impairment
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Hospital admission | | Admission defined as within 6 months before enrollment
Carey, 2008^129^ Develop and validate a prognostic index for mortality in community-living, frail elderly people. | Comorbidity | | Comorbidity includes: anemia; recurrent pneumonia; renal insufficiency or failure; pressure ulcer; malignant neoplasm; diabetes mellitus; dementia; depression; cerebrovascular disease; coronary artery disease; congestive heart failure; chronic obstructive pulmonary disease; bowel or bladder incontinence; defined as comorbidities if they were active medical problems; if they were problems that were currently controlled using diet or medications; if they affected the management of the participant’s care
Pilotto, 2008^363^; 1. to develop a multidimensional prognostic index (MPI);; 2. to validate the MPI by comparing derivation cohort and validation cohort | Functional status | 0–2;3–4;5–6 | Activities of daily living (ADL) index
Pilotto, 2008^363^; 1. to develop a multidimensional prognostic index (MPI);; 2. to validate the MPI by comparing derivation cohort and validation cohort | Functional status | 0–3;4–5;6–8 | Instrumental activities of daily living (IADL) scale
Pilotto, 2008^363^; 1. to develop a multidimensional prognostic index (MPI);; 2. to validate the MPI by comparing derivation cohort and validation cohort | Cognitive status | 0–3;4–7;8–10 | Short Portable Mental Status Questionnaire (SPMSQ)
Pilotto, 2008^363^; 1. to develop a multidimensional prognostic index (MPI);; 2. to validate the MPI by comparing derivation cohort and validation cohort | Comorbidity | 0;1–2;>3 | Comorbidity index (CIRS-CI) derived from Cumulative Illness Rating Scale (CIRS)
Pilotto, 2008^363^; 1. to develop a multidimensional prognostic index (MPI);; 2. to validate the MPI by comparing derivation cohort and validation cohort | Nutritional status | <17;17–23.5;>=24 | Mini Nutritional Assessment (MNA)
Pilotto, 2008^363^; 1. to develop a multidimensional prognostic index (MPI);; 2. to validate the MPI by comparing derivation cohort and validation cohort | Pressure development | 5–9;10–15;16–20 | 5-item Exton Smith Scale (ESS)
Pilotto, 2008^363^; 1. to develop a multidimensional prognostic index (MPI);; 2. to validate the MPI by comparing derivation cohort and validation cohort | Medication use | 0–3;4–6;>7 | Number of medications
Pilotto, 2008^363^; 1. to develop a multidimensional prognostic index (MPI);; 2. to validate the MPI by comparing derivation cohort and validation cohort | Social aspects | Living with family | Social support network includes household composition, home services
Pilotto, 2008^363^; 1. to develop a multidimensional prognostic index (MPI);; 2. to validate the MPI by comparing derivation cohort and validation cohort | | Institutionalized
Pilotto, 2008^363^; 1. to develop a multidimensional prognostic index (MPI);; 2. to validate the MPI by comparing derivation cohort and validation cohort | | Living alone
Walter, 2001^125^; 1. for baseline descriptive analysis of all the patients in both derivation and validation cohorts;; 2. enter into bivariable model to study the association between each predictor and mortality in the derivation cohort;; 3. enter into multivariable model if they are significant (p<0.2) to identify components of the prognostic index. | Age | 70–74;75–79;80–84; 85–89;>=90 | 5-year interval
| Sex | Women; Men
| Race | White; Black
| Marital status | Married; not married
| Activities of daily living(ADL) dependency at discharge | Independent in all ADLs;
| Activities of daily living(ADL) dependency at discharge | Dependent in 1–4 ADLs;
| Activities of daily living(ADL) dependency at discharge | Dependent in all ADLs
| Comorbid conditions | Absent; | Conditions include: history of myocardial infarction; congestive heart failure; cerebrovascular disease; dementia; chronic obstructive pulmonary disease; diabetes mellitus
| Comorbid conditions | Present | Conditions include: history of myocardial infarction; congestive heart failure; cerebrovascular disease; dementia; chronic obstructive pulmonary disease; diabetes mellitus
| Comorbid conditions | | Conditions include: history of myocardial infarction; congestive heart failure; cerebrovascular disease; dementia; chronic obstructive pulmonary disease; diabetes mellitus
| Cancer | Absent
| Cancer | Solitary
| Cancer | Metastatic solid
| Length of hospital stay | 1–7 days; >7days
| Discharge destination | Other
| Discharge destination | Nursing home or skilled nursing facility
| Discharge destination | Nursing home or skilled nursing facility
| Creatinine level on admission | <1.5;1.5–3;>3
| Albumin level on admission | ≥4; 3.5–3.9; 3–3.4;<3
Lee, 2006^71^; 1. for baseline descriptive analysis of all the patients in both development and validation cohorts;; 2. enter into bivariable model to study the association between each predictor and mortality in the derivation cohort;; 3. enter into multivariable model to identify components of the prognostic index. | Age | 50–59;60–64; 65–69; 70–74; 75–79; 80–84; >=85 | 5-year interval
| Sex | Women; Men
| Comorbidities and behaviors | Absent; present | Includes: diabetes mellitus; cancer; lung disease; heart failure; coronary artery
| Comorbidities and behaviors | Independent in all ADLs; | disease; dementia
| Body mass index | ≥25; ≤24.9
| Tobacco | Never and former; other
| Activities of daily living(ADL)- bathing | No difficulty; difficulty or need help
| Instrumental ADL | No difficulty | Instrumental ADL includes: preparing meals; using the telephone; managing finances
| Instrumental ADL | Difficulty, can’t, or don’t
| Other functional status measures | No difficulty | Measures include: walking several blocks; pushing heavy objects; climbing stairs
| Other functional status measures | Difficulty, can’t, or don’t | Measures include: walking several blocks; pushing heavy objects; climbing stairs
| Vigorous physical activity | Yes; no
Song, 2004^364^; 1. derive the relationships between the variables and mortality;; 2. to compare with a frailty index classification to evaluate the the predictive validity of the artificial neural networks classification | Dichotomized variables | Absent; present | Include: Living alone; coughing; feeling tired; sneezing; high blood pressure; heart/circulation problems; stroke; arthritis; Parkinson’s disease; eye trouble; ear trouble; dental, chest, stomach or kidney problems; bladder or bowel incontinence; diabetes mellitus;
| 3-level variables | Low risk; intermediate risk; high risk | Includes: need for assistance with eating, dressing, grooming, walking, transferring, bathing/showering, toileting, telephoning, getting to places out of walking distance, preparing meals, doing housework, taking medicine, handling money, having troubles that prevent normal activities.
| 5-level variables | Lowest risk; low risk; intermediate risk; high risk; highest risk | Eyesight, hearing, self-rating of health
| age | Not reported
| sex | Not reported
Fried, 1998^54^; 1. for the descriptive analysis of the entire study population at Baseline;; 2. determine the disease, functional and personal characteristics that jointly predict mortality in community-dwelling men and women aged 65 years or older. | Age | 65–69; 70–74;75–79;80–84; ≥85 | By year
| Sex | Female; Male
| Education | <high school
| Education | High school or college; postgraduate
| Education | High school or college; postgraduate
| Annual income | <50,000 | By dollar
| Annual income | ≥50,000
| Widowhood | No; yes
| Men weight | ≤63.9 | By kg (lb)
| Men weight | >63.9–70.2
| Men weight | >70.2–77.4
| Men weight | >77.4–85.5
| Men weight | >85.5
| Women weight | ≤51.8; | By kg (lb)
| Women weight | >51.8–59;
| Women weight | >59–65.2;
| Women weight | >65.2–75.6;
| Women weight | >75.6
| Physical activity | ≤282; | kJ(kcal)/wk in moderate or vigorous exercise
| Physical activity | >282–1789;
| Physical activity | >1789–4100;
| Physical activity | >4100–7908;
| Physical activity | >7908
| Pack-years smoking | Never; 1–25;26–50;>50
| Alcohol assumption | None; <=1;>1–3;>3 | Drinks/day
| Brachial systolic blood pressure | ≤128; >128–140;>140–152 | mm Hg; measured by Hawksley random-zero sphygmomanometer
| Brachial systolic blood pressure | >152–168;>169
| Posterior tibial artery blood pressure | ≤127;>127–146;>146–158 | mm Hg; measured by Hawksley random-zero sphygmomanometer
| Posterior tibial artery blood pressure | >158–168;>168
| Diuretic use | No; yes
| Low density lipoprotein cholesterol | <2.48(96); | mmol/L (mg/dL)
| Low density lipoprotein cholesterol | >2.48–3.02(96–117)
| Low density lipoprotein cholesterol | >3.02–3.46(117–134)
| Low density lipoprotein cholesterol | >3.46–3.96(134–153)
| Low density lipoprotein cholesterol | >3.96(153)
| Fasting blood glucose | ≤5.2(94); | mmol/L (mg/Dl)
| Fasting blood glucose | >5.2–5.6(94–100);
| Fasting blood glucose | >5.6–6(100–108);
| Fasting blood glucose | >6–7.2(108–130);
| Fasting blood glucose | >7.2(130)
| Albumin | ≤37; | g/L
| Albumin | >37–39;
| Albumin | >39–40;
| Albumin | >40–42;
| Albumin | >42
| Creatinine | ≤80(0.9); | μmol/L(mg/dL)
| Creatinine | >80–97(0.9–1.1);
| Creatinine | >97–106(1.1–1.2);
| Creatinine | >106–133(1.2–1.5);
| Creatinine | >133(1.5)
| Fibrinogen | ≤2.9; | g/L
| Fibrinogen | >2.9–3.1;
| Fibrinogen | >3.1–3.5;
| Fibrinogen | 3.5–4;
| Fibrinogen | >4
| Congestive heart failure | No; yes
| Coronary heart disease | No; yes
| Forced vital capacity | <=2.06 | mL (spirometry)
| Forced vital capacity | >2.06–2.54;
| Forced vital capacity | >2.54–3;
| Forced vital capacity | >3–3.6;
| Forced vital capacity | >3.6
| Ejection fraction abnormal | No; yes | echocardiogram
| Aortic stenosis | None; mild ; moderate; severe | echocardiogram
| Major ECG abnormality | No; yes
| Maximum stenosis of the internal carotid artery | 0;1–24;25–49;50–74;75–99;100 | %; by carotid ultrasound
| Maximum stenosis of the internal carotid artery
| Difficulty with instrumental activities of daily living | ≤1; 2;≥3 | Number; by self-reported
| Difficulty with instrumental activities of daily living
| Depressive symptoms | ≤18; >18–26;>26–33;>33–40;>40 | Digit symbol substitution subset of the Wechsler Adult Intelligence Scale-Revised
| Self-assessed health | Excellent ;very good; good; fair; poor
| Self-assessed health | Excellent ;very good; good; fair; poor
Inouye, 2003^122^; 1. identify key variables from sociodemographic, diagnosis, Laboratory, and functional axes that predict 1-year mortality in an older hospitalized cohort;; 2. develop a predictive model for mortality based on selected variables and to validate its performance in an independent sample;; 3. evaluate the effects of adding data from different sources of Information on index performance in the two cohorts. | Age ≥85 | Present; absent
| Male gender | Present; absent
| Nonwhite race | Present; absent
| Unmarried | Present; absent:
| Medicaid status | Present; absent
| Nursing home resident | Present; absent
| Emergent admission | Present; absent
| High risk diagnosis group A; | Present; absent | Diagnoses include: lymphoma/leukemia(6 pts);acute renal failure (5 pts);metastatic cancer (3 pts); localized cancer (3 pts); stroke (2 pts); congestive heart failure(2 pts);chronic lung disease (2 pts);chronic renal failure (2 pts); diabetes with end-organ damage (1 pts); pneumonia(1 pts). A (score of 0);B(1–2); C(3–5); D(≥6)
| B
| C
| D
| Albumin<=3.5 | Present; absent | mg/dL
| Creatinine>15l | Present; absent | mg/dL
| Hematocrit, 30 | Present; absent: | ml/dL
| Dementia | Present; absent | Defined as any evidence from the medical record of dementia, Alzheimer disease, Organic brain syndrome or chronic cognitive impairment before admission.
| Walking impairment | Present; absent | Defined as chart documentation of needing help of another person for walking or Being unable to walk.
| Depression | Present; absent | Defined as any evidence of depression before admission, such as a diagnosis of depression, suicide attempts or antidepressant therapy.
| Urinary incontinence | Present; absent | Defined as any evidence that the patient was incontinent or used a urinary catheter before admission.
Melzer, 2003*14 To show the distribution of study sample by socio- demographic, mortality and test measures. | Age | 70–74;75–79; 80–84; 85 and over
Melzer, 2003*14 To show the distribution of study sample by socio- demographic, mortality and test measures. | Sex | Female; Male
Melzer, 2003*14 To show the distribution of study sample by socio- demographic, mortality and test measures. | Site | East Boston; New Heaven
Melzer, 2003*14 To show the distribution of study sample by socio- demographic, mortality and test measures. | Cumulative death | 1 year;2 year;3 year; 4year
Melzer, 2003*14 To show the distribution of study sample by socio- demographic, mortality and test measures. | Self-reported walking 1/2 mile | Able; unable
Melzer, 2003*14 To show the distribution of study sample by socio- demographic, mortality and test measures. | Gait speed | <0.57;0.57–0.71;0.72–0.81; | m/second
Melzer, 2003*14 To show the distribution of study sample by socio- demographic, mortality and test measures. | Gait speed | 0.82–0.94;>0.94;unable to do
Melzer, 2003*14 To show the distribution of study sample by socio- demographic, mortality and test measures. | Time to do five chair stands | <10.4;10.4–12;12.1–13.6;
Melzer, 2003*14 To show the distribution of study sample by socio- demographic, mortality and test measures. | Time to do five chair stands | 13.7–16.3;>16.3; unable to do | second
Melzer, 2003*14 To show the distribution of study sample by socio- demographic, mortality and test measures. | Peak flow | <3902;3902–5021;5022–6068; | ml/second
Melzer, 2003*14 To show the distribution of study sample by socio- demographic, mortality and test measures. | Peak flow | 6069–7472;>7472
Ensrud, 2009^51^ to identify components of the Study of Osteoporotic Fractures index | Physical activity | | Physical activity scale for the elderly
Ensrud, 2009^51^ to identify components of the Study of Osteoporotic Fractures index | Depressive symptoms | | 15-item Geriatric Depression Scale score 0–15
Ensrud, 2009^51^ to identify components of the Study of Osteoporotic Fractures index | Cognitive function | | Teng Modified Mini-Mental State Examination score 0–26
Ensrud, 2009^51^ to identify components of the Study of Osteoporotic Fractures index | Functional disability | | Any of 5 instrumental activities of daily living
Ensrud, 2009^51^ to identify components of the Study of Osteoporotic Fractures index | Physical function | Grip strength | Handheld Jamar dynamometer
Ensrud, 2009^51^ to identify components of the Study of Osteoporotic Fractures index | Physical function | Walking speed | Time in seconds to walk 6 m at usual pace
Ensrud, 2009^51^ to identify components of the Study of Osteoporotic Fractures index | Physical function | One’s ability to rise from a chair 5 Times without using her arms
Ensrud, 2009^51^ to identify components of the Study of Osteoporotic Fractures index | Body Mass Index | | Weight and height
Ensrud, 2009^51^ to identify components of the Study of Osteoporotic Fractures index | Bone mineral density of the hip | | By dual-energy x-ray absorptiometry
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Age | By year | (continuous risk factors)
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Weight | | By kg
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Height | | cm
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Dairy calcium intake | | Mg/d
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | age | 70–74; 75–79; 80–84; 85–89; 90–100 | (predefined risk factors)
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Weight | <60kg; >=60kg
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Fragility fracture after age 40 | Yes; no
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Fells during last 12 months | Yes; no
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Uses arms when rising 5 times from chair | Yes; no
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Any type of fracture after age 40 | | (other possible risk factors)
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Use of cortisone medication for >3 month
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Has never given birth
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Lives in residential care | (vs. community)
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Height>167cm
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Dairy calcium intake<500 mg/d
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Impaired vision, self-reported | (vs. good vision)
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | History of maternal hip fracture
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Subjective health poor | (vs. excellent or fair)
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Current smoking
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Daily coffee intake >=2 cups | (vs. 0–1 cup)
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Menopausal age <45 years
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | No daily medication
Albertsson, 2007^365^; 1. to describe characteristics of participants by risk factors; 2. to identify components of Fracture and Mortality (FRAMO) index | Any parent of non-Nordic origin | (vs. Nordic)
Schonberg, 2009^366^; 1. to describe the demographic and health status characteristics of the development cohort;; 2. to identify components of the index to predict 5-year mortality Among community-dwelling older adults | Age | 65–69;70–74; 75–79; 80–84; 85+
| Men
| Smoking status | Current; former; never (<100 Cigarettes in lifetime)
| Body mass index >25 kg/(m*m)
| Physical inactivity | Less than 10 minutes per week of activity that causes slight to moderate increase in breathing or heart rate
| Perceived health | Excellent/very good; good; fair/poor
| Dependent in at least 1 activity of daily living (ADL) | | ADL includes: bathing; dressing; eating; getting in or out of bed or chairs; using the toilet
| Dependent in at least 1 instrumental activity of daily living (IADL) | | IADL includes: handling household chores; doing necessary business; shopping or Getting around for other purposes
| Reported functional difficulty | | Difficulty includes: walking 1/4 mile or 3 blocks; walking up ten steps; standing or sitting for 2Hours; stooping; reaching above the head; grasping small objects; lifting/carrying 10 Pounds; pushing/pulling large objects; going out to do things like shopping
| Emotional health | So sad that nothing could cheer you up; nervous; restless; hopeless that everything was a worthless effort | Measured by “during the past 30 days, how much of the time did you feel about each question?”
| Comorbid conditions | | Comorbid conditions include: hypertension; coronary heart disease; angina; heart attack; any other heart condition or heart disease; stroke; chronic obstructive pulmonary disease; asthma; stomach, duodenal or peptic ulcer; cancer (excluding nonmelanomatous skin cancer); diabetes (including borderline diabetes); weak or failing kidneys; liver condition; joint pain or stiffness in the past 30 days
| Overnight hospitalization in the past year | None; one; two or more
| Emergency room visits | None; one; two or more
| Clinic visits | 0–1; 2–5; 6+
Garcia-Gonzalez, 2009^367^; 1. to develop a frailty index to predict the mortality risk in Mexican adults | Health problems before age 10 | Yes; No | Health problems include: tuberculosis; rheumatic fever; poliomyelitis; typhoid fever;
Garcia-Gonzalez, 2009^367^; 1. to develop a frailty index to predict the mortality risk in Mexican adults | Poor self-assessed health | Poor; fair; good; very good, excellent
Garcia-Gonzalez, 2009^367^; 1. to develop a frailty index to predict the mortality risk in Mexican adults | Medically diagnosed conditions | Yes; No Legally blind; poor; fair; good; very good; excellent Legally deaf; poor; fair; good; very good; excellent | Conditions include: high blood pressure; diabetes mellitus; cancer; chronic obstructive pulmonary disease; heart attack; stroke; arthritis/rheumatism; falls in the past two years; fractures after age- 50; vision problems; hearing problems
Garcia-Gonzalez, 2009^367^; 1. to develop a frailty index to predict the mortality risk in Mexican adults | Medical symptoms during past 2 years | Yes; No | Symptoms include: sever fatigue; panting, cough or phlegm; involuntary urine loss; leg pain on walking; stomach pain, indigestion or diarrhea; bodily pain;
Garcia-Gonzalez, 2009^367^; 1. to develop a frailty index to predict the mortality risk in Mexican adults | Medical symptoms during past 2 years | Frequent and severe; frequent and moderate; frequent and mild; not frequent | Symptoms include: sever fatigue; panting, cough or phlegm; involuntary urine loss; leg pain on walking; stomach pain, indigestion or diarrhea; bodily pain;
Garcia-Gonzalez, 2009^367^; 1. to develop a frailty index to predict the mortality risk in Mexican adults | Medical symptoms during past 2 years | Yes; No | For depressive symptoms: indicate present if the participant felt depressed; unhappy; lonely; tire; sad; didn’t enjoy life; had no energy; restless sleep or thought that everything did was an effort
Garcia-Gonzalez, 2009^367^; 1. to develop a frailty index to predict the mortality risk in Mexican adults | Difficulty with activities of daily living | Yes; No | Having difficulty with mobility includes having difficulty picking up a 1-peso coin from the table; dressing including putting on shoes and socks; walking several blocks; walking across a room
Garcia-Gonzalez, 2009^367^; 1. to develop a frailty index to predict the mortality risk in Mexican adults | Difficulty with activities of daily living | Yes; No | Activities of daily living include: taking a shower; eating; getting in and out of bed; going to the toilet
Garcia-Gonzalez, 2009^367^; 1. to develop a frailty index to predict the mortality risk in Mexican adults | Difficulty with instrumental activities of daily living | Yes; No | Instrumental activities of daily living includes: meal preparation; shopping; taking medication; handling own finances
Carey, 2004^368^ Develop and validate a functional morbidity index to predict mortality in community- living elders | Age | <75; | By year
Carey, 2004^368^ Develop and validate a functional morbidity index to predict mortality in community- living elders | | 76–80;
Carey, 2004^368^ Develop and validate a functional morbidity index to predict mortality in community- living elders | | 81–85;
Carey, 2004^368^ Develop and validate a functional morbidity index to predict mortality in community- living elders | | >85
Carey, 2004^368^ Develop and validate a functional morbidity index to predict mortality in community- living elders | Gender | Female; male
Carey, 2004^368^ Develop and validate a functional morbidity index to predict mortality in community- living elders | Activities of daily living (ADL) | Independent; dependent | ADL includes: bathing; toileting; transferring; eating; dressing; walking;
Carey, 2004^368^ Develop and validate a functional morbidity index to predict mortality in community- living elders | Instrumental activity of daily living (IADL) | Independent; dependent | IADL includes: preparing meals; shopping; using the telephone; managing medications; managing finances.
Carey, 2004^368^ Develop and validate a functional morbidity index to predict mortality in community- living elders | Physical functioning measures | No difficulty; difficulty | Measures include: walking several blocks; climbing stairs; push/pull heavy object; lifting 10-lb object; picking up a dime
Levine, 2007^369^ | Age | 70–74;75–79;80–84; 85–89;≥90 | 5-year interval
Levine, 2007^369^ | Sex | Women; Men
Levine, 2007^369^ | Discharge to nursing home or skilled nursing facility | Yes; No
Levine, 2007^369^ | Length of stay ≥ 5 days | Yes; no
Levine, 2007^369^ | Comorbid conditions | Absent; present | Conditions include: myocardial infarction; congestive heart failure; peripheral vascular - disease; cerebrovascular disease; dementia; chronic obstructive pulmonary disease; rheumatologic disease; peptic ulcer disease; diabetes; renal disease; liver disease; hematologic and solid malignancy; metastatic cancer; acquired immune deficiency syndrome
Pijpers, 2009^370^; 1. for baseline descriptive analysis of all the patients; 2. enter into bivariable model to study the association between each predictor and mortality in the cohort; 3. enter into multivariable model if they are significant to identify components of the mortality risk index. | Age | | By per 10 years
| Male sex | Male; female
| Living alone | Yes; No
| Medical conditions | Present; absent | Conditions include: cardiovascular disease; chronic obstructive pulmonary disease; Cancer; diabetes; autoimmune disease; renal function estimated by glomerular filtration rate; number of medications; Charlson score is also calculated; visual problems; hearing problems; incontinence
| Body mass index | <18.5; ≥ 18.5 | Kg/(m*m)
| Weight loss
| Albumin | <34; ≥ 34 | g/l
| Mobility | <20; ≥ 20 | Measured by Elderly Mobility Scale (EMS)
| Disability in activities of daily living (ADL) | Motor deficit in ADL; process deficit In ADL | Measured by the Assessment of Motor and Process Skills (AMPS)
| Cognitive function | <24; ≥ 24 | Measured by the Mini Mental State Examination (MMSE)
Mazzaglia, 2007^187^; 1. for baseline descriptive analysis of all the patients; 2. enter into multivariable model if they are significant to identify components of the mortality risk index. | Age | 65–74; 75–84; ≥ 85
Mazzaglia, 2007^187^; 1. for baseline descriptive analysis of all the patients; 2. enter into multivariable model if they are significant to identify components of the mortality risk index. | Female | Male; female
Mazzaglia, 2007^187^; 1. for baseline descriptive analysis of all the patients; 2. enter into multivariable model if they are significant to identify components of the mortality risk index. | Living alone | Yes; No
Mazzaglia, 2007^187^; 1. for baseline descriptive analysis of all the patients; 2. enter into multivariable model if they are significant to identify components of the mortality risk index. | Hospitalization in the previous 6 months | Yes; No
Mazzaglia, 2007^187^; 1. for baseline descriptive analysis of all the patients; 2. enter into multivariable model if they are significant to identify components of the mortality risk index. | Taking ≥ 5 prescriptions | Yes; No
Mazzaglia, 2007^187^; 1. for baseline descriptive analysis of all the patients; 2. enter into multivariable model if they are significant to identify components of the mortality risk index. | Positive responses to the screening instrument | 0–1; 2–3; 4–6 | Screening questions include: need help performing basic activities of daily living - eating; toileting; bathing; dressing; transferring and walking across the room); need help performing instrumental activities of daily living (grocery shopping; preparing meals; washing clothes; managing medications; showering); poor vision(Inability to read newspapers heading); poor hearing (inability to hold a conversation); absence of home care services (personal assistance; rehabilitation; nursing services); self-perceived inadequacy of income; weight loss of >3kg in previous year.
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | 1) Impairment index includes cognition
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | 1) Impairment index includes cognition | No cognitive impairment;
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | 1) Impairment index includes cognition | Cognitive impairment, no dementia
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | 1) Impairment index includes cognition | dementia
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | Emotion | <5; 5–10;>10 | Measured by geriatric depression scale
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | Communication | No deficits in speech, hearing, vision
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | Communication | 1 deficit in either speech, hearing, or
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | Communication | Vision; ≥ 2 deficits in either speech,
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | Communication | Hearing or vision
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | Mobility | >19 or without help; 10–19 or with | Measured by Timed up and go
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | Mobility | Help; <10 or unable
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | Balance | >33 or no falls;21–33 or less than yearly falls;<21 or more than yearly falls | Measured by Functional Reach
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | Bladder | Continent; bladder deficits; Incontinent or catheterized
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | Bowel | Continent; bowel deficits; incontinent
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | Nutrition | Stable weight; 5% weight change
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | Nutrition | >5% weight change
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | Activities of daily living | Independent; complex or low level Intermediate dependence; simple or high level intermediate dependence
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | Social | Institutionalized; uses formal home Supports; living alone
Jones, 2004^144^; 1. simplify the clinical assessment of frailty while maintaining the precision of the original frailty index by constructing it from a standardized comprehensive geriatric assessment | 2) Comorbidity index | 0;1;2;3;4 | Measured by the cumulative illness Rating scale (CIRS); 14 possible co-existing diseased body system were coded as 0,1, or 2 and the range of the index was standardized into 0–4
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Weight loss | Yes; No | Frail for weight loss if answer is “yes” to “in the last year, have you lost more than 10 Pounds unintentionally (not due to dieting or exercise)?
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Exhaustion | 0;1;2;3 | Measured by the Center for Epidemiologic Studies Depression Scale (CES-D), the two statements were read: a) I felt that everything I did was an effort; b) I could not get going. The question is asked “How often in the last week did you feel this way?” 0=rarely or none of the time (<1 day);1=some or a little of the time (1–2 days); 2=a moderate amount of the time (3–4days); or 3=most of the time. Subjects answering 2 or 3 are categorized as frail by exhaustion.
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Low physical activity | For men: <383 Kcal/week; ≥383Kcal/week | Based upon the short version of the Minnesota Leisure Time Activity questionnaire, asking about walking, chores (moderately strenuous), mowing the lawn, raking, gardening, hiking, biking, exercise cycling, dancing aerobics, bowling, golf, singles, tennis, doubles tennis, racquetball, calisthenics, swimming.
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Low physical activity | For women: <270 Kcal/week; ≥270 Kcal/week
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Walk time(slowness) | For men: | Time to walk 15 feet is stratified by gender and height; frail for the slowest 20%
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Walk time(slowness) | ≥7 seconds for height ≤173cm | Time to walk 15 feet is stratified by gender and height; frail for the slowest 20%
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Walk time(slowness) | ≥6 seconds for height >173cm | Time to walk 15 feet is stratified by gender and height; frail for the slowest 20%
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Walk time(slowness) | For women: | Time to walk 15 feet is stratified by gender and height; frail for the slowest 20%
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Walk time(slowness) | ≥7 seconds for height ≤159cm | Time to walk 15 feet is stratified by gender and height; frail for the slowest 20%
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Walk time(slowness) | ≥6 seconds for height >159cm | Time to walk 15 feet is stratified by gender and height; frail for the slowest 20%
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Grip strength (weakness) | For men: | Stratified by gender and body mass index (BMI); frail for the lowest 20%.
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Grip strength (weakness) | ≥29 kg for BMI ≤24; | Stratified by gender and body mass index (BMI); frail for the lowest 20%.
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Grip strength (weakness) | ≥30 kg for BMI 24.1–26 | Stratified by gender and body mass index (BMI); frail for the lowest 20%.
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Grip strength (weakness) | ≥30 kg for BMI 26.1–28 | Stratified by gender and body mass index (BMI); frail for the lowest 20%.
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Grip strength (weakness) | ≥32 kg for BMI >28; | Stratified by gender and body mass index (BMI); frail for the lowest 20%.
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Grip strength (weakness) | For women: | Stratified by gender and body mass index (BMI); frail for the lowest 20%.
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Grip strength (weakness) | ≥17 kg for BMI ≤23; | Stratified by gender and body mass index (BMI); frail for the lowest 20%.
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Grip strength (weakness) | ≥17.3 kg for BMI 23.1–26 | Stratified by gender and body mass index (BMI); frail for the lowest 20%.
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Grip strength (weakness) | ≥18 kg for BMI26.1–29 | Stratified by gender and body mass index (BMI); frail for the lowest 20%.
Fried, 2001^55^ 1 develop and operationalize a phenotype of frailty in older adults And assess concurrent and predictive validity | Grip strength (weakness) | ≥21 kg for BMI >29 | Stratified by gender and body mass index (BMI); frail for the lowest 20%.
Markides, 2001^371^ Examine the impact of performance-based and self-reported lower body measures on 2-year mortality in Mexican American elderly persons. | Age | 65–74; 75+ | By years
Markides, 2001^371^ Examine the impact of performance-based and self-reported lower body measures on 2-year mortality in Mexican American elderly persons. | Gender | Men; women
Markides, 2001^371^ Examine the impact of performance-based and self-reported lower body measures on 2-year mortality in Mexican American elderly persons. | Performance Score | 0 (unable);1;2;3;4 | 1. three separate tasks were assessed and a combined score was created to represent lower body function. The tasks include: a timed 8-ft walk; timed repeated chair stands and stand balancing. The two timed tasks were divided into quartiles each and scored 1 (slowest) to 4 (fasted). Subjects unable to complete each task were assigned a value of 0. The standing balance tests included tandem, semi-tandem and side-by- side stands. Subjects were scored 1 to 3, with 3 indicating the highest performance; those unable to perform any of the balance tests were assigned a value of 0.; 2. the three scores were combined to form a total lower body function score ranging from 0 to 11. The scale was further categorized from 0 to 4 to approximate the timed walk categorization.
Markides, 2001^371^ Examine the impact of performance-based and self-reported lower body measures on 2-year mortality in Mexican American elderly persons. | Short walk | 0 (unable);1;2;3;4 | This task was divided into quartiles each and Scored 1 (slowest) to 4 (fasted). Subjects unable to complete each task were assigned a value of 0.
Markides, 2001^371^ Examine the impact of performance-based and self-reported lower body measures on 2-year mortality in Mexican American elderly persons. | Any activities of daily living | Yes; No
Markides, 2001^371^ Examine the impact of performance-based and self-reported lower body measures on 2-year mortality in Mexican American elderly persons. | Medical conditions | Present; not present | Medical conditions include: hypertension; heart attack; cancer; diabetes; hip fracture; Stroke.
Gill, 2006^372^ Determine the transition rates between frailty states and evaluate the effect of the preceding frailty state on subsequent frailty transitions. | Weight loss | | Frail for weight loss if answer is “yes” to “in the past year, have you lost more than 10 pounds?
Gill, 2006^372^ Determine the transition rates between frailty states and evaluate the effect of the preceding frailty state on subsequent frailty transitions. | Exhaustion | | Measured by the Center for Epidemiologic Studies Depression Scale (CES-D), the two statements were read: a I felt that everything I did was an effort; b I could not get going. The question is asked “How often in the last week did you feel this way?” Subjects answering “much or most of the time” were defined as frail
Gill, 2006^372^ Determine the transition rates between frailty states and evaluate the effect of the preceding frailty state on subsequent frailty transitions. | Low Physical activity | For men <64; ≥64 | Measured by the Physical Activity Scale for the Elderly;
Gill, 2006^372^ Determine the transition rates between frailty states and evaluate the effect of the preceding frailty state on subsequent frailty transitions. | Low Physical activity | For women <52; ≥52 | Measured by the Physical Activity Scale for the Elderly;
Gill, 2006^372^ Determine the transition rates between frailty states and evaluate the effect of the preceding frailty state on subsequent frailty transitions. | Grip strength ( muscle weakness) | | When grip strength measured as the average of 3 readings by a handheld dynamometer;
Gill, 2006^372^ Determine the transition rates between frailty states and evaluate the effect of the preceding frailty state on subsequent frailty transitions. | Slow walking speed | >10 seconds; ≤10 seconds | Defined as frail for walking speed if participant scored more than 10 seconds on the rapid gait test.
Graham, 2009^202^; 1. examine the relationship between frailty and 10-year mortality In older community- dwelling Mexican Americans. | Weight loss | 0;1 | Is evaluated as the change in body weight over the preceding year. Subjects with unintentional weight loss of 4.5 or more kilograms received a score of 1
Graham, 2009^202^; 1. examine the relationship between frailty and 10-year mortality In older community- dwelling Mexican Americans. | Exhaustion | 0;1 | Measured by the Center for Epidemiologic Studies Depression Scale (CES-D), the two statements were read: a I felt that everything I did was an effort; b I could not get going. The question is asked “How often in the last week did you feel this way?” Participants reporting yes for a moderate amount or most of the time over the previous week on either question received a score of 1
Graham, 2009^202^; 1. examine the relationship between frailty and 10-year mortality In older community- dwelling Mexican Americans. | Low Physical activity | Slowest 20% for men: ≤30 | Based upon the Physical Activity Scale for the Elderly
Graham, 2009^202^; 1. examine the relationship between frailty and 10-year mortality In older community- dwelling Mexican Americans. | Low Physical activity | Slowest 20% for women: ≤27.5 | Based upon the Physical Activity Scale for the Elderly
Graham, 2009^202^; 1. examine the relationship between frailty and 10-year mortality In older community- dwelling Mexican Americans. | Walking speed | Slowest 20% for men: ≥11.2 seconds for height ≤168cm ≥9.7 seconds for height >168cm Slowest 20% for women: ≥12 seconds for height<=154cm ≥11.2 seconds for height >154cm | Was recorded during a 4.9-meter timed walk test. Participants were instructed to walk as fast as they felt safe. Those unable to complete the walk or who scored the lowest quintile based on gender-and height specific thresholds received a Score of 1
Graham, 2009^202^; 1. examine the relationship between frailty and 10-year mortality In older community- dwelling Mexican Americans. | Grip strength (weakness) | Weakest 20% for men: | Was quantified with a hand dynamometer. Those unable to perform the test or those
Graham, 2009^202^; 1. examine the relationship between frailty and 10-year mortality In older community- dwelling Mexican Americans. | Grip strength (weakness) | ≤21 kg for BMI ≤24.2; | Scoring in the lowest quintile based on gender and BMI specific criteria received a Score of 1
Graham, 2009^202^; 1. examine the relationship between frailty and 10-year mortality In older community- dwelling Mexican Americans. | Grip strength (weakness) | ≤24.5 kg for BMI 24.3–26.8 | Scoring in the lowest quintile based on gender and BMI specific criteria received a Score of 1
Graham, 2009^202^; 1. examine the relationship between frailty and 10-year mortality In older community- dwelling Mexican Americans. | Grip strength (weakness) | ≤25.4 kg for BMI 26.9–29.5; | Scoring in the lowest quintile based on gender and BMI specific criteria received a Score of 1
Graham, 2009^202^; 1. examine the relationship between frailty and 10-year mortality In older community- dwelling Mexican Americans. | Grip strength (weakness) | ≤25.5 kg for BMI >29.5; | Scoring in the lowest quintile based on gender and BMI specific criteria received a Score of 1
Graham, 2009^202^; 1. examine the relationship between frailty and 10-year mortality In older community- dwelling Mexican Americans. | Grip strength (weakness) | Weakest 20% for women: | Scoring in the lowest quintile based on gender and BMI specific criteria received a Score of 1
Graham, 2009^202^; 1. examine the relationship between frailty and 10-year mortality In older community- dwelling Mexican Americans. | Grip strength (weakness) | ≤13.5 kg for BMI ≤24.7; | Scoring in the lowest quintile based on gender and BMI specific criteria received a Score of 1
Graham, 2009^202^; 1. examine the relationship between frailty and 10-year mortality In older community- dwelling Mexican Americans. | Grip strength (weakness) | ≤14.2 kg for BMI 24.8–28.3; | Scoring in the lowest quintile based on gender and BMI specific criteria received a Score of 1
Graham, 2009^202^; 1. examine the relationship between frailty and 10-year mortality In older community- dwelling Mexican Americans. | Grip strength (weakness) | ≤15 kg for BMI28.4.1–32.1; | Scoring in the lowest quintile based on gender and BMI specific criteria received a Score of 1
Graham, 2009^202^; 1. examine the relationship between frailty and 10-year mortality In older community- dwelling Mexican Americans. | Grip strength (weakness) | ≤15 kg for BMI >32.1 | Scoring in the lowest quintile based on gender and BMI specific criteria received a Score of 1
Purser, 2006^373^ 1 determine whether single- item performance measures are good indicators of multidimensional frailty and to estimate the association between frailty and 6-month mortality. | Measure set A
Purser, 2006^373^ 1 determine whether single- item performance measures are good indicators of multidimensional frailty and to estimate the association between frailty and 6-month mortality. | Weight loss | Yes; No | Frail for weight loss if answer is “yes” to “in the last year, have you lost more than 10 pounds unintentionally (not due to dieting or exercise)?
Purser, 2006^373^ 1 determine whether single- item performance measures are good indicators of multidimensional frailty and to estimate the association between frailty and 6-month mortality. | Weight loss | | Frail for weight loss if answer is “yes” to “in the last year, have you lost more than 10 pounds unintentionally (not due to dieting or exercise)?
Purser, 2006^373^ 1 determine whether single- item performance measures are good indicators of multidimensional frailty and to estimate the association between frailty and 6-month mortality. | Exhaustion | | Measured by the Center for Epidemiologic Studies Depression Scale (CES-D), the two statements were read: a I felt that everything I did was an effort; b I could not get going. The question is asked “How often in the last week did you feel this way?” 0=rarely or none of the time(<1 day);1=some or a little of the time (1–2days);2=a Moderate amount of the time (3–4days); or 3=most of the time. Subjects answering 2 or 3 are categorized as frail by the exhaustion;
Purser, 2006^373^ 1 determine whether single- item performance measures are good indicators of multidimensional frailty and to estimate the association between frailty and 6-month mortality. | Low Physical activity | | Based on the 36-item Medical Outcomes Study Short Form survey physical function subscale scores in the lowest quartile for sex;
Purser, 2006^373^ 1 determine whether single- item performance measures are good indicators of multidimensional frailty and to estimate the association between frailty and 6-month mortality. | Mobility | | Time to walk 15 feet is stratified by gender and height; frail for the slowest 20%
Purser, 2006^373^ 1 determine whether single- item performance measures are good indicators of multidimensional frailty and to estimate the association between frailty and 6-month mortality. | Grip strength | | Stratified by gender; frail for the lowest 20%.
Purser, 2006^373^ 1 determine whether single- item performance measures are good indicators of multidimensional frailty and to estimate the association between frailty and 6-month mortality. | Measure set B | 0;1;2;3 | Rates the number of self-reported limitations in mobility, activities of daily living, incontinence and cognitive impairment. Defined as frail if one receives a score -of 1 or more.
Purser, 2006^373^ 1 determine whether single- item performance measures are good indicators of multidimensional frailty and to estimate the association between frailty and 6-month mortality. | Single-item performance measures
Purser, 2006^373^ 1 determine whether single- item performance measures are good indicators of multidimensional frailty and to estimate the association between frailty and 6-month mortality. | Gait speed | | By 15-foot walk time; usual assistance is allowed when walking
Purser, 2006^373^ 1 determine whether single- item performance measures are good indicators of multidimensional frailty and to estimate the association between frailty and 6-month mortality. | Grip strength | | Stratified by gender; frail for the lowest 20%.
Purser, 2006^373^ 1 determine whether single- item performance measures are good indicators of multidimensional frailty and to estimate the association between frailty and 6-month mortality. | Chair stands | | 30-seconds chair-stand test is used to determine the number of times a patient could rise from a chair without the use of arms in 30-second interval.
Avila-Funes, 2009^169^ To determine whether adding cognitive impairment to frailty Improves its predictive validity for adverse health outcomes. | Weight loss | | Defined as self-report of recent and unintentional weight loss of 3 kg or more or a Body mass index lower than 21 kg/(m*m);
Avila-Funes, 2009^169^ To determine whether adding cognitive impairment to frailty Improves its predictive validity for adverse health outcomes. | Exhaustion | | Measured by the Center for Epidemiologic Studies Depression Scale (CES-D), the two statements were read: a I felt that everything I did was an effort; b I could not get going. The question is asked “How often in the last week did you feel this way?” 0=rarely or none of the time(<1 day);1=some or a little of the time (1–2days);2=a Moderate amount of the time (3–4days); or 3=most of the time. Subjects answering 2 Or 3 are categorized as frail by the exhaustion;
Avila-Funes, 2009^169^ To determine whether adding cognitive impairment to frailty Improves its predictive validity for adverse health outcomes. | Low physical activity | | Established in participants who denied doing daily leisure activities such as walking or gardening or participating in athletic activity at least once a week;
Avila-Funes, 2009^169^ To determine whether adding cognitive impairment to frailty Improves its predictive validity for adverse health outcomes. | Slowness | | Defined as the lowest quintile on a timed 6-m walking test, at usual pace, adjusted for sex and height;
Avila-Funes, 2009^169^ To determine whether adding cognitive impairment to frailty Improves its predictive validity for adverse health outcomes. | Weakness | | Participants answering “yes” to the question “do you have difficulty rising from a chair?” were categorized as frail for weakness.
Avila-Funes, 2009^169^ To determine whether adding cognitive impairment to frailty Improves its predictive validity for adverse health outcomes. | Global cognitive performance | | Measured by:1) Mini-Mental State Examination (scores ranging from 0 to 30, higher Indicates better cognitive status); 2) Issacs Set Test, which assess the verbal fluency abilities and speed of verbal production (subjects give a list of words belonging to a specific semantic category in 30 seconds; cities; fruits animals and colors were used; total number of items named is the score, the higher the better cognitive status. divided into 4 levels according to quartiles of score distribution; subjects in the lowest quartile in both tests were considered cognitively impaired.
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Vision loss | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Hearing loss | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Impaired mobility | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Vascular problem | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Gait abnormality | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Impaired vibration sense | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Difficulty bathing | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Difficulty going out | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Difficulty cooking | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Difficulty toileting | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Difficulty grooming | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Skin problem | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Resting tremor | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Changes in sleep | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Difficulty dressing | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Urinary complaints | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Gastro-intestinal problem | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Diabetes | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Hypertension | Present; not present
Mitnitski, 2002^374^ 1 estimate the frailty and fitness based on the proportion of 20 Deficits observed in a structured clinical examination. | Limb tone abnormality | Present; not present
Kiely, 2009^26^; 1. validate and compare CHS and SOF indexes using an independent diverse sample of men and women, in their ability to predict recurrent falls, overnight hospitalizations, emergency department visits, and instrumental activities of daily living disability. | 1) Fried frailty index Cardiovascular Health Study (CHS) | 1) unintentional weight loss | Defined using questions “in the last year, have you lost more than 10 pounds unintentionally that is, not due to dieting or exercise?”
| 1) Fried frailty index Cardiovascular Health Study (CHS) | 2) weakness | Defined according to the sit-stand test time, which is part of the Short Physical Performance Battery (SPPB);Time required to perform five repetitions of sit to stand was measured and used as a proxy for leg strength. The cohort was stratified by gender and body mass index; The highest 20% of sit-to-stand times (including those unable to perform the task) was defined as frail for weakness
| 1) Fried frailty index Cardiovascular Health Study (CHS) | 3) low energy level (poor | Determined according to the Center for Epidemiologic Studies Depression Scale, Hopkins
| 1) Fried frailty index Cardiovascular Health Study (CHS) | Endurance or exhaustion) | Version(CESD-R) question, “over the past week or so, did you feel like you could not get going?” Those reporting symptoms occurring on 3 days or more in the previous week were considered as demonstrating low energy level;
| 1) Fried frailty index Cardiovascular Health Study (CHS) | 4) slow gait | Defined from the timed 4-m walk. Two trials were performed and the fastest time was used. The time scores were stratified by sex and height. Those in the slowest quintile in each stratum were considered to have slow gait;
| 1) Fried frailty index Cardiovascular Health Study (CHS) | 5) low physical activity | Determined using the Physical Activity Scale for the Elderly (PASE). The PASE score was stratified according to sex and those scoring in the bottom quintile considered to exhibit low daily activity.
| 2) Ensrud frailty index Study of Osteoporotic Fracture (SOF) | 1) unintentional weight loss | Defined using questions “in the last year, have you lost more than 10 pounds unintentionally that is, not due to dieting or exercise?”
| 2) Ensrud frailty index Study of Osteoporotic Fracture (SOF) | 2) inability to rise from a chair five times without the use of arms
| 2) Ensrud frailty index Study of Osteoporotic Fracture (SOF) | 3) low energy level | Determined according to the Center for Epidemiologic Studies Depression Scale, Hopkins Version (CESD-R) question, “over the past week or so, did you feel like you could not get Going?” Those reporting symptoms occurring on 3 days or more in the previous week were considered as demonstrating low energy level

Appendix E Table 48 Index Development of Models That Predict Mortality in Older Persons Based on Geriatric Syndromes or Nonsyndromic Conditions

Prediction Outcome | Index Component | Weight | Weight Method | Risk Group | Score | Accuracy/Validation
Drame, 2008^375^ 2-year mortality | 1 age: 85 years or older | 1 | Equals to hazard ratio in the multivariable model that rounded up to the nearest integer | Low-risk | <=2 | No. of death/No. at risk, 95% CI for each risk group, and overall group were calculated and compared
Drame, 2008^375^ 2-year mortality | 2 dependent for the ADL: yes | 1 | Equals to hazard ratio in the multivariable model that rounded up to the nearest integer | Medium risk | 3–5 | No. of death/No. at risk, 95% CI for each risk group, and overall group were calculated and compared
Drame, 2008^375^ 2-year mortality | 3 delirium: yes | 2 | Equals to hazard ratio in the multivariable model that rounded up to the nearest integer | High-risk | >=6 | | Derivation Cohort | Validation Cohort
Drame, 2008^375^ 2-year mortality | 4 malnutrition risk: yes | 2 | Equals to hazard ratio in the multivariable model that rounded up to the nearest integer | High-risk | >=6 | Receiver Operating | 0.72 (0.68–0.75) | 0.71 (0.66–0.76)
Drame, 2008^375^ 2-year mortality | 5 comorbidity level: medium | 2 | Equals to hazard ratio in the multivariable model that rounded up to the nearest integer | High-risk | >=6
Drame, 2008^375^ 2-year mortality | 6 comorbidity level: high | 3 | Equals to hazard ratio in the multivariable model that rounded up to the nearest integer | High-risk | >=6
Ensrud, 2008^50^ Disability; Hip fracture; death | 1) weight loss of 5% or more between the 3^rd^ and 4^th^ examination | | Frailty is defined by the presence of 2 or more of the 3 components | robust | 0 | Number and percentage of participants with recurrent falls, disability, hip fracture and death, 95% CI, odds ratio, hazard ratio for each risk group according to Study of Osteoporotic Fractures and Cardiovascular Health Study index
Ensrud, 2008^50^ Disability; Hip fracture; death | 1) weight loss of 5% or more between the 3^rd^ and 4^th^ examination | | Frailty is defined by the presence of 2 or more of the 3 components | immediate | 1
Ensrud, 2008^50^ Disability; Hip fracture; death | 1) weight loss of 5% or more between the 3^rd^ and 4^th^ examination | | Frailty is defined by the presence of 2 or more of the 3 components | frailty | >=2
Ensrud, 2008^50^ Disability; Hip fracture; death | 2) subject’s inability to rise from a chair 5 times without using her arms | | Frailty is defined by the presence of 2 or more of the 3 components | frailty | >=2 | Receiver Operating | SOF | CHS
Ensrud, 2008^50^ Disability; Hip fracture; death | 2) subject’s inability to rise from a chair 5 times without using her arms | | Frailty is defined by the presence of 2 or more of the 3 components | frailty | >=2 | Characteristic curve area
Ensrud, 2008^50^ Disability; Hip fracture; death | 3) reduced energy level | | Frailty is defined by the presence of 2 or more of the 3 components | frailty | >=2 | Recurrent falls | 0.61 (0.59–0.64) | 0.61 (0.59–0.63)
Ensrud, 2008^50^ Disability; Hip fracture; death | 3) reduced energy level | | Frailty is defined by the presence of 2 or more of the 3 components | frailty | >=2 | Hip fracture | 0.63 (0.60–0.65) | 0.63 (0.60–0.65)
Ensrud, 2008^50^ Disability; Hip fracture; death | 3) reduced energy level | | Frailty is defined by the presence of 2 or more of the 3 components | frailty | >=2 | Death | 0.72 (0.71–0.73) | 0.72 (0.71–0.74)
Ensrud, 2008^50^ Disability; Hip fracture; death | 3) reduced energy level | | Frailty is defined by the presence of 2 or more of the 3 components | frailty | >=2 | Disability | 0.64 (0.62–0.65) | 0.64 (0.63–0.66)
Ravaglia, 2008^362^ 4-year mortality; fractures; hospital admission; worsening disability; Incident disability | 1 age >=80 | 1 | Each present predictor is assigned one point and all the points assigned to each participant is summed to be the total score | 4-year mortality | 0–2 | Not reported
Ravaglia, 2008^362^ 4-year mortality; fractures; hospital admission; worsening disability; Incident disability | 2 male gender | 1 | Each present predictor is assigned one point and all the points assigned to each participant is summed to be the total score | 4-year mortality | 3 | Not reported
Ravaglia, 2008^362^ 4-year mortality; fractures; hospital admission; worsening disability; Incident disability | 3 physical inactivity | 1 | Each present predictor is assigned one point and all the points assigned to each participant is summed to be the total score | 4-year mortality | 4 | Not reported
Ravaglia, 2008^362^ 4-year mortality; fractures; hospital admission; worsening disability; Incident disability | 4 use of >=3 drug | 1 | Each present predictor is assigned one point and all the points assigned to each participant is summed to be the total score | 4-year mortality | 5 | Not reported
Ravaglia, 2008^362^ 4-year mortality; fractures; hospital admission; worsening disability; Incident disability | 5 sensory deficits | 1 | Each present predictor is assigned one point and all the points assigned to each participant is summed to be the total score | 4-year mortality | 6 | Not reported
Ravaglia, 2008^362^ 4-year mortality; fractures; hospital admission; worsening disability; Incident disability | 6 calf circumference <31cm | 1 | Each present predictor is assigned one point and all the points assigned to each participant is summed to be the total score | 4-year mortality | ≥7 | Not reported
Ravaglia, 2008^362^ 4-year mortality; fractures; hospital admission; worsening disability; Incident disability | 7 instrumental activity of daily | 1 | Each present predictor is assigned one point and all the points assigned to each participant is summed to be the total score | 4-year risk of fracture | | Not reported
Ravaglia, 2008^362^ 4-year mortality; fractures; hospital admission; worsening disability; Incident disability | Living disability | 1 | Each present predictor is assigned one point and all the points assigned to each participant is summed to be the total score | 4-year risk of fracture | 0–2 | Not reported
Ravaglia, 2008^362^ 4-year mortality; fractures; hospital admission; worsening disability; Incident disability | 8 gait and balance test <=24 | 1 | Each present predictor is assigned one point and all the points assigned to each participant is summed to be the total score | Hospital admission | 3 | Not reported
Ravaglia, 2008^362^ 4-year mortality; fractures; hospital admission; worsening disability; Incident disability | 9 pessimism about one’s health | 1 | Each present predictor is assigned one point and all the points assigned to each participant is summed to be the total score | Worsening disability | >=4 | Not reported
Ravaglia, 2008^362^ 4-year mortality; fractures; hospital admission; worsening disability; Incident disability | 9 pessimism about one’s health | 1 | Each present predictor is assigned one point and all the points assigned to each participant is summed to be the total score | Incident disability | | Not reported
Carey, 2008^129^ 1-year mortality; 2-year mortality; 3-year mortality; | 1) male | 2 | The coefficient for each risk factor was divided by the lowest coefficient (for the partial dependence in the ADL dressing) and rounded to the nearest integer; all the points for each present risk factor were summed up and would be the risk score for each patient. | low | 0–3 | No. at risk, mortality rate for each risk group was calculated and compared between development and validation cohorts.
Carey, 2008^129^ 1-year mortality; 2-year mortality; 3-year mortality; | 2) age | | | medium | 4–5 | No. at risk, mortality rate for each risk group was calculated and compared between development and validation cohorts.
Carey, 2008^129^ 1-year mortality; 2-year mortality; 3-year mortality; | 75–79 | 2 | | high | >5 | No. at risk, mortality rate for each risk group was calculated and compared between development and validation cohorts.
Carey, 2008^129^ 1-year mortality; 2-year mortality; 3-year mortality; | 80–84 | 2 | | high | >5 | | Derivation cohort | Validation cohort
Carey, 2008^129^ 1-year mortality; 2-year mortality; 3-year mortality; | >=85 | 3 | | high | >5 | Receiver operating | 0.66 | 0.69
Carey, 2008^129^ 1-year mortality; 2-year mortality; 3-year mortality; | 3) dependence in toileting | 1 | | high | >5
Carey, 2008^129^ 1-year mortality; 2-year mortality; 3-year mortality; | 4) dressing | | | high | >5
Carey, 2008^129^ 1-year mortality; 2-year mortality; 3-year mortality; | Partially dependent | 1 | | high | >5
Carey, 2008^129^ 1-year mortality; 2-year mortality; 3-year mortality; | Fully dependent | 3 | | high | >5
Carey, 2008^129^ 1-year mortality; 2-year mortality; 3-year mortality; | 5) malignant neoplasm | 2 | | high | >5
Carey, 2008^129^ 1-year mortality; 2-year mortality; 3-year mortality; | 6) congestive heart failure | 3 | | high | >5
Carey, 2008^129^ 1-year mortality; 2-year mortality; 3-year mortality; | 7) chronic obstructive Pulmonary disease | 1 | | high | >5
Carey, 2008^129^ 1-year mortality; 2-year mortality; 3-year mortality; | 8) renal failure or insufficiency | 3 | | high | >5
Pilotto, 2008^363^ 1-year mortality | 1) Activities of daily living index | 0;0.5;1 | Each domain can be assigned one of three weights (0;0.5;1) depending on the specific scores for each domain. The sum of the calculated scores from the eight domains was divided by 8 to obtain a final multidimensional index score from 0 to 1. | Low risk | ≤0.33 | Calibration of the model was assessed by comparing the predicted mortality with the actual mortality in the development and validation cohorts; discrimination of the model was assessed by calculating the receiver operating characteristic curves for the development and validation cohorts.
Pilotto, 2008^363^ 1-year mortality | 2) instrumental activities of daily living scale | 0;0.5;1 | | Moderate risk | 0.34–0.66
Pilotto, 2008^363^ 1-year mortality | 3) Short Portable Mental Status questionnaire | 0;0.5;1 | | Severe risk | >0.66
Pilotto, 2008^363^ 1-year mortality | 4) comorbidity index | 0;0.5;1 | | Severe risk | >0.66
Pilotto, 2008^363^ 1-year mortality | 5) Mini Nutritional Assessment | 0;0.5;1 | | Severe risk | >0.66 | | Development cohort | Validation cohort
Pilotto, 2008^363^ 1-year mortality | 6) Exton Smith Scale | 0;0.5;1 | | Severe risk | >0.66 | Receiver operating | 0.751 (0.71–0.81) | Not reported
Pilotto, 2008^363^ 1-year mortality | 7) number of medications | 0;0.5;1 | | Severe risk | >0.66
Pilotto, 2008^363^ 1-year mortality | 8) social support network | 0;0.5;1 | | Severe risk | >0.66
Walter, 2001^125^ 1-year mortality | 1) male sex | 1 | A risk score was calculated for each patient by adding the points of each present risk factor | Low-risk | 0–1 | No. of death/No. at risk, 95% CI for each risk group were calculated and compared between derivation and validation cohorts.
Walter, 2001^125^ 1-year mortality | 2) dependent in 1–4 ADLs | 2 | A risk score was calculated for each patient by adding the points of each present risk factor | Medium risk | 2–3 | No. of death/No. at risk, 95% CI for each risk group were calculated and compared between derivation and validation cohorts.
Walter, 2001^125^ 1-year mortality | 2) dependent in 1–4 ADLs | 2 | A risk score was calculated for each patient by adding the points of each present risk factor | High-risk | 4–6 | Receiver Operating | Derivation Cohort | Validation Cohort
Walter, 2001^125^ 1-year mortality | 3) dependent in all ADLs | 5 | A risk score was calculated for each patient by adding the points of each present risk factor | Very high- risk | >6 | Characteristic curve area
Walter, 2001^125^ 1-year mortality | 4) congestive heart failure | 2 | A risk score was calculated for each patient by adding the points of each present risk factor | Very high- risk | >6 | By risk group | 0.75 | 0.79
Walter, 2001^125^ 1-year mortality | 5) solitary cancer | 3 | A risk score was calculated for each patient by adding the points of each present risk factor | Very high- risk | >6 | By quartile of risk | 0.75 | 0.8
Walter, 2001^125^ 1-year mortality | 6) metastatic cancer | 8 | A risk score was calculated for each patient by adding the points of each present risk factor | Very high- risk | >6
Walter, 2001^125^ 1-year mortality | 7) creatinine level on admission >3mg/dl | | A risk score was calculated for each patient by adding the points of each present risk factor | Very high- risk | >6
Walter, 2001^125^ 1-year mortality | 7) creatinine level on admission >3mg/dl | 2 | A risk score was calculated for each patient by adding the points of each present risk factor | Very high- risk | >6
Walter, 2001^125^ 1-year mortality | 8) albumin level on admission | | A risk score was calculated for each patient by adding the points of each present risk factor | Very high- risk | >6
Walter, 2001^125^ 1-year mortality | 3–3.4 g/dl | 1 | A risk score was calculated for each patient by adding the points of each present risk factor | Very high- risk | >6
Walter, 2001^125^ 1-year mortality | <3 g/dl | 2 | A risk score was calculated for each patient by adding the points of each present risk factor | Very high- risk | >6
Lee, 2006^71^ 4-year mortality | 1) male sex | 2 | Points were assigned to each risk factor by dividing each beta coefficient by the lowest beta coefficient (ability to push or pull heavy objects) and rounding to the nearest integer. A risk score was assigned to each participant by summing the points for each present risk factor. | lowest | 0–5 | No. of death/No. at risk for each risk group were calculated and compared.
Lee, 2006^71^ 4-year mortality | 2) age 60–64 | 1 | | Medium | 6–9 | between development and validation cohorts
Lee, 2006^71^ 4-year mortality | 3) age 65–69 | 2 | | High | 10–13 | Receiver Operating | Development Cohort | Validation Cohort
Lee, 2006^71^ 4-year mortality | 4) age 70–74 | 3 | | Very high | >=14 | Characteristic curve area
Lee, 2006^71^ 4-year mortality | 5) age 75–79 | 4 | | Very high | >=14 | By risk group | 0.84 | 0.817
Lee, 2006^71^ 4-year mortality | 6) age 80–84 | 5 | | Very high | >=14 | By quartile of risk | 0.842 | 0.819
Lee, 2006^71^ 4-year mortality | 7) age >=85 | 7 | | Very high | >=14
Lee, 2006^71^ 4-year mortality | 8) diabetes mellitus | 1 | | Very high | >=14
Lee, 2006^71^ 4-year mortality | 9) cancer | 2 | | Very high | >=14
Lee, 2006^71^ 4-year mortality | 10) lung cancer | 2 | | Very high | >=14
Lee, 2006^71^ 4-year mortality | 11) heart failure | 2 | | Very high | >=14
Lee, 2006^71^ 4-year mortality | 12) body mass index<25 | 1 | | Very high | >=14
Lee, 2006^71^ 4-year mortality | 13) current smoker | 2 | | Very high | >=14
Lee, 2006^71^ 4-year mortality | 14) bathing | 2 | | Very high | >=14
Lee, 2006^71^ 4-year mortality | 15) managing finances | 2 | | Very high | >=14
Lee, 2006^71^ 4-year mortality | 16) walking several blocks | 2 | | Very high | >=14
Lee, 2006^71^ 4-year mortality | 17) pushing/pulling heavy objects | 1 | | Very high | >=14
Song, 2004^364^ 6-year mortality | 1 dichotomized variables | | The artificial neural network (ANN) has 3 layers: input layer (40 neurons); intermediate hidden layer of 20 neurons; and the output neuron. All input neurons fed into each of the hidden layer neurons and every neuron in the hidden layer was connected to the single output neuron. The output of a neuron was determined by the summary input of all the neurons to it. The artificial neural network survival classification output is a function of the input variables, the network architecture and the weights. | survivors | <0.5 | The area under the receiver operating characteristic curve was calculated for the artificial neural network and unweighted frailty index
Song, 2004^364^ 6-year mortality | 2 3-level variables | | | died | >=0.5 | The area under the receiver operating characteristic curve was calculated for the artificial neural network and unweighted frailty index
Song, 2004^364^ 6-year mortality | 3 5-level variables | | | died | >=0.5 | | ANN | Frailty index
Song, 2004^364^ 6-year mortality | 3 5-level variables | | | died | >=0.5 | Receiver Operating | 0.86 | 0.62
Song, 2004^364^ 6-year mortality | 3 5-level variables | | | died | >=0.5 | Characteristic curve area
Song, 2004^364^ 6-year mortality | 3 5-level variables | | | died | >=0.5
Fried, 1998^54^ 5-year mortality | Same as above predictors | Not reported | A risk score was computed by multiplying, for each individual, the regression coefficient from each variable in the Cox model by the value of the corresponding variable for the individual. These products were summed to give a prognosis score for each individual. | 1 2 3 5 | Based on quintile | The 5-year overall mortality rate and mortality per person-year for each risk group were calculated and compared between cardiovascular health study (CHS) original cohort and the African American cohort.
Fried, 1998^54^ 5-year mortality | Same as above predictors | Not reported | | 1 2 3 5 | Based on quintile | | Original cohort | African American cohort
Fried, 1998^54^ 5-year mortality | Same as above predictors | Not reported | | 1 2 3 5 | Based on quintile | Chi-square trend | 659.73 | 55.97
Fried, 1998^54^ 5-year mortality | Same as above predictors | Not reported | | 1 2 3 5 | Based on quintile | P-value | <.001 | <.001
Inouye, 2003^122^ 1-year mortality | 1) high risk diagnoses; | 0–3 | A burden of illness score was calculated for each person by summing all the points for each present risk factor. | I | 0–1 | No. of death/No. at risk, hazard ratio, 95% CI for each risk group were calculated and compared between development and validation cohort.
Inouye, 2003^122^ 1-year mortality | 2) albumin ≤3.5 mg/dL | 0/1 | A burden of illness score was calculated for each person by summing all the points for each present risk factor. | II | 2 | No. of death/No. at risk, hazard ratio, 95% CI for each risk group were calculated and compared between development and validation cohort.
Inouye, 2003^122^ 1-year mortality | 3 Creatinine >15 mg/dL | 0/1 | A burden of illness score was calculated for each person by summing all the points for each present risk factor. | III | 3 | | Derivation Cohort | Validation Cohort
Inouye, 2003^122^ 1-year mortality | 4) dementia; | 0/1 | A burden of illness score was calculated for each person by summing all the points for each present risk factor. | IV | ≥4 | Receiver Operating | 0.83 (0.78–0.87) | 0.77 (0.74–0.8)
Inouye, 2003^122^ 1-year mortality | 5 walking impairment | 0/1 | A burden of illness score was calculated for each person by summing all the points for each present risk factor. | IV | ≥4 | Characteristic curve area
Inouye, 2003^122^ 1-year mortality | 5 walking impairment | 0/1 | A burden of illness score was calculated for each person by summing all the points for each present risk factor. | IV | ≥4 | Chi-square trend | 179.33 | 274.01
Inouye, 2003^122^ 1-year mortality | 5 walking impairment | 0/1 | A burden of illness score was calculated for each person by summing all the points for each present risk factor. | IV | ≥4 | P-value | 0.001 | 0.001
Melzer, 2003*14 4-year mortality | 1) gait speed | N/A | 1. In the logistic regression models all physiological measures were coded into ranks or categories;; 2. the ß values for different coding of three measures used in the difficulty and inability equations were calculated;; 3. difficulty and inability models for calculating MOBLI scores were developed;; 4. coefficients (beta values) of different coding in three measures used in the logistic regression models and equations to produce the MOBLI score were calculated and entered Into difficulty and inability models;; 5. MOBLI score represents the probability of risk to mobility limitations or impairments, the higher the score the higher the probability of mobility limitation and impairment. | 1^st^ quintile | <0.0416 | Crude and age/sex-adjusted death rates, hazard ratio for self-reported and predicted inability to walk 1/2 mile based on mobility-related limitation index scores (MOBLI).
Melzer, 2003*14 4-year mortality | 2) time to 5 chair stands | N/A | | 2^nd^ quintile | 0.0416–0.0954 | Crude and age/sex-adjusted death rates, hazard ratio for self-reported and predicted inability to walk 1/2 mile based on mobility-related limitation index scores (MOBLI).
Melzer, 2003*14 4-year mortality | 3) peak expiratory flow | N/A | | 3^rd^ quintile | 0.0955–0.1984 | Crude and age/sex-adjusted death rates, hazard ratio for self-reported and predicted inability to walk 1/2 mile based on mobility-related limitation index scores (MOBLI).
Melzer, 2003*14 4-year mortality | 3) peak expiratory flow | N/A | | 4^th^ quintile | 0.1985–0.4395 | Unable to walk1/2 mile | MOBLI | Self-reported
Melzer, 2003*14 4-year mortality | 3) peak expiratory flow | N/A | | 5^th^ quintile | >0.4395 | By death rate | 31.7 | 32.4
Melzer, 2003*14 4-year mortality | 3) peak expiratory flow | N/A | | 5^th^ quintile | >0.4395 | By hazard ratio | 2.71(2.28–3.21) | 2.95(2.48–3.5)
Melzer, 2003*14 4-year mortality | 3) peak expiratory flow | N/A | | 5^th^ quintile | >0.4395
Ensrud, 2009^51^ Recurrent falls; disability; non- spine fracture; death | 1) weight loss of 5% or more between the baseline and 2^nd^ examination | | Frailty is defined by the presence of 2 or more of the 3 components | robust | 0 | Number and percentage of participants with recurrent falls, disability, hip fracture and death, 95% CI, odds ratio, hazard ratio for each risk group according to Study of Osteoporotic Fractures and Cardiovascular Health Study index
Ensrud, 2009^51^ Recurrent falls; disability; non- spine fracture; death | 1) weight loss of 5% or more between the baseline and 2^nd^ examination | | Frailty is defined by the presence of 2 or more of the 3 components | immediate | 1
Ensrud, 2009^51^ Recurrent falls; disability; non- spine fracture; death | 1) weight loss of 5% or more between the baseline and 2^nd^ examination | | Frailty is defined by the presence of 2 or more of the 3 components | frailty | ≥2
Ensrud, 2009^51^ Recurrent falls; disability; non- spine fracture; death | 2) inability to rise from a chair 5 times without using the arms | | Frailty is defined by the presence of 2 or more of the 3 components | frailty | ≥2 | Receiver Operating | SOF | CHS
Ensrud, 2009^51^ Recurrent falls; disability; non- spine fracture; death | 2) inability to rise from a chair 5 times without using the arms | | Frailty is defined by the presence of 2 or more of the 3 components | frailty | ≥2 | Characteristic curve area
Ensrud, 2009^51^ Recurrent falls; disability; non- spine fracture; death | 3) poor energy | | Frailty is defined by the presence of 2 or more of the 3 components | frailty | ≥2 | Recurrent falls | 0.63 (0.6–0.66) | 0.63 (0.6–0.66)
Ensrud, 2009^51^ Recurrent falls; disability; non- spine fracture; death | 3) poor energy | | Frailty is defined by the presence of 2 or more of the 3 components | frailty | ≥2 | Non-spine fracture | 0.63 (0.58–0.67) | 0.63 (0.58–0.67)
Ensrud, 2009^51^ Recurrent falls; disability; non- spine fracture; death | 3) poor energy | | Frailty is defined by the presence of 2 or more of the 3 components | frailty | ≥2 | Death | 0.71 (0.67–0.75) | 0.72 (0.69–0.76)
Ensrud, 2009^51^ Recurrent falls; disability; non- spine fracture; death | 3) poor energy | | Frailty is defined by the presence of 2 or more of the 3 components | frailty | ≥2 | Disability | 0.68 (0.65–0.71) | 0.68 (0.65–0.71)
Albertsson, 2007^365^ 2-year Hip fractures; 2-year Fragility fractures 2-year mortality | 1) age 80 years or older | unweighted | | Low risk | 0–1 | Number and percentage of participants with hip fracture, fragility fracture and mortality, 95% CI, odds ratio, for each risk group
Albertsson, 2007^365^ 2-year Hip fractures; 2-year Fragility fractures 2-year mortality | 2) weight less than 60 kg | unweighted | | High risk | 2–4 | Number and percentage of participants with hip fracture, fragility fracture and mortality, 95% CI, odds ratio, for each risk group
Albertsson, 2007^365^ 2-year Hip fractures; 2-year Fragility fractures 2-year mortality | 3) previous fragility fracture | unweighted | | High risk | 2–4 | Number and percentage of participants with hip fracture, fragility fracture and mortality, 95% CI, odds ratio, for each risk group
Albertsson, 2007^365^ 2-year Hip fractures; 2-year Fragility fractures 2-year mortality | 4) need to use arms to rise from a chair 5 times without using her arms | unweighted | | High risk | 2–4 | Receiver Operating | Development cohort
Albertsson, 2007^365^ 2-year Hip fractures; 2-year Fragility fractures 2-year mortality | 4) need to use arms to rise from a chair 5 times without using her arms | unweighted | | High risk | 2–4 | Characteristic curve area
Albertsson, 2007^365^ 2-year Hip fractures; 2-year Fragility fractures 2-year mortality | 4) need to use arms to rise from a chair 5 times without using her arms | unweighted | | High risk | 2–4 | Hip fractures | 0.72 (0.64–0.81)
Albertsson, 2007^365^ 2-year Hip fractures; 2-year Fragility fractures 2-year mortality | 4) need to use arms to rise from a chair 5 times without using her arms | unweighted | | High risk | 2–4 | Fragility fractures
Albertsson, 2007^365^ 2-year Hip fractures; 2-year Fragility fractures 2-year mortality | 4) need to use arms to rise from a chair 5 times without using her arms | unweighted | | High risk | 2–4 | Mortality | 0.75 (0.71–0.79)
Schonberg, 2009^366^ 5-year mortality | 1) age | | Derived from the beta coefficients of each factor in the final model | | 0–1 | Number and percentage of mortality, 95% CI according to quintile of risk and
Schonberg, 2009^366^ 5-year mortality | 65–69 | 0 | Derived from the beta coefficients of each factor in the final model | | 2–3 | Point score were calculated.
Schonberg, 2009^366^ 5-year mortality | 70–74 | 1 | Derived from the beta coefficients of each factor in the final model | | 4–5
Schonberg, 2009^366^ 5-year mortality | 75–79 | 3 | Derived from the beta coefficients of each factor in the final model | | 6–7
Schonberg, 2009^366^ 5-year mortality | 80–84 | 5 | Derived from the beta coefficients of each factor in the final model | | 8–9
Schonberg, 2009^366^ 5-year mortality | 85+ | 7 | Derived from the beta coefficients of each factor in the final model | | 10–11 | Receiver Operating | 0.75 (other info isn’t reported)
Schonberg, 2009^366^ 5-year mortality | 2) Male sex | 3 | Derived from the beta coefficients of each factor in the final model | | 12–13 | Characteristic curve area
Schonberg, 2009^366^ 5-year mortality | 3) Smoking status | | Derived from the beta coefficients of each factor in the final model | | 14–15
Schonberg, 2009^366^ 5-year mortality | never | 0 | Derived from the beta coefficients of each factor in the final model | | 16–17
Schonberg, 2009^366^ 5-year mortality | Former | 1 | Derived from the beta coefficients of each factor in the final model | | 18+
Schonberg, 2009^366^ 5-year mortality | Current | 3 | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Schonberg, 2009^366^ 5-year mortality | 4) body mass index<25 kg/(m*m) | 2 | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Schonberg, 2009^366^ 5-year mortality | 5) comorbid conditions | | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Schonberg, 2009^366^ 5-year mortality | COPD | 2 | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Schonberg, 2009^366^ 5-year mortality | Diabetes mellitus | 2 | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Schonberg, 2009^366^ 5-year mortality | Cancer | 2 | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Schonberg, 2009^366^ 5-year mortality | 6) overnight hospitalization in | | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Schonberg, 2009^366^ 5-year mortality | Past year | | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Schonberg, 2009^366^ 5-year mortality | None | 0 | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Schonberg, 2009^366^ 5-year mortality | One | 1 | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Schonberg, 2009^366^ 5-year mortality | Two or more | 3 | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Schonberg, 2009^366^ 5-year mortality | 7) perceived health | | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Schonberg, 2009^366^ 5-year mortality | Excellent/very good | 0 | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Schonberg, 2009^366^ 5-year mortality | Good | 1 | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Schonberg, 2009^366^ 5-year mortality | Fair/good | 2 | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Schonberg, 2009^366^ 5-year mortality | 8) functional measures | | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Schonberg, 2009^366^ 5-year mortality | Dependent in at least 1 IADL | 2 | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Schonberg, 2009^366^ 5-year mortality | Difficulty walking several blocks | 3 | Derived from the beta coefficients of each factor in the final model | Also by quintile of risk
Garcia-Gonzalez, 2009^367^ 2-year mortality | Same as above predictors | | 1) For variables with yes/no categories, yes=1; No=0 | Level 1 | .00–.07 | Number and hazard ratios of mortality, 95% CI according to different levels of the frailty index were calculated. No ROC reported
Garcia-Gonzalez, 2009^367^ 2-year mortality | Same as above predictors | | 1) For variables with yes/no categories, yes=1; No=0 | Level 2 | .07–.14 | Number and hazard ratios of mortality, 95% CI according to different levels of the frailty index were calculated. No ROC reported
Garcia-Gonzalez, 2009^367^ 2-year mortality | Same as above predictors | | 2) for poor self-assessed health: poor=1; fair=0.75; good=0.5; very good=0.25; excellent=0 | Level 3 | .14–.21 | Number and hazard ratios of mortality, 95% CI according to different levels of the frailty index were calculated. No ROC reported
Garcia-Gonzalez, 2009^367^ 2-year mortality | Same as above predictors | | 2) for poor self-assessed health: poor=1; fair=0.75; good=0.5; very good=0.25; excellent=0 | Level 4 | .21–.35 | Number and hazard ratios of mortality, 95% CI according to different levels of the frailty index were calculated. No ROC reported
Garcia-Gonzalez, 2009^367^ 2-year mortality | Same as above predictors | | 2) for poor self-assessed health: poor=1; fair=0.75; good=0.5; very good=0.25; excellent=0 | Level 5 | .35–.65 | Number and hazard ratios of mortality, 95% CI according to different levels of the frailty index were calculated. No ROC reported
Garcia-Gonzalez, 2009^367^ 2-year mortality | Same as above predictors | | 3) For vision problems: legally blind=1; poor=0.8; fair=0.6; good=0.4; very good=0.2; excellent=0 | Level 5 | .35–.65 | Number and hazard ratios of mortality, 95% CI according to different levels of the frailty index were calculated. No ROC reported
Garcia-Gonzalez, 2009^367^ 2-year mortality | Same as above predictors | | 4) For hearing problems: legally deaf=1; poor=0.8; fair=0.6; good=0.4; very good=0.2; excellent=0 | Level 5 | .35–.65 | Number and hazard ratios of mortality, 95% CI according to different levels of the frailty index were calculated. No ROC reported
Garcia-Gonzalez, 2009^367^ 2-year mortality | Same as above predictors | | 5) for bodily pain: frequent and severe=1; Frequent and moderate=2/3; frequent and Mild=1/3; not frequent=0 | Level 5 | .35–.65 | Number and hazard ratios of mortality, 95% CI according to different levels of the frailty index were calculated. No ROC reported
Garcia-Gonzalez, 2009^367^ 2-year mortality | Same as above predictors | | 6) for depression symptoms: 1/9 for each positive answer if the participants felt: depressed; unhappy; lonely; tired; sad; did not enjoy life; had no energy; restless sleep or thought that everything was an effort; 0= none of the above Frailty index is defined as a proportion of the total number of deficits an individual has with respect to the 34 deficits included. | Level 5 | .35–.65 | Number and hazard ratios of mortality, 95% CI according to different levels of the frailty index were calculated. No ROC reported
Carey, 2004^368^ 2-year mortality; | 1) male gender | 2 | The beta-coefficient for each risk factor was divided by the lowest beta-coefficient (for bathing) and rounded to the nearest integer; all the points for each present risk factor were summed up and is the risk score for each patient. | low | 0–2 | No. at risk, mortality rate for each risk group was calculated and compared between development and validation cohorts.
Carey, 2004^368^ 2-year mortality; | 2) age | | | medium | 3–6 | No. at risk, mortality rate for each risk group was calculated and compared between development and validation cohorts.
Carey, 2004^368^ 2-year mortality; | 76–80 | 1 | | high | 7–10 | No. at risk, mortality rate for each risk group was calculated and compared between development and validation cohorts.
Carey, 2004^368^ 2-year mortality; | 81–85; | 2 | | high | 7–10 | | Derivation cohort | Validation cohort
Carey, 2004^368^ 2-year mortality; | >85 | 2 | | high | 7–10 | Receiver operating | 0.76 | 0.74
Carey, 2004^368^ 2-year mortality; | )3 dependence in bathing | 1 | | high | 7–10
Carey, 2004^368^ 2-year mortality; | 4) dependence in shopping | 2 | | high | 7–10
Carey, 2004^368^ 2-year mortality; | 5) difficulty walking several blocks | 2 | | high | 7–10
Carey, 2004^368^ 2-year mortality; | 6) difficulty pulling/pushing heavy objects | 1 | | high | 7–10
Levine, 2007^369^ 1-year mortality | 1) age | | The beta-coefficient for each risk factor was divided by the lowest beta-coefficient (for congestive heart failure) and rounded to the nearest integer; all the points for each present risk factor were added up and is the risk score for each patient. | Low-risk | 0–1 | No. of death/No. at risk, 95% CI for each risk group were calculated and
Levine, 2007^369^ 1-year mortality | 70–74 | 1 | | Medium risk | 2 | Compared between derivation and validation cohorts.
Levine, 2007^369^ 1-year mortality | 75–79 | 2 | | High-risk | 3 | Receiver Operating | Derivation Cohort | Validation Cohort
Levine, 2007^369^ 1-year mortality | 80–84 | 2 | | Very high- risk | >=4 | Characteristic curve area
Levine, 2007^369^ 1-year mortality | 85–89 | 2 | | Very high- risk | >=4 | By risk group | 0.67 | 0.65
Levine, 2007^369^ 1-year mortality | ≥90 | 2 | | Very high- risk | >=4 | By quartile of risk | 0.70 | 0.68
Levine, 2007^369^ 1-year mortality | 2) Discharge to nursing home or skilled nursing facility | | | Very high- risk | >=4
Levine, 2007^369^ 1-year mortality | 2) Discharge to nursing home or skilled nursing facility | 1 | | Very high- risk | >=4
Levine, 2007^369^ 1-year mortality | 3) length of stay ≥5 days | 1 | | Very high- risk | >=4
Levine, 2007^369^ 1-year mortality | 4) congestive heart failure | 1 | | Very high- risk | >=4
Levine, 2007^369^ 1-year mortality | 5) peripheral vascular disease | 1 | | Very high- risk | >=4
Levine, 2007^369^ 1-year mortality | 6) dementia | 1 | | Very high- risk | >=4
Levine, 2007^369^ 1-year mortality | 7) renal disease | 1 | | Very high- risk | >=4
Levine, 2007^369^ 1-year mortality | 8) hematologic and solid Malignancy | 1 | | Very high- risk | >=4
Levine, 2007^369^ 1-year mortality | 9) metastatic cancer | 2 | | Very high- risk | >=4
Pijpers, 2009^370^ 3-year mortality | 1) age: per 10 years | 4 | 1. Weight was obtained by multiplying the Regression coefficient by 10 rounded up to the nearest integer;; 2. the weight will be multiplied by the patient’s characteristics value and the sum of these values is the risk score for each patient. | Very good | <45 | ROC curves were computed; mean predicted 3-year mortality risk and observed 3-year mortality were calculated and compared in each quintile of risk score
Pijpers, 2009^370^ 3-year mortality | 2) male sex | 10 | | Good | 45–51 | ROC curves were computed; mean predicted 3-year mortality risk and observed 3-year mortality were calculated and compared in each quintile of risk score
Pijpers, 2009^370^ 3-year mortality | 3) living alone | 5 | | Moderate | 52–57
Pijpers, 2009^370^ 3-year mortality | 4) cardiovascular disease | 4 | | Poor | 58–63 | Receiver Operating | 0.78 (0.71–0.84) (other info not reported)c
Pijpers, 2009^370^ 3-year mortality | 5) diabetes | 4 | | Very poor | >63
Pijpers, 2009^370^ 3-year mortality | 6) medication number ≥2 | 5 | | Very poor | >63
Pijpers, 2009^370^ 3-year mortality | 7) Body mass index<18.5 | 12 | | Very poor | >63
Pijpers, 2009^370^ 3-year mortality | 8) Elderly Mobility Scale score <20 | 5 | | Very poor | >63
Pijpers, 2009^370^ 3-year mortality | 9) motor deficit in ADL | 4 | | Very poor | >63
Pijpers, 2009^370^ 3-year mortality | 10) process deficit in ADL | 7 | | Very poor | >63
Mazzaglia, 2007^187^ 15-month mortality 15-month hospitalization | 1) age: | | Each risk factor was assigned a score based on the ratio between the regression b-coefficient for that variable and the lowest significant b-coefficient in the corresponding logistic regression (which is being 75–84 years old). The ratio is rounded up to the nearest integer. A summary point score was calculated for each participant by adding the points for each risk factor present | | 0 | Number of death/who at risk, percentage, 95%CI, sensitivity and specificity were calculated and compared for both cohorts according to risk scores
Mazzaglia, 2007^187^ 15-month mortality 15-month hospitalization | 65–74 | 0 | | | 1 | Number of death/who at risk, percentage, 95%CI, sensitivity and specificity were calculated and compared for both cohorts according to risk scores
Mazzaglia, 2007^187^ 15-month mortality 15-month hospitalization | 75–84 | 1 | | | 2 | Receiver Operating | Development cohort | Validation cohort
Mazzaglia, 2007^187^ 15-month mortality 15-month hospitalization | >=85 | 1 | | | ≥3 | Characteristic curve area
Mazzaglia, 2007^187^ 15-month mortality 15-month hospitalization | 2) sex | | | | ≥3 | Mortality | 0.75 (0.72–0.78) | 0.75(0.73–0.78)
Mazzaglia, 2007^187^ 15-month mortality 15-month hospitalization | female | 0 | | | ≥3 | Hospitalization | 0.68(0.66–0.71) | 0.67(0.65–0.7)
Mazzaglia, 2007^187^ 15-month mortality 15-month hospitalization | Male | 1 | | | ≥3
Mazzaglia, 2007^187^ 15-month mortality 15-month hospitalization | 3) positive responses to the | | | | ≥3
Mazzaglia, 2007^187^ 15-month mortality 15-month hospitalization | Screening test | | | | ≥3
Mazzaglia, 2007^187^ 15-month mortality 15-month hospitalization | 0–1 | 0 | | | ≥3
Mazzaglia, 2007^187^ 15-month mortality 15-month hospitalization | 2–3 | 2 | | | ≥3
Mazzaglia, 2007^187^ 15-month mortality 15-month hospitalization | 4–6 | 1 | | | ≥3
Mazzaglia, 2007^187^ 15-month mortality 15-month hospitalization | 4) having hospitalization in the previous 6 months | 4 | | | ≥3
Mazzaglia, 2007^187^ 15-month mortality 15-month hospitalization | 5) having ≥5 prescriptions | 3 | | | ≥3
Jones, 2004^144^ 5-year mortality 5-year institutionalization | 1) impairment index | | 1. Each of 10 domains in impairment index was scored such that 0=no problem; 0.5=minor problem; 1=major problem; 2. the CIRS codes the severity of 14 co-existing diseased body system as 0,1, or 2 and standardized into a range of 0–4 (CIRS/6); 3. the current index is calculated as # of total deficits/total # deficits (impairment Index + comorbidity index)/14 | Level 1 | ≤0.23 | Mean and standard deviation for sociodemographic, clinical variables and uses of clinical services were calculated and compared by index levels.
Jones, 2004^144^ 5-year mortality 5-year institutionalization | 2) comorbidity index | | | Level 2 | 0.24–0.31 | Mean and standard deviation for sociodemographic, clinical variables and uses of clinical services were calculated and compared by index levels.
Jones, 2004^144^ 5-year mortality 5-year institutionalization | 2) comorbidity index | | | Level 3 | 0.32–0.4 | Receiver Operating | FI-GCA | FI
Jones, 2004^144^ 5-year mortality 5-year institutionalization | 2) comorbidity index | | | Level 4 | 0.41–0.48 | Characteristic curve area
Jones, 2004^144^ 5-year mortality 5-year institutionalization | 2) comorbidity index | | | Level 5 | 0.49–0.6 | Mortality | 0.67 | 0.7
Jones, 2004^144^ 5-year mortality 5-year institutionalization | 2) comorbidity index | | | Level 6 | 0.61–0.74 | hospitalization | 0.66 | 0.75
Jones, 2004^144^ 5-year mortality 5-year institutionalization | 2) comorbidity index | | | Level 7 | ≥0.75
Fried, 2001^55^ 3-year mortality 7-year mortality 3-year incident falls 7-year incident falls 3-year disability 7-year disability 3-year mobility 7-year mobility | 1) weight loss (shrinking); | | Defined as frail if ≥3 components present; Intermediate frail if 1 or 2 components present; Not frail if none present | Not frail | | Cox proportional hazards models were used to assess the independent Predictive validity of frailty phenotype.
Fried, 2001^55^ 3-year mortality 7-year mortality 3-year incident falls 7-year incident falls 3-year disability 7-year disability 3-year mobility 7-year mobility | 2) grip strength (weakness) | | Defined as frail if ≥3 components present; Intermediate frail if 1 or 2 components present; Not frail if none present | Intermediate frail | | Cox proportional hazards models were used to assess the independent Predictive validity of frailty phenotype.
Fried, 2001^55^ 3-year mortality 7-year mortality 3-year incident falls 7-year incident falls 3-year disability 7-year disability 3-year mobility 7-year mobility | 3) exhaustion (poor endurance) | | Defined as frail if ≥3 components present; Intermediate frail if 1 or 2 components present; Not frail if none present | Frail | | 3-year outcomes/HR(CI) | Intermediate | Ffrail
Fried, 2001^55^ 3-year mortality 7-year mortality 3-year incident falls 7-year incident falls 3-year disability 7-year disability 3-year mobility 7-year mobility | 4) walking time (slowness) | | Defined as frail if ≥3 components present; Intermediate frail if 1 or 2 components present; Not frail if none present | Frail | | Incident fall | 1.16(1–1.34) | 1.29(1–1.68)
Fried, 2001^55^ 3-year mortality 7-year mortality 3-year incident falls 7-year incident falls 3-year disability 7-year disability 3-year mobility 7-year mobility | 5) low physical activity | | Defined as frail if ≥3 components present; Intermediate frail if 1 or 2 components present; Not frail if none present | Frail | | Mobility | 1.58(1.41–1.76)* | 1.5(1.23–1.82)
Fried, 2001^55^ 3-year mortality 7-year mortality 3-year incident falls 7-year incident falls 3-year disability 7-year disability 3-year mobility 7-year mobility | 5) low physical activity | | Defined as frail if ≥3 components present; Intermediate frail if 1 or 2 components present; Not frail if none present | Frail | | Disability | 1.67(1.41–1.99) | 1.98(1.54–2.55)
Fried, 2001^55^ 3-year mortality 7-year mortality 3-year incident falls 7-year incident falls 3-year disability 7-year disability 3-year mobility 7-year mobility | 5) low physical activity | | Defined as frail if ≥3 components present; Intermediate frail if 1 or 2 components present; Not frail if none present | Frail | | First hospitalization | 1.13(1.03–1.25) | 1.29(1.09–1.54)
Fried, 2001^55^ 3-year mortality 7-year mortality 3-year incident falls 7-year incident falls 3-year disability 7-year disability 3-year mobility 7-year mobility | 5) low physical activity | | Defined as frail if ≥3 components present; Intermediate frail if 1 or 2 components present; Not frail if none present | Frail | | Mortality | 1.49(1.11–1.99) | 2.24(1.51–3.33)
Fried, 2001^55^ 3-year mortality 7-year mortality 3-year incident falls 7-year incident falls 3-year disability 7-year disability 3-year mobility 7-year mobility | 5) low physical activity | | Defined as frail if ≥3 components present; Intermediate frail if 1 or 2 components present; Not frail if none present | Frail | | 7-year outcomes/HR(CI) | Intermediate | Ffrail
Fried, 2001^55^ 3-year mortality 7-year mortality 3-year incident falls 7-year incident falls 3-year disability 7-year disability 3-year mobility 7-year mobility | 5) low physical activity | | Defined as frail if ≥3 components present; Intermediate frail if 1 or 2 components present; Not frail if none present | Frail | | Incident fall | 1.12(1–1.26) | 1.23(0.99–1.54)
Fried, 2001^55^ 3-year mortality 7-year mortality 3-year incident falls 7-year incident falls 3-year disability 7-year disability 3-year mobility 7-year mobility | 5) low physical activity | | Defined as frail if ≥3 components present; Intermediate frail if 1 or 2 components present; Not frail if none present | Frail | | Mobility | 1.41(1.29–1.54) | 1.36(1.15–1.62)
Fried, 2001^55^ 3-year mortality 7-year mortality 3-year incident falls 7-year incident falls 3-year disability 7-year disability 3-year mobility 7-year mobility | 5) low physical activity | | Defined as frail if ≥3 components present; Intermediate frail if 1 or 2 components present; Not frail if none present | Frail | | Disability | 1.55(1.38–1.75) | 1.79(1.47–2.17)
Fried, 2001^55^ 3-year mortality 7-year mortality 3-year incident falls 7-year incident falls 3-year disability 7-year disability 3-year mobility 7-year mobility | 5) low physical activity | | Defined as frail if ≥3 components present; Intermediate frail if 1 or 2 components present; Not frail if none present | Frail | | First hospitalization | 1.11(1.03–1.19) | 1.27(1.11–1.46)
Fried, 2001^55^ 3-year mortality 7-year mortality 3-year incident falls 7-year incident falls 3-year disability 7-year disability 3-year mobility 7-year mobility | 5) low physical activity | | Defined as frail if ≥3 components present; Intermediate frail if 1 or 2 components present; Not frail if none present | Frail | | Mortality | 1.32(1.13–1.55) | 1.63(1.27–2.08)
Fried, 2001^55^ 3-year mortality 7-year mortality 3-year incident falls 7-year incident falls 3-year disability 7-year disability 3-year mobility 7-year mobility | 5) low physical activity | | Defined as frail if ≥3 components present; Intermediate frail if 1 or 2 components present; Not frail if none present | Frail | | * highlighted area indicated significance ≤0.05
Markides, 2001^371^ 2-year mortality | Set one includes: | N/A | N/A | N/A | | Logistic regression models were used to assess the predictivity of summary
Markides, 2001^371^ 2-year mortality | 1) age (75+vs.65–74) | N/A | N/A | N/A | | Performance score and short walk measures on 2-year mortality.
Markides, 2001^371^ 2-year mortality | 2) gender (male) | N/A | N/A | N/A | | Outcome measures/OR(CI) | Set one | Set two
Markides, 2001^371^ 2-year mortality | 3) summary performance | N/A | N/A | N/A | | Age (75 vs.65–74) | 1.42(1.02–1.97) | 1.46(1.06–2.03)
Markides, 2001^371^ 2-year mortality | Score (vs. 9–11) | N/A | N/A | N/A | | Gender (male) | 1.84(1.34–2.52) | 1.76(1.29–2.42)
Markides, 2001^371^ 2-year mortality | 7–8 | N/A | N/A | N/A | | Summary performance
Markides, 2001^371^ 2-year mortality | 4–6 | N/A | N/A | N/A | | Score (vs. 9–11)
Markides, 2001^371^ 2-year mortality | 1–3 | N/A | N/A | N/A | | 7–8 | 2.02(1.12–3.64)*
Markides, 2001^371^ 2-year mortality | 0 | N/A | N/A | N/A | | 4–6 | 3.25(1.86–5.67)
Markides, 2001^371^ 2-year mortality | 4) lower body ADL disability | N/A | N/A | N/A | | 1–3 | 2.87(1.37–6.05)
Markides, 2001^371^ 2-year mortality | 5) chronic conditions | N/A | N/A | N/A | | 0 | 7.39(3.86–14.13)
Markides, 2001^371^ 2-year mortality | Hypertension | N/A | N/A | N/A | | Short walk (vs.4)
Markides, 2001^371^ 2-year mortality | Heart disease | N/A | N/A | N/A | | 3 | | 2.16(1.12–4.14)
Markides, 2001^371^ 2-year mortality | Cancer | N/A | N/A | N/A | | 2 | | 2.57(1.33–4.94)
Markides, 2001^371^ 2-year mortality | Diabetes | N/A | N/A | N/A | | 1 | | 3.64(1.93–6.85)
Markides, 2001^371^ 2-year mortality | Hip fracture | N/A | N/A | N/A | | 0 | | 7.47(3.83–14.55)
Markides, 2001^371^ 2-year mortality | stroke | N/A | N/A | N/A | | Lower body ADL Disability | 1.46(0.9–2.36) | 1..48(0.93–2.36)
Markides, 2001^371^ 2-year mortality | Set two includes: | N/A | N/A | N/A | | Chronic conditions
Markides, 2001^371^ 2-year mortality | 1) age (75+vs.65–74) | N/A | N/A | N/A | | hypertension | 1.09(0.79–1.51) | 1.11(0.8–1.53)
Markides, 2001^371^ 2-year mortality | 2) gender (male) | N/A | N/A | N/A | | Heart disease | 1.59(1.07–2.38) | 1.6(1.08–2.39)
Markides, 2001^371^ 2-year mortality | 3) summary performance | N/A | N/A | N/A | | Cancer | 3.18(2.02–5.01) | 3.37(2.14–5.3)
Markides, 2001^371^ 2-year mortality | Score (vs.4) | N/A | N/A | N/A | | Diabetes | 1.78(1.29–2.51) | 1.8(1.29–2.52)
Markides, 2001^371^ 2-year mortality | 3 | N/A | N/A | N/A | | Hip fracture | 1.35(0.73–2.5) | 1.35(0.73–2.48)
Markides, 2001^371^ 2-year mortality | 2 | N/A | N/A | N/A | | Stroke | 0.81(0.48–1.36) | 0.82(0.49–1.38)
Markides, 2001^371^ 2-year mortality | 2 | N/A | | N/A | | * highlighted area indicated significance 0.05
Markides, 2001^371^ 2-year mortality | 0 | N/A | | N/A | | * highlighted area indicated significance 0.05
| 4) lower body ADL disability | N/A | | N/A | | * highlighted area indicated significance 0.05
| 5) chronic conditions | N/A | | N/A | | * highlighted area indicated significance 0.05
| Hypertension | N/A | | N/A | | * highlighted area indicated significance 0.05
| Heart disease | N/A | | N/A | | * highlighted area indicated significance 0.05
| Cancer | N/A | | N/A | | * highlighted area indicated significance 0.05
| Diabetes | N/A | | N/A | | * highlighted area indicated significance 0.05
| Hip fracture | N/A | | N/A | | * highlighted area indicated significance 0.05
| Stroke | N/A | | N/A | | * highlighted area indicated significance 0.05
Gill, 2006^372^ 6-year mortality | 1) weight loss | | Defined as frail if 3 components present; | Nonfrail | | Cox proportional hazards models were used to calculate the unadjusted hazard ratios and assess the predictive validity for each component.
Gill, 2006^372^ 6-year mortality | 2) muscle weakness | | Prefrail if 1 or 2 components present; | Prefrail | | Cox proportional hazards models were used to calculate the unadjusted hazard ratios and assess the predictive validity for each component.
Gill, 2006^372^ 6-year mortality | 3) exhaustion | | Nonfrail if none present | Frail | | Outcome measures/HR | 6-year mortality
Gill, 2006^372^ 6-year mortality | 4) slow walking speed | | Nonfrail if none present | Frail | | Weight loss | 2.03*
Gill, 2006^372^ 6-year mortality | 5) low physical activity | | Nonfrail if none present | Frail | | Exhaustion | 1.97
Gill, 2006^372^ 6-year mortality | 5) low physical activity | | Nonfrail if none present | Frail | | Low physical activity | 2.83
Gill, 2006^372^ 6-year mortality | 5) low physical activity | | Nonfrail if none present | Frail | | Muscle weakness | 1.93
Gill, 2006^372^ 6-year mortality | 5) low physical activity | | Nonfrail if none present | Frail | | Slow walking speed | 2.28
Gill, 2006^372^ 6-year mortality | 5) low physical activity | | Nonfrail if none present | Frail | | * highlighted area indicated significance <=0.05 and unadjusted HR
Graham, 2009^202^ 10-year mortality | 1) weight loss | 0 or 1 | Each item was scored dichotomously (0 vs. 1); The total score was recorded as the sum of all five items (range: 0–5) | Non-frail | 0 | Cox proportional hazards models were used to assess the independent
Graham, 2009^202^ 10-year mortality | 2) grip strength | 0 or 1 | Each item was scored dichotomously (0 vs. 1); The total score was recorded as the sum of all five items (range: 0–5) | Pre-frail | 1–2 | Predictive validity of frailty index
Graham, 2009^202^ 10-year mortality | 3) exhaustion | 0 or 1 | Each item was scored dichotomously (0 vs. 1); The total score was recorded as the sum of all five items (range: 0–5) | Frail | 3–5 | 10-year outcomes/HR(CI) | Pre-frail | frail
Graham, 2009^202^ 10-year mortality | 4) slow walking | 0 or 1 | Each item was scored dichotomously (0 vs. 1); The total score was recorded as the sum of all five items (range: 0–5) | Frail | 3–5 | Mortality | 1.25(1.07–1.46) | 1.81(1.41–2.31)
Graham, 2009^202^ 10-year mortality | 5) low physical activity | 0 or 1 | Each item was scored dichotomously (0 vs. 1); The total score was recorded as the sum of all five items (range: 0–5) | Frail | 3–5 | * highlighted area indicated significance ≤0.05
Purser, 2006^373^6-month mortality | Set A | | Defined as frail if ≥3 components present | | | Logistic regressions were used to assess the independent predictive validity for
Purser, 2006^373^6-month mortality | 1) mobility | | Defined as frail if ≥3 components present | | | Each composite or single item measures.
Purser, 2006^373^6-month mortality | 2) grip strength | | Defined as frail if ≥3 components present | | | Frailty index/OR(CI) | 6-month mortality
Purser, 2006^373^6-month mortality | 3) low endurance | | Defined as frail if ≥3 components present | | | Measure set A | 1.9(0.6–6)
Purser, 2006^373^6-month mortality | 4) physical activity limitation | | Defined as frail if ≥3 components present | | | Measure set B | 1.4(0.3–5.6)
Purser, 2006^373^6-month mortality | 5) nutrition | | Defined as frail if ≥3 components present | | | Gait speed | 4(1.1–13.8)
Purser, 2006^373^6-month mortality | Set B | | People with impairments in any domain, Resulting in scores of 1 or more, were considered frail | | | Grip strength | 2.7(0.7–10)
Purser, 2006^373^6-month mortality | 1) mobility | | People with impairments in any domain, Resulting in scores of 1 or more, were considered frail | | | Chair-stand | 1.5(0.4–5)
Purser, 2006^373^6-month mortality | 2) activities of daily living | | People with impairments in any domain, Resulting in scores of 1 or more, were considered frail
Purser, 2006^373^6-month mortality | 3) incontinence | | People with impairments in any domain, Resulting in scores of 1 or more, were considered frail
Purser, 2006^373^6-month mortality | 4) cognitive impairment | | People with impairments in any domain, Resulting in scores of 1 or more, were considered frail
Purser, 2006^373^6-month mortality | Gait speed | | Walked <0.65m/s is considered frail
Purser, 2006^373^6-month mortality | Grip strength | | <25 kg is considered as frail
Purser, 2006^373^6-month mortality | Chair stands | | <7/30 seconds is considered frail
Avila-Funes, 2009^169^ 4-year mobility disability 4-year IADL disability 4-year ADL disability 4-year hospitalization 4-year mortality 4-year dementia | 1) weight loss | | | | | Logistic regressions and multivariate logistic regressions were used to assess
Avila-Funes, 2009^169^ 4-year mobility disability 4-year IADL disability 4-year ADL disability 4-year hospitalization 4-year mortality 4-year dementia | 2) exhaustion | | | | | the unadjusted and independent effect of frailty on each outcome
Avila-Funes, 2009^169^ 4-year mobility disability 4-year IADL disability 4-year ADL disability 4-year hospitalization 4-year mortality 4-year dementia | 3) low physical activity | | | | | Outcome measures/OR(CI) | Pre-frail | frail with cognitive
Avila-Funes, 2009^169^ 4-year mobility disability 4-year IADL disability 4-year ADL disability 4-year hospitalization 4-year mortality 4-year dementia | 4) slowness | | | | | | | impairment
Avila-Funes, 2009^169^ 4-year mobility disability 4-year IADL disability 4-year ADL disability 4-year hospitalization 4-year mortality 4-year dementia | 5) weakness | | | | | Mortality | 1.96(1.38–2.8)* | 3.46(2.05–5.84)
Avila-Funes, 2009^169^ 4-year mobility disability 4-year IADL disability 4-year ADL disability 4-year hospitalization 4-year mortality 4-year dementia | 6) with or without cognitive impairment | | | | | hospitalization | 1.19(1.03–1.39)** | 1.9(1.09–3.31)
Avila-Funes, 2009^169^ 4-year mobility disability 4-year IADL disability 4-year ADL disability 4-year hospitalization 4-year mortality 4-year dementia | 6) with or without cognitive impairment | | | | | Dementia | 5.21(2.95–9.23)## | 4.98(2.17–11.41)
Avila-Funes, 2009^169^ 4-year mobility disability 4-year IADL disability 4-year ADL disability 4-year hospitalization 4-year mortality 4-year dementia | 6) with or without cognitive impairment | | | | | Mobility disability | 1.34(1.13–1.59)** | 3.88(0.78–19.41)
Avila-Funes, 2009^169^ 4-year mobility disability 4-year IADL disability 4-year ADL disability 4-year hospitalization 4-year mortality 4-year dementia | 6) with or without cognitive impairment | | | | | IADL disability | 2.83(1.91–4.19)## | 3.17(1.47–6.83)
Avila-Funes, 2009^169^ 4-year mobility disability 4-year IADL disability 4-year ADL disability 4-year hospitalization 4-year mortality 4-year dementia | 6) with or without cognitive impairment | | | | | ADL disability | 3.28(1.61–6.67)* | 5.6(2.13–14.7)
Avila-Funes, 2009^169^ 4-year mobility disability 4-year IADL disability 4-year ADL disability 4-year hospitalization 4-year mortality 4-year dementia | 6) with or without cognitive impairment | | | | | *crude OR;#frail;**pre-frail without cognitive Impairment; ##pre-frail with cognitive impairment;
Mitnitski, 2002^374^ mortality | Same as aforementioned predictors | | 1. The proportion of the deficits in the individual as a state variable, measuring an individual degree of impairment and frailty; then analyzed the proportion q(t) averaged across all subjects at age t, for those with no cognitive impairment;; 2. an individual’s health status f(i) may be defined as a ratio of that person’s impairment Index to the mean index value, averaged across individuals without cognitive impairment, but of the same age f(i)=qi/m; f>1 if the individual Is frail; and the individual is fit if f<1. | | | Construct validity was examined through its relationship to chronological age; criterion validity was examined in its ability to predict mortality.
Mitnitski, 2002^374^ mortality | Same as aforementioned predictors | | | | | | Biological age | Chronological age
Mitnitski, 2002^374^ mortality | Same as aforementioned predictors | | | | | Beta coefficient | 0.0081 | 0.0081
Mitnitski, 2002^374^ mortality | Same as aforementioned predictors | | | | | Standard deviation | 0.0014 | 0.0038
Mitnitski, 2002^374^ mortality | Same as aforementioned predictors | | | | | t-value | 5.7 | 2.15
Mitnitski, 2002^374^ mortality | Same as aforementioned predictors | | | | | p-value | <0.000001 | 0.0313
Mitnitski, 2002^374^ mortality | Same as aforementioned predictors
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | 1. For Fried’s CHS frailty index, frailty status is defined as robust if 0 component; prefrail if 1–2 components; and frail if 3–5 components; 2. for Ensrud’s SOF frailty index, frailty status was defined as robust if 0 component; prefrail if 1 component; frail if ≥2 components | | | Robust | 0 | The mean value for selected variables, including outcomes were calculated by risk group and compared. Odds ratio, hazard ratio for each risk group were calculated for both CHS and SOF frailty indexes.
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | | | | Prefrail | 1–2 | The mean value for selected variables, including outcomes were calculated by risk group and compared. Odds ratio, hazard ratio for each risk group were calculated for both CHS and SOF frailty indexes.
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | | | | Frail | 3–5 | The mean value for selected variables, including outcomes were calculated by risk group and compared. Odds ratio, hazard ratio for each risk group were calculated for both CHS and SOF frailty indexes.
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | | | | Robust | 0 | The mean value for selected variables, including outcomes were calculated by risk group and compared. Odds ratio, hazard ratio for each risk group were calculated for both CHS and SOF frailty indexes.
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | | | | Prefrail | 1 | HR/OR* | SOF | CHS
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | | | | Frail | ≥2 | Recurrent falls
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | | | | Frail | ≥2 | prefrail | 1.62(1.14–2.32) | 1.1(0.8–1.5)
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | | | | Frail | ≥2 | frail | 2.19(1.19–4.03) | 1.9(1.17–3.1)
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | | | | Frail | ≥2 | Overnight hospitalization
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | | | | Frail | ≥2 | Prefrail | 2.64(1.74–4.01) | 1.97(1.37–2.84)
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | | | | Frail | ≥2 | Frail | .49(1.53–7.98) | 4.45(2.42–8.18)
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | | | | Frail | ≥2 | Emergency department visit
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | | | | Frail | ≥2 | Prefrail | 2.19(1.43–3.33) | 1.34(0.95–1.89)
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | | | | Frail | ≥2 | Frail | 3.54(1.43–8.79) | 3.1(1.64–5.86)
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | | | | Frail | ≥2 | IADL disability
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | | | | Frail | ≥2 | Prefrail | 2.88(1.81–4.58) | 2.73(1.69–4.4)
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | | | | Frail | ≥2 | Frail | 5.38(2.34–12.35) | 7.68(4.01–14.74)
Kiely, 2009^26^; 1. recurrent falls; 2. overnight hospitalization; 3. emergency department visit; 4. instrumental activities of Daily living disability (IADL) | | | | Frail | ≥2 | *adjusted; highlighted area indicating significance ≤0.05

Appendix E Table 49 Simple Models That Predict Mortality in Older Persons

Reference, Outcome | Independent Variables | Results
Albertsson, 2007^365^ 2-year mortality | 1. age 80 years or older;; 2. weight less than 60 kg;; 3. previous fragility fracture;; 4. need to use arms to rise from a chair 5 times without using her arms; | 1. 63% of women with 0 to 1 risk factor had a 2-year mortality risk of 3.2%;; 2. women with 2 to 4 risk factors had a 2-year mortality risk of 23.7% (odds ratio = 9.5; 95% CI 6.0–14.9)
Carey, 2004^368^ 2-year mortality | 1. male gender;; 2. age;; 76–80; 81–85;; >85; 3. dependence in bathing; 4. dependence in shopping; 5. difficulty walking several blocks; 6. difficulty pulling/pushing heavy objects | 1. in the development cohort, 2-year mortality was 3% in the lowest risk group (0 to 2 points), 11% in the middle risk group (3 to 6 points), and 34% in the highest risk group (>7 points).; 2. in the validation cohort, 2-year mortality was 5% in the lowest risk group, 12% in the middle risk group, and 36% in the highest risk group.
Levine, 2007^369^ 1-year mortality | 1. age; 70–74; 75–79; 80–84; 85–89; >=90; 2. Discharge to nursing home or skilled nursing facility; 3. length of stay >=5 days; 4. congestive heart failure; 5. peripheral vascular disease; 6. dementia; 7. renal disease; 8. hematologic and solid malignancy; 9. metastatic cancer | 1. In the derivation cohort, 1-year mortality was 11% in the lowest-risk group (0 or 1 point) and 48% in the highest-risk group (4 or greater points).; 2. in the validation cohort, 1-year mortality was 11% in the lowest risk group and 45% in the highest-risk group.
Walter, 2001^125^ 1-year mortality | 1. male sex; 2. dependent in 1–4 ADLs; 3. dependent in all ADLs; 4. congestive heart failure; 5. solitary cancer; 6. metastatic cancer; 7. creatinine level on admission > 3mg/dl; 8. albumin level on admission is 3–3.4 g/dL albumin level on admission is <3 g/dL | 1. In the derivation cohort, 1-year mortality was 13% in the lowest-risk group (0–1 point), 20% in the group with 2 or 3 points, 37% in the group with 4 to 6 points, and 68% in the highest-risk group (>6 points).; 2. In the validation cohort, 1-year mortality was 4% in the lowest-risk group, 19% in the group with 2 or 3 points, 34% in the group with 4 to 6 points, and 64% in the highest-risk group.
Lee, 2006^71^ 4-year mortality | 1. male sex; 2. age 60–64; 3. age 65–69; 4. age 70–74; 5. age 75–79; 6. age 80–84; 7. age >=85; 8. diabetes mellitus; 9. cancer; 10. lung cancer; 11. heart failure; 12. body mass index<25; 13. current smoker; 14. bathing; 15. managing finances; 16. walking several blocks; 17. pushing/pulling heavy objects | In validation cohort, 0 to 5 points predicting a less than 4% mortality risk, 6 to 9 points predicting a 15% risk, 10 to 13 points predicting a 42% risk, and 14 or more points predicting a 64% risk.
Inouye, 2003^122^ 1-year mortality | 1. high risk diagnoses;; 2. albumin <=3.5 mg/dL;; 3. Creatinine >15 mg/dL;; 4. dementia;; 5. walking impairment | 1. In the development cohort, where overall mortality was 154/525 (29%), 1-year mortality rates increased significantly across each risk group, from 8% to 24%, 51%, and 74%, in groups I to IV respectively; 2. Corresponding rates in the validation cohort, where overall mortality was 488/1246 (39%), were 5%, 17%, 33%, and 61% in groups I to IV, respectively
Schonberg, 2009^366^ 5-year mortality | 1. age 65–69; 70–74; 75–79; 80–84; 85+; 2. Male sex; 3. Smoking status: never, Former, Current; 4. body mass index<25 kg/m^2^; 5. comorbid conditions; COPD; Diabetes mellitus; Cancer; 6. overnight hospitalization in past year; None; One; Two or more; 7. perceived health; Excellent/very good; Good; Fair/good; 8. functional measures; Dependent in at least 1 IADL; Difficulty walking several blocks | 1. In the development cohort, 5-year mortality rates increased significantly across each quintile of risk from 6% to 10%, 14%, 27%, and 52% in quintile 1 through 5; 2. In the validation cohort, 5-year mortality rates increased significantly across each quintile of risk from 5% to 10%, 17%, 31%, and 50% in quintile 1 through 5

Appendix E Table 50 Complex Models That Predict Mortality in Older Persons

Reference, Outcome | Independent Variables | Results
Drame, 2008^375^ 2-year mortality | 1. age: 85 years or older; 2. dependent for the ADL: yes; 3. delirium: yes; 4. malnutrition risk: yes; 5. comorbidity level: medium | A point value was assigned to each characteristic according to the hazard ratio in the final model. Point values for all mortality-related characteristics present for each patient were rounded to the nearest integer and summed. Three groups were determined: low-risk (<=2), medium risk (3–5) and high-risk (>=6)
Ravaglia, 2008^362^ 4-year mortality; 4-year Fractures; 4-year Hospital admission; 4-year Worsening disability; 4-year Incident disability | 1. age >=80;; 2. male gender;; 3. physical inactivity; 4. use of >=3 drugs;; 5. sensory deficits;; 6. calf circumference <31cm;; 7. instrumental activity of daily Living disability;; 8. gait and balance test <=24;; 9. pessimism about one’s health | A risk scoring system was developed, assigning one point to each present predictor and summing the points assigned to each participant. Cox regression was used to assess the association between the score and mortality
Carey, 2008^129^ 1-year mortality; 2-year mortality; 3-year mortality; | 1. male;; 2. age;; 75–79; 80–84;; >=85; 3. dependence in toileting; 4. dressing; Partially dependent;; Fully dependent; 5. malignant neoplasm; 6. congestive heart failure; 7. chronic obstructive; Pulmonary disease; 8. renal failure or insufficiency | A point scoring system was constructed in which points were assigned to each risk factor using the coefficients (parameter estimates) from the final Cox regression model The coefficient for each risk factor was divided by the lowest coefficient (partial dependence in the ADL dressing) and rounded to the nearest integer. A risk score was then calculated for each patient by adding the points for each risk factor present.
Pilotto, 2008^363^ 1-year mortality | 1. Activities of daily living index; 2. instrumental activities of daily living scale; 3. Short Portable Mental Status questionnaire; 4. comorbidity index; 5. Mini Nutritional Assessment; 6. Exton Smith Scale; 7. number of medications; 8. social support network | Each domain can be assigned one of three weights (0;0.5;1) depending on the specific scores for each domain. The sum of the calculated scores from the eight domains was divided by 8 to obtain a final multidimensional index score from 0 to 1.
Fried, 1998^54^ 5-year mortality | 1. age; 2. male sex; 3. income less than $50 000 per year,; 4. low weight; 5. lack of moderate or vigorous exercise; 6. smoke > 50 pack-years; 7. high brachial systolic blood pressure (> 169mm Hg); 8. low tibial systolic blood pressure (<127mm Hg); 9. diuretic use by those without hypertension or congestive heart failure; 10. elevated fasting glucose level >7.2 mmol/L [130 mg/dL]; 11. low albumin level (<=37 g/L); 12. elevated creatinine level (>=106 μmol/L [1.2 mg/dL]); 13. low forced vital capacity (<=2.06 mL); 14. aortic stenosis (moderate or severe) and abnormal left ventricular ejection fraction (by echocardiography); 15. major electrocardiographic abnormality; 16. stenosis of internal carotid artery (by ultrasound),; 17. congestive heart failure; 18. difficulty in any instrumental activity of daily living,; 19. low cognitive function by Digit Symbol Substitution test score. | A risk score was computed by multiplying, for each individual, the regression coefficient from each variable in the Cox model by the value of the corresponding variable for the individual. These products were summed to give a prognosis score for each individual. The risk group is based on quintile of risk
Melzer, 2003^14^ 4-year mortality | 1. gait speed;; 2. time to 5 chair stands;; 3. peak expiratory flow | 1 In the logistic regression models all physiological measures were coded into ranks or categories
Melzer, 2003^14^ 4-year mortality | 1. gait speed;; 2. time to 5 chair stands;; 3. peak expiratory flow | 2 The ß values for different coding of three measures used in the difficulty and inability equations were calculated
Melzer, 2003^14^ 4-year mortality | 1. gait speed;; 2. time to 5 chair stands;; 3. peak expiratory flow | 3 Difficulty and inability models for calculating MOBLI scores were developed
Melzer, 2003^14^ 4-year mortality | 1. gait speed;; 2. time to 5 chair stands;; 3. peak expiratory flow | 4 Coefficients (beta values) of different coding in three measures used in the logistic regression models and equations to produce the MOBLI score were calculated and entered into difficulty and inability models;
Melzer, 2003^14^ 4-year mortality | 1. gait speed;; 2. time to 5 chair stands;; 3. peak expiratory flow | 5 MOBLI score represents the probability of risk to mobility limitations or impairments, the higher the score the higher the probability of mobility limitation and impairment.
Garcia-Gonzalez, 2009^367^ 2-year mortality | Health problems before age 10 Poor self-assessed health Medically diagnosed conditions Medical symptoms during past 2 years Difficulty with activities of daily living Difficulty with instrumental activities of Daily living | Frailty index was defined as a proportion of the total number of deficits an individual has with respect to the 34 deficits included.
Pijpers, 2009^370^ 3-year mortality | 1. age: per 10 years; 2. male sex; 3. living alone; 4. cardiovascular disease; 5. diabetes; 6. medication number>=2; 7. Body mass index<18.5; 8. Elderly Mobility Scale score <20; 9. motor deficit in ADL; 10. process deficit in ADL | 1. Weight was obtained by multiplying the regression coefficient by 10 rounded up to the nearest integer;; 2. The weight will be multiplied by the patient’s characteristics value and the assume of these values is the risk score for each patient
Mazzaglia, 2007^187^ 15-month mortality 15-month hospitalization | 1. age:; 65–74; 75–84; >=85; 2. sex; female; Male; 3. positive responses to the Screening test; 0–1; 2–3; 4–6; 4. having hospitalization in the Previous 6 months; 5. having >=5 prescriptions | Each risk factor was assigned a score based on the ratio between the regression b-coefficient for that variable and the lowest significant b-coefficient in the corresponding logistic regression (which is being 750=−84 years old); The ratio is rounded up to the nearest integer; a summary point score was calculated for each participant by adding the points for each risk factor present.
Jones, 2005^144^ 5-year mortality 5-year institutionalization | 1. Impairment index includes; cognition; Emotion; Communication; mobility; Balance; Bladder Bowel; Nutrition; Activities of daily living; Social; 2. Comorbidity index | 1. Each of 10 domains in impairment index was scored such that 0=no problem; 0.5=minor problem; 1=major problem;; 2. The CIRS codes the severity of 14 co-existing diseased body system as 0,1, or 2 and standardized into a range of 0–4 (CIRS/6);; 3. The current index is calculated as # of total deficits/total # deficits (impairment index + comorbidity index)/14
Mitnitski, 2002^374^ mortality | Vision loss; Hearing loss; Impaired mobility; Vascular problem; Gait abnormality; Impaired vibration sense; Difficulty bathing; Difficulty going out; Difficulty cooking; Difficulty toileting; Difficulty grooming Skin problem; Resting tremor; Changes in sleep; Difficulty dressing; Urinary complaints; Gastro-intestinal problem; Diabetes; Hypertension; Limb tone abnormality | 1. The proportion of the deficits in the i-th Individual as a state variable, measuring an individual degree of impairment and frailty; then analyzed the proportion q(t) averaged across all subjects at age t, for those with no cognitive impairment;; 2. An individual’s health status f(i) may be defined as a ratio of that person’s impairment Index to the mean index value, averaged across Individuals without cognitive impairment, but of the same age f(i)=qi/m; f>1 if the individual Is frail; and the individual is fit if f<1.

Appendix E Table 51 Predictive Models Based on Frailty Phenotype Definition

Reference | Outcome | Independent Variables | Accuracy and Validation
Ensrud, 2008^50^ | mortality | 1. weight loss of 5% or more between the 3rd and 4th Examination;; 2. subject’s inability to rise from a chair 5 times without using her arms;; 3. reduced energy level | mortality rate, 95% CI, odds ratio, hazard ratio for each risk group and area under the curve were calculated and compared between cohorts from study of osteoporotic fractures (SOF) and cardiovascular health study (CHS)
Ensrud, 2008^50^ | mortality | 1. weight loss of 5% or more between the 3rd and 4th Examination;; 2. subject’s inability to rise from a chair 5 times without using her arms;; 3. reduced energy level | | SOF | CHS
Ensrud, 2008^50^ | mortality | 1. weight loss of 5% or more between the 3rd and 4th Examination;; 2. subject’s inability to rise from a chair 5 times without using her arms;; 3. reduced energy level | Receiver Operating Characteristic curve area (ROC) | 0.72 (0.71–0.73) | 0.72 (0.71–0.74)
Ensrud, 2009^51^ | mortality | 1. weight loss of 5% or more between baseline and 2nd examination;; 2. subject’s inability to rise from a chair 5 times without using her arms;; 3. poor energy | mortality rate, 95% CI, odds ratio, hazard ratio for each risk group and area under the curve were calculated and compared between cohorts from study of osteoporotic fractures (SOF) and cardiovascular health study (CHS)
Ensrud, 2009^51^ | mortality | 1. weight loss of 5% or more between baseline and 2nd examination;; 2. subject’s inability to rise from a chair 5 times without using her arms;; 3. poor energy | | SOF | CHS
Ensrud, 2009^51^ | mortality | 1. weight loss of 5% or more between baseline and 2nd examination;; 2. subject’s inability to rise from a chair 5 times without using her arms;; 3. poor energy | Receiver Operating Characteristic curve area (ROC) | 0.71 (0.67–0.75) | 0.72 (0.69–0.76)
Fried, 2001^55^ | 3-year mortality 7-year mortality | 1. weight loss (shrinking);; 2. grip strength (weakness);; 3. exhaustion (poor endurance);; 4. walking time (slowness);; 5. low physical activity | Cox proportional hazards models were used to assess the independent predictive validity of frailty phenotype.
Fried, 2001^55^ | 3-year mortality 7-year mortality | 1. weight loss (shrinking);; 2. grip strength (weakness);; 3. exhaustion (poor endurance);; 4. walking time (slowness);; 5. low physical activity | 3-year outcomes/HR(CI) | Intermediate | frail
Fried, 2001^55^ | 3-year mortality 7-year mortality | 1. weight loss (shrinking);; 2. grip strength (weakness);; 3. exhaustion (poor endurance);; 4. walking time (slowness);; 5. low physical activity | Mortality | 1.49(1.11–1.99) | 2.24(1.51–3.33)
Fried, 2001^55^ | 3-year mortality 7-year mortality | 1. weight loss (shrinking);; 2. grip strength (weakness);; 3. exhaustion (poor endurance);; 4. walking time (slowness);; 5. low physical activity | 7-year outcomes/HR(CI) | Intermediate | frail
Fried, 2001^55^ | 3-year mortality 7-year mortality | 1. weight loss (shrinking);; 2. grip strength (weakness);; 3. exhaustion (poor endurance);; 4. walking time (slowness);; 5. low physical activity | Mortality | 1.32(1.13–1.55) | 1.63(1.27–2.08)
Gill, 2006^372^ | 6-year mortality | 1. weight loss; 2. muscle weakness; 3. exhaustion; 4. slow walking speed;; 5. low physical activity | Cox proportional hazards models were used to calculate the unadjusted hazard ratios and assess the predictive validity for each component
Gill, 2006^372^ | 6-year mortality | 1. weight loss; 2. muscle weakness; 3. exhaustion; 4. slow walking speed;; 5. low physical activity | Outcome measures/HR | 6-year mortality
Gill, 2006^372^ | 6-year mortality | 1. weight loss; 2. muscle weakness; 3. exhaustion; 4. slow walking speed;; 5. low physical activity | Weight loss | 2.03
Gill, 2006^372^ | 6-year mortality | 1. weight loss; 2. muscle weakness; 3. exhaustion; 4. slow walking speed;; 5. low physical activity | Exhaustion | 1.97
Gill, 2006^372^ | 6-year mortality | 1. weight loss; 2. muscle weakness; 3. exhaustion; 4. slow walking speed;; 5. low physical activity | Low physical activity | 2.83
Gill, 2006^372^ | 6-year mortality | 1. weight loss; 2. muscle weakness; 3. exhaustion; 4. slow walking speed;; 5. low physical activity | Muscle weakness | 1.93
Gill, 2006^372^ | 6-year mortality | 1. weight loss; 2. muscle weakness; 3. exhaustion; 4. slow walking speed;; 5. low physical activity | Slow walking speed | 2.28
Graham, 2009^202^ | 10-year mortality | 1. weight loss; 2. grip strength; 3. exhaustion; 4. slow walking; 5. low physical activity | Cox proportional hazards models were used to assess the independent predictive validity of frailty index
Graham, 2009^202^ | 10-year mortality | 1. weight loss; 2. grip strength; 3. exhaustion; 4. slow walking; 5. low physical activity | 10-year outcomes/HR(CI) | Pre-frail | frail
Graham, 2009^202^ | 10-year mortality | 1. weight loss; 2. grip strength; 3. exhaustion; 4. slow walking; 5. low physical activity | Mortality | 1.25(1.07–1.46) | 1.81(1.41–2.31)
Purser, 2006^373^ | 6-month mortality | measure set A; 1. mobility; 2. grip strength; 3. low endurance; 4. physical activity limitation; 5. nutrition; measure set B; 1. mobility; 2. activities of daily living; 3. incontinence; 4. cognitive impairment; single item performance measure; 1. Gait speed; 2. Grip strength; 3. Chair stands | Logistic regressions were used to assess the independent predictive validity for each composite or single item measures.
Purser, 2006^373^ | 6-month mortality | | Frailty index/OR(CI) | 6-month mortality
Purser, 2006^373^ | 6-month mortality | | Measure set A | 1.9(0.6–6)
Purser, 2006^373^ | 6-month mortality | | Measure set B | 1.4(0.3–5.6)
Purser, 2006^373^ | 6-month mortality | | Gait speed | 4(1.1–13.8)
Purser, 2006^373^ | 6-month mortality | | Grip strength | 2.7(0.7–10)
Purser, 2006^373^ | 6-month mortality | | Chair-stand | 1.5(0.4–5)
Avila-Funes, 2009^169^ | 4-year mortality | 1. weight loss; 2. exhaustion; 3. low physical activity; 4. slowness; 5. weakness; 6. with or without cognitive impairment | Logistic regressions and multivariate logistic regressions were used to assess the unadjusted and independent effect of frailty on each outcome
Avila-Funes, 2009^169^ | 4-year mortality | 1. weight loss; 2. exhaustion; 3. low physical activity; 4. slowness; 5. weakness; 6. with or without cognitive impairment | Outcome measures/OR(CI) | Pre-frail | frail with cognitive impairment
Avila-Funes, 2009^169^ | 4-year mortality | 1. weight loss; 2. exhaustion; 3. low physical activity; 4. slowness; 5. weakness; 6. with or without cognitive impairment | Mortality | 1.96(1.38–2.8) | 3.46(2.05–5.84)

Appendix E Table 52 Predictive Models Based on Frailty Accumulation of Deficits Definition

Reference | Outcome | Independent Variables | Accuracy/Validation
Drame, 2008^375^ | 2-year mortality | 1. age: 85 years or older; 2. dependent for the ADL: yes; 3. delirium: yes; 4. malnutrition risk: yes; 5. comorbidity level: medium | death rate, 95% CI for each risk group and area under the curve were calculated and compared
Drame, 2008^375^ | 2-year mortality | 1. age: 85 years or older; 2. dependent for the ADL: yes; 3. delirium: yes; 4. malnutrition risk: yes; 5. comorbidity level: medium | | Derivation Cohort | Validation Cohort
Drame, 2008^375^ | 2-year mortality | 1. age: 85 years or older; 2. dependent for the ADL: yes; 3. delirium: yes; 4. malnutrition risk: yes; 5. comorbidity level: medium | Receiver operating characteristics curve area | 0.72 (0.68–0.75) | 0.71 (0.66–0.76)
Ravaglia, 2008^362^ | 4-year mortality; 4-year Hospital admission; 4-year Worsening disability; 4-year Incident disability | 1. age >=80;; 2. male gender;; 3. physical inactivity; 4. use of >=3 drugs;; 5. sensory deficits;; 6. calf circumference <31cm;; 7. instrumental activity of daily Living disability;; 8. gait and balance test <=24;; 9. pessimism about one’s health | not reported
Carey, 2008^129^ | 1-year mortality; 2-year mortality; 3-year mortality | 1. male;; 2. age;; 75–79; 80–84;; >=85; 3. dependence in toileting; 4. dressing; Partially dependent;; Fully dependent; 5. malignant neoplasm; 6. congestive heart failure; 7. chronic obstructive Pulmonary disease; 8. renal failure or insufficiency | No. at risk, mortality rate for each risk group and area under the curve were calculated compared between development and validation cohorts.
Carey, 2008^129^ | 1-year mortality; 2-year mortality; 3-year mortality | | | Derivation cohort | Validation cohort
Carey, 2008^129^ | 1-year mortality; 2-year mortality; 3-year mortality | | Receiver operating characteristic curve (ROC) | 0.66 | 0.69
Pilotto, 2008^363^ | 1-year mortality | 1. Activities of daily living index; 2. instrumental activities of daily living scale; 3. Short Portable Mental Status questionnaire; 4. comorbidity index; 5. Mini Nutritional Assessment; 6. Exton Smith Scale; 7. number of medications; 8. social support network | Calibration of the model was assessed by comparing the predicted mortality with the actual mortality in the development and validation cohorts; discrimination of the model was assessed by calculating the receiver operating characteristic curves for the development and validation cohorts.
Pilotto, 2008^363^ | 1-year mortality | | | Development cohort | Validation cohort
Pilotto, 2008^363^ | 1-year mortality | | Receiver operating characteristic curve area (ROC) | 0.751 (0.71–0.81) | Not reported
Fried, 1998^54^ | 5-year mortality | 1. age; 2. male sex; 3. income less than $50 000 per year,; 4. low weight; 5. lack of moderate or vigorous exercise; 6. smoke > 50 pack-years; 7. high brachial systolic blood pressure (> 169mm Hg); 8. low tibial systolic blood pressure (<127mm Hg); 9. diuretic use by those without hypertension or congestive heart failure; 10. elevated fasting glucose level >7.2 mmol/L [130 mg/dL]; 11. low albumin level (<=37 g/L); 12. elevated creatinine level (>=106 μmol/L [1.2 mg/dL]); 13. low forced vital capacity (<=2.06 mL); 14. aortic stenosis (moderate or severe) and abnormal left ventricular ejection fraction (by echocardiography); 15. major electrocardiographic abnormality; 16. stenosis of internal carotid artery (by ultrasound),; 17. congestive heart failure; 18. difficulty in any instrumental activity of daily living,; 19. low cognitive function by Digit Symbol Substitution test score. | The 5-year overall mortality rate and mortality per person-year for each risk group were calculated and compared between cardiovascular health study (CHS) original cohort and the African American cohort.
Fried, 1998^54^ | 5-year mortality | | | Original cohort | African American cohort
Fried, 1998^54^ | 5-year mortality | | Chi-square trend | 659.73 | 55.97
Fried, 1998^54^ | 5-year mortality | | P-value | <.001 | <.001
Melzer, 2003^14^ | 4-year mortality | 1. gait speed;; 2. time to 5 chair stands;; 3. peak expiratory flow | Crude and age/sex-adjusted death rates, hazard ratio for self-reported and predicted inability to walk 1/2 mile based on mobility-related limitation index scores (MOBLI).
Melzer, 2003^14^ | 4-year mortality | 1. gait speed;; 2. time to 5 chair stands;; 3. peak expiratory flow | Unable to walk1/2 mile | MOBLI | Self-reported
Melzer, 2003^14^ | 4-year mortality | 1. gait speed;; 2. time to 5 chair stands;; 3. peak expiratory flow | By death rate | 31.7 | 32.4
Melzer, 2003^14^ | 4-year mortality | 1. gait speed;; 2. time to 5 chair stands;; 3. peak expiratory flow | By hazard ratio | 2.71(2.28–3.21) | 2.95(2.48–3.5)
Garcia-Gonzalez, 2009^367^ | 2-year mortality | Health problems before age 10 Poor self-assessed health Medically diagnosed conditions Medical symptoms during past 2 years Difficulty with activities of daily living Difficulty with instrumental activities of Daily living | Number and hazard ratios of mortality,95% CI according to different levels of the frailty index were calculated. No ROC reported
Pijpers, 2009^370^ | 3-year mortality | 1. age: per 10 years; 2. male sex; 3. living alone; 4. cardiovascular disease; 5. diabetes; 6. medication number>=2; 7. Body mass index<18.5; 8. Elderly Mobility Scale score <20; 9. motor deficit in ADL; 10. process deficit in ADL | ROC curves were computed; mean predicted 3-year mortality risk and observed 3-year mortality were calculated and compared in each quintile of risk score
Pijpers, 2009^370^ | 3-year mortality | | | index model
Pijpers, 2009^370^ | 3-year mortality | | Receiver Operating Characteristics curve area | 0.78 (0.71–0.84)
Mazzaglia, 2007^187^ | 15-month mortality 15-month hospitalization | 1. age:; 65–74; 75–84; >=85; 2. sex; female; Male; 3. positive responses to the Screening test; 0–1; 2–3; 4–6; 4. having hospitalization in the Previous 6 months; 5. having >=5 prescriptions | Number of death/who at risk, percentage, 95%CI, sensitivity and specificity, area under the curve were calculated and compared for both cohorts according to risk scores
Mazzaglia, 2007^187^ | 15-month mortality 15-month hospitalization | | Receiver operating characteristic curve area | Development cohort | Validation cohort
Mazzaglia, 2007^187^ | 15-month mortality 15-month hospitalization | | Mortality | 0.75 (0.72–0.78) | 0.75(0.73–0.78)
Jones, 2005^144^ | 5-year mortality 5-year institutionalization | 1. 1 Impairment index includes; cognition; Emotion; Communication; mobility; Balance; Bladder; Bowel; Nutrition; Activities of daily living Social; 2. Comorbidity index | Mean and standard deviation for socio-demographic, clinical variables and uses of clinical services were calculated and compared by index levels.
Jones, 2005^144^ | 5-year mortality 5-year institutionalization | 1. 1 Impairment index includes; cognition; Emotion; Communication; mobility; Balance; Bladder; Bowel; Nutrition; Activities of daily living Social; 2. Comorbidity index | Receiver Operating Characteristic curve area | FI-GCA | FI
Jones, 2005^144^ | 5-year mortality 5-year institutionalization | 1. 1 Impairment index includes; cognition; Emotion; Communication; mobility; Balance; Bladder; Bowel; Nutrition; Activities of daily living Social; 2. Comorbidity index | Mortality | 0.67 | 0.7
Mitnitski, 2002^374^ | mortality | Vision loss; Hearing loss; Impaired mobility; Vascular problem; Gait abnormality; Impaired vibration sense; Difficulty bathing; Difficulty going out; Difficulty cooking; Difficulty toileting; Difficulty grooming Skin problem; Resting tremor; Changes in sleep; Difficulty dressing; Urinary complaints; Gastro-intestinal problem; Diabetes; Hypertension; Limb tone abnormality | Construct validity was examined through its relationship to chronological age; criterion validity was examined in its ability to predict mortality.
Mitnitski, 2002^374^ | mortality | | | Biological age | Chronological age
Mitnitski, 2002^374^ | mortality | | Beta coefficient | 0.0081 | 0.0081
Mitnitski, 2002^374^ | mortality | | Standard deviation | 0.0014 | 0.0038
Mitnitski, 2002^374^ | mortality | | t-value | 5.7 | 2.15
Mitnitski, 2002^374^ | mortality | | p-value | <0.000001 | 0.0313
Walter, 2001^125^ | 1-year mortality | 1. male sex; 2. dependent in 1–4 ADLs; 3. dependent in all ADLs; 4. congestive heart failure; 5. solitary cancer; 6. metastatic cancer; 7. creatinine level on admission >3mg/dl; 8. albumin level on admission is 3–3.4 g/dL albumin level on admission is <3 g/dL | No. of death/No. at risk, 95% CI for each risk group and area under the curve were calculated and compared between derivation and validation cohorts
Walter, 2001^125^ | 1-year mortality | | Receiver Operating characteristic curve area | Derivation Cohort | Validation Cohort
Walter, 2001^125^ | 1-year mortality | | By risk group | 0.75 | 0.79
Walter, 2001^125^ | 1-year mortality | | By quartile of risk | 0.75 | 0.8
Lee, 2006^71^ | 4-year mortality | 1. male sex; 2. age 60–64; 3. age 65–69; 4. age 70–74; 5. age 75–79; 6. age 80–84; 7. age >=85; 8. diabetes mellitus; 9. cancer; 10. lung cancer; 11. heart failure; 12. body mass index<25; 13. current smoker; 14. bathing; 15. managing finances; 16. walking several blocks; 17. pushing/pulling heavy objects | No. of death/No. at risk for each risk group and area under the curve were calculated and compared between development and validation cohorts.
Lee, 2006^71^ | 4-year mortality | | Receiver Operating Characteristic curve area | Development Cohort | Validation Cohort
Lee, 2006^71^ | 4-year mortality | | By risk group | 0.84 | 0.817
Lee, 2006^71^ | 4-year mortality | | By quartile of risk | 0.842 | 0.819
Inouye, 2003^122^ | 1-year mortality | 1. high risk diagnoses;; 2. albumin <=3.5 mg/dL;; 3. Creatinine >15 mg/dL;; 4. dementia;; 5. walking impairment | No. of death/No. at risk, hazard ratio, 95% CI for each risk group and area under the curve were calculated and compared between development and validation cohort.
Inouye, 2003^122^ | 1-year mortality | 1. high risk diagnoses;; 2. albumin <=3.5 mg/dL;; 3. Creatinine >15 mg/dL;; 4. dementia;; 5. walking impairment | | Derivation Cohort | Validation Cohort
Inouye, 2003^122^ | 1-year mortality | 1. high risk diagnoses;; 2. albumin <=3.5 mg/dL;; 3. Creatinine >15 mg/dL;; 4. dementia;; 5. walking impairment | Receiver Operating characteristic curve | 0.83 (0.78–0.87) | 0.77 (0.74–0.8)
Inouye, 2003^122^ | 1-year mortality | 1. high risk diagnoses;; 2. albumin <=3.5 mg/dL;; 3. Creatinine >15 mg/dL;; 4. dementia;; 5. walking impairment | Chi-square trend | 179.33 | 274.01
Inouye, 2003^122^ | 1-year mortality | 1. high risk diagnoses;; 2. albumin <=3.5 mg/dL;; 3. Creatinine >15 mg/dL;; 4. dementia;; 5. walking impairment | P-value | 0.001 | 0.001
Schonberg, 2009^366^ | 5-year mortality | 1. age; 65–69; 70–74; 75–79; 80–84; 85+; 2. Male sex; 3. Smoking status; never; Former; Current; 4. body mass index<25 kg/m^2^; 5. comorbid conditions; COPD; Diabetes mellitus; Cancer; 6. overnight hospitalization in past year; None; One; Two or more; 7. perceived health; Excellent/very good; Good; Fair/good; 8. functional measures Dependent in at least 1 IADL; Difficulty walking several blocks | mortality rate, person-year rate were calculated and compared between development and validation cohorts according to quintile of risk and point score.
Schonberg, 2009^366^ | 5-year mortality | | | index model
Schonberg, 2009^366^ | 5-year mortality | | Receiver operating characteristic curve area (ROC) | 0.75
Carey, 2004^368^ | 2-year mortality; | 1. male gender;; 2. age;; 76–80; 81–85;; >85; 3. dependence in bathing; 4. dependence in shopping; 5. difficulty walking several blocks; 6. difficulty pulling/pushing heavy objects | No. at risk, mortality rate for each risk group and area under the curve were calculated and compared between development and validation cohorts.
Carey, 2004^368^ | 2-year mortality; | 1. male gender;; 2. age;; 76–80; 81–85;; >85; 3. dependence in bathing; 4. dependence in shopping; 5. difficulty walking several blocks; 6. difficulty pulling/pushing heavy objects | | Derivation cohort | Validation cohort
Carey, 2004^368^ | 2-year mortality; | 1. male gender;; 2. age;; 76–80; 81–85;; >85; 3. dependence in bathing; 4. dependence in shopping; 5. difficulty walking several blocks; 6. difficulty pulling/pushing heavy objects | Receiver Operating Characteristics curve area | 0.76 | 0.74
Levine, 2007^369^ | 1-year mortality | 1. age; 70–74; 75–79; 80–84; 85–89; >=90; 2. Discharge to nursing home or Skilled nursing facility; 3. length of stay >=5 days; 4. congestive heart failure; 5. peripheral vascular disease; 6. dementia; 7. renal disease; 8. hematologic and solid malignancy; 9. metastatic cancer | No. of death/No. at risk, 95% CI for each risk group and area under the curve were calculated and compared between derivation and validation cohorts
Levine, 2007^369^ | 1-year mortality | | Receiver operating characteristic curve area (ROC) | Derivation Cohort | Validation Cohort
Levine, 2007^369^ | 1-year mortality | | By risk group | 0.67 | 0.65
Levine, 2007^369^ | 1-year mortality | | By quartile of risk | 0.7 | 0.68

Appendix E Table 53 Short-Term Prediction of Death in Older Persons

Reference | Outcome | Independent Variables | Accuracy and validation
Purser, 2006^373^ | 6-month mortality | measure set A; 1. mobility; 2. grip strength; 3. low endurance; 4. physical activity limitation; 5. nutrition; measure set B; 1. mobility; 2. activities of daily living; 3. incontinence; 4. cognitive impairment; single item performance measure; 1. Gait speed; 2. Grip strength; 3. Chair stands | Logistic regressions were used to assess the independent predictive validity for each composite or single item measures.
Purser, 2006^373^ | 6-month mortality | | Frailty index/OR(CI) | 6-month mortality
Purser, 2006^373^ | 6-month mortality | | Measure set A | 1.9(0.6–6)
Purser, 2006^373^ | 6-month mortality | | Measure set B | 1.4(0.3–5.6)
Purser, 2006^373^ | 6-month mortality | | Gait speed | 4(1.1–13.8)
Purser, 2006^373^ | 6-month mortality | | Grip strength | 2.7(0.7–10)
Purser, 2006^373^ | 6-month mortality | | Chair-stand | 1.5(0.4–5)
Carey, 2008^129^ | 1-year mortality; | 1. male;; 2. age;; 75–79; 80–84;; >=85; 3. dependence in toileting; 4. dressing; Partially dependent;; Fully dependent; 5. malignant neoplasm; 6. congestive heart failure; 7. chronic obstructive; Pulmonary disease; 8. renal failure or insufficiency | Mortality rate for each risk group and area under the curve were calculated and compared between derivation and validation cohorts.
Carey, 2008^129^ | 1-year mortality; | | | Derivation cohort | Validation cohort
Carey, 2008^129^ | 1-year mortality; | | Receiver operating characteristic curve area (ROC) | 0.66 | 0.69
Pilotto, 2008^363^ | 1-year mortality | 1. Activities of daily living index; 2. instrumental activities of daily living scale; 3. Short Portable Mental Status questionnaire; 4. comorbidity index; 5. Mini Nutritional Assessment; 6. Exton Smith Scale; 7. number of medications; 8. social support network | Calibration of the model was assessed by comparing the predicted mortality with the actual mortality in the development and validation cohorts; discrimination of the model was assessed by calculating the receiver operating characteristic curves for the development and validation cohorts.
Pilotto, 2008^363^ | 1-year mortality | | | Development cohort | Validation cohort
Pilotto, 2008^363^ | 1-year mortality | | Receiver operating characteristic curve area (ROC) | 0.751 (0.71–0.81) | Not reported
Walter, 2001^125^ | 1-year mortality | 1. male sex; 2. dependent in 1–4 ADLs; 3. dependent in all ADLs; 4. congestive heart failure; 5. solitary cancer; 6. metastatic cancer; 7. creatinine level on admission > 3mg/dl; 8. albumin level on admission is 3–3.4 g/dL; albumin level on admission is <3 g/dL | No. of death/No. at risk, 95% CI for each risk group and area under the curve were calculated and compared between derivation and validation cohort
Walter, 2001^125^ | 1-year mortality | | Receiver operating characteristic curve area (ROC) | Derivation Cohort | Validation Cohort
Walter, 2001^125^ | 1-year mortality | | By risk group | 0.75 | 0.79
Walter, 2001^125^ | 1-year mortality | | By quartile of risk | 0.75 | 0.8
Inouye, 2003^122^ | 1-year mortality | 1. high risk diagnoses;; 2. albumin <=3.5 mg/dL;; 3. Creatinine >15 mg/dL;; 4. dementia;; 5. walking impairment | No. of death/No. at risk, hazard ratio, 95% CI for each risk group and area under the curve were calculated and compared between derivation and validation cohort.
Inouye, 2003^122^ | 1-year mortality | 1. high risk diagnoses;; 2. albumin <=3.5 mg/dL;; 3. Creatinine >15 mg/dL;; 4. dementia;; 5. walking impairment | | Derivation Cohort | Validation Cohort
Inouye, 2003^122^ | 1-year mortality | 1. high risk diagnoses;; 2. albumin <=3.5 mg/dL;; 3. Creatinine >15 mg/dL;; 4. dementia;; 5. walking impairment | Receiver operating characteristic curve area (ROC) | 0.83 (0.78–0.87) | 0.77 (0.74–0.8)
Inouye, 2003^122^ | 1-year mortality | 1. high risk diagnoses;; 2. albumin <=3.5 mg/dL;; 3. Creatinine >15 mg/dL;; 4. dementia;; 5. walking impairment | Chi-square trend | 179.33 | 274.01
Inouye, 2003^122^ | 1-year mortality | 1. high risk diagnoses;; 2. albumin <=3.5 mg/dL;; 3. Creatinine >15 mg/dL;; 4. dementia;; 5. walking impairment | P-value | 0.001 | 0.001
Levine, 2007^369^ | 1-year mortality | 1. age; 70–74; 75–79; 80–84; 85–89; >=90; 2. Discharge to nursing home or Skilled nursing facility; 3. length of stay >=5 days; 4. congestive heart failure; 5. peripheral vascular disease; 6. dementia; 7. renal disease; 8. hematologic and solid Malignancy; 9. metastatic cancer | No. of death/No. at risk, 95% CI for each risk group and area under the curve were calculated and compared between derivation and validation cohorts
Levine, 2007^369^ | 1-year mortality | | Receiver operating characteristic curve area (ROC) | Derivation Cohort | Validation Cohort
Levine, 2007^369^ | 1-year mortality | | By risk group | 0.67 | 0.65
Levine, 2007^369^ | 1-year mortality | | By quartile of risk | 0.7 | 0.68

Appendix E Table 54 Long-Term Prediction of Death in Older Persons

Reference | Outcome | Independent Variables | Accuracy and Validation
Fried, 1998^54^ | 5-year mortality | 1. age; 2. male sex; 3. income less than $50 000 per year,; 4. low weight; 5. lack of moderate or vigorous exercise; 6. smoke > 50 pack-years; 7. high brachial systolic blood pressure (> 169mm Hg); 8. low tibial systolic blood pressure (<127mm Hg); 9. diuretic use by those without hypertension or congestive heart failure; 10. elevated fasting glucose level >7.2 mmol/L [130 mg/dL]; 11. low albumin level (<=37 g/L); 12. elevated creatinine level (>=106 μmol/L [1.2 mg/dL]); 13. low forced vital capacity (<=2.06 mL); 14. aortic stenosis (moderate or severe) and abnormal left ventricular ejection fraction (by echocardiography); 15. major electrocardiographic abnormality; 16. stenosis of internal carotid artery (by ultrasound),; 17. congestive heart failure; 18. difficulty in any instrumental activity of daily living,; 19. low cognitive function by Digit Symbol Substitution test score. | The 5-year overall mortality rate and mortality per person-year for each risk group were calculated and compared between cardiovascular health study (CHS) original cohort and the African American cohort.
Fried, 1998^54^ | 5-year mortality | | | Original cohort | African American cohort
Fried, 1998^54^ | 5-year mortality | | Chi-square trend | 659.73 | 55.97
Fried, 1998^54^ | 5-year mortality | | P-value | <.001 | <.001
Schonberg, 2009^366^ | 5-year mortality | 1. age; 65–69; 70–74; 75–79; 80–84; 85+; 2. Male sex; 3. Smoking status never; Former; Current; 4. body mass index<25 kg/m^2^; 5. comorbid conditions; COPD; Diabetes mellitus; Cancer; 6. overnight hospitalization in past year; None; One; Two or more; 7. perceived health; Excellent/very good; Good; Fair/good; 8. functional measures; Dependent in at least 1 IADL; Difficulty walking several blocks | Mortality rate, person-year rate were calculated and compared between development and validation cohorts according to quintile of risk and point score.
Schonberg, 2009^366^ | 5-year mortality | | | index model
Schonberg, 2009^366^ | 5-year mortality | | Receiver operating characteristic curve area (ROC) | 0.75
Jones, 2005^144^ | 5-year mortality | 1. Impairment index includes; cognition; Emotion; Communication; mobility; Balance; Bladder; Bowel; Nutrition; Activities of daily living; Social; 2. Comorbidity index | Mean and standard deviation for socio-demographic, clinical variables and uses of clinical services were calculated and compared by index levels.
Jones, 2005^144^ | 5-year mortality | 1. Impairment index includes; cognition; Emotion; Communication; mobility; Balance; Bladder; Bowel; Nutrition; Activities of daily living; Social; 2. Comorbidity index | Receiver operating characteristic curve area (ROC) | FI-GCA | FI
Jones, 2005^144^ | 5-year mortality | 1. Impairment index includes; cognition; Emotion; Communication; mobility; Balance; Bladder; Bowel; Nutrition; Activities of daily living; Social; 2. Comorbidity index | Mortality | 0.67 | 0.7

Appendix E Table 55 Decisionmaking Models of Cost-Effectiveness of Screening

Reference | Aim | Perspective | Study Design | Subjects | Setting | Model Validity | Quality of Data
Frazier et al, 2000^376^ | 1. Evaluate the use of rehydration for fecal occult blood testing; 2. Evaluate the impact of a followup colonoscopy after the detection of a small tubular adenoma by sigmoidoscopy; 3. Consider the impact of imperfect compliance with screening in average-risk individuals | Societal | Cost effectiveness analysis | Hypothetical subjects, representative of the 50-year-old U.S. population, at average risk for colorectal cancer | Simulated clinical practice in U.S. | State-transition Markov model | 1. Age and sex specific prevalence of adenomatous polyps using a weighted logistic regression analysis of results from 6 autopsy studies; 2. Probability of transformation from low-risk to high-risk polyps was estimated from studies of small polyps left in situ and reexamined annually; 3. Prevalence of colorectal cancer and stage distribution at 50-year-old was obtained from SEER data; 4. Costs of colorectal cancer treatment by stage and time period were obtained from a cost study from a large HMO; 5. Compliance rates were obtained in the optimized setting of clinical trials of colorectal cancer screening
Vijan et al, 2001^377^ | Determine how compliance affects cost effectiveness, the optimal timing and frequency of colonoscopy, and the effects of pricing on the relative cost effectiveness of different screening procedures. | Third-party payer perspective | Cost effectiveness analysis | | | Is tested by altering the compliance rate, sensitivity and specificity of fecal occult blood testing to fit the Minnesota fecal occult blood testing screening trial and was validated
Ness et al, 2000^378^ | Investigate the age- dependent cost- utility of one-time colonoscopy screening | Societal perspective | Cost utility analysis | | | 1. Content validity was validated by literature search; 2. Construct validity was validated through the ability to match colorectal cancer incidence and adenoma prevalence data simultaneously; 3. Criterion validity was validated by modeling the National Polyp Study and correctly predicting their colorectal cancer outcomes by simulation
Loeve et al, 2000^379^ | Possible costs and savings of endoscopic colorectal cancer screening are explored to investigate whether the induced savings may compensate for the costs of screening | | Cost saving analysis | Simulated dynamic U.S. population of 1993 | | Validity of the ‘expert’ model is based on observational data and has not been tested on a large longitudinal dataset; sensitivity analysis was performed for important uncertain parameters
Song et al, 2004^380^ | Compare the potential clinical and economic consequences of fecal DNA testing with those of established screening strategies and determine the target attributes that would make fecal DNA testing comparable with screening colonoscopy | | Cost Effectiveness Analysis

Appendix E Table 56 Evaluation of Decisionmaking Models of Cost-Effectiveness of Screening

Reference | Alternative Strategies | Measure of Cost/Consequence | Differential Timing Adjustment | Incremental Analysis Performed | Uncertainty Allowance | Results
Frazier et al, 2000^376^ | 1. No screen; 2. Sigmoidoscopy-1 at age 55 years; 3. Sigmoidoscopy-2 at age 55 years; 4. Double-contrast barium enema; at age 55 years; 5. Sigmoidoscopy-1 every 10 years; 6. Sigmoidoscopy-2 every 10 years; 7. Colonoscopy at age 55 years; 8. Sigmoidoscopy-1 every 5 years; 9. Double-contrast barium enema; every 10 years; 10. Sigmoidoscopy-2 every 5 years; 11. Unrehydrated fecal occult blood testing; 12. Unrehydrated fecal occult blood testing+sigmoidoscopy-1 every 10 years; 13. Unrehydrated fecal occult blood testing+sigmoidoscopy-2 every 10 years; 14. Double-contrast barium enema; every 5 years; 15. Rehydrated fecal occult blood testing; 16. Unrehydrated fecal occult blood testing+sigmoidoscopy-1 every 5 years; 17. Colonoscopy every 10 years; 18. Unrehydrated fecal occult blood testing+sigmoidoscopy-2 every 5 years; 19. Rehydrated fecal occult blood testing+sigmoidoscopy-1 every 10 years; 20. Rehydrated fecal occult blood testing+sigmoidoscopy-2 every 10 years; 21. Rehydrated fecal occult blood testing+sigmoidoscopy-1 every 5 years; 22. Rehydrated fecal occult blood testing+sigmoidoscopy-2 every 5 years | 1. Lifetime cost per person screened, measured by dollar; 2. Life expectancy, measured by year; 3. Reduction in colorectal cancer incidence and mortality | | Yes | Yes | 1. In 1 base-case analysis, compliance was assumed to be 60% with the initial screen and 80% with followup or surveillance colonoscopy; annual rehydrated fecal occult blood testing plus sigmoidoscopy every 5 years had an incremental CE ratio of $489,900 per life-year gained compared with the same strategy every 10 years; 2. The most effective strategy for white men was annual rehydrated fecal occult blood testing plus sigmoidoscopy (followed by colonoscopy if either a low- or high-risk polyp was found) every 5 years from age 50 to 85 years, which resulted in a 60% reduction in cancer incidence and an 80% reduction in colorectal cancer mortality compared with no screening, and an incremental CE ratio of $92,900 per year of life gained compared with annual unrehydrated fecal occult blood testing plus sigmoidoscopy every 5 years; 3. In a base-case analysis in which compliance with screening and followup is assumed to be 100%, screening more often than every 10 years was prohibitively expensive; 4. Other strategies recommended by the expert panel were either less effective or cost more per year of life gained than the alternatives; 5. Colonoscopy every 10 years was less effective than the combination of annual fecal occult blood testing plus sigmoidoscopy every 5 years. However, a single colonoscopy at age 55 years achieves nearly half of the reduction in colorectal cancer mortality obtainable with colonoscopy every 10 years; 6. Because of increased life expectancy among white women and increased cancer mortality among blacks, colorectal cancer screening was even more cost effective in these groups than in white men.
Vijan et al, 2001^377^ | 1. No screening; 2. Sigmoidoscopy; 3. Colonoscopy at age 60 years; 4. Colonoscopy at age 55 years; 5. Fecal occult blood testing; 6. Colonoscopy at ages 55 years and 65 years; 7. Colonoscopy at ages 50 years and 60 years; 8. Sigmoidoscopy and fecal occult blood testing | 1. Average gain in life expectancy, measured by days; 2. Average cost, measured by dollar; 3. Relative reduction in colorectal cancer | Costs and life expectancy discounted at 3% per annum | Yes | Yes | 1. All strategies are cost effective versus no screening, at less than $20,000 per life- year saved; 2. Direct comparison suggests that the most effective strategies are twice-lifetime colonoscopy and flexible sigmoidoscopy combined with fecal occult blood testing; 3. Assuming perfect compliance, flexible sigmoidoscopy combined with fecal occult blood testing is slightly more effective than twice-lifetime colonoscopy (at ages 50 and 60 years) but is substantially more expensive, with an incremental cost effectiveness of $390,000 per additional life-year saved; 4. Colonoscopy at ages 50 and 60 years is the preferred test regardless of compliance with the primary screening test; 5. If followup colonoscopy for polyps is less than 75%, then even once-lifetime colonoscopy is preferred over most combinations of flexible sigmoidoscopy and fecal occult blood testing.
Ness et al, 2000^378^ | 1. Never screening; 2. Colonoscopy screening at age 60–64 years; 3. Colonoscopy screening at age 55–59 years; 4. Colonoscopy screening at age 50–54 years; 5. Colonoscopy screening at age 45–49 years | 1. Cost is measured by dollars; 2. Effectiveness (utility) is measured by QALYs | 1. All costs and QALYs are discounted at a 3% annual rate; 2. In sensitivity analysis discount rate varied from 0% to 5% | Yes | Yes | 1. For both sexes, one-time colonoscopic screening between 50 and 54 years of age is associated with a marginal cost-utility of less than $10,000 per additional quality-adjusted life-year compared to screening between 55 and 60 years of age; 2. Onetime colonoscopic screening between 45 and 49 years of age is either dominated (women) or associated with a marginal cost-utility of $69,000/per quality-adjusted life-year (men) compared to screening between 50 and 54 years of age; 3. The marginal cost-utility of one-time colonoscopic screening is relatively insensitive to plausible changes in the cost of colonoscopy, the cost of colorectal cancer treatment, the sensitivity of colonoscopy for colorectal neoplasia, the utility values representing the morbidity associated with the colorectal cancer-related health states, and the discount rate.
Loeve et al, 2000^379^ | 1. Sigmoidoscopy at age 50 years; 2. Sigmoidoscopy at age 55 years; 3. Sigmoidoscopy at age 60 years; 4. Sigmoidoscopy at age 65 years; 5. Sigmoidoscopy at age 70 years; 6. Sigmoidoscopy at age 75 years | All costs and savings are measured by dollars | 3% discount rate is applied to costs and health effects | N/A | Yes | 1. Given the expert opinion- based assumptions, a program based on every 5-year sigmoidoscopy screenings could result in a net savings of direct health care costs due to prevention of cancer treatment costs that compensate for the costs of screening, diagnostic followup, and surveillance; 2. This result persists when costs and health effects are discounted at 3%; 3. The “break-even” point, the time required before savings exceed costs, is 35 years for a screening program that terminates after 30 years and 44 years for a screening program that continues on indefinitely
Song et al, 2004^380^ | 1. Natural history (no screening); 2. Fecal DNA testing; 3. Flexible sigmoidoscopy; 4. Fecal occult blood testing; 5. Colonoscopy | 1. Costs are measured by dollars; 2. Effectiveness is measured by life-years gained | Life years and costs were discounted at 3% annually | Yes | Yes | 1. Compared with no screening, fecal-DNA at a screening interval of 5 years decreased colorectal cancer incidence by 35% and colorectal cancer mortality by 54% and gained 4,560 life- years per 100,000 persons at $47,700/life-year gained in the base case; 2. The average number of colonoscopies per person was 3.8 with colonoscopy and 0.8 with fecal-DNA; 3. in most 1-way sensitivity analyses and Monte Carlo simulation iterations, fecal-DNA remained reasonably cost-effective compared with no screening, but colonoscopy and fecal occult blood testing dominated fecal-DNA; 4. Assuming fecal DNA testing sensitivities of 65% for colorectal cancer and 40% for large polyp, and 95% specificity, a screening interval of 2 years and a test cost of $195 would be required to make fecal-DNA comparable with colonoscopy

## References for Appendix E

1 Plassman BL, Langa KM, Fisher GG, et al. Prevalence of cognitive impairment without dementia in the United States. [summary for patients in Ann Intern Med. 2008 Mar 18;148(6):I-53; PMID: 18347348]. Annals of internal medicine. 03. 18. 2008;148(6):427-34. [pmid: 18347351].
2 Tabbarah M, Mihelic A, Crimmins E. Disability: the demographics of physical functioning and home environments of older Americans. Journal of Architectural and Planning Research. 2001;18(3):183-93.
3 Fuller-Thomson E, Nuru-Jeter A, Minkler M, et al. Black-White disparities in disability among older Americans: further untangling the role of race and socioeconomic status. J Aging Health. 08. 2009;21(5):677-98. [pmid: 19584411].
4 Fuller-Thomson E, Yu B, Nuru-Jeter A, et al. Basic ADL disability and functional limitation rates among older AMERICANS from 2000–2005: the end of the decline?. J Gerontol A Biol Sci Med Sci. 12. 2009;64(12):1333-6. [pmid: 19723771].
5 Gallo JJ, Schoen R, Jones R. Cognitive impairment and syndromal depression in estimates of active life expectancy: the 13-year follow-up of the Baltimore Epidemiologic Catchment Area sample. Acta Psychiatrica Scandinavica. 04. 2000;101(4):265-73. [pmid: 10782545].
6 Klein BE, Klein R, Knudtson MD, et al. Frailty, morbidity and survival. Arch Gerontol Geriatr. 09–10. 2005;41(2):141-9. [pmid: 16085065].
7 Goins RT, Moss M, Buchwald D, et al. Disability among older American Indians and Alaska Natives: an analysis of the 2000 Census Public Use Microdata Sample. Gerontologist. 10. 2007;47(5):690-6. [pmid: 17989411].
8 Stookey JD, Purser JL, Pieper CF, et al. Plasma hypertonicity: another marker of frailty?. J Am Geriatr Soc. 08. 2004;52(8):1313-20. [pmid: 15271119].
9 Cohen HJ, Harris T, Pieper CF. Coagulation and activation of inflammatory pathways in the development of functional decline and mortality in the elderly. Am J Med. 02. 15. 2003;114(3):180-7. [pmid: 12637131].
10 Ferrucci L, Guralnik JM, Pahor M, et al. Hospital diagnoses, Medicare charges, and nursing home admissions in the year when older persons become severely disabled.[see comment]. JAMA. 03. 5. 1997;277(9):728-34. [pmid: 9042845].
11 Hanlon JT, Fillenbaum GG, Kuchibhatla M, et al. Impact of inappropriate drug use on mortality and functional status in representative community dwelling elders. Med Care. 02. 2002;40(2):166-76. [pmid: 11802089].
12 Corti MC, Guralnik JM, Salive ME, et al. Serum albumin level and physical disability as predictors of mortality in older persons. JAMA. 10. 5. 1994;272(13):1036-42. [pmid: 8089886].
13 Hays JC, Keller HH, Ostbye T. The effects of nutrition-related factors on four-year mortality among a biracial sample of community-dwelling elders in the North Carolina piedmont. J Nutr Elder. 2005;25(2):41-67. [pmid: 17182466].
14 Melzer D, Lan TY, Guralnik JM. The predictive validity for mortality of the index of mobility-related limitation--results from the EPESE study. Age Ageing. 11. 2003;32(6):619-25. [pmid: 14600003].
15 Pahor M, Guralnik JM, Chrischilles EA, et al. Use of laxative medication in older persons and associations with low serum albumin. J Am Geriatr Soc. 01. 1994;42(1):50-6. [pmid: 8277116].
16 Ferrucci L, Guralnik JM, Salive ME, et al. Cognitive impairment and risk of stroke in the older population. J Am Geriatr Soc. 03. 1996;44(3):237-41. [pmid: 8600190].
17 Bassuk SS, Berkman LF, Wypij D. Depressive symptomatology and incident cognitive decline in an elderly community sample. Arch Gen Psychiatry. 12. 1998;55(12):1073-81. [pmid: 9862549].
18 Royall DR, Chiodo LK, Mouton C, et al. Cognitive predictors of mortality in elderly retirees: results from the Freedom House study. Am J Geriatr Psychiatry. 03. 2007;15(3):243-51. [pmid: 17322135].
19 Brody KK, Johnson RE, Douglas Ried L. Evaluation of a self-report screening instrument to predict frailty outcomes in aging populations. Gerontologist. 04. 1997;37(2):182-91. [pmid: 9127974].
20 Chodosh J, Seeman TE, Keeler E, et al. Cognitive decline in high-functioning older persons is associated with an increased risk of hospitalization. J Am Geriatr Soc. 09. 2004;52(9):1456-62. [pmid: 15341546].
21 Seeman TE, Crimmins E, Huang MH, et al. Cumulative biological risk and socio-economic differences in mortality: MacArthur studies of successful aging. Social science & medicine. 05. 2004;58(10):1985-97. [pmid: 15020014].
22 Karlamangla AS, Singer BH, Seeman TE. Reduction in allostatic load in older adults is associated with lower all-cause mortality risk: MacArthur studies of successful aging. Psychosom Med. 05–06. 2006;68(3):500-7. [pmid: 16738085].
23 Bruce ML, Seeman TE, Merrill SS, et al. The impact of depressive symptomatology on physical disability: MacArthur Studies of Successful Aging. Am J Public Health. 11. 1994;84(11):1796-9. [pmid: 7977920].
24 Sarkisian CA, Gruenewald TL, John Boscardin W, et al. Preliminary evidence for subdimensions of geriatric frailty: the MacArthur study of successful aging. J Am Geriatr Soc. 12. 2008;56(12):2292-7. [pmid: 19016933].
25 Seeman TE, McEwen BS, Rowe JW, et al. Allostatic load as a marker of cumulative biological risk: MacArthur studies of successful aging. Proc Natl Acad Sci U S A. 04. 10. 2001;98(8):4770-5. [pmid: 11287659].
26 Kiely DK, Cupples LA, Lipsitz LA. Validation and comparison of two frailty indexes: The MOBILIZE Boston Study. J Am Geriatr Soc. 09. 2009;57(9):1532-9. [pmid: 19682112].
27 Kang HG, Costa MD, Priplata AA, et al. Frailty and the degradation of complex balance dynamics during a dual-task protocol. J Gerontol A Biol Sci Med Sci. 12. 2009;64(12):1304-11. [pmid: 19679739].
28 Cawthon PM, Marshall LM, Michael Y, et al. Frailty in older men: prevalence, progression, and relationship with mortality. J Am Geriatr Soc. 08. 2007;55(8):1216-23. [pmid: 17661960].
29 Shannon J, Shikany JM, Barrett-Connor E, et al. Demographic factors associated with the diet quality of older US men: baseline data from the Osteoporotic Fractures in Men (MrOS) study. Public Health Nutr. 08. 2007;10(8):810-8. [pmid: 17381915].
30 Wiener JM, Hanley RJ, Clark R, et al. Measuring the activities of daily living: comparisons across national surveys. J Gerontol. 11. 1990;45(6):S229-37. [pmid: 2146312].
31 Johnson TM 2nd, Bernard SL, Kincade JE, et al. Urinary incontinence and risk of death among community-living elderly people: results from the National Survey on Self-Care and Aging. J Aging Health. 02. 2000;12(1):25-46. [pmid: 10848124].
32 Gill TM, Kurland B. The burden and patterns of disability in activities of daily living among community-living older persons. J Gerontol A Biol Sci Med Sci. 01. 2003;58(1):70-5. [pmid: 12560415].
33 Gill TM, Kurland BF. Prognostic effect of prior disability episodes among nondisabled community-living older persons. Am J Epidemiol. 12. 1. 2003;158(11):1090-6. [pmid: 14630605].
34 Hardy SE, Gill TM. Recovery from disability among community-dwelling older persons. JAMA. 04. 7. 2004;291(13):1596-602. [pmid: 15069047].
35 Gill TM, Allore H, Holford TR, et al. The development of insidious disability in activities of daily living among community-living older persons. Am J Med. 10. 1. 2004;117(7):484-91. [pmid: 15464705].
36 Gill TM, Allore HG, Holford TR, et al. Hospitalization, restricted activity, and the development of disability among older persons. JAMA. 11. 3. 2004;292(17):2115-24. [pmid: 15523072].
37 Hardy SE, Dubin JA, Holford TR, et al. Transitions between states of disability and independence among older persons. Am J Epidemiol. 03. 15. 2005;161(6):575-84. [pmid: 15746474].
38 Gill TM, Allore H, Hardy SE, et al. Estimates of active and disabled life expectancy based on different assessment intervals. J Gerontol A Biol Sci Med Sci. 08. 2005;60(8):1013-6. [pmid: 16127105].
39 Gill TM, Guo Z, Allore HG. The epidemiology of bathing disability in older persons. J Am Geriatr Soc. 10. 2006;54(10):1524-30. [pmid: 17038069].
40 Gill TM, Han L, Allore HG. Predisposing factors and precipitants for bathing disability in older persons. J Am Geriatr Soc. 04. 2007;55(4):534-40. [pmid: 17397431].
41 Gill TM, Guo Z, Allore HG. Subtypes of disability in older persons over the course of nearly 8 years. J Am Geriatr Soc. 03. 2008;56(3):436-43. [pmid: 18194225].
42 Gill TM, Murphy TE, Barry LC, et al. Risk factors for disability subtypes in older persons. J Am Geriatr Soc. 10. 2009;57(10):1850-5. [pmid: 19694870].
43 Gill TM, Gahbauer EA. Evaluating disability over discrete periods of time. J Gerontol A Biol Sci Med Sci. 06. 2008;63(6):588-94. [pmid: 18559633].
44 Rothman MD, Leo-Summers L, Gill TM. Prognostic significance of potential frailty criteria. J Am Geriatr Soc. 12. 2008;56(12):2211-116. [pmid: 19093920].
45 Takahashi PY, Dyrbye LN, Thomas KG, et al. The association of transient ischemic attack symptoms with memory impairment among elderly participants of the Third US National Health and Nutrition Examination Survey. J Geriatr Psychiatry Neurol. 03. 2009;22(1):46-51. [pmid: 19073836].
46 Patel KV, Semba RD, Ferrucci L, et al. Red cell distribution width and mortality in older adults: a meta-analysis. J Gerontol A Biol Sci Med Sci. 03. 2010;65(3):258-65. [pmid: 19880817].
47 Kelman HR, Thomas C, Kennedy GJ, et al. Cognitive impairment and mortality in older community residents. American Journal of Public Health. 08. 1994;84(8):1255-60. [pmid: 8059881].
48 Albert SM, Alam M, Nizamuddin M, et al. Comparative study of functional limitation and disability in old age: Delhi and New York city. Journal of Cross-Cultural Gerontology. 09. 2005;20(3):231-41. [pmid: 17013664].
49 Ensrud KE, Ewing SK, Taylor BC, et al. Frailty and risk of falls, fracture, and mortality in older women: the study of osteoporotic fractures. J Gerontol A Biol Sci Med Sci. 07. 2007;62(7):744-51. [pmid: 17634322].
50 Ensrud KE, Ewing SK, Taylor BC, et al. Comparison of 2 frailty indexes for prediction of falls, disability, fractures, and death in older women. Arch Intern Med. 02. 25. 2008;168(4):382-9. [pmid: 18299493].
51 Ensrud KE, Ewing SK, Cawthon PM, et al. A comparison of frailty indexes for the prediction of falls, disability, fractures, and mortality in older men. J Am Geriatr Soc. 03. 2009;57(3):492-8. [pmid: 19245414].
52 Kravitz BA, Corrada MM, Kawas CH. High levels of serum C-reactive protein are associated with greater risk of all-cause mortality, but not dementia, in the oldest-old: results from The 90+ Study. J Am Geriatr Soc. 04. 2009;57(4):641-6. [pmid: 19245412].
53 Hall CB, Verghese J, Sliwinski M, et al. Dementia incidence may increase more slowly after age 90: results from the Bronx Aging Study. Neurology. 09. 27. 2005;65(6):882-6. [pmid: 16186528].
54 Fried LP, Kronmal RA, Newman AB, et al. Risk factors for 5-year mortality in older adults: the Cardiovascular Health Study. JAMA. 02. 25. 1998;279(8):585-92. [pmid: 9486752].
55 Fried LP, Tangen CM, Walston J, et al. Frailty in older adults: evidence for a phenotype. J Gerontol A Biol Sci Med Sci. 03. 2001;56(3):M146-56. [pmid: 11253156].
56 Walston J, McBurnie MA, Newman A, et al. Frailty and activation of the inflammation and coagulation systems with and without clinical comorbidities: results from the Cardiovascular Health Study. Arch Intern Med. 11. 11. 2002;162(20):2333-41. [pmid: 12418947].
57 Fitzpatrick AL, Kuller LH, Ives DG, et al. Incidence and prevalence of dementia in the Cardiovascular Health Study. J Am Geriatr Soc. 02. 2004;52(2):195-204. [pmid: 14728627].
58 Cao JJ, Arnold AM, Manolio TA, et al. Association of carotid artery intima-media thickness, plaques, and C-reactive protein with future cardiovascular disease and all-cause mortality: the Cardiovascular Health Study. Circulation. 07. 3. 2007;116(1):32-8. [pmid: 17576871].
59 Lopez OL, Jagust WJ, DeKosky ST, et al. Prevalence and classification of mild cognitive impairment in the Cardiovascular Health Study Cognition Study: part 1. Archives of Neurology. 10. 2003;60(10):1385-9. [pmid: 14568808].
60 Newman AB, Arnold AM, Sachs MC, et al. Long-term function in an older cohort--the cardiovascular health study all stars study. J Am Geriatr Soc. 03. 2009;57(3):432-40. [pmid: 19187412].
61 Zakai NA, Katz R, Hirsch C, et al. A prospective study of anemia status, hemoglobin concentration, and mortality in an elderly cohort: the Cardiovascular Health Study. Arch Intern Med. 10. 24. 2005;165(19):2214-20. [pmid: 16246985].
62 Kulminski AM, Ukraintseva SV, Kulminskaya IV, et al. Cumulative deficits better characterize susceptibility to death in elderly people than phenotypic frailty: lessons from the Cardiovascular Health Study. J Am Geriatr Soc. 05. 2008;56(5):898-903. [pmid: 18363679].
63 Jenny NS, Yanez ND, Psaty BM, et al. Inflammation biomarkers and near-term death in older men. Am J Epidemiol. 03. 15. 2007;165(6):684-95. [pmid: 17215383].
64 Newman AB, Yanez D, Harris T, et al. Weight change in old age and its association with mortality. J Am Geriatr Soc. 10. 2001;49(10):1309-18. [pmid: 11890489].
65 Tschanz JT, Corcoran C, Skoog I, et al. Dementia: the leading predictor of death in a defined elderly population: the Cache County Study. Neurology. 04. 13. 2004;62(7):1156-62. [pmid: 15079016].
66 Wilson RS, Bennett DA, Bienias JL, et al. Cognitive activity and cognitive decline in a biracial community population. Neurology. 09. 23. 2003;61(6):812-6. [pmid: 14504326].
67 Jefferson AL, Massaro JM, Wolf PA, et al. Inflammatory biomarkers are associated with total brain volume: the Framingham Heart Study. Neurology. 03. 27. 2007;68(13):1032-8. [pmid: 17389308].
68 Ledikwe JH, Smiciklas-Wright H, Mitchell DC, et al. Dietary patterns of rural older adults are associated with weight and nutritional status. J Am Geriatr Soc. 04. 2004;52(4):589-95. [pmid: 15066076].
69 Stump TE, Callahan CM, Hendrie HC. Cognitive impairment and mortality in older primary care patients. J Am Geriatr Soc. 07. 2001;49(7):934-40. [pmid: 11527485].
70 Keller BK, Potter JF. Predictors of mortality in outpatient geriatric evaluation and management clinic patients. J Gerontol. 11. 1994;49(6):M246-51. [pmid: 7963276].
71 Lee SJ, Lindquist K, Segal MR, et al. Development and validation of a prognostic index for 4-year mortality in older adults. Jama. 02. 15. 2006;295(7):801-8. [pmid: 16478903].
72 Cigolle CT, Ofstedal MB, Tian Z, et al. Comparing models of frailty: the Health and Retirement Study. J Am Geriatr Soc. 05. 2009;57(5):830-9. [pmid: 19453306].
73 Koster A, Penninx BW, Bosma H, et al. Is there a biomedical explanation for socioeconomic differences in incident mobility limitation?. J Gerontol A Biol Sci Med Sci. 08. 2005;60(8):1022-7. [pmid: 16127107].
74 Peterson MJ, Giuliani C, Morey MC, et al. Physical activity as a preventative factor for frailty: the health, aging, and body composition study. J Gerontol A Biol Sci Med Sci. 01. 2009;64(1):61-8. [pmid: 19164276].
75 Newman AB, Kupelian V, Visser M, et al. Sarcopenia: alternative definitions and associations with lower extremity function. Journal of the American Geriatrics Society. 11. 2003;51(11):1602-9. [pmid: 14687390].
76 Visser M, Pahor M, Taaffe DR, et al. Relationship of interleukin-6 and tumor necrosis factor-alpha with muscle mass and muscle strength in elderly men and women: the Health ABC Study. J Gerontol A Biol Sci Med Sci. 05. 2002;57(5):M326-32. [pmid: 11983728].
77 Yaffe K, Lindquist K, Penninx BW, et al. Inflammatory markers and cognition in well-functioning African-American and white elders. Neurology. 07. 8. 2003;61(1):76-80. [pmid: 12847160].
78 Schaap LA, Pluijm SM, Deeg DJ, et al. Higher inflammatory marker levels in older persons: associations with 5-year change in muscle mass and muscle strength. J Gerontol A Biol Sci Med Sci. 11. 2009;64(11):1183-9. [pmid: 19622801].
79 Hsu FC, Kritchevsky SB, Liu Y, et al. Association between inflammatory components and physical function in the health, aging, and body composition study: a principal component analysis approach. J Gerontol A Biol Sci Med Sci. 05. 2009;64(5):581-9. [pmid: 19228783].
80 Stewart R, Masaki K, Xue QL, et al. A 32-year prospective study of change in body weight and incident dementia: the Honolulu-Asia Aging Study. Arch Neurol. 01. 2005;62(1):55-60. [pmid: 15642850].
81 Schmidt R, Schmidt H, Curb JD, et al. Early inflammation and dementia: a 25-year follow-up of the Honolulu-Asia Aging Study. Annals of Neurology. 08. 2002;52(2):168-74. [pmid: 12210786].
82 Harris TB, Ferrucci L, Tracy RP, et al. Associations of elevated interleukin-6 and C-reactive protein levels with mortality in the elderly. Am J Med. 05. 1999;106(5):506-12. [pmid: 10335721].
83 Eaker ED, Vierkant RA, Mickel SF. Predictors of nursing home admission and/or death in incident Alzheimer’s disease and other dementia cases compared to controls: a population-based study. J Clin Epidemiol. 05. 2002;55(5):462-8. [pmid: 12007549].
84 Stewart ST, Woodward RM, Rosen AB, et al. The impact of symptoms and impairments on overall health in US national health data. Med Care. 09. 2008;46(9):954-62. [pmid: 18725850].
85 Ganguli M, Dodge HH, Mulsant BH. Rates and predictors of mortality in an aging, rural, community-based cohort: the role of depression. Arch Gen Psychiatry. 11. 2002;59(11):1046-52. [pmid: 12418938].
86 Crimmins EM, Saito Y, Reynolds SL. Further evidence on recent trends in the prevalence and incidence of disability among older Americans from two sources: the LSOA and the NHIS. J Gerontol B Psychol Sci Soc Sci. 03. 1997;52(2):S59-71. [pmid: 9060986].
87 Pressley JC, Patrick CH. Frailty bias in comorbidity risk adjustments of community-dwelling elderly populations. J Clin Epidemiol. 08. 1999;52(8):753-60. [pmid: 10465320].
88 Mathieson KM, Kronenfeld JJ, Keith VM. Maintaining functional independence in elderly adults: the roles of health status and financial resources in predicting home modifications and use of mobility equipment. Gerontologist. 02. 2002;42(1):24-31. [pmid: 11815696].
89 Silver MH, Jilinskaia E, Perls TT. Cognitive functional status of age-confirmed centenarians in a population-based study. J Gerontol B Psychol Sci Soc Sci. 05. 2001;56(3):P134-40. [pmid: 11316831].
90 Baumgartner RN, Koehler KM, Gallagher D, et al. Epidemiology of sarcopenia among the elderly in New Mexico. Am J Epidemiol. 04. 15. 1998;147(8):755-63. [pmid: 9554417].
91 Cheng H, Gurland BJ, Maurer MS. Self-reported lack of energy (anergia) among elders in a multiethnic community. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 07. 2008;63(7):707-14.
92 Weatherspoon LJ, Worthen HD, Handu D. Nutrition risk and associated factors in congregate meal participants in northern Florida: role of Elder Care Services (ECS). J Nutr Elder. 2004;24(2):37-54. [pmid: 15778156].
93 Johnson MA, Fischer JG, Park S. Vitamin D deficiency and insufficiency in the Georgia Older Americans Nutrition Program. J Nutr Elder. 2008;27(1–2):29-46. [pmid: 18928189].
94 Aggarwal NT, Wilson RS, Beck TL, et al. Motor dysfunction in mild cognitive impairment and the risk of incident Alzheimer disease. Archives of Neurology. 12. 2006;63(12):1763-9. [pmid: 17172617].
95 Buchman AS, Wilson RS, Bienias JL, et al. Change in frailty and risk of death in older persons. Exp Aging Res. 01–03. 2009;35(1):61-82. [pmid: 19173102].
96 Espinoza SE, Hazuda HP. Frailty in older Mexican-American and European-American adults: is there an ethnic disparity?. J Am Geriatr Soc. 09. 2008;56(9):1744-9. [pmid: 18662198].
97 Santos-Eggimann B, Cuenoud P, Spagnoli J, et al. Prevalence of frailty in middle-aged and older community-dwelling Europeans living in 10 countries. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 06. 2009;64(6):675-81.
98 Fried LP, Xue QL, Cappola AR, et al. Nonlinear multisystem physiological dysregulation associated with frailty in older women: implications for etiology and treatment. J Gerontol A Biol Sci Med Sci. 10. 2009;64(10):1049-57. [pmid: 19567825].
99 Bandeen-Roche K, Xue QL, Ferrucci L, et al. Phenotype of frailty: characterization in the women’s health and aging studies. J Gerontol A Biol Sci Med Sci. 03. 2006;61(3):262-6. [pmid: 16567375].
100 Volpato S, Guralnik JM, Ferrucci L, et al. Cardiovascular disease, interleukin-6, and risk of mortality in older women: the women’s health and aging study. Circulation. 02. 20. 2001;103(7):947-53. [pmid: 11181468].
101 Cappola AR, Xue QL, Ferrucci L, et al. Insulin-like growth factor I and interleukin-6 contribute synergistically to disability and mortality in older women. Journal of Clinical Endocrinology & Metabolism. 05. 2003;88(5):2019-25. [pmid: 12727948].
102 Walston J, Xue Q, Semba RD, et al. Serum antioxidants, inflammation, and total mortality in older women. Am J Epidemiol. 01. 1. 2006;163(1):18-26. [pmid: 16306311].
103 Szanton SL, Allen JK, Seplaki CL, et al. Allostatic load and frailty in the women’s health and aging studies. Biol Res Nurs. 01. 2009;10(3):248-56. [pmid: 18829589].
104 Chang SS, Weiss CO, Xue QL, et al. Patterns of comorbid inflammatory diseases in frail older women: the Women’s Health and Aging Studies I and II. J Gerontol A Biol Sci Med Sci. 04. 2010;65(4):407-13. [pmid: 19933749].
105 Semba RD, Houston DK, Ferrucci L, et al. Low serum 25-hydroxyvitamin D concentrations are associated with greater all-cause mortality in older community-dwelling women. Nutr Res. 08. 2009;29(8):525-30. [pmid: 19761886].
106 Fried LP, Bandeen-Roche K, Kasper JD, et al. Association of comorbidity with disability in older women: the Women’s Health and Aging Study. J Clin Epidemiol. 01. 1999;52(1):27-37. [pmid: 9973071].
107 Semba RD, Ricks MO, Ferrucci L, et al. Types of anemia and mortality among older disabled women living in the community: the Women’s Health and Aging Study I. Aging Clin Exp Res. 08. 2007;19(4):259-64. [pmid: 17726354].
108 Xue QL, Fried LP, Glass TA, et al. Life-space constriction, development of frailty, and the competing risk of mortality: the Women’s Health And Aging Study I. American Journal of Epidemiology. 01. 15. 2008;167(2):240-8. [pmid: 17906296].
109 Schmaltz HN, Fried LP, Xue QL, et al. Chronic cytomegalovirus infection and inflammation are associated with prevalent frailty in community-dwelling older women. J Am Geriatr Soc. 05. 2005;53(5):747-54. [pmid: 15877548].
110 Boyd CM, Xue QL, Simpson CF, et al. Frailty, hospitalization, and progression of disability in a cohort of disabled older women. American Journal of Medicine. 11. 2005;118(11):1225-31. [pmid: 16271906].
111 Blaum CS, Xue QL, Tian J, et al. Is hyperglycemia associated with frailty status in older women?. Journal of the American Geriatrics Society. 05. 2009;57(5):840-7. [pmid: 19484839].
112 Kenny AM, Waynik IY, Smith J, et al. Association between level of frailty and bone mineral density in community-dwelling men. Journal of Clinical Densitometry. 07–09. 2006;9(3):309-14. [pmid: 16931349].
113 Falconer J, Naughton BJ, Hughes SL, et al. Self-reported functional status predicts change in level of care in independent living residents of a continuing care retirement community. J Am Geriatr Soc. 03. 1992;40(3):255-8. [pmid: 1538045].
114 Shelton P, Sager MA, Schraeder C. The community assessment risk screen (CARS): identifying elderly persons at risk for hospitalization or emergency department visit. Am J Manag Care. 08. 2000;6(8):925-33. [pmid: 11186504].
115 Dorr DA, Jones SS, Burns L, et al. Use of health-related, quality-of-life metrics to predict mortality and hospitalizations in community-dwelling seniors. J Am Geriatr Soc. 04. 2006;54(4):667-73. [pmid: 16686880].
116 Malmgren JA, Koepsell TD, Martin DP, et al. Mortality, health services use, and health behavior in a cohort of well older adults. J Am Geriatr Soc. 01. 1999;47(1):51-9. [pmid: 9920229].
117 Perkins AJ, Kroenke K, Unutzer J, et al. Common comorbidity scales were similar in their ability to predict health care costs and mortality. J Clin Epidemiol. 10. 2004;57(10):1040-8. [pmid: 15528055].
118 Long SK, Liu K, Black K, et al. Getting by in the community: lessons from frail elders. J Aging Soc Policy. 2005;17(1):19-44. [pmid: 15760799].
119 Laird RD, Studenski S, Perera S, et al. Fall history is an independent predictor of adverse health outcomes and utilization in the elderly. Am J Manag Care. 12. 2001;7(12):1133-8. [pmid: 11767299].
120 Tennstedt S, Cafferata GL, Sullivan L. Depression among caregivers of impaired elders. J Aging Health. 02. 1992;4(1):58-76. [pmid: 10116446].
121 Dayhoff NE, Suhrheinrich J, Wigglesworth J, et al. Balance and muscle strength as predictors of frailty among older adults. J Gerontol Nurs. 07. 1998;24(7:):18-27. quiz 54–5. [pmid: 9801527].
122 Inouye SK, Bogardus ST Jr, Vitagliano G, et al. Burden of illness score for elderly persons: risk adjustment incorporating the cumulative impact of diseases, physiologic abnormalities, and functional impairments. Med Care. 01. 2003;41(1):70-83. [pmid: 12544545].
123 Bowles J, Brooks T, Hayes-Reams P, et al. Frailty, family, and church support among urban African American elderly. J Health Care Poor Underserved. 02. 2000;11(1):87-99. [pmid: 10778045].
124 Zarowitz BJ, Stebelsky LA, Muma BK, et al. Reduction of high-risk polypharmacy drug combinations in patients in a managed care setting. Pharmacotherapy. 11. 2005;25(11):1636-45. [pmid: 16232025].
125 Walter LC, Brand RJ, Counsell SR, et al. Development and validation of a prognostic index for 1-year mortality in older adults after hospitalization. Jama. 06. 20. 2001;285(23):2987-94. [pmid: 11410097].
126 Jette AM, Branch LG, Berlin J. Musculoskeletal impairments and physical disablement among the aged. J Gerontol. 11. 1990;45(6):M203-8. [pmid: 2229943].
127 Cho CY, Alessi CA, Cho M, et al. The association between chronic illness and functional change among participants in a comprehensive geriatric assessment program. J Am Geriatr Soc. 06. 1998;46(6):677-82. [pmid: 9625181].
128 Wieland D, Lamb VL, Sutton SR, et al. Hospitalization in the Program of All-Inclusive Care for the Elderly (PACE): rates, concomitants, and predictors. J Am Geriatr Soc. 11. 2000;48(11):1373-80. [pmid: 11083311].
129 Carey EC, Covinsky KE, Lui LY, et al. Prediction of mortality in community-living frail elderly people with long-term care needs. Journal of the American Geriatrics Society. 01. 2008;56(1):68-75. [pmid: 18031487].
130 Friedman DS, Wolfs RC, O’Colmain BJ, et al. Prevalence of open-angle glaucoma among adults in the United States. Arch Ophthalmol. 04. 2004;122(4):532-8. [pmid: 15078671].
131 Weiner M, Powe NR, Weller WE, et al. Alzheimer’s disease under managed care: implications from Medicare utilization and expenditure patterns. J Am Geriatr Soc. 06. 1998;46(6):762-70. [pmid: 9625195].
132 Marshall JA, Lopez TK, Shetterly SM, et al. Indicators of nutritional risk in a rural elderly Hispanic and non-Hispanic white population: San Luis Valley Health and Aging Study. J Am Diet Assoc. 03. 1999;99(3):315-22. [pmid: 10076583].
133 Freburger JK, Holmes GM. Physical therapy use by community-based older people. Phys Ther. 01. 2005;85(1):19-33. [pmid: 15623359].
134 Porell FW, Miltiades HB. Disability outcomes of older Medicare HMO enrollees and fee-for-service Medicare beneficiaries. J Am Geriatr Soc. 05. 2001;49(5):615-31. [pmid: 11380756].
135 Tyas SL, Salazar JC, Snowdon DA, et al. Transitions to mild cognitive impairments, dementia, and death: findings from the Nun Study.[see comment]. American Journal of Epidemiology. 06. 1. 2007;165(11):1231-8. [pmid: 17431012].
136 Thom DH, Haan MN, Van Den Eeden SK. Medically recognized urinary incontinence and risks of hospitalization, nursing home admission and mortality. Age & Ageing. 09. 1997;26(5):367-74. [pmid: 9351481].
137 Evans DA, Funkenstein HH, Albert MS, et al. Prevalence of Alzheimer’s disease in a community population of older persons. Higher than previously reported. JAMA. 11. 10. 1989;262(18):2551-6. [pmid: 2810583].
138 Martin CT, Kayser-Jones J, Stotts NA, et al. Risk for low weight in community-dwelling, older adults. Clin Nurse Spec. 07–08. 2007;21(4):203-11. quiz 12–3. [pmid: 17622809].
139 Bannerman E, Miller MD, Daniels LA, et al. Anthropometric indices predict physical function and mobility in older Australians: the Australian Longitudinal Study of Ageing. Public Health Nutr. 10. 2002;5(5):655-62. [pmid: 12372159].
140 Anpalahan M, Gibson SJ. Geriatric syndromes as predictors of adverse outcomes of hospitalization. Internal Medicine Journal. 01. 2008;38(1):16-23. [pmid: 17542997].
141 Visvanathan R, Macintosh C, Callary M, et al. The nutritional status of 250 older Australian recipients of domiciliary care services and its association with outcomes at 12 months. J Am Geriatr Soc. 07. 2003;51(7):1007-11. [pmid: 12834523].
142 Song X, Mitnitski A, Rockwood K. Prevalence and 10-year outcomes of frailty in older adults in relation to deficit accumulation. J Am Geriatr Soc. 04. 2010;58(4):681-7. [pmid: 20345864].
143 Gutman GM, Stark A, Donald A, et al. Contribution of self-reported health ratings to predicting frailty, institutionalization, and death over a 5-year period. Int Psychogeriatr. 2001;13(Supp 1):223-31. [pmid: 11892970].
144 Jones D, Song X, Mitnitski A, et al. Evaluation of a frailty index based on a comprehensive geriatric assessment in a population based study of elderly Canadians. Aging Clin Exp Res. 12. 2005;17(6):465-71. [pmid: 16485864].
145 Rockwood K, Andrew M, Mitnitski A. A comparison of two approaches to measuring frailty in elderly people. J Gerontol A Biol Sci Med Sci. 07. 2007;62(7):738-43. [pmid: 17634321].
146 Canadian study of health and aging: study methods and prevalence of dementia. CMAJ. 03. 15. 1994;150(6):899-913. [pmid: 8131123].
147 Rockwood K, Stolee P, McDowell I. Factors associated with institutionalization of older people in Canada: testing a multifactorial definition of frailty. J Am Geriatr Soc. 05. 1996;44(5):578-82. [pmid: 8617909].
148 Graham JE, Rockwood K, Beattie BL, et al. Prevalence and severity of cognitive impairment with and without dementia in an elderly population. Lancet. 06. 21. 1997;349(9068):1793-6. [pmid: 9269213].
149 Wolfson C, Wolfson DB, Asgharian M, et al. A reevaluation of the duration of survival after the onset of dementia. N Engl J Med. 04. 12. 2001;344(15):1111-6. [pmid: 11297701].
150 St John PD, Montgomery PR, Kristjansson B, et al. Cognitive scores, even within the normal range, predict death and institutionalization. Age Ageing. 09. 2002;31(5):373-8. [pmid: 12242200].
151 Fisk JD, Merry HR, Rockwood K. Variations in case definition affect prevalence but not outcomes of mild cognitive impairment. Neurology. 11. 11. 2003;61(9):1179-84. [pmid: 14610117].
152 Disability and frailty among elderly Canadians: a comparison of six surveys. Int Psychogeriatr. 2001;13(Supp 1):159-67. [pmid: 11892963].
153 Jones DM, Song X, Rockwood K. Operationalizing a frailty index from a standardized comprehensive geriatric assessment. J Am Geriatr Soc. 11. 2004;52(11):1929-33. [pmid: 15507074].
154 Wong RY, Miller WC. Adverse outcomes following hospitalization in acutely ill older patients. BMC Geriatr. 2008;8:10. [pmid: 18479512].
155 Dasgupta M, Rolfson DB, Stolee P, et al. Frailty is associated with postoperative complications in older adults with medical problems. Arch Gerontol Geriatr. 01–02. 2009;48(1):78-83. [pmid: 18068828].
156 Gu D, Dupre ME, Sautter J, et al. Frailty and mortality among Chinese at advanced ages. J Gerontol B Psychol Sci Soc Sci. 03. 2009;64(2):279-89. [pmid: 19196691].
157 Beck AM, Ovesen L, Osler M. The ‘Mini Nutritional Assessment’ (MNA) and the ‘Determine Your Nutritional Health’ Checklist (NSI Checklist) as predictors of morbidity and mortality in an elderly Danish population. Br J Nutr. 01. 1999;81(1):31-6. [pmid: 10341673].
158 Bruunsgaard H, Andersen-Ranberg K, Hjelmborg JB, et al. Elevated levels of tumor necrosis factor alpha and mortality in centenarians. Am J Med. 09. 2003;115(4):278-83. [pmid: 12967692].
159 Schultz-Larsen K, Avlund K. Tiredness in daily activities: a subjective measure for the identification of frailty among non-disabled community-living older adults. Arch Gerontol Geriatr. 01–02. 2007;44(1):83-93. [pmid: 17095107].
160 Gardener EA, Huppert FA, Guralnik JM, et al. Middle-aged and mobility-limited: prevalence of disability and symptom attributions in a national survey. J Gen Intern Med. 10. 2006;21(10):1091-6. [pmid: 16970558].
161 Tilvis RS, Kahonen-Vare MH, Jolkkonen J, et al. Predictors of cognitive decline and mortality of aged people over a 10-year period. J Gerontol A Biol Sci Med Sci. 03. 2004;59(3):268-74. [pmid: 15031312].
162 Strandberg TE, Tilvis RS. C-reactive protein, cardiovascular risk factors, and mortality in a prospective study in the elderly. Arteriosclerosis, Thrombosis & Vascular Biology. 04. 2000;20(4):1057-60.
163 Nuotio M, Tammela TL, Luukkaala T, et al. Predictors of institutionalization in an older population during a 13-year period: the effect of urge incontinence. J Gerontol A Biol Sci Med Sci. 08. 2003;58(8):756-62. [pmid: 12902536].
164 Jylha M, Paavilainen P, Lehtimaki T, et al. Interleukin-1 receptor antagonist, interleukin-6, and C-reactive protein as predictors of mortality in nonagenarians: the vitality 90+ study. J Gerontol A Biol Sci Med Sci. 09. 2007;62(9):1016-21. [pmid: 17895441].
165 Rolland Y, Lauwers-Cances V, Cesari M, et al. Physical performance measures as predictors of mortality in a cohort of community-dwelling older French women. Eur J Epidemiol. 2006;21(2):113-22. [pmid: 16518679].
166 Helmer C, Barberger-Gateau P, Letenneur L, et al. Subjective health and mortality in French elderly women and men. J Gerontol B Psychol Sci Soc Sci. 03. 1999;54(2):S84-92. [pmid: 10097778].
167 Raynaud-Simon A, Lafont S, Berr C, et al. Orosomucoid: a mortality risk factor in elderly people living in the community?. Clin Nutr. 02. 2002;21(1):45-50. [pmid: 11884012].
168 Carriere I, Dupuy AM, Lacroux A, et al. Biomarkers of inflammation and malnutrition associated with early death in healthy elderly people. J Am Geriatr Soc. 05. 2008;56(5):840-6. [pmid: 18410327].
169 Avila-Funes JA, Amieva H, Barberger-Gateau P, et al. Cognitive impairment improves the predictive validity of the phenotype of frailty for adverse health outcomes: the three-city study. J Am Geriatr Soc. 03. 2009;57(3):453-61. [pmid: 19245415].
170 Artero S, Ancelin ML, Portet F, et al. Risk profiles for mild cognitive impairment and progression to dementia are gender specific. J Neurol Neurosurg Psychiatry. 09. 2008;79(9):979-84. [pmid: 18450788].
171 Avila-Funes JA, Helmer C, Amieva H, et al. Frailty among community-dwelling elderly people in France: the three-city study. J Gerontol A Biol Sci Med Sci. 10. 2008;63(10):1089-96. [pmid: 18948560].
172 Jessen F, Wiese B, Bachmann C, et al. Prediction of dementia by subjective memory impairment: effects of severity and temporal association with cognitive impairment. Arch Gen Psychiatry. 04. 2010;67(4):414-22. [pmid: 20368517].
173 Guehne U, Luck T, Busse A, et al. Mortality in individuals with mild cognitive impairment. Results of the Leipzig Longitudinal Study of the Aged (LEILA75+). Neuroepidemiology. 2007;29(3–4):226-34. [pmid: 18073495].
174 Heun R, Kolsch H, Jessen F. Risk factors and early signs of Alzheimer’s disease in a family study sample. Risk of AD. Eur Arch Psychiatry Clin Neurosci. 02. 2006;256(1):28-36. [pmid: 15895300].
175 Cesari M, Onder G, Russo A, et al. Comorbidity and physical function: results from the aging and longevity study in the Sirente geographic area (ilSIRENTE study). Gerontology. 2006;52(1):24-32. [pmid: 16439821].
176 Cesari M, Penninx BW, Pahor M, et al. Inflammatory markers and physical performance in older persons: the InCHIANTI study. J Gerontol A Biol Sci Med Sci. 03. 2004;59(3):242-8. [pmid: 15031308].
177 Bartali B, Frongillo EA, Guralnik JM, et al. Serum micronutrient concentrations and decline in physical function among older persons. JAMA. 01. 23. 2008;299(3):308-15. [pmid: 18212315].
178 Alley DE, Crimmins E, Bandeen-Roche K, et al. Three-year change in inflammatory markers in elderly people and mortality: the Invecchiare in Chianti study. J Am Geriatr Soc. 11. 2007;55(11):1801-7. [pmid: 17727645].
179 Pizzarelli F, Lauretani F, Bandinelli S, et al. Predictivity of survival according to different equations for estimating renal function in community-dwelling elderly subjects. Nephrology Dialysis Transplantation. 04. 2009;24(4):1197-205.
180 Cesari M, Pahor M, Lauretani F, et al. Skeletal muscle and mortality results from the InCHIANTI Study. J Gerontol A Biol Sci Med Sci. 03. 2009;64(3):377-84. [pmid: 19181709].
181 Maggio M, Ceda GP, Lauretani F, et al. Relationship between higher estradiol levels and 9-year mortality in older women: the Invecchiare in Chianti study. J Am Geriatr Soc. 10. 2009;57(10):1810-5. [pmid: 19737330].
182 Ravaglia G, Forti P, Maioli F, et al. Blood inflammatory markers and risk of dementia: The Conselice Study of Brain Aging. Neurobiol Aging. 12. 2007;28(12):1810-20. [pmid: 17011077].
183 Passarino G, Montesanto A, De Rango F, et al. A cluster analysis to define human aging phenotypes. Biogerontology. 06. 2007;8(3):283-90. [pmid: 17164982].
184 Onder G, Landi F, Volpato S, et al. Serum cholesterol levels and in-hospital mortality in the elderly. Am J Med. 09. 2003;115(4):265-71. [pmid: 12967690].
185 Solfrizzi V, Scafato E, Capurso C, et al. Metabolic syndrome, mild cognitive impairment, and progression to dementia. The Italian Longitudinal Study on Aging. Neurobiol Aging. 2009. 12. 30.
186 Zoppini G, Verlato G, Targher G, et al. Variability of body weight, pulse pressure and glycaemia strongly predict total mortality in elderly type 2 diabetic patients. The Verona Diabetes Study. Diabetes Metab Res Rev. 11–12. 2008;24(8):624-8. [pmid: 18802932].
187 Mazzaglia G, Roti L, Corsini G, et al. Screening of older community-dwelling people at risk for death and hospitalization: the Assistenza Socio-Sanitaria in Italia project. J Am Geriatr Soc. 12. 2007;55(12):1955-60. [pmid: 17944891].
188 Zanetti M, Ballabio C, Abbate C, et al. Mild cognitive impairment subtypes and vascular dementia in community-dwelling elderly people: a 3-year follow-up study. J Am Geriatr Soc. 04. 2006;54(4):580-6. [pmid: 16686866].
189 de Groot LC, Verheijden MW, de Henauw S, et al. Lifestyle, nutritional status, health, and mortality in elderly people across Europe: a review of the longitudinal results of the SENECA study. J Gerontol A Biol Sci Med Sci. 12. 2004;59(12):1277-84. [pmid: 15699526].
190 Mitnitski A, Song X, Skoog I, et al. Relative fitness and frailty of elderly men and women in developed countries and their relationship with mortality. J Am Geriatr Soc. 12. 2005;53(12):2184-9. [pmid: 16398907].
191 Yap KB, Niti M, Ng TP. Nutrition screening among community-dwelling older adults in Singapore. Singapore Med J. 10. 2007;48(10):911-6. [pmid: 17909675].
192 Wikby A, Ferguson F, Forsey R, et al. An immune risk phenotype, cognitive impairment, and survival in very late life: impact of allostatic load in Swedish octogenarian and nonagenarian humans. J Gerontol A Biol Sci Med Sci. 05. 2005;60(5):556-65. [pmid: 15972602].
193 van den Biggelaar AH, Huizinga TW, de Craen AJ, et al. Impaired innate immunity predicts frailty in old age. The Leiden 85-plus study. Exp Gerontol. 09. 2004;39(9):1407-14. [pmid: 15489064].
194 Puts MT, Lips P, Deeg DJ. Sex differences in the risk of frailty for mortality independent of disability and chronic diseases. J Am Geriatr Soc. 01. 2005;53(1):40-7. [pmid: 15667374].
195 Schaap LA, Pluijm SM, Deeg DJ, et al. Inflammatory markers and loss of muscle mass (sarcopenia) and strength. Am J Med. 06. 2006;119(6):526 e9-17. [pmid: 16750969].
196 Visser M, Deeg DJ, Puts MT, et al. Low serum concentrations of 25-hydroxyvitamin D in older persons and the risk of nursing home admission. Am J Clin Nutr. 09. 2006;84(3:):616-22. quiz 71–2. [pmid: 16960177].
197 Dik MG, Jonker C, Hack CE, et al. Serum inflammatory proteins and cognitive decline in older persons. Neurology. 04. 26. 2005;64(8):1371-7. [pmid: 15851726].
198 Buurman BM, van Munster BC, Korevaar JC, et al. Prognostication in acutely admitted older patients by nurses and physicians. J Gen Intern Med. 11. 2008;23(11):1883-9. [pmid: 18769983].
199 Raji MA, Al Snih S, Ray LA, et al. Cognitive status and incident disability in older Mexican Americans: findings from the Hispanic established population for the epidemiological study of the elderly. Ethn Dis. Winter. 2004;14(1):26-31. [pmid: 15002920].
200 Espino DV, Bazaldua OV, Palmer RF, et al. Suboptimal medication use and mortality in an older adult community-based cohort: results from the Hispanic EPESE Study. J Gerontol A Biol Sci Med Sci. 02. 2006;61(2):170-5. [pmid: 16510861].
201 Raji MA, Kuo YF, Snih SA, et al. Cognitive status, muscle strength, and subsequent disability in older Mexican Americans. J Am Geriatr Soc. 09. 2005;53(9):1462-8. [pmid: 16137273].
202 Graham JE, Snih SA, Berges IM, et al. Frailty and 10-year mortality in community-living Mexican American older adults. Gerontology. 2009;55(6):644-51. [pmid: 19690395].
203 Ottenbacher KJ, Graham JE, Al Snih S, et al. Mexican Americans and frailty: findings from the Hispanic established populations epidemiologic studies of the elderly. Am J Public Health. 04. 2009;99(4):673-9. [pmid: 19197079].
204 Ottenbacher KJ, Ostir GV, Peek MK, et al. Frailty in older Mexican Americans. J Am Geriatr Soc. 09. 2005;53(9):1524-31. [pmid: 16137282].
205 Al Snih S, Raji MA, Markides KS, et al. Weight change and lower body disability in older Mexican Americans. J Am Geriatr Soc. 10. 2005;53(10):1730-7. [pmid: 16181172].
206 Syddall H, Roberts HC, Evandrou M, et al. Prevalence and correlates of frailty among community-dwelling older men and women: findings from the Hertfordshire Cohort Study. Age Ageing. 03. 2010;39(2):197-203. [pmid: 20007127].
207 Stephan BC, Matthews FE, McKeith IG, et al. Early cognitive change in the general population: how do different definitions work?. J Am Geriatr Soc. 10. 2007;55(10):1534-40. [pmid: 17908056].
208 Rait G, Fletcher A, Smeeth L, et al. Prevalence of cognitive impairment: results from the MRC trial of assessment and management of older people in the community. Age Ageing. 05. 2005;34(3):242-8. [pmid: 15863409].
209 Ahmad R, Bath PA. Identification of risk factors for 15-year mortality among community-dwelling older people using Cox regression and a genetic algorithm. J Gerontol A Biol Sci Med Sci. 08. 2005;60(8):1052-8. [pmid: 16127112].
210 Rocca WA, Hofman A, Brayne C, et al. The prevalence of vascular dementia in Europe: facts and fragments from 1980–1990 studies. EURODEM-Prevalence Research Group. Annals of Neurology. 12. 1991;30(6):817-24. [pmid: 1838681].
211 Ritchie K, Kildea D. Is senile dementia “age-related” or “ageing-related”?--evidence from meta-analysis of dementia prevalence in the oldest old. Lancet. 10. 7. 1995;346(8980):931-4. [pmid: 7564727].
212 Veehof L, Stewart R, Haaijer-Ruskamp F, et al. The development of polypharmacy. A longitudinal study. Fam Pract. 06. 2000;17(3):261-7. [pmid: 10846147].
213 Chen PC, Wilmoth JM. The effects of residential mobility on ADL and IADL limitations among the very old living in the community. J Gerontol B Psychol Sci Soc Sci. 05. 2004;59(3):S164-72. [pmid: 15118022].
214 Rakowski W, Fleischman JA, Mor V, et al. Self-Assessments of Health and Mortality Among Older Persons: Do Questions Other then Global Self-Rated Health Predict Mortality?. Research on Aging. 1993;15(1):92-116.
215 Murtagh KN, Hubert HB. Gender differences in physical disability among an elderly cohort. Am J Public Health. 08. 2004;94(8):1406-11. [pmid: 15284051].
216 Lesourd B, Decarli B, Dirren H. Longitudinal changes in iron and protein status of elderly Europeans. SENECA Investigators. Eur J Clin Nutr. 07. 1996;50(Suppl 2):S16-24. [pmid: 8841781].
217 Dallman PR, Yip R, Johnson C. Prevalence and causes of anemia in the United States, 1976 to 1980. Am J Clin Nutr. 03. 1984;39(3):437-45. [pmid: 6695843].
218 de Groot LC, Beck AM, Schroll M, et al. Evaluating the DETERMINE Your Nutritional Health Checklist and the Mini Nutritional Assessment as tools to identify nutritional problems in elderly Europeans. Eur J Clin Nutr. 12. 1998;52(12):877-83. [pmid: 9881882].
219 Nelson KM, Reiber G, Kohler T, et al. Peripheral arterial disease in a multiethnic national sample: the role of conventional risk factors and allostatic load. Ethn Dis. Autumn. 2007;17(4):669-75. [pmid: 18072377].
220 Pratt LA, Weeks JD, Goulding MR. Measures of cognitive functioning in the 1994–2000 Second Longitudinal Study of Aging. Natl Health Stat Report. 07. 7. 2008;(2):1-15. [pmid: 18839800].
221 Pearson JM, Schlettwein-Gsell D, Brzozowska A, et al. Life style characteristics associated with nutritional risk in elderly subjects aged 80–85 years. J Nutr Health Aging. 2001;5(4):278-83. [pmid: 11753495].
222 Tuokko HA, Frerichs RJ, Kristjansson B. Cognitive impairment, no dementia: concepts and issues. Int Psychogeriatr. 2001;13(Supp 1):183-202. [pmid: 11892966].
223 Lee Y, Back JH, Kim J, et al. Systematic review of health behavioral risks and cognitive health in older adults. Int Psychogeriatr. 03. 22(2):174-87. [pmid: 19883522].
224 Masur DM, Sliwinski M, Lipton RB, et al. Neuropsychological prediction of dementia and the absence of dementia in healthy elderly persons. Neurology. 08. 1994;44(8):1427-32. [pmid: 8058143].
225 Jacobs DM, Sano M, Dooneief G, et al. Neuropsychological detection and characterization of preclinical Alzheimer’s disease. Neurology. 05. 1995;45(5):957-62. [pmid: 7746414].
226 Linn RT, Wolf PA, Bachman DL, et al. The ‘preclinical phase’ of probable Alzheimer’s disease. A 13-year prospective study of the Framingham cohort. Arch Neurol. 05. 1995;52(5):485-90. [pmid: 7733843].
227 Braekhus A, Laake K, Engedal K. A low, ‘normal’ score on the Mini-Mental State Examination predicts development of dementia after three years. J Am Geriatr Soc. 06. 1995;43(6):656-61. [pmid: 7775725].
228 Schmand B, Jonker C, Hooijer C, et al. Subjective memory complaints may announce dementia. Neurology. 01. 1996;46(1):121-5. [pmid: 8559359].
229 Crystal HA, Dickson D, Sliwinski M, et al. Associations of status and change measures of neuropsychological function with pathologic changes in elderly, originally nondemented subjects. Arch Neurol. 01. 1996;53(1):82-7. [pmid: 8599564].
230 O’Rourke N, Tuokko H, Hayden S, et al. Early identification of dementia: predictive validity of the clock test. Arch Clin Neuropsychol. 1997;12(3):257-67. [pmid: 14588418].
231 Small BJ, Viitanen M, Winblad B, et al. Cognitive changes in very old persons with dementia: the influence of demographic, psychometric, and biological variables. J Clin Exp Neuropsychol. 04. 1997;19(2):245-60. [pmid: 9240484].
232 Fox NC, Warrington EK, Seiffer AL, et al. Presymptomatic cognitive deficits in individuals at risk of familial Alzheimer’s disease. A longitudinal prospective study. Brain. 09. 1998;121(Pt 9):1631-9. [pmid: 9762953].
233 Katzman R, Aronson M, Fuld P, et al. Development of dementing illnesses in an 80-year-old volunteer cohort. Ann Neurol. 04. 1989;25(4):317-24. [pmid: 2712531].
234 Fuld PA, Masur DM, Blau AD, et al. Object-memory evaluation for prospective detection of dementia in normal functioning elderly: predictive and normative data. J Clin Exp Neuropsychol. 08. 1990;12(4):520-8. [pmid: 2211974].
235 Masur DM, Fuld PA, Blau AD, et al. Predicting development of dementia in the elderly with the Selective Reminding Test. J Clin Exp Neuropsychol. 08. 1990;12(4):529-38. [pmid: 2211975].
236 Tuokko H, Vernon-Wilkinson R, Weir J, et al. Cued recall and early identification of dementia. J Clin Exp Neuropsychol. 11. 1991;13(6):871-9. [pmid: 1779027].
237 Flicker C, Ferris SH, Reisberg B. Mild cognitive impairment in the elderly: predictors of dementia. Neurology. 07. 1991;41(7):1006-9. [pmid: 2067629].
238 Flicker C, Ferris SH, Reisberg B. A longitudinal study of cognitive function in elderly persons with subjective memory complaints. J Am Geriatr Soc. 10. 1993;41(10):1029-32. [pmid: 8409146].
239 Kivipelto M, Rovio S, Ngandu T, et al. Apolipoprotein E epsilon4 magnifies lifestyle risks for dementia: a population-based study. J Cell Mol Med. 12. 2008;12(6B):2762-71. [pmid: 18318693].
240 Taaffe DR, Irie F, Masaki KH, et al. Physical activity, physical function, and incident dementia in elderly men: the Honolulu-Asia Aging Study. J Gerontol A Biol Sci Med Sci. 05. 2008;63(5):529-35. [pmid: 18511759].
241 Rovio S, Kareholt I, Viitanen M, et al. Work-related physical activity and the risk of dementia and Alzheimer’s disease. Int J Geriatr Psychiatry. 09. 2007;22(9):874-82. [pmid: 17721898].
242 Larson EB, Wang L, Bowen JD, et al. Exercise is associated with reduced risk for incident dementia among persons 65 years of age and older. Ann Intern Med. 01. 17. 2006;144(2):73-81. [pmid: 16418406].
243 Simons LA, Simons J, McCallum J, et al. Lifestyle factors and risk of dementia: Dubbo Study of the elderly. Med J Aust. 01. 16. 2006;184(2):68-70. [pmid: 16411871].
244 Podewils LJ, Guallar E, Kuller LH, et al. Physical activity, APOE genotype, and dementia risk: findings from the Cardiovascular Health Cognition Study. Am J Epidemiol. 04. 1. 2005;161(7):639-51. [pmid: 15781953].
245 Singh-Manoux A, Hillsdon M, Brunner E, et al. Effects of physical activity on cognitive functioning in middle age: evidence from the Whitehall II prospective cohort study. Am J Public Health. 12. 2005;95(12):2252-8. [pmid: 16304136].
246 Abbott RD, White LR, Ross GW, et al. Walking and dementia in physically capable elderly men. Jama. 09. 22. 2004;292(12):1447-53. [pmid: 15383515].
247 Weuve J, Kang JH, Manson JE, et al. Physical activity, including walking, and cognitive function in older women. Jama. 09. 22. 2004;292(12):1454-61. [pmid: 15383516].
248 Reitz C, den Heijer T, van Duijn C, et al. Relation between smoking and risk of dementia and Alzheimer disease: the Rotterdam Study. Neurology. 09. 4. 2007;69(10):998-1005. [pmid: 17785668].
249 Tyas SL, White LR, Petrovitch H, et al. Mid-life smoking and late-life dementia: the Honolulu-Asia Aging Study. Neurobiol Aging. 07–08. 2003;24(4):589-96. [pmid: 12714116].
250 Ott A, Slooter AJ, Hofman A, et al. Smoking and risk of dementia and Alzheimer’s disease in a population-based cohort study: the Rotterdam Study. Lancet. 06. 20. 1998;351(9119):1840-3. [pmid: 9652667].
251 Ngandu T, Helkala EL, Soininen H, et al. Alcohol drinking and cognitive functions: findings from the Cardiovascular Risk Factors Aging and Dementia (CAIDE) Study. Dement Geriatr Cogn Disord. 2007;23(3):140-9. [pmid: 17170526].
252 Dai Q, Borenstein AR, Wu Y, et al. Fruit and vegetable juices and Alzheimer’s disease: the Kame Project. Am J Med. 09. 2006;119(9):751-9. [pmid: 16945610].
253 Ganguli M, Vander Bilt J, Saxton JA, et al. Alcohol consumption and cognitive function in late life: a longitudinal community study. Neurology. 10. 25. 2005;65(8):1210-7. [pmid: 16247047].
254 Anttila T, Helkala EL, Viitanen M, et al. Alcohol drinking in middle age and subsequent risk of mild cognitive impairment and dementia in old age: a prospective population based study. Bmj. 09. 4. 2004;329(7465):539. [pmid: 15304383].
255 Luchsinger JA, Tang MX, Siddiqui M, et al. Alcohol intake and risk of dementia. J Am Geriatr Soc. 04. 2004;52(4):540-6. [pmid: 15066068].
256 Elias PK, Elias MF, D’Agostino RB, et al. Alcohol consumption and cognitive performance in the Framingham Heart Study. Am J Epidemiol. 09. 15. 1999;150(6):580-9. [pmid: 10489997].
257 Whitmer RA, Gunderson EP, Quesenberry CP Jr, et al. Body mass index in midlife and risk of Alzheimer disease and vascular dementia. Curr Alzheimer Res. 04. 2007;4(2):103-9. [pmid: 17430231].
258 Elias MF, Elias PK, Sullivan LM, et al. Obesity, diabetes and cognitive deficit: The Framingham Heart Study. Neurobiol Aging. 12. 2005;26(Suppl 1):11-6. [pmid: 16223549].
259 Kivipelto M, Ngandu T, Fratiglioni L, et al. Obesity and vascular risk factors at midlife and the risk of dementia and Alzheimer disease. Arch Neurol. 10. 2005;62(10):1556-60. [pmid: 16216938].
260 Rosengren A, Skoog I, Gustafson D, et al. Body mass index, other cardiovascular risk factors, and hospitalization for dementia. Arch Intern Med. 02. 14. 2005;165(3):321-6. [pmid: 15710796].
261 Gustafson D, Rothenberg E, Blennow K, et al. An 18-year follow-up of overweight and risk of Alzheimer disease. Arch Intern Med. 07. 14. 2003;163(13):1524-8. [pmid: 12860573].
262 Yamada M, Kasagi F, Sasaki H, et al. Association between dementia and midlife risk factors: the Radiation Effects Research Foundation Adult Health Study. J Am Geriatr Soc. 03. 2003;51(3):410-4. [pmid: 12588587].
263 Eskelinen MH, Ngandu T, Helkala EL, et al. Fat intake at midlife and cognitive impairment later in life: a population-based CAIDE study. Int J Geriatr Psychiatry. 07. 2008;23(7):741-7. [pmid: 18188871].
264 Ravaglia G, Forti P, Lucicesare A, et al. Plasma tocopherols and risk of cognitive impairment in an elderly Italian cohort. Am J Clin Nutr. 05. 2008;87(5):1306-13. [pmid: 18469254].
265 Laitinen MH, Ngandu T, Rovio S, et al. Fat intake at midlife and risk of dementia and Alzheimer’s disease: a population-based study. Dement Geriatr Cogn Disord. 2006;22(1):99-107. [pmid: 16710090].
266 Morris MC, Evans DA, Tangney CC, et al. Associations of vegetable and fruit consumption with age-related cognitive change. Neurology. 10. 24. 2006;67(8):1370-6. [pmid: 17060562].
267 Huang TL, Zandi PP, Tucker KL, et al. Benefits of fatty fish on dementia risk are stronger for those without APOE epsilon4. Neurology. 11. 8. 2005;65(9):1409-14. [pmid: 16275829].
268 Morris MC, Evans DA, Tangney CC, et al. Fish consumption and cognitive decline with age in a large community study. Archives of Neurology. 12. 2005;62(12):1849-53. [pmid: 16216930].
269 Ravaglia G, Forti P, Maioli F, et al. Homocysteine and folate as risk factors for dementia and Alzheimer disease. Am J Clin Nutr. 09. 2005;82(3):636-43. [pmid: 16155278].
270 Laurin D, Masaki KH, Foley DJ, et al. Midlife dietary intake of antioxidants and risk of late-life incident dementia: the Honolulu-Asia Aging Study.[see comment]. American Journal of Epidemiology. 05. 15. 2004;159(10):959-67. [pmid: 15128608].
271 Morris MC, Evans DA, Bienias JL, et al. Dietary niacin and the risk of incident Alzheimer’s disease and of cognitive decline. J Neurol Neurosurg Psychiatry. 08. 2004;75(8):1093-9. [pmid: 15258207].
272 Grodstein F, Chen J, Willett WC. High-dose antioxidant supplements and cognitive function in community-dwelling elderly women. Am J Clin Nutr. 04. 2003;77(4):975-84. [pmid: 12663300].
273 Luchsinger JA, Tang MX, Shea S, et al. Antioxidant vitamin intake and risk of Alzheimer disease. Arch Neurol. 02. 2003;60(2):203-8. [pmid: 12580704].
274 Engelhart MJ, Geerlings MI, Ruitenberg A, et al. Dietary intake of antioxidants and risk of Alzheimer disease. Jama. 06. 26. 2002;287(24):3223-9. [pmid: 12076218].
275 Maxwell CJ, Hogan DB, Ebly EM. Serum folate levels and subsequent adverse cerebrovascular outcomes in elderly persons. Dement Geriatr Cogn Disord. 2002;13(4):225-34. [pmid: 12006733].
276 Tuokko H, Frerichs RJ. Cognitive impairment with no dementia (CIND): longitudinal studies, the findings, and the issues. Clin Neuropsychol. 11. 2000;14(4):504-25. [pmid: 11262720].
277 O’Connor DW, Pollitt PA, Hyde JB, et al. A follow-up study of dementia diagnosed in the community using the Cambridge Mental Disorders of the Elderly Examination. Acta Psychiatr Scand. 01. 1990;81(1):78-82. [pmid: 2330834].
278 Petersen RC, Smith GE, Ivnik RJ, et al. Apolipoprotein E status as a predictor of the development of Alzheimer’s disease in memory-impaired individuals. Jama. 04. 26. 1995;273(16):1274-8. [pmid: 7646655].
279 Tierney MC, Szalai JP, Snow WG, et al. Prediction of probable Alzheimer’s disease in memory-impaired patients: A prospective longitudinal study. Neurology. 03. 1996;46(3):661-5. [pmid: 8618663].
280 Johansson B, Zarit SH. Early cognitive markers of the incidence of dementia and mortality: a longitudinal population-based study of the oldest old. Int J Geriatr Psychiatry. 01. 1997;12(1):53-9. [pmid: 9050424].
281 Johnson KA, Jones K, Holman BL, et al. Preclinical prediction of Alzheimer’s disease using SPECT. Neurology. 06. 1998;50(6):1563-71. [pmid: 9633695].
282 Devanand DP, Folz M, Gorlyn M, et al. Questionable dementia: clinical course and predictors of outcome. J Am Geriatr Soc. 03. 1997;45(3):321-8. [pmid: 9063278].
283 Jack CR Jr, Petersen RC, Xu YC, et al. Prediction of AD with MRI-based hippocampal volume in mild cognitive impairment. Neurology. 04. 22. 1999;52(7):1397-403. [pmid: 10227624].
284 Herlitz A, Small BJ, Fratiglioni L, et al. Detection of mild dementia in community surveys. Is it possible to increase the accuracy of our diagnostic instruments?. Arch Neurol. 03. 1997;54(3):319-24. [pmid: 9074402].
285 Christensen H, Henderson AS, Korten AE, et al. ICD-10 mild cognitive disorder: its outcome three years later. Int J Geriatr Psychiatry. 05. 1997;12(5):581-6. [pmid: 9193969].
286 Clarke D, Morgan K, Lilley J, et al. Dementia and ‘borderline dementia’ in Britain: 8-year incidence and post-screening outcomes. Psychol Med. 07. 1996;26(4):829-35. [pmid: 8817718].
287 Bowen J, Teri L, Kukull W, et al. Progression to dementia in patients with isolated memory loss. Lancet. 03. 15. 1997;349(9054):763-5. [pmid: 9074575].
288 Rubin EH, Morris JC, Grant EA, et al. Very mild senile dementia of the Alzheimer type. I. Clinical assessment. Arch Neurol. 04. 1989;46(4):379-82. [pmid: 2650663].
289 Aggarwal NT, Wilson RS, Beck TL, et al. Mild cognitive impairment in different functional domains and incident Alzheimer’s disease. J Neurol Neurosurg Psychiatry. 11. 2005;76(11):1479-84. [pmid: 16227534].
290 Petersen RC, Smith GE, Tangalos EG, et al. Longitudinal outcome of patients with a mild cognitive impairment. Annals of Neurology. 1993;34:294-5.
291 Hanninen T, Hallikainen M, Koivisto K, et al. A follow-up study of age-associated memory impairment: neuropsychological predictors of dementia. J Am Geriatr Soc. 09. 1995;43(9):1007-15. [pmid: 7657916].
292 Tierney MC, Szalai JP, Snow WG, et al. The prediction of Alzheimer disease. The role of patient and informant perceptions of cognitive deficits. Arch Neurol. 05. 1996;53(5):423-7. [pmid: 8624217].
293 Tierney MC, Szalai JP, Snow WG, et al. A prospective study of the clinical utility of ApoE genotype in the prediction of outcome in patients with memory impairment. Neurology. 01. 1996;46(1):149-54. [pmid: 8559365].
294 Mor V, Wilcox V, Rakowski W, et al. Functional transitions among the elderly: patterns, predictors, and related hospital use. Am J Public Health. 08. 1994;84(8):1274-80. [pmid: 8059885].
295 Grant MD, Piotrowski ZH, Chappell R. Self-reported health and survival in the Longitudinal Study of Aging, 1984–1986. Journal of Clinical Epidemiology. 03. 1995;48(3):375-87. [pmid: 7897459].
296 Wolinsky FD, Johnson RL, Stump TE. The risk of mortality among older adults over an eight-year period. Gerontologist. 04. 1995;35(2):150-61. [pmid: 7750771].
297 Steinbach U. Social networks, institutionalization, and mortality among elderly people in the United States. J Gerontol. 07. 1992;47(4):S183-90. [pmid: 1624713].
298 Goodlin S, Boult C, Bubolz T, et al. Who will need long-term care? Creation and validation of an instrument that identifies older people at risk. Dis Manag. Winter. 2004;7(4):267-74. [pmid: 15671784].
299 Miller ME, Longino CF Jr, Anderson RT, et al. Functional status, assistance, and the risk of a community-based move. Gerontologist. 04. 1999;39(2):187-200. [pmid: 10224715].
300 Wolinsky FD, Callahan CM, Fitzgerald JF, et al. The risk of nursing home placement and subsequent death among older adults. J Gerontol. 07. 1992;47(4):S173-82. [pmid: 1624712].
301 Coward RT, Netzer JK, Mullens RA. Residential differences in the incidence of nursing home admissions across a six-year period. J Gerontol B Psychol Sci Soc Sci. 09. 1996;51(5):S258-67. [pmid: 8809011].
302 Kersting RC. Impact of social support, diversity, and poverty on nursing home utilization in a nationally representative sample of older Americans. Soc Work Health Care. 2001;33(2):67-87. [pmid: 11760116].
303 Speare A Jr, Avery R, Lawton L. Disability, residential mobility, and changes in living arrangements. J Gerontol. 05. 1991;46(3):S133-42. [pmid: 2030283].
304 Kersting RC. Predictors of nursing home admission for older black Americans. Journal of Gerontological Social Work. 2001;35(3):33-50.
305 Belgrave LL, Bradsher JE. Health as a factor in institutionalization. Research on Aging. 1994;16(2):115-41.
306 Boult C, Dowd B, McCaffrey D, et al. Screening elders for risk of hospital admission. J Am Geriatr Soc. 08. 1993;41(8):811-7. [pmid: 8340558].
307 Stearns SC, Kovar MG, Hayes K, et al. Risk indicators for hospitalization during the last year of life. Health Serv Res. 04. 1996;31(1):49-69. [pmid: 8617609].
308 Laditka JN. Hazards of hospitalization for ambulatory care sensitive conditions among older women: evidence of greater risks for African Americans and Hispanics. Med Care Res Rev. 12. 2003;60(4:):468-95. discussion 96–508. [pmid: 14677221].
309 Wolinsky FD, Stump TE, Johnson RJ. Hospital utilization profiles among older adults over time: consistency and volume among survivors and decedents. J Gerontol B Psychol Sci Soc Sci. 03. 1995;50(2):S88-100. [pmid: 7757844].
310 Aliyu MH, Adediran AS, Obisesan TO. Predictors of hospital admissions in the elderly: analysis of data from the Longitudinal Study on Aging. J Natl Med Assoc. 12. 2003;95(12):1158-67. [pmid: 14717472].
311 Wolinsky FD, Culler SD, Callahan CM, et al. Hospital resource consumption among older adults: a prospective analysis of episodes, length of stay, and charges over a seven-year period. J Gerontol. 09. 1994;49(5):S240-52. [pmid: 8056953].
312 Dewey ME, Saz P. Dementia, cognitive impairment and mortality in persons aged 65 and over living in the community: a systematic review of the literature. Int J Geriatr Psychiatry. 08. 2001;16(8):751-61. [pmid: 11536341].
313 Ostbye T, Hill G, Steenhuis R. Mortality in elderly Canadians with and without dementia: a 5-year follow-up. Neurology. 08. 11. 1999;53(3):521-6. [pmid: 10449114].
314 Saz P, Launer LJ, Dia JL, et al. Mortality and mental disorders in a Spanish elderly population. Int J Geriatr Psychiatry. 12. 1999;14(12):1031-8. [pmid: 10607970].
315 Jagger C, Clarke M, Stone A. Predictors of survival with Alzheimer’s disease: a community-based study. Psychol Med. 01. 1995;25(1):171-7. [pmid: 7792352].
316 Liu CK, Lai CL, Tai CT, et al. Incidence and subtypes of dementia in southern Taiwan: impact of socio-demographic factors. Neurology. 06. 1998;50(6):1572-9. [pmid: 9633696].
317 Foley DJ, Monjan AA, Masaki KH, et al. Associations of symptoms of sleep apnea with cardiovascular disease, cognitive impairment, and mortality among older Japanese-American men. Journal of the American Geriatrics Society. 05. 1999;47(5):524-8. [pmid: 10323643].
318 Gale CR, Martyn CN, Cooper C. Cognitive impairment and mortality in a cohort of elderly people. Bmj. 03. 9. 1996;312(7031):608-11. [pmid: 8595334].
319 Ho SC. Health and social predictors of mortality in an elderly Chinese cohort. Am J Epidemiol. 05. 1. 1991;133(9):907-21. [pmid: 2028980].
320 Eagles JM, Beattie JA, Restall DB, et al. Relation between cognitive impairment and early death in the elderly. BMJ. 01. 27. 1990;300(6719):239-40. [pmid: 2106935].
321 Shapiro E, Tate RB. The impact of a mental status score and a dementia diagnosis on mortality and institutionalization. J Aging Health. 1991;3:28-46.
322 Salive ME, Satterfield S, Ostfeld AM, et al. Disability and cognitive impairment are risk factors for pneumonia-related mortality in older adults. Public Health Rep. 05–06. 1993;108(3):314-22. [pmid: 8497569].
323 Liang J, Borawski-Clark E, Liu X, et al. Transitions in cognitive status among the aged in Japan. Soc Sci Med. 08. 1996;43(3):325-37. [pmid: 8844935].
324 Gussekloo J, Westendorp RG, Remarque EJ, et al. Impact of mild cognitive impairment on survival in very elderly people: cohort study. Bmj. 10. 25. 1997;315(7115):1053-4. [pmid: 9366730].
325 Arve S, Lehtonen A, Tilvis RS. Prognosis of depression with and without dementia in old age. Arch Gerontol Geriatr. 09–10. 1998;27(2):141-6. [pmid: 18653158].
326 Korten AE, Jorm AF, Jiao Z, et al. Health, cognitive, and psychosocial factors as predictors of mortality in an elderly community sample. J Epidemiol Community Health. 02. 1999;53(2):83-8. [pmid: 10396468].
327 Fredman L, Magaziner J, Hebel JR, et al. Depressive symptoms and 6-year mortality among elderly community-dwelling women. Epidemiology. 01. 1999;10(1):54-9. [pmid: 9888280].
328 Nakanishi N, Tatara K, Ikeda K, et al. Relation between intellectual dysfunctioning and mortality in community-residing older people. J Am Geriatr Soc. 05. 1998;46(5):583-9. [pmid: 9588371].
329 Swan GE, Carmelli D, LaRue A. Performance on the digit symbol substitution test and 5-year mortality in the Western Collaborative Group Study. Am J Epidemiol. 01. 1. 1995;141(1):32-40. [pmid: 7801963].
330 Li G, Shen YC, Chen CH, et al. A three-year follow-up study of age-related dementia in an urban area of Beijing. Acta Psychiatrica Scandinavica. 02. 1991;83(2):99-104. [pmid: 2017918].
331 Jorm AF, Henderson AS, Kay DWK, et al. Mortality in relation to dementia, depression ad social integration in an elderly community sample. Int J Geriatr Psychiatry. 1991;6:5-11.
332 Aronson MK, Ooi WL, Geva DL, et al. Dementia. Age-dependent incidence, prevalence, and mortality in the old old. Arch Intern Med. 05. 1991;151(5):989-92. [pmid: 2025148].
333 Evans DA, Smith LA, Scherr PA, et al. Risk of death from Alzheimer’s disease in a community population of older persons. Am J Epidemiol. 08. 15. 1991;134(4):403-12. [pmid: 1877601].
334 Heeren TJ, van Hemert AM, Rooymans HG. A community-based study of survival in dementia. Acta Psychiatr Scand. 06. 1992;85(6):415-8. [pmid: 1642121].
335 Skoog I, Nilsson L, Palmertz B, et al. A population-based study of dementia in 85-year-olds. N Engl J Med. 01. 21. 1993;328(3):153-8. [pmid: 8417380].
336 Aevarsson O, Svanborg A, Skoog I. Seven-year survival rate after age 85 years: relation to Alzheimer disease and vascular dementia. Arch Neurol. 09. 1998;55(9):1226-32. [pmid: 9740117].
337 Snowdon J, Lane F. The Botany survey: A longitudinal study of depression and cognitive impairment in an elderly population. Int J Geriatr Psychiatry. 1995;10:349-58.
338 Hill GB, Forbes WF, Lindsay J, et al. Mortality and cognitive status among elderly Canadians living in the community and in institutions: the Canadian Study of Health and Aging. Can J Public Health. 09–10. 1997;88(5):303-4. [pmid: 9401162].
339 Ostbye T, Steenhuis R, Wolfson C, et al. Predictors of five-year mortality in older Canadians: the Canadian Study of Health and Aging. J Am Geriatr Soc. 10. 1999;47(10):1249-54. [pmid: 10522960].
340 Katzman R, Hill LR, Yu ES, et al. The malignancy of dementia. Predictors of mortality in clinically diagnosed dementia in a population survey of Shanghai, China. Arch Neurol. 12. 1994;51(12):1220-5. [pmid: 7986177].
341 Juva K, Sulkava R, Erkinjuntti T, et al. The prognosis of demented patients: One-year follow-up study of a population sample. Int J Geriatr Psychiatry. 1994;9:537-41.
342 Meller I, Fichter MM, Schroppel H. Mortality risk in the octo- and nonagenerians: longitudinal results of an epidemiological follow-up community study. Eur Arch Psychiatry Clin Neurosci. 1999;249(4):180-9. [pmid: 10449593].
343 Bonaiuto S, Mele M, Galluzzo L, et al. Survival and dementia: a 7-year follow-up of an Italian elderly population. Arch Gerontol Geriatr. 01–02. 1995;20(1):105-13. [pmid: 15374264].
344 Baldereschi M, Di Carlo A, Maggi S, et al. Dementia is a major predictor of death among the Italian elderly. ILSA Working Group. Italian Longitudinal Study on Aging. Neurology. 03. 10. 1999;52(4):709-13. [pmid: 10078714].
345 Tsuji I, Minami Y, Li JH, et al. Dementia and physical disability as competing risks for mortality in a community-based sample of the elderly Japanese. Tohoku J Exp Med. 06. 1995;176(2):99-107. [pmid: 7482527].
346 Asada T, Yamagata Z, Kinoshita T, et al. Prevalence of dementia and distribution of ApoE alleles in Japanese centenarians: an almost-complete survey in Yamanashi Prefecture, Japan. J Am Geriatr Soc. 02. 1996;44(2):151-5. [pmid: 8576504].
347 Engedal K. Mortality in the elderly - a 3-year follow-up of an elderly community sample. Int J Geriatr Psychiatry. 1996;11:467-71.
348 Aguero-Torres H, Fratiglioni L, Winblad B. Natural history of Alzheimer’s disease and other dementias: review of the literature in the light of the findings from the Kungsholmen Project. Int J Geriatr Psychiatry. 11. 1998;13(11):755-66. [pmid: 9850872].
349 Johansson B, Zarit SH. Prevalence and incidence of dementia in the oldest old: A longitudinal study of a population-based sample of 84–90-year-olds in Sweden. Int J Geriatr Psychiatry. 1995;10:359-66.
350 Gurland BJ, Wilder DE, Lantigua R, et al. Rates of dementia in three ethnoracial groups. Int J Geriatr Psychiatry. 06. 1999;14(6):481-93. [pmid: 10398359].
351 Albert SM, Costa R, Merchant C, et al. Hospitalization and Alzheimer’s disease: results from a community-based study. J Gerontol A Biol Sci Med Sci. 05. 1999;54(5):M267-71. [pmid: 10362011].
352 Banaszak-Holl J, Fendrick AM, Foster NL, et al. Predicting nursing home admission: estimates from a 7-year follow-up of a nationally representative sample of older Americans. Alzheimer Dis Assoc Disord. 04–06. 2004;18(2):83-9. [pmid: 15249852].
353 Dukers DF, Vermeer MH, Jaspars LH, et al. Expression of killer cell inhibitory receptors is restricted to true NK cell lymphomas and a subset of intestinal enteropathy-type T cell lymphomas with a cytotoxic phenotype. J Clin Pathol. 03. 2001;54(3):224-8. [pmid: 11253136].
354 Hastings SN, Purser JL, Johnson KS, et al. Frailty predicts some but not all adverse outcomes in older adults discharged from the emergency department. J Am Geriatr Soc. 09. 2008;56(9):1651-7. [pmid: 18691282].
355 Harris T, Kovar MG, Suzman R, et al. Longitudinal study of physical ability in the oldest-old. Am J Public Health. 06. 1989;79(6):698-702. [pmid: 2729466].
356 Wolinsky FD, Johnson RJ. The use of health services by older adults. J Gerontol. 11. 1991;46(6):S345-57. [pmid: 1940101].
357 Wolinsky FD, Callahan CM, Fitzgerald JF, et al. Changes in functional status and the risks of subsequent nursing home placement and death. J Gerontol. 05. 1993;48(3):S94-101. [pmid: 8482831].
358 Anderson RT, James MK, Miller ME, et al. The timing of change: patterns in transitions in functional status among elderly persons. J Gerontol B Psychol Sci Soc Sci. 01. 1998;53(1):S17-27. [pmid: 9469176].
359 Naeim A, Keeler EB, Reuben D. Perceived causes of disability added prognostic value beyond medical conditions and functional status. J Clin Epidemiol. 01. 2007;60(1):79-85. [pmid: 17161758].
360 Grabowski DC, Ellis JE. High body mass index does not predict mortality in older people: analysis of the Longitudinal Study of Aging. J Am Geriatr Soc. 07. 2001;49(7):968-79. [pmid: 11527490].
361 Rakowski W, Hickey T. Mortality and the attribution of health problems to aging among older adults. Am J Public Health. 08. 1992;82(8):1139-41. [pmid: 1636837].
362 Ravaglia G, Forti P, Lucicesare A, et al. Development of an easy prognostic score for frailty outcomes in the aged. Age Ageing. 03. 2008;37(2):161-6. [pmid: 18238805].
363 Pilotto A, Ferrucci L, Franceschi M, et al. Development and validation of a multidimensional prognostic index for one-year mortality from comprehensive geriatric assessment in hospitalized older patients. Rejuvenation Res. 02. 2008;11(1):151-61. [pmid: 18173367].
364 Song X, Mitnitski A, MacKnight C, et al. Assessment of individual risk of death using self-report data: an artificial neural network compared with a frailty index. J Am Geriatr Soc. 07. 2004;52(7):1180-4. [pmid: 15209659].
365 Albertsson DM, Mellstrom D, Petersson C, et al. Validation of a 4-item score predicting hip fracture and mortality risk among elderly women. Ann Fam Med. 01–02. 2007;5(1):48-56. [pmid: 17261864].
366 Schonberg MA, Davis RB, McCarthy EP, et al. Index to predict 5-year mortality of community-dwelling adults aged 65 and older using data from the national health interview survey. J Gen Intern Med. 10. 2009;24(10):1115-22. [pmid: 19649678].
367 Garcia-Gonzalez JJ, Garcia-Pena C, Franco-Marina F, et al. A frailty index to predict the mortality risk in a population of senior mexican adults. BMC Geriatr. 2009;9:47. [pmid: 19887005].
368 Carey EC, Walter LC, Lindquist K, et al. Development and validation of a functional morbidity index to predict mortality in community-dwelling elders. J Gen Intern Med. 10. 2004;19(10):1027-33. [pmid: 15482555].
369 Levine SK, Sachs GA, Jin L, et al. A prognostic model for 1-year mortality in older adults after hospital discharge. Am J Med. 05. 2007;120(5):455-60. [pmid: 17466658].
370 Pijpers E, Ferreira I, van de Laar RJ, et al. Predicting mortality of psychogeriatric patients: a simple prognostic frailty risk score. Postgrad Med J. 09. 2009;85(1007):464-9. [pmid: 19734513].
371 Markides KS, Black SA, Ostir GV, et al. Lower body function and mortality in Mexican American elderly people. J Gerontol A Biol Sci Med Sci. 04. 2001;56(4):M243-7. [pmid: 11283198].
372 Gill TM, Gahbauer EA, Allore HG, et al. Transitions between frailty states among community-living older persons. Arch Intern Med. 02. 27. 2006;166(4):418-23. [pmid: 16505261].
373 Purser JL, Kuchibhatla MN, Fillenbaum GG, et al. Identifying frailty in hospitalized older adults with significant coronary artery disease. J Am Geriatr Soc. 11. 2006;54(11):1674-81. [pmid: 17087693].
374 Mitnitski AB, Graham JE, Mogilner AJ, et al. Frailty, fitness and late-life mortality in relation to chronological and biological age. BMC Geriatr. 02. 27. 2002;2:1. [pmid: 11897015].
375 Drame M, Novella JL, Lang PO, et al. Derivation and validation of a mortality-risk index from a cohort of frail elderly patients hospitalised in medical wards via emergencies: the SAFES study. Eur J Epidemiol. 2008;23(12):783-91. [pmid: 18941907].
376 Frazier AL, Colditz GA, Fuchs CS, et al. Cost-effectiveness of screening for colorectal cancer in the general population. JAMA. 10. 18. 2000;284(15):1954-61. [pmid: 11035892].
377 Vijan S, Hwang EW, Hofer TP, et al. Which colon cancer screening test? A comparison of costs, effectiveness, and compliance. Am J Med. 12. 1. 2001;111(8):593-601. [pmid: 11755501].
378 Ness RM, Holmes AM, Klein R, et al. Cost-utility of one-time colonoscopic screening for colorectal cancer at various ages. Am J Gastroenterol. 07. 2000;95(7):1800-11. [pmid: 10925988].
379 Loeve F, Brown ML, Boer R, et al. Endoscopic colorectal cancer screening: a cost-saving analysis. J Natl Cancer Inst. 04. 5. 2000;92(7):557-63. [pmid: 10749911].
380 Song K, Fendrick AM, Ladabaum U. Fecal DNA testing compared with conventional colorectal cancer screening methods: a decision analysis. Gastroenterology. 05. 2004;126(5):1270-9. [pmid: 15131787].