# Abstraction Forms

Abstraction Form for Question 1

Abstraction Form for Question 2

Abstraction Form for Question 3