# Technical Expert Panel Members and Affiliations

TEP Member | Affiliation
Kathleen Buckwalter, PhD, RN | Gerontological Nursing Research The University of Iowa Iowa City, Iowa
Thomas Gill, MD | Department of Internal Medicine Yale School of Medicine New Haven, Connecticut
Jack Guralnik, MD, PhD | National Institute on Aging Bethesda, Maryland
Rosanne Leipzig, MD, PhD | Mount Sinai School of Medicine New York, New York
Joseph Ouslander, MD | Charles E. Schmidt College of Biomedical Science Florida Atlantic University Boca Raton, Florida
Barbara Resnick, PhD | School of Nursing University of Maryland Baltimore, Maryland
Albert L. Siu, MD, MSPH | Mount Sinai Medical Center New York, New York and James J. Peters VA Medical Center Bronx, New York
Gregg Warshaw, MD | College of Medicine University of Cincinnati Medical Center Cincinnati, Ohio