# Excluded Studies

1 Geriatric nurse practitioner role grows in newer delivery system. Natl Rep Subacute Care. 11. 6. 1996;4(23):6. Comment.
2 Medical management magnified under Medicare risk. Public Sect Contract Rep. 07. 1997;3(7):97-100. Comment.
3 Reduce risk by screening, managing frail elderly. Public Sect Contract Rep. 01. 1997;3(1):1-6. Not eligible full text can not be found.
4 Home visits by physicians improve care, reduce utilization, cut costs under Medicare risk. Public Sect Contract Rep. 05. 1998;4(5):70-4. Comment.
5 Finding frail elderly key to managing them. Manag Care Strateg. 08. 1998;6(8):88. 93. Comment. [pmid: 10185966].
6 Invest in data systems to manage your senior patients. Public Sect Contract Rep. 07. 1998;4(7):97-100. Comment.
7 Carle Clinic’s risk screening tools identify, help manage at-risk senior patients. Public Sect Contract Rep. 02. 1998;4(2):21-3. Comment.
8 Manage your high-risk seniors to avoid financial ruin. Public Sect Contract Rep. 07. 1999;5(7):97-100. Comment.
9 Roadmap teams improve care for over-65 population. Healthc Demand Dis Manag. 02. 1999;5(2):26-9. Comment. [pmid: 10346540].
10 Tool helps ID high-risk seniors, cut costs under Medicare risk. Capitation Manag Rep. 09. 2000;7(9):137-40. 29. Comment. [pmid: 11186343].
11 CEO says U.S. system faces ‘serious problems’. Health Care Strateg Manage. 07. 2000;18(7):11. Comment.
12 HCFA to field test MDS version 3; update to MDS 2.0 now in effect. Natl Rep Subacute Care. 09. 20. 3. 2000;8(19):1-4. Comment.
13 Prevention and treatment of infection. The role of nutrition in long-term care. Health Care Food Nutr Focus. 11. 2001;18(3):7-8. Not eligible target population.
14 Model for care of chronically ill blends DM and CM approaches. Clin Resour Manag. 09. 2001;2(9):129-32. Comment. [pmid: 11577510].
15 Screening tool helps identify high-risk seniors, cut costs. Clin Resour Manag. 04. 2001;2(4):53-6. 49. Comment. [pmid: 11351752].
16 Technical revisions to medical criteria for determinations of disability. Final rules. Fed Regist. 04. 24. 2002;67(79):20018-28. Not eligible outcomes. [pmid: 11973833].
17 Aetna turns to enhanced HRA process to manage risk for seniors. Dis Manag Advis. 06. 2003;9(6):90-1. 81. [pmid: 12872441].
18 Assisted living facilities. What they are and how to find one. Geriatrics. 02. 2003;58(2):56. Comment. [pmid: 12596498].
19 Social support and health-related quality of life among older adults--Missouri, 2000. MMWR Morb Mortal Wkly Rep. 05. 6. 2005;54(17):433-7. Not eligible outcomes. [pmid: 15889012].
20 Universal protocol cuts hip surgery fatalities. Healthcare Benchmarks Qual Improv. 03. 2005;12(3):30-1. Comment. [pmid: 15859107].
21 Depression in elderly populations. Nebr Nurse. 03–05. 2005;38(1):21-3. Comment.
22 McClellan says CMS will protect duals ... but others express doubts. Med Health. 03. 7. 2005;59(9):3-4. News.
23 Most Americans alarmed by impending Medicare cuts that will harm seniors’ access to care. Congressional action needed now to avert Medicare physician payment cuts. J Miss State Med Assoc. 10. 2006;47(10):311. Not eligible outcomes. [pmid: 17941236].
24 Differential mortality, uncertain medical expenditures, and the savings decisions of the elderly. Natl Bur Econ Res Bull Aging Health. Fall. 2006;(17):2-3. Comment.
25 Apache II Scores Illustrate Homeostenosis Model. Available at:http://www.ouhsc.edu/geriatricmedicine/Education/Homeostenosis/HomeostenosisApache_II_Scores_Illustrate_Home.htm. Not eligible outcomes.
26 Aalen OO. Heterogeneity in survival analysis. Stat Med. 11. 1988;7(11):1121-37. Not eligible outcomes. [pmid: 3201038].
27 Aartsen MJ, Martin M, Zimprich D. Gender differences in level and change in cognitive functioning. Results from the Longitudinal Aging Study Amsterdam. Gerontology. 01–02. 2004;50(1):35-8. Not eligible outcomes. [pmid: 14654725].
28 Abbott KC, Trespalacios FC, Taylor AJ, et al. Atrial fibrillation in chronic dialysis patients in the United States: risk factors for hospitalization and mortality. BMC Nephrol. 01. 24. 2003;4:1. Not eligible target population. [pmid: 12546711].
29 Abbott RD, Ando F, Masaki KH, et al. Dietary magnesium intake and the future risk of coronary heart disease (the Honolulu Heart Program). American Journal of Cardiology. 09. 15. 2003;92(6):665-9. Not eligible outcomes. [pmid: 12972103].
30 Abbott RD, Launer LJ, Rodriguez BL, et al. Serum estradiol and risk of stroke in elderly men. Neurology. 02. 20. 2007;68(8):563-8. Not eligible outcomes. [pmid: 17310026].
31 Abhayaratna WP, Smith WT, Becker NG, et al. Prevalence of heart failure and systolic ventricular dysfunction in older Australians: the Canberra Heart Study. Med J Aust. 02. 20. 2006;184(4):151-4. Not eligible outcomes. [pmid: 16489896].
32 Abou-Gareeb I, Lewallen S, Bassett K, et al. Gender and blindness: a meta-analysis of population-based prevalence surveys. Ophthalmic Epidemiol. 02. 2001;8(1):39-56. Not eligible outcomes. [pmid: 11262681].
33 Abraido-Lanza AF, White K, Armbrister AN, et al. Health status, activity limitations, and disability in work and housework among Latinos and non-Latinos with arthritis: an analysis of national data. Arthritis Rheum. 06. 15. 2006;55(3):442-50. Not eligible outcomes. [pmid: 16739212].
34 Abrams RC, Lachs M, McAvay G, et al. Predictors of self-neglect in community-dwelling elders. Am J Psychiatry. 10. 2002;159(10):1724-30. Not eligible outcome. [pmid: 12359679].
35 Abrutyn E, Mossey J, Levison M, et al. Epidemiology of asymptomatic bacteriuria in elderly women. J Am Geriatr Soc. 04. 1991;39(4):388-93. Not eligible outcomes. [pmid: 2010589].
36 Abuzeid WM, Ruckenstein MJ, Abuzeid WM, et al. Spirochetes in otology: are we testing for the right pathogens?. Otolaryngology - Head & Neck Surgery. 01. 2008;138(1):107-9. Outcomes. [pmid: 18165003].
37 Achat H, Kawachi I, Spiro A 3rd, et al. Optimism and depression as predictors of physical and mental health functioning: the Normative Aging Study. Annals of Behavioral Medicine. 2000;22(2):127-30. Not eligible outcomes. [pmid: 10962705].
38 Acierno R, Resnick H, Kilpatrick D, et al. Assessing elder victimization--demonstration of a methodology. Soc Psychiatry Psychiatr Epidemiol. 11. 2003;38(11):644-53. Not eligible outcomes. [pmid: 14614553].
39 Ackermann RT, Williams B, Nguyen HQ, et al. Healthcare cost differences with participation in a community-based group physical activity benefit for medicare managed care health plan members. J Am Geriatr Soc. 08. 2008;56(8):1459-65. Not eligible outcomes. [pmid: 18637982].
40 Adak S, Illouz K, Gorman W, et al. Predicting the rate of cognitive decline in aging and early Alzheimer disease. Neurology. 07. 13. 2004;63(1):108-14. Not eligible outcomes. [pmid: 15249619].
41 Adamis D, Lunn M, Martin FC, et al. Cytokines and IGF-I in delirious and non-delirious acutely ill older medical inpatients. Age & Ageing. discussion 251. 05. 2009;38(3):326-32. Not eligible target population. [pmid: 19269948].
42 Adams BD, Medeiros R, Dereska P, et al. Geriatric all-terrain vehicle trauma. Am Surg. 04. 2004;70(4):329-32. Not eligible outcomes. [pmid: 15098787].
43 Adams TD, Avelar E, Cloward T, et al. Design and rationale of the Utah obesity study. A study to assess morbidity following gastric bypass surgery. Contemporary Clinical Trials. 10. 2005;26(5):534-51. Not eligible outcomes. [pmid: 16046191].
44 Adams VH 3rd, Jackson JS. The contribution of hope to the quality of life among aging African Americans: 1980–1992. International Journal of Aging & Human Development. 2000;50(4):279-95. Not eligible outcomes. [pmid: 11087108].
45 Adams-Wendling L. Clocking care hours with workload measurement tools. Nurs Manage. 08. 2003;34(8):34-9. Not eligible outcomes. [pmid: 12888730].
46 Adelman RD, Greene MG, Friedmann E, et al. Discussion of depression in follow-up medical visits with older patients. J Am Geriatr Soc. 01. 2008;56(1):16-22. Not eligible outcomes. [pmid: 18184203].
47 Adeniran RK. Fraud and abuse--an overview. Geriatr Nurs. 03–04. 2002;23(2):111-2. Comment. [pmid: 11956525].
48 Adera T, Gaydos JC. Identifying comparison groups for evaluating occupational hearing loss: a statistical assessment of 22 industrial populations. American Journal of Industrial Medicine. 02. 1997;31(2):243-9. Not eligible outcomes. [pmid: 9028441].
49 Adler G, Silverstein NM. At-risk drivers with Alzheimer’s disease: recognition, response, and referral. Traffic Inj Prev. 08. 2008;9(4):299-303. Not eligible target population. [pmid: 18696385].
50 Aggarwal NT, Bennett DA, Bienias JL, et al. The prevalence of dizziness and its association with functional disability in a biracial community population. J Gerontol A Biol Sci Med Sci. 05. 2000;55(5):M288-92. Not eligible outcomes. [pmid: 10819319].
51 Agree EM, Freedman VA. Incorporating assistive devices into community-based long-term care: an analysis of the potential for substitution and supplementation. J Aging Health. 08. 2000;12(3):426-50. Not eligible target population. [pmid: 11067703].
52 Ahmed N, Mandel R, Fain MJ. Frailty: an emerging geriatric syndrome. Am J Med. 09. 2007;120(9):748-53. Not eligible outcomes. [pmid: 17765039].
53 Ai AL, Peterson C, Tice TN, et al. Differential effects of faith-based coping on physical and mental fatigue in middle-aged and older cardiac patients. Int J Psychiatry Med. 2006;36(3):351-65. Not eligible outcomes. [pmid: 17236702].
54 Aiello AE, Haan M, Blythe L, et al. The influence of latent viral infection on rate of cognitive decline over 4 years.[see comment]. Journal of the American Geriatrics Society. 07. 2006;54(7):1046-54. Not eligible outcomes. [pmid: 16866674].
55 Al Snih S, Fisher MN, Raji MA, et al. Diabetes mellitus and incidence of lower body disability among older Mexican Americans. J Gerontol A Biol Sci Med Sci. 09. 2005;60(9):1152-6. Not eligible outcomes. [pmid: 16183955].
56 Albert I, Jais JP. The use of frailty models in genetic studies: application to the relationship between end-stage renal failure and mutation type in Alport syndrome. European Community Alport Syndrome Concerted Action Group (ECASCA). J Epidemiol Biostat. 2000;5(3):169-75. Not eligible outcomes. [pmid: 11051113].
57 Aliotta SL, Aubert RE, Kirby HB. A managed care approach to high-risk screening and case management in the elderly. Eff Clin Pract. 10–11. 1998;1(2):93-4. Not eligible outcomes. [pmid: 10187229].
58 Allaire JC, Willis SL. Competence in everyday activities as a predictor of cognitive risk and mortality. Neuropsychol Dev Cogn B Aging Neuropsychol Cogn. 06. 2006;13(2):207-24. Not eligible outcomes. [pmid: 16807199].
59 Allison DB, Gallagher D, Heo M, et al. Body mass index and all-cause mortality among people age 70 and over: the Longitudinal Study of Aging. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 06. 1997;21(6):424-31. Not eligible exposure. [pmid: 9192224].
60 Allman RM, Damiano AM, Strauss MJ. Pressure ulcer status and post-discharge health care resource utilization among older adults with activity limitations. Adv Wound Care. 03–04. 1996;9(2):38-44. Not eligible outcomes. [pmid: 8845997].
61 Alter G. Height, frailty, and the standard of living: modelling the effects of diet and disease on declining mortality and increasing height. Popul Stud (Camb). 2004;58(3):265-79. Not eligible outcomes. [pmid: 15513283].
62 Alves de Moraes S, Szklo M, Knopman D, et al. The relationship between temporal changes in blood pressure and changes in cognitive function: atherosclerosis risk in communities (ARIC) study. Preventive medicine. 09. 2002;35(3):258-63. Not eligible outcomes. [pmid: 12202068].
63 Amador LF, Al Snih S, Markides KS, et al. Weight change and mortality among older Mexican Americans. Aging Clin Exp Res. 06. 2006;18(3):196-204. Not eligible outcomes. [pmid: 16804365].
64 Amir O, Hassan Y, Sarriff A, et al. Incidence of risk factors for developing hyperkalemia when using ACE inhibitors in cardiovascular diseases. Pharm World Sci. 06. 2009;31(3):387-93. Not eligible outcomes. [pmid: 19255869].
65 Ananth CV, Demissie K, Smulian JC, et al. Placenta previa in singleton and twin births in the United States, 1989 through 1998: a comparison of risk factor profiles and associated conditions. American Journal of Obstetrics & Gynecology. 01. 2003;188(1):275-81. Not eligible outcomes. [pmid: 12548229].
66 Andersen PK, Klein JP, Zhang MJ. Testing for centre effects in multi-centre survival studies: a Monte Carlo comparison of fixed and random effects tests. Stat Med. 06. 30. 1999;18(12):1489-500. Not eligible outcomes. [pmid: 10398287].
67 Anderson AA. Getting a grip on depression. Provider. 01. 2001;27(1):37-8. Not eligible outcomes. [pmid: 11191267].
68 Andres L. Motor vehicle crashes among the elderly: advocates cite the need for mandatory retesting of elderly drivers. J Emerg Nurs. 10. 2004;30(5):509-11. Not eligible outcomes. [pmid: 15452542].
69 Andresen EM, Bowley N, Rothenberg BM, et al. Test-retest performance of a mailed version of the Medical Outcomes Study 36–Item Short-Form Health Survey among older adults. Med Care. 12. 1996;34(12):1165-70. Not eligible outcomes. [pmid: 8962582].
70 Andrew MK, Mitnitski AB, Rockwood K. Social vulnerability, frailty and mortality in elderly people. PLoS One. 2008;3(5):e2232. Not eligible outcomes. [pmid: 18493324].
71 Angel JL, De Jong GF, Cornwell GT, et al. Diminished Health and Living Arrangements of Rural Elderly Americans. National Journal of Sociology. 1995;9(1):31-57. Not eligible outcomes.
72 Annaloro C, Usardi P, Airaghi L, et al. Prevalence of metabolic syndrome in long-term survivors of hematopoietic stem cell transplantation. Bone marrow transplantation. 05. 2008;41(9):797-804. Not eligible outcomes. [pmid: 18195686].
73 Asthma emerges as significant problem for elderly. Clin Resour Manag. 11. 2001;2(11):170-3. 61. Not eligible outcomes. [pmid: 11727451].
74 Summaries for patients. Cognitive impairment without dementia in older adults. [original report in Ann Intern Med. 2008 Mar 18;148(6):427–34. PMID: 18347351]. Annals of internal medicine. 03. 18. 2008;148(6):I-53. Not eligible outcomes.
75 Appelt CJ, Burant CJ, Siminoff LA, et al. Arthritis-specific health beliefs related to aging among older male patients with knee and/or hip osteoarthritis. J Gerontol A Biol Sci Med Sci. 02. 2007;62(2):184-90. Not eligible outcomes. [pmid: 17339644].
76 Appleby C. Clinical paths. Prevention is the best medicine. Hosp Health Netw. 08. 20. 1996;70(16):40. Comment.
77 Arai Y, Takayama M, Gondo Y, et al. Adipose endocrine function, insulin-like growth factor-1 axis, and exceptional survival beyond 100 years of age. J Gerontol A Biol Sci Med Sci. 11. 2008;63(11):1209-18. Not eligible outcomes. [pmid: 19038836].
78 Araujo AB, O’Donnell AB, Brambilla DJ, et al. Prevalence and incidence of androgen deficiency in middle-aged and older men: estimates from the Massachusetts Male Aging Study.[see comment]. Journal of Clinical Endocrinology & Metabolism. 12. 2004;89(12):5920-6. Not eligible outcomes. [pmid: 15579737].
79 Arbeev KG, Akushevich I, Kulminski AM, et al. Genetic model for longitudinal studies of aging, health, and longevity and its potential application to incomplete data. Journal of Theoretical Biology. 2009;258(1):103-11. Simulation study. [pmid: 19490866].
80 Arfken CL, Lichtenberg PA, Tancer ME. Cognitive impairment and depression predict mortality in medically ill older adults. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 03. 1999;54(3):M152-6. Not eligible population.
81 Argekar P, Griffin V, Litaker D, et al. Sleep apnea in hemodialysis patients: risk factors and effect on survival. Hemodialysis International. 10. 2007;11(4):435-41. Not eligible outcomes. [pmid: 17922741].
82 Arnold AM, Psaty BM, Kuller LH, et al. Incidence of cardiovascular disease in older Americans: the cardiovascular health study. J Am Geriatr Soc. 02. 2005;53(2):211-8. Not eligible outcomes. [pmid: 15673343].
83 Arnow BA, Hunkeler EM, Blasey CM, et al. Comorbid depression, chronic pain, and disability in primary care. Psychosom Med. 03–04. 2006;68(2):262-8. Not eligible outcomes. [pmid: 16554392].
84 Arora VM, Georgitis E, Woodruff JN, et al. Improving sleep hygiene of medical interns: can the sleep, alertness, and fatigue education in residency program help?[see comment]. Archives of Internal Medicine. 09. 10. 2007;167(16):1738-44. Not eligible outcomes. [pmid: 17846392].
85 Arsenault LN, Matthan N, Scott TM, et al. Validity of estimated dietary eicosapentaenoic acid and docosahexaenoic acid intakes determined by interviewer-administered food frequency questionnaire among older adults with mild-to-moderate cognitive impairment or dementia. American Journal of Epidemiology. 07. 1. 2009;170(1):95-103. Not eligible outcomes. [pmid: 19433614].
86 Arzt M, Young T, Finn L, et al. Association of sleep-disordered breathing and the occurrence of stroke. American Journal of Respiratory & Critical Care Medicine. 12. 1. 2005;172(11):1447-51. Not eligible outcomes. [pmid: 16141444].
87 Arzt M, Young T, Finn L, et al. Sleepiness and sleep in patients with both systolic heart failure and obstructive sleep apnea.[see comment]. Archives of Internal Medicine. 09. 18. 2006;166(16):1716-22. Not eligible outcomes. [pmid: 16983049].
88 Aschwanden C, Aschwanden C. Taking the long view. Science of Aging Knowledge Environment. 06. 30. 2004;2004(26):ns3. Not eligible outcomes. [pmid: 15229346].
89 Asghar M, Adhiyaman V, Greenway MW, et al. Chronic subdural haematoma in the elderly--a North Wales experience. J R Soc Med. 06. 2002;95(6):290-2. Not eligible outcomes. [pmid: 12042376].
90 Ashford JW, Kumar V, Barringer M, et al. Assessing Alzheimer severity with a global clinical scale. Int Psychogeriatr. Summer. 1992;4(1):55-74. Not eligible outcomes. [pmid: 1391672].
91 Astone NM, Ensminger M, Juon HS, et al. Early adult characteristics and mortality among inner-city African American women. American Journal of Public Health. 04. 2002;92(4):640-5. Not eligible outcomes. [pmid: 11919065].
92 Astrand B, Astrand E, Antonov K, et al. Detection of potential drug interactions - a model for a national pharmacy register. Eur J Clin Pharmacol. 09. 2006;62(9):749-56. Not eligible outcomes. [pmid: 16896788].
93 Astrand E, Astrand B, Antonov K, et al. Potential drug interactions during a three-decade study period: a cross-sectional study of a prescription register. Eur J Clin Pharmacol. 09. 2007;63(9):851-9. Not eligible outcomes. [pmid: 17598096].
94 Atchison KA, Andersen RM. Demonstrating successful aging using the International Collaborative Study for Oral Health Outcomes. Journal of Public Health Dentistry. 2000;60(4):282-8. Not eligible exposure. [pmid: 11243048].
95 Aud MA, Rantz MJ. Admissions to skilled nursing facilities from assisted living facilities. J Nurs Care Qual. 01–03. 2005;20(1):16-25. Not eligible outcomes. [pmid: 15686073].
96 Aung K, Burnett J, Smith SM, et al. Vitamin D deficiency associated with self-neglect in the elderly. J Elder Abuse Negl. 2006;18(4):63-78. Not eligible outcomes. [pmid: 17972660].
97 Avidan AY, Fries BE, James ML, et al. Insomnia and hypnotic use, recorded in the minimum data set, as predictors of falls and hip fractures in Michigan nursing homes.[see comment]. Journal of the American Geriatrics Society. 06. 2005;53(6):955-62. Not eligible target population. [pmid: 15935017].
98 Ayalon L, Mackin S, Arean PA, et al. The role of cognitive functioning and distress in suicidal ideation in older adults. J Am Geriatr Soc. 07. 2007;55(7):1090-4. Not eligible outcomes. [pmid: 17608884].
99 Aytac IA, Araujo AB, Johannes CB, et al. Socioeconomic factors and incidence of erectile dysfunction: findings of the longitudinal Massachussetts Male Aging Study. Social science & medicine. 09. 2000;51(5):771-8. Not eligible outcomes. [pmid: 10975236].
100 Azad N, Tierney M, Victor G, et al. Adverse drug events in the elderly population admitted to a tertiary care hospital. J Healthc Manag. 09–10. 2002;47(5):295-305. discussion -6. Not eligible outcomes. [pmid: 12325252].
101 Azkona G, Garcia-Belenguer S, Chacon G, et al. Prevalence and risk factors of behavioural changes associated with age-related cognitive impairment in geriatric dogs. Journal of Small Animal Practice. 02. 2009;50(2):87-91. Not eligible outcomes. [pmid: 19200264].
102 Azzopardi S, Lee G. Health-related quality of life 2 years after coronary artery bypass graft surgery. Journal of Cardiovascular Nursing. 05–06. 2009;24(3):232-40. Not eligible outcomes. [pmid: 19390341].
103 Bach P, Wormland RT, Mohring C, et al. Electromotive drug-administration: a pilot study for minimal-invasive treatment of therapy-resistant idiopathic detrusor overactivity. Neurourology & Urodynamics. 2009;28(3):209-13. Not eligible exposure. [pmid: 19205067].
104 Bachman DL, Stuckey M, Ebeling M, et al. Establishment of a predominantly African-American cohort for the study of Alzheimer’s disease: the South Carolina Alzheimer’s disease clinical core. Dementia & Geriatric Cognitive Disorders. 2009;27(4):329-36. Not eligible exposure. [pmid: 19276625].
105 Bachman SS, Vedrani M, Drainoni ML, et al. Variations in provider capacity to offer accessible health care for people with disabilities. J Soc Work Disabil Rehabil. 2007;6(3):47-63. Not eligible outcomes. [pmid: 17989034].
106 Baker FM. Ethnic minority elders: a mental health research agenda. Hosp Community Psychiatry. 04. 1992;43(4):337-8. 42. Not eligible outcomes. [pmid: 1577423].
107 Baker ML, Wang JJ, Rogers S, et al. Early age-related macular degeneration, cognitive function, and dementia: the Cardiovascular Health Study. Archives of Ophthalmology. 05. 2009;127(5):667-73. Not eligible outcomes. [pmid: 19433718].
108 Baker TA. For the patient. How chronic pain affects African Americans. Ethn Dis. Spring. 2005;15(2):353. Not eligible outcomes. [pmid: 15825986].
109 Baker TA. Chronic pain in older Black Americans: the influence of health and psychosocial factors. Ethn Dis. Spring. 2005;15(2):179-86. Not eligible outcomes. [pmid: 15825962].
110 Baker TA, Whitfield KE. Physical functioning in older blacks: an exploratory study identifying psychosocial and clinical predictors. J Natl Med Assoc. 07. 2006;98(7):1114-20. Not eligible outcomes. [pmid: 16895281].
111 Balan S, Leibovitz A, Zila SO, et al. The relation between the clinical subtypes of delirium and the urinary level of 6-SMT. Journal of Neuropsychiatry & Clinical Neurosciences. 2003;15(3):363-6. Not eligible outcomes. [pmid: 12928514].
112 Balducci L. Aging, frailty, and chemotherapy. Cancer Control. 01. 2007;14(1):7-12. Not eligible outcomes. [pmid: 17242666].
113 Balducci L, Extermann M. Management of cancer in the older person: a practical approach. Oncologist. 2000;5(3):224-37. Not eligible outcomes. [pmid: 10884501].
114 Baldwin CM, Bell IR, Guerra S, et al. Associations between chemical odor intolerance and sleep disturbances in community-living adults. Sleep Medicine. 01. 2004;5(1):53-9. Not eligible outcomes. [pmid: 14725827].
115 Baldwin RL, Craven RF, Dimond M. Falls: are rural elders at greater risk. J Gerontol Nurs. 08. 1996;22(8):14-21. Not eligible outcomes. [pmid: 8826280].
116 Ball LJ, Ogden A, Mandi D, et al. The validation of a mailed health survey for screening of dementia of the Alzheimer’s type. J Am Geriatr Soc. 06. 2001;49(6):798-802. Not eligible outcomes. [pmid: 11454121].
117 Bambauer KZ, Safran DG, Ross-Degnan D, et al. Depression and cost-related medication nonadherence in Medicare beneficiaries. Arch Gen Psychiatry. 05. 2007;64(5):602-8. Not eligible outcomes. [pmid: 17485612].
118 Banerjee S, Wall MM, Carlin BP. Frailty modeling for spatially correlated survival data, with application to infant mortality in Minnesota. Biostatistics. 01. 2003;4(1):123-42. Not eligible outcomes. [pmid: 12925334].
119 Barbieri M, Ferrucci L, Ragno E, et al. Chronic inflammation and the effect of IGF-I on muscle strength and power in older persons. Am J Physiol Endocrinol Metab. 03. 2003;284(3):E481-7. Not eligible outcomes. [pmid: 12419777].
120 Bardia A, Ebbert JO, Vierkant RA, et al. Association of aspirin and nonaspirin nonsteroidal anti-inflammatory drugs with cancer incidence and mortality. Journal of the National Cancer Institute. 06. 6. 2007;99(11):881-9. Not eligible exposure. [pmid: 17551148].
121 Barger SD, Burke SM, Limbert MJ. Do induced moods really influence health perceptions. Health Psychol. 01. 2007;26(1):85-95. Not eligible outcomes. [pmid: 17209701].
122 Barker P, Henderson R. Small sample bias in the gamma frailty model for univariate survival. Lifetime Data Anal. 06. 2005;11(2):265-84. Not eligible outcomes. [pmid: 15938549].
123 Barnes LL, Mendes de Leon CF, Wilson RS, et al. Social resources and cognitive decline in a population of older African Americans and whites. Neurology. 12. 28. 2004;63(12):2322-6. Not eligible exposure. [pmid: 15623694].
124 Barney DD. Use of mental and health services by American Indian and Alaska Native elders. Am Indian Alsk Native Ment Health Res. 1994;5(3):1-14. Not eligible outcomes. [pmid: 7918829].
125 Barrett-Connor E, Edelstein SL. A prospective study of dehydroepiandrosterone sulfate and cognitive function in an older population: the Rancho Bernardo Study. J Am Geriatr Soc. 04. 1994;42(4):420-3. Not eligible outcomes. [pmid: 8144828].
126 Barry MJ, Link CL, McNaughton-Collins MF, et al. Overlap of different urological symptom complexes in a racially and ethnically diverse, community-based population of men and women. BJU International. 01. 2008;101(1):45-51. Not eligible outcomes. [pmid: 17868419].
127 Barton C, Miller B, Yaffe K. Improved evaluation and management of cognitive impairment: results of a comprehensive intervention in long-term care.[see comment]. Journal of the American Medical Directors Association. 02. 2006;7(2):84-9. Not eligible target population. [pmid: 16461249].
128 Bass DS, Attix DK, Phillips-Bute B, et al. An efficient screening tool for preoperative depression: the Geriatric Depression Scale-Short Form. Anesthesia & Analgesia. table of contents. 03. 2008;106(3):805-9. Not eligible outcomes. [pmid: 18292422].
129 Bassett SS, Folstein MF. Memory complaint, memory performance, and psychiatric diagnosis: a community study. J Geriatr Psychiatry Neurol. 04–06. 1993;6(2):105-11. Not eligible outcomes. [pmid: 8512626].
130 Bassiony MM, Steinberg MS, Warren A, et al. Delusions and hallucinations in Alzheimer’s disease: prevalence and clinical correlates. Int J Geriatr Psychiatry. 02. 2000;15(2):99-107. Not eligible outcomes. [pmid: 10679840].
131 Basu R, Dodge H, Stoehr GP, et al. Sedative-hypnotic use of diphenhydramine in a rural, older adult, community-based cohort: effects on cognition. American Journal of Geriatric Psychiatry. 03–04. 2003;11(2):205-13. Not eligible outcomes. [pmid: 12611750].
132 Bath PA, Morgan K. Differential risk factor profiles for indoor and outdoor falls in older people living at home in Nottingham, UK. Eur J Epidemiol. 01. 1999;15(1):65-73. Not eligible outcomes. [pmid: 10098998].
133 Baumgarten M, Margolis D, Gruber-Baldini AL, et al. Pressure ulcers and the transition to long-term care. Adv Skin Wound Care. 11. 2003;16(6):299-304. Not eligible target population. [pmid: 14652516].
134 Bazargan M, Baker RS, Bazargan SH. Sensory impairments and subjective well-being among aged African American persons. J Gerontol B Psychol Sci Soc Sci. 09. 2001;56(5):P268-78. Outcomes. [pmid: 11522801].
135 Bean J, Kiely DK, Leveille SG, et al. Associating the onset of motor impairments with disability progression in nursing home residents. Am J Phys Med Rehabil. 09. 2002;81(9):696-704. quiz 5–7, 20. Not eligible target population. [pmid: 12172523].
136 Beard JL, Richards RE, Smiciklas-Wright H, et al. Iron nutrition in rural home bound elderly persons. J Nutr Elder. 1996;15(4):3-19. Not eligible outcomes. [pmid: 8949016].
137 Beard JR, Blaney S, Cerda M, et al. Neighborhood characteristics and disability in older adults. J Gerontol B Psychol Sci Soc Sci. 03. 2009;64(2):252-7. Not eligible outcomes. [pmid: 19181694].
138 Beattie ER, Song J, LaGore S. A comparison of wandering behavior in nursing homes and assisted living facilities. Res Theory Nurs Pract. Summer. 2005;19(2):181-96. Not eligible outcomes. [pmid: 16025697].
139 Beaulieu MD, Dufresne L, LeBlanc D. Treating hypertension. Are the right drugs given to the right patients?. Can Fam Physician. 02. 1998;44:294-8. 301. 2. Not eligible outcomes. [pmid: 9512833].
140 Beck J, Ferrucci L, Sun K, et al. Low serum selenium concentrations are associated with poor grip strength among older women living in the community. Biofactors. 2007;29(1):37-44. Not eligible outcomes. [pmid: 17611292].
141 Becker JT, Lopez OL, Dew MA, et al. Prevalence of cognitive disorders differs as a function of age in HIV virus infection. AIDS. 01. 1. 2004;18(Suppl 1):S11-8. Not eligible outcomes. [pmid: 15075493].
142 Beckett LA, Evans DA. Estimating prevalence and incidence of chronic conditions in the elderly: design and sampling issues. Alzheimer Dis Assoc Disord. 1994;8(Suppl 1):S274-80. Review. [pmid: 8068269].
143 Beckett WS, Hallman E, May J, et al. Follow-up to Farm Family Health and Hazard Survey.[comment]. Journal of Occupational & Environmental Medicine. 04. 2004;46(4):314-5. Comment. [pmid: 15076647].
144 Beeber AS, Thorpe JM, Clipp EC. Community-based service use by elders with dementia and their caregivers: a latent class analysis. Nurs Res. 09–10. 2008;57(5):312-21. Not eligible outcomes. [pmid: 18794715].
145 Beer C, Xiao J, Flicker L, et al. Long-term mortality following stroke, myocardial infarction and fractured neck of femur in Western Australia. Intern Med J. 12. 2007;37(12):815-9. Not eligible exposure. [pmid: 17561944].
146 Behrman JR, Sickles RC, Taubman P. Age-specific death rates with tobacco smoking and occupational activity: sensitivity to sample length, functional form, and unobserved frailty. Demography. 05. 1990;27(2):267-84. Not elgible target population. [pmid: 2185051].
147 Beissner K, Henderson CR Jr, Papaleontiou M, et al. Physical therapists’ use of cognitive-behavioral therapy for older adults with chronic pain: a nationwide survey. Phys Ther. 05. 2009;89(5):456-69. Not eligible outcomes. [pmid: 19270046].
148 Bell DS, O’Keefe JH, Bell DSH, et al. White cell count, mortality, and metabolic syndrome in the Baltimore longitudinal study of aging.[comment]. Journal of the American College of Cardiology. 10. 30. 2007;50(18):1810. author reply-1. Comment. [pmid: 17964048].
149 Bennett DA, Schneider JA, Buchman AS, et al. The Rush Memory and Aging Project: study design and baseline characteristics of the study cohort. Neuroepidemiology. 2005;25(4):163-75. Not eligible outcomes. [pmid: 16103727].
150 Berges IM, Kuo YF, Markides KS, et al. Attendance at religious services and physical functioning after stroke among older Mexican Americans. Exp Aging Res. 01–03. 2007;33(1):1-11. Not eligible outcomes. [pmid: 17132561].
151 Bergman H, Ferrucci L, Guralnik J, et al. Frailty: an emerging research and clinical paradigm--issues and controversies. J Gerontol A Biol Sci Med Sci. 07. 2007;62(7):731-7. Not eligible outcomes. [pmid: 17634320].
152 Berkey CS, Chuang SK, Douglass CW, et al. Longitudinal statistical models for loss of sound surfaces. Community Dentistry & Oral Epidemiology. 04. 1993;21(2):62-6. Not eligible outcomes. [pmid: 8485971].
153 Berkman BHLK. Social work and health care in an aging society education, policy, practice, and research. New York. Springer. [Internet Resource; Computer File Date of Entry: 20081215]. Available at:http://www.netLibrary.com/urlapi.asp?action=summary&v=1&bookid=246182. Not eligible outcomes.
154 Berlowitz DR, Bezerra HQ, Brandeis GH, et al. Are we improving the quality of nursing home care: the case of pressure ulcers. J Am Geriatr Soc. 01. 2000;48(1):59-62. Not eligible target population. [pmid: 10642022].
155 Berlowitz DR, Brandeis GH, Anderson JJ, et al. Evaluation of a risk-adjustment model for pressure ulcer development using the Minimum Data Set. J Am Geriatr Soc. 07. 2001;49(7):872-6. Not eligible target population. [pmid: 11527477].
156 Berlowitz DR, Brandeis GH, Morris JN, et al. Deriving a risk-adjustment model for pressure ulcer development using the Minimum Data Set. J Am Geriatr Soc. 07. 2001;49(7):866-71. Not eligible outcomes. [pmid: 11527476].
157 Bernabei R, Gambassi G, Lapane K, et al. Characteristics of the SAGE database: a new resource for research on outcomes in long-term care. SAGE (Systematic Assessment of Geriatric drug use via Epidemiology) Study Group, J Gerontol A Biol Sci Med Sci. 01. 1999;54(1):M25-33. Not eligible outcomes.
158 Bernabei R, Landi F, Onder G, et al. Second and third generation assessment instruments: the birth of standardization in geriatric care. J Gerontol A Biol Sci Med Sci. 03. 2008;63(3):308-13. Not eligible outcomes. [pmid: 18375880].
159 Berndt SI, Carter HB, Landis PK, et al. Prediagnostic plasma vitamin C levels and the subsequent risk of prostate cancer. Nutrition. 06. 2005;21(6):686-90. Not eligible outcomes. [pmid: 15925292].
160 Berry P, Mascia J, Steinman BA. Vision and hearing loss in older adults: “Double trouble”. Care Manag J. Spring. 2004;5(1):35-40. Not eligible outcomes. [pmid: 15792329].
161 Berry SD, Samelson EJ, Bordes M, et al. Survival of aged nursing home residents with hip fracture. J Gerontol A Biol Sci Med Sci. 07. 2009;64(7):771-7. Not eligible target population. [pmid: 19414511].
162 Best C, Eckhardt-Henn A, Tschan R, et al. Psychiatric morbidity and comorbidity in different vestibular vertigo syndromes. Results of a prospective longitudinal study over one year. Journal of neurology. 01. 2009;256(1):58-65. Not eligible outcomes. [pmid: 19221849].
163 Beydoun MA, Lhotsky A, Wang Y, et al. Association of adiposity status and changes in early to mid-adulthood with incidence of Alzheimer’s disease. American Journal of Epidemiology. 11. 15. 2008;168(10):1179-89. Not eligible exposure. [pmid: 18835864].
164 Bezjak A, Adam J, Panzarella T, et al. Radiotherapy for brain metastases: defining palliative response. Radiother Oncol. 10. 2001;61(1):71-6. Not eligible outcomes. [pmid: 11578731].
165 Bhalla RK, Butters MA, Mulsant BH, et al. Persistence of neuropsychologic deficits in the remitted state of late-life depression. Am J Geriatr Psychiatry. 05. 2006;14(5):419-27. Not eligible outcomes. [pmid: 16670246].
166 Bhargava A, Jamison DT, Lau LJ, et al. Modeling the effects of health on economic growth. J Health Econ. 05. 2001;20(3):423-40. Not eligible outcomes. [pmid: 11373839].
167 Bienias JL, Beckett LA, Bennett DA, et al. Design of the Chicago Health and Aging Project (CHAP). J Alzheimers Dis. 10. 2003;5(5):349-55. No hypothesis tested. [pmid: 14646025].
168 Bierman AS, Clancy CM. Health disparities among older women: identifying opportunities to improve quality of care and functional health outcomes. Journal of the American Medical Womens Association. 2001;188; 56(4):155-9. Not eligible outcomes.
169 Bijnen FC, Feskens EJ, Caspersen CJ, et al. Age, period, and cohort effects on physical activity among elderly men during 10 years of follow-up: the Zutphen Elderly Study. J Gerontol A Biol Sci Med Sci. 05. 1998;53(3):M235-41. Not eligible outcomes. [pmid: 9597057].
170 Bilchik GS. The age wave. Trustee. 01. 2000;53(1):14-7. 1. Comment. [pmid: 11785211].
171 Biller C. Discrete duration models combining dynamic and random effects. Lifetime Data Anal. 12. 2000;6(4):375-90. Not eligible outcomes. [pmid: 11190606].
172 Bird CE, Fremont AM. Gender, time use, and health. Journal of Health & Social Behavior. 06. 1991;32(2):114-29. Not eligible outcomes. [pmid: 1861048].
173 Birge SJ. Osteoporotic fractures: a brain or bone disease. Curr Osteoporos Rep. 06. 2008;6(2):57-61. Not eligible outcomes. [pmid: 18778564].
174 Birnbaum EH, Dreznik Z, Myerson RJ, et al. Early effect of external beam radiation therapy on the anal sphincter: a study using anal manometry and transrectal ultrasound. Diseases of the Colon & Rectum. 08. 1992;35(8):757-61. Not eligible exposure. [pmid: 1643999].
175 Birren JE. University of California Los Angeles--Multicampus Division of Geriatric Medicine and Gerontology. The Concept and Measurement of Quality of Life in the Frail Elderly. San Diego. Academic Press. 1991. Not eligible outcomes.
176 Bjarnason H, Hougaard P. Fisher information for two gamma frailty bivariate Weibull models. Lifetime Data Anal. 03. 2000;6(1):59-71. Not eligible outcomes. [pmid: 10763561].
177 Black DM, Palermo L, Nevitt MC, et al. Defining incident vertebral deformity: a prospective comparison of several approaches. The Study of Osteoporotic Fractures Research Group. Journal of Bone & Mineral Research. 01. 1999;14(1):90-101. Not eligible outcomes. [pmid: 9893070].
178 Black SA, Goodwin JS, Markides KS. The association between chronic diseases and depressive symptomatology in older Mexican Americans. J Gerontol A Biol Sci Med Sci. 05. 1998;53(3):M188-94. Not eligible outcomes. [pmid: 9597050].
179 Black SA, Markides KS. Depressive symptoms and mortality in older Mexican Americans. Ann Epidemiol. 01. 1999;9(1):45-52. Not eligible outcomes. [pmid: 9915608].
180 Black SA, Markides KS, Miller TQ. Correlates of depressive symptomatology among older community-dwelling Mexican Americans: the Hispanic EPESE. J Gerontol B Psychol Sci Soc Sci. 07. 1998;53(4):S198-208. Not eligible outcomes. [pmid: 9679521].
181 Blanchon F, Grivaux M, Asselain B, et al. 4-year mortality in patients with non-small-cell lung cancer: development and validation of a prognostic index. Lancet Oncol. 10. 2006;7(10):829-36. Not eligible outcomes. [pmid: 17012045].
182 Blank K, Hixon L, Gruman C, et al. Determinants of geropsychiatric inpatient length of stay. Psychiatr Q. Summer. 2005;76(2):195-212. Not eligible outcomes. [pmid: 15884745].
183 Blass DM, Black BS, Phillips H, et al. Medication use in nursing home residents with advanced dementia. Int J Geriatr Psychiatry. 05. 2008;23(5):490-6. Not eligible target population. [pmid: 17944007].
184 Blaum CS, Ofstedal MB, Liang J. Low cognitive performance, comorbid disease, and task-specific disability: findings from a nationally representative survey. J Gerontol A Biol Sci Med Sci. 08. 2002;57(8):M523-31. Not eligible outcomes. [pmid: 12145367].
185 Blazer DG, Sachs-Ericsson N, Hybels CF, et al. Perception of unmet basic needs as a predictor of depressive symptoms among community-dwelling older adults. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 02. 2007;62(2):191-5. Not eligible outcomes.
186 Ble A, Cherubini A, Volpato S, et al. Lower plasma vitamin E levels are associated with the frailty syndrome: the InCHIANTI study. J Gerontol A Biol Sci Med Sci. 03. 2006;61(3):278-83. Not eligible outcomes. [pmid: 16567378].
187 Blixen CE, McDougall GJ, Suen LJ. Dual diagnosis in elders discharged from a psychiatric hospital. Int J Geriatr Psychiatry. 03. 1997;12(3):307-13. Not eligible outcomes. [pmid: 9152713].
188 Blow FC, Walton MA, Barry KL, et al. The relationship between alcohol problems and health functioning of older adults in primary care settings. J Am Geriatr Soc. 07. 2000;48(7):769-74. Not eligible outcomes. [pmid: 10894315].
189 Bluestein D. Preventive services: screening. Health maintenance examinations include screening for diabetes, heart disease, cancer, osteoporosis, hearing and vision loss. Geriatrics. 02. 2005;60(2):34-9. Not eligible outcomes.
190 Blustein J, Hoy EC. Who is enrolled in for-profit vs. nonprofit Medicare HMOs?. Health Aff (Millwood). 01–02. 2000;19(1):210-20. Not eligible outcomes. [pmid: 10645089].
191 Boaz RF. Improved versus deteriorated physical functioning among long-term disabled elderly. Medical Care. 06. 1994;32(6):588-602. Not eligible outcomes. [pmid: 8189776].
192 Boeve B, McCormick J, Smith G, et al. Mild cognitive impairment in the oldest old. Neurology. 02. 11. 2003;60(3):477-80. Not eligible outcomes. [pmid: 12578930].
193 Bogner HR, Dahlberg B, de Vries HF, et al. Older patients’ views on the relationship between depression and heart disease. Fam Med. 10. 2008;40(9):652-7. Not eligible outcomes. [pmid: 18830841].
194 Bogner HR, Gallo JJ, Swartz KL, et al. Anxiety disorders and disability secondary to urinary incontinence among adults over age 50. International Journal of Psychiatry in Medicine. 2002;32(2):141-54. Not eligible exposure. [pmid: 12269595].
195 Bohannon RW, Lee N. Association of physical functioning with same-hospital readmission after stroke. Am J Phys Med Rehabil. 06. 2004;83(6):434-8. Not eligible outcomes. [pmid: 15166687].
196 Boix R, del Barrio JL, Saz P, et al. Stroke prevalence among the Spanish elderly: an analysis based on screening surveys. BMC Neurol. 2006;6:36. Not eligible outcome. [pmid: 17042941].
197 Bolge SC, Doan JF, Kannan H, et al. Association of insomnia with quality of life, work productivity, and activity impairment. Qual Life Res. 05. 2009;18(4):415-22. Not eligible outcomes. [pmid: 19288223].
198 Bonafe M, Barbi C, Olivieri F, et al. An allele of HRAS1 3’variable number of tandem repeats is a frailty allele: implication for an evolutionarily-conserved pathway involved in longevity. Gene. 03. 6. 2002;286(1):121-6. Not eligible outcomes. [pmid: 11943467].
199 Bonneux L, Birnie E. The discount rate in the economic evaluation of prevention: a thought experiment. J Epidemiol Community Health. 02. 2001;55(2):123-5. Not eligible outcomes. [pmid: 11154251].
200 Boockvar KS, Meier DE. Palliative care for frail older adults: “there are things I can’t do anymore that I wish I could . . . “. JAMA. 11. 8. 2006;296(18):2245-53. Not eligible outcomes. [pmid: 17090771].
201 Borgermans LA, Abraham IL, Milisen K, et al. Nursing case management for psychogeriatric patients and their families: description of a clinical model. Nurs Clin North Am. 09. 1998;33(3):529-42. Not eligible outcomes. [pmid: 9719696].
202 Borkon AM, Muehlebach GF, Jones PG, et al. An analysis of the effect of age on survival after heart transplant. Journal of Heart & Lung Transplantation. 07. 1999;18(7):668-74. Not eligible outcomes. [pmid: 10452343].
203 Bortz WM 2nd. The physics of frailty. J Am Geriatr Soc. 09. 1993;41(9):1004-8. Review. [pmid: 8409170].
204 Bosworth HB, Schaie KW, Willis SL. Cognitive and sociodemographic risk factors for mortality in the Seattle Longitudinal Study. J Gerontol B Psychol Sci Soc Sci. 09. 1999;54(5):P273-82. Not eligible outcomes. [pmid: 10542820].
205 Bould S. A population health perspective on disability and depression in elderly women and men. Journal of aging & social policy. 2005;17(2):7-24. Not eligible outcomes. [pmid: 15911515].
206 Boult C, Altmann M, Gilbertson D, et al. Decreasing disability in the 21st century: the future effects of controlling six fatal and nonfatal conditions.[see comment]. American Journal of Public Health. 10. 1996;86(10):1388-93. Not eligible outcomes. [pmid: 8876506].
207 Boult C, Kane RL, Louis TA, et al. Forecasting the number of future disabled elderly using Markovian and mathematical models. J Clin Epidemiol. 1991;44(9):973-80. Not eligible outcomes. [pmid: 1832442].
208 Boult C, Pualwan TF, Fox PD, et al. Identification and assessment of high-risk seniors. HMO Workgroup on Care Management. Am J Manag Care. 08. 1998;4(8):1137-46. Not eligible outcomes. [pmid: 10182889].
209 Boult C, Rassen J, Rassen A, et al. The effect of case management on the costs of health care for enrollees in Medicare Plus Choice plans: a randomized trial. J Am Geriatr Soc. 08. 2000;48(8):996-1001. Not eligible outcomes. [pmid: 10968308].
210 Boult L, Boult C, Pirie P, et al. Test-retest reliability of a questionnaire that identifies elders at risk for hospital admission. J Am Geriatr Soc. 07. 1994;42(7):707-11. Not eligible outcomes. [pmid: 8014343].
211 Bouman A, van Rossum E, Evers S, et al. Effects on health care use and associated cost of a home visiting program for older people with poor health status: a randomized clinical trial in the Netherlands. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 03. 2008;63(3):291-7. Not eligible outcomes.
212 Bourdel-Marchasson I, Berrut G. Caring the elderly diabetic patient with respect to concepts of successful aging and frailty. Diabetes Metab. 12. 2005;31(Spec No 2):5S13-5S9. Not eligible outcomes. [pmid: 16415761].
213 Bowles KH. Vulnerable links in the home care referral process. Caring. 11. 2000;19(11):34-7. Not eligible outcomes. [pmid: 11151561].
214 Boyington JE, Howard DL, Carter-Edwards L, et al. Differences in resident characteristics and prevalence of urinary incontinence in nursing homes in the southeastern United States. Nurs Res. 03–04. 2007;56(2):97-107. Not eligible target population. [pmid: 17356440].
215 Brach JS, Perera S, Studenski S, et al. The reliability and validity of measures of gait variability in community-dwelling older adults. Arch Phys Med Rehabil. 12. 2008;89(12):2293-6. Not eligible outcomes. [pmid: 19061741].
216 Brach JS, Simonsick EM, Kritchevsky S, et al. The association between physical function and lifestyle activity and exercise in the health, aging and body composition study. J Am Geriatr Soc. 04. 2004;52(4):502-9. Not eligible outcomes. [pmid: 15066063].
217 Brach JS, Solomon C, Naydeck BL, et al. Incident physical disability in people with lower extremity peripheral arterial disease: the role of cardiovascular disease. J Am Geriatr Soc. 06. 2008;56(6):1037-44. Not eligible exposure. [pmid: 18384579].
218 Brach JS, VanSwearingen JM. Physical impairment and disability: relationship to performance of activities of daily living in community-dwelling older men. Phys Ther. 08. 2002;82(8):752-61. Not eligible outcomes. [pmid: 12147005].
219 Bradley CJ, Yabroff KR, Dahman B, et al. Productivity costs of cancer mortality in the United States: 2000–2020. J Natl Cancer Inst. 12. 17. 2008;100(24):1763-70. Not eligible outcomes. [pmid: 19066273].
220 Branch LG, Jette AM. The Framingham Disability Study: I. Social disability among the aging. Am J Public Health. 11. 1981;71(11):1202-10. Not eligible outcomes. [pmid: 7294261].
221 Brand FN, Kiely DK, Kannel WB, et al. Family patterns of coronary heart disease mortality: the Framingham Longevity Study. Journal of Clinical Epidemiology. 02. 1992;45(2):169-74. Not eligible outcomes. [pmid: 1573433].
222 Brandeis GH, Ooi WL, Hossain M, et al. A longitudinal study of risk factors associated with the formation of pressure ulcers in nursing homes. J Am Geriatr Soc. 04. 1994;42(4):388-93. Not eligible target population. [pmid: 8144823].
223 Brandt DK, Hind JA, Robbins J, et al. Challenges in the design and conduct of a randomized study of two interventions for liquid aspiration. Clin Trials. 2006;3(5):457-68. Not eligible outcomes. [pmid: 17060219].
224 Breitner JC, Haneuse SJ, Walker R, et al. Risk of dementia and AD with prior exposure to NSAIDs in an elderly community-based cohort. Neurology. 06. 2. 2009;72(22):1899-905. Not eligible exposure. [pmid: 19386997].
225 Brenes GA, Kritchevsky SB, Mehta KM, et al. Scared to death: results from the Health, Aging, and Body Composition study. Am J Geriatr Psychiatry. 03. 2007;15(3):262-5. Not eligible outcomes. [pmid: 17322138].
226 Brenes GA, Miller ME, Stanley MA, et al. Insomnia in older adults with generalized anxiety disorder. American Journal of Geriatric Psychiatry. 06. 2009;17(6):465-72. Not eligible outcomes. [pmid: 19472436].
227 Brescianini S, Maggi S, Farchi G, et al. Low total cholesterol and increased risk of dying: are low levels clinical warning signs in the elderly? Results from the Italian Longitudinal Study on Aging. J Am Geriatr Soc. 07. 2003;51(7):991-6. Not eligible exposure. [pmid: 12834520].
228 Breslau N, Roth T, Rosenthal L, et al. Sleep disturbance and psychiatric disorders: a longitudinal epidemiological study of young adults. Biological psychiatry. 03. 15. 1996;39(6):411-8. Not eligible outcomes. [pmid: 8679786].
229 Bretsky P, Guralnik JM, Launer L, et al. The role of APOE-epsilon4 in longitudinal cognitive decline: MacArthur Studies of Successful Aging. Neurology. 04. 8. 2003;60(7):1077-81. Not eligible exposure. [pmid: 12682309].
230 Brhel S. Increasing the quality of life for the older adult : geriatric observable activities for longevity program. 1. Binghamton, NY. Brundage Pub. Co. 2005. Not eligible outcomes.
231 Brickman AM, Schupf N, Manly JJ, et al. Brain morphology in older African Americans, Caribbean Hispanics, and whites from northern Manhattan. Archives of Neurology. 08. 2008;65(8):1053-61. Not eligible outcomes. [pmid: 18695055].
232 Bridevaux IP, Bradley KA, Bryson CL, et al. Alcohol screening results in elderly male veterans: association with health status and mortality. J Am Geriatr Soc. 09. 2004;52(9):1510-7. Not elgible target population. [pmid: 15341553].
233 Brinkley TE, Leng X, Miller ME, et al. Chronic inflammation is associated with low physical function in older adults across multiple comorbidities. J Gerontol A Biol Sci Med Sci. 04. 2009;64(4):455-61. not eligible outcome. [pmid: 19196644].
234 Brismar K, Nilsson SE. Interrelations and associations of serum levels of steroids and pituitary hormones with markers of insulin resistance, inflammatory activity, and renal function in men and women aged >70 years in an 8-year longitudinal study of opposite-sex twins. Gender Medicine. 2009;6(Suppl 1):123-36. Not eligible outcomes. [pmid: 19318223].
235 Brody BL, Gamst AC, Williams RA, et al. Depression, visual acuity, comorbidity, and disability associated with age-related macular degeneration. Ophthalmology. 10. 2001;108(10):1893-900. discussion 900–1. Not eligible outcomes. [pmid: 11581068].
236 Brody KK, Maslow K, Perrin NA, et al. Usefulness of a single item in a mail survey to identify persons with possible dementia: a new strategy for finding high-risk elders. Dis Manag. 04. 2005;8(2):59-72. Not eligible outcomes. [pmid: 15815155].
237 Brogan DJ, Haber M, Kutner NG. Functional decline among older adults: comparing a chronic disease cohort and controls when mortality rates are markedly different. Journal of Clinical Epidemiology. 08. 2000;53(8):847-51. Not eligible outcomes. [pmid: 10942868].
238 Bromberger JT, Kravitz HM, Matthews K, et al. Predictors of first lifetime episodes of major depression in midlife women. Psychological Medicine. 01. 2009;39(1):55-64. Not eligible outcomes. [pmid: 18377672].
239 Bronikowski AM, Alberts SC, Altmann J, et al. The aging baboon: comparative demography in a non-human primate. Proc Natl Acad Sci U S A. 07. 9. 2002;99(14):9591-5. Not eligible outcomes. [pmid: 12082185].
240 Brown EL, Bruce ML, Nassisi P, et al. An agency-university research partnership: focus on late-life depression. Home Healthc Nurse. 09. 2004;22(9):597-600. Not eligible outcomes. [pmid: 15359170].
241 Brown GC, Brown MM, Sharma S, et al. Incremental cost-effectiveness of laser therapy for visual loss secondary to branch retinal vein occlusion. Ophthalmic Epidemiol. 02. 2002;9(1):1-10. Not eligible outcomes. [pmid: 11815891].
242 Brown GC, Brown MM, Sharma S, et al. The burden of age-related macular degeneration: a value-based medicine analysis. Transactions of the American Ophthalmological Society. 2005;103:173-84. discussion 84–6. Not eligible outcome. [pmid: 17057801].
243 Brown SL, Salive ME, Pahor M, et al. Occult caffeine as a source of sleep problems in an older population. Journal of the American Geriatrics Society. 08. 1995;43(8):860-4. Not eligible outcomes. [pmid: 7636092].
244 Bruce ML, McAvay GJ, Raue PJ, et al. Major depression in elderly home health care patients. Am J Psychiatry. 08. 2002;159(8):1367-74. Not eligible outcomes. [pmid: 12153830].
245 Brush JA, Threats TT, Calkins MP. Influences on perceived function of a nursing home resident. J Commun Disord. 09–10. 2003;36(5):379-93. Not eligible target population. [pmid: 12927945].
246 Bucci AT. Be a continence champion: use the CHAMMP tool to individualize the plan of care. Geriatr Nurs. 03–04. 2007;28(2):120-4. quiz 5. Not eligible target population. [pmid: 17430746].
247 Buchanan RJ, Barkley J, Wang S, et al. Analyses of nursing home residents with cancer at admission. Cancer Nurs. 09–10. 2005;28(5):406-14. Not eligible target population. [pmid: 16192833].
248 Buchman AS, Boyle PA, Wilson RS, et al. Association between late-life social activity and motor decline in older adults. Arch Intern Med. 06. 22. 2009;169(12):1139-46. Not eligible outcomes. [pmid: 19546415].
249 Buchman AS, Boyle PA, Wilson RS, et al. Pulmonary function, muscle strength and mortality in old age. Mech Ageing Dev. 11. 2008;129(11):625-31. Not eligible outcomes. [pmid: 18755207].
250 Buchsbaum GM, Duecy EE, Kerr LA, et al. Urinary incontinence in nulliparous women and their parous sisters. Obstetrics & Gynecology. 12. 2005;106(6):1253-8. Not eligible outcomes. [pmid: 16319249].
251 Budnik A, Liczbinska G. Urban and rural differences in mortality and causes of death in historical Poland. Am J Phys Anthropol. 02. 2006;129(2):294-304. Not eligible outcomes. [pmid: 16323200].
252 Bulat T, Castle SC, Rutledge M, et al. Clinical practice algorithms: medication management to reduce fall risk in the elderly--part 2, summary algorithm. J Am Acad Nurse Pract. 01. 2008;20(1):1-4. Not eligible outcomes. [pmid: 18184158].
253 Buntinx F, Niclaes L, Suetens C, et al. Evaluation of Charlson’s comorbidity index in elderly living in nursing homes. J Clin Epidemiol. 11. 2002;55(11):1144-7. Not eligible target population. [pmid: 12507679].
254 Burchfiel CM, Marcus EB, Curb JD, et al. Effects of smoking and smoking cessation on longitudinal decline in pulmonary function. American Journal of Respiratory & Critical Care Medicine. 06. 1995;151(6):1778-85. Not eligible outcomes. [pmid: 7767520].
255 Burgio KL, Locher JL, Ives DG, et al. Nocturnal enuresis in community-dwelling older adults. J Am Geriatr Soc. 02. 1996;44(2):139-43. Not eligible outcomes. [pmid: 8576502].
256 Burgio KL, Matthews KA, Engel BT. Prevalence, incidence and correlates of urinary incontinence in healthy, middle-aged women. Journal of Urology. 11. 1991;146(5):1255-9. Not eligible outcomes. [pmid: 1942274].
257 Burke GL, Arnold AM, Bild DE, et al. Factors associated with healthy aging: the cardiovascular health study. Journal of the American Geriatrics Society. 03. 2001;49(3):254-62. Not eligible outcomes. [pmid: 11300235].
258 Burns R, Graney MJ, Lummus AC, et al. Differences of self-reported osteoarthritis disability and race. J Natl Med Assoc. 09. 2007;99(9):1046-51. Not eligible outcomes. [pmid: 17913116].
259 Burns R, Nichols LO, Martindale-Adams J, et al. Interdisciplinary geriatric primary care evaluation and management: two-year outcomes. J Am Geriatr Soc. 01. 2000;48(1):8-13. Not eligible outcomes. [pmid: 10642014].
260 Burnside I. The frail elderly: those 85 and over. Nurs Adm Q. Winter. 1990;14(2):37-41. Not eligible outcomes. [pmid: 2314662].
261 Burrowes JD, Larive B, Chertow GM, et al. Self-reported appetite, hospitalization and death in haemodialysis patients: findings from the Hemodialysis (HEMO) Study. Nephrology Dialysis Transplantation. 12. 2005;20(12):2765-74. Not eligible target population.
262 Burton L, Kasper J, Shore A, et al. The structure of informal care: are there differences by race. Gerontologist. 12. 1995;35(6):744-52. Not eligible outcomes. [pmid: 8557202].
263 Busby WJ, Campbell AJ, Robertson MC. Is low blood pressure in elderly people just a consequence of heart disease and frailty. Age Ageing. 01. 1994;23(1):69-74. Not eligible outcomes. [pmid: 8010177].
264 Busse A, Bischkopf J, Riedel-Heller SG, et al. Subclassifications for mild cognitive impairment: prevalence and predictive validity. Psychol Med. 08. 2003;33(6):1029-38. Not eligible outcomes. [pmid: 12946087].
265 Busse A, Bischkopf J, Riedel-Heller SG, et al. Mild cognitive impairment: prevalence and predictive validity according to current approaches. Acta Neurol Scand. 08. 2003;108(2):71-81. Not eligible outcomes. [pmid: 12859282].
266 Busse A, Bischkopf J, Riedel-Heller SG, et al. Mild cognitive impairment: prevalence and incidence according to different diagnostic criteria. Results of the Leipzig Longitudinal Study of the Aged (LEILA75+). Br J Psychiatry. 05. 2003;182:449-54. Not eligible outcomes. [pmid: 12724250].
267 Busse A, Hensel A, Guhne U, et al. Mild cognitive impairment: long-term course of four clinical subtypes. Neurology. 12. 26. 2006;67(12):2176-85. Not eligible outcomes. [pmid: 17190940].
268 Byles J, Millar CJ, Sibbritt DW, et al. Living with urinary incontinence: a longitudinal study of older women. Age & Ageing. discussion 251. 05. 2009;38(3):333-8. Not outcome. [pmid: 19258398].
269 Bylow K, Mohile SG, Stadler WM, et al. Does androgen-deprivation therapy accelerate the development of frailty in older men with prostate cancer?: a conceptual review. Cancer. 12. 15. 2007;110(12):2604-13. Not eligible outcomes. [pmid: 17960609].
270 Cacchione PZ, Culp K, Dyck MJ, et al. Risk for acute confusion in sensory-impaired, rural, long-term-care elders. Clinical nursing research. 11. 2003;12(4):340-55. Not eligible target population. [pmid: 14620691].
271 Cacciatore F, Abete P, Mazzella F, et al. Frailty predicts long-term mortality in elderly subjects with chronic heart failure. Eur J Clin Invest. 12. 2005;35(12):723-30. Not eligible outcomes. [pmid: 16313247].
272 Cagney KA, Glass TA, Skarupski KA, et al. Neighborhood-level cohesion and disorder: measurement and validation in two older adult urban populations. J Gerontol B Psychol Sci Soc Sci. 05. 2009;64(3):415-24. Not eligible outcomes. [pmid: 19255089].
273 Cahir JG, Toms AP. Regional migratory osteoporosis. Eur J Radiol. 07. 2008;67(1):2-10. Not eligible outcomes. [pmid: 18355999].
274 Calabrese JM, Friedman PK, Rose LM, et al. Using the GOHAI to assess oral health status of frail homebound elders: reliability, sensitivity, and specificity. Spec Care Dentist. 09–10. 1999;19(5):214-9. Not eligible outcomes. [pmid: 10765888].
275 Calabrese JR, Hirschfeld RM, Reed M, et al. Impact of bipolar disorder on a U.S. community sample. J Clin Psychiatry. 04. 2003;64(4):425-32. Not eligible outcomes. [pmid: 12716245].
276 Callahan CM, Unverzagt FW, Hui SL, et al. Six-item screener to identify cognitive impairment among potential subjects for clinical research.[see comment]. Medical Care. 09. 2002;40(9):771-81. Not eligible outcomes. [pmid: 12218768].
277 Callisaya ML, Blizzard L, Schmidt MD, et al. A population-based study of sensorimotor factors affecting gait in older people. Age & Ageing. 05. 2009;38(3):290-5. Not eligible outcomes. [pmid: 19264860].
278 Cameron DJ, Yang Z, Tong Z, et al. 10q26 is associated with increased risk of age-related macular degeneration in the Utah population. Advances in Experimental Medicine & Biology. 2008;613:253-8. Not eligible exposure. [pmid: 18188952].
279 Camm AJ. Atrial fibrillation in the elderly--a near epidemic. Am J Geriatr Cardiol. 11–12. 2002;11(6):352. Not eligible outcomes. [pmid: 12417839].
280 Campbell AJ, Buchner DM. Unstable disability and the fluctuations of frailty. Age Ageing. 07. 1997;26(4):315-8. Comment. [pmid: 9271296].
281 Canada National Advisory Council on Aging. Geriatric assessment and treatment : members of the team : the contribution of interdisciplinary teamwork to the quality of life of Canada’s seniors. 1991. Not eligible outcomes.
282 Cannon KT, Choi MM, Zuniga MA. Potentially inappropriate medication use in elderly patients receiving home health care: a retrospective data analysis. American Journal Geriatric Pharmacotherapy. 06. 2006;4(2):134-43. Not eligible outcomes.
283 Capo JP Jr, Laramee C, Lucente V, et al. Solifenacin treatment for overactive bladder in Hispanic patients: patient-reported symptom bother and quality of life outcomes from the VESIcare Open-Label Trial. Int J Clin Pract. 01. 2008;62(1):39-46. Not eligible outcomes. [pmid: 18036164].
284 Caprini JA, Botteman MF, Stephens JM, et al. Economic burden of long-term complications of deep vein thrombosis after total hip replacement surgery in the United States. Value in Health. 01–02. 2003;6(1):59-74. Not eligible outcomes. [pmid: 12535239].
285 Carmelli D, DeCarli C, Swan GE, et al. The joint effect of apolipoprotein E epsilon4 and MRI findings on lower-extremity function and decline in cognitive function. J Gerontol A Biol Sci Med Sci. 02. 2000;55(2):M103-9. Not eligible outcomes. [pmid: 10737693].
286 Carnahan RM, Lund BC, Perry PJ, et al. The concurrent use of anticholinergics and cholinesterase inhibitors: rare event or common practice. J Am Geriatr Soc. 12. 2004;52(12):2082-7. Not eligible outcomes. [pmid: 15571547].
287 Carriere I, Delcourt C, Lacroux A, et al. Nutrient intake in an elderly population in southern France (POLANUT): deficiency in some vitamins, minerals and omega-3 PUFA. International Journal for Vitamin & Nutrition Research. 01. 2007;77(1):57-65. Not eligible outcomes. [pmid: 17685096].
288 Carter HB, Metter EJ, Wright J, et al. Prostate-specific antigen and all-cause mortality: results from the Baltimore Longitudinal Study On Aging. Journal of the National Cancer Institute. 04. 7. 2004;96(7):557-8. Not eligible outcomes. [pmid: 15069122].
289 Casteel C, Martin SL, Smith JB, et al. National study of physical and sexual assault among women with disabilities. Inj Prev. 04. 2008;14(2):87-90. Not eligible outcomes. [pmid: 18388227].
290 Castle NG. Mental health outcomes and physical restraint use in nursing homes {private}. Adm Policy Ment Health. 11. 2006;33(6):696-704. Not eligible target population. [pmid: 16816992].
291 Cauley JA, Zmuda JM, Lui LY, et al. Lipid-lowering drug use and breast cancer in older women: a prospective study. Journal of Women’s Health. 10. 2003;12(8):749-56. Not eligible outcome.
292 Cella D, Yount S, Rothrock N, et al. The Patient-Reported Outcomes Measurement Information System (PROMIS): progress of an NIH Roadmap cooperative group during its first two years. Med Care. 05. 2007;45(5 Suppl 1):S3-11. Not eligible outcomes. [pmid: 17443116].
293 Cepeda MS, Farrar JT, Baumgarten M, et al. Side effects of opioids during short-term administration: effect of age, gender, and race. Clinical Pharmacology & Therapeutics. 08. 2003;74(2):102-12. Not eligible outcomes. [pmid: 12891220].
294 Cerhan JR, Wallace RB, el-Khoury GY, et al. Decreased survival with increasing prevalence of full-body, radiographically defined osteoarthritis in women. American Journal of Epidemiology. 02. 1. 1995;141(3):225-34. Not eligible outcomes. [pmid: 7840096].
295 Cesari M, Leeuwenburgh C, Lauretani F, et al. Frailty syndrome and skeletal muscle: results from the Invecchiare in Chianti study. Am J Clin Nutr. 05. 2006;83(5):1142-8. Not eligible outcomes. [pmid: 16685058].
296 Cesari M, Penninx BW, Newman AB, et al. Inflammatory markers and cardiovascular disease (The Health, Aging and Body Composition [Health ABC] Study). Am J Cardiol. 09. 1. 2003;92(5):522-8. Not eligible outcomes. [pmid: 12943870].
297 Chakravarty EF, Hubert HB, Lingala VB, et al. Reduced disability and mortality among aging runners: a 21-year longitudinal study. Arch Intern Med. 08. 11. 2008;168(15):1638-46. Not eligible outcomes. [pmid: 18695077].
298 Chan BK, Marshall LM, Winters KM, et al. Incident fall risk and physical activity and physical performance among older men: the Osteoporotic Fractures in Men Study. Am J Epidemiol. 03. 15. 2007;165(6):696-703. Not eligible outcomes. [pmid: 17194749].
299 Chang JI, Karuza J, Katz PR, et al. Patient outcomes in hospital-based respite: a study of potential risks and benefits. J Am Board Fam Pract. 09–10. 1992;5(5):475-81. Not elgible target population. [pmid: 1414448].
300 Chaperon CM, Farr LA, LoChiano E. Sleep disturbance of residents in a continuing care retirement community. J Gerontol Nurs. 10. 2007;33(10):21-8. quiz 30–1. Not eligible outcomes. [pmid: 17955735].
301 Chapman DP, Williams SM, Strine TW, et al. Dementia and its implications for public health. Prev Chronic Dis. 04. 2006;3(2):A34. Review. [pmid: 16539775].
302 Chapman IM. Endocrinology of anorexia of ageing. Best Pract Res Clin Endocrinol Metab. 09. 2004;18(3):437-52. Not eligible outcomes. [pmid: 15261848].
303 Chapman RH, Benner JS, Girase P, et al. Generic and therapeutic statin switches and disruptions in therapy. Curr Med Res Opin. 05. 2009;25(5):1247-60. Not eligible outcomes. [pmid: 19344292].
304 Charlifue S, Lammertse DP, Adkins RH, et al. Aging with spinal cord injury: changes in selected health indices and life satisfaction. Archives of Physical Medicine & Rehabilitation. 11. 2004;85(11):1848-53. Not eligible outcomes. [pmid: 15520980].
305 Charlifue SW, Weitzenkamp DA, Whiteneck GG. Longitudinal outcomes in spinal cord injury: aging, secondary conditions, and well-being. Archives of Physical Medicine & Rehabilitation. 11. 1999;80(11):1429-34. Not eligible outcomes. [pmid: 10569437].
306 Chaudhry SI, Wang Y, Gill TM, et al. Geriatric conditions and subsequent mortality in older patients with heart failure. Journal of the American College of Cardiology. 01. 26. 2010;55(4):309-16. Not eligible outcomes. [pmid: 20117435].
307 Chaves PH, Varadhan R, Lipsitz LA, et al. Physiological complexity underlying heart rate dynamics and frailty status in community-dwelling older women. J Am Geriatr Soc. 09. 2008;56(9):1698-703. Not eligible outcomes. [pmid: 19166446].
308 Chen CC, Chang CK, Chyun DA, et al. Dynamics of nutritional health in a community sample of american elders: a multidimensional approach using roy adaptation model. ANS Adv Nurs Sci. 10–12. 2005;28(4):376-89. Not eligible target population. [pmid: 16292023].
309 Chen H, Guo X. Obesity and functional disability in elderly Americans. J Am Geriatr Soc. 04. 2008;56(4):689-94. Not eligible outcomes. [pmid: 18266843].
310 Chen J, Radford MJ, Wang Y, et al. Care and outcomes of elderly patients with acute myocardial infarction by physician specialty: the effects of comorbidity and functional limitations. Am J Med. 04. 15. 2000;108(6):460-9. Not eligible target population. [pmid: 10781778].
311 Chen P, Ganguli M, Mulsant BH, et al. The temporal relationship between depressive symptoms and dementia: a community-based prospective study. Archives of General Psychiatry. 03. 1999;56(3):261-6. Not eligible outcomes. [pmid: 10078504].
312 Chen P, Kales HC, Weintraub D, et al. Antidepressant treatment of veterans with Parkinson’s disease and depression: analysis of a national sample. J Geriatr Psychiatry Neurol. 09. 2007;20(3):161-5. Not eligible outcomes. [pmid: 17712099].
313 Chen Q, Kane RL. Effects of using consumer and expert ratings of an activities of daily living scale on predicting functional outcomes of postacute care. J Clin Epidemiol. 04. 2001;54(4):334-42. Not eligible target population. [pmid: 11297883].
314 Chen YM, Hwang SJ, Chen LK, et al. Urinary incontinence among institutionalized oldest old Chinese men in Taiwan. Neurourology & Urodynamics. 2009;28(4):335-8. Not eligible target population. [pmid: 19090585].
315 Cherner M, Letendre S, Heaton RK, et al. Hepatitis C augments cognitive deficits associated with HIV infection and methamphetamine.[see comment]. Neurology. 04. 26. 2005;64(8):1343-7. Not eligible outcomes. [pmid: 15851720].
316 Chertkow H. Diagnosis and treatment of dementia: introduction. Introducing a series based on the Third Canadian Consensus Conference on the Diagnosis and Treatment of Dementia. CMAJ. 01. 29. 2008;178(3):316-21. Not eligible outcomes. [pmid: 18227452].
317 Chi YY, Ibrahim JG. Joint models for multivariate longitudinal and multivariate survival data. Biometrics. 06. 2006;62(2):432-45. Not eligible outcomes. [pmid: 16918907].
318 Chichin E. Community care for the frail elderly: the case of non-professional home care workers. Women Health. 1988;14(3–4):93-104. Not eligible outcomes. [pmid: 3247759].
319 Chin APMJ, de Groot LC, van Gend SV, et al. Inactivity and weight loss: effective criteria to identify frailty. J Nutr Health Aging. 2003;7(1):55-60. Not eligible outcomes. [pmid: 12679841].
320 Chin APMJ, Dekker JM, Feskens EJ, et al. How to select a frail elderly population? A comparison of three working definitions. J Clin Epidemiol. 11. 1999;52(11):1015-21. Not eligible outcomes. [pmid: 10526994].
321 Chio A, Cocito D, Leone M, et al. Guillain-Barre syndrome: a prospective, population-based incidence and outcome survey. Neurology. 04. 8. 2003;60(7):1146-50. Not eligible outcomes. [pmid: 12682322].
322 Chiu CJ, Hubbard LD, Armstrong J, et al. Dietary glycemic index and carbohydrate in relation to early age-related macular degeneration.[see comment]. American Journal of Clinical Nutrition. 04. 2006;83(4):880-6. Not eligible outcomes. [pmid: 16600942].
323 Chiu CJ, Morris MS, Rogers G, et al. Carbohydrate intake and glycemic index in relation to the odds of early cortical and nuclear lens opacities. American Journal of Clinical Nutrition. 06. 2005;81(6):1411-6. Not eligible outcomes. [pmid: 15941895].
324 Chiu PY, Liu CH, Tsai CH. Neuropsychiatric manifestations in vascular cognitive impairment patients with and without dementia. Acta Neurologica Taiwanica. 06. 2007;16(2):86-91. Not eligible outcomes. [pmid: 17685132].
325 Choi NG. Determinants of engagement in paid work following social security benefit receipt among older women. Journal of Women & Aging. 2000;12(3–4):133-54. Not eligible outcomes. [pmid: 11151349].
326 Choi SW, Peek-Asa C, Sprince NL, et al. Hearing loss as a risk factor for agricultural injuries. American Journal of Industrial Medicine. 10. 2005;48(4):293-301. Not eligible outcomes. [pmid: 16142735].
327 Choumenkovitch SF, Selhub J, Wilson PW, et al. Folic acid intake from fortification in United States exceeds predictions. Journal of Nutrition. 09. 2002;132(9):2792-8. Not eligible outcomes. [pmid: 12221247].
328 Chrischilles EA, Carter BL, Lund BC, et al. Evaluation of the Iowa Medicaid pharmaceutical case management program. J Am Pharm Assoc. 2004. 05–06. 2003;44(3):337-49. Not eligible outcomes.
329 Christ SL, Lee DJ, Fleming LE, et al. Employment and occupation effects on depressive symptoms in older Americans: does working past age 65 protect against depression. J Gerontol B Psychol Sci Soc Sci. 11. 2007;62(6):S399-403. Not eligible outcomes. [pmid: 18079428].
330 Christensen MD, White HK. Dementia assessment and management.[see comment]. Journal of the American Medical Directors Association. 02. 2006;7(2):109-18. Review. [pmid: 16461253].
331 Christie J, Smith GR, Williamson GM, et al. Quality of informal care is multidimensional. Rehabilitation Psychology. 05. 2009;54(2):173-81. Not eligible outcomes. [pmid: 19469607].
332 Chueh KH, Yang MS, Chen CS, et al. Poor sleep quality and alcohol use problems among elderly Taiwanese aboriginal women. International Psychogeriatrics. 06. 2009;21(3):593-9. Not eligible outcomes. [pmid: 19323869].
333 Chung S, Song MY, Shin HD, et al. Korean and Caucasian overweight premenopausal women have different relationship of body mass index to percent body fat with age. Journal of Applied Physiology. 07. 2005;99(1):103-7. Not eligible target population. [pmid: 15774704].
334 Church TS, Gill TM, Newman AB, et al. Maximal fitness testing in sedentary elderly at substantial risk of disability: LIFE-P study experience. J Aging Phys Act. 10. 2008;16(4):408-15. Not eligible outcomes. [pmid: 19033602].
335 Chyou PH, Burchfiel CM, Yano K, et al. Obesity, alcohol consumption, smoking, and mortality. Annals of Epidemiology. 05. 1997;7(4):311-7. Not eligible exposure. [pmid: 9177115].
336 Cigolle CT, Langa KM, Kabeto MU, et al. Setting eligibility criteria for a care-coordination benefit. J Am Geriatr Soc. 12. 2005;53(12):2051-9. Not eligible outcomes. [pmid: 16398887].
337 Cigolle CT, Langa KM, Kabeto MU, et al. Setting eligibility criteria for a care-coordination benefit.[see comment]. Journal of the American Geriatrics Society. 12. 2005;53(12):2051-9. Not eligible outcomes. [pmid: 16398887].
338 Cipher DJ, Clifford PA, Roper KD. Behavioral manifestations of pain in the demented elderly. J Am Med Dir Assoc. 07. 2006;7(6):355-65. Not eligible outcomes. [pmid: 16843236].
339 Clark WW, Bohl CD, Clark WW, et al. Hearing levels of firefighters: risk of occupational noise-induced hearing loss assessed by cross-sectional and longitudinal data.[see comment]. Ear & Hearing. 06. 2005;26(3):327-40. Not eligible outcomes. [pmid: 15937413].
340 Class CA, Unverzagt FW, Gao S, et al. Psychiatric disorders in African American nursing home residents. Am J Psychiatry. 05. 1996;153(5):677-81. Not eligible target population. [pmid: 8615414].
341 Classen S, Meuleman J, Garvan C, et al. Review of prescription medications in home-based older adults with stroke: a pilot study. Res Social Adm Pharm. 03. 2007;3(1):104-22. Not eligible outcomes. [pmid: 17350560].
342 Clauser SB, Bierman AS. Significance of functional status data for payment and quality. Health Care Financ Rev. Spring. 2003;24(3):1-12. Not eligible outcomes. [pmid: 12894631].
343 Clerisme-Beaty E, Rand CS, Clerisme-Beaty E, et al. The effect of obesity on asthma incidence: moving past the epidemiologic evidence.[comment]. Journal of Allergy & Clinical Immunology. 01. 2009;123(1):96-7. Not eligible outcomes. [pmid: 19130929].
344 Cline CM, Broms K, Willenheimer RB, et al. Hospitalization and Health Care Costs Due to Congestive Heart Failure in the Elderly. Am J Geriatr Cardiol. 07. 1996;5(4):10-4. Not eligible outcomes. [pmid: 11416382].
345 Cline MG, Dodge R, Lebowitz MD, et al. Determinants of percent predicted FEV1 in current asthmatic subjects. Chest. 10. 1994;106(4):1089-93. Not eligible outcomes. [pmid: 7924478].
346 Coast J, Flynn TN, Natarajan L, et al. Valuing the ICECAP capability index for older people. Social science & medicine. 09. 2008;67(5):874-82. Not eligible outcomes. [pmid: 18572295].
347 Cohen A, Houck PR, Szanto K, et al. Social inequalities in response to antidepressant treatment in older adults. Arch Gen Psychiatry. 01. 2006;63(1):50-6. Not eligible outcomes. [pmid: 16389196].
348 Cohen CI, Magai C, Yaffee R, et al. Racial differences in paranoid ideation and psychoses in an older urban population. Am J Psychiatry. 05. 2004;161(5):864-71. Not eligible outcomes. [pmid: 15121652].
349 Cohen J, Cohen J. Influenza. Study questions the benefits of vaccinating the elderly. Science. 02. 18. 2005;307(5712):1026. Not eligible outcomes. [pmid: 15718436].
350 Colantonio A, Kasl SV, Ostfeld AM, et al. Prestroke physical function predicts stroke outcomes in the elderly. Arch Phys Med Rehabil. 06. 1996;77(6):562-6. Not eligible exposure. [pmid: 8831472].
351 Colbert LH, Visser M, Simonsick EM, et al. Physical activity, exercise, and inflammatory markers in older adults: findings from the Health, Aging and Body Composition Study. J Am Geriatr Soc. 07. 2004;52(7):1098-104. Not eligible outcome. [pmid: 15209647].
352 Coleman EA, Grothaus LC, Sandhu N, et al. Chronic care clinics: a randomized controlled trial of a new model of primary care for frail older adults. Journal of the American Geriatrics Society. 07. 1999;47(7):775-83. Not eligible exposure. [pmid: 10404919].
353 Coleman EA, Wagner EH, Grothaus LC, et al. Predicting hospitalization and functional decline in older health plan enrollees: are administrative data as accurate as self-report. J Am Geriatr Soc. 04. 1998;46(4):419-25. Not eligible outcomes. [pmid: 9560062].
354 Colenda CC, Sherman FT. Managed Medicare: an overview for the primary care physician. Geriatrics. 01. 1998;53(1):57-63. quiz 4. Not eligible outcomes. [pmid: 9442764].
355 Collins TCESKDSJTBCOESCSRSESEKE. Peripheral arterial disease is associated with higher rates of hip bone loss and increased fracture risk in older men. Circulation. 05. 5. 2009;119(17):2305-12. Not eligible outcomes. [pmid: 19380619].
356 Cologne JB, Cologne JB. Re: “when is baseline adjustment useful in analyses of change? An example with education and cognitive change”.[comment]. American Journal of Epidemiology. 12. 1. 2006;164(11):1138-9. author reply 9–40. Not eligible outcomes. [pmid: 17043080].
357 Congdon N, Broman KW, Lai H, et al. Cortical, but not posterior subcapsular, cataract shows significant familial aggregation in an older population after adjustment for possible shared environmental factors. Ophthalmology. 01. 2005;112(1):73-7. Not eligible outcomes. [pmid: 15629823].
358 Congdon P. Modelling frailty in area mortality. Stat Med. 09. 15. 1995;14(17):1859-74. Not eligible outcomes. [pmid: 8532980].
359 Consortium LWGftL, Belle SH, Chapman W, et al. Relationship of body mass index with demographic and clinical characteristics in the Longitudinal Assessment of Bariatric Surgery (LABS). Surgery for Obesity & Related Diseases. 07–08. 2008;4(4):474-80. Not eligible outcomes. [pmid: 18514583].
360 Conwell Y. Suicide among elderly persons. Psychiatr Serv. 06. 1995;46(6):563-4. Not eligible outcomes. [pmid: 7640996].
361 Coogan PF, Palmer JR, O’Connor GT, et al. Body mass index and asthma incidence in the Black Women’s Health Study.[see comment]. Journal of Allergy & Clinical Immunology. 01. 2009;123(1):89-95. Not eligible outcomes. [pmid: 18980776].
362 Cook SE, Marsiske M, McCoy KJ. The use of the Modified Telephone Interview for Cognitive Status (TICS-M) in the detection of amnestic mild cognitive impairment. Journal of Geriatric Psychiatry & Neurology. 06. 2009;22(2):103-9. Not eligible outcomes. [pmid: 19417219].
363 Cooke CR, Shah CV, Gallop R, et al. A simple clinical predictive index for objective estimates of mortality in acute lung injury. Crit Care Med. 06. 2009;37(6):1913-20. Not eligible outcome. [pmid: 19384214].
364 Copeland JR. Prevalence of depressive illness in the elderly community. J R Coll Gen Pract Occas Pap. 09. 1987;(36):5-7. discussion-8. Not eligible outcomes. [pmid: 1345613].
365 Copeland LA, Zeber JE, Rosenheck RA, et al. Unforeseen inpatient mortality among veterans with schizophrenia. Med Care. 02. 2006;44(2):110-6. Not elgible target population. [pmid: 16434909].
366 Corcoran TB, O’Neill MA, Webb SA, et al. Prevalence of vitamin deficiencies on admission: relationship to hospital mortality in critically ill patients. Anaesth Intensive Care. 03. 2009;37(2):254-60. Not eligible outcomes. [pmid: 19400489].
367 Corder EH, Basun H, Fratiglioni L, et al. Inherited frailty. ApoE alleles determine survival after a diagnosis of heart disease or stroke at ages 85+. Ann N Y Acad Sci. 06. 2000;908:295-8. Not eligible outcomes. [pmid: 10911969].
368 Corder LS, Woodbury MA, Manton KG. Proxy response patterns among the aged: effects on estimates of health status and medical care utilization from the 1982–1984 long-term care surveys. J Clin Epidemiol. 02. 1996;49(2):173-82. Not eligible outcomes. [pmid: 8606318].
369 Corey-Bloom J, Galasko D, Hofstetter CR, et al. Clinical features distinguishing large cohorts with possible AD, probable AD, and mixed dementia. Journal of the American Geriatrics Society. 01. 1993;41(1):31-7. Not eligible outcomes. [pmid: 8418119].
370 Corrada MM, Brookmeyer R, Berlau D, et al. Prevalence of dementia after age 90: results from the 90+ study. Neurology. 07. 29. 2008;71(5):337-43. Not eligible outcomes. [pmid: 18596243].
371 Corrada MM, Kawas CH, Mozaffar F, et al. Association of body mass index and weight change with all-cause mortality in the elderly. American Journal of Epidemiology. 05. 15. 2006;163(10):938-49. Not eligible exposure. [pmid: 16641311].
372 Corser WD. The perceptions of older veterans concerning their postdischarge outcome experiences. Appl Nurs Res. 05. 2006;19(2):63-9. Not elgible target population. [pmid: 16728289].
373 Corti MC, Guralnik JM, Salive ME, et al. Clarifying the direct relation between total cholesterol levels and death from coronary heart disease in older persons. Ann Intern Med. 05. 15. 1997;126(10):753-60. Not eligible outcomes. [pmid: 9148647].
374 Costa AJ, Gerson LW. Tetanus immunization status and predictors of immunity in older family practice outpatients. J Am Board Fam Pract. 07–09. 1998;11(4):315-7. Not eligible outcomes. [pmid: 9719354].
375 Cote V. Are your residents safe in their beds?. Director. Summer. 2004;12(3):166-8. Not eligible outcomes. [pmid: 15323299].
376 Counsell SR, Callahan CM, Buttar AB, et al. Geriatric Resources for Assessment and Care of Elders (GRACE): a new model of primary care for low-income seniors. Journal of the American Geriatrics Society. 07. 2006;54(7):1136-41. Not eligible outcomes. [pmid: 16866688].
377 Covinsky KE, Newcomer R, Fox P, et al. Patient and caregiver characteristics associated with depression in caregivers of patients with dementia. J Gen Intern Med. 12. 2003;18(12):1006-14. Not eligible outcomes. [pmid: 14687259].
378 Coward RT, Horne C, Peek CW. Predicting nursing home admissions among incontinent older adults: a comparison of residential differences across six years. Gerontologist. 12. 1995;35(6):732-43. Not eligible outcomes. [pmid: 8557201].
379 Cowie MR, Wood DA, Coats AJ, et al. Incidence and aetiology of heart failure; a population-based study. Eur Heart J. 03. 1999;20(6):421-8. Not eligible outcome. [pmid: 10213345].
380 Craig JC, Barratt A, Cumming R, et al. Feasibility study of the early detection and treatment of renal disease by mass screening. Intern Med J. 01–02. 2002;32(1–2):6-14. Not eligible outcomes. [pmid: 11783681].
381 Craig KW, Zweig SC. Evaluation of the elderly driver. Mo Med. 01–02. 2007;104(1):73-6. Not eligible outcomes. [pmid: 17410830].
382 Cravens DD, Mehr DR, Campbell JD, et al. Home-based comprehensive assessment of rural elderly persons: the CARE project. J Rural Health. Fall. 2005;21(4):322-8. Not eligible outcomes. [pmid: 16294655].
383 Cremieux PY, Meilleur MC, Ouellette P, et al. Public and private pharmaceutical spending as determinants of health outcomes in Canada. Health Econ. 02. 2005;14(2):107-16. Not eligible outcomes. [pmid: 15386658].
384 Crews JE, Campbell VA. Vision impairment and hearing loss among community-dwelling older Americans: implications for health and functioning. Am J Public Health. 05. 2004;94(5):823-9. Not eligible outcomes. [pmid: 15117707].
385 Cricco M, Simonsick EM, Foley DJ. The impact of insomnia on cognitive functioning in older adults.[see comment]. Journal of the American Geriatrics Society. 09. 2001;49(9):1185-9. Not eligible outcomes. [pmid: 11559377].
386 Crimmins E, Saito Y. Getting better and getting worse: Transitions in functional status among older Americans. Journal of Aging & Health. 1993;5(1):3-36. Not eligible outcomes.
387 Crogan NL, Alvine C. Testing of the Individual Nutrition Rx assessment process among nursing home residents. Appl Nurs Res. 05. 2006;19(2):102-4. Not eligible target population. [pmid: 16728294].
388 Crogan NL, Corbett CF, Short RA. The minimum data set: predicting malnutrition in newly admitted nursing home residents. Clin Nurs Res. 08. 2002;11(3):341-53. Not eligible target population. [pmid: 12180644].
389 Crogan NL, Shultz JA, Adams CE, et al. Barriers to nutrition care for nursing home residents. J Gerontol Nurs. 12. 2001;27(12):25-31. Not eligible target population. [pmid: 11820531].
390 Crossett JHW. The best is yet to be: preventing, detecting, and treating depression in older women. Journal of the American Medical Womens Association. 2004;59(3):210-5. Not eligible outcomes.
391 Cruickshanks KJ, Tweed TS, Wiley TL, et al. The 5-year incidence and progression of hearing loss: the epidemiology of hearing loss study. Archives of Otolaryngology -- Head & Neck Surgery. 10. 2003;129(10):1041-6. Not eligible outcomes. [pmid: 14568784].
392 Cruickshanks KJ, Wiley TL, Tweed TS, et al. Prevalence of hearing loss in older adults in Beaver Dam, Wisconsin. The Epidemiology of Hearing Loss Study. American Journal of Epidemiology. 11. 1. 1998;148(9):879-86. Not eligible outcomes. [pmid: 9801018].
393 Crum RM, Storr CL, Chan YF, et al. Sleep disturbance and risk for alcohol-related problems. American Journal of Psychiatry. 07. 2004;161(7):1197-203. Not eligible outcomes. [pmid: 15229051].
394 Crystal S, Johnson RW, Harman J, et al. Out-of-pocket health care costs among older Americans. J Gerontol B Psychol Sci Soc Sci. 01. 2000;55(1):S51-62. Not eligible outcomes. [pmid: 10728130].
395 Culleton BF, Larson MG, Kannel WB, et al. Serum uric acid and risk for cardiovascular disease and death: the Framingham Heart Study.[see comment]. Annals of internal medicine. 07. 6. 1999;131(1):7-13. Not eligible outcomes. [pmid: 10391820].
396 Cully JA, Gfeller JD, Heise RA, et al. Geriatric depression, medical diagnosis, and functional recovery during acute rehabilitation. Arch Phys Med Rehabil. 12. 2005;86(12):2256-60. Not eligible target population. [pmid: 16344020].
397 Culp KR, Cacchione PZ, Culp KR, et al. Nutritional status and delirium in long-term care elderly individuals. Applied Nursing Research. 05. 2008;21(2):66-74. Not eligible target population. [pmid: 18457745].
398 Currie MS, Rao MK, Blazer DG, et al. Age and functional correlations of markers of coagulation and inflammation in the elderly: functional implications of elevated crosslinked fibrin degradation products (D-dimers). Journal of the American Geriatrics Society. 07. 1994;42(7):738-42. Not eligible outcomes. [pmid: 8014349].
399 Currow DC, Stevenson JP, Abernethy AP, et al. Prescribing in palliative care as death approaches. J Am Geriatr Soc. 04. 2007;55(4):590-5. Not eligible outcomes. [pmid: 17397439].
400 Curtis LH, Ostbye T, Sendersky V, et al. Prescription of QT-prolonging drugs in a cohort of about 5 million outpatients. Am J Med. 02. 1. 2003;114(2):135-41. Not eligible outcomes. [pmid: 12586234].
401 Dalton DS, Cruickshanks KJ, Klein BE, et al. The impact of hearing loss on quality of life in older adults. Gerontologist. 10. 2003;43(5):661-8. Not eligible outcomes. [pmid: 14570962].
402 Dalton DS, Cruickshanks KJ, Klein R, et al. Association of NIDDM and hearing loss.[see comment]. Diabetes Care. 09. 1998;21(9):1540-4. Not eligible outcomes. [pmid: 9727906].
403 Daltroy LH, Logigian M, Iversen MD, et al. Does musculoskeletal function deteriorate in a predictable sequence in the elderly. Arthritis Care Res. 09. 1992;5(3):146-50. Not eligible outcomes. [pmid: 1457489].
404 Dam TT, Ewing S, Ancoli-Israel S, et al. Association between sleep and physical function in older men: the osteoporotic fractures in men sleep study. J Am Geriatr Soc. 09. 2008;56(9):1665-73. Not eligible outcomes. [pmid: 18759758].
405 Danaceau P. Prevention drives care management strategies for Medicare HMOs. Health Syst Lead. 06. 1995;2(5):4-10. Not eligible outcomes.
406 Danielson ME, Justice AC. Veterans Aging Cohort Study (VACS) meeting summary. Journal of Clinical Epidemiology. 12. 2001;54(Suppl 1):S9-11. Not eligible outcomes. [pmid: 11750203].
407 Danner DD, Snowdon DA, Friesen WV. Positive emotions in early life and longevity: findings from the nun study. Journal of Personality & Social Psychology. 05. 2001;80(5):804-13. Not eligible outcomes. [pmid: 11374751].
408 Datto CJ, Thompson R, Knott K, et al. Older adult report of change in depressive symptoms as a treatment decision tool. J Am Geriatr Soc. 04. 2006;54(4):627-31. Not eligible outcomes. [pmid: 16686873].
409 Davey A, Halverson CF Jr, Zonderman AB, et al. Change in depressive symptoms in the Baltimore longitudinal study of aging. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. 11. 2004;59(6):P270-7. Not eligible exposure.
410 Davidson BR, Neoptolemos JP, Carr-Locke DL. Endoscopic sphincterotomy for common bile duct calculi in patients with gall bladder in situ considered unfit for surgery. Gut. 01. 1988;29(1):114-20. Not eligible outcomes. [pmid: 3343004].
411 Davidson J, Getz M. Nutrition screening and assessment of anthropometry and bioelectrical impedance in the frail elderly: a clinical appraisal of methodology in a clinical setting. Journal of nutrition for the elderly. 2004;23(4):47-63. Not eligible outcomes. [pmid: 15149940].
412 Daviglus ML, Liu K, Yan LL, et al. Body mass index in middle age and health-related quality of life in older age: the Chicago heart association detection project in industry study. Archives of Internal Medicine. 11. 10. 2003;163(20):2448-55. Not eligible exposure. [pmid: 14609781].
413 Dawson DA. Alcohol consumption, alcohol dependence, and all-cause mortality. [erratum appears in Alcohol Clin Exp Res 2000 Mar; 24(3):395]. Alcoholism: Clinical & Experimental Research. 01. 2000;24(1):72-81. Not eligible outcomes.
414 de Carle AJ, Kohn R. Risk factors for falling in a psychogeriatric unit. Int J Geriatr Psychiatry. 08. 2001;16(8):762-7. Not eligible outcomes. [pmid: 11536342].
415 de Gramont A, Buyse M, Abrahantes JC, et al. Reintroduction of oxaliplatin is associated with improved survival in advanced colorectal cancer. J Clin Oncol. 08. 1. 2007;25(22):3224-9. Not eligible outcomes. [pmid: 17664470].
416 de Jong FJ, Masaki K, Chen H, et al. Thyroid function, the risk of dementia and neuropathologic changes: the Honolulu-Asia aging study. Neurobiology of aging. 04. 2009;30(4):600-6. Not eligible exposure. [pmid: 17870208].
417 De Lepeleire J, Iliffe S, Mann E, et al. Frailty: an emerging concept for general practice. Br J Gen Pract. 05. 2009;59(562):e177-82. Not eligible outcomes. [pmid: 19401013].
418 de Lissovoy G, Stier DM, Ciesla G, et al. Economic implications of nesiritide versus dobutamine in the treatment of patients with acutely decompensated congestive heart failure. Am J Cardiol. 09. 1. 2003;92(5):631-3. Not eligible outcomes. [pmid: 12943895].
419 Dellefield ME. Implementation of the resident assessment instrument/minimum data set in the nursing home as organization: implications for quality improvement in RN clinical assessment. Geriatr Nurs. 11–12. 2007;28(6):377-86. Not eligible target population. [pmid: 18068821].
420 Delmonico MJ, Harris TB, Lee JS, et al. Alternative definitions of sarcopenia, lower extremity performance, and functional impairment with aging in older men and women. J Am Geriatr Soc. 05. 2007;55(5):769-74. Not eligible outcomes. [pmid: 17493199].
421 Denny SD, Kuchibhatla MN, Cohen HJ, et al. Impact of anemia on mortality, cognition, and function in community-dwelling elderly. American Journal of Medicine. 04. 2006;119(4):327-34. Not eligible exposure. [pmid: 16564775].
422 Denti L, Annoni V, Cattadori E, et al. Insulin-like growth factor 1 as a predictor of ischemic stroke outcome in the elderly. Am J Med. 09. 1. 2004;117(5):312-7. Not eligible outcomes. [pmid: 15336580].
423 Denton FT, Gafni A, Spencer BG. Exploring the effects of population change on the costs of physician services. J Health Econ. 09. 2002;21(5):781-803. Not eligible outcomes. [pmid: 12349882].
424 Depp CA, Cain AE, Palmer BW, et al. Assessment of medication management ability in middle-aged and older adults with bipolar disorder. J Clin Psychopharmacol. 04. 2008;28(2):225-9. Not eligible outcomes. [pmid: 18344736].
425 Derby CA, Barbour MM, Hume AL, et al. Drug therapy and prevalence of erectile dysfunction in the Massachusetts Male Aging Study cohort. Pharmacotherapy. 06. 2001;21(6):676-83. Not eligible outcomes. [pmid: 11401181].
426 Desquilbet L, Jacobson LP, Fried LP, et al. HIV-1 infection is associated with an earlier occurrence of a phenotype related to frailty. J Gerontol A Biol Sci Med Sci. 11. 2007;62(11):1279-86. Not eligible exposure. [pmid: 18000149].
427 Desquilbet L, Margolick JB, Fried LP, et al. Relationship between a frailty-related phenotype and progressive deterioration of the immune system in HIV-infected men. J Acquir Immune Defic Syndr. 03. 1. 2009;50(3):299-306. Not eligible outcomes. [pmid: 19194312].
428 DeVita MV, Rasenas LL, Bansal M, et al. Assessment of renal osteodystrophy in hemodialysis patients. Medicine. 09. 1992;71(5):284-90. Not eligible outcomes. [pmid: 1522804].
429 Devitt R, Colantonio A, Dawson D, et al. Prediction of long-term occupational performance outcomes for adults after moderate to severe traumatic brain injury. Disabil Rehabil. 05. 15. 2006;28(9):547-59. Not eligible outcomes. [pmid: 16690584].
430 DeVore PA. Prevalence of olfactory dysfunction, hearing deficit, and cognitive dysfunction among elderly patients in a suburban family practice. South Med J. 09. 1992;85(9):894-6. Not eligible outcomes. [pmid: 1523449].
431 DeWitte SN, Wood JW. Selectivity of black death mortality with respect to preexisting health. Proc Natl Acad Sci U S A. 02. 5. 2008;105(5):1436-41. Not eligible outcomes. [pmid: 18227518].
432 Dexter PR, Wolinsky FD, Gramelspacher GP, et al. Opportunities for advance directives to influence acute medical care. Journal of Clinical Ethics. 2003;14(3):173-82. Not eligible target population. [pmid: 14740352].
433 Dharmarajan TS, Avula S, Norkus EP. Anemia increases risk for falls in hospitalized older adults: an evaluation of falls in 362 hospitalized, ambulatory, long-term care, and community patients. J Am Med Dir Assoc. 06. 2006;7(5):287-93. Not eligible target population. [pmid: 16765864].
434 Di Serio C. The protective impact of a covariate on competing failures with an example from a bone marrow transplantation study. Lifetime Data Anal. 1997;3(2):99-122. Not eligible outcomes. [pmid: 9384617].
435 Diamond PT, Gale SD, Evans BA. Relationship of initial hematocrit level to discharge destination and resource utilization after ischemic stroke: a pilot study. Arch Phys Med Rehabil. 07. 2003;84(7):964-7. Not eligible outcomes. [pmid: 12881817].
436 Diez Roux AV, Chambless L, Merkin SS, et al. Socioeconomic disadvantage and change in blood pressure associated with aging. Circulation. 08. 6. 2002;106(6):703-10. Not eligible outcomes. [pmid: 12163431].
437 DiFronzo LA, Yamin N, Patel K, et al. Benefits of early feeding and early hospital discharge in elderly patients undergoing open colon resection. J Am Coll Surg. 11. 2003;197(5):747-52. Not eligible outcomes. [pmid: 14585408].
438 Dillon CF, Hirsch R, Rasch EK, et al. Symptomatic hand osteoarthritis in the United States: prevalence and functional impairment estimates from the third U.S. National Health and Nutrition Examination Survey, 1991–1994. Am J Phys Med Rehabil. 01. 2007;86(1):12-21. Not eligible outcome. [pmid: 17304684].
439 Ding J, Visser M, Kritchevsky SB, et al. The association of regional fat depots with hypertension in older persons of white and African American ethnicity. American Journal of Hypertension. 10. 2004;17(10):971-6. Not eligible outcomes. [pmid: 15485762].
440 Dobie SA, Baldwin LM, Dominitz JA, et al. Completion of therapy by Medicare patients with stage III colon cancer. J Natl Cancer Inst. 05. 3. 2006;98(9):610-9. Not eligible outcomes. [pmid: 16670386].
441 Doblhammer G, Oeppen J. Reproduction and longevity among the British peerage: the effect of frailty and health selection. Proc Biol Sci. 08. 7. 2003;270(1524):1541-7. Not eligible outcomes. [pmid: 12908973].
442 Dobscha SK, Corson K, Perrin NA, et al. Collaborative care for chronic pain in primary care: a cluster randomized trial. JAMA. 03. 25. 2009;301(12):1242-52. Not eligible outcomes. [pmid: 19318652].
443 Dokhi M, Ohtaki M, Hiyama E. A cure Weibull gamma-frailty survival model and its application to exploring the prognosis factors of neuroblastoma. Hiroshima J Med Sci. 03. 2009;58(1):25-35. Not eligible outcomes. [pmid: 19400554].
444 Dolejs J. Theory of the age dependence of mortality from congenital defects. Mech Ageing Dev. 10. 2001;122(15):1865-85. Not eligible outcomes. [pmid: 11557286].
445 Dominick KL, Ahern FM, Gold CH, et al. Health-related quality of life among older adults with arthritis. Health Qual Life Outcomes. 2004;2:5. Not eligible outcomes. [pmid: 14720300].
446 Donini LM, De Felice MR, Cannella C. Nutritional status determinants and cognition in the elderly. Archives of Gerontology & Geriatrics. 2007;44(Suppl 1):143-53. Not eligible outcomes. [pmid: 17317448].
447 Donini LM, Savina C, Ricciardi LM, et al. Predicting the outcome of artificial nutrition by clinical and functional indices. Nutrition. 01. 2009;25(1):11-9. Not eligible outcomes. [pmid: 18848432].
448 Donini LM, Savina C, Rosano A, et al. MNA predictive value in the follow-up of geriatric patients. J Nutr Health Aging. 2003;7(5):282-93. Not eligible outcomes. [pmid: 12917741].
449 Dorfman RA, Lubben JE, Mayer-Oakes A, et al. Screening for depression among a well elderly population. Soc Work. 05. 1995;40(3):295-304. Not eligible outcomes. [pmid: 7761915].
450 Dornberger S. Insomnia: definition an prevalence in the elderly. Director. Winter. 2008;16(1):10-2. Not eligible outcomes.
451 Douris K, Pritchard M. When you suspect elder abuse. Adv Nurse Pract. 04. 1999;7(4):22. Not eligible outcomes. [pmid: 10382380].
452 Dowd JB, Haan MN, Blythe L, et al. Socioeconomic gradients in immune response to latent infection. American Journal of Epidemiology. 01. 1. 2008;167(1):112-20. Not eligible outcomes. [pmid: 17873099].
453 Drame M, Jovenin N, Novella JL, et al. Predicting early mortality among elderly patients hospitalised in medical wards via emergency department: the SAFES cohort study. J Nutr Health Aging. 10. 2008;12(8):599-604. Not eligible target population. [pmid: 18810299].
454 Drinka PJ, Krause PF, Nest LJ, et al. Determinants of vitamin D levels in nursing home residents. J Am Med Dir Assoc. 02. 2007;8(2):76-9. Not eligible target population. [pmid: 17289535].
455 Drummond MF, Sculpher MJ, Torrance GW, et al. Methods for the Economic Evaluation of Health Care Programmes. 3. Oxford. Oxford University Press. 2005. Not eligible outcomes.
456 Dubuc N, Haley S, Ni P, et al. Function and disability in late life: comparison of the Late-Life Function and Disability Instrument to the Short-Form-36 and the London Handicap Scale. Disabil Rehabil. 03. 18. 2004;26(6):362-70. Not eligible population. [pmid: 15204488].
457 Dudgeon BJ, Hoffman JM, Ciol MA, et al. Managing activity difficulties at home: a survey of Medicare beneficiaries. Arch Phys Med Rehabil. 07. 2008;89(7):1256-61. Not eligible outcomes. [pmid: 18534553].
458 Duh MS, Mody SH, Lefebvre P, et al. Anaemia and the risk of injurious falls in a community-dwelling elderly population. Drugs Aging. 2008;25(4):325-34. Not eligible outcomes. [pmid: 18361542].
459 Dulisse B. Older drivers and risk to other road users. Accid Anal Prev. 09. 1997;29(5):573-82. Not eligible outcomes. [pmid: 9316706].
460 Dumurgier J, Elbaz A, Ducimetiere P, et al. Slow walking speed and cardiovascular death in well functioning older adults: prospective cohort study. BMJ. 2009;339:b4460. Not eligible outcomes. [pmid: 19903980].
461 Duncan HD, Hodgkinson L, Deakin M, et al. The safety of diagnostic and therapeutic ERCP as a daycase procedure with a selective admission policy. Eur J Gastroenterol Hepatol. 09. 1997;9(9):905-8. Not eligible outcomes. [pmid: 9355791].
462 Duncan PW, Bode RK, Min Lai S, et al. Rasch analysis of a new stroke-specific outcome scale: the Stroke Impact Scale. Arch Phys Med Rehabil. 07. 2003;84(7):950-63. Not eligible outcomes. [pmid: 12881816].
463 Duncan PW, Lai SM, Tyler D, et al. Evaluation of proxy responses to the Stroke Impact Scale. Stroke. 11. 2002;33(11):2593-9. Not eligible outcomes. [pmid: 12411648].
464 Duncan RP, Coward RT, Gilbert GH. Rural-urban comparisons of age and health at the time of nursing home admission. J Rural Health. Spring. 1997;13(2):118-25. Not eligible target population. [pmid: 10169318].
465 Dunlop DD, Hughes SL, Edelman P, et al. Impact of joint impairment on disability-specific domains at four years. Journal of Clinical Epidemiology. 12. 1998;51(12):1253-61. Not eligible outcomes. [pmid: 10086817].
466 Dunlop DD, Hughes SL, Manheim LM. Disability in activities of daily living: patterns of change and a hierarchy of disability. American Journal of Public Health. 03. 1997;87(3):378-83. Not eligible outcomes. [pmid: 9096537].
467 Dunlop DD, Semanik P, Song J, et al. Risk factors for functional decline in older adults with arthritis. Arthritis Rheum. 04. 2005;52(4):1274-82. Not eligible target population. [pmid: 15818691].
468 Dunson DB, Chen Z. Selecting factors predictive of heterogeneity in multivariate event time data. Biometrics. 06. 2004;60(2):352-8. Not eligible outcomes. [pmid: 15180660].
469 Dupee R, Halpern R. Identifying, assessing and managing high-risk patients under Medicare risk contracts. J Med Pract Manage. 05–06. 2001;16(6):321-5. Not eligible outcomes. [pmid: 11497315].
470 Dupre ME, Franzese AT, Parrado EA. Religious attendance and mortality: implications for the black-white mortality crossover. Demography. 02. 2006;43(1):141-64. Not eligble outcomes. [pmid: 16579212].
471 Dupre ME, Gu D, Warner DF, et al. Frailty and type of death among older adults in China: prospective cohort study. BMJ. 2009;338:b1175. Not eligible population. [pmid: 19359289].
472 Duthie E, Mark D, Tresch D, et al. Utilization of cardiopulmonary resuscitation in nursing homes in one community: rates and nursing home characteristics. J Am Geriatr Soc. 04. 1993;41(4):384-8. Not eligible target population. [pmid: 8463524].
473 Dyeson TB, Murphy J, Stryker K. Demographic and psychosocial characteristics of cognitively-intact chronically Ill elders receiving home health services. Home Health Care Serv Q. 1999;18(2):1-25. Not eligible outcomes. [pmid: 11066726].
474 Dziura J, Mendes de Leon C, Kasl S, et al. Can physical activity attenuate aging-related weight loss in older people? The Yale Health and Aging Study, 1982–1994. American Journal of Epidemiology. 04. 15. 2004;159(8):759-67. Not eligible exposure. [pmid: 15051585].
475 Edwards ER, Lindquist K, Yaffe K. Clinical profile and course of cognitively normal patients evaluated in memory disorders clinics. Neurology. 05. 11. 2004;62(9):1639-42. Not eligible outcomes. [pmid: 15136703].
476 Edwards MS, Craven TE, Burke GL, et al. Renovascular disease and the risk of adverse coronary events in the elderly: a prospective, population-based study. Arch Intern Med. 01. 24. 2005;165(2):207-13. Not eligible outcomes. [pmid: 15668368].
477 Egan KM, Signorello LB, Munro HM, et al. Vitamin D insufficiency among African-Americans in the southeastern United States: implications for cancer disparities (United States). Cancer Causes & Control. 06. 2008;19(5):527-35. Not eligible outcomes. [pmid: 18219582].
478 Egede LE. Major depression in individuals with chronic medical disorders: prevalence, correlates and association with health resource utilization, lost productivity and functional disability. Gen Hosp Psychiatry. 09–10. 2007;29(5):409-16. Not eligible outcomes. [pmid: 17888807].
479 Eggermont LH, Bean JF, Guralnik JM, et al. Comparing pain severity versus pain location in the MOBILIZE Boston study: chronic pain and lower extremity function. J Gerontol A Biol Sci Med Sci. 07. 2009;64(7):763-70. Not eligible outcomes. [pmid: 19228782].
480 Ehreke L, Luppa M, Luck T, et al. Is the clock drawing test appropriate for screening for mild cognitive impairment?--Results of the German study on Ageing, Cognition and Dementia in Primary Care Patients (AgeCoDe). Dement Geriatr Cogn Disord. 2009;28(4):365-72. Not eligible outcomes. [pmid: 19887799].
481 Eigenbrodt ML, Bursac Z, Rose KM, et al. Common carotid arterial interadventitial distance (diameter) as an indicator of the damaging effects of age and atherosclerosis, a cross-sectional study of the Atherosclerosis Risk in Community Cohort Limited Access Data (ARICLAD), 1987–89. Cardiovascular Ultrasound. 2006;4:1. Not eligible outcomes. [pmid: 16390545].
482 Eisen SA, Goldberg J, True WR, et al. A co-twin control study of the effects of the Vietnam War on the self-reported physical health of veterans. American Journal of Epidemiology. 07. 1. 1991;134(1):49-58. Not eligible outcomes. [pmid: 1853860].
483 Eisner MD, Iribarren C, Yelin EH, et al. Pulmonary function and the risk of functional limitation in chronic obstructive pulmonary disease. Am J Epidemiol. 05. 1. 2008;167(9):1090-101. Not eligible outcomes. [pmid: 18343879].
484 Eklund SA, Burt BA. Risk factors for total tooth loss in the United States; longitudinal analysis of national data. Journal of Public Health Dentistry. 1994;54(1):5-14. Not eligible outcomes. [pmid: 8164192].
485 Elhai JD, Grubaugh AL, Richardson JD, et al. Outpatient medical and mental healthcare utilization models among military veterans: results from the 2001 National Survey of Veterans. J Psychiatr Res. 08. 2008;42(10):858-67. Not eligible outcomes. [pmid: 18005993].
486 Elias MF, Sullivan LM, D’Agostino RB, et al. Framingham stroke risk profile and lowered cognitive performance. Stroke. 02. 2004;35(2):404-9. Not eligible exposure. [pmid: 14726556].
487 Elie M, Boss K, Cole MG, et al. A retrospective, exploratory, secondary analysis of the association between antipsychotic use and mortality in elderly patients with delirium. International Psychogeriatrics. 06. 2009;21(3):588-92. Not eligible outcomes. [pmid: 19368755].
488 Elkins JS, Johnston SC, Ziv E, et al. Methylenetetrahydrofolate reductase C677T polymorphism and cognitive function in older women. American Journal of Epidemiology. 09. 15. 2007;166(6):672-8. Not eligible outcomes. [pmid: 17638709].
489 Elkins JS, Knopman DS, Yaffe K, et al. Cognitive function predicts first-time stroke and heart disease. Neurology. 05. 24. 2005;64(10):1750-5. Not eligible outcomes. [pmid: 15911803].
490 Elkins JS, O’Meara ES, Longstreth WT Jr, et al. Stroke risk factors and loss of high cognitive function. Neurology. 09. 14. 2004;63(5):793-9. Not eligible exposure. [pmid: 15365125].
491 Ell K, Unutzer J, Aranda M, et al. Routine PHQ-9 depression screening in home health care: depression, prevalence, clinical and treatment characteristics and screening implementation. Home Health Care Serv Q. 2005;24(4):1-19. Not eligible outcomes. [pmid: 16446263].
492 El-Solh AA, Pietrantoni C, Bhat A, et al. Microbiology of severe aspiration pneumonia in institutionalized elderly. Am J Respir Crit Care Med. 06. 15. 2003;167(12):1650-4. Not eligible outcomes. [pmid: 12689848].
493 Endeshaw Y. Correlates of self-reported nocturia among community-dwelling older adults. J Gerontol A Biol Sci Med Sci. 01. 2009;64(1):142-8. Not eligible outcomes. [pmid: 19164272].
494 Endeshaw YW, Bloom HL, Bliwise DL, et al. Sleep-disordered breathing and cardiovascular disease in the Bay Area Sleep Cohort. Sleep. 04. 1. 2008;31(4):563-8. Not eligible outcomes. [pmid: 18457244].
495 Endeshaw YW, Ouslander JG, Schnelle JF, et al. Polysomnographic and clinical correlates of behaviorally observed daytime sleep in nursing home residents. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 01. 2007;62(1):55-61. Not eligible target population.
496 Engelhart MJ, Geerlings MI, Meijer J, et al. Inflammatory proteins in plasma and the risk of dementia: the rotterdam study. Arch Neurol. 05. 2004;61(5):668-72. Not eligible target population. [pmid: 15148142].
497 Engle VF, Graney MJ. Predicting outcomes of nursing home residents: death and discharge home. J Gerontol. 09. 1993;48(5):S269-75. Not eligible target population. [pmid: 8366276].
498 Enright PL, Burchette RJ, Peters JA, et al. Peak flow lability: association with asthma and spirometry in an older cohort. Chest. 10. 1997;112(4):895-901. Not eligible outcomes. [pmid: 9377950].
499 Ensrud KE, Thompson DE, Cauley JA, et al. Prevalent vertebral deformities predict mortality and hospitalization in older women with low bone mass. Fracture Intervention Trial Research Group.[see comment]. Journal of the American Geriatrics Society. 03. 2000;48(3):241-9. Not eligible outcomes. [pmid: 10733048].
500 Ertel KA, Glymour MM, Glass TA, et al. Frailty modifies effectiveness of psychosocial intervention in recovery from stroke. Clin Rehabil. 06. 2007;21(6):511-22. Not eligble outcomes. [pmid: 17613582].
501 Escalante A, Lichtenstein MJ, Hazuda HP. Determinants of shoulder and elbow flexion range: results from the San Antonio Longitudinal Study of Aging. Arthritis Care Res. 08. 1999;12(4):277-86. Not eligible outcomes. [pmid: 10689992].
502 Espeland MA, Gu L, Masaki KH, et al. Association between reported alcohol intake and cognition: results from the Women’s Health Initiative Memory Study.[see comment]. American Journal of Epidemiology. 02. 1. 2005;161(3):228-38. Not eligible outcomes. [pmid: 15671255].
503 Espino DV, Lichtenstein MJ, Palmer RF, et al. Ethnic differences in mini-mental state examination (MMSE) scores: where you live makes a difference. J Am Geriatr Soc. 05. 2001;49(5):538-48. Not eligible outcomes. [pmid: 11380745].
504 Espino DV, Palmer RF, Miles TP, et al. Prevalence and severity of urinary incontinence in elderly Mexican-American women. Journal of the American Geriatrics Society. 11. 2003;51(11):1580-6. Not eligible outcomes. [pmid: 14687387].
505 Espino DV, Palmer RF, Miles TP, et al. Prevalence, incidence, and risk factors associated with hip fractures in community-dwelling older Mexican Americans: results of the Hispanic EPESE study. Establish Population for the Epidemiologic Study for the Elderly. J Am Geriatr Soc. 10. 2000;48(10):1252-60. Not eligible outcomes. [pmid: 11037012].
506 Everitt DE, Fields DR, Soumerai SS, et al. Resident behavior and staff distress in the nursing home. J Am Geriatr Soc. 08. 1991;39(8):792-8. Not eligible target population. [pmid: 2071810].
507 Everson-Rose SA, Mendes de Leon CF, Bienias JL, et al. Early life conditions and cognitive functioning in later life. American Journal of Epidemiology. 12. 1. 2003;158(11):1083-9. Not eligible outcomes. [pmid: 14630604].
508 Fabre JM, Wood RH, Cherry KE, et al. Age-related deterioration in flexibility is associated with health-related quality of life in nonagenarians. J Geriatr Phys Ther. 2007;30(1):16-22. Not eligible target population. [pmid: 19839176].
509 Fairhall N, Aggar C, Kurrle SE, et al. Frailty Intervention Trial (FIT). BMC Geriatr. 2008;8:27. Not eligible outcomes. [pmid: 18851754].
510 Falconer JA, Naughton BJ, Strasser DC, et al. Stroke inpatient rehabilitation: a comparison across age groups. J Am Geriatr Soc. 01. 1994;42(1):39-44. Not eligible outcomes. [pmid: 8277113].
511 Fang J, Mensah GA, Croft JB, et al. Heart failure-related hospitalization in the U.S., 1979 to 2004. J Am Coll Cardiol. 08. 5. 2008;52(6):428-34. Not eligible exposure. [pmid: 18672162].
512 Fanuele J, Koval KJ, Lurie J, et al. Distal radial fracture treatment: what you get may depend on your age and address. J Bone Joint Surg Am. 06. 2009;91(6):1313-9. Not eligible outcomes. [pmid: 19487507].
513 Faulkner KA, Cauley JA, Zmuda JM, et al. Higher 1,25-dihydroxyvitamin D3 concentrations associated with lower fall rates in older community-dwelling women. Osteoporos Int. 2006;17(9):1318-28. Not eligible exposure. [pmid: 16788853].
514 Feart C, Jutand MA, Larrieu S, et al. Energy, macronutrient and fatty acid intake of French elderly community dwellers and association with socio-demographic characteristics: data from the Bordeaux sample of the Three-City Study. Br J Nutr. 11. 2007;98(5):1046-57. Not eligible outcomes. [pmid: 17532868].
515 Feinfeld DA, Guzik H, Carvounis CP, et al. Sequential changes in renal function tests in the old old: results from the Bronx Longitudinal Aging Study.[see comment]. Journal of the American Geriatrics Society. 04. 1995;43(4):412-4. Not eligible outcomes. [pmid: 7706633].
516 Feldman HA, Johannes CB, Araujo AB, et al. Low dehydroepiandrosterone and ischemic heart disease in middle-aged men: prospective results from the Massachusetts Male Aging Study. American Journal of Epidemiology. 01. 1. 2001;153(1):79-89. Not eligible outcomes. [pmid: 11159150].
517 Feldman HA, Johannes CB, Derby CA, et al. Erectile dysfunction and coronary risk factors: prospective results from the Massachusetts male aging study. Preventive medicine. 04. 2000;30(4):328-38. Not eligible outcomes. [pmid: 10731462].
518 Felson DT, Niu J, Clancy M, et al. Effect of recreational physical activities on the development of knee osteoarthritis in older adults of different weights: the Framingham Study. Arthritis Rheum. 02. 15. 2007;57(1):6-12. Not eligible outcome. [pmid: 17266077].
519 Feng L, Yap KB, Kua EH, et al. Depressive symptoms, physician visits and hospitalization among community-dwelling older adults. International Psychogeriatrics. 06. 2009;21(3):568-75. Not eligible outcomes. [pmid: 19368754].
520 Ferguson RP, O’Connor P, Crabtree B, et al. Serum albumin and prealbumin as predictors of clinical outcomes of hospitalized elderly nursing home residents. Journal of the American Geriatrics Society. 05. 1993;41(5):545-9. Not eligible target population. [pmid: 8486890].
521 Feringa HH, Bax JJ, Hoeks S, et al. A prognostic risk index for long-term mortality in patients with peripheral arterial disease. Arch Intern Med. 12. 10. 2007;167(22):2482-9. Not eligible outcomes. [pmid: 18071171].
522 Ferrara A, Barrett-Connor E, Shan J, Total LDL. HDL cholesterol decrease with age in older men and women. The Rancho Bernardo Study 1984–1994. Circulation. 07. 1. 1997;96(1):37-43. Not eligible outcomes. [pmid: 9236414].
523 Ferraro KF. Are black older adults health-pessimistic. J Health Soc Behav. 09. 1993;34(3):201-14. Not eligible outcomes. [pmid: 7989665].
524 Ferraro KF, Farmer MM. Double jeopardy to health hypothesis for African Americans: analysis and critique. Journal of Health & Social Behavior. 03. 1996;37(1):27-43. Not eligible outcomes. [pmid: 8820309].
525 Ferraro KF, Su YP, Gretebeck RJ, et al. Body mass index and disability in adulthood: a 20-year panel study. Am J Public Health. 05. 2002;92(5):834-40. Not eligible outcomes. [pmid: 11988456].
526 Ferraro KF, Wilmoth JM. Measuring morbidity: disease counts, binary variables, and statistical power. J Gerontol B Psychol Sci Soc Sci. 05. 2000;55(3):S173-89. Not eligible outcomes. [pmid: 11833985].
527 Ferrell BA, Josephson K, Norvid P, et al. Pressure ulcers among patients admitted to home care. J Am Geriatr Soc. 09. 2000;48(9):1042-7. Not eligible outcomes. [pmid: 10983902].
528 Ferrucci L, Guralnik JM, Cavazzini C, et al. The frailty syndrome: a critical issue in geriatric oncology. Crit Rev Oncol Hematol. 05. 2003;46(2):127-37. Not eligible outcomes. [pmid: 12711358].
529 Ferrucci L, Izmirlian G, Leveille S, et al. Smoking, physical activity, and active life expectancy. American Journal of Epidemiology. 04. 1. 1999;149(7):645-53. Not eligible outcomes. [pmid: 10192312].
530 Feuerstein M, Luff GM, Harrington CB, et al. Pattern of workplace disputes in cancer survivors: a population study of ADA claims. J Cancer Surviv. 09. 2007;1(3):185-92. Not eligible outcomes. [pmid: 18648969].
531 Field TS, Mazor KM, Briesacher B, et al. Adverse drug events resulting from patient errors in older adults. J Am Geriatr Soc. 02. 2007;55(2):271-6. Not eligible outcomes. [pmid: 17302666].
532 Fields SD, Fulop G, Sachs CJ, et al. Usefulness of the Neurobehavioral Cognitive Status Examination in the hospitalized elderly. Int Psychogeriatr. Summer. 1992;4(1):93-102. Not eligible outcomes. [pmid: 1391676].
533 Fillenbaum GG, Hanlon JT, Landerman LR, et al. Impact of estrogen use on decline in cognitive function in a representative sample of older community-resident women. American Journal of Epidemiology. 01. 15. 2001;153(2):137-44. Not eligible outcomes. [pmid: 11159158].
534 Fillenbaum GG, Heyman A, Huber MS, et al. The prevalence and 3-year incidence of dementia in older Black and White community residents. J Clin Epidemiol. 07. 1998;51(7):587-95. Not eligible outcomes. [pmid: 9674666].
535 Fillenbaum GG, Landerman LR, Blazer DG, et al. The relationship of APOE genotype to cognitive functioning in older African-American and Caucasian community residents. Journal of the American Geriatrics Society. 09. 2001;49(9):1148-55. Not eligible outcomes. [pmid: 11559372].
536 Fillenbaum GG, Landerman LR, Simonsick EM. Equivalence of two screens of cognitive functioning: the Short Portable Mental Status Questionnaire and the Orientation-Memory-Concentration test. J Am Geriatr Soc. 12. 1998;46(12):1512-8. Not eligible outcomes. [pmid: 9848811].
537 Filleul L, Rondeau V, Vandentorren S, et al. Twenty five year mortality and air pollution: results from the French PAARC survey. Occup Environ Med. 07. 2005;62(7):453-60. Not eligible outcomes. [pmid: 15961621].
538 Fillit H. Challenges for acute care geriatric inpatient units under the present Medicare prospective payment system. J Am Geriatr Soc. 05. 1994;42(5):553-8. Not eligible outcomes. [pmid: 8176152].
539 Fillit HM, Futterman R, Orland BI, et al. Polypharmacy management in Medicare managed care: changes in prescribing by primary care physicians resulting from a program promoting medication reviews. Am J Manag Care. 05. 1999;5(5):587-94. Not eligible outcomes. [pmid: 10537865].
540 Finkel SI, Lyons JS, Anderson RL. A brief agitation rating scale (BARS) for nursing home elderly. J Am Geriatr Soc. 01. 1993;41(1):50-2. Not eligible target population. [pmid: 8418123].
541 Finkelstein FO, Afolalu B, Wuerth D, et al. The elderly patient on CAPD: helping patients cope with peritoneal dialysis. Perit Dial Int. 09–10. 2008;28(5):449-51. Not eligible outcomes. [pmid: 18708534].
542 Finn L, Young T, Palta M, et al. Sleep-disordered breathing and self-reported general health status in the Wisconsin Sleep Cohort Study. Sleep. 11. 1. 1998;21(7):701-6. Not eligible outcomes. [pmid: 11286346].
543 Fiocco M, Putter H, Van Houwelingen JC. A new serially correlated gamma-frailty process for longitudinal count data. Biostatistics. 04. 2009;10(2):245-57. Not eligible outcomes. [pmid: 18796463].
544 Firchow N. No room at the inn. Am J Nurs. 09. 2008;108(9):88. Not eligible outcomes. [pmid: 18756170].
545 Fischer HC, Funk GF, Karnell LH, et al. Associations between selected demographic parameters and dental status: potential implications for orodental rehabilitation. J Prosthet Dent. 05. 1998;79(5):526-31. Not eligible outcomes. [pmid: 9597605].
546 Fisher KM, Copenhaver V. Assessing the mental health of rural older adults in public housing facilities: a comparison of screening tools. J Gerontol Nurs. 09. 2006;32(9):26-33. Not eligible outcomes. [pmid: 16972606].
547 Fisher MN, Snih SA, Ostir GV, et al. Positive affect and disability among older Mexican Americans with arthritis. Arthritis Rheum. 02. 15. 2004;51(1):34-9. Not eligible outcomes. [pmid: 14872453].
548 Flaherty JH, Liu ML, Ding L, et al. China: the aging giant. Journal of the American Geriatrics Society. 08. 2007;55(8):1295-300. Not eligible outcomes. [pmid: 17661972].
549 Fleischman DA, Wilson RS, Schneider JA, et al. Parkinsonian signs and functional disability in old age. Exp Aging Res. 01–03. 2007;33(1):59-76. Not eligible outcomes. [pmid: 17132564].
550 Fleming DJ, Jacques PF, Tucker KL, et al. Iron status of the free-living, elderly Framingham Heart Study cohort: an iron-replete population with a high prevalence of elevated iron stores.[see comment]. American Journal of Clinical Nutrition. 03. 2001;73(3):638-46. Not eligible outcomes. [pmid: 11237943].
551 Florio ER, Hendryx MS, Jensen JE, et al. A comparison of suicidal and nonsuicidal elders referred to a community mental health center program. Suicide Life Threat Behav. Summer. 1997;27(2):182-93. Not eligible outcomes. [pmid: 9260301].
552 Foelker GA Jr, Shewchuk RM. Somatic complaints and the CES-D. J Am Geriatr Soc. 03. 1992;40(3):259-62. Not eligible outcomes. [pmid: 1538046].
553 Foley DJ, Masaki K, White L, et al. Sleep-disordered breathing and cognitive impairment in elderly Japanese-American men. Sleep. 08. 1. 2003;26(5):596-9. Not eligible exposure. [pmid: 12938814].
554 Foley DJ, Monjan A, Simonsick EM, et al. Incidence and remission of insomnia among elderly adults: an epidemiologic study of 6,800 persons over three years. Sleep. 05. 1. 1999;22(Suppl 2):S366-72. Not eligible outcomes. [pmid: 10394609].
555 Foley DJ, Monjan AA, Brown SL, et al. Sleep complaints among elderly persons: an epidemiologic study of three communities. Sleep. 07. 1995;18(6):425-32. Not eligible outcomes. [pmid: 7481413].
556 Foley DJ, Monjan AA, Izmirlian G, et al. Incidence and remission of insomnia among elderly adults in a biracial cohort. Sleep. 05. 1. 1999;22(Suppl 2):S373-8. Not eligible outcomes. [pmid: 10394610].
557 Foley DJ, Wallace RB, Eberhard J. Risk factors for motor vehicle crashes among older drivers in a rural community. J Am Geriatr Soc. 07. 1995;43(7):776-81. Not eligible outcomes. [pmid: 7602030].
558 Foley RN, Murray AM, Li S, et al. Chronic kidney disease and the risk for cardiovascular disease, renal replacement, and death in the United States Medicare population, 1998 to 1999. J Am Soc Nephrol. 02. 2005;16(2):489-95. Not eligible outcomes. [pmid: 15590763].
559 Folsom AR, French SA, Zheng W, et al. Weight variability and mortality: the Iowa Women’s Health Study. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 08. 1996;20(8):704-9. Not eligible exposure. [pmid: 8856391].
560 Fonda SJ, Herzog AR. Patterns and risk factors of change in somatic and mood symptoms among older adults. Ann Epidemiol. 08. 2001;11(6):361-8. Not eligible outcomes. [pmid: 11454494].
561 Foote JA, Giuliano AR, Harris RB. Older adults need guidance to meet nutritional recommendations. J Am Coll Nutr. 10. 2000;19(5):628-40. Not eligible outcomes. [pmid: 11022877].
562 Forbes GB, Reina JC. Adult lean body mass declines with age: some longitudinal observations. Metabolism: Clinical & Experimental. 09. 1970;19(9):653-63. Not eligible target population. [pmid: 5459997].
563 Ford AB, Mefrouche Z, Friedland RP, et al. Smoking and cognitive impairment: a population-based study.[see comment]. Journal of the American Geriatrics Society. 08. 1996;44(8):905-9. Not eligible exposure. [pmid: 8708298].
564 Ford K, Sowers M, Crutchfield M, et al. A longitudinal study of the predictors of prevalence and severity of symptoms commonly associated with menopause. Menopause. 05–06. 2005;12(3):308-17. Not eligible outcomes. [pmid: 15879920].
565 Forinash K, Meade DM. Trauma in the elderly. Emerg Med Serv. 09. 2000;29(9):79-84. 6. 8. quiz 106. Not eligible outcomes. [pmid: 11143039].
566 Foroni M, Salvioli G, Rielli R, et al. A retrospective study on heat-related mortality in an elderly population during the 2003 heat wave in Modena, Italy: the Argento Project. J Gerontol A Biol Sci Med Sci. 06. 2007;62(6):647-51. Not eligible target population. [pmid: 17595422].
567 Forrest KY, Zmuda JM, Cauley JA. Correlates of decline in lower extremity performance in older women: A 10-year follow-up study. J Gerontol A Biol Sci Med Sci. 11. 2006;61(11):1194-200. Not eligible outcomes. [pmid: 17167162].
568 Fortinsky RH, Iannuzzi-Sucich M, Baker DI, et al. Fall-risk assessment and management in clinical practice: views from healthcare providers. J Am Geriatr Soc. 09. 2004;52(9):1522-6. Not eligible outcomes. [pmid: 15341555].
569 Foster A. Are cohort mortality rates autocorrelated. Demography. 11. 1991;28(4):619-37. Not eligible outcomes. [pmid: 1769406].
570 Foster CB, Gorga D, Padial C, et al. The development and validation of a screening instrument to identify hospitalized medical patients in need of early functional rehabilitation assessment. Qual Life Res. 08. 2004;13(6):1099-108. Not eligible outcomes. [pmid: 15287276].
571 Fox KM, Reuland M, Hawkes WG, et al. Accuracy of medical records in hip fracture. Journal of the American Geriatrics Society. 06. 1998;46(6):745-50. Not eligible outcomes. [pmid: 9625191].
572 Fragoso CA, Gahbauer EA, Van Ness PH, et al. Peak expiratory flow as a predictor of subsequent disability and death in community-living older persons. J Am Geriatr Soc. 06. 2008;56(6):1014-20. Not eligible outcomes. [pmid: 18422951].
573 Frank RG, Elliott TR. Handbook of rehabilitation psychology. Washington, DC. American Psychological Association. [Internet Resource Date of Entry: 19991216]. Available at:http://content.apa.org/books/2000-05059-000. Not eligible outcomes.
574 Franklin GM, Stover BD, Turner JA, et al. Early opioid prescription and subsequent disability among workers with back injuries: the Disability Risk Identification Study Cohort. Spine (Phila Pa 1976). 01. 15. 2008;33(2):199-204. Not eligible exposure. [pmid: 18197107].
575 Franzini L, Dyer CB. Healthcare costs and utilization of vulnerable elderly people reported to Adult Protective Services for self-neglect.[see comment]. Journal of the American Geriatrics Society. 04. 2008;56(4):667-76. Not eligible outcomes. [pmid: 18284533].
576 Fraser C, McGurl J. Psychometric testing of the Americanized version of the Guy’s Neurological Disability Scale. J Neurosci Nurs. 02. 2007;39(1):13-9. Not eligible outcomes. [pmid: 17396533].
577 Frawley KA, Asmonga DD. HCFA publishes proposed rule on conditions of participation. J AHIMA. 03. 1998;69(3):12. 4. 6. Not eligible outcomes. [pmid: 10177478].
578 Freburger JK, Holmes GM, Agans RP, et al. The rising prevalence of chronic low back pain. Arch Intern Med. 02. 9. 2009;169(3):251-8. Not eligible outcomes. [pmid: 19204216].
579 Freedman VA, Aykan H, Martin LG. Another look at aggregate changes in severe cognitive impairment: further investigation into the cumulative effects of three survey design issues. J Gerontol B Psychol Sci Soc Sci. 03. 2002;57(2):S126-31. Not eligible outcomes. [pmid: 11867673].
580 Freedman VA, Martin LG. The role of education in explaining and forecasting trends in functional limitations among older Americans. Demography. 11. 1999;36(4):461-73. Not eligible outcomes. [pmid: 10604075].
581 French DD, Werner DC, Campbell RR, et al. A multivariate fall risk assessment model for VHA nursing homes using the minimum data set. J Am Med Dir Assoc. 02. 2007;8(2):115-22. Not eligible target population. [pmid: 17289542].
582 French SA, Jeffery RW, Folsom AR, et al. Weight variability in a population-based sample of older women: reliability and intercorrelation of measures. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 01. 1995;19(1):22-9. Not eligible outcomes. [pmid: 7719387].
583 Fried LP, Young Y, Rubin G, et al. Self-reported preclinical disability identifies older women with early declines in performance and early disease. Journal of Clinical Epidemiology. 09. 2001;54(9):889-901. Not eligible outcomes. [pmid: 11520648].
584 Fried TR, Mor V. Frailty and hospitalization of long-term stay nursing home residents.[see comment]. Journal of the American Geriatrics Society. 03. 1997;45(3):265-9. Not eligible population. [pmid: 9063269].
585 Friedman B, Delavan RL, Sheeran TH, et al. The effect of major and minor depression on Medicare home healthcare services use. J Am Geriatr Soc. 04. 2009;57(4):669-75. Not eligible outcomes. [pmid: 19392959].
586 Friedman B, Kane RL. HMO medical directors’ perceptions of geriatric practice in Medicare HMOs. J Am Geriatr Soc. 10. 1993;41(10):1144-9. Not eligible outcomes. [pmid: 8409163].
587 Friedman HS, Tucker JS, Schwartz JE, et al. Psychosocial and behavioral predictors of longevity. The aging and death of the “termites”. American Psychologist. 02. 1995;50(2):69-78. Not eligible outcomes. [pmid: 7879989].
588 Friedman SM, Munoz B, Rubin GS, et al. Characteristics of discrepancies between self-reported visual function and measured reading speed. Salisbury Eye Evaluation Project Team. Invest Ophthalmol Vis Sci. 04. 1999;40(5):858-64. Not eligible outcomes. [pmid: 10102282].
589 Frierson RL, Shea SJ, Shea MEC. Competence-to-stand-trial evaluations of geriatric defendants. Journal of the American Academy of Psychiatry & the Law. 2002;30(2):252-6. Not eligible outcomes. [pmid: 12108562].
590 Fries BE, Hawes C, Morris JN, et al. Effect of the National Resident Assessment Instrument on selected health conditions and problems. J Am Geriatr Soc. 08. 1997;45(8):994-1001. Not eligible target population. [pmid: 9256854].
591 Fries JF. Frailty, heart disease, and stroke: the Compression of Morbidity paradigm. Am J Prev Med. 12. 2005;29(5 Suppl 1):164-8. Secondary data analysis. [pmid: 16389144].
592 Frisard MI, Broussard A, Davies SS, et al. Aging, resting metabolic rate, and oxidative damage: results from the Louisiana Healthy Aging Study. J Gerontol A Biol Sci Med Sci. 07. 2007;62(7):752-9. Not eligible outcomes. [pmid: 17634323].
593 Froehlich TE, Robison JT, Inouye SK. Screening for dementia in the outpatient setting: the time and change test. J Am Geriatr Soc. 12. 1998;46(12):1506-11. Not eligible outcomes. [pmid: 9848810].
594 Fulk GD, Echternach JL, Nof L, et al. Clinometric properties of the six-minute walk test in individuals undergoing rehabilitation poststroke. Physiother Theory Pract. 05–06. 2008;24(3):195-204. Not eligible outcomes. [pmid: 18569856].
595 Fulton AT. Dementia screening: should we screen asymptomatic older adults. Med Health R I. 07. 2008;91(7):224-5. Not eligible outcomes. [pmid: 18705224].
596 Fung K, Krewski D, Burnett R, et al. Testing the harvesting hypothesis by time-domain regression analysis. II: covariate effects. J Toxicol Environ Health A. 07. 9–23. 2005;68(13–14):1155-65. Not eligible outcomes. [pmid: 16024494].
597 Furner SE. Chartbook on health data on older Americans: United States, 1992. Health status. Vital Health Stat. 05. 1993;3(29):3-19. Not eligible outcomes.
598 Furner SE. Chartbook on health data on older Americans: United States, 1992. Health care use and its cost. Vital Health Stat. 05. 1993;3(29):21-36. Not eligible outcomes.
599 Gabella BA, Mangione EJ, Hedegaard H, et al. Comparison of nursing home residents with and without traumatic brain injury: use of the Minimum Data Set. J Head Trauma Rehabil. 11–12. 2007;22(6):368-76. Not eligible target population. [pmid: 18025969].
600 Galanis DJ, Joseph C, Masaki KH, et al. A longitudinal study of drinking and cognitive performance in elderly Japanese American men: the Honolulu-Asia Aging Study. American Journal of Public Health. 08. 2000;90(8):1254-9. Not eligible exposure. [pmid: 10937006].
601 Galanis DJ, Petrovitch H, Launer LJ, et al. Smoking history in middle age and subsequent cognitive performance in elderly Japanese-American men. The Honolulu-Asia Aging Study. American Journal of Epidemiology. 03. 15. 1997;145(6):507-15. Not eligible exposure. [pmid: 9063340].
602 Gallagher-Thompson D, Brooks JO 3rd, Bliwise D, et al. The relations among caregiver stress, “sundowning” symptoms, and cognitive decline in Alzheimer’s disease. Journal of the American Geriatrics Society. 08. 1992;40(8):807-10. Not eligible outcomes. [pmid: 1634724].
603 Gallucci M, Ongaro F, Amici GP, et al. Frailty, disability and survival in the elderly over the age of seventy: Evidence from “The Treviso Longeva (TRELONG) Study”. Arch Gerontol Geriatr. 05–06. 2009;48(3):281-3. Not eligible outcomes. [pmid: 18367264].
604 Clinical strategies for successful aging management of geriatric syndromes. [Visual Material; Computer File Date of Entry: 19980702]. Fort Lee, N.J. Network for Continuing Medical Education. 1996. Not eligible outcomes.
605 Gammack JKMJE. Geriatric medicine. Medical clinics of North America. 769. 2006;90(5):xvii-1048. Not eligible outcomes.
606 Gandjour A. Aging diseases--do they prevent preventive health care from saving costs. Health Econ. 03. 2009;18(3):355-62. Not eligible outcomes. [pmid: 18833543].
607 Ganguli M, Reynolds CF, Gilby JE. Prevalence and persistence of sleep complaints in a rural older community sample: the MoVIES project. Journal of the American Geriatrics Society. 07. 1996;44(7):778-84. Not eligible outcomes. [pmid: 8675924].
608 Ganguli M, Rodriguez EG. Reporting of dementia on death certificates: a community study. J Am Geriatr Soc. 07. 1999;47(7):842-9. Not eligible outcomes. [pmid: 10404929].
609 Ganz DA, Wenger NS, Roth CP, et al. The effect of a quality improvement initiative on the quality of other aspects of health care: the law of unintended consequences. Med Care. 01. 2007;45(1):8-18. Not eligible outcomes. [pmid: 17279017].
610 Garand L, Mitchell AM, Dietrick A, et al. Suicide in older adults: nursing assessment of suicide risk. Issues in Mental Health Nursing. 05. 2006;27(4):355-70. Not eligible outcomes. [pmid: 16546935].
611 Gass KA, Gaustad G, Oberst MT, et al. Relocation appraisal, functional independence, morale, and health of nursing home residents. Issues Ment Health Nurs. 07–09. 1992;13(3):239-53. Not eligible target population. [pmid: 1399521].
612 Gates GA, Cobb JL, D’Agostino RB, et al. The relation of hearing in the elderly to the presence of cardiovascular disease and cardiovascular risk factors. Archives of Otolaryngology -- Head & Neck Surgery. 02. 1993;119(2):156-61. Not eligible outcomes. [pmid: 8427676].
613 Gaugler JE, Mittelman MS, Hepburn K, et al. Predictors of change in caregiver burden and depressive symptoms following nursing home admission. Psychology & Aging. 06. 2009;24(2):385-96. Not eligible target population. [pmid: 19485656].
614 Gerdes LU, Jeune B, Ranberg KA, et al. Estimation of apolipoprotein E genotype-specific relative mortality risks from the distribution of genotypes in centenarians and middle-aged men: apolipoprotein E gene is a “frailty gene,” not a “longevity gene”, Genet Epidemiol. 2000/10/03. 2000;19:202-10. Not eligible outcomes.
615 Gerdhem P, Ivaska KK, Isaksson A, et al. Associations between homocysteine, bone turnover, BMD, mortality, and fracture risk in elderly women. J Bone Miner Res. 01. 2007;22(1):127-34. Not eligible outcomes. [pmid: 17032146].
616 Gerdhem P, Ringsberg KA, Magnusson H, et al. Bone mass cannot be predicted by estimations of frailty in elderly ambulatory women. Gerontology. 05–06. 2003;49(3):168-72. Not eligible outcomes. [pmid: 12679607].
617 Gerrity MS, Gaylord S, Williams ME. Short versions of the Timed Manual Performance Test. Development, reliability, and validity. Med Care. 07. 1993;31(7):617-28. Not eligible outcomes. [pmid: 8326775].
618 Gerstorf D, Hoppmann CA, Anstey KJ, et al. Dynamic links of cognitive functioning among married couples: longitudinal evidence from the Australian Longitudinal Study of Ageing. Psychology & Aging. 06. 2009;24(2):296-309. Not eligible outcomes. [pmid: 19485649].
619 Ghali JK, Cooper R, Ford E. Trends in hospitalization rates for heart failure in the United States, 1973–1986. Evidence for increasing population prevalence. Arch Intern Med. 04. 1990;150(4):769-73. Not eligible outcomes. [pmid: 2327838].
620 Giannini R, Petazzoni E, Savorani G, et al. Outcomes from a program of home care attendance in very frail elderly subjects. Arch Gerontol Geriatr. 03–04. 2007;44(2):95-103. Not eligile outcomes. [pmid: 16750580].
621 Gill SS, Mamdani M, Naglie G, et al. A prescribing cascade involving cholinesterase inhibitors and anticholinergic drugs. Arch Intern Med. 04. 11. 2005;165(7):808-13. Not eligible outcomes. [pmid: 15824303].
622 Gill TM, Gahbauer EA. Overestimation of chronic disability among elderly persons. Arch Intern Med. 12. 12–26. 2005;165(22):2625-30. Not eligible outcomes. [pmid: 16344420].
623 Gill TM, Williams CS, Tinetti ME. Environmental hazards and the risk of nonsyncopal falls in the homes of community-living older persons. Medical Care. 12. 2000;38(12):1174-83. Not eligible exposure. [pmid: 11186296].
624 Given B, Given C, Azzouz F, et al. Physical functioning of elderly cancer patients prior to diagnosis and following initial treatment. Nurs Res. 07–08. 2001;50(4):222-32. Not eligible outcomes. [pmid: 11480531].
625 Given CW, Given B, Azzouz F, et al. Comparison of changes in physical functioning of elderly patients with new diagnoses of cancer. Med Care. 05. 2000;38(5):482-93. Not eligible exposure. [pmid: 10800975].
626 Givens JL, Sanft TB, Marcantonio ER, et al. Functional recovery after hip fracture: the combined effects of depressive symptoms, cognitive impairment, and delirium. Journal of the American Geriatrics Society. 06. 2008;56(6):1075-9. Not eligible exposure. [pmid: 18422945].
627 Glasgow SC, Birnbaum EH, Kodner IJ, et al. Recurrence and quality of life following perineal proctectomy for rectal prolapse. Journal of Gastrointestinal Surgery. 08. 2008;12(8):1446-51. Not eligible outcomes. [pmid: 18516652].
628 Glass TA, Bandeen-Roche K, McAtee M, et al. Neighborhood psychosocial hazards and the association of cumulative lead dose with cognitive function in older adults. American Journal of Epidemiology. 03. 15. 2009;169(6):683-92. Not eligible outcomes. [pmid: 19155330].
629 Glei DA, Goldman N, Chuang YL, et al. Do chronic stressors lead to physiological dysregulation? Testing the theory of allostatic load. Psychosom Med. 11. 2007;69(8):769-76. Not eligible outcomes. [pmid: 17942833].
630 Gloth FM 3rd, Gundberg CM, Hollis BW, et al. Vitamin D deficiency in homebound elderly persons.[see comment]. JAMA. 12. 6. 1995;274(21):1683-6. Not eligible outcomes. [pmid: 7474272].
631 Glymour MM, Weuve J, Berkman LF, et al. When is baseline adjustment useful in analyses of change? An example with education and cognitive change.[see comment]. American Journal of Epidemiology. 08. 1. 2005;162(3):267-78. Not eligible outcomes. [pmid: 15987729].
632 Glynn RJ, Field TS, Rosner B, et al. Evidence for a positive linear relation between blood pressure and mortality in elderly people. Lancet. 04. 1. 1995;345(8953):825-9. Not eligible outcomes. [pmid: 7898229].
633 Glynn RJ, Schneeweiss S, Wang PS, et al. Selective prescribing led to overestimation of the benefits of lipid-lowering drugs. J Clin Epidemiol. 08. 2006;59(8):819-28. Not eligible outcome. [pmid: 16828675].
634 Gohari MR, Mahmoudi M, Mohammed K, et al. Recurrence in breast cancer. Analysis with frailty model. Saudi Med J. 08. 2006;27(8):1187-93. Not eligible outcomes. [pmid: 16883450].
635 Golant SM. Do impaired older persons with health care needs occupy U.S. assisted living facilities? An analysis of six national studies. J Gerontol B Psychol Sci Soc Sci. 03. 2004;59(2):S68-79. Not eligible outcomes. [pmid: 15014094].
636 Gold DT, Bonnick SL, Amonkar MM, et al. Descriptive analysis of concomitant prescription medication patterns from 1999 to 2004 among US women receiving daily or weekly oral bisphosphonate therapy. Gend Med. 12. 2008;5(4):374-84. Not eligible target population. [pmid: 19108810].
637 Goldman SE, Ancoli-Israel S, Boudreau R, et al. Sleep problems and associated daytime fatigue in community-dwelling older individuals. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 10. 2008;63(10):1069-75. Not eligible outcomes.
638 Gonzalez JR, Fernandez E, Moreno V, et al. Sex differences in hospital readmission among colorectal cancer patients. J Epidemiol Community Health. 06. 2005;59(6):506-11. Not eligible exposure. [pmid: 15911648].
639 Goodis HE, Rossall JC, Kahn AJ. Endodontic status in older U.S. adults. Report of a survey. J Am Dent Assoc. 11. 2001;132(11):1525-30. quiz 95–6. Not eligible outcomes. [pmid: 11806066].
640 Goodwin RD, Friedman HS. Health status and the five-factor personality traits in a nationally representative sample. Journal of Health Psychology. 09. 2006;11(5):643-54. Not eligible outcomes. [pmid: 16908463].
641 Gopal S. Risks of care at home for the frail aged. J Long Term Home Health Care. Summer. 1997;16(3):36-46. Not eligible outcomes. [pmid: 10173284].
642 Gopinath B, Rochtchina E, Flood V, et al. Association of elevated homocysteine level and vitamin B12 deficiency with anemia in older adults. Archives of Internal Medicine. 05. 11. 2009;169(9):901-2. Not eligible outcomes. [pmid: 19433703].
643 Gopinath B, Rochtchina E, Wang JJ, et al. Prevalence of age-related hearing loss in older adults: Blue Mountains Study. Archives of Internal Medicine. 02. 23. 2009;169(4):415-6. Not eligible outcomes. [pmid: 19237727].
644 Gozalo PL, Miller SC, Intrator O, et al. Hospice effect on government expenditures among nursing home residents. Health Serv Res. 02. 2008;43(1 Pt 1):134-53. Not eligible target population. [pmid: 18211522].
645 Grabowski CJ. Falls.... A prelude to litigation. Director. Spring. 2003;11(2):50-4. Not eligible outcomes. [pmid: 12741052].
646 Grady KL, Jalowiec A, Grusk BB, et al. Symptom distress in cardiac transplant candidates. Heart & Lung. 09–10. 1992;21(5):434-9. Not eligible outcomes. [pmid: 1399662].
647 Graham JE, Mitnitski AB, Mogilner AJ, et al. Dynamics of cognitive aging: distinguishing functional age and disease from chronologic age in a population. Am J Epidemiol. 11. 15. 1999;150(10):1045-54. Not eligible outcomes. [pmid: 10568619].
648 Graves AB, Rajaram L, Bowen JD, et al. Cognitive decline and Japanese culture in a cohort of older Japanese Americans in King County, WA: the Kame Project. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. 05. 1999;54(3):S154-61. Not eligible outcomes.
649 Graves MT, Slater MA, Maravilla V, et al. Implementing an early intervention case management program in three medical groups. Case Manager. 09–10. 2003;14(5):48-52. Not eligible outcomes. [pmid: 14593346].
650 Graziano F, Santini D, Testa E, et al. A phase II study of weekly cisplatin, 6S-stereoisomer leucovorin and fluorouracil as first-line chemotherapy for elderly patients with advanced gastric cancer. British journal of cancer. 10. 20. 2003;89(8):1428-32. Not eligible outcomes. [pmid: 14562012].
651 Green CR, Ndao-Brumblay SK, Nagrant AM, et al. Race, age, and gender influences among clusters of African American and white patients with chronic pain. J Pain. 04. 2004;5(3):171-82. Not eligible outcomes. [pmid: 15106130].
652 Green JL, Hawley JN, Rask KJ. Is the number of prescribing physicians an independent risk factor for adverse drug events in an elderly outpatient population. American Journal Geriatric Pharmacotherapy. 03. 2007;5(1):31-9. Not eligible outcomes.
653 Greenlee RT, Zentner J, Kieke B Jr, et al. Farm health surveillance in the Marshfield Epidemiologic Study Area: a pilot study. Journal of Agricultural Safety & Health. 05. 2005;11(2):211-8. Not eligible target population. [pmid: 15931947].
654 Gregg EW, Mangione CM, Cauley JA, et al. Diabetes and incidence of functional disability in older women. Diabetes Care. 01. 2002;25(1):61-7. Not eligible exposure. [pmid: 11772902].
655 Gregg EW, Yaffe K, Cauley JA, et al. Is diabetes associated with cognitive impairment and cognitive decline among older women? Study of Osteoporotic Fractures Research Group.[see comment]. Archives of Internal Medicine. 01. 24. 2000;160(2):174-80. Not eligible exposure. [pmid: 10647755].
656 Griffore RJ, Barboza GE, Mastin T, et al. Family members’ reports of abuse in Michigan nursing homes. J Elder Abuse Negl. 04. 2009;21(2):105-14. Not eligible target population. [pmid: 19347713].
657 Grinker J, Rush D, Vokonas P. Changing body habitus among healthy older men: the NAS Boston VA study of weight stability in healthy male volunteers aged 40–80 years. Diabetes Research & Clinical Practice. 1990;10(Suppl 1):S89-94. Not eligible outcomes. [pmid: 2286157].
658 Grinker JA, Tucker K, Vokonas PS, et al. Overweight and leanness in adulthood: prospective study of male participants in the Normative Aging Study. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 06. 1996;20(6):561-9. Not eligible outcomes. [pmid: 8782733].
659 Grisso JA, Schwarz DF, Wolfson V, et al. The impact of falls in an inner-city elderly African-American population. J Am Geriatr Soc. 07. 1992;40(7):673-8. outcomes. [pmid: 1318889].
660 Grodstein F, Fretts R, Lifford K, et al. Association of age, race, and obstetric history with urinary symptoms among women in the Nurses’ Health Study. American Journal of Obstetrics & Gynecology. 08. 2003;189(2):428-34. Not eligible outcomes. [pmid: 14520212].
661 Groessl EJ, Kaplan RM, Rejeski WJ, et al. Health-related quality of life in older adults at risk for disability. Am J Prev Med. 09. 2007;33(3):214-8. Not eligible outcomes. [pmid: 17826582].
662 Gronniger JT, Gronniger JT. Familial obesity as a proxy for omitted variables in the obesity-mortality relationship. Demography. 11. 2005;42(4):719-35. Not eligible exposure. [pmid: 16463918].
663 Groot W, Van Den Brink HM, Plug E. Money for health: the equivalent variation of cardiovascular diseases. Health Econ. 09. 2004;13(9):859-72. Not eligible outcomes. [pmid: 15362178].
664 Grossi EA, Schwartz CF, Yu PJ, et al. High-risk aortic valve replacement: are the outcomes as bad as predicted. Ann Thorac Surg. 01. 2008;85(1):102-6. discussion 7. Not eligible outcomes. [pmid: 18154791].
665 Gruber-Baldini AL, Zimmerman SI, Mortimore E, et al. The validity of the minimum data set in measuring the cognitive impairment of persons admitted to nursing homes. J Am Geriatr Soc. 12. 2000;48(12):1601-6. Not eligible target population. [pmid: 11129749].
666 Gu MG, Sun L, Zuo G. A baseline-free procedure for transformation models under interval censorship. Lifetime Data Anal. 12. 2005;11(4):473-88. Not eligible outcomes. [pmid: 16328572].
667 Gubler KD, Maier RV, Davis R, et al. Trauma recidivism in the elderly. J Trauma. 12. 1996;41(6):952-6. Not eligible outcomes. [pmid: 8970545].
668 Guess HA, Arrighi HM, Metter EJ, et al. Cumulative prevalence of prostatism matches the autopsy prevalence of benign prostatic hyperplasia. Prostate. 1990;17(3):241-6. Not eligible exposure. [pmid: 1700403].
669 Guilfoyle SM, Hale LJ. Community-based fall prevention programs for older adults in Wisconsin. WMJ. 01. 2005;104(1):29-32. Not eligible outcomes. [pmid: 15779721].
670 Guill JV, Griffin LA, Goodwin TD. Columbus Air Force Base medication profile intervention practice innovation. J Am Pharm Assoc. 2008. 09–10. 2003;48(5):654-8. Not eligible outcomes.
671 Guralnik JM, Ferrucci L, Balfour JL, et al. Progressive versus catastrophic loss of the ability to walk: implications for the prevention of mobility loss. J Am Geriatr Soc. 11. 2001;49(11):1463-70. Not eligible outcomes. [pmid: 11890584].
672 Guralnik JM, Ferrucci L, Penninx BW, et al. New and worsening conditions and change in physical and cognitive performance during weekly evaluations over 6 months: the Women’s Health and Aging Study. J Gerontol A Biol Sci Med Sci. 08. 1999;54(8):M410-22. Not eligible outcomes. [pmid: 10496547].
673 Guralnik JM, Simonsick EM. Physical disability in older Americans. J Gerontol. 09. 1993;48(Spec No:3–10). Not eligible outcomes.
674 Guttman C. Older Americans 2000. New data system that tracks health and well-being finds successes and disparities. Geriatrics. 10. 2000;55(10):63-6. 9. Not eligible outcomes. [pmid: 11054952].
675 Haan MN, Aiello AE, West NA, et al. C-reactive protein and rate of dementia in carriers and non carriers of Apolipoprotein APOE4 genotype. Neurobiology of aging. 12. 2008;29(12):1774-82. Not eligible outcomes. [pmid: 17540481].
676 Haan MN, Weldon M. The influence of diabetes, hypertension, and stroke on ethnic differences in physical and cognitive functioning in an ethnically diverse older population. Ann Epidemiol. 09. 1996;6(5):392-8. Not eligible outcomes. [pmid: 8915470].
677 Hadaegh F, Zabetian A, Tohidi M, et al. Prevalence of metabolic syndrome by the Adult Treatment Panel III, International Diabetes Federation, and World Health Organization definitions and their association with coronary heart disease in an elderly Iranian population. Annals of the Academy of Medicine, Singapore. 02. 2009;38(2):142-9. Not eligible outcomes.
678 Haentjens P, Autier P, Barette M, et al. Survival and functional outcome according to hip fracture type: a one-year prospective cohort study in elderly women with an intertrochanteric or femoral neck fracture. Bone. 12. 2007;41(6):958-64. Not eligible exposure. [pmid: 17913614].
679 Haessler AL, Nguyen JN, Bhatia NN. Impact of urodynamic based incontinence diagnosis on quality of life in women. Neurourology & Urodynamics. 2009;28(3):183-7. Not eligible outcomes. [pmid: 18973144].
680 Hagberg B, Bauer Alfredson B, Poon LW, et al. Cognitive functioning in centenarians: a coordinated analysis of results from three countries. J Gerontol B Psychol Sci Soc Sci. 05. 2001;56(3):P141-51. Not eligible outcomes. [pmid: 11316832].
681 Haghjoo M, Faghfurian B, Taherpour M, et al. Predictors of syncope in patients with hypertrophic cardiomyopathy. Pacing & Clinical Electrophysiology. 05. 2009;32(5):642-7. Not eligible outcomes. [pmid: 19422586].
682 Hailu A, Knutsen SF, Fraser GE. Associations between meat consumption and the prevalence of degenerative arthritis and soft tissue disorders in the adventist health study, California U.S.A. Journal of Nutrition, Health & Aging. 01–02. 2006;10(1):7-14. Not eligible outcomes.
683 Hain DJ. Cognitive function and adherence of older adults undergoing hemodialysis. Nephrol Nurs J. 01–02. 2008;35(1):23-9. Not eligible outcomes. [pmid: 18372760].
684 Haines T, Brown C, Morrison J. Public provision of four-wheeled walkers: contingent valuation study of economic benefit. Australasian Journal on Ageing. 09. 2008;27(3):161-4. Not eligible outcomes. [pmid: 18713177].
685 Hakim AA, Curb JD, Burchfiel CM, et al. Screening for coronary heart disease in elderly men based on current and past cholesterol levels. Journal of Clinical Epidemiology. 12. 1999;52(12):1257-65. Not eligible outcomes. [pmid: 10580790].
686 Halbert RJ, Natoli JL, Gano A, et al. Global burden of COPD: systematic review and meta-analysis. European Respiratory Journal. 09. 2006;28(3):523-32. Not eligible outcomes. [pmid: 16611654].
687 Hall JA, Nelson MA, Meyer JW, et al. Costs and resources associated with the treatment of overactive bladder using retrospective medical care claims data. Managed Care Interface. 08. 2001;14(8):69-75. Not eligible outcomes. [pmid: 11517841].
688 Hall KS, Gao S, Baiyewu O, et al. Prevalence rates for dementia and Alzheimer’s disease in African Americans: 1992 versus 2001. Alzheimer’s & Dementia. 05. 2009;5(3):227-33. Not eligible outcomes.
689 Hallfors D, Leutz W, Capitman J, et al. Stability of frailty in the social/health maintenance organization. Health Care Financ Rev. Summer. 1994;15(4):105-16. Not eligible outcomes. [pmid: 10138480].
690 Halmin M, Bellocco R, Lagerlund M, et al. Long-term inequalities in breast cancer survival--a ten year follow-up study of patients managed within a National Health Care System (Sweden). Acta Oncol. 2008;47(2):216-24. Not eligible outcomes. [pmid: 18210298].
691 Hamasha AA, Hand JS, Levy SM. Medical conditions associated with missing teeth and edentulism in the institutionalized elderly. Spec Care Dentist. 05–06. 1998;18(3):123-7. Not eligible target population. [pmid: 9680923].
692 Hamilton BH, Hamilton VH. Estimating surgical volume--outcome relationships applying survival models: accounting for frailty and hospital fixed effects. Health Econ. 07–08. 1997;6(4):383-95. Not eligible outcomes. [pmid: 9285231].
693 Hanayama N, Hanayama N. An extended age period cohort model for analysing (age, period)-tabulated data. Statistics in Medicine. 08. 15. 2007;26(18):3459-75. Not eligible outcomes. [pmid: 17431852].
694 Handy J. Options in ambulatory care for the elderly. J Ambul Care Manage. 05. 1990;13(2):33-41. Not eligible outcomes. [pmid: 10106522].
695 Haney EM, Stadler D, Bliziotes MM. Vitamin D insufficiency in internal medicine residents. Calcified tissue international. 01. 2005;76(1):11-6. Not eligible outcomes. [pmid: 15478001].
696 Hanlon JT, Schmader KE, Koronkowski MJ, et al. Adverse drug events in high risk older outpatients. J Am Geriatr Soc. 08. 1997;45(8):945-8. Not eligible outcomes. [pmid: 9256846].
697 Hanrahan P, Raymond M, McGowan E, et al. Criteria for enrolling dementia patients in hospice: a replication. Am J Hosp Palliat Care. 01–02. 1999;16(1):395-400. Not eligible outcomes. [pmid: 10085797].
698 Hansberry MR, Chen E, Gorbien MJ. Dementia and elder abuse. Clinics in geriatric medicine. 05. 2005;21(2):315-32. Not eligible outcomes. [pmid: 15804553].
699 Harder S, Saal K, Blauth E, et al. Appropriateness and surveillance of medication in a cohort of diabetic patients on polypharmacy. Int J Clin Pharmacol Ther. 02. 2009;47(2):104-10. Not eligible outcomes. [pmid: 19203566].
700 Harms SL, Eberly LE, Garrard JM, et al. Prevalence of appropriate and problematic antiepileptic combination therapy in older people in the nursing home. J Am Geriatr Soc. 06. 2005;53(6):1023-8. Not eligible target population. [pmid: 15935028].
701 Harris AH, Thoresen CE, Harris AHS, et al. Volunteering is associated with delayed mortality in older people: analysis of the longitudinal study of aging. Journal of Health Psychology. 11. 2005;10(6):739-52. Not eligible outcomes. [pmid: 16176953].
702 Harris CJ. Detecting depression. Provider. 06. 1998;24(6):67-8. Not eligible outcomes. [pmid: 10180047].
703 Harris T. Comparative analysis of health statistics for selected diseases common in older persons in the United States. Vital Health Stat. 08. 1991;5(6):261-2. Not eligible outcomes.
704 Harris Y. Depression as a risk factor for nursing home admission among older individuals. J Am Med Dir Assoc. 01. 2007;8(1):14-20. Not eligible outcomes. [pmid: 17210498].
705 Harris Y, Cooper JK. Depressive symptoms in older people predict nursing home admission. J Am Geriatr Soc. 04. 2006;54(4):593-7. Not eligible outcomes. [pmid: 16686868].
706 Harrison TC. A qualitative analysis of the meaning of aging for women with disabilities with policy implications. ANS Adv Nurs Sci. 04–06. 2006;29(2):E1-13. Not eligible outcomes. [pmid: 16717482].
707 Hart DL, Wang YC, Stratford PW, et al. A computerized adaptive test for patients with hip impairments produced valid and responsive measures of function. Arch Phys Med Rehabil. 11. 2008;89(11):2129-39. Not eligible outcomes. [pmid: 18996242].
708 Hartz AJ, Daly JM, Kohatsu ND, et al. Risk factors for insomnia in a rural population. Annals of Epidemiology. 12. 2007;17(12):940-7. Not eligible outcomes. [pmid: 17937993].
709 Harwood DG, Sultzer DL, Wheatley MV. Impaired insight in Alzheimer disease: association with cognitive deficits, psychiatric symptoms, and behavioral disturbances. Neuropsychiatry, Neuropsychology, & Behavioral Neurology. 04. 2000;13(2):83-8. Not eligible outcomes.
710 Hatch J, Gill-Body KM, Portney LG. Determinants of balance confidence in community-dwelling elderly people. Phys Ther. 12. 2003;83(12):1072-9. Not eligible outcomes. [pmid: 14640866].
711 Haugh R. ACE units take a wholistic, team approach to meet the needs of an aging America. A fresh model for gerontology. Hosp Health Netw. 03. 2004;78(3):52-6. 2. Not eligible outcomes.
712 Hayden KM, Zandi PP, Khachaturian AS, et al. Does NSAID use modify cognitive trajectories in the elderly? The Cache County study.[see comment]. Neurology. 07. 17. 2007;69(3):275-82. Not eligible outcomes. [pmid: 17636065].
713 Hazuda HP, Gerety MB, Lee S, et al. Measuring subclinical disability in older mexican americans. Psychosom Med. 05–06. 2002;64(3):520-30. Not eligible population. [pmid: 12021426].
714 Hazzard WR. Depressed albumin and high-density lipoprotein cholesterol: signposts along the final common pathway of frailty. J Am Geriatr Soc. 09. 2001;49(9):1253-4. Not eligible outcomes. [pmid: 11559388].
715 He K, Hu FB, Colditz GA, et al. Changes in intake of fruits and vegetables in relation to risk of obesity and weight gain among middle-aged women. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 12. 2004;28(12):1569-74. Not eligible outcomes. [pmid: 15467774].
716 Heading RC. Prevalence of upper gastrointestinal symptoms in the general population: a systematic review. Scand J Gastroenterol Suppl. 1999;231:3-8. Not eligible outcomes. [pmid: 10565617].
717 Hebert LE, Scherr PA, Bennett DA, et al. Blood pressure and late-life cognitive function change: a biracial longitudinal population study. Neurology. 06. 8. 2004;62(11):2021-4. Not eligible outcomes. [pmid: 15184608].
718 Hee Kang J, Grodstein F, Hee Kang J, et al. Regular use of nonsteroidal anti-inflammatory drugs and cognitive function in aging women. Neurology. 05. 27. 2003;60(10):1591-7. Not eligible outcomes. [pmid: 12771247].
719 Hefflin BJ. Final-year-of life pacemaker recipients. J Am Geriatr Soc. 11. 1998;46(11):1396-400. Not eligible outcomes. [pmid: 9809761].
720 Hegland A. Nutrition: at what price. Contemp Longterm Care. 09. 1993;16(9):62-4. 104. Not eligible outcomes.
721 Heinonen M, Karppi P, Huusko T, et al. Postoperative degree of mobilization at two weeks predicts one-year mortality after hip fracture. Aging Clin Exp Res. 12. 2004;16(6):476-80. Not eligible outcomes. [pmid: 15739600].
722 Helfand AE. Foot problems in older patients: a focused podogeriatric assessment study in ambulatory care. J Am Podiatr Med Assoc. 05–06. 2004;94(3):293-304. Not eligible outcomes. [pmid: 15153592].
723 Heller DA, Ahern FM, Pringle KE, et al. Among older adults, the responsiveness of self-rated health to changes in Charlson comorbidity was moderated by age and baseline comorbidity. J Clin Epidemiol. 02. 2009;62(2):177-87. Not eligible outcomes. [pmid: 18722090].
724 Henderson R. Modelling conditional distributions in bivariate survival. Lifetime Data Anal. 1996;2(3):241-59. Not eligible outcomes. [pmid: 9384635].
725 Hendriks MR, Evers SM, Bleijlevens MH, et al. Cost-effectiveness of a multidisciplinary fall prevention program in community-dwelling elderly people: a randomized controlled trial (ISRCTN 64716113). International Journal of Technology Assessment in Health Care. 2008;24(2):193-202. Not eligible outcomes. [pmid: 18400123].
726 Hennen J, Krumholz HM, Radford MJ. Mortality experience, 30-days and 365-days after admission, for the 20 most frequent DRG groups among Medicare inpatients aged 65 or older in Connecticut hospitals, fiscal years 1991, 1992, and 1993. Conn Med. 03. 1995;59(3):137-42. Not eligible outcomes. [pmid: 7729135].
727 Henry OF, Blacher J, Verdavaine J, et al. Alpha 1-acid glycoprotein is an independent predictor of inhospital death in the elderly. Age Ageing. 01. 2003;32(1):37-42. Not eligible target population. [pmid: 12540346].
728 Hensel A, Angermeyer MC, Riedel-Heller SG. Measuring cognitive change in older adults. Do reliable change indices of the SIDAM predict dementia?. J Neurol. 10. 2007;254(10):1359-65. Not eligible outcomes. [pmid: 17932704].
729 Hentati H, Arfa N, Haouas N, et al. Pancreaticoduodenectomy in the elderly over 80 years: a case report. Hepatobiliary Pancreat Dis Int. 02. 2007;6(1):104-7. Not eligible outcomes. [pmid: 17287177].
730 Henton FE, Hays BJ, Walker SN, et al. Determinants of Medicare home healthcare service use among Medicare recipients. Nurs Res. 11–12. 2002;51(6):355-62. Not eligible outcomes. [pmid: 12464755].
731 Herzog AR, Diokno AC, Brown MB, et al. Two-year incidence, remission, and change patterns of urinary incontinence in noninstitutionalized older adults. Journal of Gerontology. 03. 1990;45(2):M67-74. Not eligible outcomes. [pmid: 2313045].
732 Hewitt M, Rowland JH, Yancik R. Cancer survivors in the United States: age, health, and disability. J Gerontol A Biol Sci Med Sci. 01. 2003;58(1):82-91. Not eligible outcomes. [pmid: 12560417].
733 Hicks GE, Manal TJ. Psychometric properties of commonly used low back disability questionnaires: are they useful for older adults with low back pain. Pain Med. 01. 2009;10(1):85-94. Not eligible outcomes. [pmid: 19222773].
734 High K, Bradley S, Loeb M, et al. A new paradigm for clinical investigation of infectious syndromes in older adults: assessing functional status as a risk factor and outcome measure. Journal of the American Geriatrics Society. 03. 2005;53(3):528-35. Review. [pmid: 15743301].
735 Himes CL. Obesity, disease, and functional limitation in later life. Demography. 02. 2000;37(1):73-82. Not eligible exposure. [pmid: 10748990].
736 Hirdes JP, Frijters DH, Teare GF. The MDS-CHESS scale: a new measure to predict mortality in institutionalized older people. J Am Geriatr Soc. 01. 2003;51(1):96-100. Not eligible outcomes. [pmid: 12534853].
737 Hirsch HR. Can an improved environment cause maximum lifespan to decrease? Comments on lifespan criteria and longitudinal Gompertzian analysis. Experimental Gerontology. 03–04. 1994;29(2):119-37. Not eligible outcomes. [pmid: 8026566].
738 Ho KK, Pinsky JL, Kannel WB, et al. The epidemiology of heart failure: the Framingham Study. J Am Coll Cardiol. 10. 1993;22(4 Suppl A):6A-13A. Not eligible outcomes. [pmid: 8509564].
739 Hochberg MC, Lethbridge-Cejku M, Scott WW Jr, et al. Upper extremity bone mass and osteoarthritis of the knees: data from the Baltimore Longitudinal Study of Aging, Journal of Bone & Mineral Research. 03. 1995;10(3):432-8. Not eligible exposure.
740 Hollins S, Attard MT, von Fraunhofer N, et al. Mortality in people with learning disability: risks, causes, and death certification findings in London. Dev Med Child Neurol. 01. 1998;40(1):50-6. Not eligible target population. [pmid: 9459217].
741 Hollis D. New pilot program helps physicians monitor chronically ill patients between office visits. Tenn Med. 06. 2006;99(6):35. Not eligible outcomes. [pmid: 16802661].
742 Holroyd-Leduc JM, Mehta KM, Covinsky KE. Urinary incontinence and its association with death, nursing home admission, and functional decline. J Am Geriatr Soc. 05. 2004;52(5):712-8. Not eligible exposure. [pmid: 15086650].
743 Holtzman J, Saleh K, Kane R. Gender differences in functional status and pain in a Medicare population undergoing elective total hip arthroplasty. Med Care. 06. 2002;40(6):461-70. Not eligible outcomes. [pmid: 12021672].
744 Honsberg AE, Dodge RR, Cline MG, et al. Incidence and remission of habitual snoring over a 5- to 6-year period. Chest. 09. 1995;108(3):604-9. Not eligible outcomes. [pmid: 7656604].
745 Horgas AL, Yoon SL, Nichols AL, et al. The relationship between pain and functional disability in Black and White older adults. Res Nurs Health. 08. 2008;31(4):341-54. Not eligible outcomes. [pmid: 18231972].
746 Horner RD, Cohen HJ, Blazer DG. Accuracy of self-reported stroke among elderly veterans. Aging Ment Health. 08. 2001;5(3):275-81. Not elgible target population. [pmid: 11575067].
747 Hornick T, Aron DC. Managing diabetes in the elderly: go easy, individualize. Cleve Clin J Med. 01. 2008;75(1):70-8. Not eligible outcomes. [pmid: 18236732].
748 Horton AM Jr, Roberts C. Demographic effects on the Trail Making Test in marijuana abusers. International Journal of Neuroscience. 2001;110(3–4):173-80. Not eligible outcomes. [pmid: 11912867].
749 Horton AM Jr, Roberts C, Horton AM Jr, et al. Derived trail making test indices in a sample of narcotic/other opiate abusers: demographic effects. International Journal of Neuroscience. 09. 2002;112(9):1075-84. Not eligible outcomes. [pmid: 12487096].
750 Houston DK, Ding J, Nicklas BJ, et al. The association between weight history and physical performance in the Health, Aging and Body Composition study. Int J Obes (Lond). 11. 2007;31(11):1680-7. Not eligible outcomes. [pmid: 17515911].
751 Houston DK, Johnson MA, Daniel TD, et al. Health and dietary characteristics of supplement users in an elderly population. International Journal for Vitamin & Nutrition Research. 1997;67(3):183-91. Not eligible outcomes. [pmid: 9202979].
752 Hoverman C, Shugarman LR, Saliba D, et al. Use of postacute care by nursing home residents hospitalized for stroke or hip fracture: how prevalent and to what end. J Am Geriatr Soc. 08. 2008;56(8):1490-6. Not eligible target population. [pmid: 18662206].
753 Howard DH. Life expectancy and the value of early detection. J Health Econ. 09. 2005;24(5):891-906. Not eligible outcomes. [pmid: 16129128].
754 Howieson DB, Camicioli R, Quinn J, et al. Natural history of cognitive decline in the old old. Neurology. 05. 13. 2003;60(9):1489-94. Not eligible exposure. [pmid: 12743237].
755 Howland J, Peterson EW, Levin WC, et al. Fear of falling among the community-dwelling elderly. J Aging Health. 05. 1993;5(2):229-43. Not eligible outcomes. [pmid: 10125446].
756 Hozawa A, Okamura T, Kadowaki T, et al. Is weak association between cigarette smoking and cardiovascular disease mortality observed in Japan explained by low total cholesterol? NIPPON DATA80. Int J Epidemiol. 10. 2007;36(5):1060-7. Not eligible outcomes. [pmid: 17846054].
757 Hsieh LJ, Carter HB, Landis PK, et al. Association of energy intake with prostate cancer in a long-term aging study: Baltimore Longitudinal Study of Aging (United States). Urology. 02. 2003;61(2):297-301. Not eligible outcomes. [pmid: 12597934].
758 Hu H, Wu MT, Cheng Y, et al. The delta-aminolevulinic acid dehydratase (ALAD) polymorphism and bone and blood lead levels in community-exposed men: the Normative Aging Study. Environmental Health Perspectives. 08. 2001;109(8):827-32. Not eligible outcomes. [pmid: 11564619].
759 Hu P, Wagle N, Goldman N, et al. The associations between socioeconomic status, allostatic load and measures of health in older Taiwanese persons: Taiwan social environment and biomarkers of aging study. J Biosoc Sci. 07. 2007;39(4):545-56. Not eligible outcomes. [pmid: 17052381].
760 Hu PS, Trumble DA, Foley DJ, et al. Crash risks of older drivers: a panel data analysis. Accid Anal Prev. 09. 1998;30(5):569-81. Not eligible outcomes. [pmid: 9678211].
761 Huang C, Ross PD, Fujiwara S, et al. Determinants of vertebral fracture prevalence among native Japanese women and women of Japanese descent living in Hawaii. Bone. 05. 1996;18(5):437-42. Not eligible outcomes. [pmid: 8739901].
762 Huang ES, Basu A, Finch M, et al. The complexity of medication regimens and test ordering for patients with diabetes from 1995 to 2003. Curr Med Res Opin. 06. 2007;23(6):1423-30. Not eligible exposure. [pmid: 17559738].
763 Huang X, Liu L. A joint frailty model for survival and gap times between recurrent events. Biometrics. 06. 2007;63(2):389-97. Not eligible oucomes. [pmid: 17688491].
764 Huang X, Wolfe RA. A frailty model for informative censoring. Biometrics. 09. 2002;58(3):510-20. Not eligible outcomes. [pmid: 12229985].
765 Huang X, Wolfe RA, Hu C. A test for informative censoring in clustered survival data. Stat Med. 07. 15. 2004;23(13):2089-107. Not eligible outcomes. [pmid: 15211605].
766 Huang ZB, Neufeld RR, Likourezos A, et al. Sociodemographic and health characteristics of older Chinese on admission to a nursing home: a cross-racial/ethnic study. J Am Geriatr Soc. 03. 2003;51(3):404-9. Not eligible outcomes. [pmid: 12588586].
767 Hubbard JS, Rohrmann S, Landis PK, et al. Association of prostate cancer risk with insulin, glucose, and anthropometry in the Baltimore longitudinal study of aging. Urology. 02. 2004;63(2):253-8. Not eligible exposure. [pmid: 14972466].
768 Hubbard RE, Searle SD, Mitnitski A, et al. Effect of smoking on the accumulation of deficits, frailty and survival in older adults: a secondary analysis from the Canadian Study of Health and Aging. J Nutr Health Aging. 05. 2009;13(5):468-72. Not eligible outcomes. [pmid: 19390755].
769 Hubbert AO, Hays BJ. Seniors’ need for and use of Medicare home health services. Home Health Care Serv Q. 2002;21(2):19-34. Not eligible outcomes. [pmid: 12362999].
770 Huber-Carol C, Vonta I. Frailty models for arbitrarily censored and truncated data. Lifetime Data Anal. 12. 2004;10(4):369-88. Not eligible outcomes. [pmid: 15690991].
771 Hughes SL, Edelman P, Naughton B, et al. Estimates and determinants of valid self-reports of musculoskeletal disease in the elderly. J Aging Health. 05. 1993;5(2):244-63. Not eligible outcomes. [pmid: 10125447].
772 Huikuri HV, Makikallio TH, Airaksinen KE, et al. Power-law relationship of heart rate variability as a predictor of mortality in the elderly. Circulation. 05. 26. 1998;97(20):2031-6. Not eligible outcomes. [pmid: 9610533].
773 Hung WW, Wisnivesky JP, Siu AL, et al. Cognitive decline among patients with chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. 07. 15. 2009;180(2):134-7. Not eligible outcomes. [pmid: 19423714].
774 Hupfeld S. Rich and healthy-better than poor and sick? An empirical analysis of income, health, and the duration of the pension benefit spell. J Health Econ. 03. 2009;28(2):427-43. Not eligible outcomes. [pmid: 19187987].
775 Hutton B, Feine J, Morais J. Is there an association between edentulism and nutritional state. J Can Dent Assoc. 03. 2002;68(3):182-7. Not eligible outcomes. [pmid: 11911815].
776 Hybels CF, Blazer DG, Pieper CF. Toward a threshold for subthreshold depression: an analysis of correlates of depression by severity of symptoms using data from an elderly community sample. Gerontologist. 06. 2001;41(3):357-65. Not eligible outcomes. [pmid: 11405433].
777 Ide BA, Dahlen B, Gragert M, et al. Needs assessment of Standing Rock elders. J Cult Divers. Winter. 2006;13(4):186-9. Not eligible outcomes. [pmid: 17338488].
778 Il’yasova D, Colbert LH, Harris TB, et al. Circulating levels of inflammatory markers and cancer risk in the health aging and body composition cohort. Cancer Epidemiology, Biomarkers & Prevention. 10. 2005;14(10):2413-8. Not eligible outcom.
779 Ingersoll-Dayton B, Starrels ME, Dowler D. Caregiving for parents and parents-in-law: is gender important. Gerontologist. 08. 1996;36(4):483-91. Not eligible outcomes. [pmid: 8771976].
780 Inouye SK. Delirium in hospitalized older patients: recognition and risk factors. J Geriatr Psychiatry Neurol. Fall. 1998;11(3):118-25. discussion 57–8. Not eligible target population. [pmid: 9894730].
781 Inouye SK, Robison JT, Froehlich TE, et al. The time and change test: a simple screening test for dementia. J Gerontol A Biol Sci Med Sci. 07. 1998;53(4):M281-6. Not eligible outcomes. [pmid: 18314567].
782 Intrator O, Castle NG, Mor V. Facility characteristics associated with hospitalization of nursing home residents: results of a national study. Med Care. 03. 1999;37(3):228-37. Not eligible target population. [pmid: 10098567].
783 Ives DG, Bonino P, Traven ND, et al. Characteristics and comorbidities of rural older adults with hearing impairment. J Am Geriatr Soc. 07. 1995;43(7):803-6. Not eligible outcomes. [pmid: 7602037].
784 Iwao S, Iwao N, Muller DC, et al. Effect of aging on the relationship between multiple risk factors and waist circumference. J Am Geriatr Soc. 07. 2000;48(7):788-94. Not eligible exposure. [pmid: 10894318].
785 Izawa S, Kuzuya M, Okada K, et al. The nutritional status of frail elderly with care needs according to the mini-nutritional assessment. Clinical Nutrition. 12. 2006;25(6):962-7. Not eligible outcomes. [pmid: 16859814].
786 Izumi S, Ohtaki M. Incorporation of inter-individual heterogeneity into the multistage carcinogenesis model: approach to the analysis of cancer incidence data. Biom J. 08. 2007;49(4):539-50. Not eligible exposure. [pmid: 17722193].
787 Jach L. Alcohol and drug problems in the elderly. Perspect Addict Nurs. Winter. 1995;5(4):6-7. Not eligible outcomes. [pmid: 7773847].
788 Jack CR Jr, Petersen RC, Grundman M, et al. Longitudinal MRI findings from the vitamin E and donepezil treatment study for MCI. Neurobiology of aging. 09. 2008;29(9):1285-95. Not eligible outcomes. [pmid: 17452062].
789 Jackson JC, Obremskey W, Bauer R, et al. Long-term cognitive, emotional, and functional outcomes in trauma intensive care unit survivors without intracranial hemorrhage. Journal of Trauma-Injury Infection & Critical Care. 01. 2007;62(1):80-8. Not eligible outcomes.
790 Jackson KM, Sher KJ, Cooper ML, et al. Adolescent alcohol and tobacco use: onset, persistence and trajectories of use across two samples. Addiction. 05. 2002;97(5):517-31. Not eligible outcomes. [pmid: 12033653].
791 Jackson LA, Nelson JC, Benson P, et al. Functional status is a confounder of the association of influenza vaccine and risk of all cause mortality in seniors. Int J Epidemiol. 04. 2006;35(2):345-52. Review. [pmid: 16368724].
792 Jackson ME, Burwell B, Clark RF, et al. Eligibility for publicly financed home care. Am J Public Health. 06. 1992;82(6):853-6. Not eligible outcomes. [pmid: 1533996].
793 Jackson RA, Vittinghoff E, Kanaya AM, et al. Urinary incontinence in elderly women: findings from the Health, Aging, and Body Composition Study. Obstetrics & Gynecology. 08. 2004;104(2):301-7. Not eligible outcomes. [pmid: 15292003].
794 Jacqmin-Gadda H, Fourrier A, Commenges D, et al. Risk factors for fractures in the elderly. Epidemiology. 07. 1998;9(4):417-23. Not eligible outcomes. [pmid: 9647906].
795 Jaeger AA, Hlatky MA, Paul SM, et al. Functional capacity after cardiac surgery in elderly patients. Journal of the American College of Cardiology. 07. 1994;24(1):104-8. Not eligible outcomes. [pmid: 8006250].
796 James ML, Wiley E, Fries BE. Predicting nursing facility transition candidates using AID: a case study. Gerontologist. 10. 2007;47(5):625-32. Not eligible outcomes. [pmid: 17989404].
797 James NT, Miller CW, Brown KC, et al. Pain disability among older adults with arthritis. J Aging Health. 02. 2005;17(1):56-69. Not eligible outcomes. [pmid: 15601783].
798 James NT, Miller CW, Fos PJ, et al. Health status, physical disability, and obesity among adult Mississippians with chronic joint symptoms or doctor-diagnosed arthritis: findings from the Behavioral Risk Factor Surveillance System, 2003. Prev Chronic Dis. 07. 2008;5(3):A85. Not eligible outcomes. [pmid: 18558035].
799 Jang Y, Kim G, Chiriboga DA. Health perception and depressive symptoms among older Korean Americans. J Cross Cult Gerontol. 09–12. 2006;21(3–4):91-102. Not eligible outcomes. [pmid: 17195097].
800 Janssen B, Weinmann S, Berger M, et al. Validation of polypharmacy process measures in inpatient schizophrenia care. Schizophr Bull. 2004;30(4):1023-33. Not eligible outcomes. [pmid: 15954205].
801 Janssen F, Nusselder WJ, Looman CW, et al. Stagnation in mortality decline among elders in the Netherlands. Gerontologist. 10. 2003;43(5):722-34. Not eligible exposure. [pmid: 14570968].
802 Janssen I, Katzmarzyk PT, Church TS, et al. The Cooper Clinic Mortality Risk Index: clinical score sheet for men. Am J Prev Med. 10. 2005;29(3):194-203. Not eligible outcome. [pmid: 16168868].
803 Jazwinski SM. Biological aging research today: potential, peeves, and problems. Exp Gerontol. 10–11. 2002;37(10–11):1141-6. Not eligible outcomes. [pmid: 12470824].
804 Jellinger KA, Jellinger KA. Accuracy of clinical criteria for AD in the Honolulu-Asia Aging Study, a population-based study.[comment]. Neurology. 03. 26. 2002;58(6):989-90. author reply 90. comment. [pmid: 11914431].
805 Jenkins KR, Fultz NH. Functional impairment as a risk factor for urinary incontinence among older Americans. Neurourol Urodyn. 2005;24(1):51-5. Not eligible Outcomes. [pmid: 15578629].
806 Jeste DV, Alexopoulos GS, Bartels SJ, et al. Consensus statement on the upcoming crisis in geriatric mental health: research agenda for the next 2 decades. Archives of General Psychiatry. 09. 1999;56(9):848-53. Review. [pmid: 12884891].
807 Jette AM, Branch LG. A ten-year follow-up of driving patterns among community-dwelling elderly. Hum Factors. 02. 1992;34(1):25-31. Not eligible outcomes. [pmid: 1577500].
808 Jette AM, Pinsky JL, Branch LG, et al. The Framingham Disability Study: physical disability among community-dwelling survivors of stroke. J Clin Epidemiol. 1988;41(8):719-26. Not eligible outcomes. [pmid: 2971099].
809 Jiang H, Fine JP, Chappell R. Semiparametric analysis of survival data with left truncation and dependent right censoring. Biometrics. 06. 2005;61(2):567-75. Not eligible outcomes. [pmid: 16011706].
810 Johannesson M. On the discounting of gained life-years in cost-effectiveness analysis. Int J Technol Assess Health Care. Spring. 1992;8(2):359-64. Not eligible outcomes. [pmid: 1628916].
811 Johannesson M. The cost-effectiveness of hypertension treatment in Sweden: an analysis of the criteria for intervention and the choice of drug treatment. J Hum Hypertens. 02. 1996;10(Suppl 2):S23-6. Not eligible outcomes. [pmid: 8868040].
812 Johannesson M, Meltzer D, O’Conor RM. Incorporating future costs in medical cost-effectiveness analysis: implications for the cost-effectiveness of the treatment of hypertension. Med Decis Making. 10–12. 1997;17(4):382-9. Not eligible outcomes. [pmid: 9343796].
813 Johansen KL, Chertow GM, Jin C, et al. Significance of frailty among dialysis patients. J Am Soc Nephrol. 11. 2007;18(11):2960-7. Not eligible target population. [pmid: 17942958].
814 Johanson JF, Lafferty J. Epidemiology of fecal incontinence: the silent affliction. American Journal of Gastroenterology. 01. 1996;91(1):33-6. Not eligible outcome. [pmid: 8561140].
815 Johnson BC. The case for a new medical cohort: teliatrics. Journal of Health & Social Policy. 1995;6(3):13-40. Not eligible outcomes. [pmid: 10184360].
816 Johnson CD. Therapeutic recreation treats depression in the elderly. Home Health Care Serv Q. 1999;18(2):79-90. Not eligible outcomes. [pmid: 11066730].
817 Johnson DK, Wilkins CH, Morris JC. Accelerated weight loss may precede diagnosis in Alzheimer disease. Arch Neurol. 09. 2006;63(9):1312-7. Not eligible outcomes. [pmid: 16966511].
818 Johnson MF, Kramer AM, Lin MK, et al. Outcomes of older persons receiving rehabilitation for medical and surgical conditions compared with hip fracture and stroke. J Am Geriatr Soc. 11. 2000;48(11):1389-97. Not eligible outcomes. [pmid: 11083313].
819 Johnson RJ, Wolinsky FD. The structure of health status among older adults: disease, disability, functional limitation, and perceived health. J Health Soc Behav. 06. 1993;34(2):105-21. Not eligible exposure. [pmid: 8277124].
820 Johnston JM, Nazar-Stewart V, Kelsey SF, et al. Relationships between cerebrovascular events, APOE polymorphism and Alzheimer’s disease in a community sample. Neuroepidemiology. 11–12. 2000;19(6):320-6. Not eligible outcomes. [pmid: 11060506].
821 Johnston MV, Graves D, Greene M. The uniform postacute assessment tool: systematically evaluating the quality of measurement evidence. Arch Phys Med Rehabil. 11. 2007;88(11):1505-12. Not eligible target population. [pmid: 17964897].
822 Johnston MV, Wood K, Stason WB, et al. Rehabilitative placement of poststroke patients: reliability of the Clinical Practice Guideline of the Agency for Health Care Policy and Research. Arch Phys Med Rehabil. 05. 2000;81(5):539-48. Not eligible outcomes. [pmid: 10807089].
823 Jones ED, Kennedy-Malone L, Wideman L. Early detection of type 2 diabetes among older African Americans. Geriatr Nurs. 01–02. 2004;25(1):24-8. Not eligible outcomes. [pmid: 14976500].
824 Jones GC, Sinclair LB. Multiple health disparities among minority adults with mobility limitations: san application of the ICF framework and codes. Disabil Rehabil. 2008;30(12–13):901-15. Not eligible outcomes. [pmid: 18597985].
825 Jones RN. Racial bias in the assessment of cognitive functioning of older adults. Aging Ment Health. 03. 2003;7(2):83-102. Not eligible outcomes. [pmid: 12745387].
826 Jones RN, Fonda SJ, Jones RN, et al. Use of an IRT-based latent variable model to link different forms of the CES-D from the Health and Retirement Study. Social Psychiatry & Psychiatric Epidemiology. 10. 2004;39(10):828-35. Not eligible outcomes. [pmid: 15669664].
827 Joo MJ, Herdegen JJ, Joo MJ, et al. Sleep apnea in an urban public hospital: assessment of severity and treatment adherence. Journal of Clinical Sleep Medicine. 04. 15. 2007;3(3):285-8. Not eligible outcomes. [pmid: 17561598].
828 Jordan JM, Helmick CG, Renner JB, et al. Prevalence of knee symptoms and radiographic and symptomatic knee osteoarthritis in African Americans and Caucasians: the Johnston County Osteoarthritis Project.[see comment]. Journal of Rheumatology. 01. 2007;34(1):172-80. Not eligible outcome. [pmid: 17216685].
829 Jorgensen T, Johansson S, Kennerfalk A, et al. Prescription drug use, diagnoses, and healthcare utilization among the elderly. Ann Pharmacother. 09. 2001;35(9):1004-9. Not eligible outcomes. [pmid: 11573845].
830 Jorm AF, Masaki KH, Petrovitch H, et al. Cognitive deficits 3 to 6 years before dementia onset in a population sample: the Honolulu-Asia aging study. J Am Geriatr Soc. 03. 2005;53(3):452-5. Not eligible outcomes. [pmid: 15743288].
831 Joseph J, Koka M, Aronow WS. Prevalence of a hemoglobin A1c less than 7.0%, of a blood pressure less than 130/80 mm Hg, and of a serum low-density lipoprotein cholesterol less than 100 mg/dL in older patients with diabetes mellitus in an academic nursing home. J Am Med Dir Assoc. 01. 2008;9(1):51-4. Not eligible population. [pmid: 18187113].
832 Jung S, Coleman A, Weintraub NT. Vision screening in the elderly. Journal of the American Medical Directors Association. 07. 2007;8(6):355-62. Review. [pmid: 17619034].
833 Justice AC, Landefeld CS, Asch SM, et al. Justification for a new cohort study of people aging with and without HIV infection. Journal of Clinical Epidemiology. 12. 2001;54(Suppl 1):S3-8. Not elgible target population. [pmid: 11750202].
834 Jylha M, Volpato S, Guralnik JM. Self-rated health showed a graded association with frequently used biomarkers in a large population sample. J Clin Epidemiol. 05. 2006;59(5):465-71. Not eligible outcomes. [pmid: 16632134].
835 Jyrkka J, Enlund H, Korhonen MJ, et al. Patterns of drug use and factors associated with polypharmacy and excessive polypharmacy in elderly persons: results of the Kuopio 75+ study: a cross-sectional analysis. Drugs Aging. 2009;26(6):493-503. Not eligible outcomes. [pmid: 19591524].
836 Jyrkka J, Vartiainen L, Hartikainen S, et al. Increasing use of medicines in elderly persons: a five-year follow-up of the Kuopio 75+Study. Eur J Clin Pharmacol. 02. 2006;62(2):151-8. Not eligible outcomes. [pmid: 16408226].
837 Kado DM, Duong T, Stone KL, et al. Incident vertebral fractures and mortality in older women: a prospective study. Osteoporos Int. 07. 2003;14(7):589-94. Not eligible outcomes. [pmid: 12827222].
838 Kadushin G, Kulys R. Discharge planning revisited: what do social workers actually do in discharge planning. Soc Work. 11. 1993;38(6):713-26. Not eligible outcomes. [pmid: 8256143].
839 Kagansky N, Berner Y, Koren-Morag N, et al. Poor nutritional habits are predictors of poor outcome in very old hospitalized patients. Am J Clin Nutr. 10. 2005;82(4):784-91. quiz 913–4. Not eligible target population. [pmid: 16210707].
840 Kagansky N, Levy S, Keter D, et al. Non-alcoholic fatty liver disease--a common and benign finding in octogenarian patients. Liver International. 12. 2004;24(6):588-94. Not eligible target population. [pmid: 15566509].
841 Kahonen MH, Tilvis RS, Jolkkonen J, et al. Predictors and clinical significance of declining plasma dehydroepiandrosterone sulfate in old age. Aging (Milano). 08. 2000;12(4):308-14. Not eligible outcomes. [pmid: 11073351].
842 Kalaydjian A, Zandi PP, Swartz KL, et al. How migraines impact cognitive function: findings from the Baltimore ECA, Neurology. [see comment][summary for patients in Neurology. 2007 Apr 24; 68(17):E23-4; PMID: 17452572]. 04. 24. 2007;68(17):1417-24. Not eliglble exposure.
843 Kalmijn S, Foley D, White L, et al. Metabolic cardiovascular syndrome and risk of dementia in Japanese-American elderly men. The Honolulu-Asia aging study. Arteriosclerosis, Thrombosis & Vascular Biology. 10. 2000;20(10):2255-60. Not eligible exposure.
844 Kalogeropoulos A, Georgiopoulou V, Kritchevsky SB, et al. Epidemiology of incident heart failure in a contemporary elderly cohort: the health, aging, and body composition study. Arch Intern Med. 04. 13. 2009;169(7):708-15. Not eligible outcomes. [pmid: 19365001].
845 Kanagala R, Murali NS, Friedman PA, et al. Obstructive sleep apnea and the recurrence of atrial fibrillation. Circulation. 05. 27. 2003;107(20):2589-94. Not eligible outcomes. [pmid: 12743002].
846 Kane RA, Wilson KB. Improving practice through research in and about assisted living: implications for a research agenda. Gerontologist. 2007;47(Spec No 3):4-7. Not eligible outcomes. [pmid: 18162564].
847 Kane RL, Chen Q, Finch M, et al. Functional outcomes of posthospital care for stroke and hip fracture patients under medicare. J Am Geriatr Soc. 12. 1998;46(12):1525-33. Not eligible outcomes. [pmid: 9848813].
848 Kane RL, Kane RA, editors. Assessing Older Persons: Measures, Meaning, and Practical Applications. New York. Oxford University Press. 2000. Not eligible outcomes.
849 Kane RL, Ouslander JG, Abrass IB, et al. Essentials of Clinical Geriatrics. 6. New York. McGraw Hill. 2009. Not eligible outcomes.
850 Kaneene JB, Miller R, Ross W, et al. Patterns of health maintenance on Michigan equine operations. Preventive Veterinary Medicine. 01. 1997;29(3):201-20. Not eligible outcomes. [pmid: 9234405].
851 Kang JH, Grodstein F, Kang JH, et al. Plasma carotenoids and tocopherols and cognitive function: a prospective study. Neurobiology of aging. 09. 2008;29(9):1394-403. Not eligible outcomes. [pmid: 17433501].
852 Kang JH, Weuve J, Grodstein F, et al. Postmenopausal hormone therapy and risk of cognitive decline in community-dwelling aging women. Neurology. 07. 13. 2004;63(1):101-7. Not eligible exposure. [pmid: 15249618].
853 Kant AK, Schatzkin A, Graubard BI, et al. Frequency of eating occasions and weight change in the NHANES I Epidemiologic Follow-up Study. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 07. 1995;19(7):468-74. Not eligible outcomes. [pmid: 8520636].
854 Karlamangla AS, Singer BH, Reuben DB, et al. Increases in serum non-high-density lipoprotein cholesterol may be beneficial in some high-functioning older adults: MacArthur studies of successful aging. J Am Geriatr Soc. 04. 2004;52(4):487-94. Not eligible outcomes. [pmid: 15066061].
855 Karp A, Andel R, Parker MG, et al. Mentally stimulating activities at work during midlife and dementia risk after age 75: follow-up study from the Kungsholmen Project. American Journal of Geriatric Psychiatry. 03. 2009;17(3):227-36. Not eligible outcomes. [pmid: 19454849].
856 Kasper JD, Shapiro S, Guralnik JM, et al. Designing a community study of moderately to severely disabled older women: the Women’s Health and Aging Study. Ann Epidemiol. 11. 1999;9(8):498-507. Not eligible outcomes. [pmid: 10549883].
857 Katsiaras A, Newman AB, Kriska A, et al. Skeletal muscle fatigue, strength, and quality in the elderly: the Health ABC Study. Journal of Applied Physiology. 07. 2005;99(1):210-6. Not eligible outcomes. [pmid: 15718402].
858 Katz IR, Lesher E, Kleban M, et al. Clinical features of depression in the nursing home. Int Psychogeriatr. Spring. 1989;1(1):5-15. Not eligible target population. [pmid: 2518789].
859 Kaufer DI, Williams CS, Braaten AJ, et al. Cognitive screening for dementia and mild cognitive impairment in assisted living: comparison of 3 tests. J Am Med Dir Assoc. 10. 2008;9(8):586-93. Not eligible outcomes. [pmid: 19083293].
860 Kausch O. Cocaine abuse in the elderly: a series of three case reports. J Nerv Ment Dis. 08. 2002;190(8):562-5. Not eligible outcomes. [pmid: 12193845].
861 Kearney MT, Nolan J, Lee AJ, et al. A prognostic index to predict long-term mortality in patients with mild to moderate chronic heart failure stabilised on angiotensin converting enzyme inhibitors. Eur J Heart Fail. 08. 2003;5(4):489-97. Not eligible outcomes. [pmid: 12921810].
862 Keefover RW, Rankin ED, Keyl PM, et al. Dementing illnesses in rural populations: the need for research and challenges confronting investigators. J Rural Health. Summer. 1996;12(3):178-87. Not eligible outcomes. [pmid: 10172872].
863 Keller CR, Odden MC, Fried LF, et al. Kidney function and markers of inflammation in elderly persons without chronic kidney disease: the health, aging, and body composition study. Kidney Int. 02. 2007;71(3):239-44. Not eligible outcomes. [pmid: 17183246].
864 Kelley-Gillespie N. Mobile medical care units: an innovative use of Medicare funding. J Health Soc Policy. 2005;20(2):33-48. Not eligible outcomes. [pmid: 16048881].
865 Kelley-Moore JA, Schumacher JG, Kahana E, et al. When do older adults become “disabled”? Social and health antecedents of perceived disability in a panel study of the oldest old. J Health Soc Behav. 06. 2006;47(2):126-41. Not eligible outcomes. [pmid: 16821507].
866 Kelsey SG, Laditka SB, Laditka JN. Transitioning dementia residents from assisted living to memory care units: a pilot study. American Journal of Alzheimer’s Disease & Other Dementias. 08–09. 2008;23(4):355-62. Not eligible outcomes. [pmid: 18375532].
867 Kenefick AL, Kenefick AL. Patterns of symptom distress in older women after surgical treatment for breast cancer. Oncology Nursing Forum Online. 03. 2006;33(2):327-35. Not eligible outcomes.
868 Kennedy J. Unmet and undermet need for activities of daily living and instrumental activities of daily living assistance among adults with disabilities: estimates from the 1994 and 1995 disability follow-back surveys. Med Care. 12. 2001;39(12):1305-12. Not eligible population. [pmid: 11717572].
869 Kent R, Henary B, Matsuoka F. On the fatal crash experience of older drivers. Annu Proc Assoc Adv Automot Med. 2005;49:371-91. Not eligible outcomes. [pmid: 16179160].
870 Kerber CS, Black DW, Buckwalter K. Comorbid psychiatric disorders among older adult recovering pathological gamblers. Issues Ment Health Nurs. 09. 2008;29(9):1018-28. Not eligible outcomes. [pmid: 18770105].
871 Kerber CS, Dyck MJ, Culp KR, et al. Antidepressant treatment of depression in rural nursing home residents. Issues Ment Health Nurs. 09. 2008;29(9):959-73. Not eligible target population. [pmid: 18770101].
872 Kevorkian CG, Nambiar SV, Rintala DH. Low ejection fraction: effect on the rehabilitation progress and outcome of stroke patients. Am J Phys Med Rehabil. 09. 2005;84(9):655-61. Not eligible outcomes. [pmid: 16141741].
873 Kezirian EJ, Harrison SL, Ancoli-Israel S, et al. Behavioral correlates of sleep-disordered breathing in older women. Sleep. 09. 1. 2007;30(9):1181-8. Not eligible outcomes. [pmid: 17910390].
874 Khachaturian AS, Corcoran CD, Mayer LS, et al. Apolipoprotein E epsilon4 count affects age at onset of Alzheimer disease, but not lifetime susceptibility: The Cache County Study. Archives of General Psychiatry. 05. 2004;61(5):518-24. Not eligible outcomes. [pmid: 15123497].
875 Khokhar SR, Stern Y, Bell K, et al. Persistent mobility deficit in the absence of deficits in activities of daily living: a risk factor for mortality. J Am Geriatr Soc. 11. 2001;49(11):1539-43. Not eligible exposure. [pmid: 11890596].
876 Kim H, Capezuti E, Boltz M, et al. Factor structure of the geriatric care environment scale. Nurs Res. 09–10. 2007;56(5):339-47. Not eligible outcomes. [pmid: 17846555].
877 Kim I, Williamson DF, Byers T, et al. Vitamin and mineral supplement use and mortality in a US cohort.[see comment]. American Journal of Public Health. 04. 1993;83(4):546-50. Not eligible outcomes. [pmid: 8460732].
878 Kinder LS, Bryson CL, Sun H, et al. Alcohol screening scores and all-cause mortality in male Veterans Affairs patients. J Stud Alcohol Drugs. 03. 2009;70(2):253-60. Not eligible exposure. [pmid: 19261237].
879 Klarin I, Fastbom J, Wimo A. A population-based study of drug use in the very old living in a rural district of Sweden, with focus on cardiovascular drug consumption: comparison with an urban cohort. Pharmacoepidemiol Drug Saf. 12. 2003;12(8):669-78. Not eligible outcomes. [pmid: 14762983].
880 Klay M, Marfyak K. Use of a continence nurse specialist in an extended care facility. Urol Nurs. 04. 2005;25(2):101-2. 7. 8. Not eligible target population. [pmid: 15900978].
881 Klein BE, Cruickshanks KJ, Nondahl DM, et al. Cataract and hearing loss in a population-based study: the Beaver Dam studies. American Journal of Ophthalmology. 10. 2001;132(4):537-43. Not eligible outcomes. [pmid: 11589876].
882 Klein BE, Klein R, Lee KE. Diabetes, cardiovascular disease, selected cardiovascular disease risk factors, and the 5-year incidence of age-related cataract and progression of lens opacities: the Beaver Dam Eye Study. American Journal of Ophthalmology. 12. 1998;126(6):782-90. Not eligible outcomes. [pmid: 9860001].
883 Klein BE, Klein R, Lee KE, et al. Performance-based and self-assessed measures of visual function as related to history of falls, hip fractures, and measured gait time. The Beaver Dam Eye Study Ophthalmology. 01. 1998;105(1):160-4. Not eligible exposure.
884 Klein BE, Klein R, Lee KE, et al. Drug use and five-year incidence of age-related cataracts: The Beaver Dam Eye Study. Ophthalmology. 09. 2001;108(9):1670-4. Not eligible outcome. [pmid: 11535471].
885 Klein BE, Klein R, Lee KE, et al. Incidence of age-related cataract over a 10-year interval: the Beaver Dam Eye Study. Ophthalmology. 11. 2002;109(11):2052-7. Not eligible outcomes. [pmid: 12414414].
886 Klein BE, Knudtson MD, Lee KE, et al. Supplements and age-related eye conditions the beaver dam eye study. Ophthalmology. 07. 2008;115(7):1203-8. Not eligible outcomes. [pmid: 17997484].
887 Klein JP. Semiparametric estimation of random effects using the Cox model based on the EM algorithm. Biometrics. 09. 1992;48(3):795-806. Not eligible outcomes. [pmid: 1420842].
888 Klein R, Klein BE, Knudtson MD, et al. Fifteen-year cumulative incidence of age-related macular degeneration: the Beaver Dam Eye Study. Ophthalmology. 02. 2007;114(2):253-62. Not eligible outcome. [pmid: 17270675].
889 Klein WC, Jess C. One last pleasure? Alcohol use among elderly people in nursing homes. Health Soc Work. 08. 2002;27(3):193-203. Not eligible target population. [pmid: 12230044].
890 Klonoff-Cohen H, Barrett-Connor EL, Edelstein SL. Albumin levels as a predictor of mortality in the healthy elderly. J Clin Epidemiol. 03. 1992;45(3):207-12. Not eligible target population. [pmid: 1569417].
891 Klymko KW, Artinian NT, Washington OG, et al. Effect of impaired cognition on hypertension outcomes in older urban African Americans. Medsurg Nurs. 12. 2008;17(6):405-10. Not eligible outcomes. [pmid: 19248406].
892 Knutson KL, Knutson KL. Sex differences in the association between sleep and body mass index in adolescents. Journal of Pediatrics. 12. 2005;147(6):830-4. Not eligible outcomes. [pmid: 16356441].
893 Ko D, Wang Y, Berger AK, et al. Nonsteroidal antiinflammatory drugs after acute myocardial infarction. American Heart Journal. 03. 2002;143(3):475-81. Not eligible target population. [pmid: 11868054].
894 Kobayashi I, Sledjeski EM, Spoonster E, et al. Effects of early nightmares on the development of sleep disturbances in motor vehicle accident victims. Journal of Traumatic Stress. 12. 2008;21(6):548-55. Not eligible outcomes. [pmid: 19107721].
895 Koenig HG. Depression in hospitalized older patients with congestive heart failure. General Hospital Psychiatry. 01. 1998;20(1):29-43. Not eligible outcomes. [pmid: 9506252].
896 Koenig HG, George LK, Titus P. Religion, spirituality, and health in medically ill hospitalized older patients. J Am Geriatr Soc. 04. 2004;52(4):554-62. Not eligible outcomes. [pmid: 15066070].
897 Koenig HG, Meador KG, Cohen HJ, et al. Screening for depression in hospitalized elderly medical patients: taking a closer look. J Am Geriatr Soc. 10. 1992;40(10):1013-7. Not elgible target population. [pmid: 1401673].
898 Koepsell TD, Wolf ME, Buchner DM, et al. Footwear style and risk of falls in older adults. J Am Geriatr Soc. 09. 2004;52(9):1495-501. Not eligible outcomes. [pmid: 15341551].
899 Kogut SJ, El-Maouche D, Abughosh SM. Decreased persistence to cholinesterase inhibitor therapy with concomitant use of drugs that can impair cognition. Pharmacotherapy. 12. 2005;25(12):1729-35. Not eligible outcomes. [pmid: 16305292].
900 Kohout FJ, Berkman LF, Evans DA, et al. Two shorter forms of the CES-D (Center for Epidemiological Studies Depression) depression symptoms index. J Aging Health. 05. 1993;5(2):179-93. Not eligible outcomes. [pmid: 10125443].
901 Kominski G, Andersen R, Bastani R, et al. UPBEAT: the impact of a psychogeriatric intervention in VA medical centers. Unified Psychogeriatric Biopsychosocial Evaluation and Treatment. Med Care. 05. 2001;39(5):500-12. Not eligible outcomes. [pmid: 11317098].
902 Konig HH, Gunther OH, Angermeyer MC, et al. Utility assessment in patients with mental disorders: validity and discriminative ability of the time tradeoff method. Pharmacoeconomics. 2009;27(5):405-19. Not eligible outcomes. [pmid: 19586078].
903 Kontodimopoulos N, Niakas D. An estimate of lifelong costs and QALYs in renal replacement therapy based on patients’ life expectancy. Health Policy. 04. 2008;86(1):85-96. Not eligible outcomes. [pmid: 17996975].
904 Koopman K, Uyttenboogaart M, Vroomen PC, et al. Long-term sequelae after cerebral venous thrombosis in functionally independent patients. Journal of Stroke & Cerebrovascular Diseases. 05–06. 2009;18(3):198-202. Not eligible outcomes. [pmid: 19426890].
905 Korf ES, White LR, Scheltens P, et al. Brain aging in very old men with type 2 diabetes: the Honolulu-Asia Aging Study. Diabetes Care. 10. 2006;29(10):2268-74. Not eligible outcomes. [pmid: 17003305].
906 Koroukian SM, Murray P, Madigan E. Comorbidity, disability, and geriatric syndromes in elderly cancer patients receiving home health care. J Clin Oncol. 05. 20. 2006;24(15):2304-10. Not eligible outcomes. [pmid: 16710028].
907 Kotz K, Deleger S, Cohen R, et al. Osteoporosis and health-related quality-of-life outcomes in the Alameda County Study population. Prev Chronic Dis. 01. 2004;1(1):A05. Not eligible exposure. [pmid: 15634367].
908 Kovar MG. Functional ability and the need for care: issues for measurement research. Vital Health Stat. 08. 1991;5(6):97-103. Not eligible outcomes.
909 Kozauer NA, Mielke MM, Chan GK, et al. Apolipoprotein E genotype and lifetime cognitive decline. International Psychogeriatrics. 02. 2008;20(1):109-23. Not eligible outcomes. [pmid: 17711604].
910 Krahenbuhl JM, Decollogny A, Bugnon O. Using the costs of drug therapy to screen patients for a community pharmacy-based medication review program. Pharm World Sci. 12. 2008;30(6):816-22. Not eligible outcomes. [pmid: 18551382].
911 Krall EA, Garvey AJ, Garcia RI, et al. Smoking relapse after 2 years of abstinence: findings from the VA Normative Aging Study. Nicotine & Tobacco Research. 02. 2002;4(1):95-100. Not elgible target population. [pmid: 11906685].
912 Krause JS, Broderick L. A 25-year longitudinal study of the natural course of aging after spinal cord injury. Spinal Cord. 06. 2005;43(6):349-56. Not eligible outcomes. [pmid: 15711611].
913 Krause N. Age and decline in role-specific feelings of control. J Gerontol B Psychol Sci Soc Sci. 01. 2007;62(1):S28-35. Not eligible outcomes. [pmid: 17284563].
914 Kravitz HM, Janssen I, Santoro N, et al. Relationship of day-to-day reproductive hormone levels to sleep in midlife women. Archives of Internal Medicine. 11. 14. 2005;165(20):2370-6. Not eligible outcomes. [pmid: 16287766].
915 Kress D. Hospital and physician partnership succeeds with Medicare managed care. Med Manag Netw. 11. 1998;6(11):1-4. Not eligible outcomes. [pmid: 10187429].
916 Kressin NR, Atchison KA, Miller DR. Comparing the impact of oral disease in two populations of older adults: application of the geriatric oral health assessment index. J Public Health Dent. Fall. 1997;57(4):224-32. Not eligible outcomes. [pmid: 9558626].
917 Kroenke CH, Kubzansky LD, Adler N, et al. Prospective change in health-related quality of life and subsequent mortality among middle-aged and older women. American Journal of Public Health. 11. 2008;98(11):2085-91. Not eligible target population. [pmid: 18511734].
918 Kroenke CH, Rosner B, Chen WY, et al. Functional impact of breast cancer by age at diagnosis. Journal of Clinical Oncology. 05. 15. 2004;22(10):1849-56. Not eligible outcomes. [pmid: 15143077].
919 Krumholz HM, Parent EM, Tu N, et al. Readmission after hospitalization for congestive heart failure among Medicare beneficiaries. Arch Intern Med. 01. 13. 1997;157(1):99-104. Not eligible outcomes. [pmid: 8996046].
920 Kruse RL, Mehr DR, Boles KE, et al. Does hospitalization impact survival after lower respiratory infection in nursing home residents. Med Care. 09. 2004;42(9):860-70. Not eligible outcomes. [pmid: 15319611].
921 Ku PW, Fox KR, Chen LJ. Physical activity and depressive symptoms in Taiwanese older adults: a seven-year follow-up study. Preventive medicine. 03. 2009;48(3):250-5. Not eligible outcomes. [pmid: 19297687].
922 Kubzansky LD, Kawachi I, Sparrow D. Socioeconomic status, hostility, and risk factor clustering in the Normative Aging Study: any help from the concept of allostatic load?. Annals of Behavioral Medicine. Fall. 1999;21(4):330-8. Not eligible outcomes. [pmid: 10721441].
923 Kubzansky LD, Koenen KC, Spiro A 3rd, et al. Prospective study of posttraumatic stress disorder symptoms and coronary heart disease in the Normative Aging Study. Archives of General Psychiatry. 01. 2007;64(1):109-16. Not eligible outcomes. [pmid: 17199060].
924 Kucharska-Newton AM, Couper DJ, Pankow JS, et al. Hemostasis, inflammation, and fatal and nonfatal coronary heart disease: long-term follow-up of the atherosclerosis risk in communities (ARIC) cohort. Arteriosclerosis, Thrombosis & Vascular Biology. 12. 2009;29(12):2182-90. Not eligible outcomes.
925 Kuchel GA. Chapter 51 Aging and Homeostatic Regulation. Halter JB, Hazzard W, Ouslander JG, et al., editors. Hazzard’s Geriatric Medicine and Gerontology. 6. New York. McGraw-Hill. 2009. Not eligible outcomes.
926 Kulminski A, Ukraintseva SV, Arbeev KG, et al. Association between APOE epsilon 2/epsilon 3/epsilon 4 polymorphism and disability severity in a national long-term care survey sample. Age Ageing. 05. 2008;37(3):288-93. Not eligible outcomes. [pmid: 18250093].
927 Kulminski A, Yashin A, Ukraintseva S, et al. Accumulation of health disorders as a systemic measure of aging: Findings from the NLTCS data. Mech Ageing Dev. 11. 2006;127(11):840-8. Not eligible population. [pmid: 16978683].
928 Kunin CM, Douthitt S, Dancing J, et al. The association between the use of urinary catheters and morbidity and mortality among elderly patients in nursing homes. Am J Epidemiol. 02. 1. 1992;135(3):291-301. Not eligible target population. [pmid: 1546705].
929 Kupari M, Lindroos M, Iivanainen AM, et al. Congestive heart failure in old age: prevalence, mechanisms and 4-year prognosis in the Helsinki Ageing Study. J Intern Med. 05. 1997;241(5):387-94. Not eligible outcomes. [pmid: 9183306].
930 Kuriacose R, Olive KE, Kuriacose R, et al. Prevalence of vitamin D deficiency and insufficiency in northeast Tennessee. Southern Medical Journal. 09. 2008;101(9):906-9. Not eligible outcomes. [pmid: 18708969].
931 Kurlowicz LH, Outlaw FH, Ratcliffe SJ, et al. An exploratory study of depression among older African American users of an academic outpatient rehabilitation program. Arch Psychiatr Nurs. 02. 2005;19(1):3-9. Not eligibe outcomes. [pmid: 15765366].
932 Kurtz ME, Kurtz JC, Given CW, et al. Utilization of services among elderly cancer patients--relationship to age, symptoms, physical functioning, comorbidity, and survival status. Ethn Dis. Spring. 2005;15(2 Suppl 2):S17-22. Not eligible outcomes. [pmid: 15822832].
933 Kutner NG, Ory MG, Baker DI, et al. Measuring the quality of life of the elderly in health promotion intervention clinical trials. Public Health Rep. 09–10. 1992;107(5):530-9. Not eligible outcomes. [pmid: 1410233].
934 Kuzuya M, Kanda S, Koike T, et al. Evaluation of Mini-Nutritional Assessment for Japanese frail elderly. Nutrition. 04. 2005;21(4):498-503. Not eligible target population. [pmid: 15811771].
935 Lachs MS, Feinstein AR, Cooney LM Jr, et al. A simple procedure for general screening for functional disability in elderly patients. Ann Intern Med. 05. 1. 1990;112(9):699-706. Not eligible outcomes. [pmid: 2334082].
936 LaClair RE, Hellman RN, Karp SL, et al. Prevalence of calcidiol deficiency in CKD: a cross-sectional study across latitudes in the United States.[see comment]. American Journal of Kidney Diseases. 06. 2005;45(6):1026-33. Not eligible outcomes. [pmid: 15957131].
937 Laditka JN, Laditka SB, Eleazer GP, et al. High variation in Alzheimer’s disease prevalence among South Carolina counties. J S C Med Assoc. 10. 2008;104(7):215-8. Not eligible outcomes. [pmid: 19058733].
938 LaFleur J, McBeth C, Gunning K, et al. Prevalence of drug-related problems and cost-savings opportunities in medicaid high utilizers identified by a pharmacist-run drug regimen review center. J Manag Care Pharm. 10. 2006;12(8):677-85. Not eligible outcomes. [pmid: 17269846].
939 Laforge RG, Mignon SI. Alcohol use and alcohol problems among the elderly. R I Med. 01. 1993;76(1):21-6. Not eligible outcomes. [pmid: 8428028].
940 Lagergren M, Fratiglioni L, Hallberg IR, et al. A longitudinal study integrating population, care and social services data. The Swedish National study on Aging and Care (SNAC). Aging Clin Exp Res. 04. 2004;16(2):158-68. Not eligible outcomes. [pmid: 15195992].
941 Lai DW. Measuring depression of elderly Chinese Americans: a replication study. Home Health Care Serv Q. 2003;22(2):69-85. Not eligible outcomes. [pmid: 12870713].
942 Lakey SL, Gray SL, Sales AE, et al. Psychotropic use in community residential care facilities: A prospective cohort study. American Journal Geriatric Pharmacotherapy. 09. 2006;4(3):227-35. Not eligible target population.
943 Lally F, Crome P. Understanding frailty. Postgrad Med J. 01. 2007;83(975):16-20. Not eligible outcomes. [pmid: 17267673].
944 Lamb SE, McCabe C, Becker C, et al. The optimal sequence and selection of screening test items to predict fall risk in older disabled women: the Women’s Health and Aging Study. J Gerontol A Biol Sci Med Sci. 10. 2008;63(10):1082-8. Not eligible outcomes. [pmid: 18948559].
945 Landgraff NC, Whitney SL, Rubinstein EN, et al. Use of the physical performance test to assess preclinical disability in subjects with asymptomatic carotid artery disease. Phys Ther. 04. 2006;86(4):541-8. Not eligible outcomes. [pmid: 16579670].
946 Landi F, Gambassi G, Lapane KL, et al. Comorbidity and drug use in cognitively impaired elderly living in long-term care. Dement Geriatr Cogn Disord. 11–12. 1998;9(6):347-56. Not eligible target population. [pmid: 9769448].
947 Landi F, Onder G, Cattel C, et al. Functional status and clinical correlates in cognitively impaired community-living older people. J Geriatr Psychiatry Neurol. Spring. 2001;14(1):21-7. Not eligibe outcomes. [pmid: 11281312].
948 Landi F, Russo A, Danese P, et al. Anemia status, hemoglobin concentration, and mortality in nursing home older residents. J Am Med Dir Assoc. 06. 2007;8(5):322-7. Not eligible target population. [pmid: 17570312].
949 Landrigan CP, Barger LK, Cade BE, et al. Interns’ compliance with accreditation council for graduate medical education work-hour limits. JAMA. 09. 6. 2006;296(9):1063-70. Not eligible outcomes. [pmid: 16954485].
950 Lang IA, Guralnik JM, Melzer D. Physical activity in middle-aged adults reduces risks of functional impairment independent of its effect on weight. J Am Geriatr Soc. 11. 2007;55(11):1836-41. Not eligible outcomes. [pmid: 17979901].
951 Lang PO, Heitz D, Hedelin G, et al. Early markers of prolonged hospital stays in older people: a prospective, multicenter study of 908 inpatients in French acute hospitals. J Am Geriatr Soc. 07. 2006;54(7):1031-9. Not eligible target population. [pmid: 16866672].
952 Lang W. Frailty selection and HIV. Lancet. 06. 17. 1989;1(8651):1397. Not eligible outcomes. [pmid: 2567419].
953 Langa KM, Plassman BL, Wallace RB, et al. The Aging, Demographics, and Memory Study: study design and methods. Neuroepidemiology. 2005;25(4):181-91. Not eligible outcomes. [pmid: 16103729].
954 Laniece I, Couturier P, Drame M, et al. Incidence and main factors associated with early unplanned hospital readmission among French medical inpatients aged 75 and over admitted through emergency units. Age Ageing. 07. 2008;37(4):416-22. Not eligible outcomes. [pmid: 18487268].
955 Lapid MI, Rummans TA. Evaluation and management of geriatric depression in primary care. Mayo Clinic proceedings. 11. 2003;78(11):1423-9. Not eligible outcomes. [pmid: 14601704].
956 Lappe JM, Davies KM, Travers-Gustafson D, et al. Vitamin D status in a rural postmenopausal female population. Journal of the American College of Nutrition. 10. 2006;25(5):395-402. Not eligible exposure. [pmid: 17031008].
957 Larsen WI, Yavorek TA, Larsen WI, et al. Pelvic organ prolapse and urinary incontinence in nulliparous women at the United States Military Academy. International Urogynecology Journal. 05. 2006;17(3):208-10. Not eligible outcomes.
958 Larue S, Verreault S, Gould P, et al. A case of familial Creutzfeldt-Jakob disease presenting with dry cough. Canadian Journal of Neurological Sciences. 05. 2006;33(2):243-5. Not eligible outcomes. [pmid: 16736740].
959 Lauderdale DS, Cagney KA. Limitations to the use of education as an SES indicator in studies of the elderly. Confounding by cognition. Ann N Y Acad Sci. 1999;896:373-5. Not eligible outcomes. [pmid: 10681926].
960 Lauer MS, Pashkow FJ, Snader CE, et al. Age and referral to coronary angiography after an abnormal treadmill thallium test. American Heart Journal. 02. 1997;133(2):139-46. Not eligible outcomes. [pmid: 9023158].
961 Laughlin A, Parsons M, Kosloski KD, et al. Predictors of mortality following involuntary interinstitutional relocation. J Gerontol Nurs. 09. 2007;33(9):20-6. quiz 8–9. Not eligible target population. [pmid: 17899997].
962 Launer LJ, Ross GW, Petrovitch H, et al. Midlife blood pressure and dementia: the Honolulu-Asia aging study. Neurobiology of aging. 01–02. 2000;21(1):49-55. Not eligible exposure. [pmid: 10794848].
963 Laurin D, David Curb J, Masaki KH, et al. Midlife C-reactive protein and risk of cognitive decline: a 31-year follow-up. Neurobiol Aging. 11. 2009;30(11):1724-7. Not eligible outcome. [pmid: 18316138].
964 Laurin D, Masaki KH, White LR, et al. Ankle-to-brachial index and dementia: the Honolulu-Asia Aging Study. Circulation. 11. 13. 2007;116(20):2269-74. Not eligible exposure. [pmid: 17967779].
965 Lavery LL, Starenchak SM, Flynn WB, et al. The clock drawing test is an independent predictor of incident use of 24-hour care in a retirement community. J Gerontol A Biol Sci Med Sci. 07. 2005;60(7):928-32. Not eligible population. [pmid: 16079220].
966 Lawhorne L. Depression in the older adult. Primary Care; Clinics in Office Practice. 09. 2005;32(3):777-92. Not eligible outcomes.
967 Lawhorne LW, Ouslander JG, Parmelee PA, et al. Urinary incontinence: a neglected geriatric syndrome in nursing facilities. Journal of the American Medical Directors Association. 01. 2008;9(1):29-35. Not eligible outcomes. [pmid: 18187110].
968 Lawrence HP, Garcia RI, Essick GK, et al. A longitudinal study of the association between tooth loss and age-related hearing loss. Special Care in Dentistry. 07–08. 2001;21(4):129-40. Not eligible outcomes. [pmid: 11669061].
969 Layton D, Pearce GL, Shakir SA. Safety profile of tolterodine as used in general practice in England: results of prescription-event monitoring. Drug Saf. 2001;24(9):703-13. Not eligible outcomes. [pmid: 11522122].
970 LeBrasseur NK, Sayers SP, Ouellette MM, et al. Muscle impairments and behavioral factors mediate functional limitations and disability following stroke. Phys Ther. 10. 2006;86(10):1342-50. Not eligible outcomes. [pmid: 17012638].
971 Ledikwe JH, Smiciklas-Wright H, Mitchell DC, et al. Nutritional risk assessment and obesity in rural older adults: a sex difference. American Journal of Clinical Nutrition. 03. 2003;77(3):551-8. Not eligible outcomes. [pmid: 12600842].
972 Ledwidge M, Travers B, Ryder M, et al. Specialist care of heart failure improves appropriate pharmacotherapy at the expense of greater polypharmacy and drug-interactions. Eur J Heart Fail. 03. 1. 2004;6(2):235-43. Not eligible outcomes. [pmid: 14984732].
973 Lee AG, Beaver HA, Jogerst G, et al. Screening elderly patients in an outpatient ophthalmology clinic for dementia, depression, and functional impairment. Ophthalmology. 04. 2003;110(4):651-7. discussion 7. Not eligible outcomes. [pmid: 12689881].
974 Lee IM, Paffenbarger RS Jr. Change in body weight and longevity.[see comment]. JAMA. 10. 21. 1992;268(15):2045-9. Not eligible outcomes. [pmid: 1404740].
975 Lee JS, Frongillo EA Jr. Understanding needs is important for assessing the impact of food assistance program participation on nutritional and health status in U.S. elderly persons. Journal of Nutrition. 03. 2001;131(3):765-73. Not eligible outcomes. [pmid: 11238757].
976 Lee JS, Kritchevsky SB, Harris TB, et al. Short-term weight changes in community-dwelling older adults: the Health, Aging, and Body Composition Weight Change Substudy. Am J Clin Nutr. 09. 2005;82(3):644-50. Not eligible outcomes. [pmid: 16155279].
977 Lee JS, Kritchevsky SB, Tylavsky F, et al. Weight change, weight change intention, and the incidence of mobility limitation in well-functioning community-dwelling older adults. J Gerontol A Biol Sci Med Sci. 08. 2005;60(8):1007-12. Not eligible exposure. [pmid: 16127104].
978 Lee JS, Kritchevsky SB, Tylavsky FA, et al. Weight-loss intention in the well-functioning, community-dwelling elderly: associations with diet quality, physical activity, and weight change. Am J Clin Nutr. 08. 2004;80(2):466-74. Not eligible outcomes. [pmid: 15277172].
979 Lee KE, Klein BE, Klein R. Changes in refractive error over a 5-year interval in the Beaver Dam Eye Study. Investigative Ophthalmology & Visual Science. 07. 1999;40(8):1645-9. Not eligible outcomes. [pmid: 10393030].
980 Lee KE, Klein BE, Klein R, et al. Changes in refraction over 10 years in an adult population: the Beaver Dam Eye study. Investigative Ophthalmology & Visual Science. 08. 2002;43(8):2566-71. Not eligible outcome. [pmid: 12147586].
981 Lee ML, Rosner BA, Weiss ST. Relationship of blood pressure to cardiovascular death: the effects of pulse pressure in the elderly. Annals of Epidemiology. 02. 1999;9(2):101-7. Not eligible outcomes. [pmid: 10037553].
982 Lee PG, Cigolle C, Blaum C. The co-occurrence of chronic diseases and geriatric syndromes: the health and retirement study. Journal of the American Geriatrics Society. 03. 2009;57(3):511-6. Not eligible outcomes. [pmid: 19187416].
983 Lee PP, Feldman ZW, Ostermann J, et al. Longitudinal prevalence of major eye diseases. Archives of Ophthalmology. 09. 2003;121(9):1303-10. Not eligible outcomes. [pmid: 12963614].
984 Lee R, Tuljapurkar S. Death and taxes: longer life, consumption, and social security. Demography. 02. 1997;34(1):67-81. Not eligible outcomes. [pmid: 9074832].
985 Lee W, Eng C, Fox N, et al. PACE: a model for integrated care of frail older patients. Program of All-inclusive Care for the Elderly. Geriatrics. 06. 5. 1998;53(6):62-6. 9. 73. quiz 4. Not eligible outcomes. [pmid: 9634107].
986 Lee YS. Awareness of blood pressure among older adults: a cross-sectional descriptive study. Int J Nurs Stud. 07. 2007;44(5):796-804. Not eligible outcomes. [pmid: 16569407].
987 Legrand C, Duchateau L, Janssen P, et al. Validation of prognostic indices using the frailty model. Lifetime Data Anal. 03. 2009;15(1):59-78. Not eligible outcomes. [pmid: 18618249].
988 Lehtimaki T, Hervonen A, Rontu R, et al. Survival related to plasma C-reactive-protein in nonagenarians is modified by apolipoprotein E genotype. Clinical Chemistry. 02. 2007;53(2):365-7. Comment. [pmid: 17259254].
989 Leibson CL, Tosteson AN, Gabriel SE, et al. Mortality, disability, and nursing home use for persons with and without hip fracture: a population-based study. J Am Geriatr Soc. 10. 2002;50(10):1644-50. Not eligible exposure. [pmid: 12366617].
990 Leng S, Chaves P, Koenig K, et al. Serum interleukin-6 and hemoglobin as physiological correlates in the geriatric syndrome of frailty: a pilot study. J Am Geriatr Soc. 07. 2002;50(7):1268-71. Not eligible outcomes. [pmid: 12133023].
991 Leng SX, Yang H, Walston JD. Decreased cell proliferation and altered cytokine production in frail older adults. Aging Clin Exp Res. 06. 2004;16(3):249-52. Not eligible outcomes. [pmid: 15462470].
992 Leroi I, Sheppard JM, Lyketsos CG, et al. Cognitive function after 11.5 years of alcohol use: relation to alcohol use.[see comment]. American Journal of Epidemiology. 10. 15. 2002;156(8):747-52. not eligible outcome. [pmid: 12370163].
993 Lethbridge-Cejku M, Tobin JD, Scott WW Jr, et al. The relationship of age and gender to prevalence and pattern of radiographic changes of osteoarthritis of the knee: data from Caucasian participants in the Baltimore Longitudinal Study of Aging. Aging-Clinical & Experimental Research. 10. 1994;6(5):353-7. Not eligible exposure.
994 Leung KK, Tang LY, Chie WC, et al. Mortality trends of elderly people in Taiwan from 1974 to 1994. Age Ageing. 03. 1999;28(2):199-203. Not eligible outcomes. [pmid: 10350419].
995 Leutz W, Brody KK, Nonnenkamp LL, et al. Selection bias between 2 Medicare capitated benefit programs. Am J Manag Care. 04. 2007;13(4):201-7. Not eligible outcomes. [pmid: 17408340].
996 Leveille SG, Bean J, Bandeen-Roche K, et al. Musculoskeletal pain and risk for falls in older disabled women living in the community. Journal of the American Geriatrics Society. 04. 2002;50(4):671-8. Not eligible outcomes. [pmid: 11982667].
997 Leveille SG, Bean J, Ngo L, et al. The pathway from musculoskeletal pain to mobility difficulty in older disabled women. Pain. 03. 2007;128(1–2):69-77. Not eligible outcomes. [pmid: 17055167].
998 Leveille SG, Guralnik JM, Ferrucci L, et al. Aging successfully until death in old age: opportunities for increasing active life expectancy. American Journal of Epidemiology. 04. 1. 1999;149(7):654-64. Not eligible outcomes. [pmid: 10192313].
999 Leveille SG, Penninx BW, Melzer D, et al. Sex differences in the prevalence of mobility disability in old age: the dynamics of incidence, recovery, and mortality. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. 01. 2000;55(1):S41-50. Not eligible outcomes.
1000 Levenson SA, Saffel DA. The consultant pharmacist and the physician in the nursing home: roles, relationships, and a recipe for success. J Am Med Dir Assoc. 01. 2007;8(1):55-64. Not eligible target population. [pmid: 17210503].
1001 Levy BR, Slade MD, Kunkel SR, et al. Longevity increased by positive self-perceptions of aging. Journal of Personality & Social Psychology. 08. 2002;83(2):261-70. Not eligible exposure. [pmid: 12150226].
1002 Levy G, Tang MX, Cote LJ, et al. Motor impairment in PD: relationship to incident dementia and age. Neurology. 08. 22. 2000;55(4):539-44. Not eligible exposure. [pmid: 10953188].
1003 Levy WC, Soine LA, Huth MM, et al. Thiamine deficiency in congestive heart failure.[comment]. American Journal of Medicine. 12. 1992;93(6):705-6. Not eligible outcomes. [pmid: 1466372].
1004 Lewis T. Assessing an older adult for alcohol use disorders. Nursing. 06. 2008;38(6):60-1. Not eligible outcomes. [pmid: 18497665].
1005 Li C, Friedman B, Conwell Y, et al. Validity of the Patient Health Questionnaire 2 (PHQ-2) in identifying major depression in older people. J Am Geriatr Soc. 04. 2007;55(4):596-602. Not eligible outcomes. [pmid: 17397440].
1006 Li Y, Healy EW, Drane JW, et al. Comorbidity between and risk factors for severe hearing and memory impairment in older Americans. Prev Med. 11. 2006;43(5):416-21. Not eligible outcomes. [pmid: 16876854].
1007 Liao S, Ferrell BA. Fatigue in an older population. J Am Geriatr Soc. 04. 2000;48(4):426-30. Not eligible outcomes. [pmid: 10798471].
1008 Lichtenstein MJ, Hazuda HP. Cross-cultural adaptation of the hearing handicap inventory for the Elderly-Screening Version (HHIE-S) for use with Spanish-speaking Mexican Americans. J Am Geriatr Soc. 04. 1998;46(4):492-8. Not eligible outcomes. [pmid: 9560075].
1009 Lichtman JH, Krumholz HM, Wang Y, et al. Risk and predictors of stroke after myocardial infarction among the elderly: results from the Cooperative Cardiovascular Project.[see comment]. Circulation. 03. 5. 2002;105(9):1082-7. Not eligible exposure. [pmid: 11877359].
1010 Liebson CL, Petterson TM, Bailey KR, et al. Risk factors for venous thromboembolism in nursing home residents. Mayo Clin Proc. 02. 2008;83(2):151-7. Not eligible target population. [pmid: 18241624].
1011 Lifford KL, Townsend MK, Curhan GC, et al. The epidemiology of urinary incontinence in older women: incidence, progression, and remission. Journal of the American Geriatrics Society. 07. 2008;56(7):1191-8. Not eligible outcomes. [pmid: 18492035].
1012 Lin MY, Gutierrez PR, Stone KL, et al. Vision impairment and combined vision and hearing impairment predict cognitive and functional decline in older women. Journal of the American Geriatrics Society. 12. 2004;52(12):1996-2002. Not eligible outcomes. [pmid: 15571533].
1013 Lin WC, Lum TY, Mehr DR, et al. Measuring pain presence and intensity in nursing home residents. J Am Med Dir Assoc. 03. 2006;7(3):147-53. Not eligible target population. [pmid: 16503307].
1014 Lind BK, Goodwin JL, Hill JG, et al. Recruitment of healthy adults into a study of overnight sleep monitoring in the home: experience of the Sleep Heart Health Study. Sleep & Breathing. 03. 2003;7(1):13-24. Not eligible outcomes. [pmid: 12712393].
1015 Lindenbaum J, Rosenberg IH, Wilson PW, et al. Prevalence of cobalamin deficiency in the Framingham elderly population.[see comment]. American Journal of Clinical Nutrition. 07. 1994;60(1):2-11. Not eligible outcomes. [pmid: 8017332].
1016 Lindrooth RC, Hoerger TJ, Norton EC. Expectations among the elderly about nursing home entry. Health Serv Res. 12. 2000;35(5 Pt 2):1181-202. Not eligible outcomes. [pmid: 11130816].
1017 Lindsay J, Sykes E, McDowell I, et al. More than the epidemiology of Alzheimer’s disease: contributions of the Canadian Study of Health and Aging. Can J Psychiatry. 02. 2004;49(2):83-91. Review. [pmid: 15065741].
1018 Linnebur SA, Vondracek SF, Vande Griend JP, et al. Prevalence of vitamin D insufficiency in elderly ambulatory outpatients in Denver, Colorado. American Journal Geriatric Pharmacotherapy. 03. 2007;5(1):1-8. Not eligible outcomes.
1019 Linton A, Garber M, Fagan NK, et al. Examination of multiple medication use among TRICARE beneficiaries aged 65 years and older. J Manag Care Pharm. 03. 2007;13(2):155-62. Not eligible outcomes. [pmid: 17330976].
1020 Liperoti R, Gambassi G, Lapane KL, et al. Cerebrovascular events among elderly nursing home patients treated with conventional or atypical antipsychotics. J Clin Psychiatry. 09. 2005;66(9):1090-6. Not eligible target population. [pmid: 16187764].
1021 Lipfert FW, Baty JD, Miller JP, et al. PM2.5 constituents and related air quality variables as predictors of survival in a cohort of U.S. military veterans. Inhalation Toxicology. 08. 2006;18(9):645-57. Not eligible exposure. [pmid: 16864555].
1022 Litonjua AA, Sparrow D, Guevarra L, et al. Serum interferon-gamma is associated with longitudinal decline in lung function among asthmatic patients: the Normative Aging Study. Annals of Allergy, Asthma, & Immunology. 04. 2003;90(4):422-8. Not eligible outcomes.
1023 Littner MR. Snoring in pregnancy. Disease or not?[comment]. Chest. 04. 1996;109(4):859-61. Not eligible outcomes. [pmid: 8635357].
1024 Liu L, Wolfe RA, Huang X. Shared frailty models for recurrent events and a terminal event. Biometrics. 09. 2004;60(3):747-56. Not eligible outcomes. [pmid: 15339298].
1025 Lloyd-Jones DM, Larson MG, Leip EP, et al. Lifetime risk for developing congestive heart failure: the Framingham Heart Study. Circulation. 12. 10. 2002;106(24):3068-72. Not eligible outcomes. [pmid: 12473553].
1026 Lo D, Chiu E, Jassal SV. A prospective pilot study to measure changes in functional status associated with hospitalization in elderly dialysis-dependent patients. Am J Kidney Dis. 11. 2008;52(5):956-61. Not eligible outcomes. [pmid: 18562063].
1027 Loesche WJ, Abrams J, Terpenning MS, et al. Dental findings in geriatric populations with diverse medical backgrounds. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 07. 1995;80(1):43-54. Not eligible outcomes. [pmid: 7552861].
1028 Long HL, Miller WA. Oral status and well-being of home delivered meal recipients. Gerodontology. 12. 1994;11(2):115-23. Not eligible outcomes. [pmid: 7750965].
1029 Long JS, Pavalko E. Comparing alternative measures of functional limitation. Med Care. 01. 2004;42(1):19-27. Not eligible target population. [pmid: 14713736].
1030 Longstreth WT Jr, Bernick C, Fitzpatrick A, et al. Frequency and predictors of stroke death in 5,888 participants in the Cardiovascular Health Study. Neurology. 02. 13. 2001;56(3):368-75. Not eligible outcomes. [pmid: 11171903].
1031 Lopez L. Improving care for the frail elderly. Healthplan. 09–10. 1996;37(5):38-46. Not eligible outcomes. [pmid: 10161663].
1032 Lopez OL, Jagust WJ, Dulberg C, et al. Risk factors for mild cognitive impairment in the Cardiovascular Health Study Cognition Study: part 2. Archives of Neurology. 10. 2003;60(10):1394-9. Not eligible outcomes. [pmid: 14568809].
1033 Loukissa D. Under diagnosis of alcohol misuse in the older adult population. British Journal of Nursing. 11. 8–21. 2007;16(20):1254-8. Review. [pmid: 18073655].
1034 Lu SE, Wang MC. Marginal analysis for clustered failure time data. Lifetime Data Anal. 03. 2005;11(1):61-79. Not eligible outcomes. [pmid: 15747590].
1035 Luchi RJ, Taffet GE, Teasdale TA. Congestive heart failure in the elderly. J Am Geriatr Soc. 08. 1991;39(8):810-25. Not eligible outcomes. [pmid: 2071813].
1036 Luchins DJ, Hanrahan P, Murphy K. Criteria for enrolling dementia patients in hospice. J Am Geriatr Soc. 09. 1997;45(9):1054-9. Not eligible outcomes. [pmid: 9288011].
1037 Luchsinger JA, Reitz C, Patel B, et al. Relation of diabetes to mild cognitive impairment. Archives of Neurology. 04. 2007;64(4):570-5. Not eligible exposure. [pmid: 17420320].
1038 Lucicesare A, Hubbard RE, Searle SD, et al. An index of self-rated health deficits in relation to frailty and adverse outcomes in older adults. Aging Clin Exp Res. 2009. 11. 17. Not eligible outcome.
1039 Luck T, Riedel-Heller SG, Kaduszkiewicz H, et al. Mild cognitive impairment in general practice: age-specific prevalence and correlate results from the German study on ageing, cognition and dementia in primary care patients (AgeCoDe). Dement Geriatr Cogn Disord. 2007;24(4):307-16. Not eligible outcomes. [pmid: 17848793].
1040 Lunney JR, Lynn J, Hogan C. Profiles of older medicare decedents. J Am Geriatr Soc. 06. 2002;50(6):1108-12. Not eligible outcomes. [pmid: 12110073].
1041 Lupon J, Gonzalez B, Santaeugenia S, et al. Prognostic implication of frailty and depressive symptoms in an outpatient population with heart failure. Rev Esp Cardiol. 08. 2008;61(8):835-42. Not eligible outcomes. [pmid: 18684366].
1042 Lutz BJ, Chumbler NR, Lyles T, et al. Testing a home-telehealth programme for US veterans recovering from stroke and their family caregivers. Disabil Rehabil. 2009;31(5):402-9. Not elgible target population. [pmid: 18720112].
1043 Lyketsos CG, Chen LS, Anthony JC. Cognitive decline in adulthood: an 115-year follow-up of the Baltimore Epidemiologic Catchment Area study. Am J Psychiatry. 01. 1999;156(1):58-65. Not eligible target population. [pmid: 9892298].
1044 Lyketsos CG, Steinberg M, Tschanz JT, et al. Mental and behavioral disturbances in dementia: findings from the Cache County Study on Memory in Aging. Am J Psychiatry. 05. 2000;157(5):708-14. Not eligible outcomes. [pmid: 10784462].
1045 Lyles A. The medicare drug benefit, prescribing variations, and drug utilization review. Clin Ther. 01. 2004;26(1):100-1. Not eligible outcomes. [pmid: 14996522].
1046 Lynch SM, Brown JS, Harmsen KG. The Effect of altering ADL thresholds on active life expectancy estimates for older persons. J Gerontol B Psychol Sci Soc Sci. 05. 2003;58(3):S171-8. Not eligible population. [pmid: 12730318].
1047 Lynch SM, George LK, Lynch SM, et al. Interlocking trajectories of loss-related events and depressive symptoms among elders. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. 03. 2002;57(2):S117-25. Not eligible outcomes.
1048 Lyyra TM, Tormakangas TM, Read S, et al. Satisfaction with present life predicts survival in octogenarians. J Gerontol B Psychol Sci Soc Sci. 11. 2006;61(6):P319-26. Not eligible outcomes. [pmid: 17114300].
1049 MacAdam M, Capitman J, Yee D, et al. Case management for frail elders: the Robert Wood Johnson Foundation’s Program for Hospital Initiatives in Long-Term Care. Gerontologist. 12. 1989;29(6):737-44. Not eligible outcomes. [pmid: 2515999].
1050 Mack W, Langholz B, Thomas DC. Survival models for familial aggregation of cancer. Environ Health Perspect. 07. 1990;87:27-35. Not eligible outcomes. [pmid: 2269231].
1051 Maddens M, Imam K, Ashkar A. Hypertension in the elderly. Primary Care; Clinics in Office Practice. 09. 2005;32(3):723-53. Not eligible outcomes.
1052 Madigan EA. A description of adverse events in home healthcare. Home Healthc Nurse. 03. 2007;25(3):191-7. Not eligible outcomes. [pmid: 17353712].
1053 Maestad O, Norheim OF. Eliciting people’s preferences for the distribution of health: A procedure for a more precise estimation of distributional weights. J Health Econ. 05. 2009;28(3):570-7. Not eligible outcomes. [pmid: 19368983].
1054 Maffei P, Menegazzo C, Michelotto M, et al. Sudden death due to aortic rupture in acromegaly. Heart Vessels. 01. 2008;23(1):71-4. Not eligible outcomes. [pmid: 18273550].
1055 Magaziner J, German P, Zimmerman SI, et al. The prevalence of dementia in a statewide sample of new nursing home admissions aged 65 and older: diagnosis by expert panel. Epidemiology of Dementia in Nursing Homes Research Group. Gerontologist. 12. 2000;40(6):663-72. Not eligible outcomes. [pmid: 11131083].
1056 Maggio M, Cappola AR, Ceda GP, et al. The hormonal pathway to frailty in older men. J Endocrinol Invest. 2005;28(11 Suppl Proceedings):15-9. Review. [pmid: 16760619].
1057 Mahoney JE, Palta M, Johnson J, et al. Temporal association between hospitalization and rate of falls after discharge. Arch Intern Med. 10. 9. 2000;160(18):2788-95. Not eligible outcomes. [pmid: 11025789].
1058 Mahony SO, Blank A, Simpson J, et al. Preliminary report of a palliative care and case management project in an emergency department for chronically ill elderly patients. J Urban Health. 05. 2008;85(3):443-51. Not eligible outcomes. [pmid: 18363108].
1059 Maillet JM, Somme D, Hennel E, et al. Frailty after aortic valve replacement (AVR) in octogenarians. Arch Gerontol Geriatr. 05–06. 2009;48(3):391-6. Not eligible outcomes. [pmid: 18456353].
1060 Mailloux J, Finno M, Rainville J. Long-term exercise adherence in the elderly with chronic low back pain. Am J Phys Med Rehabil. 02. 2006;85(2):120-6. Not eligible outcomes. [pmid: 16428902].
1061 Malani PN, Rana MM, Banerjee M, et al. Staphylococcus aureus bloodstream infections: the association between age and mortality and functional status. J Am Geriatr Soc. 08. 2008;56(8):1485-9. Not eligible exposure. [pmid: 18662207].
1062 Mallett V, Burks D, Garely AD, et al. Solifenacin treatment for overactive bladder in black patients: patient-reported symptom bother and health-related quality of life outcomes. Curr Med Res Opin. 04. 2007;23(4):821-31. Not eligible outcomes. [pmid: 17407639].
1063 Maly RC, Hirsch SH, Reuben DB. The performance of simple instruments in detecting geriatric conditions and selecting community-dwelling older people for geriatric assessment. Age Ageing. 05. 1997;26(3):223-31. Not eligible outcomes. [pmid: 9223719].
1064 Mandelblatt JS, Bierman AS, Gold K, et al. Constructs of burden of illness in older patients with breast cancer: a comparison of measurement methods. Health Serv Res. 12. 2001;36(6 Pt 1):1085-107. Not eligible outcomes. [pmid: 11775669].
1065 Mandelblatt JS, Schechter CB, Yabroff KR, et al. Toward optimal screening strategies for older women. Costs, benefits, and harms of breast cancer screening by age, biology, and health status. J Gen Intern Med. 06. 2005;20(6):487-96. Not eligible outcomes. [pmid: 15987322].
1066 Manders K, van de Poll-Franse LV, Creemers GJ, et al. Clinical management of women with metastatic breast cancer: a descriptive study according to age group. BMC Cancer. 2006;6:179. Noto eligible outcomes. [pmid: 16824210].
1067 Mangione CM, Marcantonio ER, Goldman L, et al. Influence of age on measurement of health status in patients undergoing elective surgery. J Am Geriatr Soc. 04. 1993;41(4):377-83. Not eligible outcomes. [pmid: 8463523].
1068 Mangione CM, Phillips RS, Seddon JM, et al. Development of the ‘Activities of Daily Vision Scale’. A measure of visual functional status. Med Care. 12. 1992;30(12):1111-26. Not eligible outcomes. [pmid: 1453816].
1069 Mann WC, Kimble C, Justiss MD, et al. Problems with dressing in the frail elderly. Am J Occup Ther. 07–08. 2005;59(4):398-408. Not eligible outcomes. [pmid: 16124206].
1070 Mant A, King M, Saunders NA, et al. Four-year follow-up of mortality and sleep-related respiratory disturbance in non-demented seniors. Sleep. 07. 1995;18(6):433-8. Not eligible outcomes. [pmid: 7481414].
1071 Manton KG. Epidemiological, demographic, and social correlates of disability among the elderly. Milbank Q. 1989;67(Suppl 2 Pt 1):13-58. Not eligible population. [pmid: 2532293].
1072 Manton KG. Demographic trends for the aging female population. Journal of the American Medical Womens Association. 1997;52(3):99-105. Not eligible population.
1073 Manton KG, Gu X. Changes in the prevalence of chronic disability in the United States black and nonblack population above age 65 from 1982 to 1999. Proc Natl Acad Sci U S A. 05. 22. 2001;98(11):6354-9. Not eligible population. [pmid: 11344275].
1074 Manton KG, Stallard E, Corder LS. The dynamics of dimensions of age-related disability 1982 to 1994 in the U.S. elderly population. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 01. 1998;53(1):B59-70. Not eligible population.
1075 Manton KG, Vaupel JW. Survival after the age of 80 in the United States, Sweden, France, England, and Japan.[see comment]. New England Journal of Medicine. 11. 2. 1995;333(18):1232-5. Not eligible exposure. [pmid: 7565998].
1076 Mar J, Sainz-Ezkerra M, Miranda-Serrano E. Calculation of prevalence with Markov models: budget impact analysis of thrombolysis for stroke. Med Decis Making. 07–08. 2008;28(4):481-90. Not eligible outcomes. [pmid: 18349439].
1077 Maraldi C, Volpato S, Kritchevsky SB, et al. Impact of inflammation on the relationship among alcohol consumption, mortality, and cardiac events: the health, aging, and body composition study. [erratum appears in Arch Intern Med. 2006 Oct 9; 166(18):2026]. Archives of Internal Medicine. 07. 24. 2006;166(14):1490-7. Not eligible exposure. [pmid: 16864759].
1078 Maraldi C, Volpato S, Penninx BW, et al. Diabetes mellitus, glycemic control, and incident depressive symptoms among 70- to 79-year-old persons: the health, aging, and body composition study. Archives of Internal Medicine. 06. 11. 2007;167(11):1137-44. Not eligible exposure. [pmid: 17563021].
1079 Marc LG, Raue PJ, Bruce ML. Screening performance of the 15-item geriatric depression scale in a diverse elderly home care population. Am J Geriatr Psychiatry. 11. 2008;16(11):914-21. Not eligible outcomes. [pmid: 18978252].
1080 Mariani E, Monastero R, Ercolani S, et al. Vascular risk factors in mild cognitive impairment subtypes. Findings from the ReGAl project. Dement Geriatr Cogn Disord. 2007;24(6):448-56. Not eligible target population. [pmid: 17975314].
1081 Marin R, Cyhan T, Miklos W, et al. Sleep disturbance in patients with chronic low back pain. American Journal of Physical Medicine & Rehabilitation. 05. 2006;85(5):430-5. Not eligible outcomes. [pmid: 16628150].
1082 Markland AD, Goode PS, Burgio KL, et al. Correlates of urinary, fecal, and dual incontinence in older African-American and white men and women. J Am Geriatr Soc. 02. 2008;56(2):285-90. Not eligible outcomes. [pmid: 18070007].
1083 Marks R. Physical and psychological correlates of disability among a cohort of individuals with knee osteoarthritis. Can J Aging. Winter. 2007;26(4):367-77. Not eligible exposure. [pmid: 18304923].
1084 Marottoli RA, Berkman LF, Leo-Summers L, et al. Predictors of mortality and institutionalization after hip fracture: the New Haven EPESE cohort. Established Populations for Epidemiologic Studies of the Elderly. Am J Public Health. 11. 1994;84(11):1807-12. Not eligible outcomes. [pmid: 7977922].
1085 Marottoli RA, de Leon CFM, Glass TA, et al. Consequences of driving cessation: decreased out-of-home activity levels. J Gerontol B Psychol Sci Soc Sci. 11. 2000;55(6):S334-40. Not eligible outcomes. [pmid: 11078110].
1086 Marshall D, Simpson KN, Earle CC, et al. Potential cost-effectiveness of one-time screening for lung cancer (LC) in a high risk cohort. Lung Cancer. 06. 2001;32(3):227-36. Not eligible outcomes. [pmid: 11390004].
1087 Marshall TA, Stumbo PJ, Warren JJ, et al. Inadequate nutrient intakes are common and are associated with low diet variety in rural, community-dwelling elderly. Journal of Nutrition. 08. 2001;131(8):2192-6. Not eligible outcomes. [pmid: 11481416].
1088 Marvel ME, Pratt DS, Marvel LH, et al. Occupational hearing loss in New York dairy farmers. American Journal of Industrial Medicine. 1991;20(4):517-31. Not eligible outcomes. [pmid: 1785614].
1089 Masaidi M, Cuspidi C, Negri F, et al. Left and right ventricular structural changes in obese hypertensives. Blood pressure. 2009;18(1–2):23-9. Not eligible outcomes. [pmid: 19353408].
1090 Masaki KH, Schatz IJ, Burchfiel CM, et al. Orthostatic hypotension predicts mortality in elderly men: the Honolulu Heart Program. Circulation. 11. 24. 1998;98(21):2290-5. Not eligible exposure. [pmid: 9826316].
1091 Maselko J, Kubzansky L, Kawachi I, et al. Religious service attendance and allostatic load among high-functioning elderly. Psychosom Med. 06. 2007;69(5):464-72. Not eligible outcomes. [pmid: 17567709].
1092 Mason H, Jones-Lee M, Donaldson C. Modelling the monetary value of a QALY: a new approach based on UK data. Health Econ. 08. 2009;18(8):933-50. Not eligible outcomes. [pmid: 18855880].
1093 Mast BT. Impact of cognitive impairment on the phenomenology of geriatric depression. Am J Geriatr Psychiatry. 08. 2005;13(8):694-700. Not eligible outcomes. [pmid: 16085785].
1094 Matheson JK. Sleep disorders in the elderly. Med Health R I. 05. 2008;91(5):144-6. Not eligible outcomes. [pmid: 18549042].
1095 Matteini AM, Walston JD, Fallin MD, et al. Markers of B-vitamin deficiency and frailty in older women. Journal of Nutrition, Health & Aging. 05. 2008;12(5):303-8. Not eligible outcomes.
1096 Matthias RE, Atchison KA, Lubben JE, et al. Factors affecting self-ratings of oral health. J Public Health Dent. Fall. 1995;55(4):197-204. Not eligible outcomes. [pmid: 8551458].
1097 Mauk KL. Rooting out hypothyroidism in the elderly. Nursing. 12. 2005;35(12):65-6. Not eligible outcomes. [pmid: 16331234].
1098 Maurer MS, Cuddihy P, Weisenberg J, et al. The prevalence and impact of anergia (lack of energy) in subjects with heart failure and its associations with actigraphy. Journal of cardiac failure. 03. 2009;15(2):145-51. Not eligible outcomes. [pmid: 19254674].
1099 May JJ, Marvel M, Regan M, et al. Noise-induced hearing loss in randomly selected New York dairy farmers. American Journal of Industrial Medicine. 1990;18(3):333-7. Not eligible outcomes. [pmid: 2220840].
1100 McAuley P, Pittsley J, Myers J, et al. Fitness and fatness as mortality predictors in healthy older men: the veterans exercise testing study. J Gerontol A Biol Sci Med Sci. 06. 2009;64(6):695-9. Not eligible outcomes. [pmid: 19196639].
1101 McAvay GJ, Van Ness PH, Bogardus ST Jr, et al. Older adults discharged from the hospital with delirium: 1-year outcomes. J Am Geriatr Soc. 08. 2006;54(8):1245-50. Not eligible outcomes. [pmid: 16913993].
1102 McDermott MM, Ferrucci L, Guralnik JM, et al. Elevated levels of inflammation, d-dimer, and homocysteine are associated with adverse calf muscle characteristics and reduced calf strength in peripheral arterial disease. Journal of the American College of Cardiology. 08. 28. 2007;50(9):897-905. Not eligible population. [pmid: 17719478].
1103 McDermott MM, Ferrucci L, Liu K, et al. D-dimer and inflammatory markers as predictors of functional decline in men and women with and without peripheral arterial disease. J Am Geriatr Soc. 10. 2005;53(10):1688-96. Not eligible outcome. [pmid: 16181167].
1104 McDermott MM, Guralnik JM, Greenland P, et al. Inflammatory and thrombotic blood markers and walking-related disability in men and women with and without peripheral arterial disease. J Am Geriatr Soc. 11. 2004;52(11):1888-94. Not eligible target population. [pmid: 15507067].
1105 McDonald M, Hertz RP, Unger AN, et al. Prevalence, awareness, and management of hypertension, dyslipidemia, and diabetes among United States adults aged 65 and older. J Gerontol A Biol Sci Med Sci. 02. 2009;64(2):256-63. Not eligible outcomes. [pmid: 19181717].
1106 McDougall GJ, Balyer J. Decreasing mental frailty in at-risk elders. Geriatr Nurs. 07–08. 1998;19(4):220-4. Review. [pmid: 9866512].
1107 McDougall GJ Jr, Becker H, Arheart KL. Older adults in the SeniorWISE study at risk for mild cognitive impairment. Arch Psychiatr Nurs. 06. 2006;20(3):126-34. Not eligible outcomes. [pmid: 16716856].
1108 McDowell BJ, Burgio KL, Dombrowski M, et al. An interdisciplinary approach to the assessment and behavioral treatment of urinary incontinence in geriatric outpatients. J Am Geriatr Soc. 04. 1992;40(4):370-4. Not eligible outcomes. [pmid: 1556364].
1109 McGarry K, Schoeni RF. Social security, economic growth, and the rise in elderly widows’ independence in the twentieth century. Demography. 05. 2000;37(2):221-36. Not eligible outcomes. [pmid: 10836180].
1110 McGowan JA, Pottern L. Commentary on the Women’s Health Initiative. Maturitas. 02. 15. 2000;34(2):109-12. Not eligible outcomes. [pmid: 10714904].
1111 McGuire LC, Strine TW, Allen RS, et al. The Patient Health Questionnaire 8: current depressive symptoms among U.S. older adults, 2006 Behavioral Risk Factor Surveillance System. American Journal of Geriatric Psychiatry. 04. 2009;17(4):324-34. Not eligible outcomes. [pmid: 19307861].
1112 McGwin G Jr, Melton SM, May AK, et al. Long-term survival in the elderly after trauma. J Trauma. 09. 2000;49(3):470-6. Not eligible outcomes. [pmid: 11003325].
1113 McKenna MJ. Differences in vitamin D status between countries in young adults and the elderly. Am J Med. 07. 1992;93(1):69-77. Not eligible outcomes. [pmid: 1385673].
1114 McMahan S, Meyer J. Symptom prevalence and worry about high voltage transmission lines. Environmental Research. 08. 1995;70(2):114-8. Not eligible outcomes. [pmid: 8674479].
1115 McMahon PM, Kong CY, Johnson BE, et al. Estimating long-term effectiveness of lung cancer screening in the Mayo CT screening study. Radiology. 07. 2008;248(1):278-87. Not eligible exposure. [pmid: 18458247].
1116 McMahon PM, Zaslavsky AM, Weinstein MC, et al. Estimation of mortality rates for disease simulation models using Bayesian evidence synthesis. Med Decis Making. 09–10. 2006;26(5):497-511. Not eligible outcomes. [pmid: 16997927].
1117 McMichael AJ. Vegetarians and longevity: imagining a wider reference population.[see comment][comment]. Epidemiology. 09. 1992;3(5):389-91. Not eligible outcomes. [pmid: 1391128].
1118 McMurtray A, Nakamoto B, Shikuma C, et al. Cortical atrophy and white matter hyperintensities in HIV: the Hawaii Aging with HIV Cohort Study. Journal of Stroke & Cerebrovascular Diseases. 07–08. 2008;17(4):212-7. Not eligible outcomes. [pmid: 18589342].
1119 McNamee P, Bond J, Buck D. Costs of dementia in England and Wales in the 21st century. Br J Psychiatry. 09. 2001;179:261-6. Not eligible outcomes. [pmid: 11532805].
1120 McQuaid JR, Stein MB, Laffaye C, et al. Depression in a primary care clinic: the prevalence and impact of an unrecognized disorder. J Affect Disord. 09. 1999;55(1):1-10. Not eligible outcomes. [pmid: 10512600].
1121 Mecocci P, von Strauss E, Cherubini A, et al. Cognitive impairment is the major risk factor for development of geriatric syndromes during hospitalization: results from the GIFA study. Dement Geriatr Cogn Disord. 2005;20(4):262-9. Not eligible outcomes. [pmid: 16103670].
1122 Medland ME. The future of elder care. Hosp Top. Fall. 1998;76(4):13-6. Not eligible outcomes. [pmid: 10538908].
1123 Mehta KM, Simonsick EM, Penninx BW, et al. Prevalence and correlates of anxiety symptoms in well-functioning older adults: findings from the health aging and body composition study. J Am Geriatr Soc. 04. 2003;51(4):499-504. not eligible outcomes. [pmid: 12657069].
1124 Meigs JB, Muller DC, Nathan DM, et al. The natural history of progression from normal glucose tolerance to type 2 diabetes in the Baltimore Longitudinal Study of Aging. Diabetes. 06. 2003;52(6):1475-84. Not eligible exposure. [pmid: 12765960].
1125 Meldon SW, Emerman CL, Moffa DA, et al. Utility of clinical characteristics in identifying depression in geriatric ED patients. Am J Emerg Med. 10. 1999;17(6):522-5. Not eligible outcomes. [pmid: 10530527].
1126 Melis RJ, Adang E, Teerenstra S, et al. Cost-effectiveness of a multidisciplinary intervention model for community-dwelling frail older people. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 03. 2008;63(3):275-82. Not eligible outcomes.
1127 Melton PE, Zlojutro M, Kimminau K, et al. Biological aging and Cox hazard analysis of mortality trends in a Mennonite community from south-central Kansas. Am J Hum Biol. 05–06. 2006;18(3):387-401. Not eligible outcomes. [pmid: 16634024].
1128 Meltzer D, Egleston B, Stoffel D, et al. Effect of future costs on cost-effectiveness of medical interventions among young adults: the example of intensive therapy for type 1 diabetes mellitus. Med Care. 06. 2000;38(6):679-85. Not eligible outcomes. [pmid: 10843315].
1129 Melzer D, Gardener E, Guralnik JM. Mobility disability in the middle-aged: cross-sectional associations in the English Longitudinal Study of Ageing. Age Ageing. 11. 2005;34(6):594-602. Not eligible outcomes. [pmid: 16267185].
1130 Melzer D, Izmirlian G, Leveille SG, et al. Educational differences in the prevalence of mobility disability in old age: the dynamics of incidence, mortality, and recovery. J Gerontol B Psychol Sci Soc Sci. 09. 2001;56(5):S294-301. Not eligible outcomes. [pmid: 11522811].
1131 Melzer D, Lan TY, Tom BD, et al. Variation in thresholds for reporting mobility disability between national population subgroups and studies. J Gerontol A Biol Sci Med Sci. 12. 2004;59(12):1295-303. Not eligible outcomes. [pmid: 15699529].
1132 Meng L, Maskarinec G, Lee J, et al. Lifestyle factors and chronic diseases: application of a composite risk index. Preventive medicine. 10. 1999;29(4):296-304. Not eligible exposure. [pmid: 10547055].
1133 Mentes JC. A typology of oral hydration problems exhibited by frail nursing home residents. J Gerontol Nurs. 01. 2006;32(1):13-9. quiz 20–1. Not eligible target population. [pmid: 16475460].
1134 Menzel P, Gold MR, Nord E, et al. Toward a broader view of values in cost-effectiveness analysis of health. Hastings Cent Rep. 05–06. 1999;29(3):7-15. Not eligible outcomes. [pmid: 10420299].
1135 Mermelstein R, Miller B, Prohaska T, et al. Health data on older Americans: United States, 1992. Measures of health. Vital Health Stat. 01. 1993;3(27):9-21. Not eligible outcomes.
1136 Merritt BK, Fisher AG. Gender differences in the performance of activities of daily living. Arch Phys Med Rehabil. 12. 2003;84(12):1872-7. Not eligible population. [pmid: 14669197].
1137 Metlay JP, Cohen A, Polsky D, et al. Medication safety in older adults: home-based practice patterns. Journal of the American Geriatrics Society. 06. 2005;53(6):976-82. Not eligible outcomes. [pmid: 15935020].
1138 Metter EJ, Schrager M, Ferrucci L, et al. Evaluation of movement speed and reaction time as predictors of all-cause mortality in men. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 07. 2005;60(7):840-6. Not eligible outcomes.
1139 Meuser TM, Carr DB, Ulfarsson GF. Motor-vehicle crash history and licensing outcomes for older drivers reported as medically impaired in Missouri. Accid Anal Prev. 03. 2009;41(2):246-52. Not eligible outcomes. [pmid: 19245882].
1140 Meyer JS, Xu G, Thornby J, et al. Is mild cognitive impairment prodromal for vascular dementia like Alzheimer’s disease. Stroke. 08. 2002;33(8):1981-5. Not eligible outcomes. [pmid: 12154249].
1141 Meyer PM, Powell LH, Wilson RS, et al. A population-based longitudinal study of cognitive functioning in the menopausal transition.[see comment]. Neurology. 09. 23. 2003;61(6):801-6. Not eligible target population. [pmid: 14504324].
1142 Meyer TJ, Eveloff SE, Kline LR, et al. One negative polysomnogram does not exclude obstructive sleep apnea. Chest. 03. 1993;103(3):756-60. Not eligible outcomes. [pmid: 8449064].
1143 Miceli DG, Strumpf NE, Reinhard SC, et al. Current approaches to postfall assessment in nursing homes. Journal of the American Medical Directors Association. 11–12. 2004;5(6):387-94. Not eligible target population. [pmid: 15530177].
1144 Michael KM, Allen JK, Macko RF. Fatigue after stroke: relationship to mobility, fitness, ambulatory activity, social support, and falls efficacy. Rehabil Nurs. 09–10. 2006;31(5):210-7. Not eligible outcomes. [pmid: 16948443].
1145 Miech RA, Eaton WW, Brennan K, et al. Mental health disparities across education and sex: a prospective analysis examining how they persist over the life course. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. 10. 2005;60(Spec No 2):93-8. Not eligible outcomes.
1146 Mielenz T, Jackson E, Currey S, et al. Psychometric properties of the Centers for Disease Control and Prevention. Health-Related Quality of Life (CDC HRQOL) items in adults with arthritis. Health Qual Life Outcomes. 2006;4:66. Not eligible outcomes. [pmid: 16995955].
1147 Mielke MM, Rosenberg PB, Tschanz J, et al. Vascular factors predict rate of progression in Alzheimer disease. Neurology. 11. 6. 2007;69(19):1850-8. Not eligible exposure. [pmid: 17984453].
1148 Milanese TR, Hartmann LC, Sellers TA, et al. Age-related lobular involution and risk of breast cancer[see comment], Journal of the National Cancer Institute. 11. 15. 2006;98(22):1600-7. Not eligible outcomes.
1149 Miles TP, Briscoe BT, Kim SH. Age, gender, and impaired clock drawing in the generalist primary care setting. J Ky Med Assoc. 02. 2007;105(2):59-65. Not eligible outcomes. [pmid: 17390733].
1150 Miles TP, Palmer RF, Espino DV, et al. New-onset incontinence and markers of frailty: data from the Hispanic Established Populations for Epidemiologic Studies of the Elderly. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 01. 2001;56(1):M19-24. Not eligible outcomes.
1151 Milidonis MK, Greene BL. The impact of function on work status for community dwelling disabled persons with arthritis: an analysis of the National Health Interview Survey Disability Supplement. Work. 2005;24(1):71-6. Not eligible outcomes. [pmid: 15706074].
1152 Milisen K, Braes T, Fick DM, et al. Cognitive assessment and differentiating the 3 Ds (dementia, depression, delirium). Nursing Clinics of North America. 03. 2006;41(1):1-22. Review. [pmid: 16492451].
1153 Miller JW, Garrod MG, Rockwood AL, et al. Measurement of total vitamin B12 and holotranscobalamin, singly and in combination, in screening for metabolic vitamin B12 deficiency. Clinical Chemistry. 02. 2006;52(2):278-85. Not eligible outcome. [pmid: 16384886].
1154 Miller JW, Green R, Ramos MI, et al. Homocysteine and cognitive function in the Sacramento Area Latino Study on Aging.[see comment]. American Journal of Clinical Nutrition. 09. 2003;78(3):441-7. Not eligible exposure. [pmid: 12936927].
1155 Miller SW. Evaluating medication regimens in the elderly. Consult Pharm. 07. 2008;23(7):538-47. Not eligible outcomes. [pmid: 18764672].
1156 Miller T. Increasing longevity and Medicare expenditures. Demography. 05. 2001;38(2):215-26. Not eligible outcomes. [pmid: 11392909].
1157 Millis SR, Straube D, Iramaneerat C, et al. Measurement properties of the National Institutes of Health Stroke Scale for people with right- and left-hemisphere lesions: further analysis of the clomethiazole for acute stroke study-ischemic (classI) trial. Arch Phys Med Rehabil. 03. 2007;88(3):302-8. Not eligible target population. [pmid: 17321821].
1158 Mitchell AJ, Shiri-Feshki M. Rate of progression of mild cognitive impairment to dementia--meta-analysis of 41 robust inception cohort studies. Acta Psychiatrica Scandinavica. 04. 2009;119(4):252-65. Not eligible outcomes. [pmid: 19236314].
1159 Mitchell JL, Cruickshanks KJ, Klein BE, et al. Postmenopausal hormone therapy and its association with cognitive impairment. Archives of Internal Medicine. 11. 10. 2003;163(20):2485-90. Not eligible outcomes. [pmid: 14609785].
1160 Mitnitski AB, Mogilner AJ, MacKnight C, et al. The mortality rate as a function of accumulated deficits in a frailty index. Mech Ageing Dev. 09. 2002;123(11):1457-60. Secondary data simulation. [pmid: 12425952].
1161 Mitnitski AB, Mogilner AJ, Rockwood K. Accumulation of deficits as a proxy measure of aging. ScientificWorldJournal. 08. 8. 2001;1:323-36. Not eligible outcomes. [pmid: 12806071].
1162 Miyake K, Kusunoki M, Shinji Y, et al. Bisphosphonate increases risk of gastroduodenal ulcer in rheumatoid arthritis patients on long-term nonsteroidal antiinflammatory drug therapy. J Gastroenterol. 2009;44(2):113-20. Not eligible target population. [pmid: 19214672].
1163 Mizrahi EH, Fleissig Y, Arad M, et al. The impact of previous strokes on the rehabilitation of elderly patients sustaining a hip fracture. Arch Phys Med Rehabil. 09. 2007;88(9):1136-9. Not eligible outcomes. [pmid: 17826458].
1164 Moffat SD, Zonderman AB, Metter EJ, et al. Free testosterone and risk for Alzheimer disease in older men.[see comment]. Neurology. 01. 27. 2004;62(2):188-93. Not eligible exposure. [pmid: 14745052].
1165 Moger TA, Aalen OO. A distribution for multivariate frailty based on the compound Poisson distribution with random scale. Lifetime Data Anal. 03. 2005;11(1):41-59. Not eligible outcomes. [pmid: 15747589].
1166 Mohr BA, Bhasin S, Kupelian V, et al. Testosterone, sex hormone-binding globulin, and frailty in older men. J Am Geriatr Soc. 04. 2007;55(4):548-55. Not eligible outcome. [pmid: 17397433].
1167 Mohr BA, Bhasin S, Link CL, et al. The effect of changes in adiposity on testosterone levels in older men: longitudinal results from the Massachusetts Male Aging Study. European Journal of Endocrinology. 09. 2006;155(3):443-52. Not eligible outcomes. [pmid: 16914599].
1168 Mojtabai R, Olfson M. Cognitive deficits and the course of major depression in a cohort of middle-aged and older community-dwelling adults. J Am Geriatr Soc. 07. 2004;52(7):1060-9. Not eligible outcomes. [pmid: 15209642].
1169 Molander U, Arvidsson L, Milsom I, et al. A longitudinal cohort study of elderly women with urinary tract infections. Maturitas. 02. 15. 2000;34(2):127-31. Not eligible outcomes. [pmid: 10714907].
1170 Mold JW, Fryer GE, Thomas CH. Who are the uninsured elderly in the United States. J Am Geriatr Soc. 04. 2004;52(4):601-6. Not eligible outcomes. [pmid: 15066078].
1171 Molony SL. Monitoring medication use in older adults. Am J Nurs. 01. 2009;109(1):68-78. quiz-9. Not eligible outcomes. [pmid: 19112274].
1172 Monastero R, Palmer K, Qiu C, et al. Heterogeneity in risk factors for cognitive impairment, no dementia: population-based longitudinal study from the Kungsholmen Project. Am J Geriatr Psychiatry. 01. 2007;15(1):60-9. Not eligible outcomes. [pmid: 17194816].
1173 Monfardini S, Aversa SM, Zoli V, et al. Vinorelbine and prednisone in frail elderly patients with intermediate-high grade non-Hodgkin’s lymphomas. Ann Oncol. 08. 2005;16(8):1352-8. Not eligible outcomes. [pmid: 15857841].
1174 Moore AA, Siu AL. Screening for common problems in ambulatory elderly: clinical confirmation of a screening instrument. Am J Med. 04. 1996;100(4):438-43. Not eligible outcomes. [pmid: 8610731].
1175 Moore H, Reams SM, Wiesen K, et al. National Kidney Foundation Council on Renal Nutrition survey: past-present clinical practices and future strategic planning. Journal of Renal Nutrition. 07. 2003;13(3):233-40. Not eligible target population. [pmid: 12874750].
1176 Mor V, Murphy J, Masterson-Allen S, et al. Risk of functional decline among well elders. J Clin Epidemiol. 1989;42(9):895-904. Not eligible outcomes. [pmid: 2778468].
1177 Morey MC, Peterson MJ, Pieper CF, et al. Project LIFE--Learning to Improve Fitness and Function in Elders: methods, design, and baseline characteristics of randomized trial. J Rehabil Res Dev. 2008;45(1):31-42. Not eligible outcomes. [pmid: 18566924].
1178 Moritz DJ, Ostfeld AM, Blazer D 2nd, et al. The health burden of diabetes for the elderly in four communities. Public Health Rep. 11–12. 1994;109(6):782-90. Not eligible outcomes. [pmid: 7800788].
1179 Morley JEWM-MG. Management of geriatric syndromes : a practical guide. Totowa, NJ. Humana: Oxford. 2004. Not eligible outcomes.
1180 Mormino EC, Kluth JT, Madison CM, et al. Episodic memory loss is related to hippocampal-mediated beta-amyloid deposition in elderly subjects. Brain. 05. 2009;132(Pt 5):1310-23. Not eligible outcomes. [pmid: 19042931].
1181 Morrato EH, Dodd S, Oderda G, et al. Prevalence, utilization patterns, and predictors of antipsychotic polypharmacy: experience in a multistate Medicaid population, 1998–2003. Clin Ther. 01. 2007;29(1):183-95. Not eligible outcomes. [pmid: 17379060].
1182 Morris MC, Evans DA, Bienias JL, et al. Dietary folate and vitamin B12 intake and cognitive decline among community-dwelling older persons.[see comment]. Archives of Neurology. 04. 2005;62(4):641-5. Not eligible outcomes. [pmid: 15824266].
1183 Morris MC, Evans DA, Bienias JL, et al. Dietary fat intake and 6-year cognitive change in an older biracial community population. Neurology. 05. 11. 2004;62(9):1573-9. Not eligible outcomes. [pmid: 15136684].
1184 Morrison RS, Meier DECC. Geriatric palliative care. New York, N.Y. Oxford University Press. [Internet Resource; Computer File Date of Entry: 20060110]. Available at:http://www.netLibrary.com/urlapi.asp?action=summary&v=1&bookid=146875. Not eligible outcomes.
1185 Morrison S, Smith G, Morrison S, et al. Monogrammic determinism?[see comment]. Psychosomatic medicine. 09–10. 2005;67(5):820-4. Not eligible outcomes. [pmid: 16204444].
1186 Mosenthal AC, Livingston DH, Lavery RF, et al. The effect of age on functional outcome in mild traumatic brain injury: 6-month report of a prospective multicenter trial. J Trauma. 05. 2004;56(5):1042-8. Not eligible outcomes. [pmid: 15179244].
1187 Mosley TH Jr, Knopman DS, Catellier DJ, et al. Cerebral MRI findings and cognitive functioning: the Atherosclerosis Risk in Communities study.[see comment]. Neurology. 06. 28. 2005;64(12):2056-62. Not eligible exposure. [pmid: 15985571].
1188 Moss KL, Beck JD, Mauriello SM, et al. Risk indicators for third molar caries and periodontal disease in senior adults. J Oral Maxillofac Surg. 05. 2007;65(5):958-63. Not eligible outcomes. [pmid: 17448848].
1189 Mossaheb N, Weissgram S, Zehetmayer S, et al. Late-onset depression in elderly subjects from the Vienna Transdanube Aging (VITA) study. Journal of Clinical Psychiatry. 04. 2009;70(4):500-8. Not eligible outcomes. [pmid: 19358786].
1190 Mosterd A, Hoes AW, de Bruyne MC, et al. Prevalence of heart failure and left ventricular dysfunction in the general population; The Rotterdam Study. Eur Heart J. 03. 1999;20(6):447-55. Not eligible outcomes. [pmid: 10213348].
1191 Moultry AM, Poon IO. Perceived value of a home-based medication therapy management program for the elderly. Consult Pharm. 11. 2008;23(11):877-85. Not eligible outcomes. [pmid: 19072012].
1192 Mouton CP, Bazaldua OV, Pierce B, et al. Common infections in older adults. Health Care Food Nutr Focus. 11. 3. 2001;18(3):1-7. Not eligible outcomes. [pmid: 11688342].
1193 Moye J, Butz SW, Marson DC, et al. A conceptual model and assessment template for capacity evaluation in adult guardianship. Gerontologist. 10. 2007;47(5):591-603. Not eligible outcomes. [pmid: 17989401].
1194 Moye J, Wood S, Edelstein B, et al. Clinical evidence in guardianship of older adults is inadequate: findings from a tri-state study. Gerontologist. 10. 2007;47(5):604-12. Not eligible outcomes. [pmid: 17989402].
1195 Mroczek DK, Spiro A 3rd, Mroczek DK, et al. Personality change influences mortality in older men. Psychological Science. 05. 2007;18(5):371-6. Not eligible outcomes. [pmid: 17576273].
1196 Muir SW, Berg K, Chesworth B, et al. Use of the Berg Balance Scale for predicting multiple falls in community-dwelling elderly people: a prospective study. Phys Ther. 04. 2008;88(4):449-59. Not eligible outcomes. [pmid: 18218822].
1197 Mukamal KJ, Longstreth WT Jr, Mittleman MA, et al. Alcohol consumption and subclinical findings on magnetic resonance imaging of the brain in older adults: the cardiovascular health study. Stroke. 09. 2001;32(9):1939-46. Not eligible outcomes. [pmid: 11546878].
1198 Mulsant BH, Reynolds CF 3rd, Shear MK, et al. Comorbid anxiety disorders in late-life depression. Anxiety. 1996;2(5):242-7. Not eligible outcomes. [pmid: 9160629].
1199 Muntner P, Garrett E, Klag MJ, et al. Trends in stroke prevalence between 1973 and 1991 in the US population 25 to 74 years of age. Stroke. 05. 2002;33(5):1209-13. Not eligible outcomes. [pmid: 11988592].
1200 Murabito JM, Yang Q, Fox CS, et al. Genome-wide linkage analysis to age at natural menopause in a community-based sample: the Framingham Heart Study. Fertility & Sterility. 12. 2005;84(6):1674-9. Not eligible outcomes. [pmid: 16359963].
1201 Murase T, Ishida H, Kiso M, et al. A facile, regio- and stereo-selective synthesis of ganglioside GM3. Carbohydr Res. 06. 1. 1989;188:71-80. Not eligible outcome. [pmid: 2776130].
1202 Murphy KM, Topel RH. Black-white differences in the economic value of improving health. Perspect Biol Med. Winter. 2005;48(1 Suppl):S176-94. Not eligible outcomes. [pmid: 15842095].
1203 Murray AM, Tupper DE, Knopman DS, et al. Cognitive impairment in hemodialysis patients is common. [see comment][erratum appears in Neurology. 2007 Jul 3; 69(1):120]. Neurology. 07. 25. 2006;67(2):216-23. Not eligible exposure. [pmid: 16864811].
1204 Murray MD, Lane KA, Gao S, et al. Preservation of cognitive function with antihypertensive medications: a longitudinal analysis of a community-based sample of African Americans. Archives of Internal Medicine. 10. 14. 2002;162(18):2090-6. Not eligible outcomes. [pmid: 12374517].
1205 Myers SA, Johanning JM, Stergiou N, et al. Claudication distances and the Walking Impairment Questionnaire best describe the ambulatory limitations in patients with symptomatic peripheral arterial disease. J Vasc Surg. 03. 2008;47(3):550-5. Not eligible outcomes. [pmid: 18207355].
1206 Nahin RL, Pecha M, Welmerink DB, et al. Concomitant use of prescription drugs and dietary supplements in ambulatory elderly people. J Am Geriatr Soc. 07. 2009;57(7):1197-205. Not eligible outcome. [pmid: 19515113].
1207 Nakanishi N, Tatara K, Shinsho F, et al. Mortality in relation to urinary and faecal incontinence in elderly people living at home. Age Ageing. 05. 1999;28(3):301-6. Not eligible exposure. [pmid: 10475868].
1208 Narasimhan K, Rizvi AA, Narasimhan K, et al. Vitamin D levels in patients seen in the diabetes unit of an academic medical center. Southern Medical Journal. 10. 2008;101(10):1069. Comment. [pmid: 18791513].
1209 Needham BL, Needham BL. Gender differences in trajectories of depressive symptomatology and substance use during the transition from adolescence to young adulthood. Social science & medicine. 09. 2007;65(6):1166-79. Not eligible outcomes. [pmid: 17574316].
1210 Neeser K, Szucs T, Bulliard JL, et al. Cost-effectiveness analysis of a quality-controlled mammography screening program from the Swiss statutory health-care perspective: quantitative assessment of the most influential factors. Value in Health. 01–02. 2007;10(1):42-53. Not eligible outcomes. [pmid: 17261115].
1211 Nelson DE, Sattin RW, Langlois JA, et al. Alcohol as a risk factor for fall injury events among elderly persons living in the community. J Am Geriatr Soc. 07. 1992;40(7):658-61. Not eligible outcomes. [pmid: 1607580].
1212 Nelson JE, Tandon N, Mercado AF, et al. Brain dysfunction: another burden for the chronically critically ill. Archives of Internal Medicine. 10. 9. 2006;166(18):1993-9. Not eligible outcomes. [pmid: 17030833].
1213 Ness J, Aronow WS. Prevalence of coexistence of coronary artery disease, ischemic stroke, and peripheral arterial disease in older persons, mean age 80 years, in an academic hospital-based geriatrics practice. J Am Geriatr Soc. 10. 1999;47(10):1255-6. Not eligible outcomes. [pmid: 10522961].
1214 Ness J, Hoth A, Barnett MJ, et al. Anticholinergic medications in community-dwelling older veterans: prevalence of anticholinergic symptoms, symptom burden, and adverse drug events. American Journal Geriatric Pharmacotherapy. 03. 2006;4(1):42-51. Not eligible outcomes.
1215 Neumann PJ, Araki SS, Arcelus A, et al. Measuring Alzheimer’s disease progression with transition probabilities: estimates from CERAD. Neurology. 09. 25. 2001;57(6):957-64. Not eligible outcomes. [pmid: 11571317].
1216 Neundorfer MM, McClendon MJ, Smyth KA, et al. A longitudinal study of the relationship between levels of depression among persons with Alzheimer’s disease and levels of depression among their family caregivers. J Gerontol B Psychol Sci Soc Sci. 09. 2001;56(5):P301-13. Not eligible outcomes. [pmid: 11522805].
1217 Newman AB, Enright PL, Manolio TA, et al. Sleep disturbance, psychosocial correlates, and cardiovascular disease in 5201 older adults: the Cardiovascular Health Study. J Am Geriatr Soc. 01. 1997;45(1):1-7. Not eligible outcomes. [pmid: 8994480].
1218 Newman AB, Foster G, Givelber R, et al. Progression and regression of sleep-disordered breathing with changes in weight: the Sleep Heart Health Study. Archives of Internal Medicine. 11. 14. 2005;165(20):2408-13. Not eligible outcomes. [pmid: 16287771].
1219 Newman AB, Lee JS, Visser M, et al. Weight change and the conservation of lean mass in old age: the Health, Aging and Body Composition Study. Am J Clin Nutr. 10. 2005;82(4):872-8. quiz 915–6. Not eligible outcomes. [pmid: 16210719].
1220 Newman AB, Nieto FJ, Guidry U, et al. Relation of sleep-disordered breathing to cardiovascular disease risk factors: the Sleep Heart Health Study. American Journal of Epidemiology. 07. 1. 2001;154(1):50-9. Not eligible outcomes. [pmid: 11434366].
1221 Newman AB, Spiekerman CF, Enright P, et al. Daytime sleepiness predicts mortality and cardiovascular disease in older adults. The Cardiovascular Health Study Research Group.[see comment]. Journal of the American Geriatrics Society. 02. 2000;48(2):115-23. Not eligible exposure. [pmid: 10682939].
1222 Newmann JP, Klein MH, Jensen JE, et al. Depressive symptom experiences among older women: a comparison of alternative measurement approaches. Psychol Aging. 03. 1996;11(1):112-26. Not eligible outcomes. [pmid: 8726377].
1223 Ng TP, Niti M, Zaw MH, et al. Depressive symptoms and incident cognitive impairment in cognitively well-functioning older men and women. Journal of the American Geriatrics Society. 06. 2009;57(6):1058-63. Not eligible outcomes. [pmid: 19467145].
1224 Ng YS, Stein J, Salles SS, et al. Clinical characteristics and rehabilitation outcomes of patients with posterior cerebral artery stroke. Arch Phys Med Rehabil. 11. 2005;86(11):2138-43. Not eligible target population. [pmid: 16271561].
1225 Nguyen JK, Fouts MM, Kotabe SE, et al. Polypharmacy as a risk factor for adverse drug reactions in geriatric nursing home residents. American Journal Geriatric Pharmacotherapy. 03. 2006;4(1):36-41. Not eligible target population.
1226 Nichols CL, Willis LA. The paired RAI/MDS specialist model. Improving outcomes in Veterans Affairs nursing home care units. J Gerontol Nurs. 10. 2004;30(10):6-11. Not eligible target population. [pmid: 15515439].
1227 Nicolas AS, Faisant C, Nourhashemi F, et al. The nutritional intake of a free-living healthy French population : a four-year follow-up. J Nutr Health Aging. 2000;4(2):77-80. Not eligible outcomes. [pmid: 10842418].
1228 Niv N, Cohen AN, Sullivan G, et al. The MIRECC version of the Global Assessment of Functioning scale: reliability and validity. Psychiatr Serv. 04. 2007;58(4):529-35. Not eligible outcomes. [pmid: 17412856].
1229 Nondahl DM, Cruickshanks KJ, Dalton DS, et al. The use of hearing protection devices by older adults during recreational noise exposure. Noise & Health. 10–12. 2006;8(33):147-53. Not eligible outcomes. [pmid: 17851219].
1230 Novielli KD, Simpson Z, Hua G, et al. Urinary incontinence in primary care: a comparison of older African-American and Caucasian women. Int Urol Nephrol. 2003;35(3):423-8. Not eligible outcomes. [pmid: 15160551].
1231 Nuotio M, Tammela TL, Luukkaala T, et al. Urgency and urge incontinence in an older population: ten-year changes and their association with mortality. Aging Clin Exp Res. 10. 2002;14(5):412-9. Not eligible outcomes. [pmid: 12602577].
1232 Nusbaum NJ. Improving elder care by integrating geriatric expertise into medicare: a proposal. Drugs Aging. 2005;22(5):371-4. Review. [pmid: 15903350].
1233 Nusbaum NJ, Cheung VM, Cohen J, et al. Role of first responders in detecting and evaluating elders at risk. Arch Gerontol Geriatr. 11–12. 2006;43(3):361-7. Not eligible outcomes. [pmid: 16513192].
1234 Nusselder WJ, Mackenbach JP. Lack of improvement of life expectancy at advanced ages in The Netherlands. Int J Epidemiol. 02. 2000;29(1):140-8. Not eligible outcomes. [pmid: 10750616].
1235 Nygaard IE, Lemke JH. Urinary incontinence in rural older women: prevalence, incidence and remission. Journal of the American Geriatrics Society. 09. 1996;44(9):1049-54. Not eligible outcomes. [pmid: 8790229].
1236 O’Connor GT, Caffo B, Newman AB, et al. Prospective study of sleep-disordered breathing and hypertension: the Sleep Heart Health Study.[see comment]. American Journal of Respiratory & Critical Care Medicine. 06. 15. 2009;179(12):1159-64. Not eligible outcomes. [pmid: 19264976].
1237 O’Donnell BF, Drachman DA, Barnes HJ, et al. Incontinence and troublesome behaviors predict institutionalization in dementia. Journal of Geriatric Psychiatry & Neurology. 01–03. 1992;5(1):45-52. Not eligible outcomes. [pmid: 1571074].
1238 O’Fallon E, Pop-Vicas A, D’Agata E. The emerging threat of multidrug-resistant gram-negative organisms in long-term care facilities. J Gerontol A Biol Sci Med Sci. 01. 2009;64(1):138-41. Not eligible target population. [pmid: 19164271].
1239 Ohayon MM, Ohayon MM. Severe hot flashes are associated with chronic insomnia. Archives of Internal Medicine. 06. 26. 2006;166(12):1262-8. Not eligible outcomes. [pmid: 16801508].
1240 Ojo F, Al Snih S, Ray LA, et al. History of fractures as predictor of subsequent hip and nonhip fractures among older Mexican Americans. J Natl Med Assoc. 04. 2007;99(4):412-8. Not eligible exposure. [pmid: 17444431].
1241 Oka RK, Szuba A, Giacomini JC, et al. Predictors of physical function in patients with peripherial arterial disease and claudication. Prog Cardiovasc Nurs. Summer. 2004;19(3):89-94. Not eligible outcomes. [pmid: 15249768].
1242 Okereke OI, Kang JH, Cook NR, et al. Type 2 diabetes mellitus and cognitive decline in two large cohorts of community-dwelling older adults. Journal of the American Geriatrics Society. 06. 2008;56(6):1028-36. Not eligible outcomes. [pmid: 18384580].
1243 Okereke OI, Pollak MN, Hu FB, et al. Plasma C-peptide levels and rates of cognitive decline in older, community-dwelling women without diabetes. Psychoneuroendocrinology. 05. 2008;33(4):455-61. Not eligible outcomes. [pmid: 18261857].
1244 Okumiya K, Matsubayashi K, Wada T, et al. A U-shaped association between home systolic blood pressure and four-year mortality in community-dwelling older men. J Am Geriatr Soc. 12. 1999;47(12):1415-21. Not eligible exposure. [pmid: 10591234].
1245 Oliver DP, Bickel-Swenson D, Zweig S, et al. Experience with implementation of a quality improvement project for the care of nursing home residents. Journal of Nursing Care Quality. 04–06. 2009;24(2):100-4. Not eligible target population. [pmid: 19287246].
1246 Oliveria SA, Liperoti R, L’Italien G, et al. Adverse events among nursing home residents with Alzheimer’s disease and psychosis. Pharmacoepidemiol Drug Saf. 11. 2006;15(11):763-74. Not eligible target population. [pmid: 16823890].
1247 Ondo WG, Sutton L, Dat Vuong K, et al. Hearing impairment in essential tremor. Neurology. 10. 28. 2003;61(8):1093-7. Not eligible outcomes. [pmid: 14581670].
1248 Opotowsky AR, Su BW, Bilezikian JP, et al. Height and lower extremity length as predictors of hip fracture: results of the NHANES I Epidemiologic Follow-up Study. Journal of Bone & Mineral Research. 09. 2003;18(9):1674-81. Not eligible outcomes. [pmid: 12968677].
1249 Oran B, Giralt S, Saliba R, et al. Allogeneic hematopoietic stem cell transplantation for the treatment of high-risk acute myelogenous leukemia and myelodysplastic syndrome using reduced-intensity conditioning with fludarabine and melphalan. Biol Blood Marrow Transplant. 04. 2007;13(4):454-62. Not eligible outcomes. [pmid: 17382251].
1250 Ory MG, Schechtman KB, Miller JP, et al. Frailty and injuries in later life: the FICSIT trials. J Am Geriatr Soc. 03. 1993;41(3):283-96. Not eligible outcomes. [pmid: 8440853].
1251 Ostermann J, Sloan FA. Effects of alcohol consumption on disability among the near elderly: a longitudinal analysis. Milbank Q. 2001;79(4):487-515. iii. Not eligible outcomes. [pmid: 11789115].
1252 Ostir GV, Markides KS, Black SA, et al. Emotional well-being predicts subsequent functional independence and survival. J Am Geriatr Soc. 05. 2000;48(5):473-8. Not eligible outcomes. [pmid: 10811538].
1253 Ostir GV, Raji MA, Ottenbacher KJ, et al. Cognitive function and incidence of stroke in older Mexican Americans. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 06. 2003;58(6):531-5. Not eligible outcomes.
1254 Ostir GV, Volpato S, Kasper JD, et al. Summarizing amount of difficulty in ADLs: a refined characterization of disability. Results from the women’s health and aging study. Aging (Milano). 12. 2001;13(6):465-72. Not eligible population. [pmid: 11845974].
1255 Otiniano ME, Du XL, Ottenbacher K, et al. The effect of diabetes combined with stroke on disability, self-rated health, and mortality in older Mexican Americans: results from the Hispanic EPESE. Arch Phys Med Rehabil. 05. 2003;84(5):725-30. Not eligible outcomes. [pmid: 12736889].
1256 Ouellet N, Morris DL. Sleep satisfaction of older adults living in the community: identifying associated behavioral and health factors. J Gerontol Nurs. 10. 2006;32(10):5-11. Not eligible outcomes. [pmid: 17048751].
1257 Ouslander JG, Simmons S, Schnelle J, et al. Effects of prompted voiding on fecal continence among nursing home residents. Journal of the American Geriatrics Society. 04. 1996;44(4):424-8. Not eligible target population. [pmid: 8636590].
1258 Overcash JA, Beckstead J. Predicting falls in older patients using components of a comprehensive geriatric assessment. Clin J Oncol Nurs. 12. 2008;12(6):941-9. Not eligible outcomes. [pmid: 19064388].
1259 Owen CG, Fletcher AE, Donoghue M, et al. How big is the burden of visual loss caused by age related macular degeneration in the United Kingdom. Br J Ophthalmol. 03. 2003;87(3):312-7. Not eligible outcomes. [pmid: 12598445].
1260 Owens JA, Avidan A, Baldwin D, et al. Improving sleep hygiene.[comment]. Archives of Internal Medicine. 06. 9. 2008;168(11):1229-30. author reply 30. Not eligible outcomes. [pmid: 18541835].
1261 Owens JF, Matthews KA. Sleep disturbance in healthy middle-aged women. Maturitas. 09. 20. 1998;30(1):41-50. Not eligible outcomes. [pmid: 9819782].
1262 Palmer AJ, Valentine WJ, Chen R, et al. A health economic analysis of screening and optimal treatment of nephropathy in patients with type 2 diabetes and hypertension in the USA. Nephrology Dialysis Transplantation. 04. 2008;23(4):1216-23. Not eligible outcomes.
1263 Palmer MH, Newman DK. Bladder matters: urinary incontinence in nursing homes. Am J Nurs. 11. 2004;104(11):57-9. Not eligible target population. [pmid: 15616452].
1264 Palmisano-Mills C. Common problems in hospitalized older adults. J Gerontol Nurs. 01. 2007;33(1):48-54. Not eligible target population. [pmid: 17305269].
1265 Pan W, Chappell R. A nonparametric estimator of survival functions for arbitrarily truncated and censored data. Lifetime Data Anal. 1998;4(2):187-202. Not eligible outcomes. [pmid: 9658775].
1266 Pan W, Chappell R. Estimation in the cox proportional hazards model with left-truncated and interval-censored data. Biometrics. 03. 2002;58(1):64-70. Not eligible outcomes. [pmid: 11890328].
1267 Panza F, Capurso C, D’Introno A, et al. Effect of a clinical stroke on the risk of dementia in a prospective cohort.[comment]. Neurology. 05. 15. 2007;68(20):1748-9. author reply 479. Not eligible exposure. [pmid: 17502563].
1268 Parazzini F, Chiaffarino F, Ricci E. The aging males’ symptoms in the Italian population: results from a cross sectional study using the AMS scale. Arch Ital Urol Androl. 09. 2006;78(3):87-91. Not eligible outcomes. [pmid: 17137021].
1269 Parker AB, Naylor CD, Chong A, et al. Clinical prognosis, pre-existing conditions and the use of reperfusion therapy for patients with ST segment elevation acute myocardial infarction. Can J Cardiol. 02. 2006;22(2):131-9. Not eligible exposure. [pmid: 16485048].
1270 Parker M, Heiss DW, Harris MJ. Geriatric care management reduces Medicare losses. Healthc Financ Manage. 10. 1993;47(10):22-4. 6. Not eligible outcomes. [pmid: 10145878].
1271 Parker M, Lee Roff L, Klemmack DL, et al. Religiosity and mental health in southern, community-dwelling older adults. Aging Ment Health. 09. 2003;7(5):390-7. Not eligible outcomes. [pmid: 12959809].
1272 Parmelee PA, Lawton MP, Katz IR. The structure of depression among elderly institution residents: affective and somatic correlates of physical frailty. J Gerontol A Biol Sci Med Sci. 03. 1998;53(2):M155-62. Not eligible outcomes. [pmid: 9520923].
1273 Pasternak R, Rosenweig A, Booth B, et al. Morbidity of homebound versus inpatient elderly psychiatric patients. Int Psychogeriatr. 06. 1998;10(2):117-25. Not eligible population. [pmid: 9677499].
1274 Pathy MSJSA, Morely JE. Principles and practice of geriatric medicine. 2006;2:ill. Not eligible outcomes.
1275 Patten CA, Choi WS, Gillin JC, et al. Depressive symptoms and cigarette smoking predict development and persistence of sleep problems in US adolescents. Pediatrics. 08. 2000;106(2):E23. Not eligible outcomes. [pmid: 10920179].
1276 Paudel ML, Taylor BC, Diem SJ, et al. Association between depressive symptoms and sleep disturbances in community-dwelling older men. J Am Geriatr Soc. 07. 2008;56(7):1228-35. Not eligible outcomes. [pmid: 18482297].
1277 Paulus AT, van Raak AJ, Maarse HJ. Is integrated nursing home care cheaper than traditional care? A cost comparison. International journal of nursing studies. 12. 2008;45(12):1764-77. Not eligible target population. [pmid: 18755460].
1278 Pawaskar MD, Anderson RT, Balkrishnan R. Self-reported predictors of depressive symptomatology in an elderly population with type 2 diabetes mellitus: a prospective cohort study. Health Qual Life Outcomes. 2007;5:50. Not eligible outcomes. [pmid: 17683531].
1279 Payette H, Coulombe C, Boutier V, et al. Weight loss and mortality among free-living frail elders: a prospective study. J Gerontol A Biol Sci Med Sci. 09. 1999;54(9):M440-5. Not eligible population. [pmid: 10536646].
1280 Payne IR. Symptom syndromes among geriatric patients. Not eligible outcomes.
1281 Payne JL, Sheppard JM, Steinberg M, et al. Incidence, prevalence, and outcomes of depression in residents of a long-term care facility with dementia. Int J Geriatr Psychiatry. 03. 2002;17(3):247-53. Not eligible target population. [pmid: 11921153].
1282 Pearce JD, Edwards MS, Craven TE, et al. Renal duplex parameters, blood pressure, and renal function in elderly people. American Journal of Kidney Diseases. 05. 2005;45(5):842-50. Not eligible outcomes. [pmid: 15861349].
1283 Pearlman RA. Quality of life factors in geriatric medicine decisions. Rockville, Md. National Center for Health Services Research and Health Care Technology Assessment. 1987. Not eligible outcomes.
1284 Pearlman RA. Quality of life factors in geriatric medical decisions : [executive summary]. Rockville, Md. US Dept of Health and Human Services, Public Health Service, National Center for Health Services Research and Health Care Technology Assessment. 1987. Not eligible outcomes.
1285 Peck CA, Moak MN. Is Medicare risk a feasible strategy for providers. Health Care Strateg Manage. 11. 19. 1998;16(11):1-23. Not eligible outcomes.
1286 Peek MK, Coward RT. Gender differences in the risk of developing disability among older adults with arthritis. J Aging Health. 05. 1999;11(2):131-50. Not eligible outcomes. [pmid: 10558433].
1287 Peila R, White LR, Petrovich H, et al. Joint effect of the APOE gene and midlife systolic blood pressure on late-life cognitive impairment: the Honolulu-Asia aging study. Stroke. 12. 1. 2001;32(12):2882-9. Not eligible exposure. [pmid: 11739991].
1288 Peila R, Yucesoy B, White LR, et al. A TGF-beta1 polymorphism association with dementia and neuropathologies: the HAAS. Neurobiol Aging. 09. 2007;28(9):1367-73. Not eligible outcomes. [pmid: 16904244].
1289 Penninx BW, Guralnik JM, Onder G, et al. Anemia and decline in physical performance among older persons. American Journal of Medicine. 08. 1. 2003;115(2):104-10. Not eligible exposure. [pmid: 12893395].
1290 Penninx BW, Leveille S, Ferrucci L, et al. Exploring the effect of depression on physical disability: longitudinal evidence from the established populations for epidemiologic studies of the elderly. Am J Public Health. 09. 1999;89(9):1346-52. Not eligible outcomes. [pmid: 10474551].
1291 Pennypacker LC, Allen RH, Kelly JP, et al. High prevalence of cobalamin deficiency in elderly outpatients.[see comment]. Journal of the American Geriatrics Society. 12. 1992;40(12):1197-204. Not eligible outcomes. [pmid: 1447433].
1292 Penrod JD, Litke A, Hawkes WG, et al. Heterogeneity in hip fracture patients: age, functional status, and comorbidity. J Am Geriatr Soc. 03. 2007;55(3):407-13. Not eligible outcomes. [pmid: 17341244].
1293 Pepersack T. Minimum geriatric screening tools to detect common geriatric problems. J Nutr Health Aging. 05. 2008;12(5):348-52. Not eligible outcomes. [pmid: 18443718].
1294 Perera V, Bajorek BV, Matthews S, et al. The impact of frailty on the utilisation of antithrombotic therapy in older patients with atrial fibrillation. Age Ageing. 03. 2009;38(2):156-62. Not eligible target population. [pmid: 19151165].
1295 Perls T, Kohler IV, Andersen S, et al. Survival of parents and siblings of supercentenarians. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 09. 2007;62(9):1028-34. Not eligible outcomes.
1296 Perperoglou A, le Cessie S, van Houwelingen HC. Reduced-rank hazard regression for modelling non-proportional hazards. Stat Med. 08. 30. 2006;25(16):2831-45. Not eligible outcomes. [pmid: 16158396].
1297 Perperoglou A, van Houwelingen HC, Henderson R. A relaxation of the gamma frailty (Burr) model. Stat Med. 12. 30. 2006;25(24):4253-66. Not eligible outcomes. [pmid: 16921549].
1298 Perri M 3rd, Menon AM, Deshpande AD, et al. Adverse outcomes associated with inappropriate drug use in nursing homes. Ann Pharmacother. 03. 2005;39(3):405-11. Not eligible target population. [pmid: 15671088].
1299 Perrin PB, Heesacker M, Hinojosa MS, et al. Identifying at-risk, ethnically diverse stroke caregivers for counseling: a longitudinal study of mental health. Rehabilitation Psychology. 05. 2009;54(2):138-49. Not eligible outcomes. [pmid: 19469603].
1300 Perroco TR, Bustamante SE, del Moreno MP, et al. Performance of Brazilian long and short IQCODE on the screening of dementia in elderly people with low education. International Psychogeriatrics. 06. 2009;21(3):531-8. Not eligible outcomes. [pmid: 19323868].
1301 Persson RE, Hollender LG, Powell LV, et al. Assessment of periodontal conditions and systemic disease in older subjects. I. Focus on osteoporosis. J Clin Periodontol. 09. 2002;29(9):796-802. Not eligible outcomes. [pmid: 12423291].
1302 Persson RE, Hollender LG, Powell VL, et al. Assessment of periodontal conditions and systemic disease in older subjects. II. Focus on cardiovascular diseases. J Clin Periodontol. 09. 2002;29(9):803-10. Not eligible outcomes. [pmid: 12423292].
1303 Persson RE, Persson GR, Kiyak HA, et al. Oral health and medical status in dentate low-income older persons. Spec Care Dentist. 03–04. 1998;18(2):70-7. Not eligible outcomes. [pmid: 9680914].
1304 Pertchik K, Shaffer TW, Erdberg P, et al. Rorschach Comprehensive System data for a sample of 52 older adult nonpatients from the United States. J Pers Assess. 2007;89(Suppl 1):S166-73. Not eligible outcomes. [pmid: 18039157].
1305 Peters TG, Charlton RK, Jones KW, et al. Kidney transplantation in the older patient. Journal of the Florida Medical Association. 08. 1994;81(8):535-8. Not eligible outcomes. [pmid: 7964580].
1306 Petersen JH. An additive frailty model for correlated life times. Biometrics. 06. 1998;54(2):646-61. Not eligible outcomes. [pmid: 9660631].
1307 Petersen L, Sorensen TI, Nielsen GG, et al. Inference methods for correlated left truncated lifetimes: parent and offspring relations in an adoption study. Lifetime Data Anal. 03. 2006;12(1):5-20. Not eligible outcomes. [pmid: 16583296].
1308 Petrea RE, Beiser AS, Seshadri S, et al. Gender differences in stroke incidence and poststroke disability in the Framingham heart study. Stroke. 04. 2009;40(4):1032-7. Not eligible outcomes. [pmid: 19211484].
1309 Petrie MC, Berry C, Stewart S, et al. Failing ageing hearts. Eur Heart J. 11. 2001;22(21):1978-90. Not eligible outcomes. [pmid: 11603905].
1310 Pfeifer LA, White LR, Ross GW, et al. Cerebral amyloid angiopathy and cognitive function: the HAAS autopsy study.[see comment]. Neurology. 06. 11. 2002;58(11):1629-34. Not eligible exposure. [pmid: 12058090].
1311 Phan HM, Alpert JS, Fain M. Frailty, inflammation, and cardiovascular disease: evidence of a connection. Am J Geriatr Cardiol. 03–04. 2008;17(2):101-7. Review. [pmid: 18326951].
1312 Phelan CH, Heidrich SM, Phelan CH, et al. Patterns of pain and well-being in older women: a 10-year longitudinal study. Journal of Women & Aging. 2007;19(3–4):21-35. Not eligible outcomes. [pmid: 18032251].
1313 Phelan EA, Williams B, Snyder SJ, et al. A five state dissemination of a community-based disability prevention program for older adults. Clin Interv Aging. 2006;1(3):267-74. Not eligible outcomes. [pmid: 18046880].
1314 Phibbs CS, Holty JE, Goldstein MK, et al. The effect of geriatrics evaluation and management on nursing home use and health care costs: results from a randomized trial. Med Care. 01. 2006;44(1):91-5. Not eligible outcomes. [pmid: 16365618].
1315 Phillips B, Mannino DM, Phillips B, et al. Do insomnia complaints cause hypertension or cardiovascular disease?. Journal of Clinical Sleep Medicine. 08. 15. 2007;3(5):489-94. Not eligible exposure. [pmid: 17803012].
1316 Phillips SL, Phillips JV, Branaman-Phillips J, et al. Geriatric versus non-geriatric approach of care to moderate Pra risk senior population. J Am Med Dir Assoc. 11–12. 2005;6(6):396-9. Not eligible outcomes. [pmid: 16286061].
1317 Phoha RL, Dickel MJ, Mosko SS. Preliminary longitudinal assessment of sleep in the elderly. Sleep. 10. 1990;13(5):425-9. Not eligible outcomes. [pmid: 2287854].
1318 Pickens S, Burnett J, Naik AD, et al. Is pain a significant factor in elder self-neglect. J Elder Abuse Negl. 2006;18(4):51-61. Not eligible outcomes. [pmid: 17972659].
1319 Pierce CA. Program of All-inclusive Care for the Elderly in 2002. Geriatr Nurs. 05–06. 2002;23(3):173-4. Comment. [pmid: 12075285].
1320 Pilz S, Henry RM, Snijder MB, et al. 25-hydroxyvitamin D is not associated with carotid intima-media thickness in older men and women. Calcified tissue international. 05. 2009;84(5):423-4. Not eligible outcomes. [pmid: 19308629].
1321 Pincus T, Keysor J, Sokka T, et al. Patient questionnaires and formal education level as prospective predictors of mortality over 10 years in 97% of 1416 patients with rheumatoid arthritis from 15 United States private practices. Journal of Rheumatology. 02. 2004;31(2):229-34. Not eligible exposure. [pmid: 14760789].
1322 Pinsky JL, Branch LG, Jette AM, et al. Framingham Disability Study: relationship of disability to cardiovascular risk factors among persons free of diagnosed cardiovascular disease. Am J Epidemiol. 10. 1985;122(4):644-56. Not eligible outcomes. [pmid: 3161323].
1323 Pinsky JL, Jette AM, Branch LG, et al. The Framingham Disability Study: relationship of various coronary heart disease manifestations to disability in older persons living in the community. Am J Public Health. 11. 1990;80(11):1363-7. Duplicate report of 7294262. [pmid: 2240306].
1324 Pittock SJ, Mayr WT, McClelland RL, et al. Change in MS-related disability in a population-based cohort: a 10-year follow-up study. Neurology. 01. 13. 2004;62(1):51-9. Not eligible outcomes. [pmid: 14718697].
1325 Pittock SJ, McClelland RL, Mayr WT, et al. Prevalence of tremor in multiple sclerosis and associated disability in the Olmsted County population. Mov Disord. 12. 2004;19(12):1482-5. Not eligible outcomes. [pmid: 15390075].
1326 Podewils LJ, Guallar E, Beauchamp N, et al. Physical activity and white matter lesion progression: assessment using MRI. Neurology. 04. 10. 2007;68(15):1223-6. Not eligible outcomes. [pmid: 17420407].
1327 Podewils LJ, Lyketsos CG, Podewils LJ, et al. Tricyclic antidepressants and cognitive decline. Psychosomatics. 01–02. 2002;43(1):31-5. Not eligible outcomes. [pmid: 11927755].
1328 Podewils LJ, McLay RN, Rebok GW, et al. Relationship of self-perceptions of memory and worry to objective measures of memory and cognition in the general population. Psychosomatics. 11–12. 2003;44(6):461-70. Not eligible outcomes. [pmid: 14597680].
1329 Polich CL, Parker M. Geriatric care management saves money, improves care. Trustee. 01. 1991;44(1):18-9. Not eligible outcomes. [pmid: 10108506].
1330 Ponzetto M, Zanocchi M, Maero B, et al. Post-hospitalization mortality in the elderly. Arch Gerontol Geriatr. 01–02. 2003;36(1):83-91. Not eligible outcomes. [pmid: 12849102].
1331 Popa MA, Reynolds SL, Small BJ. Is the effect of reported physical activity on disability mediated by cognitive performance in white and african american older adults. J Gerontol B Psychol Sci Soc Sci. 01. 2009;64(1):4-13. Not eligible exposure. [pmid: 19196688].
1332 Popelka MM, Cruickshanks KJ, Wiley TL, et al. Moderate alcohol consumption and hearing loss: a protective effect. Journal of the American Geriatrics Society. 10. 2000;48(10):1273-8. Not eligible outcomes. [pmid: 11037015].
1333 Porell FW, Miltiades HB. Access to care and functional status change among aged Medicare beneficiaries. J Gerontol B Psychol Sci Soc Sci. 03. 2001;56(2):S69-83. Not eligible outcomes. [pmid: 11245367].
1334 Porello PT, Madsen L, Futterman A, et al. Description of a geriatric medical/psychiatry unit in a small community general hospital. J Ment Health Adm. Winter. 1995;22(1):38-48. Not eligible outcomes. [pmid: 10141269].
1335 Porensky EK, Dew MA, Karp JF, et al. The burden of late-life generalized anxiety disorder: effects on disability, health-related quality of life, and healthcare utilization. American Journal of Geriatric Psychiatry. 06. 2009;17(6):473-82. Not eligible outcomes. [pmid: 19472438].
1336 Porock D, Oliver DP, Zweig S, et al. Predicting death in the nursing home: development and validation of the 6-month Minimum Data Set mortality risk index. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 04. 2005;60(4):491-8. Not eligible target population.
1337 Previtali M, Repetto A, Panigada S, et al. Left ventricular apical ballooning syndrome: prevalence, clinical characteristics and pathogenetic mechanisms in a European population. International journal of cardiology. 05. 1. 2009;134(1):91-6. Not eligible outcomes. [pmid: 18508143].
1338 Prohaska T, Mermelstein R, Miller B, et al. Health data on older Americans: United States, 1992. Functional status and living arrangements. Vital Health Stat. 01. 1993;3(27):23-39. Not eligible outcomes.
1339 Pugh MJ, Palmer RF, Parchman ML, et al. Association of suboptimal prescribing and change in lower extremity physical function over time. Gerontology. 2007;53(6):445-53. Not eligible outcomes. [pmid: 18309233].
1340 Purchase-Helzner EL, Cauley JA, Faulkner KA, et al. Hearing sensitivity and the risk of incident falls and fracture in older women: the study of osteoporotic fractures. [erratum appears in Ann Epidemiol. 2004 Sep; 14(8):625]. Annals of Epidemiology. 05. 2004;14(5):311-8. Not eligible outcomes. [pmid: 15177269].
1341 Putzke JD, Richards JS, Hicken BL, et al. Interference due to pain following spinal cord injury: important predictors and impact on quality of life. Pain. 12. 2002;100(3):231-42. Not eligible outcomes. [pmid: 12467994].
1342 Pynsent PB, Carter SR, Bulstrode CJ. The total cost of hip-joint replacement; a model for purchasers. J Public Health Med. 06. 1996;18(2):157-68. Not eligible outcomes. [pmid: 8816313].
1343 Qu T, Walston JD, Yang H, et al. Upregulated ex vivo expression of stress-responsive inflammatory pathway genes by LPS-challenged CD14(+) monocytes in frail older adults. Mech Ageing Dev. 03. 2009;130(3):161-6. Not eligible target population. [pmid: 19027777].
1344 Quan SF, O’Connor GT, Quan JS, et al. Association of physical activity with sleep-disordered breathing. Sleep & Breathing. 09. 2007;11(3):149-57. Not eligible outcomes. [pmid: 17221274].
1345 Quander CR, Morris MC, Melson J, et al. Prevalence of and factors associated with fecal incontinence in a large community study of older individuals. Am J Gastroenterol. 04. 2005;100(4):905-9. Not eligible outcomes. [pmid: 15784039].
1346 Quigley KK, Hermann JR, Warde WD. Factors associated with Oklahoma Older Americans Act Nutrition Program participants ability to shop, cook, and feed themselves. J Nutr Elder. 2005;25(2):69-82. Not eligible outcomes. [pmid: 17182467].
1347 Quinn ME, Johnson MA, Andress EL, et al. Health characteristics of elderly residents in personal care homes. Dementia, possible early dementia, and no dementia. J Gerontol Nurs. 08. 2003;29(8):16-23. Not eligible outcomes. [pmid: 13677156].
1348 Rabbitt P, Lunn M, Wong D. Neglect of dropout underestimates effects of death in longitudinal studies. J Gerontol B Psychol Sci Soc Sci. 03. 2005;60(2):P106-9. Not eligible outcomes. [pmid: 15746019].
1349 Raccio-Robak N, McErlean MA, Fabacher DA, et al. Socioeconomic and health status differences between depressed and nondepressed ED elders. Am J Emerg Med. 03. 2002;20(2):71-3. Not eligible outcomes. [pmid: 11880865].
1350 Raji MA, Al Snih S, Ray LA, et al. Early mental ability may predict future ability to live independently. Ethn Dis. Winter. 2004;14(1):158-9. Patient Education Handout. [pmid: 15002936].
1351 Rakel RE. Clinical and societal consequences of obstructive sleep apnea and excessive daytime sleepiness. Postgraduate medicine. 01. 2009;121(1):86-95. Not eligible outcomes. [pmid: 19179816].
1352 Rakowski W, Mor V, Hiris J. The association of self-rated health with two-year mortality in a sample of well elderly. Journal of Aging & Health. 1991;3(4):527-45. Not eligible exposure.
1353 Rakowski W, Mor V, Hiris J. An investigation of nonresponse to self-assessment of health by older persons. Associations with mortality. J Aging Health. 11. 1994;6(4):469-88. Not eligible outcomes. [pmid: 10138384].
1354 Ramos MI, Allen LH, Mungas DM, et al. Low folate status is associated with impaired cognitive function and dementia in the Sacramento Area Latino Study on Aging. American Journal of Clinical Nutrition. 12. 2005;82(6):1346-52. Not eligible exposure. [pmid: 16332669].
1355 Ramulu PY, West SK, Munoz B, et al. Glaucoma and reading speed: the Salisbury Eye Evaluation project. Arch Ophthalmol. 01. 2009;127(1):82-7. Not eligible outcomes. [pmid: 19139345].
1356 Rantanen T, Sakari-Rantala R, Heikkinen E. Muscle strength before and mortality after a bone fracture in older people. Scand J Med Sci Sports. 10. 2002;12(5):296-300. Not eligibe exposure. [pmid: 12383075].
1357 Rantanen T, Volpato S, Ferrucci L, et al. Handgrip strength and cause-specific and total mortality in older disabled women: exploring the mechanism. J Am Geriatr Soc. 05. 2003;51(5):636-41. Not eligible exposure. [pmid: 12752838].
1358 Rantz MJ, Aud MA, Alexander G, et al. Falls, technology, and stunt actors: new approaches to fall detection and fall risk assessment. J Nurs Care Qual. 07–09. 2008;23(3):195-201. Not eligible outcomes. [pmid: 18562859].
1359 Rao SV, Schulman KA, Curtis LH, et al. Socioeconomic status and outcome following acute myocardial infarction in elderly patients. Arch Intern Med. 05. 24. 2004;164(10):1128-33. Not eligible exposure. [pmid: 15159271].
1360 Rao V, Spiro JR, Samus QM, et al. Sleep disturbances in the elderly residing in assisted living: findings from the Maryland Assisted Living Study. Int J Geriatr Psychiatry. 10. 2005;20(10):956-66. Not eligible outcomes. [pmid: 16163747].
1361 Rapp SR, Espeland MA, Hogan P, et al. Baseline experience with Modified Mini Mental State Exam: The Women’s Health Initiative Memory Study (WHIMS). Aging Ment Health. 05. 2003;7(3):217-23. Not eligible outcomes. [pmid: 12775404].
1362 Rasch EK, Hochberg MC, Magder L, et al. Health of community-dwelling adults with mobility limitations in the United States: prevalent health conditions. Part I. Arch Phys Med Rehabil. 02. 2008;89(2):210-8. Not eligible outcomes. [pmid: 18226643].
1363 Rasu RS, Jayawant SS, Abercrombie M, et al. Treatment of anemia among women with chronic kidney disease in United States outpatient settings. Womens Health Issues. 05–06. 2009;19(3):211-9. Not eligible outcomes. [pmid: 19447325].
1364 Ratcliffe SJ, Guo W, Ten Have TR. Joint modeling of longitudinal and survival data via a common frailty. Biometrics. 12. 2004;60(4):892-9. Not eligible outcomes. [pmid: 15606409].
1365 Rathore SS, Hinn AR, Cooper LS, et al. Characterization of incident stroke signs and symptoms: findings from the atherosclerosis risk in communities study. Stroke. 11. 2002;33(11):2718-21. Not eligible exposure. [pmid: 12411667].
1366 Raz N, Rodrigue KM, Head D, et al. Differential aging of the medial temporal lobe: a study of a five-year change. Neurology. 02. 10. 2004;62(3):433-8. Not eligible outcomes. [pmid: 14872026].
1367 Rehm CG, Ross SE. Elderly drivers involved in road crashes: a profile. American Surgeon. 05. 1995;61(5):435-7. Not eligible outcomes. [pmid: 7733551].
1368 Reid KF, Naumova EN, Carabello RJ, et al. Lower extremity muscle mass predicts functional performance in mobility-limited elders. J Nutr Health Aging. 08–09. 2008;12(7):493-8. Not eligible exposure. [pmid: 18615232].
1369 Reisberg B, Ferris SH, Franssen EH, et al. Mortality and temporal course of probable Alzheimer’s disease: a 5-year prospective study. Int Psychogeriatr. Summer. 1996;8(2):291-311. Not eligible population. [pmid: 8994898].
1370 Reitz C, Brickman AM, Luchsinger JA, et al. Frequency of subclinical heart disease in elderly persons with dementia. Am J Geriatr Cardiol. 05–06. 2007;16(3):183-8. Not eligible outcomes. [pmid: 17483671].
1371 Rejeski WJ, Ip EH, Marsh AP, et al. Obesity influences transitional states of disability in older adults with knee pain. Arch Phys Med Rehabil. 11. 2008;89(11):2102-7. Not eligible outcomes. [pmid: 18996238].
1372 Rejeski WJ, Miller ME, King AC, et al. Predictors of adherence to physical activity in the Lifestyle Interventions and Independence for Elders pilot study (LIFE-P). Clin Interv Aging. 2007;2(3):485-94. Not eligible outcomes. [pmid: 18044198].
1373 Repetto L, Venturino A, Fratino L, et al. Geriatric oncology: a clinical approach to the older patient with cancer. Eur J Cancer. 05. 2003;39(7):870-80. Not eligible outcomes. [pmid: 12706355].
1374 Resnick B. Alcohol use in a continuing care retirement community. J Gerontol Nurs. 10. 2003;29(10):22-9. Not eligible outcomes. [pmid: 14558232].
1375 Resnick B, Perry D, Applebaum G, et al. The impact of alcohol use in community-dwelling older adults. J Community Health Nurs. Fall. 2003;20(3):135-45. Not eligible outcomes. [pmid: 12925311].
1376 Reuben DB, Keeler E, Seeman TE, et al. Identification of risk for high hospital use: cost comparisons of four strategies and performance across subgroups. J Am Geriatr Soc. 05. 2003;51(5):615-20. Not eligible exposure. [pmid: 12752835].
1377 Reuben DB, Zwanziger J, Bradley TB, et al. How many physicians will be needed to provide medical care for older persons? Physician manpower needs for the twenty-first century. J Am Geriatr Soc. 04. 1993;41(4):444-53. Not eligible outcomes. [pmid: 8463534].
1378 Reuser M, Bonneux LG, Willekens FJ. Smoking kills, obesity disables: a multistate approach of the US Health and Retirement Survey. Obesity. 04. 2009;17(4):783-9. Not eligible outcomes. [pmid: 19165165].
1379 Reyes-Ortiz CA, Kuo YF, DiNuzzo AR, et al. Near vision impairment predicts cognitive decline: data from the Hispanic Established Populations for Epidemiologic Studies of the Elderly. Journal of the American Geriatrics Society. 04. 2005;53(4):681-6. Not eligible outcomes. [pmid: 15817017].
1380 Reynolds MW, Fredman L, Langenberg P, et al. Weight, weight change, mortality in a random sample of older community-dwelling women.[see comment]. Journal of the American Geriatrics Society. 12. 1999;47(12):1409-14. Not eligible outcomes. [pmid: 10591233].
1381 Reynolds SL, McIlvane JM. The impact of obesity and arthritis on active life expectancy in older Americans. Obesity. 02. 2009;17(2):363-9. Not eligible outcomes. [pmid: 19023280].
1382 Rhoades DA, Welty TK, Wang W, et al. Aging and the prevalence of cardiovascular disease risk factors in older American Indians: the Strong Heart Study. Journal of the American Geriatrics Society. 01. 2007;55(1):87-94. Not eligible outcomes. [pmid: 17233690].
1383 Rhoads J, Clayman A, Nelson S. The relationship of urinary tract infections and falls in a nursing home. Director. Winter. 2007;15(1):22-6. Not eligible target population. [pmid: 19348053].
1384 Ricci JA, Stewart WF, Chee E, et al. Pain exacerbation as a major source of lost productive time in US workers with arthritis. Arthritis Rheum. 10. 15. 2005;53(5):673-81. Not eligible outcomes. [pmid: 16208644].
1385 Rice SC, Zonderman AB, Metter EJ, et al. Absence of relation between depressive symptoms and carotid intimal medial thickness in the Baltimore Longitudinal Study of Aging. Psychosomatic medicine. 01. 2009;71(1):70-6. Not eligible exposure. [pmid: 18842746].
1386 Richard E, Kuiper R, Dijkgraaf MG, et al. Vascular care in patients with Alzheimer’s disease with cerebrovascular lesions-a randomized clinical trial. Journal of the American Geriatrics Society. 05. 2009;57(5):797-805. Not eligible outcomes. [pmid: 19484836].
1387 Richter HE, Redden DT, Duxbury AS, et al. Pelvic floor surgery in the older woman: enhanced compared with usual preoperative assessment. Obstet Gynecol. 04. 2005;105(4):800-7. Not eligible outcomes. [pmid: 15802408].
1388 Riekse RG, Leverenz JB, McCormick W, et al. Effect of vascular lesions on cognition in Alzheimer’s disease: a community-based study. J Am Geriatr Soc. 09. 2004;52(9):1442-8. Not eligible outcomes. [pmid: 15341544].
1389 Riggs BL, Melton LJ, Robb RA, et al. A population-based assessment of rates of bone loss at multiple skeletal sites: evidence for substantial trabecular bone loss in young adult women and men. Journal of Bone & Mineral Research. 02. 2008;23(2):205-14. Not eligible outcomes. [pmid: 17937534].
1390 Riggs JE. Mortality from accidental falls among the elderly in the United States, 1962–1988 demonstrating the impact of improved trauma management. J Trauma. 08. 1993;35(2):212-9. Not eligible outcomes. [pmid: 8355298].
1391 Ringland C, Mant A, McGettigan P, et al. Uncovering the potential risk of serotonin toxicity in Australian veterans using pharmaceutical claims data. Br J Clin Pharmacol. 11. 2008;66(5):682-8. Not eligible outcomes. [pmid: 18754849].
1392 Rinkel GJ, Djibuti M, Algra A, et al. Prevalence and risk of rupture of intracranial aneurysms: a systematic review. Stroke. 01. 1998;29(1):251-6. Not eligible outcomes. [pmid: 9445359].
1393 Ripatti S, Gatz M, Pedersen NL, et al. Three-state frailty model for age at onset of dementia and death in Swedish twins. Genet Epidemiol. 02. 2003;24(2):139-49. Not eligible outcomes. [pmid: 12548675].
1394 Rivenes AC, Harvey SB, Mykletun A. The relationship between abdominal fat, obesity, and common mental disorders: results from the HUNT study. Journal of psychosomatic research. 04. 2009;66(4):269-75. Not eligible outcomes. [pmid: 19302883].
1395 Rivera JA, Fried LP, Weiss CO, et al. At the tipping point: predicting severe mobility difficulty in vulnerable older women. J Am Geriatr Soc. 08. 2008;56(8):1417-23. Not eligible outcomes. [pmid: 18808598].
1396 Robert SA, Cherepanov D, Palta M, et al. Socioeconomic status and age variations in health-related quality of life: results from the national health measurement study. J Gerontol B Psychol Sci Soc Sci. 05. 2009;64(3):378-89. Not eligible outcomes. [pmid: 19307286].
1397 Roberts C, Horton AM Jr. Demographic effects on the Trail Making Test in amphetamine abusers. International Journal of Neuroscience. 2001;110(3–4):181-7. Not eligible outcomes. [pmid: 11912868].
1398 Roberts C, Horton AR Jr. Demographic effects on the Trail Making Test in sedatives abusers. International Journal of Neuroscience. 2001;110(3–4):189-95. Not eligible target population. [pmid: 11912869].
1399 Roberts RE, Shema SJ, Kaplan GA. Prospective data on sleep complaints and associated risk factors in an older cohort. Psychosomatic medicine. 03–04. 1999;61(2):188-96. Not eligible outcomes. [pmid: 10204972].
1400 Roberts RE, Shema SJ, Kaplan GA, et al. Sleep complaints and depression in an aging cohort: A prospective perspective. American Journal of Psychiatry. 01. 2000;157(1):81-8. Not eligible exposure. [pmid: 10618017].
1401 Roberts RO, Jacobsen SJ, Rhodes T, et al. Urinary incontinence in a community-based cohort: prevalence and healthcare-seeking. J Am Geriatr Soc. 04. 1998;46(4):467-72. Not eligible outcomes. [pmid: 9560070].
1402 Rocca WA, Grossardt BR, Geda YE, et al. Long-term risk of depressive and anxiety symptoms after early bilateral oophorectomy.[see comment]. Menopause. 11–12. 2008;15(6):1050-9. Not eligible outcomes. [pmid: 18724263].
1403 Rocca WA, Grossardt BR, Peterson BJ, et al. The Mayo Clinic cohort study of personality and aging: design and sampling, reliability and validity of instruments, and baseline description. Neuroepidemiology. 2006;26(3):119-29. Not eligible outcomes. [pmid: 16424675].
1404 Roccaforte WH, Burke WJ, Bayer BL, et al. Validation of a telephone version of the mini-mental state examination. J Am Geriatr Soc. 07. 1992;40(7):697-702. outcomes. [pmid: 1607586].
1405 Roccaforte WH, Burke WJ, Bayer BL, et al. Reliability and validity of the Short Portable Mental Status Questionnaire administered by telephone. J Geriatr Psychiatry Neurol. 01–03. 1994;7(1):33-8. outcomes. [pmid: 8192828].
1406 Rochtchina E, Mukesh BN, Wang JJ, et al. Projected prevalence of age-related cataract and cataract surgery in Australia for the years 2001 and 2021: pooled data from two population-based surveys. Clin Experiment Ophthalmol. 06. 2003;31(3):233-6. Not eligible outcomes. [pmid: 12786774].
1407 Rockwood K. What would make a definition of frailty successful. Age Ageing. 09. 2005;34(5):432-4. Comment. [pmid: 16107450].
1408 Rockwood K, Abeysundera MJ, Mitnitski A. How should we grade frailty in nursing home patients. J Am Med Dir Assoc. 11. 2007;8(9):595-603. Not eligible target population. [pmid: 17998116].
1409 Rockwood K, Davis HS, Merry HR, et al. Sleep disturbances and mortality: results from the Canadian Study of Health and Aging. Journal of the American Geriatrics Society. 05. 2001;49(5):639-41. Not eligible outcomes. [pmid: 11380758].
1410 Rockwood K, Mogilner A, Mitnitski A. Changes with age in the distribution of a frailty index. Mech Ageing Dev. 07. 2004;125(7):517-9. Not eligible outcomes. [pmid: 15246748].
1411 Rockwood K, Nassar B, Mitnitski A. Apolipoprotein E-polymorphism, frailty and mortality in older adults. J Cell Mol Med. 12. 2008;12(6B):2754-61. Not eligible exposure. [pmid: 18266965].
1412 Rockwood K, Song X, MacKnight C, et al. A global clinical measure of fitness and frailty in elderly people. Canadian Medical Association Journal. 2005;173(5):489-95. Not eligible outcomes. [pmid: 16129869].
1413 Rodriguez A, Muller DC, Engelhardt M, et al. Contribution of impaired glucose tolerance in subjects with the metabolic syndrome: Baltimore Longitudinal Study of Aging. Metabolism: Clinical & Experimental. 04. 2005;54(4):542-7. Not eligible exposure. [pmid: 15798964].
1414 Roebuck-Spencer TM, Yarboro C, Nowak M, et al. Use of computerized assessment to predict neuropsychological functioning and emotional distress in patients with systemic lupus erythematosus. Arthritis & Rheumatism. 06. 15. 2006;55(3):434-41. Not eligible outcomes. [pmid: 16739211].
1415 Roff LL, Klemmack DL, Simon C, et al. Functional limitations and religious service attendance among African American and white older adults. Health Soc Work. 11. 2006;31(4):246-55. Not eligible outcomes. [pmid: 17176972].
1416 Rogers A, Rogers RG, Branch LG. A multistate analysis of active life expectancy. Public Health Rep. 05–06. 1989;104(3):222-6. Not eligible outcomes. [pmid: 2498971].
1417 Rogers MA, Plassman BL, Kabeto M, et al. Parental education and late-life dementia in the United States. Journal of Geriatric Psychiatry & Neurology. 03. 2009;22(1):71-80. Not eligible exposure. [pmid: 19073840].
1418 Rogers RG, Leeman LM, Migliaccio L, et al. Does the severity of spontaneous genital tract trauma affect postpartum pelvic floor function. International Urogynecology Journal. 03. 2008;19(3):429-35. Not eligible outcomes.
1419 Rolfson DB, Majumdar SR, Tsuyuki RT, et al. Validity and reliability of the Edmonton Frail Scale. Age Ageing. 09. 2006;35(5):526-9. Not eligible outcomes. [pmid: 16757522].
1420 Roman MW, Callen BL. Screening instruments for older adult depressive disorders: updating the evidence-based toolbox. Issues in Mental Health Nursing. 09. 2008;29(9):924-41. Review. [pmid: 18770099].
1421 Rondeau V, Filleul L, Joly P. Nested frailty models using maximum penalized likelihood estimation. Stat Med. 12. 15. 2006;25(23):4036-52. Not eligible outcomes. [pmid: 16463308].
1422 Rondeau V, Mathoulin-Pelissier S, Jacqmin-Gadda H, et al. Joint frailty models for recurring events and death using maximum penalized likelihood estimation: application on cancer events. Biostatistics. 10. 2007;8(4):708-21. Simulation study. [pmid: 17267392].
1423 Rondinelli RD, Beller TA. Impairment rating and disability evaluation of the pulmonary system. Phys Med Rehabil Clin N Am. 08. 2001;12(3):667-79. xi. Review. [pmid: 11478197].
1424 Roos LL, Walld RK, Romano PS, et al. Short-term mortality after repair of hip fracture. Do Manitoba elderly do worse?. Med Care. 04. 1996;34(4):310-26. Not eligible outcomes. [pmid: 8606556].
1425 Rosano C, Brach J, Longstreth WT Jr, et al. Quantitative measures of gait characteristics indicate prevalence of underlying subclinical structural brain abnormalities in high-functioning older adults. Neuroepidemiology. 2006;26(1):52-60. Not eligible outcomes. [pmid: 16254454].
1426 Rose PG, Lappas PT. Analysis of the cost effectiveness of concurrent cisplatin-based chemoradiation in cervical cancer: implications from five randomized trials. Gynecol Oncol. 07. 2000;78(1):3-6. Not eligible outcomes. [pmid: 10873400].
1427 Rosen J, Mittal V, Degenholtz H, et al. Pressure ulcer prevention in black and white nursing home residents: A QI initiative of enhanced ability, incentives, and management feedback. Adv Skin Wound Care. 06. 2006;19(5):262-8. Not eligible target population. [pmid: 16732072].
1428 Rosen R, Altwein J, Boyle P, et al. Lower urinary tract symptoms and male sexual dysfunction: the multinational survey of the aging male (MSAM-7). European Urology. 12. 2003;44(6):637-49. Not eligible outcomes. [pmid: 14644114].
1429 Rosenberg PB, Mielke MM, Samus QM, et al. Transition to nursing home from assisted living is not associated with dementia or dementia-related problem behaviors. J Am Med Dir Assoc. 02. 2006;7(2):73-8. Not eligible outcomes. [pmid: 16461247].
1430 Rosenblatt A, Mehta KM, Romanoski A, et al. Major depression and cognitive decline after 11.5 years: findings from the ECA study. Journal of Nervous & Mental Disease. 12. 2003;191(12):827-30. Not eligible outcomes. [pmid: 14671460].
1431 Rosenthal MJ. Analyses of nursing home residents with diabetes at admission.[comment]. Journal of the American Medical Directors Association. 09–10. 2004;5(5):353-5. Not eligible target population. [pmid: 15357894].
1432 Rosero-Bixby L. The exceptionally high life expectancy of Costa Rican nonagenarians. Demography. 08. 2008;45(3):673-91. Not eligible outcomes. [pmid: 18939667].
1433 Rosero-Bixby L, Dow WH. Surprising SES Gradients in mortality, health, and biomarkers in a Latin American population of adults. J Gerontol B Psychol Sci Soc Sci. 01. 2009;64(1):105-17. Not eligible outcomes. [pmid: 19196695].
1434 Roush GC, McKay L, Holford TR. A reversal in the long-term increase in deaths attributable to malignant melanoma. Cancer. 04. 1. 1992;69(7):1714-20. Not eligible outcomes. [pmid: 1551056].
1435 Rozario PA, Morrow-Howell N, Proctor E. Comparing the congruency of self-report and provider records of depressed elders’ service use by provider type. Med Care. 10. 2004;42(10):952-9. Not eligible outcomes. [pmid: 15377927].
1436 Rozzini R, Frisoni GB, Ferrucci L, et al. Geriatric Index of Comorbidity: validation and comparison with other measures of comorbidity. Age Ageing. 07. 2002;31(4):277-85. Not eligible target population. [pmid: 12147566].
1437 Rozzini R, Frisoni GB, Franzoni S, et al. Change in functional status during hospitalization in older adults: a geriatric concept of frailty. J Am Geriatr Soc. 08. 2000;48(8):1024-5. Comment. [pmid: 10968318].
1438 Rozzini R, Sabatini T, Cassinadri A, et al. Relationship between functional loss before hospital admission and mortality in elderly persons with medical illness. J Gerontol A Biol Sci Med Sci. 09. 2005;60(9):1180-3. Not eligible outcomes. [pmid: 16183960].
1439 Rozzini R, Sabatini T, Frisoni GB, et al. Frailty is a strong modulator of heart failure-associated mortality. Arch Intern Med. 03. 24. 2003;163(6):737-8. author reply 8. Not eligible outcomes. [pmid: 12639210].
1440 Rubenstein LZ, Solomon DH, Roth CP, et al. Detection and management of falls and instability in vulnerable elders by community physicians. J Am Geriatr Soc. 09. 2004;52(9):1527-31. Not eligible outcomes. [pmid: 15341556].
1441 Rubin CD, Sizemore MT, Loftis PA, et al. The effect of geriatric evaluation and management on Medicare reimbursement in a large public hospital: a randomized clinical trial. J Am Geriatr Soc. 10. 1992;40(10):989-95. Not eligible outcomes. [pmid: 1401688].
1442 Rubin GS, West SK, Munoz B, et al. A comprehensive assessment of visual impairment in a population of older Americans. The SEE Study. Salisbury Eye Evaluation Project. Investigative Ophthalmology & Visual Science. 03. 1997;38(3):557-68. Not eligible outcomes. [pmid: 9071208].
1443 Rudberg MA, Furner SE, Dunn JE, et al. The relationship of visual and hearing impairments to disability: an analysis using the longitudinal study of aging. J Gerontol. 11. 1993;48(6):M261-5. Not eligible exposure. [pmid: 8227996].
1444 Rudman D, Bross D, Mattson DE. Clinical indicators derived from the patient assessment instrument in the long-stay residents of 69 VA nursing homes. J Gen Intern Med. 05. 1994;9(5):261-7. Not eligible target population. [pmid: 8046528].
1445 Rudnicka AR, Mt-Isa S, Owen CG, et al. Variations in primary open-angle glaucoma prevalence by age, gender, and race: a Bayesian meta-analysis. Invest Ophthalmol Vis Sci. 10. 2006;47(10):4254-61. Not eligible outcomes. [pmid: 17003413].
1446 Rudy TE, Weiner DK, Lieber SJ, et al. The impact of chronic low back pain on older adults: a comparative study of patients and controls. Pain. 10. 2007;131(3):293-301. Not eligible outcomes. [pmid: 17317008].
1447 Ruggiero C, Cherubini A, Guralnik J, et al. The interplay between uric acid and antioxidants in relation to physical function in older persons. J Am Geriatr Soc. 08. 2007;55(8):1206-15. Not eligible outcome. [pmid: 17661959].
1448 Russell DW, Cutrona CE, de la Mora A, et al. Loneliness and nursing home admission among rural older adults. Psychology & Aging. 12. 1997;12(4):574-89. Not eligible exposure. [pmid: 9416627].
1449 Ryan EL, Morgello S, Isaacs K, et al. Neuropsychiatric impact of hepatitis C on advanced HIV.[see comment]. Neurology. 03. 23. 2004;62(6):957-62. Not eligible outcomes. [pmid: 15037699].
1450 Rychnovsky J, Hunter LP, Rychnovsky J, et al. The relationship between sleep characteristics and fatigue in healthy postpartum women. Womens Health Issues. 01–02. 2009;19(1):38-44. Not eligible outcomes. [pmid: 19111786].
1451 Ryerson B, Tierney EF, Thompson TJ, et al. Excess physical limitations among adults with diabetes in the U.S. population, 1997–1999. Diabetes Care. 01. 2003;26(1):206-10. Not eligible population. [pmid: 12502682].
1452 Rywik TM, O’Connor FC, Gittings NS, et al. Role of nondiagnostic exercise-induced ST-segment abnormalities in predicting future coronary events in asymptomatic volunteers. Circulation. 11. 26. 2002;106(22):2787-92. Not eligible exposure. [pmid: 12451004].
1453 Sa Carvalho M, Henderson R, Shimakura S, et al. Survival of hemodialysis patients: modeling differences in risk of dialysis centers. Int J Qual Health Care. 06. 2003;15(3):189-96. Not eligible outcomes. [pmid: 12803346].
1454 Sackett CS, Schenning S, Sackett CS, et al. The age-related eye disease study: the results of the clinical trial. Insight (American Society of Ophthalmic Registered Nurses). 01–03. 2002;27(1):5-7. Not eligible outcomes. [pmid: 11962062].
1455 Sackett K, Smith T, D’Angelo L, et al. The Medicare health risk assessment program. Case Manager. 05–06. 2001;12(3):52-5. Not eligible outcomes. [pmid: 11351235].
1456 Sacks GS, Dearman K, Replogle WH, et al. Use of subjective global assessment to identify nutrition-associated complications and death in geriatric long-term care facility residents. J Am Coll Nutr. 10. 2000;19(5):570-7. Not eligible target population. [pmid: 11022870].
1457 Saczynski JS, Pfeifer LA, Masaki K, et al. The effect of social engagement on incident dementia: the Honolulu-Asia Aging Study. American Journal of Epidemiology. 03. 1. 2006;163(5):433-40. Not eligible exposure. [pmid: 16410348].
1458 Salvatore S, Serati M, Digesu GA, et al. Efficacy of tolterodine in relation to different urodynamic findings of detrusor overactivity. International Urogynecology Journal. 05. 2008;19(5):701-4. Not eligible outcomes.
1459 Salvi F, Miller MD, Grilli A, et al. A manual of guidelines to score the modified cumulative illness rating scale and its validation in acute hospitalized elderly patients. J Am Geriatr Soc. 10. 2008;56(10):1926-31. Not eligible population. [pmid: 18811613].
1460 Samus QM, Rosenblatt A, Onyike C, et al. Correlates of caregiver-rated quality of life in assisted living: the Maryland Assisted Living study. J Gerontol B Psychol Sci Soc Sci. 09. 2006;61(5):P311-4. Not eligible outcomes. [pmid: 16960235].
1461 Sangi-Haghpeykar H, Mozayeni P, Young A, et al. Stress urinary incontinence and counseling and practice of pelvic floor exercises postpartum in low-income Hispanic women. [erratum appears in Int Urogynecol J Pelvic Floor Dysfunct. 2008 Oct; 19(10):1459 Note: Sangi-Haphpeykar, Haleh [corrected to Sangi-Haghpeykar, Haleh]]. International Urogynecology Journal. 03. 2008;19(3):361-5. Not eligible outcomes.
1462 Santin M, Trout JM, Fayer R, et al. A longitudinal study of cryptosporidiosis in dairy cattle from birth to 2 years of age. Veterinary Parasitology. 08. 1. 2008;155(1–2):15-23. Not eligible outcomes. [pmid: 18565677].
1463 Santos-Eggimann B, Karmaniola A, Seematter-Bagnoud L, et al. The Lausanne cohort Lc65+: a population-based prospective study of the manifestations, determinants and outcomes of frailty. BMC Geriatr. 2008;8:20. No associative hypothesis tested. [pmid: 18706113].
1464 Sarkisian CA, Liu H, Ensrud KE, et al. Correlates of attributing new disability to old age. Study of Osteoporotic Fractures Research Group. J Am Geriatr Soc. 02. 2001;49(2):134-41. Not eligible outcomes. [pmid: 11207866].
1465 Satz P, Forney DL, Zaucha K, et al. Depression, cognition, and functional correlates of recovery outcome after traumatic brain injury. Brain Injury. 07. 1998;12(7):537-53. Not eligible outcomes. [pmid: 9653518].
1466 Saunders R, Friedman B. Oral health conditions of community-dwelling cognitively intact elderly persons with disabilities. Gerodontology. 06. 2007;24(2):67-76. Not eligible outcomes. [pmid: 17518953].
1467 Savitz SI, Lew R, Bluhmki E, et al. Shift analysis versus dichotomization of the modified Rankin scale outcome scores in the NINDS and ECASS-II trials. Stroke. 12. 2007;38(12):3205-12. Not eligible outcomes. [pmid: 17975102].
1468 Sawaya GF, Guirguis-Blake J, LeFevre M, et al. Update on the methods of the U.S. Preventive Services Task Force: estimating certainty and magnitude of net benefit. Ann Intern Med. 12. 18. 2007;147(12):871-5. Not eligible outcomes. [pmid: 18087058].
1469 Sayers SP, Jette AM, Haley SM, et al. Validation of the Late-Life Function and Disability Instrument. J Am Geriatr Soc. 09. 2004;52(9):1554-9. Not eligible outcomes. [pmid: 15341561].
1470 Schantz SL, Gasior DM, Polverejan E, et al. Impairments of memory and learning in older adults exposed to polychlorinated biphenyls via consumption of Great Lakes fish.[see comment]. Environmental Health Perspectives. 06. 2001;109(6):605-11. Not eligible exposure. [pmid: 11445515].
1471 Schatz IJ, Masaki K, Yano K, et al. Cholesterol and all-cause mortality in elderly people from the Honolulu Heart Program: a cohort study.[see comment]. Lancet. 08. 4. 2001;358(9279):351-5. Not eligible exposure. [pmid: 11502313].
1472 Schaubel DE, Cai J. Analysis of clustered recurrent event data with application to hospitalization rates among renal failure patients. Biostatistics. 07. 2005;6(3):404-19. Not eligible exposure. [pmid: 15831581].
1473 Scheetz LJ, Zhang J, Kolassa JE. Using crash scene variables to predict the need for trauma center care in older persons. Res Nurs Health. 08. 2007;30(4):399-412. Not eligible outcomes. [pmid: 17654535].
1474 Scherr PA, LaCroix AZ, Wallace RB, et al. Light to moderate alcohol consumption and mortality in the elderly. J Am Geriatr Soc. 07. 1992;40(7):651-7. Not eligible outcomes. [pmid: 1607579].
1475 Schmitt J, Di Fabio RP. The validity of prospective and retrospective global change criterion measures. Arch Phys Med Rehabil. 12. 2005;86(12):2270-6. Not eligible outcomes. [pmid: 16344022].
1476 Schneeweiss S, Setoguchi S, Brookhart MA, et al. Assessing residual confounding of the association between antipsychotic medications and risk of death using survey data. CNS Drugs. 2009;23(2):171-80. Not eligible outcomes. [pmid: 19173375].
1477 Schneider JA, Wilson RS, Cochran EJ, et al. Relation of cerebral infarctions to dementia and cognitive function in older persons. Neurology. 04. 8. 2003;60(7):1082-8. Not eligible outcomes. [pmid: 12682310].
1478 Schnelle JF, Wood S, Schnelle ER, et al. Measurement sensitivity and the Minimum Data Set depression quality indicator. Gerontologist. 06. 2001;41(3):401-5. Not eligible target population. [pmid: 11405438].
1479 Schonknecht OD, Hunt A, Toro P, et al. Neural correlates of delayed episodic memory in patients with mild cognitive impairment--a FDG PET study. Neurosci Lett. 12. 25. 2009;467(2):100-4. Not eligible outcomes. [pmid: 19819300].
1480 Schooling CM, Lam TH, Li ZB, et al. Obesity, physical activity, and mortality in a prospective chinese elderly cohort. Arch Intern Med. 07. 24. 2006;166(14):1498-504. Not eligible exposure. [pmid: 16864760].
1481 Schootman M, Andresen EM, Wolinsky FD, et al. Neighborhood conditions and risk of incident lower-body functional limitations among middle-aged African Americans. American Journal of Epidemiology. 03. 1. 2006;163(5):450-8. Not eligible outcomes. [pmid: 16421245].
1482 Schraeder C, Britt T, Shelton P. Integrated risk assessment and feedback reporting for clinical decision making in a Medicare Risk plan. J Ambul Care Manage. 10. 2000;23(4):40-7. Not eligible outcomes. [pmid: 11067092].
1483 Schraeder C, Shelton P, Britt T, et al. Case management in a capitated system: the community nursing organization. J Case Manag. Summer. 1996;5(2):58-64. Not eligible outcomes. [pmid: 8900778].
1484 Schram MT, Euser SM, de Craen AJ, et al. Systemic markers of inflammation and cognitive decline in old age. J Am Geriatr Soc. 05. 2007;55(5):708-16. Not eligible outcomes. [pmid: 17493190].
1485 Schroeder SD. Quality focus: Welcome to Medicare exams--a great opportunity for South Dakota seniors. S D Med. 05. 2007;60(5):207. Not eligible outcomes. [pmid: 17694942].
1486 Schuler J, Duckelmann C, Beindl W, et al. Polypharmacy and inappropriate prescribing in elderly internal-medicine patients in Austria. Wien Klin Wochenschr. 2008;120(23–24):733-41. Not eligible target population. [pmid: 19122984].
1487 Schulman E, Gairola G, Kuder L, et al. Depression and associated characteristics among community-based elderly people. J Allied Health. Fall. 2002;31(3):140-6. Not eligible outcomes. [pmid: 12227264].
1488 Schulz R, Beach SR, Hebert RS, et al. Spousal suffering and partner’s depression and cardiovascular disease: the Cardiovascular Health Study. American Journal of Geriatric Psychiatry. 03. 2009;17(3):246-54. Not eligible outcomes. [pmid: 19454851].
1489 Schulz R, Mittelmark M, Kronmal R, et al. Predictors of perceived health status in elderly men and women. The Cardiovascular Health Study. J Aging Health. 11. 1994;6(4):419-47. Not eligible outcomes. [pmid: 10138383].
1490 Schulz R, Williamson GM. Psychosocial and behavioral dimensions of physical frailty. J Gerontol. 09. 1993;48(Spec No:39–43). Review.
1491 Schupf N, Costa R, Luchsinger J, et al. Relationship between plasma lipids and all-cause mortality in nondemented elderly. J Am Geriatr Soc. 02. 2005;53(2):219-26. Not eligible exposure. [pmid: 15673344].
1492 Schupf N, Costa R, Tang MX, et al. Preservation of cognitive and functional ability as markers of longevity. Neurobiology of aging. 10. 2004;25(9):1231-40. Not eligible exposure. [pmid: 15312969].
1493 Schwab TC. Social HMOs: lessons learned and future direction. Med Interface. 12. 1996;9(12):106-10. Not eligible outcomes. [pmid: 10163857].
1494 Schweitzer SO, Atchison KA, Lubben JE, et al. Health promotion and disease prevention for older adults: opportunity for change or preaching to the converted. Am J Prev Med. 07–08. 1994;10(4):223-9. Not eligible outcomes. [pmid: 7803065].
1495 Scott CM, Popovich DJ. Undiagnosed alcoholism & prescription drug misuse among the elderly. Special considerations for home assessment. Caring. 01. 2001;20(1):20-3. quiz 4–5. Not eligible outcomes. [pmid: 11190975].
1496 Scott LD, Hwang WT, Rogers AE, et al. The impact of multiple care giving roles on fatigue, stress, and work performance among hospital staff nurses. Journal of Nursing Administration. 02. 2006;36(2):86-95. Not eligible outcomes. [pmid: 16528150].
1497 Scott TE, Mendez MV, LaMorte WW, et al. Are varicose veins a marker for susceptibility to coronary heart disease in men? Results from the Normative Aging Study. Annals of Vascular Surgery. 07. 2004;18(4):459-64. Not eligible outcomes. [pmid: 15156364].
1498 Searle SD, Mitnitski A, Gahbauer EA, et al. A standard procedure for creating a frailty index. BMC Geriatr. 2008;8:24. Not eligible outcomes. [pmid: 18826625].
1499 Seebacher C, Hillmann E, Roitzsch E, et al. Yersinia enterocolitica as an aetiological factor of erythema nodosum and erythema exsudativum multiforme (author’s transl). Dermatol Monatsschr. 11. 1978;164(11):779-85. Not eligible outcomes. [pmid: 720709].
1500 Seeman I. Sampler of findings from the 1986 national mortality followback survey on risk factors, disability, and health care. Public Health Reports. 11–12. 1992;107(6):707-12. Not eligible outcomes. [pmid: 1454983].
1501 Seeman TE, Charpentier PA, Berkman LF, et al. Predicting changes in physical performance in a high-functioning elderly cohort: MacArthur studies of successful aging. J Gerontol. 05. 1994;49(3):M97-108. Not eligible outcomes. [pmid: 8169338].
1502 Seeman TE, Huang MH, Bretsky P, et al. Education and APOE-e4 in longitudinal cognitive decline: MacArthur Studies of Successful Aging. J Gerontol B Psychol Sci Soc Sci. 03. 2005;60(2):P74-83. Not eligible outcomes. [pmid: 15746021].
1503 Seeman TE, McEwen BS, Singer BH, et al. Increase in urinary cortisol excretion and memory declines: MacArthur studies of successful aging. Journal of Clinical Endocrinology & Metabolism. 08. 1997;82(8):2458-65. Not eligible outcomes. [pmid: 9253318].
1504 Seeman TE, Singer BH, Rowe JW, et al. Price of adaptation--allostatic load and its health consequences. MacArthur studies of successful aging. Arch Intern Med. 10. 27. 1997;157(19):2259-68. Not eligible outcomes. [pmid: 9343003].
1505 Seeman TE, Singer BH, Ryff CD, et al. Social relationships, gender, and allostatic load across two age cohorts. Psychosom Med. 05–06. 2002;64(3):395-406. Not eligible outcomes. [pmid: 12021414].
1506 Sehl ME. Senescence, frailty and mortality: mathematical models of aging. Med Health R I. 11. 2001;84(11):360-4. Not eligible outcomes. [pmid: 12355663].
1507 Sellars C, Bowie L, Bagg J, et al. Risk factors for chest infection in acute stroke: a prospective cohort study. Stroke. 08. 2007;38(8):2284-91. Not eligible outcomes. [pmid: 17569875].
1508 Selmer R, Halvorsen S, Myhre KI, et al. Cost-effectiveness of primary percutaneous coronary intervention versus thrombolytic therapy for acute myocardial infarction. Scand Cardiovasc J. 10. 2005;39(5):276-85. Not eligible target population. [pmid: 16269397].
1509 Selnes OA, Grega MA, Bailey MM, et al. Cognition 6 years after surgical or medical therapy for coronary artery disease. Annals of Neurology. 05. 2008;63(5):581-90. Not eligible outcomes. [pmid: 18481292].
1510 Semba RD, Bandinelli S, Sun K, et al. Plasma carboxymethyl-lysine, an advanced glycation end product, and all-cause and cardiovascular disease mortality in older community-dwelling adults. J Am Geriatr Soc. 10. 2009;57(10):1874-80. Not eligible exposure. [pmid: 19682127].
1511 Semba RD, Bartali B, Zhou J, et al. Low serum micronutrient concentrations predict frailty among older women living in the community. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 06. 2006;61(6):594-9. Not eligible exposure.
1512 Semba RD, Blaum CS, Bartali B, et al. Denture use, malnutrition, frailty, and mortality among older women living in the community. J Nutr Health Aging. 03–04. 2006;10(2):161-7. Not eligible outcomes. [pmid: 16554954].
1513 Semba RD, Ferrucci L, Sun K, et al. Oxidative stress is associated with greater mortality in older women living in the community. Journal of the American Geriatrics Society. 09. 2007;55(9):1421-5. Not eligible outcomes. [pmid: 17767685].
1514 Semba RD, Margolick JB, Leng S, et al. T cell subsets and mortality in older community-dwelling women. Exp Gerontol. 01–02. 2005;40(1–2):81-7. Not eligible outcomes. [pmid: 15664735].
1515 Semba RD, Patel KV, Sun K, et al. Association between serum carboxymethyl-lysine, a dominant advanced glycation end product, and anemia in adults: the Baltimore longitudinal study of aging. Journal of the American Geriatrics Society. 11. 2008;56(11):2145-7. Not eligible exposure. [pmid: 19016950].
1516 Semke J, Jensen J. High utilization of inpatient psychiatric services by older adults. Psychiatric Services. 02. 1997;48(2):172-4. Not eligible outcomes. [pmid: 9021846].
1517 Senni M, Tribouilloy CM, Rodeheffer RJ, et al. Congestive heart failure in the community: a study of all incident cases in Olmsted County, Minnesota, in 1991. Circulation. 11. 24. 1998;98(21):2282-9. Not eligible outcomes. [pmid: 9826315].
1518 Senni M, Tribouilloy CM, Rodeheffer RJ, et al. Congestive heart failure in the community: trends in incidence and survival in a 10-year period. Arch Intern Med. 01. 11. 1999;159(1):29-34. Not eligible outcomes. [pmid: 9892327].
1519 Seripa D, Forno GD, Matera MG, et al. Methylenetetrahydrofolate reductase and angiotensin converting enzyme gene polymorphisms in two genetically and diagnostically distinct cohort of Alzheimer patients. Neurobiology of aging. 11. 2003;24(7):933-9. Not eligible exposure. [pmid: 12928053].
1520 Service PM, Ochoa R, Valenzuela R, et al. Cohort size and maximum likelihood estimation of mortality parameters. Exp Gerontol. 06. 1998;33(4):331-42. Not eligible outcomes. [pmid: 9639169].
1521 Seshamani M, Gray A. Time to death and health expenditure: an improved model for the impact of demographic change on health care costs. Age Ageing. 11. 2004;33(6):556-61. Not eligible outcomes. [pmid: 15308460].
1522 Setiati S. Comprehensive geriatric assessment: important tool in evaluating health care problems in geriatric patient. Acta Med Indones. 01. 2008;40(1):1-2. Not eligible outcomes. [pmid: 19054876].
1523 Seton M, Jackson V, Lasser KE, et al. Low 25-hydroxyvitamin D and osteopenia are prevalent in persons > or =55 yr with fracture at any site: a prospective, observational study of persons fracturing in the community. Journal of Clinical Densitometry. 2005;8(4):454-60. Not eligible outcomes. [pmid: 16311431].
1524 Shahar E, Redline S, Young T, et al. Hormone replacement therapy and sleep-disordered breathing.[see comment]. American Journal of Respiratory & Critical Care Medicine. 05. 1. 2003;167(9):1186-92. Not eligible outcomes. [pmid: 12531779].
1525 Shamliyan T, Wyman J, Bliss DZ, et al. Prevention of urinary and fecal incontinence in adults. Evid Rep Technol Assess (Full Rep). 12. 2007;(161):1-379. Not eligible outcomes.
1526 Shardell M, Hicks GE, Miller RR, et al. Association of low vitamin D levels with the frailty syndrome in men and women. J Gerontol A Biol Sci Med Sci. 01. 2009;64(1):69-75. Not eligible outcomes. [pmid: 19164273].
1527 Sharkey JR. Variation in nutritional risk among Mexican American and non-Mexican American homebound elders who receive home-delivered meals. J Nutr Elder. 2004;23(4):1-19. Not eligible target population. [pmid: 15149938].
1528 Sharp DS, Burchfiel CM, Curb JD, et al. The synergy of low lung function and low body mass index predicting all-cause mortality among older Japanese-American men. J Am Geriatr Soc. 12. 1997;45(12):1464-71. Not eligible outcomes. [pmid: 9400556].
1529 Shea D. Use of the electronic record in the home-based primary care programs of the Department of Veterans Affairs Health Care System. Home Healthc Nurse. 05. 2007;25(5):323-6. Not eligible outcomes. [pmid: 17495562].
1530 Shearer J. Improving oral medication management in home health agencies. Home Healthc Nurse. 03. 2009;27(3):184-92. Not eligible outcomes. [pmid: 19279485].
1531 Sheehan TJ, DeChello LM, Garcia R, et al. Measuring disability: application of the Rasch model to activities of daily living (ADL/IADL). J Outcome Meas. 2000;4(3):681-705. Not eligible outcomes. [pmid: 11253903].
1532 Sheffield KM, Peek MK, Sheffield KM, et al. Neighborhood context and cognitive decline in older Mexican Americans: results from the Hispanic Established Populations for Epidemiologic Studies of the Elderly. American Journal of Epidemiology. 05. 1. 2009;169(9):1092-101. Not eligible outcomes. [pmid: 19270047].
1533 Shemesh AA, Kohn R, Radomislensky I, et al. Emotional distress and other health-related dimensions among elderly survivors of the Shoa living in the community. Israel Journal of Psychiatry & Related Sciences. 2008;45(4):230-8. Not eligible outcomes. [pmid: 19439828].
1534 Sherman FT. Medication nonadherence: a national epidemic among America’s seniors. Geriatrics. 04. 2007;62(4):5-6. Not eligible outcomes. [pmid: 17408313].
1535 Sherman SE, D’Agostino RB, Cobb JL, et al. Does exercise reduce mortality rates in the elderly? Experience from the Framingham Heart Study. American Heart Journal. 11. 1994;128(5):965-72. Not eligible outcomes. [pmid: 7942491].
1536 Sherman SE, D’Agostino RB, Cobb JL, et al. Physical activity and mortality in women in the Framingham Heart Study. American Heart Journal. 11. 1994;128(5):879-84. Not eligible outcomes. [pmid: 7942478].
1537 Sherrill DL, Lebowitz MD, Knudson RJ, et al. Longitudinal methods for describing the relationship between pulmonary function, respiratory symptoms and smoking in elderly subjects: the Tucson Study.[see comment]. European Respiratory Journal. 03. 1993;6(3):342-8. Not eligible outcomes. [pmid: 8472823].
1538 Shih JH, Louis TA. Assessing gamma frailty models for clustered failure time data. Lifetime Data Anal. 1995;1(2):205-20. Not eligible outcomes. [pmid: 9385102].
1539 Shin KR, Jung D, Jo I, et al. Depression among community-dwelling older adults in Korea: a prediction model of depression. Archives of Psychiatric Nursing. 02. 2009;23(1):50-7. Not eligible outcomes. [pmid: 19216988].
1540 Ship JA, Beck JD. Ten-year longitudinal study of periodontal attachment loss in healthy adults. Oral Surgery Oral Medicine Oral Pathology Oral Radiology & Endodontics. 03. 1996;81(3):281-90. Not eligible exposure.
1541 Shippy RA, Karpiak SE. The aging HIV/AIDS population: fragile social networks. Aging & Mental Health. 05. 2005;9(3):246-54. Not eligible outcomes. [pmid: 16019278].
1542 Short PF, Vasey JJ, Belue R. Work disability associated with cancer survivorship and other chronic conditions. Psychooncology. 01. 2008;17(1):91-7. Not eligible outcomes. [pmid: 17429835].
1543 Shum NC, Hui WW, Chu FC, et al. Prevalence of malnutrition and risk factors in geriatric patients of a convalescent and rehabilitation hospital. Hong Kong Med J. 08. 2005;11(4):234-42. Not eligible target population. [pmid: 16085939].
1544 Shumaker SA, Wyman JF, Uebersax JS, et al. Health-related quality of life measures for women with urinary incontinence: the Incontinence Impact Questionnaire and the Urogenital Distress Inventory. Continence Program in Women (CPW) Research Group. Qual Life Res. 10. 1994;3(5):291-306. Not eligible outcomes. [pmid: 7841963].
1545 Siddiqui A, Pena Sahdala hn, Nazario HE, et al. Obesity is associated with an increased prevalence of advanced adenomatous colon polyps in a male veteran population. Digestive Diseases & Sciences. 07. 2009;54(7):1560-4. Not eligible outcomes. [pmid: 19399615].
1546 Siem CA, Wipke-Tevis DD, Rantz MJ, et al. Skin assessment and pressure ulcer care in hospital-based skilled nursing facilities. Ostomy Wound Manage. 06. 2003;49(6):42-4. 6. 8 passim, contd. Not eligible target population. [pmid: 12874483].
1547 Sigurdson AJ, Hauptmann M, Alexander BH, et al. DNA damage among thyroid cancer and multiple cancer cases, controls, and long-lived individuals. Mutation Research. 10. 3. 2005;586(2):173-88. Not eligible outcomes. [pmid: 16099702].
1548 Silverberg SJ, Shane E, Dempster DW, et al. The effects of vitamin D insufficiency in patients with primary hyperparathyroidism. American Journal of Medicine. 12. 1999;107(6):561-7. Not eligible outcomes. [pmid: 10625024].
1549 Simon SE, Bergmann MA, Jones RN, et al. Reliability of a structured assessment for nonclinicians to detect delirium among new admissions to postacute care. J Am Med Dir Assoc. 09. 2006;7(7):412-5. Not eligible target population. [pmid: 16979083].
1550 Sims RV, McGwin G Jr, Allman RM, et al. Exploratory study of incident vehicle crashes among older drivers. J Gerontol A Biol Sci Med Sci. 01. 2000;55(1):M22-7. Not eligible outcomes. [pmid: 10719769].
1551 Sivakova D, Lajdova A, Basistova Z, et al. ACE insertion/deletion polymorphism and its relationships to the components of metabolic syndrome in elderly Slovaks. Anthropologischer Anzeiger. 03. 2009;67(1):1-11. Not eligible outcomes.
1552 Skarupski KA, de Leon CF, McCann JJ, et al. Is lower cognitive function in one spouse associated with depressive symptoms in the other spouse?. Aging & Mental Health. 11. 2006;10(6):621-30. Not eligible outcomes. [pmid: 17050091].
1553 Skarupski KA, Mendes de Leon CF, Bienias JL, et al. Black-white differences in depressive symptoms among older adults over time. J Gerontol B Psychol Sci Soc Sci. 05. 2005;60(3):P136-42. Not eligible outcomes. [pmid: 15860783].
1554 Sloan FA, Ruiz D Jr, Platt A. Changes in functional status among persons over age sixty-five undergoing total knee arthroplasty. Med Care. 07. 2009;47(7):742-8. Not eligible outcomes. [pmid: 19536027].
1555 Slovacek L, Slovackova B, Slanska I, et al. Cancer and depression: a prospective study. Neoplasma. 2009;56(3):187-93. Not eligible outcomes. [pmid: 19309220].
1556 Sluka KA, Turk DC. Invited commentary. Phys Ther. 05. 2009;89(5):470-2. author reply 2–3. Not eligible outcomes. [pmid: 19411242].
1557 Smith AK, Maloney EM, Falkenberg VR, et al. An angiotensin-1 converting enzyme polymorphism is associated with allostatic load mediated by C-reactive protein, interleukin-6 and cortisol. Psychoneuroendocrinology. 05. 2009;34(4):597-606. Not eligible target population. [pmid: 19081678].
1558 Smith SL, Colenda CC. Mental health and health care utilization in geriatric primary care patients. International Journal of Psychiatry in Medicine. 1997;27(1):23-32. Not eligible outcomes. [pmid: 9565711].
1559 Smola S, Justice AC, Wagner J, et al. Veterans aging cohort three-site study (VACS 3): overview and description. Journal of Clinical Epidemiology. 12. 2001;54(Suppl 1):S61-76. Not eligible outcomes. [pmid: 11750212].
1560 Smoliner C, Norman K, Scheufele R, et al. Effects of food fortification on nutritional and functional status in frail elderly nursing home residents at risk of malnutrition. Nutrition. 11–12. 2008;24(11–12):1139-44. Not eligible target population. [pmid: 18789649].
1561 Snowdon DA. Aging and Alzheimer’s disease: lessons from the Nun Study.[see comment]. Gerontologist. 04. 1997;37(2):150-6. Not eligible outcomes. [pmid: 9127971].
1562 Soejono CH. The impact of ‘comprehensive geriatric assessment (CGA)’ implementation on the effectiveness and cost (CEA) of healthcare in an acute geriatric ward. Acta Medica Indonesiana. 01. 2008;40(1):3-10. Not eligible target population. [pmid: 19054877].
1563 Sokol KC, Knudsen JF, Li MM. Polypharmacy in older oncology patients and the need for an interdisciplinary approach to side-effect management. J Clin Pharm Ther. 04. 2007;32(2):169-75. Not eligible exposure. [pmid: 17381667].
1564 Solberg OG, Dahl M, Mowinckel P, et al. Derivation and validation of a simple risk score for predicting 1-year mortality in stroke. J Neurol. 10. 2007;254(10):1376-83. Not eligible outcomes. [pmid: 17934885].
1565 Solfrizzi V, Capurso C, D’Introno A, et al. Change of diagnoses in probable and possible mild cognitive impairment: the Italian Longitudinal Study on Aging. J Am Geriatr Soc. 09. 2007;55(9):1480-2. Comment. [pmid: 17767698].
1566 Solomon DH, Avorn J, Katz JN, et al. Compliance with osteoporosis medications. Arch Intern Med. 11. 14. 2005;165(20):2414-9. Not eligible outcomes. [pmid: 16287772].
1567 Song HJ, Shim KN, Yoon SJ, et al. The prevalence and clinical characteristics of reflux esophagitis in koreans and its possible relation to metabolic syndrome. Journal of Korean medical science. 04. 2009;24(2):197-202. Not eligible outcomes. [pmid: 19399258].
1568 Song J, Chang HJ, Tirodkar M, et al. Racial/ethnic differences in activities of daily living disability in older adults with arthritis: a longitudinal study. Arthritis Rheum. 08. 15. 2007;57(6):1058-66. Not eligible population. [pmid: 17665484].
1569 Song K, Fendrick AM, Ladabaum U. Fecal DNA testing compared with conventional colorectal cancer screening methods: a decision analysis. Gastroenterology. 05. 2004;126(5):1270-9. Not eligible outcomes. [pmid: 15131787].
1570 Sonohara K, Kozaki K, Akishita M, et al. White matter lesions as a feature of cognitive impairment, low vitality and other symptoms of geriatric syndrome in the elderly. Geriatrics & gerontology international. 06. 2008;8(2):93-100. Not eligible outcomes. [pmid: 18713161].
1571 SoRelle R. Death rate higher in elderly with low cholesterol. Circulation. 08. 14. 2001;104(7):E9011-3. Not eligible outcomes.
1572 Sorkin JD, Andres R, Muller DC, et al. Cholesterol as a risk factor for coronary heart disease in elderly men. The Baltimore Longitudinal Study of Aging. Annals of Epidemiology. 01–03. 1992;2(1–2):59-67. Not eligible exposure. [pmid: 1342266].
1573 Sorrell J. Struggling to do the right thing: stories from people living with Alzheimer’s disease. J Psychosoc Nurs Ment Health Serv. 07. 2005;43(7):13-6. Not eligible outcomes. [pmid: 16116922].
1574 Spada RS, Toscano G, Cosentino FI, et al. Low total cholesterol predicts mortality in the nondemented oldest old. Arch Gerontol Geriatr. 2007;44(Suppl 1):381-4. Not eligible outcomes. [pmid: 17317479].
1575 Sparrow D, O’Connor GT, Rosner B, et al. Predictors of longitudinal change in methacholine airway responsiveness among middle-aged and older men: the Normative Aging Study. American Journal of Respiratory & Critical Care Medicine. 02. 1994;149(2 Pt 1):376-81. Not eligible outcomes. [pmid: 8306033].
1576 Sparrow D, O’Connor GT, Young JB, et al. Relationship of urinary serotonin excretion to cigarette smoking and respiratory symptoms. The Normative Aging Study.[see comment]. Chest. 04. 1992;101(4):976-80. Not eligible outcomes. [pmid: 1372851].
1577 Srikanth VK, Anderson JF, Donnan GA, et al. Progressive dementia after first-ever stroke: a community-based follow-up study.[see comment]. Neurology. 09. 14. 2004;63(5):785-92. Not eligible exposure. [pmid: 15365124].
1578 Srikanth VK, Fryer JL, Zhai G, et al. A meta-analysis of sex differences prevalence, incidence and severity of osteoarthritis. Osteoarthritis Cartilage. 09. 2005;13(9):769-81. Not eligible outcomes. [pmid: 15978850].
1579 Stamatiadis N, Deacon JA. Trends in highway safety: effects of an aging population on accident propensity. Accident Analysis & Prevention. 08. 1995;27(4):443-59. Not eligible outcomes. [pmid: 7546059].
1580 Stamler J, Dyer AR, Shekelle RB, et al. Relationship of baseline major risk factors to coronary and all-cause mortality, and to longevity: findings from long-term follow-up of Chicago cohorts. Cardiology. 1993;82(2–3):191-222. Not eligible exposure. [pmid: 8324780].
1581 Staplin L, Gish KW, Wagner EK. MaryPODS revisited: updated crash analysis and implications for screening program implementation. J Safety Res. 2003;34(4):389-97. Not eligible outcomes. [pmid: 14636661].
1582 Starr JM, McGurn B, Whiteman M, et al. Life long changes in cognitive ability are associated with prescribed medications in old age. Int J Geriatr Psychiatry. 04. 2004;19(4):327-32. Not eligible outcomes. [pmid: 15065225].
1583 Stefanacci RG, Lester PE, Kohen I. Nursing home resident smoking policies. Director. Summer. 2008;16(3):37-9. 41. 3. Not eligible target population. [pmid: 19343890].
1584 Steffens DC, McQuoid DR, Potter GG. Outcomes of older cognitively impaired individuals with current and past depression in the NCODE study. J Geriatr Psychiatry Neurol. 03. 2009;22(1):52-61. Not eligible outcomes. [pmid: 19196631].
1585 Steiber AL, Handu DJ, Cataline DR, et al. The impact of nutrition intervention on a reliable morbidity and mortality indicator: the hemodialysis-prognostic nutrition index. Journal of Renal Nutrition. 07. 2003;13(3):186-90. Not eligible target population. [pmid: 12874742].
1586 Stein BE. Adult vaccinations: protecting your patients from avoidable illness. Geriatrics. 09. 9. 1993;48(9):46-52. 5. Not eligible outcomes. [pmid: 8365662].
1587 Stein PD, Beemath A, Meyers FA, et al. Pulmonary embolism as a cause of death in patients who died with cancer. Am J Med. 02. 2006;119(2):163-5. Not eligible outcomes. [pmid: 16443419].
1588 Steinman MA, Maaravi Y, Walter LC, et al. Evolution of medication use in Jerusalem elders: Results from the Jerusalem Longitudinal Study. Drugs Aging. 2007;24(2):133-45. Not eligible outcomes. [pmid: 17313201].
1589 Steinman MA, Rosenthal GE, Landefeld CS, et al. Conflicts and concordance between measures of medication prescribing quality. Med Care. 01. 2007;45(1):95-9. Not eligible outcomes. [pmid: 17279026].
1590 Stellato RK, Feldman HA, Hamdy O, et al. Testosterone, sex hormone-binding globulin, and the development of type 2 diabetes in middle-aged men: prospective results from the Massachusetts male aging study. Diabetes Care. 04. 2000;23(4):490-4. Not eligible outcomes. [pmid: 10857940].
1591 Sternfeld B, Wang H, Quesenberry CP Jr, et al. Physical activity and changes in weight and waist circumference in midlife women: findings from the Study of Women’s Health Across the Nation. Am J Epidemiol. 11. 1. 2004;160(9):912-22. Not eligible outcomes. [pmid: 15496544].
1592 Stewart R, White LR, Xue QL, et al. Twenty-six-year change in total cholesterol levels and incident dementia: the Honolulu-Asia Aging Study. Arch Neurol. 01. 2007;64(1):103-7. Not eligible outcomes. [pmid: 17210816].
1593 Stolk RP, Rosmalen JG, Postma DS, et al. Universal risk factors for multifactorial diseases: LifeLines: a three-generation population-based study. Eur J Epidemiol. 2008;23(1):67-74. Not eligible review. [pmid: 18075776].
1594 Stookey JD, Pieper CF, Cohen HJ. Is the prevalence of dehydration among community-dwelling older adults really low? Informing current debate over the fluid recommendation for adults aged 70+years. Public Health Nutr. 12. 2005;8(8):1275-85. Not eligible outcomes. [pmid: 16372923].
1595 Stranges S, Dorn JM, Shipley MJ, et al. Correlates of short and long sleep duration: a cross-cultural comparison between the United Kingdom and the United States: the Whitehall II Study and the Western New York Health Study.[see comment]. American Journal of Epidemiology. 12. 15. 2008;168(12):1353-64. Not eligible outcomes. [pmid: 18945686].
1596 Strine TW, Hootman JM, Chapman DP, et al. Health-related quality of life, health risk behaviors, and disability among adults with pain-related activity difficulty. Am J Public Health. 11. 2005;95(11):2042-8. Not eligible outcomes. [pmid: 16195508].
1597 Strozyk D, Blennow K, White LR, et al. CSF Abeta 42 levels correlate with amyloid-neuropathology in a population-based autopsy study. Neurology. 02. 25. 2003;60(4):652-6. Not eligible outcomes. [pmid: 12601108].
1598 Sturman MT, de Leon CF, Bienias JL, et al. Body mass index and cognitive decline in a biracial community population. Neurology. 01. 29. 2008;70(5):360-7. Not eligible outcomes. [pmid: 17881716].
1599 Subramanian S, Surani S. Sleep disorders in the elderly. Geriatrics. 12. 2007;62(12):10-32. Not eligible outcomes. [pmid: 18069880].
1600 Sullivan DH. Risk factors for early hospital readmission in a select population of geriatric rehabilitation patients: the significance of nutritional status. J Am Geriatr Soc. 08. 1992;40(8):792-8. Not eligible target population. [pmid: 1634723].
1601 Sullivan G, Craske MG, Sherbourne C, et al. Design of the Coordinated Anxiety Learning and Management (CALM) study: innovations in collaborative care for anxiety disorders. Gen Hosp Psychiatry. 09–10. 2007;29(5):379-87. Not eligible outcomes. [pmid: 17888803].
1602 Sun X, Zhang S, Wang N, et al. Utility assessment among patients of primary angle closure/glaucoma in China: a preliminary study. British Journal of Ophthalmology. 07. 2009;93(7):871-4. Not eligible outcomes. [pmid: 19208679].
1603 Sung HY, Wang L, Jin S, et al. Economic burden of smoking in China, 2000. Tob Control. 06. 2006;15(Suppl 1):i5-11. Not eligible outcomes. [pmid: 16723677].
1604 Susser E, Terry MB, Matte T. The birth cohorts grow up: new opportunities for epidemiology. Paediatric and Perinatal Epidemiology. 04. 2000;14(2):98-100. Not eligible outcomes. [pmid: 10791650].
1605 Sussman D, Garely A. Treatment of overactive bladder with once-daily extended-release tolterodine or oxybutynin: the antimuscarinic clinical effectiveness trial (ACET). Curr Med Res Opin. 2002;18(4):177-84. Not eligible outcomes. [pmid: 12201616].
1606 Sutaria N, Elder AT, Shaw TR. Long term outcome of percutaneous mitral balloon valvotomy in patients aged 70 and over. Heart. 04. 2000;83(4):433-8. Not eligible outcomes. [pmid: 10722546].
1607 Syddall H, Cooper C, Martin F, et al. Is grip strength a useful single marker of frailty. Age Ageing. 11. 2003;32(6):650-6. Not eligible exposure. [pmid: 14600007].
1608 Szklo-Coxe M, Young T, Finn L, et al. Depression: relationships to sleep paralysis and other sleep disturbances in a community sample. Journal of Sleep Research. 09. 2007;16(3):297-312. Not eligible outcomes. [pmid: 17716279].
1609 Szwast SJ, Hendrie HC, Lane KA, et al. Association of statin use with cognitive decline in elderly African Americans. Neurology. 11. 6. 2007;69(19):1873-80. Not eligible exposure. [pmid: 17984456].
1610 Taaffe DR, Harris TB, Ferrucci L, et al. Cross-sectional and prospective relationships of interleukin-6 and C-reactive protein with physical performance in elderly persons: MacArthur studies of successful aging. J Gerontol A Biol Sci Med Sci. 12. 2000;55(12):M709-15. Not eligible outcome. [pmid: 11129392].
1611 Tager IB, Haight T, Sternfeld B, et al. Effects of physical activity and body composition on functional limitation in the elderly: application of the marginal structural model. Epidemiology. 07. 2004;15(4):479-93. Not eligible outcomes. [pmid: 15232410].
1612 Talbot LA, Morrell CH, Fleg JL, et al. Changes in leisure time physical activity and risk of all-cause mortality in men and women: the Baltimore Longitudinal Study of Aging. Prev Med. 08–09. 2007;45(2–3):169-76. Not eligible exposure. [pmid: 17631385].
1613 Talbott EO, Findlay RC, Kuller LH, et al. Noise-induced hearing loss: a possible marker for high blood pressure in older noise-exposed populations. Journal of Occupational Medicine. 08. 1990;32(8):690-7. Not eligible exposure. [pmid: 2401923].
1614 Talcott JA, Manola J, Clark JA, et al. Time course and predictors of symptoms after primary prostate cancer therapy. Journal of Clinical Oncology. 11. 1. 2003;21(21):3979-86. Not eligible outcomes. [pmid: 14581420].
1615 Tavris DR, Rock PJ, Miesbauer K, et al. Depression in the elderly. Wis Med J. 04. 1997;96(4):52-3. Not eligible outcomes. [pmid: 9128436].
1616 Taylor A, Jacques PF, Chylack LT Jr, et al. Long-term intake of vitamins and carotenoids and odds of early age-related cortical and posterior subcapsular lens opacities. American Journal of Clinical Nutrition. 03. 2002;75(3):540-9. Not eligible outcomes. [pmid: 11864861].
1617 Taylor BC, Schreiner PJ, Stone KL, et al. Long-term prediction of incident hip fracture risk in elderly white women: study of osteoporotic fractures. J Am Geriatr Soc. 09. 2004;52(9):1479-86. Not eligible outcomes. [pmid: 15341549].
1618 Taylor DH Jr, Schenkman M, Zhou J, et al. The relative effect of Alzheimer’s disease and related dementias, disability, and comorbidities on cost of care for elderly persons. J Gerontol B Psychol Sci Soc Sci. 09. 2001;56(5):S285-93. Not eligible population. [pmid: 11522810].
1619 Teno JM, Harrell FE Jr, Knaus W, et al. Prediction of survival for older hospitalized patients: the HELP survival model. Hospitalized Elderly Longitudinal Project. J Am Geriatr Soc. 05. 2000;48(5 Suppl):S16-24. Not eligible outcomes. [pmid: 10809452].
1620 Teresi J. Overview of methodological issues in the study of chronic care populations. Alzheimer Disease & Associated Disorders. 1994;8(Suppl 1):S247-73. Review. [pmid: 8068268].
1621 Terpenning MS, Taylor GW, Lopatin DE, et al. Aspiration pneumonia: dental and oral risk factors in an older veteran population. J Am Geriatr Soc. 05. 2001;49(5):557-63. Not elgible target population. [pmid: 11380747].
1622 Terry DF, Evans JC, Pencina MJ, et al. Characteristics of Framingham offspring participants with long-lived parents.[see comment]. Archives of Internal Medicine. 03. 12. 2007;167(5):438-44. Not eligible outcomes. [pmid: 17353490].
1623 Thal LJ, Carta A, Doody R, et al. Prevention protocols for Alzheimer disease. Position paper from the International Working Group on Harmonization of Dementia Drug Guidelines. Alzheimer Dis Assoc Disord. 1997;11(Suppl 3):46-9. Not eligible outcomes. [pmid: 9305516].
1624 Thamer M, Chan JK, Ray NF, et al. Drug use concomitant with cyclosporine immunosuppressive therapy for 3 years after renal transplantation. Am J Kidney Dis. 02. 1998;31(2):283-92. Not eligible outcomes. [pmid: 9469499].
1625 Thapa PB, Brockman KG, Gideon P, et al. Injurious falls in nonambulatory nursing home residents: a comparative study of circumstances, incidence, and risk factors. J Am Geriatr Soc. 03. 1996;44(3):273-8. Not eligible target population. [pmid: 8600195].
1626 Thein M, Ershler WB, Artz AS, et al. Diminished quality of life and physical function in community-dwelling elderly with anemia. Medicine. 03. 2009;88(2):107-14. Not eligible outcomes. [pmid: 19282701].
1627 Theodos P. Fall prevention in frail elderly nursing home residents: a challenge to case management: part I. Lippincotts Case Manag. 11–12. 2003;8(6):246-51. Not eligible target population. [pmid: 14646782].
1628 Thobaben M. Mistreatment of elders by family members. Home Care Provid. 08. 2001;6(4):112-3. Not eligible outcomes. [pmid: 11496259].
1629 Thom D. Variation in estimates of urinary incontinence prevalence in the community: effects of differences in definition, population characteristics, and study type. Journal of the American Geriatrics Society. 04. 1998;46(4):473-80. Not eligible outcomes. [pmid: 9560071].
1630 Thomas D. Why do estimates of the acute and chronic effects of air pollution on mortality differ. J Toxicol Environ Health A. 07. 9–23. 2005;68(13–14):1167-74. Not eligible outcomes. [pmid: 16024495].
1631 Thomas DR, Kamel H, Azharrudin M, et al. The relationship of functional status, nutritional assessment, and severity of illness to in-hospital mortality. J Nutr Health Aging. 2005;9(3):169-75. Not eligible target population. [pmid: 15864397].
1632 Thomas DR, Verdery RB, Gardner L, et al. A prospective study of outcome from protein-energy malnutrition in nursing home residents. Jpen: Journal of Parenteral & Enteral Nutrition. 07–08. 1991;15(4):400-4. [pmid: 1910102].
1633 Thomas DR, Zdrowski CD, Wilson MM, et al. Malnutrition in subacute care. Am J Clin Nutr. 02. 2002;75(2):308-13. Not eligible target population. [pmid: 11815323].
1634 Thompson DL. Geriatric incontinence: the long-term care challenge. Urologic Nursing. 2004 quiz 314. 08. 2004;24(4):305-13. Not eligible target population. [pmid: 15446379].
1635 Thompson GW, Kreisel PS. The impact of the demographics of aging and the edentulous condition on dental care services. Journal of Prosthetic Dentistry. 01. 1998;79(1):56-9. No eligible outcomes. [pmid: 9474542].
1636 Thomson WM, Chalmers JM, Spencer AJ, et al. Medication and dry mouth: findings from a cohort study of older people. J Public Health Dent. Winter. 2000;60(1):12-20. Not eligible outcomes. [pmid: 10734611].
1637 Thorpe RJ Jr, Kasper JD, Szanton SL, et al. Relationship of race and poverty to lower extremity function and decline: findings from the Women’s Health and Aging Study. Social science & medicine. 02. 2008;66(4):811-21. Not eligible outcomes. [pmid: 18164113].
1638 Thorpe RJ Jr, Weiss C, Xue QL, et al. Transitions among disability levels or death in African American and white older women. J Gerontol A Biol Sci Med Sci. 06. 2009;64(6):670-4. Not eligible outcomes. [pmid: 19228790].
1639 Tinetti ME, Baker DI, McAvay G, et al. A multifactorial intervention to reduce the risk of falling among elderly people living in the community. N Engl J Med. 09. 29. 1994;331(13):821-7. Not eligible outcomes. [pmid: 8078528].
1640 Tinetti ME, McAvay GJ, Fried TR, et al. Development of a tool for eliciting patient priority from among competing cardiovascular disease, medication-symptoms, and fall injury outcomes. J Am Geriatr Soc. 04. 2008;56(4):730-6. Not eligible outcomes. [pmid: 18266842].
1641 Torres OH, Munoz J, Ruiz D, et al. Outcome predictors of pneumonia in elderly patients: importance of functional assessment. J Am Geriatr Soc. 10. 2004;52(10):1603-9. Not eligible outcomes. [pmid: 15450034].
1642 Tosteson AN, Gottlieb DJ, Radley DC, et al. Excess mortality following hip fracture: the role of underlying health status. Osteoporos Int. 11. 2007;18(11):1463-72. Not eligible outcomes. [pmid: 17726622].
1643 Touger M, Gennis P, Nathanson N, et al. Validity of a decision rule to reduce cervical spine radiography in elderly patients with blunt trauma. Ann Emerg Med. 09. 2002;40(3):287-93. Not eligible outcomes. [pmid: 12192352].
1644 Townsend MK, Curhan GC, Resnick NM, et al. Postmenopausal hormone therapy and incident urinary incontinence in middle-aged women. American Journal of Obstetrics & Gynecology. 01. 2009;200(1):86.e1-5. Not eligible outcomes. [pmid: 19019333].
1645 Townsend MK, Danforth KN, Rosner B, et al. Body mass index, weight gain, and incident urinary incontinence in middle-aged women. Obstetrics & Gynecology. 08. 2007;110(2 Pt 1):346-53. Not eligible outcomes. [pmid: 17666610].
1646 Tracy JI, Lippincott C, Mahmood T, et al. Are depression and cognitive performance related in temporal lobe epilepsy. Epilepsia. 12. 2007;48(12):2327-35. Not eligible outcomes. [pmid: 17697111].
1647 Travis SS, Buchanan RJ, Wang S, et al. Analyses of nursing home residents with diabetes at admission. J Am Med Dir Assoc. 09–10. 2004;5(5):320-7. Not eligible target population. [pmid: 15357889].
1648 Travison TG, Araujo AB, Kupelian V, et al. The relative contributions of aging, health, and lifestyle factors to serum testosterone decline in men. Journal of Clinical Endocrinology & Metabolism. 02. 2007;92(2):549-55. Not eligible exposure. [pmid: 17148559].
1649 Treharne GJ, Douglas KM, Iwaszko J, et al. Polypharmacy among people with rheumatoid arthritis: the role of age, disease duration and comorbidity. Musculoskeletal Care. 12. 2007;5(4):175-90. Not eligible outcomes. [pmid: 17623274].
1650 Troncoso JC, Zonderman AB, Resnick SM, et al. Effect of infarcts on dementia in the Baltimore longitudinal study of aging. Annals of Neurology. 08. 2008;64(2):168-76. Not eligible exposure. [pmid: 18496870].
1651 Trygstad TK, Christensen D, Garmise J, et al. Pharmacist response to alerts generated from Medicaid pharmacy claims in a long-term care setting: results from the North Carolina polypharmacy initiative. J Manag Care Pharm. 09. 2005;11(7):575-83. Not eligible target population. [pmid: 16137215].
1652 Tucker D, Dirico L. Managing costly Medicare patients in the hospital. Geriatr Nurs. 09–10. 2003;24(5):294-7. Not eligible outcomes. [pmid: 14571245].
1653 Tucker KL, Hallfrisch J, Qiao N, et al. The combination of high fruit and vegetable and low saturated fat intakes is more protective against mortality in aging men than is either alone: the Baltimore Longitudinal Study of Aging. Journal of Nutrition. 03. 2005;135(3):556-61. Not eligible exposure. [pmid: 15735093].
1654 Tullai-McGuinness S, Madigan EA, Fortinsky RH. Validity testing the Outcomes and Assessment Information Set (OASIS). Home Health Care Serv Q. 2009;28(1):45-57. Not eligible outcomes. [pmid: 19266370].
1655 Tulner LR, Frankfort SV, Gijsen GJ, et al. Drug-drug interactions in a geriatric outpatient cohort: prevalence and relevance. Drugs Aging. 2008;25(4):343-55. Not eligible outcomes. [pmid: 18361544].
1656 Tumolo J. Caregivers who hurt. The tragedy of elder abuse. Adv Nurse Pract. 10. 2000;8(10):63-5. Not eligible outcomes. [pmid: 11761541].
1657 Tune L. Assessing psychiatric illness in geriatric patients. Clinical cornerstone. 2001;3(3):23-36. Not eligible outcomes. [pmid: 11351784].
1658 Turner-Stokes L, Frank AO. Urinary incontinence among patients with arthritis--a neglected disability. J R Soc Med. 07. 1992;85(7):389-93. Not eligible outcomes. [pmid: 1629846].
1659 Turvey CL, Schultz SK, Arndt S, et al. Caregiver report of hallucinations and paranoid delusions in elders aged 70 or older. International Psychogeriatrics. 06. 2001;13(2):241-9. Not eligible outcomes. [pmid: 11495398].
1660 Ukoli FA, Lynch BS, Adams-Campbell LL. Radical prostatectomy and quality of life among African Americans. Ethnicity & disease. 2006;16(4):988-93. Not eligible outcomes. [pmid: 17061757].
1661 Ulmer H, Kelleher C, Diem G, et al. Why Eve is not Adam: prospective follow-up in 149650 women and men of cholesterol and other risk factors related to cardiovascular and all-cause mortality. J Womens Health (Larchmt). 01–02. 2004;13(1):41-53. Not eligible outcomes. [pmid: 15006277].
1662 Umberson D, Williams K, Umberson D, et al. Marital quality, health, and aging: gender equity?. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. 10. 2005;60(Spec No 2):109-13. Not eligible outcomes.
1663 Ungar A, Mussi C, Del Rosso A, et al. Diagnosis and characteristics of syncope in older patients referred to geriatric departments. Journal of the American Geriatrics Society. 10. 2006;54(10):1531-6. Not eligible outcomes. [pmid: 17038070].
1664 Unruh ML, Sanders MH, Redline S, et al. Subjective and objective sleep quality in patients on conventional thrice-weekly hemodialysis: comparison with matched controls from the sleep heart health study. American Journal of Kidney Diseases. 08. 2008;52(2):305-13. Not eligible outcomes. [pmid: 18617308].
1665 Valcour V, Shikuma C, Shiramizu B, et al. Higher frequency of dementia in older HIV-1 individuals: the Hawaii Aging with HIV-1 Cohort. Neurology. 09. 14. 2004;63(5):822-7. Not eligible outcomes. [pmid: 15365130].
1666 Valcour V, Shikuma C, Shiramizu B, et al. Age, apolipoprotein E4, and the risk of HIV dementia: the Hawaii Aging with HIV Cohort. Journal of Neuroimmunology. 12. 2004;157(1–2):197-202. Not eligible outcomes. [pmid: 15579298].
1667 Valenti G, Denti L, Maggio M, et al. Effect of DHEAS on skeletal muscle over the life span: the InCHIANTI study. J Gerontol A Biol Sci Med Sci. 05. 2004;59(5):466-72. Not eligible outcomes. [pmid: 15123757].
1668 Valete-Rosalino CM, Rozenfeld S. Auditory screening in the elderly: comparison between self-report and audiometry. Braz J Otorhinolaryngol. 03–04. 2005;71(2):193-200. Not eligible outcomes. [pmid: 16446917].
1669 Valk M, Post MW, Cools HJ, et al. Measuring disability in nursing home residents: validity and reliability of a newly developed instrument. J Gerontol B Psychol Sci Soc Sci. 05. 2001;56(3):P187-91. Not eligible target population. [pmid: 11316837].
1670 van den Kommer TN, Dik MG, Comijs HC, et al. Total cholesterol and oxysterols: early markers for cognitive decline in elderly?[see comment]. Neurobiology of aging. 04. 2009;30(4):534-45. Not eligible outcomes. [pmid: 17888546].
1671 van der Steen JT, Mehr DR, Kruse RL, et al. Dementia, lower respiratory tract infection, and long-term mortality. J Am Med Dir Assoc. 07. 2007;8(6):396-403. Not eligible outcomes. [pmid: 17619038].
1672 van der Steen JT, Ooms ME, van der Wal G, et al. Withholding or starting antibiotic treatment in patients with dementia and pneumonia: prediction of mortality with physicians’ judgment of illness severity and with specific prognostic models. Med Decis Making. 03–04. 2005;25(2):210-21. Not eligible outcomes. [pmid: 15800305].
1673 van Hout HP, Nijpels G, van Marwijk HW, et al. Design and pilot results of a single blind randomized controlled trial of systematic demand-led home visits by nurses to frail elderly persons in primary care [ISRCTN05358495]. BMC Geriatr. 2005;5:11. Not eligible outcomes. [pmid: 16150147].
1674 Van Nostrand JF, Miller B, Furner SE. Selected issues in long-term care: profile of cognitive disability of nursing home residents and the use of informal and formal care by elderly in the community. Vital Health Stat. 01. 1993;3(27):143-85. Not eligible target population.
1675 VandenLangenberg GM, Mares-Perlman JA, Klein R, et al. Associations between antioxidant and zinc intake and the 5-year incidence of early age-related maculopathy in the Beaver Dam Eye Study. American Journal of Epidemiology. 07. 15. 1998;148(2):204-14. Not eligible outcomes. [pmid: 9676703].
1676 Varadhan R, Chaves PH, Lipsitz LA, et al. Frailty and impaired cardiac autonomic control: new insights from principal components aggregation of traditional heart rate variability indices. J Gerontol A Biol Sci Med Sci. 06. 2009;64(6):682-7. Not eligible exposure. [pmid: 19223607].
1677 Varadhan R, Walston J, Cappola AR, et al. Higher levels and blunted diurnal variation of cortisol in frail older women. J Gerontol A Biol Sci Med Sci. 02. 2008;63(2):190-5. Not eligible outcomes. [pmid: 18314456].
1678 Varma RN. Risk for drug-induced malnutrition is unchecked in elderly patients in nursing homes. J Am Diet Assoc. 02. 1994;94(2):192-4. Not eligible target population. [pmid: 8300997].
1679 Vasan RS, Larson MG, Benjamin EJ, et al. Congestive heart failure in subjects with normal versus reduced left ventricular ejection fraction: prevalence and mortality in a population-based cohort. J Am Coll Cardiol. 06. 1999;33(7):1948-55. Not eligible outcomes. [pmid: 10362198].
1680 Vasunilashorn S, Coppin AK, Patel KV, et al. Use of the Short Physical Performance Battery Score to predict loss of ability to walk 400 meters: analysis from the InCHIANTI study. J Gerontol A Biol Sci Med Sci. 02. 2009;64(2):223-9. Not eligible outcomes. [pmid: 19182232].
1681 Vaupel JW, Manton KG, Stallard E. The impact of heterogeneity in individual frailty on the dynamics of mortality. Demography. 08. 1979;16(3):439-54. Simulation model. [pmid: 510638].
1682 Vaz Fragoso CA, Gahbauer EA, Van Ness PH, et al. Sleep-wake disturbances and frailty in community-living older persons. J Am Geriatr Soc. 11. 2009;57(11):2094-100. Not eligible outcomes. [pmid: 19793356].
1683 Veehof LJ, Stewart RE, Meyboom-de Jong B, et al. Adverse drug reactions and polypharmacy in the elderly in general practice. Eur J Clin Pharmacol. 09. 1999;55(7):533-6. Not eligible outcomes. [pmid: 10501824].
1684 Verbrugge LM, Juarez L. Profile of arthritis disability. Public Health Rep. 2001;116(Suppl 1):157-79. Not eligible outcomes. [pmid: 11889283].
1685 Verbrugge LM, Juarez L. Profile of arthritis disability: II. Arthritis Rheum. 02. 15. 2006;55(1):102-13. Not eligible outcomes. [pmid: 16463411].
1686 Verghese J. Cognitive and mobility profile of older social dancers. J Am Geriatr Soc. 08. 2006;54(8):1241-4. Not eligible outcomes. [pmid: 16913992].
1687 Verghese J, Cuiling W, Katz MJ, et al. Leisure activities and risk of vascular cognitive impairment in older adults. Journal of Geriatric Psychiatry & Neurology. 06. 2009;22(2):110-8. Not eligible exposure. [pmid: 19307322].
1688 Verghese J, LeValley A, Hall CB, et al. Epidemiology of gait disorders in community-residing older adults. Journal of the American Geriatrics Society. 02. 2006;54(2):255-61. Not eligible outcomes. [pmid: 16460376].
1689 Vestergaard S, Nayfield SG, Patel KV, et al. Fatigue in a representative population of older persons and its association with functional impairment, functional limitation, and disability. J Gerontol A Biol Sci Med Sci. 01. 2009;64(1):76-82. Not eligible outcome. [pmid: 19176328].
1690 Vig EK, Brodkin KI, Raugi GJ, et al. Blue rubber bleb nevus syndrome in a patient with ataxia and dementia. Journal of Geriatric Psychiatry & Neurology. 2002;15(1):7-11. Not eligible outcomes. [pmid: 11936246].
1691 Vincent HK, Vincent KR, Lee LW, et al. Effect of obesity on inpatient rehabilitation outcomes following total knee arthroplasty. Clin Rehabil. 02. 2007;21(2):182-90. Not eligible target population. [pmid: 17264112].
1692 Vischer UM, Safar ME, Safar H, et al. Cardiometabolic determinants of mortality in a geriatric population: is there a “reverse metabolic syndrome”. Diabetes Metab. 04. 2009;35(2):108-14. Not eligible outcomes. [pmid: 19237305].
1693 Vitagliano G, Curtis JP, Concato J, et al. Association between functional status and use and effectiveness of beta-blocker prophylaxis in elderly survivors of acute myocardial infarction. J Am Geriatr Soc. 04. 2004;52(4):495-501. Not eligible outcomes. [pmid: 15066062].
1694 Vitolins MZ, Quandt SA, Bell RA, et al. Quality of diets consumed by older rural adults. J Rural Health. Winter. 2002;18(1):49-56. Not eligible outcomes. [pmid: 12043755].
1695 Vladutiu CJ, Casteel C, Runyan CW. Disability and risk of non-fatal residential injuries among adults. Inj Prev. 10. 2008;14(5):302-5. Not eligible outcomes. [pmid: 18836046].
1696 Vogt MT, Simonsick EM, Harris TB, et al. Neck and shoulder pain in 70- to 79-year-old men and women: findings from the Health, Aging and Body Composition Study. Spine J. 11–12. 2003;3(6):435-41. Not eligible outcomes. [pmid: 14609687].
1697 Volicer BJ, Hurley A, Fabiszewski KJ, et al. Predicting short-term survival for patients with advanced Alzheimer’s disease. J Am Geriatr Soc. 05. 1993;41(5):535-40. Not eligible target population. [pmid: 8486888].
1698 Volkert D, Berner YN, Berry E, et al. ESPEN Guidelines on Enteral Nutrition: Geriatrics. Clin Nutr. 04. 2006;25(2):330-60. Not eligible outcomes. [pmid: 16735082].
1699 Volpato S, Zuliani G, Guralnik JM, et al. The inverse association between age and cholesterol level among older patients: the role of poor health status. Gerontology. 01–02. 2001;47(1):36-45. Not eligible outcomes. [pmid: 11244290].
1700 von Kanel R, Dimsdale JE, Mills PJ, et al. Effect of Alzheimer caregiving stress and age on frailty markers interleukin-6, C-reactive protein, and D-dimer. J Gerontol A Biol Sci Med Sci. 09. 2006;61(9):963-9. Not eligible target population. [pmid: 16960028].
1701 Von Korff M, Crane P, Lane M, et al. Chronic spinal pain and physical-mental comorbidity in the United States: results from the national comorbidity survey replication. Pain. 02. 2005;113(3):331-9. Not eligible outcomes. [pmid: 15661441].
1702 Vonta F, Karagrigoriou A. Variable selection strategies in survival models with multiple imputations. Lifetime Data Anal. 09. 2007;13(3):295-315. Not eligible outcomes. [pmid: 17786554].
1703 Vradenburg JA, Simoes EJ, Jackson-Thompson J, et al. The prevalence of arthritis and activity limitation and their predictors in Missouri. J Community Health. 04. 2002;27(2):91-107. Not eligible outcomes. [pmid: 11936760].
1704 Wackerbarth SB, Johnson MM, Markesbery WR, et al. Urban-rural differences in a memory disorders clinical population. J Am Geriatr Soc. 05. 2001;49(5):647-50. Not eligible target population. [pmid: 11380760].
1705 Wadley VG, McClure LA, Howard VJ, et al. Cognitive status, stroke symptom reports, and modifiable risk factors among individuals with no diagnosis of stroke or transient ischemic attack in the REasons for Geographic and Racial Differences in Stroke (REGARDS) Study. Stroke. 04. 2007;38(4):1143-7. Not eligible outcome. [pmid: 17322077].
1706 Waetjen LE, Liao S, Johnson WO, et al. Factors associated with prevalent and incident urinary incontinence in a cohort of midlife women: a longitudinal analysis of data: study of women’s health across the nation. American Journal of Epidemiology. 02. 1. 2007;165(3):309-18. Not eligible outcomes. [pmid: 17132698].
1707 Wagner L. Providers tame risks by: preventing falls. Provider. 06. 1997;23(6):32-4. 6. 7. Not eligible outcomes. [pmid: 10168002].
1708 Wakefield BJ, Mentes J, Holman JE, et al. Risk factors and outcomes associated with hospital admission for dehydration. Rehabil Nurs. 11–12. 2008;33(6):233-41. Not eligible target population. [pmid: 19024237].
1709 Walsh PN. Health indicators and intellectual disability. Curr Opin Psychiatry. 09. 2008;21(5):474-8. Review. [pmid: 18650690].
1710 Walston J, Arking DE, Fallin D, et al. IL-6 gene variation is not associated with increased serum levels of IL-6, muscle, weakness, or frailty in older women. Exp Gerontol. 04. 2005;40(4):344-52. Not eligible exposure. [pmid: 15820616].
1711 Wang CY, Baldwin LM, Saver BG, et al. The contribution of longitudinal comorbidity measurements to survival analysis. Med Care. 07. 2009;47(7):813-21. Not eligible exposure. [pmid: 19536031].
1712 Wang J, Mentes JC. Detection of acute confusion in Taiwanese elderly individuals. Journal of Gerontological Nursing. 06. 2006;32(6):7-12. Review. [pmid: 16773858].
1713 Wang K, Yau KK, Lee AH, et al. Multilevel survival modelling of recurrent urinary tract infections. Comput Methods Programs Biomed. 09. 2007;87(3):225-9. Not eligible outcomes. [pmid: 17619063].
1714 Wang Y, Lim LL, Heller RF, et al. A prediction model of 1-year mortality for acute ischemic stroke patients. Arch Phys Med Rehabil. 07. 2003;84(7):1006-11. Not eligible outcomes. [pmid: 12881825].
1715 Wang YC, Byers KL, Velozo CA. Rasch analysis of Minimum Data Set mandated in skilled nursing facilities. J Rehabil Res Dev. 2008;45(9):1385-99. Not elgible target population. [pmid: 19319762].
1716 Wang YC, Colditz GA, Kuntz KM. Forecasting the obesity epidemic in the aging U.S. population. Obesity. 11. 2007;15(11):2855-65. Not eligible outcomes. [pmid: 18070778].
1717 Warnick LD, Erb HN, White ME. The relationship of calfhood morbidity with survival after calving in 25 New York Holstein herds. Preventive Veterinary Medicine. 08. 1997;31(3–4):263-73. Not eligible outcomes. [pmid: 9234450].
1718 Warwick J, Tabar L, Vitak B, et al. Time-dependent effects on survival in breast carcinoma: results of 20 years of follow-up from the Swedish Two-County Study. Cancer. 04. 1. 2004;100(7):1331-6. Not eligible outcomes. [pmid: 15042664].
1719 Wassell JT, Moeschberger ML. A bivariate survival model with modified gamma frailty for assessing the impact of interventions. Stat Med. 02. 1993;12(3–4):241-8. Not eligible outcomes. [pmid: 8456209].
1720 Wasserberg N, Haney M, Petrone P, et al. Morbid obesity adversely impacts pelvic floor function in females seeking attention for weight loss surgery. Diseases of the Colon & Rectum. 12. 2007;50(12):2096-103. Not eligible outcomes. [pmid: 17899277].
1721 Waterer GW, Wan JY, Kritchevsky SB, et al. Airflow limitation is underrecognized in well-functioning older people. J Am Geriatr Soc. 08. 2001;49(8):1032-8. Not eligible outcomes. [pmid: 11555063].
1722 Watson A. HIV and the elderly. J Pract Nurs. Spring. 2004;54(1):11-2. Not eligible outcomes. [pmid: 15193013].
1723 Watters MR, Poff PW, Shiramizu BT, et al. Symptomatic distal sensory polyneuropathy in HIV after age 50. Neurology. 04. 27. 2004;62(8):1378-83. Not eligible outcomes. [pmid: 15111677].
1724 Weale RA. On the age-related prevalence of anisometropia. Ophthalmic Res. 11–12. 2002;34(6):389-92. Not eligible outcomes. [pmid: 12483028].
1725 Weamer EA, Emanuel JE, Varon D, et al. The relationship of excess cognitive impairment in MCI and early Alzheimer’s disease to the subsequent emergence of psychosis. Int Psychogeriatr. 02. 2009;21(1):78-85. Not eligible target population. [pmid: 18814807].
1726 Weber J, Kehoe T, Bakoss M, et al. Safety at home: a practical home-injury control program for independent seniors. Caring. 06. 1996;15(6):62-6. Not eligible outcomes. [pmid: 10158233].
1727 Weber V, White A, McIlvried R. An electronic medical record (EMR)-based intervention to reduce polypharmacy and falls in an ambulatory rural elderly population. J Gen Intern Med. 04. 2008;23(4):399-404. Not eligible outcomes. [pmid: 18373136].
1728 Webster JB, Bell KR, Hussey JD, et al. Sleep apnea in adults with traumatic brain injury: a preliminary investigation. Archives of Physical Medicine & Rehabilitation. 03. 2001;82(3):316-21. Not eligible outcomes. [pmid: 11245752].
1729 Weinberger J, Marin DB. Brain function in aging: solutions for significant challenges. Geriatrics. 01. 2002;57(1):37. Not eligible outcomes. [pmid: 11802358].
1730 Weiss KM. The biodemography of variation in human frailty. Demography. 05. 1990;27(2):185-206. Comment. [pmid: 2332085].
1731 Weiss ST, Segal MR, Sparrow D, et al. Relation of FEV1 and peripheral blood leukocyte count to total mortality. The Normative Aging Study. American Journal of Epidemiology. 09. 1. 1995;142(5):493-8. discussion 9–503. Not eligible outcomes. [pmid: 7677128].
1732 Weisskopf MG, Proctor SP, Wright RO, et al. Cumulative lead exposure and cognitive performance among elderly men. Epidemiology. 01. 2007;18(1):59-66. Not eligible exposure. [pmid: 17130688].
1733 Weissman MM, Greenwald S, Nino-Murcia G, et al. The morbidity of insomnia uncomplicated by psychiatric disorders. General Hospital Psychiatry. 07. 1997;19(4):245-50. Not eligible outcomes. [pmid: 9327253].
1734 Wells SJ, Garber LP, Hill GW. Health status of preweaned dairy heifers in the United States. Preventive Veterinary Medicine. 01. 1997;29(3):185-99. Not eligible outcomes. [pmid: 9234404].
1735 Werblow A, Felder S, Zweifel P. Population ageing and health care expenditure: a school of ‘red herrings’. Health Econ. 10. 2007;16(10):1109-26. Not eligible outcomes. [pmid: 17311357].
1736 West DS, Golden WE. Medicare part D and medication management in the elderly. J Ark Med Soc. 06. 2006;102(12):320-1. Not eligible outcomes. [pmid: 16776305].
1737 West JC, Wilk JE, Muszynski IL, et al. Medication access and continuity: the experiences of dual-eligible psychiatric patients during the first 4 months of the Medicare prescription drug benefit. Am J Psychiatry. 05. 2007;164(5):789-96. Not eligible target population. [pmid: 17475738].
1738 West NA, Haan MN, West NA, et al. Body adiposity in late life and risk of dementia or cognitive impairment in a longitudinal community-based study. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 01. 2009;64(1):103-9. Not eligible exposure.
1739 West SK, Munoz B, Rubin GS, et al. Compensatory strategy use identifies risk of incident disability for the visually impaired. Arch Ophthalmol. 09. 2005;123(9):1242-7. Not eligible outcomes. [pmid: 16157806].
1740 Wetter DW, Young TB. The relation between cigarette smoking and sleep disturbance. Preventive medicine. 05. 1994;23(3):328-34. Not eligible outcomes. [pmid: 8078854].
1741 Wetter DW, Young TB, Bidwell TR, et al. Smoking as a risk factor for sleep-disordered breathing. Archives of Internal Medicine. 10. 10. 1994;154(19):2219-24. Not eligible outcomes. [pmid: 7944843].
1742 Weuve J, Ridker PM, Cook NR, et al. High-sensitivity C-reactive protein and cognitive function in older women. Epidemiology. 03. 2006;17(2):183-9. Not eligible outcomes. [pmid: 16477259].
1743 Weyant RJ, Jones JA, Hobbins M, et al. Oral health status of a long-term-care, veteran population. Community Dent Oral Epidemiol. 08. 1993;21(4):227-33. Not eligible target population. [pmid: 8370261].
1744 White L, Katzman R, Losonczy K, et al. Association of education with incidence of cognitive impairment in three established populations for epidemiologic studies of the elderly. Journal of Clinical Epidemiology. 04. 1994;47(4):363-74. Not eligible outcomes. [pmid: 7730861].
1745 Whitmer RA, Gustafson DR, Barrett-Connor E, et al. Central obesity and increased risk of dementia more than three decades later.[see comment]. Neurology. 09. 30. 2008;71(14):1057-64. Not eligible exposure. [pmid: 18367704].
1746 Whooley MA, Cauley JA, Zmuda JM, et al. Depressive symptoms and bone mineral density in older men. Journal of Geriatric Psychiatry & Neurology. 06. 2004;17(2):88-92. Not eligible outcomes. [pmid: 15157349].
1747 Wieland D, Hedrick SC, Rubenstein LZ, et al. Inpatient geriatric evaluation and management units: organization and care patterns in the Department of Veterans Affairs. Gerontologist. 10. 1994;34(5):652-7. Not eligible outcomes. [pmid: 7959133].
1748 Wienke A, Christensen K, Holm NV, et al. Heritability of death from respiratory diseases: an analysis of Danish twin survival data using a correlated frailty model. Stud Health Technol Inform. 2000;77:407-11. Not eligible outcomes. [pmid: 11187584].
1749 Wienke A, Herskind AM, Christensen K, et al. The heritability of CHD mortality in danish twins after controlling for smoking and BMI. Twin Res Hum Genet. 02. 2005;8(1):53-9. Not eligible outcomes. [pmid: 15836811].
1750 Wienke A, Holm NV, Christensen K, et al. The heritability of cause-specific mortality: a correlated gamma-frailty model applied to mortality due to respiratory diseases in Danish twins born 1870–1930. Stat Med. 12. 30. 2003;22(24):3873-87. Not eligible outcomes. [pmid: 14673944].
1751 Wienke A, Holm NV, Skytthe A, et al. The heritability of mortality due to heart diseases: a correlated frailty model applied to Danish twins. Twin Res. 08. 2001;4(4):266-74. Not eligible outcomes. [pmid: 11665307].
1752 Wight RG, Cummings JR, Karlamangla AS, et al. Urban neighborhood context and change in depressive symptoms in late life. J Gerontol B Psychol Sci Soc Sci. 03. 2009;64(2):247-51. Not eligible outcomes. [pmid: 19181693].
1753 Wikby K, Ek AC, Christensson L. Nutritional status in elderly people admitted to community residential homes: comparisons between two cohorts. J Nutr Health Aging. 05–06. 2006;10(3):232-8. Not eligible target population. [pmid: 16622585].
1754 Wilkinson TJ, Sainsbury R. A census-based comparison of centenarians in New Zealand with those in the United States. J Am Geriatr Soc. 04. 1998;46(4):488-91. Not eligible outcomes. [pmid: 9560074].
1755 Wilkinson TJ, Warren MR. What is the prognosis of mild normocytic anaemia in older people. Intern Med J. 01–02. 2003;33(1–2):14-7. Not eligible outcomes. [pmid: 12534873].
1756 Williams AR, Meuleman JM, Shaw MM. Mortality one-year postdischarge from a Veterans Affairs geriatric evaluation and management unit: assessing mortality risks. J Am Geriatr Soc. 07. 1999;47(7):860-3. Not eligible outcomes. [pmid: 10404932].
1757 Williams B. Comparison of services among different types of home health agencies. Med Care. 11. 1994;32(11):1134-52. Not eligible target population. [pmid: 7967854].
1758 Williams BC, Fitzgerald JT. Brief report: Brief instrument to assess geriatrics knowledge of surgical and medical subspecialty house officers. Journal of General Internal Medicine. 05. 2006;21(5):490-3. Not eligible outcomes. [pmid: 16704394].
1759 Williams FM, Wynne H, Woodhouse KW, et al. Plasma aspirin esterase: the influence of old age and frailty. Age Ageing. 01. 1989;18(1):39-42. Not eligible outcomes. [pmid: 2496585].
1760 Williams R, Bosnic N, Duncan AW, et al. Prevalence of opioid dispensings and concurrent gastrointestinal medications in an elderly population from Ontario, Canada. J Opioid Manag. 07–08. 2008;4(4):193-200. Not eligible outcomes. [pmid: 18837202].
1761 Williams SJ, Seidman RL, Drew JA, et al. Identifying depressive symptoms among elderly Medicare HMO enrollees. HMO Pract. 12. 1995;9(4):168-73. Not eligible outcomes. [pmid: 10170168].
1762 Wilson RS, Hebert LE, Scherr PA, et al. Educational attainment and cognitive decline in old age. Neurology. 02. 3. 2009;72(5):460-5. not eligible exposure. [pmid: 19188578].
1763 Wilson RS, Li Y, Aggarwal NT, et al. Cognitive decline and survival in Alzheimer’s disease. International Journal of Geriatric Psychiatry. 04. 2006;21(4):356-62. Not eligible target population. [pmid: 16534773].
1764 Wilson RS, Schneider JA, Boyle PA, et al. Chronic distress and incidence of mild cognitive impairment. Neurology. 06. 12. 2007;68(24):2085-92. Not eligible exposure. [pmid: 17562829].
1765 Wipke-Tevis DD, Rantz MJ, Mehr DR, et al. Prevalence, incidence, management, and predictors of venous ulcers in the long-term-care population using the MDS. Adv Skin Wound Care. 09–10. 2000;13(5):218-24. Not eligible target population. [pmid: 11075021].
1766 Wirth R, Bauer JM, Sieber CC. Cognitive function, body weight and body composition in geriatric patients. Zeitschrift fur Gerontologie und Geriatrie. 02. 2007;40(1):13-20. Not eligible target population. [pmid: 17318727].
1767 Witham MD, Gillespie ND, Hutcheon SD, et al. B-type natriuretic peptide is associated with mortality in older functionally impaired patients. J Am Geriatr Soc. 11. 2005;53(11):1991-5. Not eligible exposure. [pmid: 16274384].
1768 Wittchen HU, Jacobi F. Size and burden of mental disorders in Europe--a critical review and appraisal of 27 studies. Eur Neuropsychopharmacol. 08. 2005;15(4):357-76. Not eligible outcomes. [pmid: 15961293].
1769 Wolf DA, Mendes de Leon CF, Glass TA. Trends in rates of onset of and recovery from disability at older ages: 1982–1994. J Gerontol B Psychol Sci Soc Sci. 01. 2007;62(1):S3-10. Not eligible outcomes. [pmid: 17284564].
1770 Wolf SL, Barnhart HX, Kutner NG, et al. Reducing frailty and falls in older persons: an investigation of Tai Chi and computerized balance training. Atlanta FICSIT Group. Frailty and Injuries: Cooperative Studies of Intervention Techniques. J Am Geriatr Soc. 05. 1996;44(5):489-97. Not eligible outcomes. [pmid: 8617895].
1771 Wolfe F, Skevington SM. Measuring the epidemiology of distress: the rheumatology distress index. Journal of Rheumatology. 08. 2000;27(8):2000-9. Not eligible outcomes. [pmid: 10955344].
1772 Wolff JL, Meadow A, Weiss CO, et al. Medicare home health patients’ transitions through acute and post-acute care settings. Med Care. 11. 2008;46(11):1188-93. Not eligible target population. [pmid: 18953231].
1773 Wolff JL, Roter DL. Hidden in plain sight: medical visit companions as a resource for vulnerable older adults. Arch Intern Med. 07. 14. 2008;168(13):1409-15. Not eligible outcomes. [pmid: 18625921].
1774 Wolf-Klein GP, Levy AP, Silverstone FA, et al. Psychiatric profile of the noncompliant geriatric patient in the community. Int Psychogeriatr. Fall. 1989;1(2):177-84. Not eligible outcomes. [pmid: 2491144].
1775 Wolinsky FD, Fitzgerald JF, Stump TE. The effect of hip fracture on mortality, hospitalization, and functional status: a prospective study. American Journal of Public Health. 03. 1997;87(3):398-403. Not eligible exposure. [pmid: 9096540].
1776 Wolinsky FD, Miller DK, Andresen EM, et al. Further evidence for the importance of subclinical functional limitation and subclinical disability assessment in gerontology and geriatrics. J Gerontol B Psychol Sci Soc Sci. 05. 2005;60(3):S146-51. Not eligible outcomes. [pmid: 15860791].
1777 Wolinsky FD, Miller DK, Andresen EM, et al. Effect of subclinical status in functional limitation and disability on adverse health outcomes 3 years later. J Gerontol A Biol Sci Med Sci. 01. 2007;62(1):101-6. Not eligible outcomes. [pmid: 17301046].
1778 Wolinsky FD, Miller TR, Geweke JF, et al. An interpersonal continuity of care measure for Medicare Part B claims analyses. J Gerontol B Psychol Sci Soc Sci. 05. 2007;62(3):S160-8. Not eligible outcomes. [pmid: 17507591].
1779 Wolinsky FD, Overhage JM, Stump TE, et al. The risk of hospitalization for congestive heart failure among older adults. Med Care. 10. 1997;35(10):1031-43. Not eligible exposure. [pmid: 9338529].
1780 Wolinsky FD, Stump TE. A measurement model of the Medical Outcomes Study 36-Item Short-Form Health Survey in a clinical sample of disadvantaged, older, black, and white men and women. Med Care. 06. 1996;34(6):537-48. Not eligible outcomes. [pmid: 8656720].
1781 Won A, Lapane K, Gambassi G, et al. Correlates and management of nonmalignant pain in the nursing home SAGE Study Group. Systematic Assessment of Geriatric drug use via Epidemiology. J Am Geriatr Soc. 08. 1999;47(8):936-42. Not eligible target population. [pmid: 10443853].
1782 Woo J, Ho SC, Yu AL. Walking speed and stride length predicts 36 months dependency, mortality, and institutionalization in Chinese aged 70 and older. J Am Geriatr Soc. 10. 1999;47(10):1257-60. Not eligible population. [pmid: 10522962].
1783 Woo J, Tang NL, Suen E, et al. Telomeres and frailty. Mech Ageing Dev. 11. 2008;129(11):642-8. Not eligible outcomes. [pmid: 18809425].
1784 Wood RY, Giuliano KK, Bignell CU, et al. Assessing cognitive ability in research: use of MMSE with minority populations and elderly adults with low education levels. J Gerontol Nurs. 04. 2006;32(4):45-54. Not eligible outcomes. [pmid: 16615712].
1785 Woolf SH, Kamerow DB, Lawrence RS, et al. The periodic health examination of older adults: the recommendations of the U.S. Preventive Services Task Force. Part II. Screening tests. J Am Geriatr Soc. 08. 1990;38(8):933-42. Not eligible outcomes. [pmid: 2387958].
1786 Wray LA, Alwin DF, McCammon RJ, et al. Social status and risky health behaviors: results from the health and retirement study. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. 10. 2005;60(Spec No 2):85-92. Not eligible outcomes.
1787 Wright CB, Elkind MS, Luo X, et al. Reported alcohol consumption and cognitive decline: The northern Manhattan study. Neuroepidemiology. 2006;27(4):201-7. Not eligible outcomes. [pmid: 17047373].
1788 Wu AH, Eagle KA, Montgomery DG, et al. Relation of body mass index to mortality after development of heart failure due to acute coronary syndrome. American Journal of Cardiology. 06. 15. 2009;103(12):1736-40. Not eligible outcomes. [pmid: 19539085].
1789 Wu CY, Yu TJ, Chen MJ. Age related testosterone level changes and male andropause syndrome. Chang Gung Med J. 06. 2000;23(6):348-53. Not eligible outcomes. [pmid: 10958037].
1790 Wu JY, Leung WY, Chang S, et al. Effectiveness of telephone counselling by a pharmacist in reducing mortality in patients receiving polypharmacy: randomised controlled trial. BMJ. 09. 9. 2006;333(7567):522. Not eligible outcomes. [pmid: 16916809].
1791 Wuthrich P, Gervaz P, Ambrosetti P, et al. Functional outcome and quality of life after restorative proctocolectomy and ileo-anal pouch anastomosis. Swiss Medical Weekly. 04. 4. 2009;139(13–14):193-7. Not eligible outcomes. [pmid: 19350425].
1792 Xiong GL, Plassman BL, Helms MJ, et al. Vascular risk factors and cognitive decline among elderly male twins.[see comment]. Neurology. 11. 14. 2006;67(9):1586-91. Not eligible exposure. [pmid: 17101888].
1793 Xu R, Harrington DP. A semiparametric estimate of treatment effects with censored data. Biometrics. 09. 2001;57(3):875-85. Not eligible outcomes. [pmid: 11550940].
1794 Xu X, Weiss ST, Dockery DW, et al. Comparing FEV1 in adults in two community-based studies. Chest. 09. 1995;108(3):656-62. Not eligible outcomes. [pmid: 7656612].
1795 Yaffe K, Barnes D, Nevitt M, et al. A prospective study of physical activity and cognitive decline in elderly women: women who walk.[see comment]. Archives of Internal Medicine. 07. 23. 2001;161(14):1703-8. Not eligible outcomes. [pmid: 11485502].
1796 Yaghoubian A, de Virgilio C, White RA, et al. Increased incidence of renal cysts in patients with abdominal aortic aneurysms: a common pathogenesis?. Annals of Vascular Surgery. 11. 2006;20(6):787-91. Not eligible outcomes. [pmid: 17080232].
1797 Yancik R, Havlik RJ, Wesley MN, et al. Cancer and comorbidity in older patients: a descriptive profile. Ann Epidemiol. 09. 1996;6(5):399-412. Not eligible outcomes. [pmid: 8915471].
1798 Yao Y, Yao SL, Yao SS, et al. Prevalence of vitamin B12 deficiency among geriatric outpatients.[see comment]. Journal of Family Practice. 11. 1992;35(5):524-8. Not eligible target population. [pmid: 1331288].
1799 Yasar S, Corrada M, Brookmeyer R, et al. Calcium channel blockers and risk of AD: the Baltimore Longitudinal Study of Aging. Neurobiology of aging. 02. 2005;26(2):157-63. Not eligible exposure. [pmid: 15582745].
1800 Yashin AI, Arbeev KG, Akushevich I, et al. Stochastic model for analysis of longitudinal data on aging and mortality. Mathematical Biosciences. 2007;208(2):538-51. Not eligible outcomes. [pmid: 17300818].
1801 Yashin AI, Arbeev KG, Akushevich I, et al. Model of hidden heterogeneity in longitudinal data. Theoretical Population Biology. 2008;73(1):1-10. Not eligible outcomes. [pmid: 17977568].
1802 Yashin AI, Arbeev KG, Kulminski A, et al. Cumulative index of elderly disorders and its dynamic contribution to mortality and longevity. Rejuvenation Res. 03. 2007;10(1):75-86. Not eligible outcomes. [pmid: 17378754].
1803 Yashin AI, De Benedictis G, Vaupel JW, et al. Genes, demography, and life span: the contribution of demographic data in genetic studies on aging and longevity. Am J Hum Genet. 10. 1999;65(4):1178-93. Not eligible outcomes. [pmid: 10486337].
1804 Yashin AI, Iachine IA. Genetic analysis of durations: correlated frailty model applied to survival of Danish twins. Genet Epidemiol. 1995;12(5):529-38. Not eligible outcomes. [pmid: 8557185].
1805 Yashin AI, Iachine IA, Harris JR. Half of the variation in susceptibility to mortality is genetic: findings from Swedish twin survival data. Behav Genet. 01. 1999;29(1):11-9. Not eligible outcomes. [pmid: 10371754].
1806 Yashin AI, Manton KG, Vaupel JW. Mortality and aging in a heterogeneous population: a stochastic process model with observed and unobserved variables. Theor Popul Biol. 04. 1985;27(2):154-75. Not eligible outcomes. [pmid: 4023952].
1807 Yashin AI, Manton KG, Woodbury MA, et al. The effects of health histories on stochastic process models of aging and mortality. J Math Biol. 1995;34(1):1-16. Not eligible outcomes. [pmid: 8568421].
1808 Yashin AI, Ukraintseva SV, Boiko SI, et al. Individual aging and mortality rate: how are they related?. Soc Biol. Fall-Winter. 2002;49(3–4):206-17. Not eligible outcomes. [pmid: 14652918].
1809 Yasmeen S, Romano PS, Pettinger M, et al. Incidence of cervical cytological abnormalities with aging in the women’s health initiative: a randomized controlled trial. Obstetrics & Gynecology. 08. 2006;108(2):410-9. Not eligible outcomes. [pmid: 16880313].
1810 Yau KK, McGilchrist CA. ML and REML estimation in survival analysis with time dependent correlated frailty. Stat Med. 06. 15. 1998;17(11):1201-13. Not eligible outcomes. [pmid: 9670410].
1811 Ye Y, Kalbfleisch JD, Schaubel DE. Semiparametric analysis of correlated recurrent and terminal events. Biometrics. 03. 2007;63(1):78-87. Not eligible outcomes. [pmid: 17447932].
1812 Yelin E, Trupin L, Wong B, et al. The impact of functional status and change in functional status on mortality over 18 years among persons with rheumatoid arthritis. Journal of Rheumatology. 09. 2002;29(9):1851-7. Not eligible outcomes. [pmid: 12233878].
1813 Yin G, Ibrahim JG. A class of Bayesian shared gamma frailty models with multivariate failure time data. Biometrics. 03. 2005;61(1):208-16. Not eligible outcomes. [pmid: 15737095].
1814 Young RF. Nursing home admission of female Alzheimer’s patients: family care aspects. Womens Health Issues. 01–02. 2003;13(1):2-7. Not eligible outcomes. [pmid: 12598053].
1815 Young T. Analytic epidemiology studies of sleep disordered breathing--what explains the gender difference in sleep disordered breathing?[see comment]. Sleep. 12. 1993;16(8 Suppl):S1-2. Not eligible outcomes. [pmid: 8177989].
1816 Young T, Finn L, Austin D, et al. Menopausal status and sleep-disordered breathing in the Wisconsin Sleep Cohort Study.[see comment]. American Journal of Respiratory & Critical Care Medicine. 05. 1. 2003;167(9):1181-5. Not eligible outcomes. [pmid: 12615621].
1817 Young T, Finn L, Palta M. Chronic nasal congestion at night is a risk factor for snoring in a population-based cohort study. Archives of Internal Medicine. 06. 25. 2001;161(12):1514-9. Not eligible outcomes. [pmid: 11427099].
1818 Young T, Palta M, Dempsey J, et al. The occurrence of sleep-disordered breathing among middle-aged adults.[see comment]. New England Journal of Medicine. 04. 29. 1993;328(17):1230-5. Not eligible outcomes. [pmid: 8464434].
1819 Yu EW, Blackwell T, Ensrud KE, et al. Acid-suppressive medications and risk of bone loss and fracture in older adults. Calcified tissue international. 10. 2008;83(4):251-9. Not eligible outcomes. [pmid: 18813868].
1820 Yu YF, Nichol MB, Yu AP, et al. Persistence and adherence of medications for chronic overactive bladder/urinary incontinence in the california medicaid program. Value in Health. 07–08. 2005;8(4):495-505. Not eligible outcomes. [pmid: 16091027].
1821 Yu Z, Lin X, Haas JD, et al. Obesity related metabolic abnormalities: distribution and geographic differences among middle-aged and older Chinese populations. Preventive medicine. 03. 2009;48(3):272-8. Not eligible exposure. [pmid: 19272300].
1822 Zandi PP, Sparks DL, Khachaturian AS, et al. Do statins reduce risk of incident dementia and Alzheimer disease. The Cache County Study. Arch Gen Psychiatry. 02. 2005;62(2):217-24. Not eligible outcomes. [pmid: 15699299].
1823 Zarowitz BJ. Medication overuse and misuse. Geriatr Nurs. 07–08. 2006;27(4):204-6. Not eligible outcomes. [pmid: 16890100].
1824 Zarowitz BJ. Fixed-dose combinations for improving medication adherence in assisted living environments. Geriatr Nurs. 11–12. 2007;28(6):341-5. Not eligible outcomes. [pmid: 18068817].
1825 Zarowitz BJ, Stefanacci R, Hollenack K, et al. The application of evidence-based principles of care in older persons (issue 1): management of osteoporosis. J Am Med Dir Assoc. 02. 2006;7(2):102-8. Not eligible outcomes. [pmid: 16461252].
1826 Zauber AG, Lansdorp-Vogelaar I, Knudsen AB, et al. Evaluating test strategies for colorectal cancer screening: a decision analysis for the U. S Preventive Services Task Force. Ann Intern Med. 11. 4. 2008;149(9):659-69. Not eligible outcomes. [pmid: 18838717].
1827 Zauszniewski JA, Morris DL, Preechawong S, et al. Reports on depressive symptoms in older adults with chronic conditions. Res Theory Nurs Pract. Summer-Fall. 2004;18(2–3):185-96. Not eligible outcomes. [pmid: 15553346].
1828 Zdravkovic S, Wienke A, Pedersen NL, et al. Heritability of death from coronary heart disease: a 36-year follow-up of 20 966 Swedish twins. J Intern Med. 09. 2002;252(3):247-54. Not eligible outcomes. [pmid: 12270005].
1829 Zdravkovic S, Wienke A, Pedersen NL, et al. Genetic influences on CHD-death and the impact of known risk factors: comparison of two frailty models. Behav Genet. 11. 2004;34(6):585-92. Not eligible outcomes. [pmid: 15520515].
1830 Zhang W, Mason EE, Renquist KE, et al. Factors influencing survival following surgical treatment of obesity. Obes Surg. 01. 2005;15(1):43-50. Not eligible outcomes. [pmid: 16013115].
1831 Zhang Y, Niu J, Kelly-Hayes M, et al. Prevalence of symptomatic hand osteoarthritis and its impact on functional status among the elderly: The Framingham Study. Am J Epidemiol. 12. 1. 2002;156(11):1021-7. Not eligible outcomes. [pmid: 12446258].
1832 Zhou H, Lawson AB, Hebert JR, et al. Joint spatial survival modeling for the age at diagnosis and the vital outcome of prostate cancer. Stat Med. 08. 15. 2008;27(18):3612-28. Not eligible outcomes. [pmid: 18416442].
1833 Zhu CW, Leibman C, McLaughlin T, et al. The effects of patient function and dependence on costs of care in Alzheimer’s disease. J Am Geriatr Soc. 08. 2008;56(8):1497-503. Not eligible outcomes. [pmid: 18662215].
1834 Zimmaro Bliss D, Zehrer C, Savik K, et al. Incontinence-associated skin damage in nursing home residents: a secondary analysis of a prospective, multicenter study. Ostomy Wound Management. 12. 2006;52(12):46-55. Not eligible target population.
1835 Zochling J, Chen JS, Seibel M, et al. Calcium metabolism in the frail elderly. Clin Rheumatol. 11. 2005;24(6):576-82. Not eligible target population. [pmid: 16082497].
1836 Zonderman AB, Zonderman AB. Predicting Alzheimer’s disease in the Baltimore longitudinal study of aging. Journal of Geriatric Psychiatry & Neurology. 12. 2005;18(4):192-5. Review. [pmid: 16306238].
1837 Zuliani G, Volpatol S, Romagnoni F, et al. Combined measurement of serum albumin and high-density lipoprotein cholesterol strongly predicts mortality in frail older nursing-home residents. Aging Clin Exp Res. 12. 2004;16(6):472-5. Not eligible outcomes. [pmid: 15739599].
1838 Zweifel P, Felder S, Meier M. Reply to: Econometric issues in testing the age neutrality of health care expenditure. Health Econ. 10. 2001;10(7):673-4. Not eligible outcomes. [pmid: 11747049].
1839 Zweifel P, Felder S, Meiers M. Ageing of population and health care expenditure: a red herring. Health Econ. 09. 1999;8(6):485-96. Not eligible outcomes. [pmid: 10544314].
1840 Brogan D, Kutner NG, Flagg E. Survival differences among older dialysis patients in the southeast. Am J Kidney Dis. 10. 1992;20(4):376-86. Not eligible outcomes. [pmid: 1415207].
1841 Nichols CM, Gill EJ, Nguyen T, et al. Anal sphincter injury in women with pelvic floor disorders. Obstetrics & Gynecology. 10. 2004;104(4):690-6. Not eligible outcomes. [pmid: 15458887].
1842 Rockwood K, Rockwood MR, Andrew MK, et al. Reliability of the hierarchical assessment of balance and mobility in frail older adults. J Am Geriatr Soc. 07. 2008;56(7):1213-7. Not eligible outcomes. [pmid: 18503518].
1843 Vasquez MS. Preventing rehospitalization through effective home health nursing care. Home Healthc Nurse. 02. 2008;26(2):75-81. Secondary data analysis. [pmid: 18301108].
1844 Wilhelm-Leen ER, Hall YN, Tamura MK, et al. Frailty and chronic kidney disease: the Third National Health and Nutrition Evaluation Survey. Am J Med. 07. 2009;122(7):664-71. e2. Not eligible outcomes. [pmid: 19559169].
1845 Cress C. Handbook of geriatric care management: Toronto. 2007. Not eligible outcomes.
1846 Minkler M, Fuller-Thomson E, Guralnik JM. Gradient of disability across the socioeconomic spectrum in the United States. N Engl J Med. 08. 17. 2006;355(7):695-703. Not eligible outcomes. [pmid: 16914705].
1847 Barry LC, Allore HG, Bruce ML, et al. Longitudinal association between depressive symptoms and disability burden among older persons. J Gerontol A Biol Sci Med Sci. 12. 2009;64(12):1325-32. Not eligible outcomes. [pmid: 19776217].
1848 Gill TM, Van Ness PH, Gahbauer EA. Factors associated with accurate recall of prior disability in older persons. J Am Geriatr Soc. 10. 2009;57(10):1897-901. Not eligible outcomes. [pmid: 19737329].
1849 Naik AD, Concato J, Gill TM. Bathing disability in community-living older persons: common, consequential, and complex. J Am Geriatr Soc. 11. 2004;52(11):1805-10. Not eligible outcomes. [pmid: 15507055].
1850 Gill TM, Han L, Allore HG. Bath aids and the subsequent development of bathing disability in community-living older persons. J Am Geriatr Soc. 11. 2007;55(11):1757-63. Not eligible outcomes/ duplicate reporting. [pmid: 17916117].
1851 Cesari M, Pahor M, Marzetti E, et al. Self-assessed health status, walking speed and mortality in older Mexican-Americans. Gerontology. 2009;55(2):194-201. Not eligible outcomes. [pmid: 19018125].
1852 Landi F, Russo A, Pahor M, et al. Serum high-density lipoprotein cholesterol levels and mortality in frail, community-living elderly. Gerontology. 2008;54(2):71-8. Not eligible outcomes. [pmid: 18025809].
1853 Coppin AK, Ferrucci L, Lauretani F, et al. Low socioeconomic status and disability in old age: evidence from the InChianti study for the mediating role of physiological impairments. J Gerontol A Biol Sci Med Sci. 01. 2006;61(1):86-91. Not eligible outcomes. [pmid: 16456198].
1854 Penninx BW, Pahor M, Cesari M, et al. Anemia is associated with disability and decreased physical performance and muscle strength in the elderly. J Am Geriatr Soc. 05. 2004;52(5):719-24. Not eligible outcomes. [pmid: 15086651].
1855 Vestergaard S, Patel KV, Walkup MP, et al. Stopping to rest during a 400-meter walk and incident mobility disability in older persons with functional limitations. J Am Geriatr Soc. 02. 2009;57(2):260-5. Not eligible outcomes. [pmid: 19170785].
1856 Chevarley FM, Thierry JM, Gill CJ, et al. Health, preventive health care, and health care access among women with disabilities in the 1994–1995 National Health Interview Survey, Supplement on Disability. Womens Health Issues. 11–12. 2006;16(6):297-312. Not eligible outcomes. [pmid: 17188213].
1857 Atkinson HH, Cesari M, Kritchevsky SB, et al. Predictors of combined cognitive and physical decline. J Am Geriatr Soc. 07. 2005;53(7):1197-202. Not eligible outcomes. [pmid: 16108938].
1858 Bartali B, Semba RD, Frongillo EA, et al. Low micronutrient levels as a predictor of incident disability in older women. Archives of Internal Medicine. 11. 27. 2006;166(21):2335-40. Not eligible outcomes. [pmid: 17130386].
1859 Jylha M, Guralnik JM, Balfour J, et al. Walking difficulty, walking speed, and age as predictors of self-rated health: the women’s health and aging study. J Gerontol A Biol Sci Med Sci. 10. 2001;56(10):M609-17. Not eligible outcomes. [pmid: 11584033].
1860 Onder G, Penninx BW, Ferrucci L, et al. Measures of physical performance and risk for progressive and catastrophic disability: results from the Women’s Health and Aging Study. J Gerontol A Biol Sci Med Sci. 01. 2005;60(1):74-9. Not eligible outcomes. [pmid: 15741286].
1861 Rantanen T, Guralnik JM, Ferrucci L, et al. Coimpairments as predictors of severe walking disability in older women. J Am Geriatr Soc. 01. 2001;49(1):21-7. Not eligible outcomes. [pmid: 11207838].
1862 Semba RD, Ferrucci L, Sun K, et al. Oxidative stress and severe walking disability among older women. Am J Med. 12. 2007;120(12):1084-9. Not eligible outcomes. [pmid: 18060930].
1863 Gersten O. Neuroendocrine biomarkers, social relations, and the cumulative costs of stress in Taiwan. Soc Sci Med. 02. 2008;66(3):507-19. discussion 20–35. [pmid: 18022742].
1864 Ceresini G, Lauretani F, Maggio M, et al. Thyroid function abnormalities and cognitive impairment in elderly people: results of the Invecchiare in Chianti study. J Am Geriatr Soc. 01. 2009;57(1):89-93. [pmid: 19054181].
1865 Shumway-Cook A, Guralnik JM, Phillips CL, et al. Age-associated declines in complex walking task performance: the Walking InCHIANTI toolkit. J Am Geriatr Soc. 01. 2007;55(1):58-65. [pmid: 17233686].