# Literature Search

Ovid Technologies, Inc., email service
Search for: limit 9 to (English language and humans and yr=“1999–Current”)
Results: 1–52

Database: Ovid MEDLINE(R) <1950 to July Week 3 2009>
Search Strategy:
1 | exp geriatric assessment/ (12945)
2 | exp health services for the aged/ (12535)
3 | (common$ adj3 syndrome$).mp. (4417)
4 | 1 or 2 (24542)
5 | 4 and 3 (19)
6 | geriatric syndrome$.mp. (239)
7 | common$.mp. (752036)
8 | 6 and 7 (58)
9 | 8 or 5 (65)
10 | limit 9 to (English language and humans and yr=“1999-Current”) (52)

Database: Ovid MEDLINE(R) <1950 to July Week 3 2009>
Search Strategy:
1 | exp health services for the aged/ (12535)
2 | exp geriatric assessment/ (12945)
3 | exp aged/ (1824150)
4 | exp aging/ (161093)
5 | 1 or 2 or 3 or 4 (1931689)
6 | syndrome/ or syndrome$.mp. (769191)
7 | exp cognition disorders/ (40357)
8 | exp sleep disorders/ (45845)
9 | exp frail elderly/ (4572)
10 | exp nutrition disorders/ (190734)
11 | exp gait disorders, neurologic/ (2115)
12 | exp urinary incontinence/ (22048)
13 | exp fecal incontinence/ (6234)
14 | exp vision disorders/ (48713)
15 | exp hearing disorders/ (58328)
16 | exp depression/ (52923)
17 | exp delirium, dementia, amnestic, cognitive disorders/ (132607)
18 | exp dizziness/ (2746)
19 | exp syncope/ (8746)
20 | exp osteoporosis/ (34707)
21 | 11 or 7 or 9 or 17 or 12 or 20 or 15 or 14 or 8 or 18 or 19 or 16 or 10 or 13 (587526)
22 | 6 or 21 (1285830)
23 | 22 and 5 (247880)
24 | exp age factors/ (339878)
25 | exp sex factors/ (171269)
26 | exp Comorbidity/ (40572)
27 | 25 or 24 or 26 (468826)
28 | 27 and 23 (24028)
29 | exp epidemiologic studies/ (1154895)
30 | 28 and 29 (7943)
31 | (aging or aged or elder$ or geriatric or gerontol$ or older$).ti. (167258)
32 | 30 and 31 (1566)
33 | limit 32 to (English language and humans and yr=“1999-Current”) (1104)

Database: Ovid MEDLINE(R) <1950 to July Week 3 2009>
Search Strategy:
1 | exp health services for the aged/ (12535)
2 | exp geriatric assessment/ (12945)
3 | exp aged/ (1824150)
4 | exp aging/ (161093)
5 | 1 or 2 or 3 or 4 (1931689)
6 | syndrome/ or syndrome$.mp. (769191)
7 | exp cognition disorders/ (40357)
8 | exp sleep disorders/ (45845)
9 | exp frail elderly/ (4572)
10 | exp nutrition disorders/ (190734)
11 | exp gait disorders, neurologic/ (2115)
12 | exp urinary incontinence/ (22048)
13 | exp fecal incontinence/ (6234)
14 | exp vision disorders/ (48713)
15 | exp hearing disorders/ (58328)
16 | exp depression/ (52923)
17 | exp delirium, dementia, amnestic, cognitive disorders/ (132607)
18 | exp dizziness/ (2746)
19 | exp syncope/ (8746)
20 | exp osteoporosis/ (34707)
21 | 11 or 7 or 9 or 17 or 12 or 20 or 15 or 14 or 8 or 18 or 19 or 16 or 10 or 13 (587526)
22 | 6 or 21 (1285830)
23 | 22 and 5 (247880)
24 | exp “Quality of Life”/ (76778)
25 | exp “Activities of Daily Living”/ (37977)
26 | exp Morbidity/ (260042)
27 | exp mortality/ (209930)
28 | 27 or 25 or 24 or 26 (551893)
29 | 28 and 23 (31277)
30 | limit 29 to (English language and humans and yr=“1999-Current”) (20039)
31 | exp epidemiologic studies/ (1154895)
32 | 30 and 31 (9581)

Database: Ovid MEDLINE(R) <1950 to July Week 3 2009>
Search Strategy:
1 | exp geriatric assessment/ (12945)
2 | exp predictive value of tests/ (93910)
3 | exp Survival Analysis/ (100091)
4 | exp survival rate/ (90889)
5 | exp mortality/ (209930)
6 | exp forecasting/ (59830)
7 | 6 or 4 or 3 or 2 or 5 (436400)
8 | 1 and 7 (1483)
9 | exp epidemiologic studies/ (1154895)
10 | 8 and 9 (822)
11 | exp Mass Screening/ (95484)
12 | screen$.mp. (347938)
13 | target$.mp. (477594)
14 | predictor$.mp. (122940)
15 | 11 or 13 or 12 or 14 (918257)
16 | 10 and 15 (332)
17 | limit 16 to (English language and humans) (323)

July 30, 2009
Strings | Number Retrieved
“Comprehensive Geriatric Assessment” | 318
Syndrome AND “Investigative Techniques”[Mesh] AND “Geriatric Assessment”[Mesh] Limits: Humans, English | 222
Screening AND Survival AND “Investigative Techniques”[Mesh] AND “Geriatric Assessment”[Mesh] Limits: Humans, English | 454
Frailty and mortality limits: Humans, English | 343
“Investigative Techniques”[Mesh] AND “Geriatric Assessment”[Mesh] AND #42 Limits: Humans, Journal Article, English | 735
“Geriatric Assessment”[Mesh] AND #42 AND Prevalence AND Cohort Limits: Humans, Journal Article, English | 104
Fatigue Syndrome AND Frailty NOT Review Limits: Humans, Journal Article, English | 7
Search: Prediction, Mortality, Elderly, Cohort, Geriatric NOT Review Limits: Humans, Journal Article, English | 21

Ovid Technologies, Inc., email service
Search for: 1 and 12
Results: 1

Database: Ovid MEDLINE(R) <1950 to July Week 3 2009>
Search Strategy:
1 | exp geriatric assessment/ (12945)
2 | exp “Predictive Value of Tests”/ (93910)
3 | 1 and 2 (598)
4 | limit 3 to (English language and humans and yr=“1990-Current”) (571)
5 | limit 4 to (research support, NIH, extramural or research support, NIH, intramural or research support, non US gov’t or research support, US gov’t, non PHS or research support, US gov’t, PHS) (347)
6 | 4 not 5 (224)
7 | exp statistics as topic/ (1363257)
8 | 7 and 5 (276)
9 | sn.fs. (330737)
10 | 9 and 5 (120)
11 | 8 or 10 (289)
12 | exp mass screening/ (95484)
13 | 1 and 12 (698)

Ovid Technologies, Inc., email service
Search for: from 31 [limit 30 to (English language and humans)] keep 1–17
Results: 1–17

Database: Ovid MEDLINE(R) <1950 to July Week 4 2009>
Search Strategy:
1 | exp frail elderly/ (4580)
2 | exp cognition disorders/ (40416)
3 | exp urinary incontinence/ (22064)
4 | exp fecal incontinence/ (6249)
5 | 4 or 3 (26864)
6 | exp sleep disorders/ (45899)
7 | exp malnutrition/ (78569)
8 | exp gait disorders, neurologic/ (2121)
9 | 8 or 6 or 7 or 2 or 5 (192419)
10 | 1 and 9 (325)
11 | 8 or 6 or 1 or 7 or 5 (157604)
12 | 11 and 2 (1346)
13 | 8 or 6 or 1 or 7 or 2 (170158)
14 | 13 and 5 (348)
15 | 8 or 1 or 7 or 2 or 5 (151675)
16 | 6 and 15 (900)
17 | 8 or 6 or 1 or 2 or 5 (118535)
18 | 7 and 17 (430)
19 | 6 or 1 or 7 or 2 or 5 (194716)
20 | 8 and 19 (163)
21 | 18 or 16 or 10 or 12 or 20 or 14 (1737)
22 | exp mass screening/ or screen$.mp. (353711)
23 | 22 and 21 (82)
24 | exp predictive value of tests/ (94078)
25 | 24 and 23 (6)
26 | exp mortality/ or exp morbidity/ (452142)
27 | exp survival analysis/ (100261)
28 | 27 or 26 (531928)
29 | 28 and 23 (13)
30 | 25 or 29 (19)
31 | limit 30 to (English language and humans) (17)
32 | from 31 keep 1–17 (17)
33 | from 32 keep 1–17 (17)

Database: Ovid MEDLINE(R) <1950 to July Week 4 2009>
Search Strategy:
1 | exp geriatric assessment/ (12973)
2 | exp cost-benefit analysis/ (46253)
3 | 1 and 2 (113)
4 | exp health services for the aged/ec [Economics] (1833)
5 | exp mass screening/ or screen$.mp. (353711)
6 | 4 and 5 (31)
7 | exp health services for the aged/ (12540)
8 | 7 and 5 (372)
9 | ec.fs. (258305)
10 | 9 or 2 (267756)
11 | 8 and 10 (37)
12 | 6 or 11 or 3 (149)
13 | limit 12 to (English language and humans) (131)

July 31
Strings | Number Retrieved
exp Geriatric Assessment/sn, cl, mt [Statistics & Numerical Data, Classification, Methods] AND exp Cohort Studies/ AND exp United States/ep [Epidemiology] | 34
*”quality of life”/ or exp “health care quality, access, and evaluation”/ AND exp Geriatric Assessment/sn, cl, mt [Statistics & Numerical Data, Classification, Methods] AND exp United States/ep [Epidemiology] | 126
September 24
“Disability Evaluation”[Mesh] AND (“United States”[Mesh] OR “United States Agency for Healthcare Research and Quality”[Mesh]) Limits: Humans, Journal Article, English, Aged: 65+ years, selected 201 | 578
September 29
Related Articles for PubMed (Select 15051585) | 145
“The Yale Health and Aging Study” | 51
“The Framingham Disability Study” | 39
October 13, 2009
“Polypharmacy”[Mesh] AND Medicare | 29
“Polypharmacy”[Mesh] AND Cohort Limits: Humans, Journal Article, English, Aged: 65+ years, 80 and over: 80+ years | 65
October 21, 2009
“Models, Economic”[Mesh] AND “Life Expectancy”[Mesh] NOT Review Limits: Humans, English, Aged: 65+ years | 40
Select 5 document(s) | 5
Search Kuntz KM[author] Limits: Humans, English, Aged: 65+ years | 51
November 23, 2009
Definition: Frailty Limits: Humans, Journal Article, English, Aged: 65+ years, 80 and over: 80+ years | 55
February 10, 2010
Search: Prevalence, Frailty, Cohort Limits: Journal Article, English | 138
Select 30 document(s) | 30
Related Articles for PubMed (Select 19196644) | 1099
Search: Prevalence, “Chronic Inflammation,” Cohort Limits: Humans, Journal Article, English, Aged: 65+ years, 80 and over: 80+ years | 38
Select 4 document(s) | 4
Related articles for PubMed (Select 17685096) | 458
Search: Prevalence, Malnutrition, Cohort, Limits: Humans, Journal Article, English, Aged: 65+ years, 80 and over: 80+ years | 294
March 17, 2010
Search: Allostatic Limits: Humans, Journal Article, English, Aged: 65+ years, 80 and over: 80+ years | 36