# Appendixes

Appendix A Literature Search

Appendix B Excluded Studies

Appendix C Technical Expert Panel Members and Affiliations

Appendix D Abstraction Forms

Appendix E Evidence Tables