# Acronyms/Abbreviations

3MSE: Modified Mini-Mental State Examination
ADLs: Activities of daily living
AHEAD: Asset and Health Dynamics Among the Oldest Old
AHRQ: Agency for Healthcare Research and Quality
AUC: Area under the receiver operating characteristic curve
BADLs: Basic activities of daily living
BISEP: Burden of Illness Score for Elderly Persons
BMI: Body mass index
CDC: Centers for Disease Control and Prevention
CHS: Cardiovascular Health Study
CI: Confidence interval
COL: Colonoscopy
CRP: C-reactive protein
DCBE: Double-contrast barium enema
DSM: Diagnostic and Statistical Manual of Mental Disorders
ED: Emergency department
EWGSOP: European Working Group on Sarcopenia in Older People
F-DNA: Fecal DNA testing
FOBT: Fecal occult blood testing
GMS: Geriatric Mental Status Examination
Health ABC: Health Aging and Body Composition
HR: Hazard ratio
IADLs: Instrumental activities of daily living
IL: Interleukin
LSOA: Longitudinal Study of Aging
MHCPS: Massachusetts Health Care Panel Study
MeSH: Medical subject headings
MMSE: Mini-Mental State Examination
MNA: Mini Nutritional Assessment
NHANES: National Health and Nutrition Examination Survey
OR: Odds ratio
PAQUID: Personnes Agées QUID
PAR: Population attributable risk
PICOTS: Population, Intervention, Comparator, Outcomes, Time, and Settings
PEP: Precipitating Events Project
RCT: Randomized controlled trial
RDW: Red cell distribution width
RR: Relative risk
SHARE: Survey of Health, Aging, and Retirement in Europe
SIG: Flexible sigmoidoscopy
SPMSQ: Short Portable Mental Status Questionnaire
TEP: Technical expert panel
TICS: Telephone Interview of Cognitive Status
USPSTF: U.S. Preventive Services Task Force