# Results

## Overview

The results are presented by specific aim. Each section refers to a table that presents the expected number of false-positives (defined as women with abnormal screening results and normal histology), colposcopies, cases of CIN2-3, cases of cancer, and cancer deaths per 1,000 women. The outcomes in these tables are presented with two significant digits so that the outcome per 100,000 women can also be determined. The base-case results for Specific Aim 1 and Sub-Aim 1 are summarized in the accompanying tables and figures. Each table presents only the strategies that are identified as efficient, in the sense that they provide a reasonable trade-off between the burden and benefits of screening. Each figure presents the same strategies using an efficiency curve; the metric used for each curve is colposcopies per (undiscounted) life-year. Three different sets of results are presented for Specific Aim 2. Key sensitivity analyses are presented as outlined previously.

## Summary of Results for Specific Aim 1

Tables 7 through 9 and Figures 1 and 2 summarize the results for the base-case analyses for Specific Aim 1, regarding the age at which to begin screening. Tables 7 and 8 present estimates of expected false-positive test results, colposcopies, CIN2-3 cases, cancer cases, and cancer deaths associated with screening in 1-year age increments, beginning at age 15 years and ending at age 25 years. The results are grouped according to screening interval (every 1 year [q1], 2 years [q2], 3 years [q3], and 5 years [q5]). Tables 7 and 8 show results over a short time horizon (cohort is followed until age 30 years) and lifetime horizon (cohort is followed until age 100 years). When comparing by age across the row, increasing age at first screening is generally associated with fewer false-positive test results, fewer colposcopies, and fewer CIN2-3 cases, but more cancer cases and cancer deaths. There are some fluctuations between successive ages due to differences based on screening interval and age at which to end screening. However, some of the fluctuation in the estimates is also due to ASCCP guidelines,33 which allow for repeated screening in women younger than age 21 years with abnormal cytology results. If all adolescent women are assumed to attend colposcopy, the outcomes are more consistent by age (data not shown). The inclusion of this aspect of the guidelines in the decision model may also explain the shape of the curve for false-positive test results presented in Figure 1, in which the largest number of false-positive test results occurs in adolescents younger than age 21 years (range per 1,000, 190 at age 20 years to 232 at age 15 years). This age group also has the lowest number of expected cancer cases (range per 1,000, <1 [or 16 to 22 cancer cases per 100,000]). In contrast, the number of false-positive test results is lower (range per 1,000, 101 at age 25 years to 161 at age 22 years) with each successive year that screening is delayed beyond age 21 years (compared to beginning at age 21 years). However, as shown in Figure 1, the number of expected cancer cases begins to rise (range per 100,000, 31 at age 22 years to 58 at age 25 years) with each successive year that screening is delayed beyond age 21 years.

Table 7 Sensitivity Analysis Showing Expected False-Positives, Colposcopies, CIN2-3 Cases, Cancer Cases, and Cancer Deaths Associated With Screening Beginning at Age 15 Years and Increased in 1-Year Increments to Age 25 Years, Among Women Followed to Age 30 Years*

Strategy | | Age 15 | Age 16 | Age 17 | Age 18 | Age 19 | Age 20 | Age 21 | Age 22 | Age 23 | Age 24 | Age 25
Cytology with repeat cytology for ASC-US
q5 | False Positives | 40.62 | 51.90 | 51.90 | 51.82 | 51.17 | 31.57 | 42.86 | 42.88 | 42.80 | 42.17 | 21.71
q3 | False Positives | 82.25 | 82.16 | 82.40 | 73.20 | 73.12 | 73.38 | 64.20 | 64.13 | 63.53 | 42.99 | 42.72
q2 | False Positives | 132.68 | 113.06 | 123.66 | 104.04 | 114.66 | 95.07 | 105.74 | 85.27 | 84.63 | 63.99 | 63.19
q1 | False Positives | 232.42 | 223.87 | 215.32 | 206.80 | 198.29 | 189.85 | 181.18 | 161.29 | 141.25 | 121.07 | 100.88
q5 | Colposcopies | 68.59 | 100.23 | 101.26 | 102.16 | 102.40 | 59.53 | 91.09 | 91.94 | 92.60 | 92.52 | 47.99
q3 | Colposcopies | 152.67 | 153.66 | 154.97 | 143.61 | 144.55 | 145.76 | 134.25 | 134.98 | 134.99 | 92.50 | 92.79
q2 | Colposcopies | 244.44 | 204.84 | 235.41 | 195.78 | 226.27 | 186.56 | 217.03 | 176.12 | 176.04 | 176.45 | 134.37
q1 | Colposcopies | 411.63 | 403.07 | 394.50 | 385.89 | 377.24 | 368.59 | 360.61 | 322.27 | 283.84 | 245.27 | 206.61
q5 | CIN 2-3s | 9.06 | 10.56 | 11.83 | 13.04 | 14.15 | 9.04 | 10.45 | 11.53 | 12.49 | 13.29 | 7.47
q3 | CIN 2-3s | 14.09 | 15.55 | 16.93 | 14.08 | 15.47 | 16.72 | 13.71 | 14.90 | 15.87 | 12.17 | 12.95
q2 | CIN 2-3s | 18.90 | 17.36 | 18.90 | 17.31 | 18.75 | 17.05 | 18.39 | 16.46 | 17.50 | 15.19 | 15.97
q1 | CIN 2-3s | 21.08 | 21.08 | 21.05 | 20.98 | 20.84 | 20.65 | 20.41 | 20.02 | 19.50 | 18.84 | 18.00
q5 | Cancer Cases | 0.42 | 0.42 | 0.46 | 0.50 | 0.57 | 0.42 | 0.43 | 0.49 | 0.56 | 0.65 | 0.52
q3 | Cancer Cases | 0.35 | 0.39 | 0.43 | 0.35 | 0.40 | 0.45 | 0.39 | 0.46 | 0.54 | 0.52 | 0.62
q2 | Cancer Cases | 0.31 | 0.29 | 0.31 | 0.30 | 0.33 | 0.33 | 0.37 | 0.40 | 0.48 | 0.53 | 0.64
q1 | Cancer Cases | 0.16 | 0.16 | 0.16 | 0.17 | 0.19 | 0.22 | 0.25 | 0.31 | 0.39 | 0.48 | 0.58
q5 | Cancer Deaths | 0.06 | 0.06 | 0.06 | 0.06 | 0.05 | 0.06 | 0.06 | 0.07 | 0.07 | 0.07 | 0.08
q3 | Cancer Deaths | 0.05 | 0.05 | 0.05 | 0.05 | 0.05 | 0.05 | 0.05 | 0.06 | 0.07 | 0.08 | 0.09
q2 | Cancer Deaths | 0.03 | 0.03 | 0.03 | 0.04 | 0.04 | 0.04 | 0.05 | 0.06 | 0.07 | 0.08 | 0.09
q1 | Cancer Deaths | 0.02 | 0.02 | 0.02 | 0.02 | 0.02 | 0.03 | 0.03 | 0.04 | 0.06 | 0.08 | 0.09

Table 8 Sensitivity Analysis Showing Expected False-Positives, Colposcopies, CIN2-3 Cases, Cancer Cases, and Cancer Deaths Associated With Screening Beginning at Age 15 Years and Increased in 1-Year Increments to Age 25 Years, Among Women Followed for a Lifetime^*^

Strategy | | Age 15 | Age 16 | Age 17 | Age 18 | Age 19 | Age 20 | Age 21 | Age 22 | Age 23 | Age 24 | Age 25
Cytology with repeat cytology for ASC-US
q5 | False Positives | 220.74 | 223.01 | 220.20 | 217.50 | 214.84 | 211.69 | 213.97 | 211.17 | 208.49 | 205.85 | 201.86
q3 | False Positives | 367.97 | 362.65 | 352.67 | 358.93 | 353.61 | 343.65 | 349.92 | 344.62 | 333.82 | 328.80 | 323.33
q2 | False Positives | 542.21 | 529.73 | 533.19 | 520.72 | 524.19 | 511.74 | 515.26 | 501.94 | 494.23 | 480.77 | 472.93
q1 | False Positives | 1002.73 | 994.17 | 985.63 | 977.09 | 968.58 | 960.13 | 951.45 | 931.62 | 911.68 | 891.64 | 871.61
q5 | Colposcopies | 481.05 | 492.49 | 487.71 | 483.13 | 478.74 | 471.99 | 483.36 | 478.44 | 473.65 | 469.01 | 461.00
q3 | Colposcopies | 776.54 | 766.76 | 746.04 | 767.48 | 757.65 | 736.59 | 758.16 | 748.16 | 725.97 | 717.04 | 706.79
q2 | Colposcopies | 1,110.92 | 1,085.93 | 1,101.89 | 1,076.87 | 1,092.75 | 1,067.65 | 1,083.52 | 1,057.27 | 1,042.80 | 1,016.43 | 1,001.77
q1 | Colposcopies | 1,982.10 | 1,973.54 | 1,964.96 | 1,956.35 | 1,947.67 | 1,939.00 | 1,931.00 | 1,892.74 | 1,854.45 | 1,816.09 | 1,777.71
q5 | CIN 2-3s | 67.38 | 66.10 | 66.66 | 67.12 | 67.56 | 67.36 | 66.01 | 66.39 | 66.64 | 66.81 | 66.25
q3 | CIN 2-3s | 80.55 | 80.87 | 79.80 | 80.53 | 80.80 | 79.61 | 80.21 | 80.30 | 78.88 | 79.22 | 79.03
q2 | CIN 2-3s | 88.01 | 87.64 | 88.00 | 87.59 | 87.86 | 87.35 | 87.52 | 86.85 | 86.89 | 86.05 | 85.92
q1 | CIN 2-3s | 92.14 | 92.14 | 92.11 | 92.04 | 91.91 | 91.72 | 91.50 | 91.25 | 90.94 | 90.56 | 90.08
q5 | Cancer Cases | 12.70 | 12.67 | 12.65 | 12.66 | 12.73 | 12.70 | 12.69 | 12.69 | 12.74 | 12.85 | 12.89
q3 | Cancer Cases | 8.45 | 8.47 | 8.66 | 8.45 | 8.48 | 8.62 | 8.50 | 8.55 | 8.73 | 8.70 | 8.82
q2 | Cancer Cases | 5.73 | 5.73 | 5.73 | 5.73 | 5.75 | 5.77 | 5.80 | 5.84 | 5.93 | 6.01 | 6.14
q1 | Cancer Cases | 2.41 | 2.41 | 2.41 | 2.42 | 2.44 | 2.47 | 2.50 | 2.56 | 2.65 | 2.75 | 2.86
q5 | Cancer Deaths | 2.70 | 2.70 | 2.69 | 2.69 | 2.70 | 2.70 | 2.71 | 2.70 | 2.71 | 2.73 | 2.75
q3 | Cancer Deaths | 1.54 | 1.54 | 1.59 | 1.54 | 1.54 | 1.57 | 1.55 | 1.56 | 1.60 | 1.60 | 1.62
q2 | Cancer Deaths | 0.90 | 0.91 | 0.90 | 0.91 | 0.91 | 0.92 | 0.92 | 0.94 | 0.95 | 0.98 | 1.00
q1 | Cancer Deaths | 0.31 | 0.31 | 0.31 | 0.31 | 0.31 | 0.32 | 0.32 | 0.33 | 0.35 | 0.37 | 0.40

* Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared. Cases are per 1,000 women.

Table 9 Base-Case Analysis^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Age 25, q5 | 461 | 461 | 69178.79 | 162.49 | 3
Age 20, q5 | 472 | 11 | 69181.23 | 2.44 | 5
Age 22, q5 | 478 | 6 | 69182.04 | 0.81 | 7
Age 24, q3 | 717 | 239 | 69210.25 | 28.21 | 8
Age 20, q3 | 737 | 20 | 69212.16 | 1.91 | 10
Age 20, q2 | 1068 | 331 | 69230.20 | 18.04 | 18
Age 18, q2 | 1077 | 9 | 69230.60 | 0.40 | 23
Age 18, q1 | 1956 | 879 | 69247.39 | 16.79 | 52
Age 17, q1 | 1965 | 9 | 69247.48 | 0.09 | 100
Age 16, q1 | 1974 | 9 | 69247.51 | 0.03 | 300
Age 15, q1 | 1982 | 8 | 69247.51 | <0.01 | 1990

* Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) associated with screening beginning at different ages (varying in 1-year increments from age 15 to 25 years). Screening intervals of 1 (q1), 2 (q2), 3 (q3), and 5 years (q5) are compared.

Figure 1 Expected False-Positives and Cancer Cases for Adolescent Women Who Begin Screening at Ages Varying From 15 to 25 Years and Are Followed to Age 30 Years*

*Results presented assume an annual screening interval and are calculated per 1,000 women.

Figure 1 shows the expected false-positives and cancer cases per 1000 adolescent women who begin screening at ages varying from 15 to 25 years and who are followed to age 30 years. The number of cancer and false-positive cases (per 1000) are presented on the y and z axes, respectively. The x-axis shows the age in years in which screening begins,varying from 15 to 25 years. The number of cancer cases varies from 0.16 per 1000 at age 15 years to 0.58 per 1000 at age 25 years. The number of false-positives per 1000 varies from 232.42 for screening beginning at age 15 to 100.88 for screening beginning at age 25 years.

Figure 2 Efficiency Curve Comparing Strategies Differing By Age at First Screening*

*Strategies presented are those identified as efficient using incremental colposcopies per life-year.

Figure 2 presents an efficiency curve comparing strategies that differ by age at first screening. The average number of colposcopies per 1000 women varies from 0 to 2250 along the x-axis. The average number of life-years varies from 69,000 to 69,300 per 1000 women. Strategies are compared by ranking them in order of average number of colposcopies per 1000 women. Adjacent strategies are then compared using an incremental colposcopy per life-year ratio, which is calculated using the difference in colposcopies divided by the difference in life-years. The strategies on the curve are those that are not dominated. A strategy that is “dominated” is eliminated from consideration because it is associated with more colposcopies and less effectiveness or fewer colposcopies but a higher colposcopy per life-year ratio than an adjacent strategy.

In terms of screening interval, for both time horizons the patterns are similar: the number of false-positive test results and colposcopies increase as screening frequency increases, whereas the number of CIN2-3 cases, cancer cases, and cancer deaths decrease. Of the two time horizons, the lifetime horizon shows fewer fluctuations within successive age intervals. For both horizons, a screening interval of every year is associated with the highest number of colposcopies, exceeding one per woman screened for the lifetime horizon. Compared to screening beginning at age 21 years and conducted every 3 years (which is part of the current USPSTF recommendations), screening every year beginning at age 21 years results in more (1,931 vs. 758 per 1,000) colposcopies but is also associated with a reduction (approximately 3 vs. 9 per 1,000) in cancer cases. Screening every 2 years is associated with approximately 1,084 colposcopies and 6 cancer cases per 1,000 women. Taken together, these patterns can be used to explain the base-case findings presented in Table 9 and summarized in Figure 2. If the strategies that fall on the steepest part of the efficiency curve are assumed to represent a reasonable trade-off between colposcopies and life expectancy gained, then strategies of screening every 3 to 5 years beginning in the early 20s are more attractive, compared to those strategies that are identified as efficient but are based on screening every year in the teens. A strategy of screening every 5 years beginning at age 22 years is also more effective, but is associated with more colposcopies than screening every 5 years beginning at age 20 years. This is because the ASCCP guidelines for triage to immediate colposcopy start at age 21 years.33 Even though women aged 20 years have one more opportunity for screening (14 vs. 13, when screened through age 85 years), this additional screening occurs before age 21 years. As a result, those with abnormal results undergo repeat cytology instead of immediate referral to colposcopy; all women with abnormal test results are not referred for immediate colposcopy until age 26 years. This aspect of the guidelines may also explain why the currently recommended strategy of the USPSTF is not identified as an efficient strategy—the number of colposcopies is high, but fewer cancer cases are prevented at age 21 years compared to earlier ages.

### CIN2 as a Percentage of CIN2-3

Table 10 uses different outcomes than other tables included in this report. Table 10 presents the total number of cases of CIN2-3 (per 1,000 women) over the shorter time horizon (until age 30 years), and the percentage of CIN2-3 cases estimated to actually be CIN2.

Table 10 Percentage of CIN2-3 Cases Estimated to Be CIN2^*^

Strategy | Total CIN2-3 (per 1,000) | % CIN2
Age 25, q5 | 7.47 | 48
Age 20, q5 | 9.04 | 71
Age 22, q5 | 11.53 | 71
Age 24, q3 | 12.17 | 71
Age 20, q3 | 16.72 | 71
Age 20, q2 | 17.05 | 71
Age 18, q2 | 17.31 | 73
Age 18, q1 | 20.98 | 73
Age 17, q1 | 21.05 | 73
Age 16, q1 | 21.08 | 73
Age 15, q1 | 21.08 | 73

* Strategies listed are those identified as efficient in the base-case analysis.

### Key Sensitivity Analyses

Tables 11 through 16 present the results of the sensitivity analyses. The range of sensitivity analyses confirm the base-case findings, namely that screening frequently in the teens is associated with a large number of colposcopies, but relatively small gains in life expectancy. Results were similar to the base case when the sensitivity and specificity of colposcopy and biopsy were varied or different conditional probabilities of cytology results given underlying histology were used (data not shown). As shown in Table 10, approximately 70 percent of high-grade disease detected in this younger age group may be CIN2 rather than CIN3. This suggests that disease detected in these early years may be very likely to regress and that overdiagnosis and treatment of these lesions are potential concerns. The sensitivity analysis that uses screening cytology tests per life-year also shows that screening in the teens is associated with a high number of cytology tests per life-year gained. Finally, results from the revised natural history model, in which higher disease regression and lower progression is modeled, suggests that, if correct, screening could potentially be delayed past the early 20s.

#### 1 Natural History

Table 11 Sensitivity Analysis Varying Multiple Natural History Parameters^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69074.37
Age 25, q5 | 598 | 598 | 69191.45 | 117.08 | 5
Age 25, q3 | 874 | 276 | 69216.05 | 24.60 | 11
Age 24, q3 | 885 | 11 | 69216.57 | 0.52 | 21
Age 25, q2 | 1187 | 302 | 69230.39 | 13.82 | 22
Age 24, q2 | 1202 | 15 | 69230.97 | 0.58 | 26
Age 20, q2 | 1256 | 54 | 69232.06 | 1.09 | 50
Age 18, q2 | 1266 | 10 | 69232.27 | 0.21 | 48
Age 25, q1 | 1983 | 717 | 69244.98 | 12.71 | 56
Age 24, q1 | 2023 | 40 | 69245.52 | 0.54 | 74
Age 23, q1 | 2063 | 40 | 69246.00 | 0.48 | 83
Age 18, q1 | 2169 | 106 | 69247.20 | 1.20 | 88
Age 17, q1 | 2177 | 8 | 69247.25 | 0.05 | 160
Age 16, q1 | 2186 | 9 | 69247.27 | 0.02 | 450
Age 15, q1 | 2195 | 9 | 69247.28 | 0.01 | 900

* Refer to Appendix B for details.

#### 2 Screening Cytology Tests per Life-Year (Undiscounted)

Table 12 Sensitivity Analysis Showing Expected Screening Cytology Tests, Incremental Cytology Tests, Life-Years, Incremental Life-Years, and Incremental Cytology Tests per Life-Year Associated With Screening Beginning at Different Ages^*^

Strategy | Screening Cytology tests | Incremental Screening Cytology test | Life Years (LYs) | Incremental LYs | Incremental Cytology tests per LY
No intervention | 0 | | 69016.30
Age 25, q5 | 9834 | 9834 | 69178.79 | 162.49 | 61
Age 23, q5 | 10139 | 305 | 69181.25 | 2.46 | 124
Age 22, q5 | 10266 | 127 | 69182.04 | 0.79 | 161
Age 24, q3 | 15998 | 5732 | 69210.25 | 28.21 | 203
Age 22, q3 | 16747 | 749 | 69212.10 | 1.85 | 405
Age 21,q3 | 16999 | 252 | 69212.69 | 0.59 | 427
Age 24, q2 | 23406 | 6407 | 69227.31 | 14.62 | 438
Age 22, q2 | 24406 | 1000 | 69229.32 | 2.01 | 498
Age 20, q2 | 25402 | 996 | 69230.20 | 0.88 | 1132
Age 22, q1 | 45386 | 19984 | 69245.87 | 15.67 | 1275
Age 21, q1 | 46333 | 947 | 69246.58 | 0.71 | 1334
Age 20, q1 | 47277 | 944 | 69246.92 | 0.34 | 2776
Age 19, q1 | 48219 | 942 | 69247.21 | 0.29 | 3248
Age 18, q1 | 49162 | 943 | 69247.39 | 0.18 | 5239
Age 17, q1 | 50105 | 943 | 69247.48 | 0.09 | 10478
Age 16, q1 | 51049 | 944 | 69247.51 | 0.03 | 31467
Age 15, q1 | 51993 | 944 | 69247.51 | <.01 | 219524

* Per 1,000 women. Screening varies in 1-year increments from age 15 to 25 years. Screening intervals of 1 (q1), 2 (q2), 3 (q3), and 5 years (q5) are compared.

#### 3 Adherence to Screening <100%^61^

Table 13 Sensitivity Analysis Varying Adherence to Screening^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Age 25, q5 | 207 | 207 | 69120.83 | 104.53 | 2
Age 20, q5 | 212 | 5 | 69122.39 | 1.56 | 3
Age 25, q3 | 331 | 119 | 69156.84 | 34.45 | 3
Age 24, q2 | 473 | 142 | 69183.18 | 26.34 | 5
Age 20, q2 | 494 | 21 | 69185.65 | 2.47 | 9
Age 25, q1 | 851 | 357 | 69217.93 | 32.28 | 11
Age 24, q1 | 867 | 16 | 69218.92 | 0.99 | 16
Age 23, q1 | 884 | 17 | 69219.86 | 0.94 | 18
Age 19, q1 | 924 | 40 | 69222.01 | 2.15 | 19
Age 18, q1 | 928 | 4 | 69222.19 | 0.18 | 22
Age 17, q1 | 931 | 3 | 69222.28 | 0.09 | 33
Age 16, q1 | 935 | 4 | 69222.32 | 0.04 | 100
Age 15, q1 | 939 | 4 | 69222.32 | <0.01 | 627

* Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years , incremental life-years, and incremental colposcopies per life-year (ICLY) associated with screening beginning at different ages (varying in 1-year increments from age 15 to 25 years). Screening intervals of 1 (q1), 2 (q2), 3 (q3), and 5 years (q5) are compared.

#### 4 Adherence to Screening <100%: NSFG Survey58

Table 14 Sensitivity Analysis Varying Adherence to Screening Using Estimates From the National Survey of Family Growth8,*

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Age 25, q5 | 301 | 301 | 69140.21 | 123.91 | 2
Age 20, q5 | 308 | 7 | 69142.23 | 2.02 | 3
Age 24, q3 | 470 | 162 | 69176.70 | 34.47 | 5
Age 24, q2 | 669 | 199 | 69201.39 | 24.69 | 8
Age 20, q2 | 701 | 32 | 69204.15 | 2.76 | 12
Age 18, q2 | 705 | 4 | 69204.40 | 0.25 | 16
Age 25, q1 | 1167 | 462 | 69228.78 | 24.38 | 19
Age 24, q1 | 1192 | 25 | 69230.03 | 1.25 | 20
Age 23, q1 | 1220 | 28 | 69231.27 | 1.24 | 23
Age 18, q1 | 1287 | 67 | 69233.65 | 2.38 | 28
Age 17, q1 | 1289 | 2 | 69233.69 | 0.04 | 50
Age 16, q1 | 1290 | 1 | 69233.70 | 0.01 | 100
Age 15, q1 | 1291 | 1 | 69233.70 | <.01 | 603

* Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) associated with screening beginning at different ages (varying in 1-year increments from age 15 to 25 years). Screening intervals of 1 (q1), 2 (q2), 3 (q3), and 5 years (q5) are compared.

#### 5 Highest Estimates of Sensitivity and Lowest Estimates of Specificity

Table 15 Sensitivity Analysis in Which the Highest Estimates of Sensitivity and Lowest Estimates of Specificity Are Assumed^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Age 25, q5 | 1299 | 1299 | 69211.02 | 194.72 | 7
Age 20, q5 | 1333 | 34 | 69213.66 | 2.64 | 13
Age 20, q3 | 2120 | 787 | 69235.38 | 21.72 | 36
Age 19, q3 | 2179 | 59 | 69236.15 | 0.77 | 77
Age 18, q2 | 3139 | 960 | 69246.04 | 9.89 | 97
Age 17, q1 | 5369 | 2230 | 69253.35 | 7.31 | 305
Age 16, q1 | 5391 | 22 | 69253.37 | 0.02 | 1100
Age 15, q1 | 5413 | 22 | 69253.38 | 0.01 | 2200

* Sensitivity for CIN2+ is 0.772 instead of 0.569; specificity for CIN2+ is 0.847 instead of 0.945; sensitivity for ASCUS is 0.956 instead of 0.762; specificity for ASCUS is 0.475 instead of 0.638. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) associated with screening beginning at different ages (varying in 1-year increments from age 15 to 25 years). Screening intervals of 1 (q1), 2 (q2), 3 (q3), and 5 years (q5) are compared.

#### 6 Lowest Estimates of Sensitivity and Highest Estimates of Specificity

Table 16 Sensitivity Analysis in Which the Lowest Estimates of Sensitivity and Highest Estimates of Specificity Are Assumed^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Age 22, q5 | 106 | 106 | 69096.58 | 80.28 | 1
Age 24, q3 | 158 | 52 | 69126.49 | 29.92 | 2
Age 25, q1 | 375 | 217 | 69194.77 | 68.28 | 3
Age 23, q1 | 390 | 15 | 69197.66 | 2.88 | 5
Age 19, q1 | 407 | 17 | 69200.16 | 2.50 | 7
Age 18, q1 | 409 | 2 | 69200.33 | 0.17 | 12
Age 17, q1 | 410 | 1 | 69200.42 | 0.09 | 11
Age 16, q1 | 412 | 2 | 69200.46 | 0.04 | 50
Age 15, q1 | 414 | 2 | 69200.46 | <.01 | 354

* Sensitivity for CIN2+ is 0.200 instead of 0.569; specificity for CIN2+ is 0.990 instead of 0.945; sensitivity for ASCUS is 0.450 instead of 0.762; specificity for ASCUS is 0.756 instead of 0.638. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) associated with screening beginning at different ages (varying in 1-year increments from age 15 to 25 years). Screening intervals of 1 (q1), 2 (q2), 3 (q3), and 5 years (q5) are compared.

## Summary of Results for Specific Aim 1–Sub-Aim 1

Tables 17 through 19 and Figures 3 and 4 summarize the results for the base-case analyses for Sub-Aim 1, regarding the age at which to end screening. Outcomes for women, grouped by screening interval and whether they have never been screened or have been screened annually prior to age 65 years, are presented in Table 17. Among women who have never been screened, varying the age at which to end screening has a relatively small impact on cancer cases and cancer deaths, but a large impact on the number of colposcopies and false-positive test results. For instance, cancer deaths range from approximately 9 per 1,000 women (860 per 100,000) if screening is conducted every 5 years and ends at age 70 years, to approximately 8 per 1,000 women (789 per 100,000) if screening ends at age 90 years. For the same comparison, colposcopies range from 36.95 to 135.78 per 1,000 women. A similar pattern is seen with increasing the frequency of screening—small reductions in cancer cases and deaths, but large increases in false-positives and colposcopies. Although a similar pattern is also seen among women who have been screened every 3 years prior to age 65 years (i.e., many more colposcopies and false-positive test results associated with small decreases in cancer cases and deaths), compared to those who have never been screened, there is a large increase in colposcopies. For example, among women who have never been screened prior to age 65 years, screening every 5 years and ending at age 70 years is associated with approximately 37 colposcopies per 1,000 women, compared to 621 if screening is conducted every 3 years. Although deaths are increased, as expected, if age-specific survival ratios are used instead of pooled estimates of survival, the patterns observed above are similar. As a result, among those who have never been screened, strategies associated with infrequent screening (every 2 through 5 years) and ending at age 70 years fall on the steep part of the efficiency curve (Table 18 and Figure 3).

Table 17 Sensitivity Analysis Showing Expected False-Positives, Colposcopies, CIN2-3 Cases, Cancer Cases, and Cancer Deaths Associated With Different Ages at Which to End Screening, Varying in 5-Year Increments From Age 65 to 90 Years^*,†,‡^

| | Age 70 | Age 75 | Age 80 | Age 85 | Age 90
No screening (until age 65)
q5 | False Positives | 13.72 | 36.82 | 46.08 | 52.60 | 56.07
q5 | Colposcopies | 36.95 | 91.70 | 112.94 | 127.84 | 135.78
q5 | CIN 2-3s | 8.16 | 16.49 | 19.31 | 21.26 | 22.28
q5 | Cancer Cases | 28.76 | 27.30 | 27.02 | 26.91 | 26.88
q5 | Cancer Deaths | 8.60 | 8.04 | 7.95 | 7.91 | 7.89
q5^‡^ | Cancer Deaths | 10.52 | 9.58 | 9.42 | 9.35 | 9.34
No screening (until age 65)
q3 | False Positives | 26.24 | 49.63 | 68.71 | 76.60 | 85.78
q3 | Colposcopies | 66.49 | 118.54 | 160.44 | 177.64 | 197.81
q3 | CIN 2-3s | 12.55 | 18.32 | 22.61 | 24.29 | 26.36
q3 | Cancer Cases | 27.84 | 26.80 | 26.26 | 26.12 | 26.00
q3 | Cancer Deaths | 8.24 | 7.88 | 7.71 | 7.67 | 7.64
q3^‡^ | Cancer Deaths | 9.88 | 9.24 | 8.94 | 8.87 | 8.81
No screening (until age 65)
q2 | False Positives | 38.65 | 72.77 | 92.51 | 114.36 | 122.99
q2 | Colposcopies | 93.45 | 166.42 | 208.35 | 254.84 | 273.17
q2 | CIN 2-3s | 15.02 | 20.94 | 24.14 | 27.75 | 29.15
q2 | Cancer Cases | 27.29 | 26.20 | 25.76 | 25.43 | 25.34
q2 | Cancer Deaths | 8.04 | 7.70 | 7.58 | 7.49 | 7.47
q2^‡^ | Cancer Deaths | 9.51 | 8.88 | 8.64 | 8.48 | 8.44
No screening (until age 65)
q1 | False Positives | 72.43 | 125.82 | 170.98 | 205.32 | 225.27
q1 | Colposcopies | 162.55 | 272.12 | 364.75 | 435.21 | 476.15
q1 | CIN 2-3s | 18.07 | 23.08 | 27.26 | 30.45 | 32.31
q1 | Cancer Cases | 26.51 | 25.51 | 24.88 | 24.55 | 24.40
q1 | Cancer Deaths | 7.80 | 7.53 | 7.38 | 7.30 | 7.27
q1^‡^ | Cancer Deaths | 9.02 | 8.48 | 8.17 | 8.02 | 7.96
Screening q3 (until age 65)
q5 | False Positives | 287.69 | 300.56 | 311.67 | 320.51 | 326.20
q5 | Colposcopies | 621.45 | 650.61 | 676.05 | 696.34 | 709.44
q5 | CIN 2-3s | 66.05 | 69.74 | 73.12 | 75.85 | 77.62
q5 | Cancer Cases | 10.66 | 9.95 | 9.46 | 9.21 | 9.12
q5 | Cancer Deaths | 2.25 | 2.00 | 1.83 | 1.75 | 1.71
q5^‡^ | Cancer Deaths | 3.62 | 3.18 | 2.89 | 2.75 | 2.70
Screening q3 (until age 65)
q3 | False Positives | 300.14 | 323.48 | 334.08 | 349.92 | 358.25
q3 | Colposcopies | 648.96 | 700.23 | 723.36 | 758.16 | 776.44
q3 | CIN 2-3s | 69.02 | 74.33 | 76.62 | 80.21 | 82.09
q3 | Cancer Cases | 10.03 | 9.10 | 8.80 | 8.50 | 8.40
q3 | Cancer Deaths | 2.03 | 1.74 | 1.65 | 1.55 | 1.52
q3^‡^ | Cancer Deaths | 3.23 | 2.69 | 2.52 | 2.36 | 2.31

* Women are assumed to either never have been screened or screened every 3 years prior to age 65 years. Thereafter, they are screened until age 70, 75, 80, 85, or 90 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared for those who have never been screened, and intervals of every 3 (q3) or 5 (q5) years are compared for those who have. All women are assumed to be followed until age 100 years or death.

† Among women who are screened every 3 years until age 65 years, the number of false-positives, colposcopies, CIN2-3 cases, cancer cases, and cancer deaths are 273.44, 590.30, 63, 11, and 2.5, respectively.

‡ Sensitivity analysis estimates are based on age-specific survival. Cancer deaths are calculated using pooled and age-specific survival.

Table 18 Base-Case Analysis for Strategies Identified as Efficient Among Women Who Have Never Been Screened Prior to Age 65 Years^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Screening q5 from Age 65 to Age 70 | 37 | 37 | 69025.14 | 8.84 | 4
Screening q3 from Age 65 to Age 70 | 66 | 30 | 69028.63 | 3.49 | 8
Screening q2 from Age 65 to Age 70 | 93 | 27 | 69030.63 | 2.00 | 13
Screening q1 from Age 65 to Age 70 | 163 | 70 | 69033.27 | 2.64 | 27
Screening q1 from Age 65 to Age 75 | 272 | 109 | 69035.38 | 2.11 | 52
Screening q1 from Age 65 to Age 80 | 365 | 93 | 69036.33 | 0.95 | 98
Screening q1 from Age 65 to Age 85 | 435 | 70 | 69036.68 | 0.35 | 200
Screening q1 from Age 65 to Age 90 | 476 | 41 | 69036.77 | 0.09 | 456

* Women are assumed to never have been screened prior to age 65 years. Thereafter, they are screened until age 70, 75, 80, 85, or 90 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY).

Table 19 Base-Case Analysis for Strategies Identified as Efficient Among Women Who Have Been Screened Every 3 Years Prior to Age 65 Years^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
Screening q3 from Age 21 to Age 65 | 590 | | 69204.77
Screening q3 from Age 21 to Age 65 and then q5 to Age 70 | 621 | 31 | 69207.50 | 2.73 | 11
Screening q3 from Age 21 to Age 65 and then q3 to Age 70 | 649 | 28 | 69209.47 | 1.97 | 14
Screening q3 from Age 21 to Age 65 and then q5 to Age 75 | 651 | 2 | 69209.57 | 0.10 | 20
Screening q3 from Age 21 to Age 65 and then q3 to Age 75 | 700 | 49 | 69211.72 | 2.15 | 23
Screening q3 from Age 21 to Age 65 and then q3 to Age 80 | 723 | 23 | 69212.26 | 0.54 | 43
Screening q3 from Age 21 to Age 65 and then q3 to Age 85 | 758 | 35 | 69212.69 | 0.43 | 81
Screening q3 from Age 21 to Age 65 and then q3 to Age 90 | 776 | 18 | 69212.76 | 0.07 | 257

* Thereafter, women are screened to age 70, 75, 80, 85, or 90 years. Screening intervals of every 3 (q3) and 5 (q5) years are compared.

Figure 3 Efficiency Curve Comparing Strategies Differing By Age at Which to End Screening, Among Women Who Have Not Been Screened Prior to Age 65 Years*

*Strategies presented are those identified as efficient using incremental colposcopies per life-year.

Figure 3 presents an efficiency curve comparing strategies that differ by the age at which to end screening. Women are assumed to not have been screened prior to age 65. The age at which to end screening varies in 5-year increments from age 70 to age 90. The number of colposcopies per 1000 women varies from 0 to 500 along the x-axis. The number of life-years varies from 69,015 to 69,040 per 1000 women. Strategies are compared by ranking them in order of average number of colposcopies per 1000 women. Adjacent strategies are then compared using an incremental colposcopy per life-year ratio, which is calculated using the difference in colposcopies divided by the difference in life-years. The strategies on the curve are those that are not dominated. A strategy that is “dominated” is eliminated from consideration because it is associated with more colposcopies and less effectiveness or fewer colposcopies but a higher colposcopy per life-year ratio than an adjacent strategy.

Figure 4 Efficiency Curve Comparing Strategies Differing By Age at Which to End Screening, Among Women Who Have Been Screened Every 3 Years Prior to Age 65 Years*

*Screening is assumed to begin at age 21 years. After age 65 years, screening is then varied by interval (q3 and q5) and age at which to end screening (70, 75, 80, 85, and 90 years). Strategies presented are those identified as efficient using colposcopies per (undiscounted) life-year.

Figure 4 presents an efficiency curve comparing strategies that differ by the age at which to end screening. Women are assumed to have been screened every 3 years prior to age 65. The age at which to end screening varies in 5-year increments from age 70 to age 90. The number of colposcopies per 1000 women varies from 590 to 790 along the x-axis. The number of life-years varies from 69,204 to 69,214 per 1000 women. Strategies are compared by ranking them in order of average number of colposcopies per 1000 women. Adjacent strategies are then compared using an incremental colposcopy per life-year ratio, which is calculated using the difference in colposcopies divided by the difference in life-years. The strategies on the curve are those that are not dominated. A strategy that is “dominated” is eliminated from consideration because it is associated with more colposcopies and less effectiveness or fewer colposcopies but a higher colposcopy per life-year ratio than an adjacent strategy.

In contrast, there are much smaller differences between the strategies identified as efficient for women who have been screened frequently prior to age 65 years (Table 19 and Figure 4). The strategies cluster very closely together based on life expectancy, with an approximate 1-year gain in life expectancy per 1,000 women at most, which represents less than 1 day’s gain in life expectancy per woman. These results are robust across a range of sensitivity analyses (Tables 20-29), including the analyses which assume less than perfect compliance with screening and low estimates for sensitivity. Results are also robust when the sensitivity and specificity of colposcopy and biopsy are varied or different conditional probabilities of cytology results given underlying histology are used (data not shown).

### Key Sensitivity Analyses

#### 1 Age-Specific Survival Ratios

Table 20 Sensitivity Analysis Varying Age-Specific Survival Ratios^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 68984.74
Screening q5 from Age 65 to Age 70 | 37 | 37 | 69002.67 | 17.93 | 2
Screening q3 from Age 65 to Age 70 | 66 | 29 | 69008.82 | 6.15 | 5
Screening q2 from Age 65 to Age 70 | 93 | 27 | 69012.66 | 3.84 | 7
Screening q1 from Age 65 to Age 70 | 163 | 70 | 69018.11 | 5.45 | 13
Screening q1 from Age 65 to Age 75 | 272 | 109 | 69022.33 | 4.22 | 26
Screening q1 from Age 65 to Age 80 | 365 | 93 | 69024.26 | 1.93 | 48
Screening q1 from Age 65 to Age 85 | 435 | 70 | 69024.98 | 0.72 | 97
Screening q1 from Age 65 to Age 90 | 476 | 41 | 69025.15 | 0.17 | 241

* Refer to Appendix B for details.

Table 21 Sensitivity Analysis Varying Age-Specific Survival Ratios^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
Screening q3 from Age 21 to Age 65 | 590 | | 69186.98
Screening q3 from Age 21 to Age 65 and then q5 to Age 70 | 621 | 31 | 69192.31 | 5.33 | 6
Screening q3 from Age 21 to Age 65 and then q3 to Age 70 | 649 | 28 | 69195.86 | 3.55 | 8
Screening q3 from Age 21 to Age 65 and then q3 to Age 75 | 700 | 51 | 69199.87 | 4.01 | 13
Screening q3 from Age 21 to Age 65 and then q3 to Age 80 | 723 | 23 | 69200.80 | 0.93 | 25
Screening q3 from Age 21 to Age 65 and then q3 to Age 85 | 758 | 35 | 69201.53 | 0.73 | 48
Screening q3 from Age 21 to Age 65 and then q3 to Age 90 | 776 | 18 | 69201.61 | 0.08 | 225

* Refer to Appendix B for details.

#### 2 Natural History

Table 22 Sensitivity Analysis Varying Multiple Natural History Parameters^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69074.37
Screening q5 from Age 65 to Age 70 | 67 | 67 | 69085.38 | 11.01 | 6
Screening q3 from Age 65 to Age 70 | 111 | 44 | 69089.63 | 4.25 | 10
Screening q2 from Age 65 to Age 70 | 146 | 35 | 69092.01 | 2.38 | 15
Screening q1 from Age 65 to Age 70 | 222 | 76 | 69095.03 | 3.02 | 25
Screening q1 from Age 65 to Age 75 | 346 | 124 | 69097.14 | 2.11 | 59
Screening q1 from Age 65 to Age 80 | 449 | 103 | 69097.98 | 0.84 | 123
Screening q1 from Age 65 to Age 85 | 526 | 77 | 69098.27 | 0.29 | 266
Screening q1 from Age 65 to Age 90 | 571 | 45 | 69098.34 | 0.07 | 643

* Refer to Appendix B for details.

Table 23 Sensitivity Analysis Varying Multiple Natural History Parameters^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
Screening q3 from Age 21 to Age 65 | 723 | | 69210.27
Screening q3 from Age 21 to Age 65 and then q5 to Age 70 | 761 | 38 | 69212.80 | 2.53 | 15
Screening q3 from Age 21 to Age 65 and then q3 to Age 70 | 795 | 34 | 69214.58 | 1.78 | 19
Screening q3 from Age 21 to Age 65 and then q3 to Age 75 | 857 | 62 | 69216.55 | 1.97 | 32
Screening q3 from Age 21 to Age 65 and then q3 to Age 80 | 885 | 28 | 69217.01 | 0.46 | 61
Screening q3 from Age 21 to Age 65 and then q3 to Age 85 | 928 | 43 | 69217.37 | 0.36 | 119
Screening q3 from Age 21 to Age 65 and then q3 to Age 90 | 950 | 22 | 69217.43 | 0.06 | 367

* Refer to Appendix B for details.

#### 3 Adherence to Screening <100%^61^

Table 24 Sensitivity Analysis Varying Adherence to Screening Among Women Who Have Never Been Screened Prior to Age 65 Years^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Screening q5 from Age 65 to Age 70 | 14 | 14 | 69019.62 | 3.32 | 4
Screening q3 from Age 65 to Age 70 | 26 | 12 | 69021.61 | 1.99 | 6
Screening q2 from Age 65 to Age 70 | 38 | 12 | 69023.28 | 1.67 | 7
Screening q1 from Age 65 to Age 70 | 62 | 24 | 69026.28 | 3.00 | 8
Screening q1 from Age 65 to Age 75 | 74 | 12 | 69027.00 | 0.72 | 17
Screening q1 from Age 65 to Age 80 | 83 | 9 | 69027.34 | 0.34 | 26
Screening q1 from Age 65 to Age 85 | 86 | 3 | 69027.37 | 0.03 | 100
Screening q1 from Age 65 to Age 90 | 88 | 2 | 69027.38 | 0.01 | 200

* Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are screened to age 70, 75, 80, 85, or 90 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 25 Sensitivity Analysis Varying Adherence to Screening Among Women Who Have Been Screened Every 3 Years Prior to Age 65 Years^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
Screening q3 from Age 21 to Age 65 | 319 | | 69155.90
Screening q3 from Age 21 to Age 65 and then q5 to Age 70 | 332 | 13 | 69157.63 | 1.73 | 8
Screening q3 from Age 21 to Age 65 and then q3 to Age 70 | 343 | 11 | 69158.90 | 1.27 | 9
Screening q3 from Age 21 to Age 65 and then q3 to Age 75 | 349 | 6 | 69159.25 | 0.35 | 17
Screening q3 from Age 21 to Age 65 and then q3 to Age 80 | 352 | 3 | 69159.34 | 0.09 | 33
Screening q3 from Age 21 to Age 65 and then q3 to Age 85 | 353 | 1 | 69159.36 | 0.02 | 50
Screening q3 from Age 21 to Age 65 and then q3 to Age 90 | 354 | 1 | 69159.36 | <0.01 | 650

* Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are screened to age 70, 75, 80, 85, or 90 years. Screening intervals of every 3 (q3) and 5 (q5) years are compared.

#### 4 Highest Estimates of Sensitivity and Lowest Estimates of Specificity

Table 26 Sensitivity Analysis Using the Highest Estimates of Sensitivity and Lowest Estimates of Specificity Among Women Who Have Never Been Screened Prior to Age 65 Years^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Screening q5 from Age 65 to Age 70 | 98 | 98 | 69028.58 | 12.28 | 8
Screening q3 from Age 65 to Age 70 | 179 | 81 | 69031.98 | 3.40 | 24
Screening q2 from Age 65 to Age 70 | 255 | 76 | 69033.49 | 1.51 | 50
Screening q3 from Age 65 to Age 75 | 327 | 72 | 69034.72 | 1.23 | 59
Screening q2 from Age 65 to Age 75 | 467 | 140 | 69035.96 | 1.24 | 113
Screening q2 from Age 65 to Age 80 | 590 | 123 | 69036.67 | 0.71 | 173
Screening q1 from Age 65 to Age 80 | 982 | 392 | 69037.90 | 1.23 | 319
Screening q1 from Age 65 to Age 85 | 1175 | 193 | 69038.18 | 0.28 | 689
Screening q1 from Age 65 to Age 90 | 1286 | 111 | 69038.25 | 0.07 | 1586

* Sensitivity for CIN2+ is 0.772 instead of 0.569; specificity for CIN2+ is 0.847 instead of 0.945; sensitivity for ASCUS is 0.956 instead of 0.762; specificity for ASCUS is 0.475 instead of 0.638. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are screened to age 70, 75, 80, 85, or 90 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 27 Sensitivity Analysis Using the Highest Estimates of Sensitivity and Lowest Estimates of Specificity Among Women Who Have Been Screened Every 3 Years Prior to Age 65 Years^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
Screening q3 from Age 21 until Age 65 | 1703 | | 69228.04
Screening q3 from Age 21 to Age 65 and then q5 to Age 70 | 1793 | 90 | 69230.71 | 2.67 | 34
Screening q3 from Age 21 to Age 65 and then q5 to Age 75 | 1876 | 83 | 69232.92 | 2.21 | 38
Screening q3 from Age 21 to Age 65 and then q5 to Age 80 | 1948 | 72 | 69234.06 | 1.14 | 63
Screening q3 from Age 21 to Age 65 and then q3 to Age 75 | 2018 | 70 | 69234.79 | 0.73 | 96
Screening q3 from Age 21 to Age 65 and then q3 to Age 80 | 2086 | 68 | 69235.32 | 0.53 | 128
Screening q3 from Age 21 to Age 65 and then q3 to Age 85 | 2185 | 99 | 69235.75 | 0.43 | 230
Screening q3 from Age 21 to Age 65 and then q3 to Age 90 | 2238 | 53 | 69235.83 | 0.08 | 663

* Sensitivity for CIN2+ is 0.772 instead of 0.569; specificity for CIN2+ is 0.847 instead of 0.945; sensitivity for ASCUS is 0.956 instead of 0.762; specificity for ASCUS is 0.475 instead of 0.638. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are screened to age 70, 75, 80, 85, or 90 years. Screening intervals of every 3 (q3) and 5 (q5) years are compared.

Table 28 Sensitivity Analysis Using the Lowest Estimates of Sensitivity and Highest Estimates of Specificity Among Women Who Have Never Been Screened Prior to Age 65 Years^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Screening q5 from Age 65 to Age 70 | 9 | 9 | 69019.43 | 3.13 | 3
Screening q2 from Age 65 to Age 70 | 22 | 13 | 69022.76 | 3.33 | 4
Screening q1 from Age 65 to Age 70 | 39 | 17 | 69026.11 | 3.35 | 5
Screening q1 from Age 65 to Age 75 | 62 | 23 | 69028.22 | 2.11 | 11
Screening q1 from Age 65 to Age 80 | 82 | 20 | 69029.03 | 0.81 | 25
Screening q1 from Age 65 to Age 85 | 96 | 14 | 69029.29 | 0.26 | 54
Screening q1 from Age 65 to Age 90 | 105 | 9 | 69029.33 | 0.04 | 225

* Sensitivity for CIN2+ is 0.200 instead of 0.569; specificity for CIN2+ is 0.990 instead of 0.945; sensitivity for ASCUS is 0.450 instead of 0.762; specificity for ASCUS is 0.756 instead of 0.638. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are screened to age 70, 75, 80, 85, or 90 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 29 Sensitivity Analysis Using the Lowest Estimates of Sensitivity and Highest Estimates of Specificity Among Women Who Have Been Screened Every 3 Years Prior to Age 65 Years^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
Screening q3 from Age 21 until Age 65 | 128 | | 69124.03
Screening q3 from Age 21 to Age 65 and then q5 to Age 70 | 135 | 7 | 69125.75 | 1.72 | 4
Screening q3 from Age 21 to Age 65 and then q3 to Age 70 | 141 | 6 | 69126.95 | 1.20 | 5
Screening q3 from Age 21 to Age 65 and then q3 to Age 75 | 153 | 12 | 69128.22 | 1.27 | 9
Screening q3 from Age 21 to Age 65 and then q3 to Age 80 | 158 | 5 | 69128.48 | 0.26 | 19
Screening q3 from Age 21 to Age 65 and then q3 to Age 85 | 165 | 7 | 69128.62 | 0.14 | 50

* Sensitivity for CIN2+ is 0.200 instead of 0.569; specificity for CIN2+ is 0.990 instead of 0.945; sensitivity for ASCUS is 0.450 instead of 0.762; specificity for ASCUS is 0.756 instead of 0.638. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are screened to age 70, 75, 80, 85, or 90 years. Screening intervals of every 3 (q3) and 5 (q5) years are compared.

## Summary of Results for Specific Aim 2

Tables 30a–c and 31a–c and Figures 5 through 7 summarize the results for Specific Aim 2, which compares strategies that include HPV DNA testing to cytology only using three different sets of test accuracy estimates. As shown in Tables 30a–c, the results are similar regardless of estimates used; there are fewer colposcopies but more cancer cases and cancer deaths associated with screening using cytology tests conducted at intervals of every 2, 3, and 5 years, compared to screening with cytology only prior to age 30 years, and then with cytology and HPV beginning at age 30 years. At an annual screening interval, the cytology-only strategy is associated with more colposcopies but fewer cases of cancer and cancer deaths, compared to the cytology and HPV strategy. The reason for this switch is that at less frequent intervals, a sufficient amount of disease is detected by adding the HPV test, which offsets any loss in disease detection due to women with dually negative test results being screened once every 3 years (beginning at age 30 years) for the cytology and HPV strategy. However, at the most frequent screening interval, the impact of women with dually negative results being screened every 3 years becomes evident, with fewer colposcopies and false-positives, but more cases of disease for the HPV and cytology strategy compared to the cytology-only strategy.

Table 30a Vesco et al35: Sensitivity Analysis Showing Expected False-Positives, Colposcopies, CIN2-3 Cases, Cancer Cases, and Cancer Deaths Associated With Cytology and HPV Test-Based Strategies Either Alone or in Combination^*^

Strategy | Interval | False-Positives | Colposcopies | CIN2-3 Cases | Cancer Cases | Cancer Deaths
Cytology and HPV | q5 | 280.88 | 625.91 | 84.78 | 7.07 | 1.29
Cytology | q5 | 213.97 | 483.36 | 66.01 | 12.69 | 2.71
Cytology and HPV | q3 | 381.33 | 824.74 | 93.10 | 4.73 | 0.74
Cytology | q3 | 349.92 | 758.16 | 80.21 | 8.50 | 1.55
Cytology and HPV | q2 | 539.64 | 1129.39 | 94.39 | 3.64 | 0.52
Cytology | q2 | 515.26 | 1083.52 | 87.52 | 5.80 | 0.92
Cytology and HPV | q1 | 727.22 | 1488.19 | 95.19 | 2.57 | 0.35
Cytology | q1 | 951.45 | 1931.00 | 91.50 | 2.50 | 0.32

* Per 1,000 women. Time horizon is a lifetime. Age at which to begin screening is fixed at age 21 years. For the combined cytology and HPV strategies, cytology-based screening only is assumed prior to age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Women with normal cytology results and HPV negative results are assumed to be screened every 3 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 30b Mayrand et al8: Sensitivity Analysis Showing Expected False-Positives, Colposcopies, CIN2-3 Cases, Cancer Cases, and Cancer Deaths Associated With Cytology and HPV Test-Based Strategies Either Alone or in Combination^*^

Strategy | Interval | False-Positives | Colposcopies | CIN2-3 Cases | Cancer Cases | Cancer Deaths
Cytology and HPV | q5 | 129.70 | 347.79 | 86.98 | 7.39 | 1.35
Cytology | q5 | 100.94 | 274.01 | 66.93 | 13.15 | 2.81
Cytology and HPV | q3 | 175.67 | 446.38 | 96.53 | 5.02 | 0.79
Cytology | q3 | 165.52 | 416.44 | 82.61 | 8.97 | 1.65
Cytology and HPV | q2 | 252.91 | 600.90 | 99.35 | 3.94 | 0.57
Cytology | q2 | 244.38 | 580.58 | 91.71 | 6.24 | 0.99
Cytology and HPV | q1 | 348.59 | 790.56 | 101.93 | 2.82 | 0.38
Cytology | q1 | 464.75 | 1024.42 | 99.89 | 2.79 | 0.36

* Time horizon is a lifetime. Age at which to begin screening is fixed at age 21 years. For the combined cytology and HPV strategies, cytology-based screening only is assumed prior to age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Women with normal cytology results and HPV negative results are assumed to be screened every 3 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 30c Koliopoulos et al36: Sensitivity Analysis Showing Expected False-Positives, Colposcopies, CIN2-3 Cases, Cancer Cases, and Cancer Deaths Associated With Cytology and HPV Test-Based Strategies Either Alone or in Combination^*^

Strategy | Interval | False-Positives | Colposcopies | CIN2-3 Cases | Cancer Cases | Cancer Deaths
Cytology and HPV | q5 | 441.29 | 907.30 | 85.28 | 6.23 | 1.01
Cytology | q5 | 328.93 | 693.97 | 74.85 | 9.76 | 1.86
Cytology and HPV | q3 | 600.89 | 1209.54 | 92.36 | 3.94 | 0.53
Cytology | q3 | 535.05 | 1090.56 | 86.16 | 5.98 | 0.95
Cytology and HPV | q2 | 834.47 | 1646.02 | 92.33 | 2.86 | 0.36
Cytology | q2 | 784.70 | 1563.96 | 90.13 | 3.79 | 0.51
Cytology and HPV | q1 | 1101.24 | 2141.58 | 91.41 | 1.92 | 0.23
Cytology | q1 | 1409.78 | 2744.25 | 88.30 | 1.37 | 0.16

* Time horizon is a lifetime. Age at which to begin screening is fixed at age 21 years. For the combined cytology and HPV strategies, cytology-based screening only is assumed prior to age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Women with normal cytology results and HPV negative results are assumed to be screened every 3 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 31a Vesco et al35: Sensitivity Analysis Showing Expected Colposcopies, Incremental Colposcopies, Life-Years, Incremental Life-Years, and Incremental Colposcopies per Life-Year for Strategies Identified as Efficient^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Cytology, q5, Age 21 | 483 | 483 | 69182.25 | 165.95 | 3
Cytology and HPV, q5, Age 30 | 626 | 143 | 69218.11 | 35.86 | 4
Cytology and HPV, q3, Age 30 | 825 | 199 | 69233.80 | 15.69 | 13
Cytology and HPV, q2, Age 30 | 1129 | 304 | 69240.06 | 6.26 | 49
Cytology and HPV, q1, Age 30 | 1488 | 359 | 69245.94 | 5.88 | 61
Cytology, q1, Age 21 | 1931 | 443 | 69246.58 | 0.64 | 692

* Per 1,000 women. Women are assumed to begin screening at age 21 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 31b Mayrand et al8: Sensitivity Analysis Showing Expected Colposcopies, Incremental Colposcopies, Life-Years, Incremental Life-Years, and Incremental Colposcopies per Life-Year for Strategies Identified as Efficient^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Cytology and HPV, q5, Age 30 | 348 | 348 | 69216.41 | 200.11 | 2
Cytology and HPV, q3, Age 30 | 446 | 98 | 69232.50 | 16.09 | 6
Cytology and HPV, q2, Age 30 | 601 | 155 | 69238.85 | 6.35 | 24
Cytology and HPV, q1, Age 30 | 791 | 190 | 69245.03 | 6.18 | 31
Cytology, q1, Age 21 | 1024 | 233 | 69245.57 | 0.54 | 431

* Per 1,000 women. Women are assumed to begin screening at age 21 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 31c Koliopoulos et al36: Sensitivity Analysis Showing Expected Colposcopies, Incremental Colposcopies, Life-Years, Incremental Life-Years, and Incremental Colposcopies per Life-Year for Strategies Identified as Efficient^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Cytology, q5, Age 21 | 694 | 694 | 69205.11 | 188.81 | 4
Cytology and HPV, q5, Age 30 | 907 | 213 | 69226.66 | 21.55 | 10
Cytology and HPV, q3, Age 30 | 1210 | 303 | 69240.14 | 13.48 | 22
Cytology and HPV, q2, Age 30 | 1646 | 436 | 69245.20 | 5.06 | 86
Cytology and HPV, q1, Age 30 | 2142 | 496 | 69249.40 | 4.20 | 118
Cytology, q1, Age 21 | 2744 | 602 | 69251.10 | 1.70 | 354

* Per 1,000 women. Women are assumed to begin screening at age 21 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Figure 5 Efficiency Curve Comparing Strategies Based on Cytology Either Alone or in Combination With HPV*

*For cytology and HPV combined strategies, women are assumed to be screened with cytology only (with a repeat cytology test for ASC-US results) before age 30 years. Strategies presented are those identified as efficient using incremental colposcopies per life-year.

Figure 5 presents an efficiency curve comparing strategies based on cytology alone or in combination with HPV testing. The number of colposcopies per 1000 women varies from 0 to 2500 along the x-axis. The number of life-years varies from 69,000 to 69,300 per 1000 women. Strategies are compared by ranking them in order of average number of colposcopies per 1000 women. Adjacent strategies are then compared using an incremental colposcopy per life-year ratio, which is calculated using the difference in colposcopies divided by the difference in life-years. The strategies on the curve are those that are not dominated. A strategy that is “dominated” is eliminated from consideration because it is associated with more colposcopies and less effectiveness or fewer colposcopies but a higher colposcopy per life year ratio than an adjacent strategy.

Figure 6 Efficiency Curve Comparing Strategies Based on Cytology Either Alone or in Combination With HPV*

*For cytology and HPV combined strategies, women are assumed to be screened with cytology only (with a repeat cytology test for ASC-US results) before age 30 years. Strategies presented are those identified as efficient using incremental colposcopies per life-year.

Figure 6 presents an efficiency curve comparing strategies based on cytology alone or in combination with HPV testing. The number of colposcopies per 1000 women varies from 0 to 1200 along the x-axis. The number of life-years varies from 69,000 to 69,300 per 1000 women. Strategies are compared by ranking them in order of average number of colposcopies per 1000 women. Adjacent strategies are then compared using an incremental colposcopy per life-year ratio, which is calculated using the difference in colposcopies divided by the difference in life-years. The strategies on the curve are those that are not dominated. A strategy that is “dominated” is eliminated from consideration because it is associated with more colposcopies and less effectiveness or fewer colposcopies but a higher colposcopy per life-year ratio than an adjacent strategy.

Figure 7 Efficiency Curve Comparing Strategies Based on Cytology Either Alone or in Combination With HPV*

*For cytology and HPV combined strategies, women are assumed to be screened with cytology only (with a repeat cytology test for ASC-US results) before age 30 years. Strategies presented are those identified as efficient using incremental colposcopies per life-year.

Figure 7 presents an efficiency curve comparing strategies based on cytology alone or in combination with HPV testing. The number of colposcopies per 1000 women varies from 0 to 3000 along the x-axis. The number of life-years varies from 69,000 to 69,300 per 1000 women. Strategies are compared by ranking them in order of average number of colposcopies per 1000 women. Adjacent strategies are then compared using an incremental colposcopy per life-year ratio, which is calculated using the difference in colposcopies divided by the difference in life-years. The strategies on the curve are those that are not dominated. A strategy that is “dominated” is eliminated from consideration because it is associated with more colposcopies and less effectiveness or fewer colposcopies but a higher colposcopy per life-year ratio than an adjacent strategy.

As a result, HPV and cytology is identified as a strategy that may provide a reasonable trade-off between the burden and benefits of screening, especially when conducted every 3 or 5 years (Tables 31a–c and Figures 5–7). The base-case findings are generally similar across a range of sensitivity analyses (Tables 32-37a–c), including varying the sensitivity and specificity of colposcopy and biopsy as well as the conditional probability of cytology given underlying histology (data not shown). If women with normal cytology results who are HPV negative are assumed to be screened every 5 years instead of every 3 (Tables 33a–c), and the difference in test accuracy between cytology and HPV is large (Tables 33a and 33b), cytology conducted every 3 years beginning at age 21 years is dominated (more colposcopies and fewer gains in life expectancy) by the cytology and HPV strategy. Exceptions to the findings for the base case (for the three sets of estimates) are when screening and triage tests are used to reflect the burden of screening instead of colposcopies (Tables 32a–c) and when a strategy of HPV followed by cytology for HPV positive women is modeled (Tables 36a–c and 37a–c). When screening and triage tests are used instead of colposcopies to quantify burden, cytology-only strategies are primarily identified as efficient. While the currently recommended strategy of cytology and HPV conducted every 3 years for women with dually negative results also falls on the efficiency curve, there is a large number of additional tests per life-year gained (approximately 1,000 to 1,200). A sensitivity analysis of HPV followed by cytology for HPV positive women shows that this is a potentially efficient strategy whether tests or colposcopies are used to quantify the burden of screening. This strategy, although not currently recommended, is more efficient than either the cytology-only or cytology and HPV strategies. This is because only those women with positive results on both tests are referred to colposcopy (compared to cytology-only strategies), reducing the burden of colposcopies due to false-positive results. Those women with discordant results (HPV positive, normal cytology) are assumed to undergo repeat screening 1 year later, with referral to colposcopy only if repeat testing is abnormal; thus, this strategy detects more disease than cytology only. Although the cytology and HPV strategy is associated with greater gains in life expectancy compared to HPV followed by cytology, it is associated with more colposcopies at the less frequent screening intervals (every 3 and 5 years). At the more frequent screening intervals (every 1 and 2 years), HPV followed by cytology is associated with greater gains in life expectancy because only a small proportion of women undergo routine screening at these intervals; the majority (with negative HPV and normal cytology results) are screened every 3 years. Use of tests instead of colposcopies produces similar results except when estimates of test accuracy from Koliopoulos et al36 are used. In this instance, cytology-based screening strategies are identified as efficient, which suggests that the magnitude of the difference in test accuracy between HPV and cytology, as well as the metric used to quantify burden of screening, influences the degree to which this strategy is considered efficient.

### Key Sensitivity Analyses

#### 1 Screening and Triage Tests per Life-Year

Table 32a Vesco et al35: Sensitivity Analysis Showing Expected Tests (Screening and Triage), Incremental Tests, Life-Years, Incremental Life-Years, and Incremental Tests per Life-Year for Strategies Identified as Efficient^*^

Strategy | Tests | Incremental Tests | Life Years (LYs) | Incremental LYs | ITLY
No intervention | 0 | | 69016.30
Cytology, q5, Age 21 | 11190 | 11190 | 69182.25 | 165.95 | 67
Cytology, q3, Age 21 | 18295 | 7105 | 69212.70 | 30.45 | 233
Cytology, q2, Age 21 | 26955 | 8660 | 69229.79 | 17.09 | 507
Cytology and HPV, q3, Age 30 | 31924 | 4969 | 69233.80 | 4.01 | 1239
Cytology, q1, Age 21 | 49887 | 17963 | 69246.58 | 12.78 | 1406

* Per 1,000 women. Age at which to begin screening is fixed at age 21 years. For the combined cytology and HPV strategies, cytology-based screening only is assumed prior to age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 32b Mayrand et al8: Sensitivity Analysis Showing Expected Tests (Screening and Triage), Incremental Tests, Life-Years, Incremental Life-Years, and Incremental Tests per Life-Year for Strategies Identified as Efficient^*^

Strategy | Tests | Incremental Tests | Life Years (LYs) | Incremental LYs | ITLY
No intervention | 0 | | 69016.30
Cytology, q5, Age 21 | 10754 | 10754 | 69179.46 | 163.16 | 66
Cytology, q3, Age 21 | 17593 | 6839 | 69210.24 | 30.78 | 222
Cytology, q2, Age 21 | 25944 | 8351 | 69227.79 | 17.55 | 476
Cytology and HPV, q3, Age 30 | 30797 | 4853 | 69232.50 | 4.71 | 1030
Cytology, q1, Age 21 | 49315 | 18518 | 69245.57 | 13.07 | 1417

* Per 1,000 women. Age at which to begin screening is fixed at age 21 years. For the combined cytology and HPV strategies, cytology-based screening only is assumed prior to age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 32c Koliopoulos et al36: Sensitivity Analysis Showing Expected Tests (Screening and Triage), Incremental Tests, Life-Years, Incremental Life-Years, and Incremental Tests per Life-Year for Strategies Identified as Efficient^*^

Strategy | Tests | Incremental Tests | Life Years (LYs) | Incremental LYs | ITLY
No intervention | 0 | | 69016.30
Cytology, q5, Age 21 | 11658 | 11658 | 69205.11 | 188.81 | 62
Cytology, q3, Age 21 | 18997 | 7339 | 69229.37 | 24.26 | 303
Cytology, q2, Age 21 | 27929 | 8932 | 69241.12 | 11.75 | 760
Cytology, q1, Age 21 | 50416 | 22487 | 69251.10 | 9.98 | 2253

* Per 1,000 women. Age at which to begin screening is fixed at age 21 years. For the combined cytology and HPV strategies, cytology-based screening only is assumed prior to age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

#### 2 Screening Every 5 Years for Women With Normal Cytology and HPV Negative Results

Table 33a Vesco et al35: Sensitivity Analysis Showing Expected Colposcopies, Incremental Colposcopies, Life-Years, Incremental Life-Years, and Incremental Colposcopies per Life-Year for Strategies Identified as Efficient^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Cytology and HPV, q5, Age 30 | 535 | 535 | 69214.72 | 198.42 | 3
Cytology and HPV, q3, Age 30 | 825 | 290 | 69233.80 | 19.08 | 15
Cytology and HPV, q2, Age 30 | 1129 | 304 | 69240.06 | 6.26 | 49
Cytology and HPV, q1, Age 30 | 1488 | 359 | 69245.94 | 5.88 | 61
Cytology, q1, Age 21 | 1931 | 443 | 69246.58 | 0.64 | 692

* Per 1,000 women. Age at which to begin screening is fixed at age 21 years. For the combined cytology and HPV strategies, cytology-based screening only is assumed prior to age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Women with HPV negative, cytology normal test results are assumed to be screened every 3 or 5 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 33b Mayrand et al8: Sensitivity Analysis Showing Expected Colposcopies, Incremental Colposcopies, Life-Years, Incremental Life-Years, and Incremental Colposcopies per Life-Year for Strategies Identified as Efficient^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Cytology and HPV, q5, Age 30 | 303 | 303 | 69213.14 | 196.84 | 2
Cytology and HPV, q3, Age 30 | 446 | 143 | 69232.50 | 19.36 | 7
Cytology and HPV, q2, Age 30 | 601 | 155 | 69238.85 | 6.35 | 24
Cytology and HPV, q1, Age 30 | 791 | 190 | 69245.03 | 6.18 | 31
Cytology, q1, Age 21 | 1024 | 233 | 69245.57 | 0.54 | 431

* Per 1,000 women. Age at which to begin screening is fixed at age 21 years. For the combined cytology and HPV strategies, cytology-based screening only is assumed prior to age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Women with HPV negative, cytology normal test results are assumed to be screened every 3 or 5 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 33c Koliopoulos et al36: Sensitivity Analysis Showing Expected Colposcopies, Incremental Colposcopies, Life-Years, Incremental Life-Years, and Incremental Colposcopies per Life-Year for Strategies Identified as Efficient^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Cytology and HPV, q5, Age 30 | 773 | 773 | 69223.52 | 207.22 | 4
Cytology and HPV, q3, Age 30 | 1210 | 437 | 69240.14 | 16.62 | 26
Cytology and HPV, q2, Age 30 | 1646 | 436 | 69245.20 | 5.06 | 86
Cytology and HPV, q1, Age 30 | 2142 | 496 | 69249.40 | 4.20 | 118
Cytology, q1, Age 21 | 2744 | 602 | 69251.10 | 1.70 | 354

* Per 1,000 women. Age at which to begin screening is fixed at age 21 years. For the combined cytology and HPV strategies, cytology-based screening only is assumed prior to age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Women with HPV negative, cytology normal test results are assumed to be screened every 3 or 5 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

#### 3 Natural History

Table 34a Vesco et al35: Sensitivity Analysis Varying Multiple Natural History Parameters^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69074.37
Cytology, q5, Age 21 | 622 | 622 | 69193.09 | 118.72 | 5
Cytology and HPV, q5, Age 30 | 808 | 186 | 69223.26 | 30.17 | 6
Cytology and HPV, q3, Age 30 | 1028 | 220 | 69235.69 | 12.43 | 18
Cytology and HPV, q2, Age 30 | 1342 | 314 | 69241.13 | 5.44 | 58
Cytology and HPV, q1, Age 30 | 1714 | 372 | 69246.53 | 5.40 | 69
Cytology, q1, Age 21 | 2142 | 428 | 69246.75 | 0.22 | 1945

* Refer to Appendix B for details. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years. For the combined cytology and HPV strategies, cytology-based screening only is assumed prior to age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 34b Mayrand et al8: Sensitivity Analysis Varying Multiple Natural History Parameters^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69074.37
Cytology and HPV, q5, Age 30 | 527 | 527 | 69222.37 | 148.00 | 4
Cytology and HPV, q3, Age 30 | 646 | 119 | 69234.99 | 12.62 | 9
Cytology and HPV, q2, Age 30 | 810 | 164 | 69240.51 | 5.52 | 30
Cytology and HPV, q1, Age 30 | 1012 | 202 | 69246.11 | 5.60 | 36
Cytology, q1, Age 21 | 1239 | 227 | 69246.30 | 0.19 | 1195

* Refer to Appendix B for details. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years. For the combined cytology and HPV strategies, cytology-based screening only is assumed prior to age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 34c Koliopoulos et al36: Sensitivity Analysis Varying Multiple Natural History Parameters^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69074.37
Cytology, q5, Age 21 | 856 | 856 | 69210.83 | 136.46 | 6
Cytology and HPV, q5, Age 30 | 1100 | 244 | 69229.38 | 18.55 | 13
Cytology and HPV, q3, Age 30 | 1426 | 327 | 69240.81 | 11.44 | 29
Cytology and HPV, q2, Age 30 | 1874 | 448 | 69245.51 | 4.70 | 95
Cytology and HPV, q1, Age 30 | 2385 | 511 | 69249.75 | 4.24 | 121
Cytology, q1, Age 21 | 2969 | 584 | 69251.13 | 1.38 | 423

* Refer to Appendix B for details. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years. For the combined cytology and HPV strategies, cytology-based screening only is assumed prior to age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

#### 4 Adherence to Screening <100%^61^

Table 35a Vesco et al35: Sensitivity Analysis Varying Estimates of Screening Adherence^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Cytology and HPV, q5, Age 30 | 254 | 254 | 69152.04 | 135.74 | 2
Cytology and HPV, q3, Age 30 | 367 | 112 | 69183.39 | 31.34 | 4
Cytology and HPV, q2, Age 30 | 526 | 160 | 69203.85 | 20.47 | 8
Cytology and HPV, q1, Age 30 | 770 | 243 | 69225.94 | 22.09 | 11

* Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Age at which to begin screening is fixed at age 21 years. For the combined cytology and HPV strategies, cytology-based screening only is assumed prior to age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 35b Mayrand et al8: Sensitivity Analysis Varying Estimates of Screening Adherence^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Cytology and HPV, q5, Age 30 | 148 | 148 | 69150.17 | 133.87 | 1
Cytology and HPV, q3, Age 30 | 208 | 60 | 69181.46 | 31.29 | 2
Cytology and HPV, q2, Age 30 | 292 | 84 | 69201.93 | 20.47 | 4
Cytology and HPV, q1, Age 30 | 417 | 125 | 69224.30 | 22.37 | 6

* Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Age at which to begin screening is fixed at age 21 years. For the combined cytology and HPV strategies, cytology-based screening only is assumed prior to age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 35c Koliopoulos et al36: Sensitivity Analysis Varying Estimates of Screening Adherence^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
Cytology, q5, Age 21 | 303 | 303 | 69140.40 | 124.10 | 2
Cytology and HPV, q5, Age 30 | 363 | 60 | 69160.64 | 20.24 | 3
Cytology and HPV, q3, Age 30 | 528 | 165 | 69191.65 | 31.01 | 5
Cytology and HPV, q2, Age 30 | 760 | 232 | 69211.64 | 19.99 | 12
Cytology and HPV, q1, Age 30 | 1114 | 354 | 69231.74 | 20.10 | 18

* Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Age at which to begin screening is fixed at age 21 years. For the combined cytology and HPV strategies, cytology-based screening only is assumed prior to age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

#### 5 HPV Followed By Cytology

Table 36a Vesco et al35: Sensitivity Analysis Including a Strategy of HPV Followed By Cytology if HPV Positive^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
HPV, followed by Cytology, q5, Age 30 | 234 | 234 | 69211.89 | 195.59 | 1
HPV, followed by Cytology, q3, Age 30 | 301 | 66 | 69231.50 | 19.61 | 3
HPV, followed by Cytology, q2, Age 30 | 423 | 122 | 69239.62 | 8.12 | 15
HPV, followed by Cytology, q1, Age 30 | 643 | 220 | 69247.71 | 8.09 | 27

* Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years. Women aged 30 years or older receive HPV testing first, followed by cytology if HPV positive. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 36b Mayrand et al8: Sensitivity Analysis Including a Strategy of HPV Followed By Cytology if HPV Positive^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
HPV followed by Cytology, q5, Age 30 | 154 | 154 | 69211.41 | 195.11 | 1
HPV followed by Cytology, q3, Age 30 | 190 | 36 | 69231.08 | 19.67 | 2
HPV followed by Cytology, q2, Age 30 | 246 | 56 | 69239.32 | 8.24 | 7
HPV followed by Cytology, q1, Age 30 | 351 | 105 | 69247.51 | 8.19 | 13

* Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years. Women aged 30 years or older receive HPV testing first, followed by cytology if HPV positive. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 36c Koliopoulos et al36: Sensitivity Analysis Including a Strategy of HPV Followed By Cytology if HPV Positive^*^

Strategy | Colposcopies | Incremental Colposcopies | Life Years (LYs) | Incremental LYs | ICLY
No intervention | 0 | | 69016.30
HPV followed by Cytology, q5, Age 30 | 334 | 334 | 69219.18 | 202.88 | 2
HPV followed by Cytology, q3, Age 30 | 436 | 102 | 69237.06 | 17.88 | 6
HPV followed by Cytology, q2, Age 30 | 632 | 196 | 69244.12 | 7.06 | 28
HPV followed by Cytology, q1, Age 30 | 975 | 343 | 69250.53 | 6.41 | 54
Cytology, q1, Age 21 | 2744 | 1769 | 69251.10 | 0.57 | 3104

* Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years. Women aged 30 years or older receive HPV testing first, followed by cytology if HPV positive. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

#### 6 HPV Followed By Cytology: Tests

Table 37a Vesco et al35: Sensitivity Analysis Showing Expected Tests (Screening and Triage), Incremental Tests, Life-Years, Incremental Life-Years, and Incremental Tests per Life-Year for Strategies Identified as Efficient^*^

Strategy | Tests | Incremental Tests | Life Years (LYs) | Incremental LYs | ITLY
No intervention | 0 | | 69016.30
Cytology, q5, Age 21 | 11190 | 11190 | 69182.25 | 165.95 | 67
HPV followed by Cytology, q5, Age 30 | 13223 | 2033 | 69211.89 | 29.64 | 69
HPV followed by Cytology, q3, Age 30 | 20842 | 7619 | 69231.50 | 19.61 | 389
HPV followed by Cytology, q2, Age 30 | 29748 | 8906 | 69239.62 | 8.12 | 1097
HPV followed by Cytology, q1, Age 30 | 53079 | 23331 | 69247.71 | 8.09 | 2884

* Per 1,000 women. Women are assumed to begin screening at age 21 years. Women aged 30 years or older receive HPV testing first, followed by cytology if HPV positive. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 37b Mayrand et al8: Sensitivity Analysis Showing Expected Tests (Screening and Triage), Incremental Tests, Life-Years, Incremental Life-Years, and Incremental Tests per Life-Year for Strategies Identified as Efficient^*^

Strategy | Tests | Incremental Tests | Life Years (LYs) | Incremental LYs | ITLY
No intervention | 0 | | 69016.30
HPV followed by Cytology, q5, Age 30 | 12168 | 12168 | 69211.41 | 195.11 | 62
HPV followed by Cytology, q3, Age 30 | 19348 | 7180 | 69231.08 | 19.67 | 365
HPV followed by Cytology, q2, Age 30 | 27947 | 8599 | 69239.32 | 8.24 | 1044
HPV followed by Cytology, q1, Age 30 | 51455 | 23508 | 69247.51 | 8.19 | 2870

* Per 1,000 women. Women are assumed to begin screening at age 21 years. Women aged 30 years or older receive HPV testing first, followed by cytology if HPV positive. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

Table 37c Koliopoulos et al36: Sensitivity Analysis Showing Expected Tests (Screening and Triage), Incremental Tests, Life-Years, Incremental Life-Years, and Incremental Tests per Life-Year for Strategies Identified as Efficient^*^

Strategy | Tests | Incremental Tests | Life Years (LYs) | Incremental LYs | ITLY
No intervention | 0 | | 69016.30
Cytology, q5, Age 21 | 11658 | 11658 | 69205.11 | 188.81 | 62
HPV followed by Cytology, q5, Age 30 | 14467 | 2809 | 69219.18 | 14.07 | 200
Cytology, q3, Age 21 | 18997 | 4530 | 69229.37 | 10.19 | 445
HPV followed by Cytology, q3, Age 30 | 22634 | 3637 | 69237.06 | 7.69 | 473
HPV followed by Cytology, q2, Age 30 | 31826 | 9192 | 69244.12 | 7.06 | 1302
Cytology, q1, Age 21 | 50416 | 18590 | 69251.10 | 6.98 | 2663

* Per 1,000 women. Women are assumed to begin screening at age 21 years. Women aged 30 years or older receive HPV testing first, followed by cytology if HPV positive. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.