# References

1 Parkin DM, Bray F. Chapter 2: the burden of HPV-related cancers. Vaccine. 2006;24(Suppl 3):S11-S25.
2 Howlader N, Noone AM, Krapcho M, et al., editors. SEER Cancer Statistics Review, 1975-2008. Bethesda, MD. National Cancer Institute. 2011. Accessed at http://www.seer.cancer.gov/csr/1975_2008/index.html. 28 April 2011.
3 Ries LA, Kosary CL, Hankey BF, et al., editors. SEER Cancer Statistics Review, 1973-1994. Bethesda, MD. National Cancer Institute. 1997. Accessed at http://www.seer.cancer.gov/csr/1973_1994/. 28 April 2011.
4 Gustafsson L, Ponten J, Zack M, et al. International incidence rates of invasive cervical cancer after introduction of cytological screening. Cancer Causes Control. 1997;8:755-63. [pmid: 9328198].
5 U.S. Preventive Services Task Force. Screening for cervical cancer: recommendations and rationale. Guide to Clinical Preventive Services. 3rd ed. Rockville, MD. Agency for Healthcare Research and Quality. 2003.
6 Arbyn M, Bergeron C, Klinkhamer P, et al. Liquid compared with conventional cervical cytology: a systematic review and meta-analysis. Obstet Gynecol. 2008;111:167-77. [pmid: 18165406].
7 Davey E, Barratt A, Irwig L, et al. Effect of study design and quality on unsatisfactory rates, cytology classifications, and accuracy in liquid-based versus conventional cervical cytology: a systematic review. Lancet. 2006;367:122-32. [pmid: 16413876].
8 Mayrand MH, Duarte-Franco E, Rodrigues I, et al. Human papillomavirus DNA versus Papanicolaou screening tests for cervical cancer. New Engl J Med. 2007;357:1579-88. [pmid: 17942871].
9 McCrory D, Matchar D, Bastian L. Evaluation of Cervical Cytology: Evidence Report/Technology Assessment No. 5. AHCPR Publication No. 99-E010. Rockville, MD. Agency for Health Care Policy and Research. 1999. Accessed at http://www.ncbi.nlm.nih.gov/books/NBK32961/. 28 April 2011.
10 Smith RA, Cokkinides V, Eyre HJ. American Cancer Society guideline for the early detection of cancer, 2006. CA Cancer J Clin. 2006;56:11-25. [pmid: 16449183].
11 Clifford GM, Smith JS, Aguado T, et al. Comparison of HPV type distribution in high-grade cervical lesions and cervical cancer: a meta-analysis. Br J Cancer. 2003;89:101-5. [pmid: 12838308].
12 Clifford GM, Smith JS, Plummer M, et al. Human papillomavirus types in invasive cervical cancer worldwide: a meta-analysis. Br J Cancer. 2003;88:63-73. [pmid: 12556961].
13 Dunne EF, Unger ER, Sternberg M, et al. Prevalence of HPV infection among females in the United States. JAMA. 2007;297:813-9. [pmid: 17327523].
14 Kulasingam SL, Hughes JP, Kiviat NB, et al. Evaluation of human papillomavirus testing in primary screening for cervical abnormalities: comparison of sensitivity, specificity, and frequency of referral. JAMA. 2002;288:1749-57. [pmid: 12365959].
15 Schiffman M, Kjaer SK. Chapter 2: natural history of anogenital human papillomavirus infection and neoplasia. J Natl Cancer Inst Monogr. 2003;(31):14-9. [pmid: 12807940].
16 Castle PE, Schiffman M, Herrero R, et al. A prospective study of age trends in cervical human papillomavirus acquisition and persistence in Guanacaste, Costa Rica. J Infect Dis. 2005;191:1808-16. [pmid: 15871112].
17 Myers ER, McCrory DC, Nanda K, et al. Mathematical model for the natural history of human papillomavirus infection and cervical carcinogenesis. Am J Epidemiol. 2000;151:1158-71. [pmid: 10905528].
18 Bidus MA, Maxwell GL, Kulasingam S, et al. Cost-effectiveness analysis of liquid-based cytology and human papillomavirus testing in cervical cancer screening. Obstet Gynecol. 2006;107:997-1005. [pmid: 16648402].
19 Kulasingam S, Benard S, Barnabas R, et al. Adding a quadrivalent human papillomavirus vaccine to the UK Cervical Cancer Screening Programme: a cost-effectiveness analysis. Cost Eff Resour Alloc. 2008;6:4. [pmid: 18279515].
20 Kulasingam SL, Myers ER. Potential health and economic impact of adding a human papillomavirus vaccine to screening programs. JAMA. 2003;290:781-9. [pmid: 12915431].
21 Sawaya GF, McConnell KJ, Kulasingam SL, et al. Risk of cervical cancer associated with extending the interval between cervical-cancer screenings. New Engl J Med. 2003;349:1501-9. [pmid: 14561792].
22 Winer RL, Kiviat NB, Hughes JP, et al. Development and duration of human papillomavirus lesions, after initial infection. J Infect Dis. 2005;191:731-8. [pmid: 15688287].
23 Woodman CB, Collins S, Winter H, et al. Natural history of cervical human papillomavirus infection in young women: a longitudinal cohort study. Lancet. 2001;357:1831-6. [pmid: 11410191].
24 Baseman JG, Koutsky LA. The epidemiology of human papillomavirus infections. J Clin Virol. 2005;32(Suppl 1):S16-S24. [pmid: 15753008].
25 McCredie MR, Sharples KJ, Paul C, et al. Natural history of cervical neoplasia and risk of invasive cancer in women with cervical intraepithelial neoplasia 3: a retrospective cohort study. Lancet Oncol. 2008;9:425-34. [pmid: 18407790].
26 Sasieni P, Castanon A, Parkin DM. How many cervical cancers are prevented by treatment of screen-detected disease in young women?. Int J Cancer. 2009;124:461-4. [pmid: 18844220].
27 ASCUS-LSIL Traige Study (ALTS) Group. Results of a randomized trial on the management of cytology interpretations of atypical squamous cells of undetermined significance. Am J Obstet Gynecol. 2003;188:1383-92. [pmid: 12824967].
28 Fuchs K, Weitzen S, Wu L, et al. Management of cervical intraepithelial neoplasia 2 in adolescent and young women. J Pediatr Adolesc Gynecol. 2007;20:269-74. [pmid: 17868892].
29 Carreon JD, Sherman ME, Guillen D, et al. CIN2 is a much less reproducible and less valid diagnosis than CIN3: results from a histological review of population-based cervical samples. Int J Gynecol Pathol. 2007;26:441-6. [pmid: 17885496].
30 Cai B, Ronnett BM, Stoler M, et al. Longitudinal evaluation of interobserver and intraobserver agreement of cervical intraepithelial neoplasia diagnosis among an experienced panel of gynecologic pathologists. Am J Surg Pathol. 2007;31:1854-60. [pmid: 18043039].
31 Wright TC Jr, Massad LS, Dunton CJ, et al. 2006 consensus guidelines for the management of women with cervical intraepithelial neoplasia or adenocarcinoma in situ. Am J Obstet Gynecol. 2007;197:340-345. [pmid: 17904956].
32 Insinga RP, Glass AG, Rush BB. Diagnoses and outcomes in cervical cancer screening: a population-based study. Am J Obstet Gynecol. 2004;191:105-13. [pmid: 15295350].
33 American Society for Colposcopy and Cervical Pathology. 2006 Consensus Guidelines. Hagerstown, MD. American Society for Colposcopy and Cervical Pathology. 2011. Accessed at http://www.asccp.org/ConsensusGuidelines/tabid/7436/Default.aspx. 28 April 2011.
34 Saslow D, Runowicz CD, Solomon D, et al. American Cancer Society guideline for the early detection of cervical neoplasia and cancer. CA Cancer J Clin. 2002;52:342-62. [pmid: 12469763].
35 Vesco KK, Whitlock EP, Eder M, et al. Screening for Cervical Cancer: A Systematic Evidence Review for the US Preventive Services Task Force. Evidence Report No. 86. AHRQ Publication No. 11-05156-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
36 Koliopoulos G, Arbyn M, Martin-Hirsch P, et al. Diagnostic accuracy of human papillomavirus testing in primary cervical screening: a systematic review and meta-analysis of non-randomized studies. Gynecol Oncol. 2007;104:232-46. [pmid: 17084886].
37 Bigras G, de Marval F. The probability for a Pap test to be abnormal is directly proportional to HPV viral load: results from a Swiss study comparing HPV testing and liquid-based cytology to detect cervical cancer precursors in 13,842 women. Br J Cancer. 2005;93:575-81. [pmid: 16136031].
38 Cochand-Priollet B, Le Gales C, de Cremoux P, et al. Cost-effectiveness of monolayers and human papillomavirus testing compared to that of conventional Papanicolaou smears for cervical cancer screening: protocol of the study of the French Society of Clinical Cytology. Diagn Cytopathol. 2001;24:412-20. [pmid: 11391824].
39 de Cremoux P, Coste J, Sastre-Garau X, et al. Efficiency of the Hybrid Capture 2 HPV DNA test in cervical cancer screening: a study by the French Society of Clinical Cytology. Am J Clin Pathol. 2003;120:492-9. [pmid: 14560561].
40 Coste J, Cochand-Priollet B, de Cremoux P, et al. Cross sectional study of conventional cervical smear, monolayer cytology, and human papillomavirus DNA testing for cervical cancer screening. BMJ. 2003;326:733. [pmid: 12676841].
41 Mayrand MH, Duarte-Franco E, Coutlee F, et al. Randomized controlled trial of human papillomavirus testing versus Pap cytology in the primary screening for cervical cancer precursors: design, methods and preliminary accrual results of the Canadian Cervical Cancer Screening Trial (CCCaST). Int J Cancer. 2006;119:615-23. [pmid: 16572425].
42 Petry KU, Menton S, Menton M, et al. Inclusion of HPV testing in routine cervical cancer screening for women above 29 years in Germany: results for 8466 patients. Br J Cancer. 2003;88:1570-7. [pmid: 12771924].
43 Cardenas-Turanzas M, Nogueras-Gonzalez GM, Scheurer ME, et al. The performance of human papillomavirus high-risk DNA testing in the screening and diagnostic settings. Cancer Epidemiol Biomarkers Prev. 2008;17:2865-71. [pmid: 18843032].
44 Manos MM, Kinney WK, Hurley LB, et al. Identifying women with cervical neoplasia: using human papillomavirus DNA testing for equivocal Papanicolaou results. JAMA. 1999;281:1605-10. [pmid: 10235153].
45 Bergeron C, Jeannel D, Poveda J, et al. Human papillomavirus testing in women with mild cytologic atypia. Obstet Gynecol. 2000;95(6 Pt 1):821-7. [pmid: 10831974].
46 Andersson S, Dillner L, Elfgren K, et al. A comparison of the human papillomavirus test and Papanicolaou smear as a second screening method for women with minor cytological abnormalities. Acta Obstet Gynecol Scand. 2005;84:996-1000. [pmid: 16167918].
47 Del Mistro A, Frayle-Salamanca H, Trevisan R, et al. Triage of women with atypical squamous cells of undetermined significance (ASC-US): results of an Italian multicentric study. Gynecol Oncol. 2010;117:77-81. [pmid: 20116836].
48 Mitchell MF, Schottenfeld D, Tortolero-Luna G, et al. Colposcopy for the diagnosis of squamous intraepithelial lesions: a meta-analysis. Obstet Gynecol. 1998;91:626-31. [pmid: 9540955].
49 Chacho MS, Mattie ME, Schwartz PE. Cytohistologic correlation rates between conventional Papanicolaou smears and ThinPrep cervical cytology: a comparison. Cancer. 2003;99:135-40. [pmid: 12811853].
50 Ronco G, Cuzick J, Pierotti P, et al. Accuracy of liquid based versus conventional cytology: overall results of New Technologies For Cervical Cancer screening randomized control trial. BMJ. 2007;335:28. [pmid: 17517761].
51 Balasubramanian A. Message detailing conditional probabilities of cytology given histology. Kulasingam DS. December. 14. 2007.
52 Simsir A, Ioffe O, Sun P, et al. Effect of Bethesda 2001 on reporting of atypical squamous cells (ASC) with special emphasis on atypical squamous cells-cannot rule out high grade (ASC-H). Diagn Cytopathol. 2006;34:62-6. [pmid: 16355376].
53 Schabert VF, Ye X, Insinga RP, et al. Five-year routine cervical cancer screening rates and intervals in a US health plan. Curr Med Res Opin. 2008;24:2429-35. [pmid: 18662493].
54 Suarez L, Goldman DA, Weiss NS. Validity of Pap smear and mammogram self-reports in a low-income Hispanic population. Am J Prev Med. 1995;11:94-8. [pmid: 7632456].
55 Paskett ED, Tatum CM, Mack DW, et al. Validation of self-reported breast and cervical cancer screening tests among low-income minority women. Cancer Epidemiol Biomarkers Prev. 1996;5:721-6. [pmid: 8877064].
56 McGovern PG, Lurie N, Margolis KL, et al. Accuracy of self-report of mammography and Pap smear in a low-income urban population. Am J Prev Med. 1998;14:201-8. [pmid: 9569221].
57 McPhee SJ, Nguyen TT, Shema SJ, et al. Validation of recall of breast and cervical cancer screening by women in an ethnically diverse population. Prev Med. 2002;35:463-73. [pmid: 12431895].
58 Martinez GM, Chandra A, Abma JC, et al. Fertility, contraception, and fatherhood: data on men and women from cycle 6 (2002) of the 2002 National Survey of Family Growth. Vital Health Stat 23. 2006;(26):1-142. [pmid: 16900800].
59 Hartmann KE, Hall SA, Nanda K, et al. Screening for Cervical Cancer Systematic. Evidence Review No. 25. Rockville, MD. Agency for Healthcare Research and Quality. 2002. Accessed at http://www.ncbi.nlm.nih.gov/books/NBK42831/. 28 April 2011.
60 Ries LA, Melbert D, Krapcho M, et al., editors. SEER Cancer Statistics Review, 1975-2004. Bethesda, MD. National Cancer Institute. 2007. Accessed at http://www.seer.cancer.gov/csr/1975_2004/. 28 April 2011.
61 Insinga RP, Glass AG, Rush BB. Pap screening in a US health plan. Cancer Epidemiol Biomarkers Prev. 2004;13:355-60. [pmid: 15006908].
62 Arbyn M, Kyrgiou M, Simoens C, et al. Perinatal mortality and other severe adverse pregnancy outcomes associated with treatment of cervical intraepithelial neoplasia: meta-analysis. BMJ. 2008;337:a1284. [pmid: 18801868].
63 Sadler L, Saftlas A, Wang W, et al. Treatment for cervical intraepithelial neoplasia and risk of preterm delivery. JAMA. 2004;291:2100-6. [pmid: 15126438].
64 Wright TC Jr, Massad L, Dunton C, et al. 2006 consensus guidelines for the management of women with abnormal cervical cancer screening tests. Am J Obstet Gynecol. 2007;197:346-55. [pmid: 17904957].
65 Zauber A, Lansdorp-Vogelaar I, Knudsen A, et al. Evaluating Test Strategies for Colorectal Cancer Screening—Age to Begin, Age to Stop, and Timing of Screening Intervals: A Decision Analysis of Colorectal Cancer Screening for the U.S. Preventive Services Task Force from the Cancer Intervention and Surveillance Modeling Network (CISNET). Evidence Synthesis No. 65.2. Rockville, MD. Agency for Healthcare Research and Quality. 2009. Accessed at http://www.ncbi.nlm.nih.gov/books/NBK34013/. 28 April 2011.
66 Sonnenberg FA, Beck JR. Markov models in medical decision making: a practical guide. Med Decis Making. 1993;13:322-38. [pmid: 8246705].
67 Schorge JO, Knowles LM, Lea JS. Adenocarcinoma of the cervix. Curr Treat Options Oncol. 2004;5:119-27. [pmid: 14990206].
68 Keshavarz H, Hillis SD, Kieke BA, Marchbanks PA. Hysterectomy surveillance—United States, 1994-1999. MMWR CDC Surveill Summ. 2002;51(SS-5):1-8.
69 Ratnam S, Franco EL, Ferenczy A. Human papillomavirus testing for primary screening of cervical cancer precursors. Cancer Epidemiol Biomarkers Prev. 2000;9:945-51. [pmid: 11008913].
70 Koutsky LA, Holmes KK, Critchlow CW, et al. A cohort study of the risk of cervical intraepithelial neoplasia grade 2 or 3 in relation to papillomavirus infection. New Engl J Med. 1992;327:1272-8. [pmid: 1328880].
71 Ho GY, Bierman R, Beardsley L, et al. Natural history of cervicovaginal papillomavirus infection in young women. New Engl J Med. 1998;338:423-8. [pmid: 9459645].
72 Moscicki AB, Hills N, Shiboski S, et al. Risks for incident human papillomavirus infection and low-grade squamous intraepithelial lesion development in young females. JAMA. 2001;285:2995-3002. [pmid: 11410098].
73 de Brux J, Orth G, Croissant O, et al. Condylomatous lesions of the uterine cervix: their course in 2466 patients [in French]. Bull Cancer. 1983;70:410-22. [pmid: 6686786].
74 Syrjanen K, Kataja V, Yliskoski M, et al. Natural history of cervical human papillomavirus lesions does not substantiate the biologic relevance of the Bethesda System. Obstet Gynecol. 1992;79(5 Pt 1):675-82. [pmid: 1314359].
75 Kataja V, Syrjanen K, Mantyjarvi R, et al. Prospective follow-up of cervical HPV infections: life table analysis of histopathological, cytological and colposcopic data. Eur J Epidemiol. 1989;5:1-7. [pmid: 2540024].
76 De Aloysio D, Miliffi L, Iannicelli T, et al. Intramuscular interferon-beta treatment of cervical intraepithelial neoplasia II associated with human papillomavirus infection. Acta Obstet Gynecol Scand. 1994;73:420-4. [pmid: 8009976].
77 Matsumoto K, Yasugi T, Oki A, et al. IgG antibodies to HPV16, 52, 58 and 6 L1-capsids and spontaneous regression of cervical intraepithelial neoplasia. Cancer Lett. 2006;231:309-13. [pmid: 16399232].
78 Minino A, Heron M, Murphy S, et al. Deaths: final data for 2004. Natl Vital Stat Rep. 2007;55:1-1190. [pmid: 17867520].