# Purpose and Specific Aims

The purpose of this report is to provide data to address the following two specific aims outlined by the USPSTF.

## Specific Aim 1

To estimate expected colposcopies, life-years, and colposcopies per life-year gained using cytology, with a repeat cytology test for results of ASC-US, to determine the appropriate age at which to begin screening (varying in 1-year increments from ages 15 to 25 years).

### Sub-Aim 1

To estimate expected colposcopies, life-years, and colposcopies per life-year gained using cytology, with a repeat cytology test for results of ASC-US, to determine the appropriate age at which to end screening (varying in 5-year increments from ages 65 to 90 years).

### Sub-Aim 2

To estimate expected colposcopies, life-years, and colposcopies per life-year gained based on screening intervals of 1, 2, 3, or 5 years, to determine the appropriate screening interval and whether it varies by age at which to begin and end screening.

## Specific Aim 2

To estimate expected colposcopies, life-years, and colposcopies per life-year gained associated with screening strategies that use HPV DNA testing in conjunction with cytology, compared to strategies that use cytology only.

### Sub-Aim 1

To estimate expected colposcopies, life-years, and colposcopies per life-year gained based on screening intervals of 1, 2, 3, or 5 years, to determine the appropriate screening interval.