# Discussion

We conducted a decision analysis to determine the number of colposcopies per life-year associated with cervical cancer screening strategies that differed based on the age at which to start and end screening, the screening interval, and the screening test (cytology alone or in combination with HPV).

In terms of the age at which to begin screening, screening in the teens is associated with a high number of colposcopies but small gains in life expectancy. In addition, a large percentage of high-grade lesions are estimated to be CIN2, which is more likely to regress in younger women. As such, detection of CIN2-3 in this population may result in overdiagnosis and treatment. This is important because studies of cone or loop electrosurgical excision procedure treatments for CIN in reproductive-aged women have been associated with an increased risk of adverse pregnancy outcomes.62-63 If the age at first screening is delayed past age 21 years, there is an increasing risk of cancer for each year that screening is delayed. Although these findings are relatively robust, it should be noted that the measure of colposcopies per life-year gained may be misleading in terms of the burden of screening, as well as resource use, when applied to adolescents, since the latest ASCCP guidelines recommend repeated screening prior to referral for colposcopy in women younger than age 21 years.64 If a measure of screening cytology tests per life-year is used, screening beginning at age 21 years and conducted at least every 3 years, as currently recommended by the USPSTF, is also identified as a strategy that provides a reasonable trade-off between the burden and benefits of screening.

In terms of the age at which to end screening, these results support the current recommendation that women who have been screened frequently until age 65 years should no longer be screened. In this group, there are small gains in life expectancy associated with a large number of colposcopies. For women who have never been screened prior to age 65 years, these analyses suggest that a few additional screenings for these women, ending in the mid-70s, result in increased life expectancy; after this, there are diminishing gains in life expectancy, with large increases in the number of colposcopies.

Our results for HPV testing in conjunction with cytology demonstrate that the choice of strategy (cytology only or cytology and HPV [co-testing]) is sensitive to the metric chosen to quantify the burden of testing. Although cytology and HPV (co-testing) is identified as an efficient strategy using colposcopies per life-year, cytology-only strategies are identified as efficient if tests are used to quantify burden of screening. The analysis in which HPV testing is followed by cytology for women who are HPV positive suggests that this strategy warrants further study.

A limitation of this analysis is the use of colposcopies per life-year gained. This metric was chosen by the USPSTF as a measure that better captures the clinical burden and benefits of screening than cost per life-year. However, depending on the strategy modeled, not all women with abnormal test results are triaged to immediate colposcopy; some undergo repeat testing. As a result, our findings for some of the analyses, especially those that include HPV in addition to cytology, are sensitive to whether tests or colposcopies are used to quantify screening burden. It is also unclear to what extent colposcopies represent a burden to women who undergo cervical cancer screening and what threshold of colposcopies per life-year gained should be used to define “high burden.” A related issue is the definition of efficient in this analysis; while we highlighted strategies that fall on the steepest part of the curve, the incremental colposcopies per life-year associated with these strategies vary from one question to the next. Another issue is that the choice of strategies using this metric may not be consistent with those using the more traditional metrics of cost per life-year or cost per quality-adjusted life year (QALY). This is of particular concern, since there are known differences in costs, such as the costs of the tests examined in this report, that are not captured in these analyses. As such, the results of these analyses should be interpreted with caution and should not be directly compared with the results of other analyses that report different metrics. The extent to which “optimal” strategies identified by using a metric such as colposcopies/life-year or colonoscopies/life-year correlate with those identified by cost/life-year or cost/QALY is an important topic for further methodologic development.

Other potential limitations are the presentation of results per 1,000 women, and the small differences in disease outcomes which may well be within the margin of error associated with the different parameters used in the model. The USPSTF requested that the results be presented per 1,000 women for consistency with a previous decision analysis for colorectal cancer,65 so that comparisons could be made. As noted, however, many of the differences in disease outcomes between the strategies, particularly cancer cases and deaths, are small and differ only when a denominator of 100,000 is used. These small differences translate into very small differences in life expectancy between strategies and underscore the fact that the greatest gains from screening will always be from screening unscreened or underscreened women.