# Conclusions

In conclusion, this decision analysis supports current recommendations regarding the age at which to begin and end screening. In terms of the screening interval, strategies conducted every 3 to 5 years consistently fall on the steepest part of the efficiency frontier, suggesting that these intervals may provide a reasonable balance between the burden and benefits of screening. Strategies that include HPV in addition to cytology (co-testing) are sensitive to the use of either tests or colposcopies to quantify the burden of screening. Co-testing strategies are identified as efficient across a range of analyses and test accuracy estimates if colposcopies are used to quantify burden. However, cytology-only strategies are identified as efficient if tests are used to quantify burden. Finally, our analyses suggest that a strategy of HPV followed by cytology for HPV positive women may provide a reasonable trade-off between the burden and benefits of screening and warrants further study.