# Background

Worldwide, carcinoma of the cervix is one of the most common malignancies in women.1 In the United States in 2010, approximately 12,200 women were expected to be diagnosed with cervical cancer, and 4,210 women were expected to die.2 Assuming no change in risk, approximately 0.68 percent of women born today will be diagnosed with cervical cancer at some time during their lifetime, and the risk of dying from the disease is 0.24 percent.

The incidence of cervical cancer and associated mortality have both decreased by over 40 percent since 1973.^3^ These declines are largely attributable to the success of mass screening using the Papanicolaou (Pap) cytology test to diagnose premalignant or early-stage disease.4 The decrease in invasive cervical cancer incidence and mortality since the introduction of this test has been so dramatic that it is one of the few interventions to receive an “A” recommendation from the U.S. Preventive Services Task Force (USPSTF).5

Despite the impact of cytology-based screening, there is still uncertainty about the details of cytology test performance, with specific concerns surrounding the poor sensitivity of cytology for detection of cervical intraepithelial neoplasia (CIN) grades 2 and 3.^6-9^ Efforts to improve cytology test performance have focused on reducing the number of false-negative smears; that is, cases in which premalignant or malignant cells are not diagnosed either because of sampling error (failure to place abnormal cells on the slide) or detection error (abnormal cells are misdiagnosed as normal).

The human papillomavirus (HPV) deoxyribonucleic acid (DNA) test is currently recommended for use in cervical cancer screening.10 Squamous cell carcinoma of the cervix and its cytologic precursors occur among women who are sexually active. Infection with high-risk types of HPV, acquired sexually, is the most important risk factor for cervical cancer. Based on sensitive HPV detection methods, 95 to 100 percent of squamous cell cervical cancer and 75 to 95 percent of CIN2-3 lesions have detectable HPV DNA.11-12 In the United States, peak incidence and prevalence of HPV infection occur among women younger than age 25 years,13-15 but most infections in younger women are transient. HPV infections in older women are much less prevalent, but may carry a higher risk of progression to cervical neoplasia.16 As such, the American Cancer Society currently recommends that HPV testing be limited to women aged 30 years and older as part of a strategy of combination screening with cytology.10 HPV DNA tests currently approved for use in the United States include the Cervista HPV HR (Hologic, Inc., Bedford, MA), the Cervista HPV 16/18 (Hologic, Inc., Bedford, MA), and the Hybrid Capture 2 (HC2) high-risk HPV DNA test (Qiagen Inc., Germantown, MD). In its previous recommendations, the USPSTF concluded that the evidence was insufficient to recommend for or against the routine use of HPV testing as a screening test for cervical cancer, although the U.S. Food and Drug Administration approved the use of HPV DNA testing for triage of atypical squamous cells of undetermined significance (ASC-US) or in conjunction with cytology for women aged 30 years or older. Quantifying the harms and benefits of HPV testing in order to inform any changes to the existing recommendations is one focus of this report. For the purposes of this report, HPV testing refers to use of the HC2 test only.

Other questions addressed in this report include the optimal ages at which to begin and end screening, as well as the interval at which screening should be conducted. Currently, the USPSTF recommends that women begin screening within 3 years of onset of sexual activity or at age 21 years (whichever comes first), and that screening be conducted at least every 3 years.5 In terms of the age at which to end screening, the USPSTF recommendation states that screening should not be routinely recommended for women aged 65 years or older who have a history of normal Pap tests and are not otherwise at high risk for cervical cancer. Despite these recommendations, the summary states that direct evidence to estimate the optimal starting and stopping age and interval for screening is limited.5

This report summarizes the results from a decision analysis conducted using a previously developed and validated cervical cancer decision model.9 The Duke Cervical Cancer model was originally developed as part of a review of new screening technologies for the Agency for Healthcare Research and Quality.17 The model has been used to estimate the effectiveness of new screening technologies in a number of different settings and populations.18-21 It can be updated to incorporate the best available evidence on the natural history of HPV and cervical cancer, as well as new screening tests, to project various outcomes, such as life-years gained. The model is now used to provide evidence to answer two questions posed by the USPSTF concerning the age at which to begin screening and the use of HPV DNA tests. These questions are presented in the form of specific aims and have been worded to complement the key questions and contextual questions posed by the USPSTF to the Oregon Evidence-based Practice Center (EPC). Operational decisions and model outcomes are presented in Appendix A. Appendix B provides a summary of the model, including model inputs for the natural history component of the model. Appendix C presents the criteria used to select studies for estimating the sensitivity and specificity of cytology and HPV DNA testing. Key inputs and changes to the model to address the specific aims are discussed below.