# Appendixes

Appendix A Operational Decisions Made in Conjunction With the U.S. Preventive Services Task Force

Appendix B Model Description

Appendix C Selection Criteria for Studies Used to Estimate Sensitivity and Specificity of Cytology and HPV DNA Testing