# Addendum

## Summary of New Analyses

The model analyses presented here were performed after the publication of the original report. These new analyses are based on a strategy of screening with cytology every 3 years (q3) before age 30 years and then after age 30 years, co-testing every 5 years (q5) in women with HPV negative/cytology normal results (referred to as “Cytology, q3, age 21; Cytology and HPV, q5, age 30”).

As shown in the outcomes tables, this strategy only dominates cytology conducted every 3 years (based on a comparison of expected colposcopies and cancer), using estimates from Mayrand et al (8) and Vesco et al (35).

Sensitivity analyses show that whether co-testing strategies conducted at different intervals are identified as “efficient” depends on the metric used to quantify burden (HPV testing or expected colposcopies). The results are also sensitive to whether a strategy of HPV testing followed by cytology in women who test HPV positive is modeled. This strategy dominates co-testing regardless of whether HPV testing or expected colposcopies is used to quantify burden.

## Modeling Strategies

### HPV and Cytology (Co-testing)

For this strategy, women younger than age 30 years are assumed to be screened with cytology only, with repeat cytology for ASC-US results or referral to immediate colposcopy for results of ASC-H or LSIL+. The interval for screening before age 30 years varied from 1 to 3 years. Women ages 30 years and older are assumed to receive HPV testing and cytology. Women with LSIL+ cytology results or ASC-US cytology results with a positive HPV test result are assumed to be referred to colposcopy. Women with an ASC-US cytology result who have a negative HPV test result are assumed to undergo repeat testing in 1 year. Women with a normal cytology test result but a positive HPV test result are assumed to undergo repeat testing with both tests in 1 year, and if either is abnormal they are referred to colposcopy. Women with normal cytology and negative HPV test results are assumed to return to routine screening conducted every 3 or 5 years. It should be noted that for this strategy, “routine screening” means a combination of intervals; that is, screening every 1, 2, or 3 years before age 30 in women with normal cytology results, and then every 3 or 5 years in women with normal cytology and HPV test results after age 30. Women are assumed to begin screening at age 21 years and to continue screening to age 85 years.

### HPV Followed by Cytology

For this strategy, women younger than age 30 years are assumed to be screened with cytology only, with repeat cytology for ASC-US results or referral to immediate colposcopy for results of ASC-H or LSIL+. All women ages 30 years and older are assumed to have an initial HPV test. Women who are HPV positive are assumed to receive cytology testing. If their cytology test result is ASC-US+, they are assumed to undergo colposcopy; if their cytology test result is normal, they are assumed to undergo repeat testing in 1 year, with referral to colposcopy if they have a subsequent abnormality. Women with negative HPV results are assumed to return to routine HPV-based screening conducted every 1, 2, 3, or 5 years. Women are assumed to begin screening at age 21 years and to continue screening to age 85 years.

Table 1 Sensitivity and Specificity of Cytology and HPV Testing for Primary Screening and Triage of Abnormal Cytology Results

Screening or Triage Test | Sensitivity for CIN2+ | Specificity for <CIN2 | Delta of HPV Compared to Cytology in Same Study
Screening or Triage Test | Sensitivity for CIN2+ | Specificity for <CIN2 | Sensitivity (CIN2+) | Specificity (CIN2+)
Cytology
EPC-QRS (2011)35 | 0.569 | 0.945
Mayrand et al (2007)8 | 0.564 | 0.973
Koliopoulos et al (2007)36 | 0.727 | 0.919
Range8,37,41-43 | 0.20–0.772 | 0.847–0.990
Triage for ASC-US44 | 0.762 | 0.638
Range45-47 | 0.45–0.956 | 0.475–0.756
HPV DNA (HC2)
EPC-QRS (2011)35 | 0.964 | 0.906 | 0.395 | -0.039
Mayrand et al (2007)8 | 0.974 | 0.943 | 0.41 | -0.03
Koliopoulos et al (2007)36 | 0.948 | 0.86 | 0.221 | -0.059
Range8,37,41-43 | 0.341–1.00 | 0.767–0.966
Triage for ASC-US44 | 0.892 | 0.641 | 0.13 | 0.003
Range45-47 | 0.67–0.976 | 0.31–0.672

## Outcomes Tables

Table 2 Vesco et al35: Expected False Positives, Colposcopies, CIN2-3 Cases, Cancer Cases, and Cancer Deaths Associated With Cytology and HPV Test-Based Strategies, Either Alone or in Combination^*^

Strategy | False Positives | Colposcopies | CIN2-3 Cases | Cancer Cases | Cancer Deaths
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 255.35 | 575.46 | 84.39 | 7.44 | 1.35
Cytology, q5, age 21 | 213.97 | 483.36 | 66.01 | 12.69 | 2.71
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 381.33 | 824.74 | 93.10 | 4.73 | 0.74
Cytology, q3, age 21 | 349.92 | 758.16 | 80.21 | 8.50 | 1.55
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 539.64 | 1129.39 | 94.39 | 3.64 | 0.52
Cytology, q2, age 21 | 515.26 | 1083.52 | 87.52 | 5.80 | 0.92
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 727.22 | 1488.19 | 95.19 | 2.57 | 0.35
Cytology, q1, age 21 | 951.45 | 1931.00 | 91.50 | 2.50 | 0.32

* Per 1,000 women. Time horizon is a lifetime. Age at which to begin screening is fixed at 21 years. For the combined cytology and HPV testing strategies, cytology-based screening is assumed before age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Women with normal cytology results and HPV negative results are assumed to be screened every 3 or 5 years.

Table 3 Mayrand et al8: Expected False Positives, Colposcopies, CIN2-3 Cases, Cancer Cases, and Cancer Deaths Associated With Cytology and HPV Test-Based Strategies, Either Alone or in Combination^*^

Strategy | False Positives | Colposcopies | CIN2-3 Cases | Cancer Cases | Cancer Deaths
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 117.70 | 323.00 | 86.36 | 7.74 | 1.42
Cytology, q5, age 21 | 100.94 | 274.01 | 66.93 | 13.15 | 2.81
Cytology, q3; age 21; Cytology and HPV, q3, age 30 | 175.67 | 446.38 | 96.53 | 5.02 | 0.79
Cytology, q3, age 21 | 165.52 | 416.44 | 82.61 | 8.97 | 1.65
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 252.91 | 600.90 | 99.35 | 3.94 | 0.57
Cytology, q2, age 21 | 244.38 | 580.58 | 91.71 | 6.24 | 0.99
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 348.59 | 790.56 | 101.93 | 2.82 | 0.38
Cytology, q1, age 21 | 464.75 | 1024.42 | 99.89 | 2.79 | 0.36

* Per 1,000 women. Time horizon is a lifetime. Age at which to begin screening is fixed at 21 years. For the combined cytology and HPV testing strategies, cytology-based screening is assumed before age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Women with normal cytology results and HPV negative results are assumed to be screened every 3 or 5 years.

Table 4 Koliopoulos et al36: Expected False Positives, Colposcopies, CIN2-3 Cases, Cancer Cases, and Cancer Deaths Associated With Cytology and HPV Test-Based Strategies, Either Alone or in Combination^*^

Strategy | False Positives | Colposcopies | CIN2-3 Cases | Cancer Cases | Cancer Deaths
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 401.90 | 832.28 | 85.13 | 6.62 | 1.08
Cytology, q5, age 21 | 328.93 | 693.97 | 74.85 | 9.76 | 1.86
Cytology, q3; age 21; Cytology and HPV, q3, age 30 | 600.89 | 1209.54 | 92.36 | 3.94 | 0.53
Cytology, q3, age 21 | 535.05 | 1090.56 | 86.16 | 5.98 | 0.95
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 834.47 | 1646.02 | 92.33 | 2.86 | 0.36
Cytology, q2, age 21 | 784.70 | 1563.96 | 90.13 | 3.79 | 0.51
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 1101.24 | 2141.58 | 91.41 | 1.92 | 0.23
Cytology, q1, age 21 | 1409.78 | 2744.25 | 88.30 | 1.37 | 0.16

* Per 1,000 women. Time horizon is a lifetime. Age at which to begin screening is fixed at 21 years. For the combined cytology and HPV testing strategies, cytology-based screening is assumed before age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing begins at age 30 years. Women with normal cytology results and HPV negative results are assumed to be screened every 3 or 5 years.

Table 5 Vesco et al35: Expected Colposcopies, Incremental Colposcopies, Life-Years, Incremental Life-Years, and Incremental Colposcopies per Life-Year (ICLY) for Strategies Identified as Efficient^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69016.30
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 575 | 575 | 69217.77 | 201.47 | 3
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 825 | 249 | 69233.80 | 16.03 | 16
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 1129 | 305 | 69240.06 | 6.27 | 49
Cytology, q1, Age 21; Cytology and HPV, q3, age 30 | 1488 | 359 | 69245.94 | 5.88 | 61
Cytology, q1, age 21 | 1931 | 443 | 69246.58 | 0.64 | 690

* Per 1,000 women. Women are assumed to begin screening at age 21 years.

Table 6 Mayrand et al8: Expected Colposcopies, Incremental Colposcopies, Life-Years, Incremental Life-Years, and Incremental Colposcopies per Life-Year (ICLY) for Strategies Identified as Efficient^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69016.30
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 323 | 323 | 69216.10 | 199.80 | 2
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 446 | 123 | 69232.50 | 16.40 | 8
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 601 | 155 | 69238.85 | 6.35 | 24
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 791 | 190 | 69245.03 | 6.19 | 31
Cytology, q1, age 21 | 1024 | 234 | 69245.57 | 0.54 | 433

* Per 1,000 women. Women are assumed to begin screening at age 21 years.

Table 7 Koliopoulos et al36: Expected Colposcopies, Incremental Colposcopies, Life-Years, Incremental Life-Years, and Incremental Colposcopies per Life-Year (ICLY) for Strategies Identified as Efficient^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69016.30
Cytology, q5, age 21 | 694 | 694 | 69205.11 | 188.81 | 4
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 832 | 138 | 69226.18 | 21.07 | 7
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 1210 | 377 | 69240.14 | 13.96 | 27
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 1646 | 436 | 69245.20 | 5.06 | 86
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 2142 | 496 | 69249.40 | 4.21 | 118
Cytology, q1, age 21 | 2744 | 603 | 69251.10 | 1.70 | 355

* Per 1,000 women. Women are assumed to begin screening at age 21 years.

## Sensitivity Analyses

Table 8 Vesco et al35: Expected Tests (Screening and Triage), Incremental Tests, Life-Years, Incremental Life-Years, and Incremental Tests per Life-Year (ITLY) for Strategies Identified as Efficient^*^

Strategy | Tests | Incremental Tests | Life-Years | Incremental Life-Years | ITLY
No intervention | 0 | | 69016.30
Cytology, q5, age 21 | 11190 | 11190 | 69182.25 | 165.95 | 67
Cytology, q3, age 21 | 18295 | 7105 | 69212.70 | 30.45 | 233
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 20341 | 2046 | 69217.77 | 5.07 | 404
Cytology, q2, age 21 | 26955 | 6614 | 69229.79 | 12.02 | 550
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 31924 | 4969 | 69233.80 | 4.01 | 1239
Cytology, q1, age 21 | 49887 | 17963 | 69246.58 | 12.78 | 1406

* Per 1,000 women. Age at which to begin screening is fixed at 21 years. For the combined cytology and HPV testing strategies, cytology-based screening is assumed before age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing is assumed to begin at age 30 years.

Table 9 Mayrand et al8: Expected Tests (Screening and Triage), Incremental Tests, Life-Years, Incremental Life-Years, and Incremental Tests per Life-Year (ITLY) for Strategies Identified as Efficient^*^

Strategy | Tests | Incremental Tests | Life-Years | Incremental Life-Years | ITLY
No intervention | 0 | | 69016.30
Cytology, q5, age 21 | 10754 | 10754 | 69179.46 | 163.16 | 66
Cytology, q3, age 21 | 17593 | 6839 | 69210.24 | 30.78 | 222
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 19619 | 2026 | 69216.10 | 5.86 | 346
Cytology, q2, age 21 | 25944 | 6325 | 69227.79 | 11.69 | 541
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 30797 | 4853 | 69232.50 | 4.71 | 1030
Cytology, q1, age 21 | 49315 | 18518 | 69245.57 | 13.07 | 1417

* Per 1,000 women. Age at which to begin screening is fixed at 21 years. For the combined cytology and HPV testing strategies, cytology-based screening is assumed before age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing is assumed to begin at age 30 years.

Table 10 Koliopoulos et al36: Expected Tests (Screening and Triage), Incremental Tests, Life-Years, Incremental Life-Years, and Incremental Tests per Life-Year (ITLY) for Strategies Identified as Efficient^*^

Strategy | Tests | Incremental Tests | Life-Years | Incremental Life-Years | ITLY
No intervention | 0 | | 69016.30
Cytology, q5, age 21 | 11658 | 11658 | 69205.11 | 188.81 | 62
Cytology, q3, age 21 | 18997 | 7339 | 69229.37 | 24.26 | 303
Cytology, q2, age 21 | 27929 | 8932 | 69241.12 | 11.75 | 760
Cytology, q1, age 21 | 50416 | 22487 | 69251.10 | 9.98 | 2253

* Per 1,000 women. Age at which to begin screening is fixed at 21 years. For the combined cytology and HPV testing strategies, cytology-based screening is assumed before age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing is assumed to begin at age 30 years.

Table 11 Vesco et al35: Expected Colposcopies, Incremental Colposcopies, Life-Years, Incremental Life-Years, and Incremental Colposcopies per Life-Year (ICLY) for Strategies Identified as Efficient^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69016.30
Cytology, q5, age 21; Cytology and HPV, q5, age 30 | 535 | 535 | 69214.72 | 198.42 | 3
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 575 | 40 | 69217.77 | 3.05 | 13
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 825 | 250 | 69233.80 | 16.03 | 16
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 1129 | 304 | 69240.06 | 6.26 | 49
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 1488 | 359 | 69245.94 | 5.88 | 61
Cytology, q1, age 21 | 1931 | 443 | 69246.58 | 0.64 | 692

* Per 1,000 women. Age at which to begin screening is fixed at 21 years. For the combined cytology and HPV testing strategies, cytology-based screening is assumed before age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing is assumed to begin at age 30 years.

Table 12 Mayrand et al8: Expected Colposcopies, Incremental Colposcopies, Life-Years, Incremental Life-Years, and Incremental Colposcopies per Life-Year (ICLY) for Strategies Identified as Efficient^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69016.30
Cytology, q5, age 21; Cytology and HPV, q5, age 30 | 303 | 303 | 69213.14 | 196.84 | 2
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 323 | 20 | 69216.10 | 2.96 | 7
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 446 | 123 | 69232.50 | 16.40 | 8
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 601 | 155 | 69238.85 | 6.35 | 24
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 791 | 190 | 69245.03 | 6.18 | 31
Cytology, q1, age 21 | 1024 | 233 | 69245.57 | 0.54 | 431

* Per 1,000 women. Age at which to begin screening is fixed at 21 years. For the combined cytology and HPV testing strategies, cytology-based screening is assumed before age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing is assumed to begin at age 30 years.

Table 13 Koliopoulos et al36: Expected Colposcopies, Incremental Colposcopies, Life-Years, Incremental Life-Years, and Incremental Colposcopies per Life-Year (ICLY) for Strategies Identified as Efficient^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69016.30
Cytology, q5, Age 21; Cytology and HPV, q5, Age 30 | 773 | 773 | 69223.52 | 207.22 | 4
Cytology, q3, Age 21; Cytology and HPV, q5, Age 30 | 832 | 59 | 69226.18 | 2.66 | 22
Cytology, q3, Age 21; Cytology and HPV, q3, Age 30 | 1210 | 378 | 69240.14 | 13.96 | 27
Cytology, q2, Age 21; Cytology and HPV, q3, Age 30 | 1646 | 436 | 69245.20 | 5.06 | 86
Cytology, q1, Age 21; Cytology and HPV, q3, Age 30 | 2142 | 496 | 69249.40 | 4.20 | 118
Cytology, q1, Age 21 | 2744 | 602 | 69251.10 | 1.70 | 354

* Per 1,000 women. Age at which to begin screening is fixed at 21 years. For the combined cytology and HPV testing strategies, cytology-based screening is assumed before age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing is assumed to begin at age 30 years.

Table 14 Vesco et al35: Sensitivity Analysis Varying Multiple Natural History Parameters^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69074.37
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 758 | 758 | 69222.11 | 147.74 | 5
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 1028 | 270 | 69235.69 | 13.58 | 20
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 1342 | 314 | 69241.13 | 5.44 | 58
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 1714 | 372 | 69246.53 | 5.40 | 69
Cytology, q1, age 21 | 2142 | 428 | 69246.75 | 0.22 | 1945

* Refer to Appendix B for details. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years. For the combined cytology and HPV strategies, cytology-based screening is assumed before age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing is assumed to begin at age 30 years.

Table 15 Mayrand et al8: Sensitivity Analysis Varying Multiple Natural History Parameters^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69074.37
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 502 | 502 | 69221.28 | 146.91 | 3
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 646 | 144 | 69234.99 | 13.71 | 11
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 810 | 164 | 69240.51 | 5.52 | 30
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 1012 | 202 | 69246.11 | 5.60 | 36
Cytology, q1, age 21 | 1239 | 227 | 69246.30 | 0.19 | 1195

* Refer to Appendix B for details. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years. For the combined cytology and HPV strategies, cytology-based screening is assumed before age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing is assumed to begin at age 30 years.

Table 16 Koliopoulos et al36: Sensitivity Analysis Varying Multiple Natural History Parameters^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69074.37
Cytology, q5, age 21 | 856 | 856 | 69210.82 | 136.45 | 6
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 1027 | 171 | 69228.57 | 17.75 | 10
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 1426 | 399 | 69240.81 | 12.24 | 33
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 1874 | 448 | 69245.51 | 4.70 | 95
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 2385 | 511 | 69249.75 | 4.24 | 121
Cytology, q1, age 21 | 2969 | 584 | 69251.13 | 1.38 | 423

* Refer to Appendix B for details. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years. For the combined cytology and HPV strategies, cytology-based screening is assumed before age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing is assumed to begin at age 30 years.

Table 17 Vesco et al35: Sensitivity Analysis Varying Estimates of Screening Adherence^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69016.30
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 262 | 262 | 69155.13 | 138.83 | 2
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 367 | 105 | 69183.39 | 28.26 | 4
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 526 | 159 | 69203.85 | 20.46 | 8
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 770 | 244 | 69225.94 | 22.09 | 11

* Adherence to screening is assumed to be <100%. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years. For the combined cytology and HPV strategies, cytology-based screening is assumed before age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing is assumed to begin at age 30 years.

Table 18 Mayrand et al8: Sensitivity Analysis Varying Estimates of Screening Adherence^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69016.30
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 153 | 153 | 69153.21 | 136.91 | 1
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 208 | 55 | 69181.46 | 28.25 | 2
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 292 | 84 | 69201.93 | 20.47 | 4
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 417 | 125 | 69224.30 | 22.37 | 6

* Adherence to screening is assumed to be <100%. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years. For the combined cytology and HPV strategies, cytology-based screening is assumed before age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing is assumed to begin at age 30 years.

Table 19 Koliopoulos et al36: Sensitivity Analysis Varying Estimates of Screening Adherence^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69016.30
Cytology, q5, age 21 | 303 | 303 | 69140.40 | 124.10 | 2
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 374 | 71 | 69164.08 | 23.68 | 3
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 528 | 154 | 69191.65 | 27.57 | 6
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 760 | 232 | 69211.64 | 19.99 | 12
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 1114 | 354 | 69231.74 | 20.10 | 18

* Adherence to screening is assumed to be <100%. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years. For the combined cytology and HPV strategies, cytology-based screening is assumed before age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing is assumed to begin at age 30 years.

Table 20 Vesco et al35: Sensitivity Analysis Including a Strategy of HPV Testing Followed by Cytology if HPV Positive^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69016.30
HPV followed by cytology, q5, age 30 | 234 | 234 | 69211.89 | 195.59 | 1
HPV followed by cytology, q3, age 30 | 301 | 66 | 69231.50 | 19.61 | 3
HPV followed by cytology, q2, age 30 | 423 | 122 | 69239.62 | 8.12 | 15
HPV followed by cytology, q1, age 30 | 643 | 220 | 69247.71 | 8.09 | 27

* Assumes a strategy of HPV testing first, followed by cytology if HPV positive, for women ages 30 years and older. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years.

Table 21 Mayrand et al8: Sensitivity Analysis Including a Strategy of HPV Testing Followed by Cytology if HPV Positive^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69016.30
HPV followed by cytology, q5, age 30 | 154 | 154 | 69211.41 | 195.11 | 1
HPV followed by cytology, q3, age 30 | 190 | 36 | 69231.08 | 19.67 | 2
HPV followed by cytology, q2, age 30 | 246 | 56 | 69239.32 | 8.24 | 7
HPV followed by cytology, q1, age 30 | 351 | 105 | 69247.51 | 8.19 | 13

* Assumes a strategy of HPV testing first, followed by cytology if HPV positive, for women ages 30 years and older. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years.

Table 22 Koliopoulos et al36: Sensitivity Analysis of a Strategy of HPV Testing Followed by Cytology if HPV Positive^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69016.30
HPV followed by cytology, q5, age 30 | 334 | 334 | 69219.18 | 202.88 | 2
HPV followed by cytology, q3, age 30 | 436 | 102 | 69237.06 | 17.88 | 6
HPV followed by cytology, q2, age 30 | 632 | 196 | 69244.12 | 7.06 | 28
HPV followed by cytology, q1, age 30 | 975 | 343 | 69250.53 | 6.41 | 54
Cytology, q1, age 21 | 2744 | 1769 | 69251.10 | 0.57 | 3104

* Assumes a strategy of HPV testing first, followed by cytology if HPV positive, for women ages 30 years and older. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years.

Table 23 Vesco et al35: Sensitivity Analysis Showing Expected Tests (Screening and Triage), Incremental Tests, Life-Years, Incremental Life-Years, and Incremental Tests per Life-Year (ITLY) for Strategies Identified as Efficient^*^

Strategy | Tests | Incremental Tests | Life-Years | Incremental Life-Years | ITLY
No intervention | 0 | | 69016.30
Cytology, q5, age 21 | 11190 | 11190 | 69182.25 | 165.95 | 67
HPV followed by cytology, q5, age 30 | 13223 | 2033 | 69211.89 | 29.64 | 69
HPV followed by cytology, q3, age 30 | 20842 | 7619 | 69231.50 | 19.61 | 389
HPV followed by cytology, q2, age 30 | 29748 | 8906 | 69239.62 | 8.12 | 1097
HPV followed by cytology, q1, age 30 | 53079 | 23331 | 69247.71 | 8.09 | 2884

* Per 1,000 women. Assumes a strategy of HPV testing first, followed by cytology if HPV positive, for women ages 30 years and older. Women are assumed to begin screening at age 21 years.

Table 24 Mayrand et al8: Sensitivity Analysis Showing Expected Tests (Screening and Triage), Incremental Tests, Life-Years, Incremental Life-Years, and Incremental Tests per Life-Year (ITLY) for Strategies Identified as Efficient^*^

Strategy | Tests | Incremental Tests | Life-Years | Incremental Life-Years | ITLY
No intervention | 0 | | 69016.30
HPV followed by cytology, q5, age 30 | 12168 | 12168 | 69211.41 | 195.11 | 62
HPV followed by cytology, q3, age 30 | 19348 | 7180 | 69231.08 | 19.67 | 365
HPV followed by cytology, q2, age 30 | 27947 | 8599 | 69239.32 | 8.24 | 1044
HPV followed by cytology, q1, age 30 | 51455 | 23508 | 69247.51 | 8.19 | 2870

* Per 1,000 women. Assumes a strategy of HPV testing first, followed by cytology if HPV positive, for women ages 30 years and older. Women are assumed to begin screening at age 21 years.

Table 25 Koliopoulos et al36: Sensitivity Analysis Showing Expected Tests (Screening and Triage), Incremental Tests, Life-Years, Incremental Life-Years, and Incremental Tests per Life-Year (ITLY) for Strategies Identified as Efficient^*^

Strategy | Tests | Incremental Tests | Life-Years | Incremental Life-Years | ITLY
No intervention | 0 | | 69016.30
Cytology, q5, age 21 | 11658 | 11658 | 69205.11 | 188.81 | 62
HPV followed by cytology, q5, age 30 | 14467 | 2809 | 69219.18 | 14.07 | 200
Cytology, q3, age 21 | 18997 | 4530 | 69229.37 | 10.19 | 445
HPV followed by cytology, q3, age 30 | 22634 | 3637 | 69237.06 | 7.69 | 473
HPV followed by cytology, q2, age 30 | 31826 | 9192 | 69244.12 | 7.06 | 1302
Cytology, q1, age 21 | 50416 | 18590 | 69251.10 | 6.98 | 2663

* Per 1,000 women. Assumes a strategy of HPV testing first, followed by cytology if HPV positive, for women ages 30 years and older. Women are assumed to begin screening at age 21 years.

Table 26 Vesco et al35: Sensitivity Analysis of a Strategy in Which Screening Ends at Age 65 Years^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69016.30
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 455 | 455 | 69208.97 | 192.67 | 2
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 640 | 185 | 69225.54 | 16.57 | 11
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 896 | 256 | 69233.35 | 7.81 | 33
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 1200 | 304 | 69238.94 | 5.59 | 54
Cytology, q1, age 21 | 1525 | 325 | 69239.18 | 0.24 | 1343

* Screening is assumed to end at age 65 years instead of age 85 years. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years.

Table 27 Mayrand et al8: Sensitivity Analysis of a Strategy in Which Screening Ends at Age 65 Years^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69016.30
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 255 | 255 | 69207.20 | 190.90 | 1
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 347 | 92 | 69224.06 | 16.86 | 5
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 477 | 130 | 69231.97 | 7.91 | 16
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 638 | 161 | 69237.81 | 5.84 | 28

* Screening is assumed to end at age 65 years instead of age 85 years. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years.

Table 28 Koliopoulos et al36: Sensitivity Analysis of a Strategy in Which Screening Ends at Age 65 Years^*^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69016.30
Cytology, q5, age 21 | 540 | 540 | 69196.51 | 180.206 | 3
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 658 | 118 | 69217.09 | 20.59 | 6
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 937 | 279 | 69231.80 | 14.70 | 19
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 1305 | 368 | 69238.47 | 6.67 | 55
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 1726 | 421 | 69242.47 | 4.00 | 105
Cytology, q1, age 21 | 2167 | 441 | 69244.00 | 1.53 | 288

* Screening is assumed to end at age 65 years instead of age 85 years. Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years.

Table 29 Sensitivity Analysis Using the Highest Estimates of Test Sensitivity and Lowest Estimates of Specificity^*,†,‡^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69016.30
Cytology, q5, age 21 | 1369 | 1369 | 69214.69 | 198.39 | 7
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 1824 | 455 | 69232.89 | 18.20 | 25
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 2720 | 896 | 69244.40 | 11.51 | 78
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 3638 | 918 | 69248.36 | 3.95 | 232
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 4571 | 933 | 69251.42 | 3.06 | 305
Cytology, q1, age 21 | 5283 | 712 | 69252.51 | 1.09 | 651

* Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years. Screening intervals of every 1 (q1), 2 (q2), 3 (q3), and 5 (q5) years are compared.

† Sensitivity for CIN2+ is 0.772 instead of 0.569; specificity for CIN2+ is 0.847 instead of 0.945; sensitivity for ASC-US is 0.956 instead of 0.762; specificity for ASC-US is 0.475 instead of 0.638.

‡ HC2 sensitivity for CIN2+ is 1.000 instead of 0.860; HC2 specificity for CIN2+ is 0.767 instead of 0.844; HC2 sensitivity for ASC-US is 0.976 instead of 0.892; HC2 specificity for ASC-US is 0.310 instead of 0.641.

Table 30 Sensitivity Analysis Using the Lowest Estimates of Test Sensitivity and Highest Estimates of Specificity^*,†,‡^

Strategy | Colposcopies | Incremental Colposcopies | Life-Years | Incremental Life-Years | ICLY
No intervention | 0 | | 69016.30
Cytology, q3, age 21; Cytology and HPV, q5, age 30 | 132 | 132 | 69123.68 | 107.38 | 1
Cytology, q3, age 21; Cytology and HPV, q3, age 30 | 187 | 55 | 69153.38 | 29.70 | 2
Cytology, q2, age 21; Cytology and HPV, q3, age 30 | 250 | 63 | 69172.50 | 19.12 | 3
Cytology, q1, age 21; Cytology and HPV, q3, age 30 | 327 | 77 | 69191.32 | 18.82 | 4
Cytology, q1, age 21 | 404 | 77 | 69199.49 | 8.17 | 9

* Results are presented as expected colposcopies per 1,000 women, incremental colposcopies, life-years, incremental life-years, and incremental colposcopies per life-year (ICLY) for strategies identified as efficient. Women are assumed to begin screening at age 21 years. For the combined cytology and HPV strategies, cytology-based screening is assumed before age 30 years, with a repeat cytology test for ASC-US results. The strategy of cytology and HPV testing is assumed to begin at age 30 years.

† Sensitivity for CIN2+ is 0.200 instead of 0.569; specificity for CIN2+ is 0.990 instead of 0.945; sensitivity for ASC-US is 0.450 instead of 0.762; specificity for ASC-US is 0.756 instead of 0.638.

‡ HC2 sensitivity for CIN2+ is 0.341 instead of 0.860; HC2 specificity for CIN2+ is 0.966 instead of 0.844; HC2 sensitivity for ASC-US is 0.670 instead of 0.892; HC2 specificity for ASC-US is 0.672 instead of 0.641.