# October 2011 Update

The literature search conducted for this systematic review was completed in September 2010. A manuscript that was derived from this systematic review was published in Annals of Internal Medicine on October 18, 2011. In preparing this manuscript, the review team conducted an ancillary search in PubMed (September 1, 2010 to August 3, 2011) to identify any updated information from trials included (or identified as pending) in this review We also queried three selected experts to determine their knowledge about recent relevant publications on August 8, 2011.

Our search identified nine additional studies, none of which provided additional data on trials included in this review. Instead, the studies represented four reports from previously identified cohorts that were contextually relevant1,2 or unrelated3,4 to the focus of this review, one performance study for a new human papillomavirus test,5 two unrelated reports from trial authors,6,7 and two public health reports.8,9

None of these reports added any new data to our review. Several were added to the discussion section in the Annals manuscript, which is available at www.annals.org.

## Additional Identified Reports

1 Katki HA, et al. Cervical cancer risk for women undergoing concurrent testing for human papillomavirus and cervical cytology: a population-based study in routine clinical practice. Lancet Oncol. 2011;12(7):663-72. [pmid: 21684207].
2 Schiffman M, et al. A long-term prospective study of type-specific human papillomavirus infection and risk of cervical neoplasia among 20,000 women in the Portland Kaiser Cohort Study. Cancer Epidemiol Biomarkers Prev. 2011;20(7):1398-409. [pmid: 21602310].
3 Castle PE, et al. Variable risk of cervical precancer and cancer after a human papillomavirus- positive test. Obstet Gyencol. 2011;117(3):650-6.
4 Littell RD, et al. Risk of cervical precancer and cancer in women aged 30 years and older with an HPV-negative low-grade squamous intraepithelial lesion screening result. J Low Genit Tract Dis. 2011;15(1):54-9. [pmid: 21192178].
5 Castle PE, et al. Evaluation of a new DNA test for detection of carcinogenic human papillomavirus. J Clin Microbiol. 2011;49(8):3029-32. [pmid: 21632892].
6 Kotaniemi-Talonen L, et al. Intensified screening among high risk women within the organised screening programme for cervical cancer in Finland. Acta Oncol. 2011;50(1):106-11. [pmid: 20560860].
7 Anttila A, et al. Cervical cancer patterns with automation-assisted and conventional cytological screening: a randomized study. Int J Cancer. 2011;128(5):1204-12. [pmid: 20848590].
8 Arbyn M, et al. Worldwide burden of cervical cancer in 2008. Ann Oncol. 2011. 04. 6. [Epub ahead of print].
9 Franceschi S, et al. Eurogin 2010 roadmap on cervical cancer prevention. Int J Cancer. 2011;128(12):2765-74. [pmid: 21207409].