# Cervical Cancer and HPV: Prevalence, Incidence and Mortality Rates

Country | HPV
Country | Prevalence among women with normal cytology (general population) % (95% CI) | Adjusted Prevalence among women with normal cytology (general population), by region,^*^ % (95% CI)^†^ | Crude age-specific prevalence among women with normal cytology (general population) % (95% CI) (Estimated from Figure 24) | | | | | Prevalence of HPV types 16 and 18 among cervical cancer cases % (95% CI)
Country | Prevalence among women with normal cytology (general population) % (95% CI) | Adjusted Prevalence among women with normal cytology (general population), by region,^*^ % (95% CI)^†^ | < 25y | 25–34y | 35–44y | 45–54y | 55+y | Prevalence of HPV types 16 and 18 among cervical cancer cases % (95% CI)
Canada | 9.9 (9.5–10.4) | North America: 11.3 (10.6–12.1) | 26 (22.5–32.5) | 27.5 (22.5–34) | 14 (6.3–25) | 12 (4.4–24) | 12.5 (5.0–25) | 74.3 (67.0–80.6)
China | 12.2 (11.8–12.6) | Eastern Asia: 13.6 (12.5–14.9) | 9 (6–14) | 10 (8–12.5) | 13.5 (12–15.5) | 12.5 (10–15) | 10 (7.5–14) | 71.0 (69.8–72.2)
England (UK) | 8.9 (8.6–9.1) | Northern Europe: 7.9 (7.4–8.4) | 22 (21.5–23) | 14 (13.5–15) | 7 (6–7.5) | 6 (5–6.5) | 6 (5.0–6.4) | 79.1 (74.4–83.2)
Finland | 7.5 (7.1–7.9) | NR | No data available | 18.5 (17–20) | 8.5 (7.5–9) | 4.3 (3.9–5.0) | 4 (3.5–5) | 88.5 (85.2–91.2)
France | 12.8 (12.3–13.4) | Western Europe: 8.4 (8.0–8.8) | 43 (35–51) | 31.5 (26.5–38.5) | 19 (16–24) | 21 (16–26.5) | 13 (8–18.5) | 75.6 (73.3–77.8)
Germany | 6.3 (5.9–6.8) | Western Europe: 8.4 (8.0–8.8) | No data available | | | | | 76.8 (65.1–86.1)
India | 7.9 (7.5–8.2) | South-Central Asia: 7.5 (7.0–8.0) | 15.5 (14–18) | 14 (13–15) | 14 (11–15) | 14 (10–16) | 14.5 (9.5–19) | 82.5 (79.5–85.1)
Italy | 9.0 (8.7–9.3) | Southern Europe: 6.8 (5.7–7.7) | 22 (19–25) | 10 (9.5–10.5) | 11.5 (8.5–15) | 9.5 (7–13) | 9 (7–12) | 72.1 (67.6–76.4)
Netherlands | 3.9 (3.6–4.1) | Western Europe: 8.4 (8.0–8.8) | 16.5 (5–35) | 8 (7.5–9) | 5 (NR) | 3.5 (NR) | 2.5 (NR) | 87.9 (84.6–90.7)
Sweden | 5.5 (4.9–6.0) | Northern Europe: 7.9 (7.4–8.4) | 7 (3.5–11) | 7.5 (6–8) | 5 (4.5–6.5) | 5.5 (1–16) | No data available | 68.5 (64.7–72.2)
Switzerland | 6.3 (5.9–6.7) | NR | 17.1 (11.5–25.0) | 7.8 (6.4–8.5) | 6.4 (5.7–7.4) | 5.3 (4.7–6.4) | 5.7 (5.0–6.4) | 78.7 (77.0–80.3)^‡^
United States | 13.3 (13.0–13.6) | North America: 11.3 (10.6–12.1) | 27 (26.5–27.5) | 12 (11–12.5) | 6 (5.5–6.5) | 4.5 (3.5–5) | 3 (2.5–3.5) | 76.6 (74.3–78.8)

Country | Cervical Cancer
Country | Crude Incidence Rate (per 100,000 women per year) | Age- standardized Incidence Rate (per 100,000 women per year) | Age-specific incidence rates (per 100,000 women per year) (Estimated from Figure 17) | | | | Crude Mortality Rate (per 100,000 women per year) | Age- standardized Mortality Rate (per 100,000 women per year) | Age-specific mortality rates (per 100,000 women per year) (Estimated from Figure 17)
Country | Crude Incidence Rate (per 100,000 women per year) | Age- standardized Incidence Rate (per 100,000 women per year) | 15–44y | 45–54y | 55–64y | 65+y | Crude Mortality Rate (per 100,000 women per year) | Age- standardized Mortality Rate (per 100,000 women per year) | 15–44y | 45–54y | 55–64y | 65+y
Canada | 8.5 | 6.6 | 8.5 | 12 | 12 | 11 | 3.2 | 1.9 | 1 | 4 | 5.5 | 10
China | 11.7 | 9.6 | 11 | 21 | 22 | 15 | 5.2 | 4.2 | 2 | 8.5 | 13 | 21.5
England (UK) | 9.3 | 7.2 | 10 | 12 | 10.5 | 13 | 3.6 | 2.0 | 1 | 4.5 | 5 | 10
Finland | 5.2 | 3.7 | 4.5 | 6 | 6 | 9.5 | 1.9 | 0.9 | 0.5 | 1 | 2.5 | 6
France | 9.1 | 7.1 | 9 | 16 | 11.5 | 11 | 3.1 | 1.8 | 1 | 5 | 5 | 7
Germany | 10.6 | 6.9 | 6 | 20 | 15 | 15.5 | 4.8 | 2.3 | 1 | 5.5 | 7 | 12.5
India | 23.5 | 27.0 | 15.5 | 72 | 90 | 68 | 12.8 | 15.2 | 6 | 33 | 53 | 63
Italy | 9.4 | 6.7 | 7.5 | 16.5 | 15 | 11 | 3.0 | 1.5 | 1 | 4 | 4 | 6.5
Netherlands | 7.1 | 5.4 | 7 | 10 | 8 | 11 | 2.8 | 1.5 | 1 | 3 | 3.5 | 9.5
Sweden | 9.7 | 7.4 | 10 | 13 | 13 | 13.5 | 3.8 | 1.8 | 1 | 4 | 5 | 11.5
Switzerland | 5.7 | 4.0 | 5 | 7 | 7 | 10.5 | 1.9 | 0.9 | 0.5 | 1.5 | 2.5 | 6
United States | 7.0 | 5.7 | 7 | 11 | 10 | 10 | 2.4 | 1.7 | 1.5 | 4 | 4.5 | 6

Unless otherwise specified, all data from WHO/ICO Information Center on HPV and Cervical Cancer, 2008; http://apps.who.int/hpvcentre/statistics/dynamic/ico/SummaryReportsSelect.cfm (updated September 15, 2010)

* Data from de Sanjose S, Diaz M, Castellsague X, et al. Worldwide prevalence and genotype distribution of cervical human papillomavirus DNA in women with normal cytology: a meta-analysis. Lancet. 2007;7:453–459.

† Adjusted for region, study type, study design, publication year, sampling collection device, cell storage medium, HPV assay, primer used, study youngest age included, and study oldest age included

‡ Western Europe regional estimated used instead as specific data unavailable