# Recommendations of Other Groups

Organization | Age to start screening | Screening interval | Definition of high risk | Interval for high risk | Age to stop screening
American College of Obstetricians and Gynecologists, 2009^1^ | Age 21 | Under age 30: 2 years Age 30+ with three consecutive normal screenings: every 3 years | HIV infection Immunosuppressed Diethylstilbestrol exposure in utero Women previously treated for CIN 2, CIN 3, or cancer in the past | Annual HIV: twice in the first year of diagnosis and annually after | 65 or 70 years with 3 normal screenings and no abnormalities within past 10 years. Assess risk factors annually. After total hysterectomy if no prior high-grade CIN If had CIN 2 or 3, then continue screening
American College of Preventive Medicine, Practice Guidelines Committee, 1996^2^ “Although the research on which this statement was based is out of date, the position/recommendations contained in this policy were reaffirmed by the ACPM Board of Regents on 1/31/2005 until the evidence can be reevaluated.” | At onset of sexual activity or age 18 if sexual history is unknown | At least 2 initial screening tests 1 year apart; then interval lengthened at discretion of patient and doctor, but not to exceed >3 year interval | Not mentioned | Not mentioned | Age 65, if no abnormal smears
American Academy of Family Physicians, 2008^3^ | Onset of sexual activity or age 18 | Once a year until at least 3 normal smears After this, you should have a Pap smear at least every 3 years | Starting to have sex early (before age 20) Having had many sexual partners Being infected with an STD or having had a sex partner who has an STD Smoking Using birth control pills and/or giving birth to many children when also infected with HPV | Not mentioned | Throughout life even after menopause; discuss with physician if > 65 years
Canadian Task Force on Preventive Health Care, 1994^4^ Is on priority list for update | Women > age 18 who have had sexual intercourse | Two annual screens, then every three years | Early onset of sexual intercourse Many sexual partners Sexual partner with many sexual partners | More frequently than 3 years | Until age 69
American Cancer Society, 2009^5^ | Three years after beginning to have vaginal intercourse, but no later than age 21 years | Testing should be done every year with the regular Pap test or every 2 years using the newer liquid-based Pap test Beginning at age 30, women who have had 3 normal Pap test results in a row may get tested every 2 to 3 years with either the conventional (regular) or liquid-based Pap test or every 3 years with HPV testing | HPV Infection Smoking HIV infection/Immunosupressed Chlamydia infection Diet (overweight, low in fruits/veggies) Oral contraceptives >2 full-term pregnancies Low SES First full-term pregnancy at <17 yrs Diethylstilbestrol (DES) Family history of cervical cancer | Yearly | Women 70 years of age or older who have had 3 or more normal Pap tests in a row and no abnormal Pap test results in the last 10 years may choose to stop having cervical cancer testing Women with a history of cervical cancer, DES exposure before birth, HIV infection, or a weakened immune system should continue to have annual screening Women who have had a total hysterectomy (removal of the uterus and cervix) may also choose to stop having cervical cancer testing, unless the surgery was done as a treatment for cervical cancer or pre-cancer
Institute for Clinical Systems Improvement, 2009^6^ | Three years post-onset of sexual activity or by age 21 | Every 3 years after 3 consecutive normal smears over 5 years. - | Not mentioned | Not mentioned | No age recommended for screening to stop Women with total hysterectomy for benign disease and no history of CIN 2 or 3 can stop screening.
UK National Health Service Cervical Screening Programme, 2009^7^ | Age 25 | Age 25–49: every 3 years Age 50–65: every 5 years Age 65+: Only screen those who have not been screened since age 50 or have had recent abnormal tests | Not mentioned | Not mentioned | Age 65+: Only screen those who have not been screened since age 50 or have had recent abnormal tests
Australian National Cervical Screening Program, 2009^8^ | 18–20 years or 1–2 yrs within first sexual intercourse whichever is later | Every 2 years | | “check with your doctor” | Age 70 if two normal Pap smears in last 5 years.
New Zealand National Cervical Screening Programme, 2008^9^ | Age 20 for all women who have had sexual intercourse | If first cervical smear test, or if haven’t had a test for over 5 years, have a second cervical smear test at 1 year Otherwise, every three years for most women | Immunosuppressed | Annual | Age 70
European guidelines for quality assurance in cervical cancer screening, 2008^10^ | Age 20 to 30 yrs | 3–5-year intervals until the age of 60 | Special attention should be paid to the problem of older women who have never attended screening, as they exhibit increased risk for cervical cancer. | | The upper limit should not be lower than 60 years. Stopping screening in older women is probably appropriate among women who have had three or more consecutive previous (recent) normal cytology results.

## References

1 ACOG Committee on Practice Bulletins—Gynecology. ACOG Practice Bulletin No. 109: cervical cytology screening. Obstet Gynecol. 2009;114(6):1409-1419. [pmid: 20134296].
2 Hawkes AP, Kronenberger CB, MacKenzie TD, et al. Cervical cancer screening: American College of Preventive Medicine practice policy statement. Am J Prev Med. 1996;12(5):342-344. [pmid: 8909644].
3 American Academy of Family Physicians. Pap Smears. Leawood, KS. American Academy of Family Physicians. 2008. Accessed at http://familydoctor.org/online/famdocen/home/women/reproductive/gynecologic/138.html. 11 May 2011.
4 Canadian Task Force on Preventive Health Care. Screening for Cervical Cancer. Ottawa, Ontario. Canadian Task Force on Preventive Health Care. 1994. Accessed at http://www.canadiantaskforce.ca/_archive/index.html. 11 May 2011.
5 American Cancer Society. Guidelines for the Early Detection of Cancer. Atlanta, GA. American Cancer Society. 2010. Accessed at http://www.cancer.org/Healthy/FindCancerEarly/CancerScreeningGuidelines/american-cancer-society-guidelines-for-the-early-detection-of-cancer. 11 May 2011.
6 Institute for Clinical Systems Improvement. Health Care Guideline: Preventive Services for Adults. Bloomington, MN. Institute for Clinical Systems Improvement. 2010. Accessed at http://www.icsi.org/preventive_services_for_adults/preventive_services_for_adults_4.html. 11 May 2011.
7 NHS Cervical Screening Programme. About Cervical Screening. London. National Health Service. 2011. Accessed at http://www.cancerscreening.nhs.uk/cervical/about-cervical-screening.html. 11 May 2011.
8 Australia Department of Health and Ageing. National Cervical Screening Program. Canberra, Australia. Australia Department of Health and Ageing. 2009. Accessed at http://www.cancerscreening.gov.au/internet/screening/publishing.nsf/Content/cervical-about. 11 May 2011.
9 New Zealand National Cervical Screening Programme. Guidelines for Cervical Screening in New Zealand. Wellington, New Zealand. National Screening Unit, Ministry of Health. 2008. Accessed at http://www.nsu.govt.nz/files/NCSP/NCSP_Guidelines_ALL_small(1).pdf. 11 May 2011.
10 Arbyn M, Anttila A, Jordan J, et al. European Guidelines for Quality Assurance in Cervical Cancer Screening: second edition—summary document. Ann Oncol. 2010;21(3):448-458. [pmid: 20176693].