# Ongoing and Pending Trials

Principal investigators | Location | Population | Approximate size | Investigations | Outcomes | Status as of 2010
KQ1: Age to begin screening
KQ2: Liquid-based cytology
KQ3: HPV testing
Coldman^*^ | Vancouver, BC | Routine screening Age 25–69 | 33,000 | HPV DNA testing with cytology triage | ≥ CIN2 ≥ CIN3 Cost analysis | Trial expected to finish March 2014
Murphy^*^ | Toronto, ON | Routine screening Aged ≥ 18 | 1712 | HPV testing alone or in combination with conventional cytology | ≥ CIN2 ≥ CIN3 Rate of colposcopies | Trial expected to finish January 2011
Ngan^*^ | Hong Kong | Routine screening Age 30–60 | 12,000 | HPV cotesting with conventional cytology compared to conventional cytology alone | ≥ CIN2 ≥ CIN3 | Trial expected to finish January 2017
KQ4: Harms of liquid-based cytology
KQ5: Harms of HPV testing

* Available at: www.clinicaltrials.gov. Accessed September 29, 2010.