# Screening Benefit Considerations Illustrated by NTCC Phase II Trial113

The recently reported NTCC Phase II trial of primary HPV screening (compared with cytology) illustrates the tricky and complicated considerations when trying to determine screening benefit, much less net impact (screening benefit minus harms), for alternative approaches in a program of cervical cancer screening. After a single round of HPV screening, disease detection was relatively greater (2–4 times greater, depending on age and whether defined as CIN3+ or CIN2+) compared with cytology alone, although cancers were uncommon in both arms. However, colposcopies were also relatively elevated, at least 2–4 times, with a much higher burden in younger women undergoing primary HPV screening (13.1% in those under 35 vs. 5.8% in women 35 and older) and as compared to younger and older women undergoing conventional cytology (3.6% and 2.4% respectively). This trial also reported a relative decrease in CIN3+ in the HPV arm compared with cytology at the second screening round 3.5 years later which consisted of both groups receiving conventional cytology. While this finding has been interpreted as indicating preventive benefit, since the same test was used in both arms, it is unfortunate that this approach renders the trial non-informative about repeat HPV screening. Experts have suggested that reduced CIN3+ detection in subsequent screening rounds may be a surrogate measure of screening program benefit, by signaling earlier disease detection and treatment. However, CIN3+ is a combined outcome (CIN3, CIS, ICC) that includes some potentially regressive disease. And in NTCC Phase II (as with most trials to date) no impact on cancers was detected. Also, even if one accepts this trial as evidence of HPV screening benefit, net impact cannot be determined as cumulative colposcopy burden is not reported yet for this study. Colposcopy burden could conceivably be improved in the HPV screening arm relative to cytology if early treatment has prevented disease, but whether this is true and how much remains to be demonstrated. And, the potential harms from diagnosis and treatment of non-progressive disease cannot even be estimated due to incomplete reporting. Longer term follow-up and more complete reporting of all screening-related activities and results, including colposcopies, are needed to fully interpret this trial. However, this trial provides several take-away messages as presented. First, given the greatly increased colposcopy requirement and relatively diminished cancer burden in younger women, HPV screening alone in women under 35 is not promising. Second, unless future reporting confirms an ongoing reduction in CIN3+ (and ideally cervical cancers) after one-time HPV screening in older women, careful weighing of benefits with harms from additional colposcopy requirements will be necessary even for modeling an ongoing program of repeat cervical cancer screening. Finally, modeling will also need to adjust for the difference between the trial colposcopy referral threshold (ASC-US+) and US practice.

ASC-US: atypical squamous cells of undetermined significance; CIN: cervical intraepithelial neoplasia; CIS: carcinoma in situ; HPV: human papillomavirus; ICC: invasive cervical cancer; NTCC: New Technologies for Cervical Cancer ; US: United States