# Excluded Studies

Appendix D Table 1 Studies Excluded From the Review for KQ1

Key Question 1: When should cervical cancer screening begin, and does this vary by screening technology or by age, sexual history, or other patient characteristics?
Reference | Reason for exclusion^*^
Acladious NN, Mandal D. Cervical cytology screening for sexually-active teenagers. International Journal of STD & AIDS. 2000;11:648–650. | Reported outcomes do not address a key question
Baay MF, Tjalma WA, Lambrechts HA et al. Combined Pap and HPV testing in primary screening for cervical abnormalities: should HPV detection be delayed until age 35? Eur J Cancer. 2005;41:2704–2708. | Reported outcomes do not address a key question
Bacon J, Francoeur D, Goldfarb AF, Breech LL. Abnormal pap smears in adolescents. J Pediatr Adolesc Gynecol. 2003;16:157–166. | Editorials; letters; non- systematic reviews; opinions
Bano F, Kolhe S, Zamblera D et al. Cervical screening in under 25s: a high-risk young population. European Journal of Obstetrics, Gynecology, & Reproductive Biology. 2008;139:86–89. | Provides prevalence data only
Barnholtz-Sloan J, Patel N, Rollison D, Kortepeter K, MacKinnon J, Giuliano A. Incidence trends of invasive cervical cancer in the United States by combined race and ethnicity. Cancer Causes & Control. 2009;20:1129–1138. | Ecological study without link to screening
Benard VB, Eheman CR, Lawson HW et al. Cervical screening in the National Breast and Cervical Cancer Early Detection Program, 1995–2001. Obstetrics & Gynecology. 2004;103:564–571. | Data not stratified by age, age groupings not appropriate, or denominators not known
Bos AB, Rebolj M, Habbema JD, van Ballegooijen M. Nonattendance is still the main limitation for the effectiveness of screening for cervical cancer in the Netherlands. Int J Cancer. 2006;119:2372–2375. | Data not stratified by age, age groupings not appropriate, or denominators not known
Bray F, Loos AH, McCarron P et al. Trends in cervical squamous cell carcinoma incidence in 13 European countries: changing risk and the effects of screening. Cancer Epidemiology, Biomarkers & Prevention. 2005;14:677–686. | Ecological study without link to screening
Bulk S, Visser O, Rozendaal L, Verheijen RH, Meijer CJ. Cervical cancer in the Netherlands 1989–1998: Decrease of squamous cell carcinoma in older women, increase of adenocarcinoma in younger women. Int J Cancer. 2005;113:1005–1009. | Ecological study without link to screening
Bulkmans NW, Berkhof J, Bulk S et al. High-risk HPV type-specific clearance rates in cervical screening. Br J Cancer. 2007;96:1419–1424. | Data not stratified by age, age groupings not appropriate, or denominators not known
Canfell K, Barnabas R, Patnick J, Beral V. The predicted effect of changes in cervical screening practice in the UK: results from a modelling study. Br J Cancer. 2004;91:530–536. | Modeling study
Canfell K, Sitas F, Beral V. Cervical cancer in Australia and the United Kingdom: comparison of screening policy and uptake, and cancer incidence and mortality. Med J Aust. 2006;185:482–486. | Data not stratified by age, age groupings not appropriate, or denominators not known
Cecchini S, Ciatto S, Zappa M, Biggeri A. Trends in the prevalence of cervical intraepithelial neoplasia grade 3 in the district of Florence, Italy. Tumori. 1995;81:330–333. | Poor reporting
Cervical Cancer Screening Programme. Cervical Cancer Screening Programme, England: 2002–03. 1–44. 2003. England, Government Statistical Service. | Reported outcomes do not address a key question
Chan PG, Sung HY, Sawaya GF. Changes in cervical cancer incidence after three decades of screening US women less than 30 years old. Obstet Gynecol. 2003;102:765–773. | Ecological study without link to screening
Chan PK, Chang AR, Yu MY et al. Age distribution of human papillomavirus infection and cervical neoplasia reflects caveats of cervical screening policies. Int J Cancer. 2010;126:297–301. | Data not stratified by age, age groupings not appropriate, or denominators not known
Cohen D. BMA meeting: Doctors urge government to lower age limit for cervical cancer screening. BMJ. 2009;339:b2711. | Editorials; letters; non- systematic reviews; opinions
Coldman A, Phillips N, Kan L, Matisic J, Benedet L, Towers L. Risk of invasive cervical cancer after three consecutive negative Pap smears. J Med Screen. 2003;10:196–200. | Data not stratified by age, age groupings not appropriate, or denominators not known
Coldman A, Phillips N, Kan L, Matisic J, Benedet L, Towers L. Risk of invasive cervical cancer after Pap smears: the protective effect of multiple negatives. J Med Screen. 2005;12:7–11. | Data not stratified by age, age groupings not appropriate, or denominators not known
Colgan TJ, Clarke A, Hakh N, Seidenfeld A. Screening for cervical disease in mature women: strategies for improvement. Cancer. 2002;96:195–203. | Reported outcomes do not address a key question
Coppell K, Paul C, Cox B. An evaluation of the National Cervical Screening Programme Otago site. N Z Med J. 2000;113:48–51. | Reported outcomes do not address a key question
Cotton SC, Sharp L, Seth R et al. Lifestyle and socio-demographic factors associated with high-risk HPV infection in UK women. Br J Cancer. 2007;97:133–139. | Reported outcomes do not address a key question
Coupe VM, Berkhof J, Bulkmans NW, Snijders PJ, Meijer CJ. Age-dependent prevalence of 14 high-risk HPV types in the Netherlands: implications for prophylactic vaccination and screening. Br J Cancer. 2008;98:646–651. | Reported outcomes do not address a key question
Crowther S, Turner L, Magee D, Gibbons D. Role of age stratification for colposcopy referral following initial diagnosis of mild dyskaryosis. J Clin Pathol. 2008;61:665–668. | Reported outcomes do not address a key question
Fiander AN. Cervical screening in young women aged 20–24 years. Journal of Family Planning & Reproductive Health Care. 2008;34:19. | Editorials; letters; non- systematic reviews; opinions
Fraser A, Hellmann S, Leibovici L, Levavi H. Screening for cervical cancer--an evidence-based approach. Eur J Gynaecol Oncol. 2005;26:372–375. | Reported outcomes do not address a key question
Ghosh A, Rao S, Pramanik T. Is it relevant to screen women younger than 26 years for precancerous and malignant cervical lesions ?[see comment]. Asian Pacific Journal of Cancer Prevention: Apjcp. 2005;6:123–124. | Reported outcomes do not address a key question
Giannopoulos T, Butler-Manuel S, Tailor A, Demetriou E, Daborn L. Prevalence of high-grade CIN following mild dyskaryotic smears in different age groups.[see comment]. Cytopathology. 2005;16:277–280. | Conducted solely in referred population or does not report routine and referred population outcomes separately
Guido R. Guidelines for screening and treatment of cervical disease in the adolescent. Journal of Pediatric & Adolescent Gynecology. 2004;17:303–311. | Editorials; letters; non- systematic reviews; opinions
Hall HI, Rogers JD, Weir HK, Miller DS, Uhler RJ. Breast and cervical carcinoma mortality among women in the Appalachian region of the U.S., 1976–1996. Cancer. 2000;89:1593–1602. | Ecological study without link to screening
Hartmann, KE, Hall, SA, Nanda, K, Boggess, JF, and Zolnoun, D. Screening for Cervical Cancer. ii-74. 2002. Agency for Healthcare Research and Quality. | Data covered in other articles
Hemminki K, Li X, Mutanen P. Age-incidence relationships and time trends in cervical cancer in Sweden. Eur J Epidemiol. 2001;17:323–328. | Ecological study without link to screening
Herbert A, Anshu, Gregory M, Gupta SS, Singh N. Screen-detected invasive cervical carcinoma and its clinical significance during the introduction of organized screening. BJOG: An International Journal of Obstetrics & Gynaecology. 2009;116:854–859. | Data not stratified by age, age groupings not appropriate, or denominators not known
Herbert A, Holdsworth G, Kubba AA. Cervical screening: why young women should be encouraged to be screened. Journal of Family Planning & Reproductive Health Care. 2008;34:21–25. | Ecological study without link to screening
Howell LP, Tabnak F, Tudury AJ, Stoodt G. Role of Pap Test terminology and age in the detection of carcinoma invasive and carcinoma in situ in medically underserved California women. Diagn Cytopathol. 2004;30:227–234. | Data not stratified by age, age groupings not appropriate, or denominators not known
Hoyer H, Scheungraber C, Kuehne-Heid R et al. Cumulative 5-year diagnoses of CIN2, CIN3 or cervical cancer after concurrent high-risk HPV and cytology testing in a primary screening setting. Int J Cancer. 2005;116:136–143. | Data not stratified by age, age groupings not appropriate, or denominators not known
Insinga RP, Dasbach EJ, Elbasha EH, Liaw KL, Barr E. Incidence and duration of cervical human papillomavirus 6, 11, 16, and 18 infections in young women: an evaluation from multiple analytic perspectives. Cancer Epidemiology, Biomarkers & Prevention. 2007;16:709–715. | Ecological study without link to screening
Insinga RP, Dasbach EJ, Elbasha EH, Liaw KL, Barr E. Progression and regression of incident cervical HPV 6, 11, 16 and 18 infections in young women. Infectious Agents & Cancer. 2007;2:15. | Ecological study without link to screening
Jacobs MV, Walboomers JM, Snijders PJ et al. Distribution of 37 mucosotropic HPV types in women with cytologically normal cervical smears: the age-related patterns for high-risk and low-risk types. Int J Cancer. 2000;87:221–227. | Reported outcomes do not address a key question
Kahn JA, Hillard PJ. Cervical cytology screening and management of abnormal cytology in adolescent girls. J Pediatr Adolesc Gynecol. 2003;16:167–171. | Editorials; letters; non- systematic reviews; opinions
Kyndi M, Frederiksen K, Kruger KS. Cervical cancer incidence in Denmark over six decades (1943–2002). Acta Obstet Gynecol Scand. 2006;85:106–111. | Ecological study without link to screening
Lawson HW, Lee NC, Thames SF, Henson R, Miller DS. Cervical cancer screening among low-income women: results of a national screening program, 1991–1995. Obstet Gynecol. 1998;92:745–752. | Data not stratified by age, age groupings not appropriate, or denominators not known
Liu S, Semenciw R, Probert A, Mao Y. Cervical cancer in Canada: changing patterns in incidence and mortality. International Journal of Gynecological Cancer. 2001;11:24–31. | Ecological study without link to screening
Luke C, Nguyen AM, Heard A, Kenny B, Shorne L, Roder D. Benchmarking epidemiological characteristics of cervical cancer in advance of change in screening practice and commencement of vaccination. Australian & New Zealand Journal of Public Health. 2007;31:149–154. | Data not stratified by age, age groupings not appropriate, or denominators not known
Massad SL, Markwell S, Cejtin HE, Collins Y. Risk of high-grade cervical intraepithelial neoplasia among young women with abnormal screening cytology. Journal of Lower Genital Tract Disease. 2005;9:225–229. | Conducted solely in referred population or does not report routine and referred population outcomes separately
Mitchell H, Medley G, Higgins V. An audit of the women who died during 1994 from cancer of the cervix in Victoria, Australia. Aust N Z J Obstet Gynaecol. 1996;36:73–76. | Data not stratified by age, age groupings not appropriate, or denominators not known
Monteiro DL, Trajano AJ, da Silva KS, Russomano FB. Pre-invasive cervical disease and uterine cervical cancer in Brazilian adolescents: prevalence and related factors. Cad Saude Publica. 2006;22:2539–2548. | Conducted solely in referred population or does not report routine and referred population outcomes separately
Moscicki AB, Cox JT. Practice improvement in cervical screening and management (PICSM): symposium on management of cervical abnormalities in adolescents and young women. Journal of Lower Genital Tract Disease. 2010;14:73–80. | Editorials; letters; non- systematic reviews; opinions
Moscicki AB. HPV infections in adolescents. Dis Markers. 2007;23:229–234. | Editorials; letters; non- systematic reviews; opinions
Mount SL, Papillo JL. A study of 10,296 pediatric and adolescent Papanicolaou smear diagnoses in northern New England. Pediatrics. 1999;103:539–545. | Reported outcomes do not address a key question
Nair MS, Bhandari HM, Nordin AJ. Cervical cancer in women aged less than 25: East Kent experience. Journal of Obstetrics & Gynaecology. 2007;27:706–708. | Editorials; letters; non- systematic reviews; opinions
O’Mahony C, Steedman N, Yong M, Anderson ER, Finnegan V, Price L. Cervical screening by age: let’s not screen women under 25 throughout the UK. BMJ. 2009;339:b3426. | Editorials; letters; non- systematic reviews; opinions
Omar H, Callahan P, Aggarwal S, Perkins K, Young K. Cervical pathology in West Virginia adolescents. W V Med J. 2000;96:408–409. | Reported outcomes do not address a key question
Partridge EE, bu-Rustum N, Campos S et al. Cervical cancer screening. Journal of the National Comprehensive Cancer Network. 2008;6:58–82. | Editorials; letters; non- systematic reviews; opinions
Petignat P, Faltin D, Goffin F et al. Age-related performance of human papillomavirus testing used as an adjunct to cytology for cervical carcinoma screening in a population with a low incidence of cervical carcinoma. Cancer. 2005;105:126–132. | Data not stratified by age, age groupings not appropriate, or denominators not known
Prussia PR, Gay GH, Bruce A. Analysis of cervicovaginal (Papanicolaou) smears, in girls 18 years and under. West Indian Med J. 2002;51:37–39. | Reported outcomes do not address a key question
Quinn M, Babb P, Jones J, Allen E. Effect of screening on incidence of and mortality from cancer of cervix in England: evaluation based on routinely collected statistics. BMJ. 1999;318:904–908. | Ecological study without link to screening
Rieck GC, Tristram A, Hauke A, Fielder H, Fiander AN. Cervical screening in 20–24- year olds. J Med Screen. 2006;13:64–71. | Insufficient information
Rodriguez AC, Burk R, Herrero R et al. The natural history of human papillomavirus infection and cervical intraepithelial neoplasia among young women in the Guanacaste cohort shortly after initiation of sexual life. Sex Transm Dis. 2007;34:494–502. | Data not stratified by age, age groupings not appropriate, or denominators not known
Saleh MM, Seoud AA, Zaklama MS. Abnormal cervical smears in adolescents: a ten- year comparative study of demographic criteria and management. Clinical & Experimental Obstetrics & Gynecology. 2007;34:139–142. | Conducted solely in referred population or does not report routine and referred population outcomes separately
Saleh MM, Seoud AA, Zaklama MS. Study of the demographic criteria and management of adolescents referred with abnormal cervical smears. Journal of Obstetrics & Gynaecology. 2007;27:824–827. | Conducted solely in referred population or does not report routine and referred population outcomes separately
Saraiya M, Ahmed F, Krishnan S, Richards TB, Unger ER, Lawson HW. Cervical cancer incidence in a prevaccine era in the United States, 1998–2002. Obstetrics & Gynecology. 2007;109:t−70. | Ecological study without link to screening
Sasieni P, Adams J, Cuzick J. Benefit of cervical screening at different ages: evidence from the UK audit of screening histories. Br J Cancer. 2003;89:88–93. | Data not stratified by age, age groupings not appropriate, or denominators not known
Sasieni P, Adams J. Effect of screening on cervical cancer mortality in England and Wales: analysis of trends with an age period cohort model. BMJ. 1999;318:1244–1245. | Ecological study without link to screening
Sasieni P, Castanon A, Cuzick J. What is the right age for cervical cancer screening? Women’s health. 2010;6:1–4. | Editorials; letters; non- systematic reviews; opinions
Sasieni P, Castanon A, Parkin DM. How many cervical cancers are prevented by treatment of screen-detected disease in young women? Int J Cancer. 2009;124:461–464. | Modeling study
Sasieni, P. and Castanon, A. Call and recall cervical screening programme: screening interval and age limits. Current Diagnostic Pathology 12, 114–126. 2006. | Editorials; letters; non- systematic reviews; opinions
Sawaya GF. Should routine screening Papanicolaou smears be done for women older than 65 years? Arch Intern Med. 2004;164:243–245. | Editorials; letters; non- systematic reviews; opinions
Sellors JW, Karwalajtys TL, Kaczorowski J et al. Incidence, clearance and predictors of human papillomavirus infection in women. CMAJ Canadian Medical Association Journal. 2003;168:421–425. | Reported outcomes do not address a key question
Sigurdsson K, Adalsteinsson S. Risk variables affecting high-grade Pap smears at second visit: effects of screening interval, year, age and low-grade smears. Int J Cancer. 2001;94:884–888. | Data not stratified by age, age groupings not appropriate, or denominators not known
Sigurdsson K, Sigvaldason H. Effectiveness of cervical cancer screening in Iceland, 1964–2002: a study on trends in incidence and mortality and the effect of risk factors. Acta Obstet Gynecol Scand. 2006;85:343–349. | Data not stratified by age, age groupings not appropriate, or denominators not known
Sigurdsson K, Sigvaldason H. Longitudinal trends in cervical cytological lesions and the effect of risk factors. A 30-year overview. Acta Obstet Gynecol Scand. 2006;85:350–358. | Reported outcomes do not address a key question
Sigurdsson K, Sigvaldason H. Longitudinal trends in cervical histological lesions (CIN 2–3+): a 25-year overview. Acta Obstet Gynecol Scand. 2006;85:359–365. | Data covered in other articles
Sigurdsson K. Trends in cervical intra-epithelial neoplasia in Iceland through 1995: evaluation of targeted age groups and screening intervals. Acta Obstet Gynecol Scand. 1999;78:486–492. | Reported outcomes do not address a key question
Silva CS, Souza MA, Angelo AG, Pavani R, Adad SJ, Murta EF. Increased frequency of abnormal Papanicolaou smears in adolescents. Archives of Gynecology & Obstetrics. 2002;266:154–156. | Reported outcomes do not address a key question
Soren K, Kharbanda EO, Chen S, Westhoff C. A 6-year experience with Pap smears in an urban adolescent practice: the scope and burden of abnormalities. Journal of Pediatric & Adolescent Gynecology. 2009;22:217–222. | Provides prevalence data only
Stuart G, Taylor G, Bancej CM et al. Report of the 2003 pan-Canadian forum on cervical cancer prevention and control. J Obstet Gynaecol Can. 2004;26:1004–1028. | Editorials; letters; non- systematic reviews; opinions
Sykes P, Harker D, Peddie D. Findings and outcome of teenage women referred for colposcopy at Christchurch Women’s Hospital, New Zealand. N Z Med J. 2005;118:U1350. | Conducted solely in referred population or does not report routine and referred population outcomes separately
Syrjanen S, Shabalova I, Petrovichev N et al. Acquisition of high-risk human papillomavirus infections and pap smear abnormalities among women in the New Independent States of the Former Soviet Union. J Clin Microbiol. 2004;42:505–511. | Reported outcomes do not address a key question
Syrjanen S, Shabalova I, Petrovichev N et al. Age-specific incidence and clearance of high-risk human papillomavirus infections in women in the former Soviet Union. International Journal of STD & AIDS. 2005;16:217–223. | Reported outcomes do not address a key question
Tiews S, Steinberg W, Schneider W, Hanrath C. Determination of the diagnostic accuracy of testing for high-risk (HR) human papillomavirus (HPV) types 16, 18 and 45 in precancerous cervical lesions: preliminary data. J Clin Virol. 2009;46:Suppl-5. | Data not stratified by age, age groupings not appropriate, or denominators not known
Tota J, Franco EL. Effectiveness of cervical cancer screening at different ages. Women’s health. 2009;5:613–616. | Editorials; letters; non- systematic reviews; opinions
van den Akker-van Marle ME, van Ballegooijen M, Habbema JD. Low risk of cervical cancer during a long period after negative screening in the Netherlands. Br J Cancer. 2003;88:1054–1057. | Data not stratified by age, age groupings not appropriate, or denominators not known
van der Aa MA, de Kok IM, Siesling S, van Ballegooijen M, Coebergh JW. Does lowering the screening age for cervical cancer in The Netherlands make sense? Int J Cancer. 2008;123:1403–1406. | Data not stratified by age, age groupings not appropriate, or denominators not known
Vetrano G, Lombardi G, Di LG et al. Cervical intraepithelial neoplasia: risk factors for persistence and recurrence in adolescents. Eur J Gynaecol Oncol. 2007;28:189–192. | Conducted solely in referred population or does not report routine and referred population outcomes separately
Wang SS, Sherman ME, Hildesheim A, Lacey JV, Jr., Devesa S. Cervical adenocarcinoma and squamous cell carcinoma incidence trends among white women and black women in the United States for 1976–2000. Cancer. 2004;100:1035–1044. | Ecological study without link to screening
Wise J. Age for starting cervical cancer screening in England will not be lowered. BMJ. 2009;338:b2583. | Editorials; letters; non- systematic reviews; opinions
Wright VC, Riopelle MA. Age at beginning of coitus versus chronologic age as a basis for Papanicolaou smear screening: an analysis of 747 cases of preinvasive disease. Am J Obstet Gynecol. 1984;149:824–830. | Conducted solely in referred population or does not report routine and referred population outcomes separately
Wu S, Meng L, Wang S, Ma D. A comparison of four screening methods for cervical neoplasia. International Journal of Gynaecology & Obstetrics. 2005;91:189–193. | Data not stratified by age, age groupings not appropriate, or denominators not known

* See Appendix B Table 2 for more detailed exclusion criteria

Appendix D Table 2 Studies Excluded From the Review for KQ2

Key Question 2: To what extent does liquid-based cytology improve sensitivity, specificity, and diagnostic yield and reduce indeterminate results and inadequate samples compared to conventional cervical cytology?
Reference | Reason for exclusion^*^
Abulafia O, Pezzullo JC, Sherer DM. Performance of ThinPrep liquid-based cervical cytology in comparison with conventionally prepared Papanicolaou smears: a quantitative survey. Gynecol Oncol. 2003;90:137–144. | Includes studies that do not meet design criteria
Almonte M, Ferreccio C, Winkler JL et al. Cervical screening by visual inspection, HPV testing, liquid-based and conventional cytology in Amazonian Peru. Int J Cancer. 2007;121:796–802. | Colposcopy and/or histology only in positives
Angstetra D, Tait T, Tan J, Symonds I. Should liquid-based cytology be performed prior to colposcopy? A comparison of the accuracy, unsatisfactory rates and cost in a tertiary referral setting. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2009;49:681–684. | Screening conducted solely in referred population or does not report routine and referred outcomes separately
Anton RC, Ramzy I, Schwartz MR, Younes P, Chakraborty S, Mody DR. Should the cytologic diagnosis of “atypical squamous cells of undetermined significance” be qualified? An assessment including comparison between conventional and liquid- based technologies. Cancer. 2001;93:93–99. | Reported outcomes do not address a key question
Aponte-Cipriani SL, Teplitz C, Rorat E, Savino A, Jacobs AJ. Cervical smears prepared by an automated device versus the conventional method. A comparative analysis. Acta Cytol. 1995;39:623–630. | Does not systematically apply reference standard
Arbyn M, Bergeron C, Klinkhamer P, Martin-Hirsch P, Siebers AG, Bulten J. Liquid Compared With Conventional Cervical Cytology: A Systematic Review and Meta- analysis. Obstet Gynecol. 2008;111:167–177. | Includes studies that do not meet design criteria
Ashfaq R, Gibbons D, Vela C, Saboorian MH, Iliya F. ThinPrep Pap Test. Accuracy for glandular disease. Acta Cytol. 1999;43:81–85. | Does not systematically apply reference standard
Atkins KA, Jeronimo J, Stoler MH, ALTS Group. Description of patients with squamous cell carcinoma in the atypical squamous cells of undetermined significance/low-grade squamous intraepithelial lesion triage study. Cancer. 2006;108:212–221. | Reported outcomes do not address a key question
Australian Health Technology Advisory Committee. Review of Automated and Semi- Automated Cervical Screening Devices. 1–86. 1998. Canberra, Commonwealth Department of Health and Family Services. | Focus on excluded screening methods
Awen C, Hathway S, Eddy W, Voskuil R, Janes C. Efficacy of ThinPrep preparation of cervical smears: a 1,000-case, investigator-sponsored study. Diagn Cytopathol. 1994;11:33–36. | Does not systematically apply reference standard
Bacon J, Francoeur D, Goldfarb AF, Breech LL. Abnormal pap smears in adolescents. J Pediatr Adolesc Gynecol. 2003;16:157–166. | Editorials, letters, non- systematic review, opinion or case-control
Bai H, Sung CJ, Steinhoff MM. ThinPrep Pap Test promotes detection of glandular lesions of the endocervix. Diagn Cytopathol. 2000;23:19–22. | Editorials, letters, non- systematic review, opinion or case-control
Baker JJ. Conventional and liquid-based cervicovaginal cytology: a comparison study with clinical and histologic follow-up. Diagn Cytopathol. 2002;27:185–188. | Physician choice of cytology
Bastian, L., Datta, S., Hasselblad, V., Hickey, J., Myers, E., and Nanda, K. Evidence Report No. 5, Summary. Evaluation of Cervical Cytology. 5. 1999. Rockville, MD, Agency for Heath Care Policy and Research. | Precedes search period
Beerman H, van-Dorst EB, Kuenen B, V, Hogendoorn PC. Superior performance of liquid-based versus conventional cytology in a population-based cervical cancer screening program. SO: Gynecologic oncology. 2009;112:572–576. | Does not systematically apply reference standard
Belinson J, Qiao YL, Pretorius R et al. Shanxi Province Cervical Cancer Screening Study: a cross-sectional comparative trial of multiple techniques to detect cervical neoplasia. Gynecol Oncol. 2001;83:439–444. | No comparison to conventional cytology
Bergeron C, Fagnani F. Performance of a new, liquid-based cervical screening technique in the clinical setting of a large French laboratory. Acta Cytol. 2003;47:753–761. | Colposcopy and/or histology only in positives
Bergeron C. Accuracy of thin-layer cytology in patients undergoing cervical cone biopsy. Acta Cytol. 2001;519–524. | Screening conducted solely in referred population or does not report routine and referred outcomes separately
Bernstein SJ, Sanchez-Ramos L, Ndubisi B. Liquid-based cervical cytologic smear study and conventional Papanicolaou smears: a metaanalysis of prospective studies comparing cytologic diagnosis and sample adequacy. Am J Obstet Gynecol. 2001;185:308–317. | Precedes search period
Biscotti CV, O’Brien DL, Gero MA, Gramlich TL, Kennedy AW, Easley KA. Thin- layer Pap test vs. conventional Pap smear. Analysis of 400 split samples. J Reprod Med. 2002;47:9–13. | Does not systematically apply reference standard
Bishop JW, Bigner SH, Colgan TJ et al. Multicenter masked evaluation of AutoCyte PREP thin layers with matched conventional smears. Including initial biopsy results. Acta Cytol. 1998;42:189–197. | Does not systematically apply reference standard
Bishop JW. Comparison of the CytoRich system with conventional cervical cytology. Preliminary data on 2,032 cases from a clinical trial site. Acta Cytol. 1997;41:15–23. | Does not systematically apply reference standard
Bolick DR, Hellman DJ. Laboratory implementation and efficacy assessment of the ThinPrep cervical cancer screening system. Acta Cytol. 1998;42:209–213. | Physician choice of cytology
Boon ME, Rijkaart DC, Ouwerkerk-Noordam E, Korporaal H. Dutch solutions for liquid-based cytology: analysis of unsatisfactory slides and HPV testing of equivocal cytology. Diagn Cytopathol. 2006;34:644–648. | Reported outcomes do not address a key question
Bratti MC, Rodriguez AC, Schiffman M et al. Description of a seven-year prospective study of human papillomavirus infection and cervical neoplasia among 10000 women in Guanacaste, Costa Rica. Rev Panam Salud Publica. 2004;15:75–89. | Reference standard not independent of screening test^‡^
Bur M, Knowles K, Pekow P, Corral O, Donovan J. Comparison of ThinPrep preparations with conventional cervicovaginal smears. Practical considerations. Acta Cytol. 1995;39:631–642. | Does not systematically apply reference standard
Canda MT, Demir N, Sezer O, Doganay L, Ortac R. Clinical results of the liquid- based cervical cytology tool, Liqui-PREP, in comparison with conventional smears for detection of squamous cell abnormalities. Asian Pacific Journal of Cancer Prevention: Apjcp. 2009;10:399–402. | Does not systematically apply reference standard
Carpenter AB, Davey DD. ThinPrep Pap Test: performance and biopsy follow-up in a university hospital. Cancer. 1999;87:105–112. | Editorials, letters, non- systematic review, opinion or case-control
Celik C, Gezginc K, Toy H, Findik S, Yilmaz O. A comparison of liquid-based cytology with conventional cytology. International Journal of Gynaecology & Obstetrics. 2008;100:163–166. | Colposcopy and/or histology only in positives
Cheung AN, Szeto EF, Leung BS, Khoo US, Ng AW. Liquid-based cytology and conventional cervical smears: a comparison study in an Asian screening population. Cancer. 2003;99:331–335. | Reported outcomes do not address a key question
Cheuvront DA, Elston RJ Bishop JW. Effect of a thin-layer preparation system on workload in a cytology laboratory. Laboratory Medicine 29, 174–179. 1998. | Does not systematically apply reference standard
Chung JH, Park EJ, Choi YD et al. Efficacy assessment of CellSlide in liquid-based gynecologic cytology. Gynecol Oncol. 2005;99:597–602. | Focus on excluded screening methods
Clavel C, Masure M, Bory JP et al. Human papillomavirus testing in primary screening for the detection of high-grade cervical lesions: a study of 7932 women. Br J Cancer. 2001;84:1616–1623. | Poor reporting
Cochand-Priollet B, Cartier I, de Cremoux P et al. Cost-effectiveness of liquid-based cytology with or without hybrid-capture II HPV test compared with conventional Pap smears: a study by the French Society of Clinical Cytology. Diagn Cytopathol. 2005;33:338–343. | Provides data already covered in other article
Confortini M, Bulgaresi P, Cariaggi MP et al. Comparing conventional and liquid- based smears from a consecutive series of 297 subjects referred to colposcopy assessment. Cytopathology. 2004;15:168–170. | Poor reporting
Confortini M, Bulgaresi P, Cariaggi MP et al. Conventional pap smear and liquid- based cervical cytology smear: comparison from the same patient. Tumori. 2002;88:288–290. | Screening conducted solely in referred population or does not report routine and referred outcomes separately
Corkill MM, Knapp DC, Hutchinson MLM. Improved Accuracy for Cervical Cytology with the ThinPrep Method and the Endocervical Brush-Spatula Collection Procedure. Journal of Lower Genital Tract Disease. 1998;2:12–16. | Does not systematically apply reference standard
Davey E, Barratt A, Irwig L et al. Effect of study design and quality on unsatisfactory rates, cytology classifications, and accuracy in liquid-based versus conventional cervical cytology: a systematic review. Lancet. 2006;367:122–132. | Includes studies that do not meet design criteria
Davey E, d’Assuncao J, Irwig L et al. Accuracy of reading liquid based cytology slides using the ThinPrep Imager compared with conventional cytology: prospective study. BMJ. 2007;335:31. | Focus on excluded screening methods
Day SJ, Deszo EL, Freund GG. Dual sampling of the endocervix and its impact on AutoCyte Prep endocervical adequacy. Am J Clin Pathol. 2002;118:41–46. | Reported outcomes do not address a key question
Diaz-Rosario LA, Kabawat SE. Performance of a fluid-based, thin-layer papanicolaou smear method in the clinical setting of an independent laboratory and an outpatient screening population in New England. Arch Pathol Lab Med. 1999;123:817–821. | Does not systematically apply reference standard
Dupree WB, Suprun HZ, Beckwith DG, Shane JJ, Lucente V. The promise and risk of a new technology: The Lehigh Valley Hospital’s experience with liquid-based cervical cytology. Cancer. 1998;84:202–207. | Does not systematically apply reference standard
Ferenczy A, Franco E, Arseneau J, Wright TC, Richart RM. Diagnostic performance of Hybrid Capture human papillomavirus deoxyribonucleic acid assay combined with liquid-based cytologic study. Am J Obstet Gynecol. 1996;175:651–656. | Reported outcomes do not address a key question
Ferenczy A, Robitaille J, Franco E, Arseneau J, Richart RM, Wright TC. Conventional cervical cytologic smears vs. ThinPrep smears. A paired comparison study on cervical cytology. Acta Cytol. 1996;40:1136–1142. | Screening conducted solely in referred population or does not report routine and referred outcomes separately
Ferreccio C, Bratti MC, Sherman ME et al. A comparison of single and combined visual, cytologic, and virologic tests as screening strategies in a region at high risk of cervical cancer. Cancer Epidemiology, Biomarkers & Prevention. 2003;12:815–823. | Reference standard not independent of screening test
Ferris DG, Heidemann NL, Litaker MS, Crosby JH, Macfee MS. The efficacy of liquid-based cervical cytology using direct-to-vial sample collection. J Fam Pract. 2000;49:1005–1011. | Does not systematically apply reference standard
Fremont-Smith M, Marino J, Griffin B, Spencer L, Bolick D. Comparison of the SurePath liquid-based Papanicolaou smear with the conventional Papanicolaou smear in a multisite direct-to-vial study. Cancer. 2004;102:269–279. | Reported outcomes do not address a key question
Genova NJ. Evidence-based medicine--in real time. Comparing methods of cervical Ca screening. JAAPA. 2000;13:55–60, 63. | Editorials, letters, non- systematic review, opinion or case-control
Geyer JW, Hancock F, Carrico C, Kirkpatrick M. Preliminary evaluation of Cyto-Rich: an improved automated cytology preparation. Diagn Cytopathol. 1993;9:417–422. | Does not systematically apply reference standard
Girianelli VR, Thuler LC, Szklo M et al. Comparison of human papillomavirus DNA tests, liquid-based cytology and conventional cytology for the early detection of cervix uteri cancer. Eur J Cancer Prev. 2006;15:504–510. | Focus on excluded screening methods
Guidos BJ, Selvaggi SM. Detection of endometrial adenocarcinoma with the ThinPrep Pap test. Diagn Cytopathol. 2000;23:260–265. | Physician choice of cytology
Guidos BJ, Selvaggi SM. Use of the Thin Prep Pap Test in clinical practice. Diagn Cytopathol. 1999;20:70–73. | Physician choice of cytology
Guo M, Hu L, Martin L, Liu S, Baliga M, Hughson MD. Accuracy of liquid-based Pap tests: comparison of concurrent liquid-based tests and cervical biopsies on 782 women with previously abnormal Pap smears. Acta Cytol. 2005;49:132–138. | No comparison to conventional cytology
Harkness CB, Theofrastous JP, Ibrahim SN, Galvin SL, Lawrence HC. Papanicolaou and thin-layer cervical cytology with colposcopic biopsy control. A comparison. J Reprod Med. 2003;48:681–686. | Colposcopy and/or histology only in positives
Hartmann KE, Nanda K, Hall S, Myers E. Technologic advances for evaluation of cervical cytology: is newer better? Obstet Gynecol Surv. 2001;56:765–774. | Provides data already covered in other article
Hartmann, KE, Hall, SA, Nanda, K, Boggess, JF, and Zolnoun, D. Screening for Cervical Cancer. ii-74. 2002. Agency for Healthcare Research and Quality. | Provides data already covered in other article
Hatch KD, Sheets E, Kennedy A, Ferris DG, Darragh T, Twiggs L. Multicenter direct to vial evaluation of a liquid-based pap test. J Low Genit Tract Dis. 2004;8:308–312. | Editorials, letters, non- systematic review, opinion or case-control
Hatch, K. D. Multi-site clinical outcome trial to evaluate performance of the ThinPrep test. Obstet Gynecol 95[4, Suppl. 1], S51. 2000. | Editorials, letters, non- systematic review, opinion or case-control
HAYES and Inc. Thin-layer pap preparations for detecting cervical cancer. 2003. | Editorials, letters, non- systematic review, opinion or case-control
Health Technology Advisory Committee. Screening for cervical cancer: recent advances. 2002. | Editorials, letters, non- systematic review, opinion or case-control
Herrero R, Schiffman MH, Bratti C et al. Design and methods of a population-based natural history study of cervical neoplasia in a rural province of Costa Rica: the Guanacaste Project. Rev Panam Salud Publica. 1997;1:362–375. | Reference standard not independent of screening test
Hessling JJ, Raso DS, Schiffer B, Callicott J, Jr., Husain M, Taylor D. Effectiveness of thin-layer preparations vs. conventional Pap smears in a blinded, split-sample study. Extended cytologic evaluation. J Reprod Med. 2001;46:880–886. | Does not systematically apply reference standard
Howell LP, Davis RL, Belk TI, Agdigos R, Lowe J. The AutoCyte preparation system for gynecologic cytology. Acta Cytol. 1998;42:171–177. | Does not systematically apply reference standard
Hussein T, Desai M, Tomlinson A, Kitchener HC. The comparative diagnostic accuracy of conventional and liquid-based cytology in a colposcopic setting. BJOG: An International Journal of Obstetrics & Gynaecology. 2005;112:1542–1546. | Screening conducted solely in referred population or does not report routine and referred outcomes separately
Hutchinson ML, Agarwal P, Denault T, Berger B, Cibas ES. A new look at cervical cytology. ThinPrep multicenter trial results. Acta Cytol. 1992;36:499–504. | Does not systematically apply reference standard
Hutchinson ML, Cassin CM, Ball HG, III. The efficacy of an automated preparation device for cervical cytology. Am J Clin Pathol. 1991;96:300–305. | Does not systematically apply reference standard
Hutchinson ML, Zahniser DJ, Sherman ME et al. Utility of liquid-based cytology for cervical carcinoma screening: results of a population-based study conducted in a region of Costa Rica with a high incidence of cervical carcinoma. Cancer. 1999;87:48–55. | Reference standard not independent of screening test
Inhorn SLM, Wilbur DM, Zahniser DP, Linder JM. Validation of the ThinPrep Papanicolaou Test for Cervical Cancer Diagnosis. Journal of Lower Genital Tract Disease. 1998;2:212. | Reported outcomes do not address a key question
Institute for Clinical Systems Improvement. Liquid-based cervical cytology. 2003. | Editorials, letters, non- systematic review, opinion or case-control
Kahn JA, Hillard PJ. Cervical cytology screening and management of abnormal cytology in adolescent girls. J Pediatr Adolesc Gynecol. 2003;16:167–171. | Editorials, letters, non- systematic review, opinion or case-control
Karnon J, Peters J, Platt J, Chilcott J, McGoogan E, Brewer N. Liquid-based cytology in cervical screening: an updated rapid and systematic review and economic analysis. Health Technol Assess. 2004;8:iii, 1-iii,78. | Includes studies that do not meet design criteria
Kim HS, Park JS, Park JY et al. Comparison of two preparation methods for endocervical evaluation. Acta Cytol. 2007;51:742–748. | Screening conducted solely in referred population or does not report routine and referred outcomes separately
Kim JJ, Leung GM, Woo PP, Goldie SJ. Cost-effectiveness of organized versus opportunistic cervical cytology screening in Hong Kong. J Public Health (Oxf). 2004;26:130–137. | Editorials, letters, non- systematic review, opinion or case-control
Klinkhamer PJ, Meerding WJ, Rosier PF, Hanselaar AG. Liquid-based cervical cytology. Cancer. 2003;99:263–271. | Precedes search period
Kruger J. Randomized pilot study comparing rates of endocervical cell recovery between conventional pap smears and liquid-based cytology in a pregnant population. Journal of Lower Genital Tract Disease. 2003;101–103. | Does not systematically apply reference standard
Lancaster JM RSB. Evaluation of three cervical cytology screening techniques for use with liquid-based preparations. Adequacy of the endocervical component. Gynecol Oncol. 2001;293–294. | Focus on comparison of cytologic collection tools
Laverty CR, Farnsworth A, Thurloe JK, Grieves A, Bowditch R. Evaluation of the CytoRich slide preparation process. Anal Quant Cytol Histol. 1997;19:239–245. | Does not systematically apply reference standard
Laverty CR, Thurloe JK, Redman NL, Farnsworth A. An Australian trial of ThinPrep: a new cytopreparatory technique. Cytopathology. 1995;6:140–148. | Does not systematically apply reference standard
Lee KR, Ashfaq R, Birdsong GG, Corkill ME, McIntosh KM, Inhorn SL. Comparison of conventional Papanicolaou smears and a fluid-based, thin-layer system for cervical cancer screening. Obstet Gynecol. 1997;90:278–284. | Does not systematically apply reference standard
Lerma E, Quintana MJ, Quilez M et al. Effectiveness of liquid-based cytology and papanicolaou tests in a low risk population. Acta Cytol. 2007;51:399–406. | Colposcopy and/or histology only in positives
Levine T. ThinPrep LBC cervical sample. Cytopathology. 2007;18:391. | Editorials, letters, non- systematic review, opinion or case-control
Longatto FA, Pereira SM, Di LC et al. DCS liquid-based system is more effective than conventional smears to diagnosis of cervical lesions: study in high-risk population with biopsy-based confirmation. Gynecol Oncol. 2005;97:497–500. | Focus on excluded screening methods
Longatto-Filho A, Maeda MY, Erzen M et al. Conventional Pap smear and liquid- based cytology as screening tools in low-resource settings in Latin America: experience of the Latin American screening study. Acta Cytol. 2005;49:500–506. | Colposcopy and/or histology only in positives
Luthra UK CM. Performance of monolayered cervical smears in a gynecology outpatient setting in Kuwait. Acta Cytol. 2002;303–310. | Does not systematically apply reference standard
Maccallini V, Angeloni C, Caraceni D et al. Comparison of the conventional cervical smear and liquid-based cytology: results of a controlled, prospective study in the Abruzzo Region of Italy. SO: Acta Cytologica. 2008;52:568–574. | Colposcopy and/or histology only in positives
Malle D, Pateinakis P, Chakka E, Destouni C. Experience with a thin-layer, liquid- based cervical cytologic screening method. Acta Cytol. 2003;47:129–134. | Does not systematically apply reference standard
Marino JF, Fremont-Smith M. Direct-to-vial experience with AutoCyte PREP in a small New England regional cytology practice. J Reprod Med. 2001;46:353–358. | Does not systematically apply reference standard
Masumoto N, Fujii T, Ishikawa M et al. Papanicolaou tests and molecular analyses using new fluid-based specimen collection technology in 3000 Japanese women. Br J Cancer. 2003;88:1883–1888. | Poor reporting
Mattosinho de Castro Ferraz Mda, Nicolau SM, Stavale JN et al. Cervical biopsy- based comparison of a new liquid-based thin-layer preparation with conventional Pap smears. Diagn Cytopathol. 2004;30:220–226. | Focus on excluded screening methods
McGoogan E, Reith A. Would monolayers provide more representative samples and improved preparations for cervical screening? Overview and evaluation of systems available. Acta Cytol. 1996;40:107–119. | Focus on comparison of cytologic collection tools
McGoogan, E. Improved adequacy rates using ThinPrep Pap test for routine cytopahtology. Cytopathology 10 (Suppl 1), 2. 1999. | Reported outcomes do not address a key question
Medical Services Advisory Committee. Liquid based cytology for cervical screening. 2002. | Includes studies that do not meet design criteria
Minge L, Fleming M, VanGeem T, Bishop JW. AutoCyte Prep system vs. conventional cervical cytology. Comparison based on 2,156 cases. J Reprod Med. 2000;45:179–184. | Does not systematically apply reference standard
Monsonego J, utillo-Touati A, Bergeron C et al. Liquid-based cytology for primary cervical cancer screening: a multi-centre study. Br J Cancer. 2001;84:360–366. | Does not systematically apply reference standard
Moscicki AB, Cox JT. Practice improvement in cervical screening and management (PICSM): symposium on management of cervical abnormalities in adolescents and young women. Journal of Lower Genital Tract Disease. 2010;14:73–80. | Editorials, letters, non- systematic review, opinion or case-control
Moseley RP, Paget S. Liquid-based cytology: is this the way forward for cervical screening? Cytopathology. 2002;13:71–82. | Precedes search period
Moss SM, Gray A, Legood R, and Henstock E. Evaluation of hpv/lvc: cervical screening pilot studies. First report to the Department of Health on LBC. 1–96. 2003. | Reported outcomes do not address a key question
Nanda K, McCrory DC, Myers ER et al. Accuracy of the Papanicolaou test in screening for and follow-up of cervical cytologic abnormalities: a systematic review. Ann Intern Med. 2000;132:810–819. | Precedes search period
NHS, Quality, I. The use of liquid-based cytology for cervical screening (review). 2003. | Editorials, letters, non- systematic review, opinion or case-control
Noorani, H. Z., Brown, A., Skidmore, B., and Stuart, G. C. E. Liquid-based cytology and human papillomavirus testing in cervical cancer screening. 2003. | Includes studies that do not meet design criteria
Obwegeser JH BS. Does liquid-based technology really improve detection of cervical neoplasia? A prospective, randomized trial comparing the ThinPrep Pap Test with the conventional Pap Test, including follow-up of HSIL cases. Acta Cytol. 2001;709–714. | Colposcopy and/or histology only in positives
Pan Q, Belinson JL, Li L et al. A thin-layer, liquid-based pap test for mass screening in an area of China with a high incidence of cervical carcinoma. A cross-sectional, comparative study. Acta Cytol. 2003;47:45–50. | No comparison to conventional cytology
Papillo JL, Zarka MA, St John TL. Evaluation of the ThinPrep Pap test in clinical practice. A seven-month, 16,314-case experience in northern Vermont. Acta Cytol. 1998;42:203–208. | Does not systematically apply reference standard
Park IA, Lee SN, Chae SW, Park KH, Kim JW, Lee HP. Comparing the accuracy of ThinPrep Pap tests and conventional Papanicolaou smears on the basis of the histologic diagnosis: a clinical study of women with cervical abnormalities. Acta Cytol. 2001;45:525–531. | Colposcopy and/or histology only in positives
Partridge EE, bu-Rustum N, Campos S et al. Cervical cancer screening. Journal of the National Comprehensive Cancer Network. 2008;6:58–82. | Editorials, letters, non- systematic review, opinion or case-control
Payne N, Chilcott J, McGoogan E. Liquid-based cytology in cervical screening: a rapid and systematic review. Health Technol Assess. 2000;4:1–73. | Precedes search period
Pretorius RG, Kim RJ, Belinson JL, Elson P, Qiao YL. Inflation of sensitivity of cervical cancer screening tests secondary to correlated error in colposcopy. Journal of Lower Genital Tract Disease. 2006;10:5–9. | No comparison to conventional cytology
Ring M, Bolger N, O’Donnell M et al. Evaluation of liquid-based cytology in cervical screening of high-risk populations: a split study of colposcopy and genito-urinary medicine populations. Cytopathology. 2002;13:152–159. | Does not systematically apply reference standard
Roberts JM, Gurley AM, Thurloe JK, Bowditch R, Laverty CR. Evaluation of the ThinPrep Pap test as an adjunct to the conventional Pap smear. Med J Aust. 1997;167:466–469. | Does not systematically apply reference standard
Roberts JM, Thurloe JK, Bowditch RC et al. A three-armed trial of the ThinPrep Imaging System. Diagn Cytopathol. 2007;35:96–102. | Focus on excluded screening methods
Ronco G, Giorgi RP, Carozzi F et al. Human papillomavirus testing and liquid-based cytology in primary screening of women younger than 35 years: results at recruitment for a randomised controlled trial. The lancet oncology. 2006;7:547–555. | Differential loss to followup and referral criteria
Rosenthal DL, Geddes S, Trimble CL, Carson KA, Alli PM. The PapSpin: a reasonable alternative to other, more expensive liquid-based Papanicolaou tests. Cancer. 2006;108:137–143. | Focus on excluded screening methods
Sheets EE, Constantine NM, Dinisco S, Dean B, Cibas ES. Colposcopically Directed Biopsies Provide a Basis for Comparing the Accuracy of ThinPrep and Papanicolaou Smears. Obstetrical & Gynecological Survey. 1995;50:659–661. | Does not systematically apply reference standard
Sherman M, Schiffman M. Effects of age and human papilloma viral load on colposcopy triage: data from the randomized Atypical Squamous Cells of Undetermined Significance/Low-Grade Squamous Intraepithelial Lesion Triage Study (ALTS). J Natl Cancer Inst. 2002;102–107. | Reported outcomes do not address a key question
Sherman ME, Mendoza M, Lee KR et al. Performance of liquid-based, thin-layer cervical cytology: correlation with reference diagnoses and human papillomavirus testing. Mod Pathol. 1998;11:837–843. | Does not systematically apply reference standard
Sherman ME, Schiffman MH, Lorincz AT et al. Cervical specimens collected in liquid buffer are suitable for both cytologic screening and ancillary human papillomavirus testing. Cancer. 1997;81:89–97. | Reported outcomes do not address a key question
Shield PW, Nolan GR, Phillips GE, Cummings MC. Improving cervical cytology screening in a remote, high risk population. Med J Aust. 1999;170:255–258. | Does not systematically apply reference standard
Sprenger E, Schwarzmann P, Kirkpatrick M et al. The false negative rate in cervical cytology. Comparison of monolayers to conventional smears. Acta Cytol. 1996;40:81–89. | Does not systematically apply reference standard
Stevens MW, Nespolon WW, Milne AJ, Rowland R. Evaluation of the CytoRich technique for cervical smears. Diagn Cytopathol. 1998;18:236–242. | Does not systematically apply reference standard
Strander B, ndersson-Ellstrom A, Milsom I, Radberg T, Ryd W. Liquid-based cytology versus conventional Papanicolaou smear in an organized screening program : a prospective randomized study. Cancer. 2007;111:285–291. | Does not systematically apply reference standard
Stuart G, Taylor G, Bancej CM et al. Report of the 2003 pan-Canadian forum on cervical cancer prevention and control. J Obstet Gynaecol Can. 2004;26:1004–1028. | Editorials, letters, non- systematic review, opinion or case-control
Sulik SM, Kroeger K, Schultz JK, Brown JL, Becker LA, Grant WD. Are fluid-based cytologies superior to the conventional Papanicolaou test? A systematic review. J Fam Pract. 2001;50:1040–1046. | Precedes search period
Syrjanen K, Derchain S, Roteli-Martins C et al. Value of conventional pap smear, liquid-based cytology, visual inspection and human papillomavirus testing as optional screening tools among Latin American women <35 and > or =35 years of age: experience from the Latin American Screening Study. Acta Cytol. 2008;52:641–653. | Poor reporting
Syrjanen K, Naud P, Derchain S et al. Comparing PAP smear cytology, aided visual inspection, screening colposcopy, cervicography and HPV testing as optional screening tools in Latin America. Study design and baseline data of the LAMS study. Anticancer Res. 2005;25:3469–3480. | Reported outcomes do not address a key question
Takahashi M, Naito M. Application of the CytoRich monolayer preparation system for cervical cytology. A prelude to automated primary screening. Acta Cytol. 1997;41:1785–1789. | Does not systematically apply reference standard
Tench W. Preliminary assessment of the AutoCyte PREP. Direct-to-vial performance. J Reprod Med. 2000;45:912–916. | Does not systematically apply reference standard
Tezuka F, Oikawa H, Shuki H, Higashiiwai H. Diagnostic efficacy and validity of the ThinPrep method in cervical cytology. Acta Cytol. 1996;40:513–518. | Colposcopy and/or histology only in positives
Tuncer ZS, Baaran M, Sezgin Y, Firat P, Mocan KG. Clinical results of a split sample liquid-based cytology (ThinPrep) study of 4,322 patients in a Turkish institution. Eur J Gynaecol Oncol. 2005;26:646–648. | Colposcopy and/or histology only in positives
Utagawa ML, Pereira SM, Makabe S et al. Pap test in a high-risk population comparison of conventional and liquid-base cytology. Diagn Cytopathol. 2004;31:169–172. | Focus on excluded screening methods
Vassilakos P, Cossali D, Albe X, Alonso L, Hohener R, Puget E. Efficacy of monolayer preparations for cervical cytology: emphasis on suboptimal specimens. Acta Cytol. 1996;40:496–500. | Reported outcomes do not address a key question
Vassilakos P, Griffin S, Megevand E, Campana A. CytoRich liquid-based cervical cytologic test. Screening results in a routine cytopathology service. Acta Cytol. 1998;42:198–202. | Does not systematically apply reference standard
Vassilakos P, Saurel J, Rondez R. Direct-to-vial use of the AutoCyte PREP liquid- based preparation for cervical-vaginal specimens in three European laboratories. Acta Cytol. 1999;43:65–68. | Does not systematically apply reference standard
Wang TY, Chen HS, Yang YC, Tsou MC. Comparison of fluid-based, thin-layer processing and conventional Papanicolaou methods for uterine cervical cytology. J Formos Med Assoc. 1999;98:500–505. | Does not systematically apply reference standard
Weintraub J, Morabia A. Efficacy of a liquid-based thin layer method for cervical cancer screening in a population with a low incidence of cervical cancer. Diagn Cytopathol. 2000;22:52–59. | Does not systematically apply reference standard
Weintraub, J. The coming revolution in cervical cytology: a pathologist’s guide for the clinician. References en Gynecologie Obstetrique 5, 1–6. 1997. | Editorials, letters, non- systematic review, opinion or case-control
Wilbur DC, Cibas ES, Merritt S, James LP, Berger BM, Bonfiglio TA. ThinPrep Processor. Clinical trials demonstrate an increased detection rate of abnormal cervical cytologic specimens. Am J Clin Pathol. 1994;101:209–214. | Does not systematically apply reference standard
Wilbur DC, Dubeshter B, Angel C, Atkison KM. Use of thin-layer preparations for gynecologic smears with emphasis on the cytomorphology of high-grade intraepithelial lesions and carcinomas. Diagn Cytopathol. 1996;14:201–211. | Setting not primary care or comparable
Wilbur DC, Facik MS, Rutkowski MA, Mulford DK, Atkison KM. Clinical trials of the CytoRich specimen-preparation device for cervical cytology. Preliminary results. Acta Cytol. 1997;41:24–29. | Does not systematically apply reference standard
Yeoh GP, Chan KW, Lauder I, Lam MB. Evaluation of the ThinPrep Papanicolaou test in clinical practice: 6-month study of 16,541 cases with histological correlation in 220 cases. Hong Kong Med J. 1999;5:233–239. | Physician choice of cytology
Yeoh GP, Chan KW. Cell block preparation on residual ThinPrep sample. Diagn Cytopathol. 1999;21:427–431. | Reported outcomes do not address a key question
Zhu J, Norman I, Elfgren K et al. A comparison of liquid-based cytology and Pap smear as a screening method for cervical cancer. Oncol Rep. 2007;18:157–160. | Screening conducted solely in referred population or does not report routine and referred outcomes separately
Zielinski SL. Trial quickly changed management of cervical abnormalities. J Natl Cancer Inst. 2005;97:479–480. | Editorials, letters, non- systematic review, opinion or case-control

* See Appendix B Table 2 for more detailed exclusion criteria

‡ One example of a large study that did not meet criteria for our review is the Guanacaste study, a population-based study of over 10,000 high-risk women that compared liquid-based to conventional cytology. In this study, the final histologic diagnosis included the results of the screening tests. Additionally, the reference standard of colposcopy and biopsy was not systematically applied.

Appendix D Table 3 Studies Excluded From the Review for KQ3

Key Question 3: What are the benefits of using HPV testing as a screening test, either alone or in combination with cytology, compared with not testing for HPV?
Reference | Reason for exclusion^*^
Adam E, Kaufman RH, Berkova Z, Icenogle J, Reeves WC. Is human papillomavirus testing an effective triage method for detection of high-grade (grade 2 or 3) cervical intraepithelial neoplasia? Am J Obstet Gynecol. 1998;1998:1235–1244. | Included women with repeated abnormal smears or abnormal smear other than ASC
Adamopoulou M, Kalkani E, Charvalos E, Avgoustidis D, Haidopoulos D, Yapijakis C. Comparison of cytology, colposcopy, HPV typing and biomarker analysis in cervical neoplasia. Anticancer Res. 2009;29:3401–3409. | Included women with repeated abnormal smears or abnormal smear other than ASC
Agorastos T, Dinas K, Lloveras B et al. Human papillomavirus testing for primary screening in women at low risk of developing cervical cancer. The Greek experience. Gynecol Oncol. 2005;96:714–720. | Poor reporting
Agorastos T, Sotiriadis A, Emmanouilides CJ. Effect of type-specific human papillomavirus incidence on screening performance and cost. International Journal of Gynecological Cancer. 2010;20:276–282. | Editorial, letter, non- systematic review, opinion, or case-control
Al-Alwan NA. Colposcopy, cervical cytology and human papillomavirus detection as screening tools for cervical cancer. Eastern Mediterranean Health Journal. 2001;7:100–105. | No relevant outcomes
Almonte M, Ferreccio C, Winkler JL et al. Cervical screening by visual inspection, HPV testing, liquid-based and conventional cytology in Amazonian Peru. Int J Cancer. 2007;121:796–802. | Colposcopy and/or histology only in positives
Antonishyn NA, Horsman GB, Kelln RA, Severini A. Human papillomavirus typing and viral gene expression analysis for the triage of women with abnormal results from papanicolaou test smears to colposcopy. Archives of Pathology & Laboratory Medicine. 2009;133:1577–1586. | Included women with repeated abnormal smears or abnormal smear other than ASC
Arbyn M, Buntinx F, Van Ranst M, Paraskevaidis E, Martin-Hirsch P, Dillner J. Virologic versus cytologic triage of women with equivocal Pap smears: a meta-analysis of the accuracy to detect high-grade intraepithelial neoplasia. J Natl Cancer Inst. 2004;96:280–293. | SER includes studies that do not meet design criteria
Arbyn M, Paraskevaidis E, Martin-Hirsch P, Prendiville W, Dillner J. Clinical utility of HPV-DNA detection: triage of minor cervical lesions, follow-up of women treated for high-grade CIN: an update of pooled evidence. Gynecol Oncol. 2005;99:S7–11. | SER includes studies that do not meet design criteria
Arbyn M, Ronco G, Meijer CJ, Naucler P. Trials comparing cytology with human papillomavirus screening. Lancet Oncology. 2009;10:935–936. | Editorial, letter, non- systematic review, opinion, or case-control
Arbyn M, Sankaranarayanan R, Muwonge R et al. Pooled analysis of the accuracy of five cervical cancer screening tests assessed in eleven studies in Africa and India. Int J Cancer. 2008;123:153–160. | SER includes studies that do not meet design criteria
Arbyn M, Sasieni P, Meijer CJ, Clavel C, Koliopoulos G, Dillner J. Chapter 9: Clinical applications of HPV testing: A summary of meta-analyses. Vaccine. 2006;24 Suppl 3:S78–S89. | Editorial, letter, non- systematic review, opinion, or case-control
Arbyn M., Buntinx F Van Ranst M Corinas Abrahantes J. Triage of women with atypical or low-grade cytological abnormalities of the cervix by HPV testing: systematic review and meta-analysis. IPH/EPI-REPORTS Nr.2001-019, 1–240. 2002. Brussels, Scientific Institute of Public Health. | SER includes studies that do not meet design criteria
Arbyn, M. HPV testing in triage of women with equivocal cytology. HPV Today 11, 6–7. 2007. | SER includes studies that do not meet design criteria
Arora R, Kumar A, Prusty BK, Kailash U, Batra S, Das BC. Prevalence of high-risk human papillomavirus (HR-HPV) types 16 and 18 in healthy women with cytologically negative Pap smear. European Journal of Obstetrics, Gynecology, & Reproductive Biology. 2005;121:104–109. | No relevant outcomes
Atkins KA, Jeronimo J, Stoler MH, ALTS Group. Description of patients with squamous cell carcinoma in the atypical squamous cells of undetermined significance/low-grade squamous intraepithelial lesion triage study. Cancer. 2006;108:212–221. | No relevant outcomes
Bacon J, Francoeur D, Goldfarb AF, Breech LL. Abnormal pap smears in adolescents. J Pediatr Adolesc Gynecol. 2003;16:157–166. | Editorial, letter, non- systematic review, opinion, or case-control
Bais AG, Rebolj M, Snijders PJ et al. Triage using HPV-testing in persistent borderline and mildly dyskaryotic smears: proposal for new guidelines. Int J Cancer. 2005;116:122–129. | No comparison to cytology
Bavin PJ, Giles JA, Deery A et al. Use of semi-quantitative PCR for human papillomavirus DNA type 16 to identify women with high grade cervical disease in a population presenting with a mildly dyskaryotic smear report. Br J Cancer. 1993;67:602–605. | No relevant outcomes
Belinson JL, Qiao YL, Pretorius RG et al. Shanxi Province cervical cancer screening study II: self-sampling for high-risk human papillomavirus compared to direct sampling for human papillomavirus and liquid based cervical cytology. International Journal of Gynecological Cancer. 2003;13:819–826. | Focus on excluded screening methods
Bengtsson E, Lindell M, Wikstrom I, Wilander E. Human papilloma virus tests of normal cervical smears collected prior to the development of squamous carcinoma: a pilot study. Acta Derm Venereol. 2009;89:516–517. | Editorial, letter, non- systematic review, opinion, or case-control
Bergeron C, Cas F, Fagnani F, iller-Lambert F, Poveda JD. Human papillomavirus testing with a liquid-based system: feasibility and comparison with reference diagnoses. Acta Cytol. 2006;50:16–22. | Editorial, letter, non- systematic review, opinion, or case-control
Berkhof J, Coupe VM, Bogaards JA et al. The health and economic effects of HPV DNA screening in The Netherlands. Int J Cancer. 2010. | Editorial, letter, non- systematic review, opinion, or case-control
Bewtra C, Xie Q, Soundararajan S, Gatalica Z, Hatcher L. Genital human papillomavirus testing by in situ hybridization in liquid atypical cytologic materials and follow-up biopsies. Acta Cytol. 2005;49:127–131. | Focus on excluded screening methods
Bhatla N, Mukhopadhyay A, Kriplani A et al. Evaluation of adjunctive tests for cervical cancer screening in low resource settings. Indian J Cancer. 2007;44:51–55. | Population not comparable to primary care
Blumenthal PD, Gaffikin L, Chirenje ZM, McGrath J, Womack S, Shah K. Adjunctive testing for cervical cancer in low resource settings with visual inspection, HPV, and the Pap smear. International Journal of Gynaecology & Obstetrics. 2001;72:47–53. | Population not comparable to primary care
Boardman LA, Weitzen S, Stanko C. Atypical squamous cells of undetermined significance, human papillomavirus, and cervical intraepithelial neoplasia 2 or 3 in adolescents: ASC-US, age, and high-grade cervical neoplasia. Journal of Lower Genital Tract Disease. 2006;10:140–145. | No relevant outcomes
Bollen LJ, Tjong AHS, van der Velden J et al. Human papillomavirus deoxyribonucleic acid detection in mildly or moderately dysplastic smears: a possible method for selecting patients for colposcopy. Am J Obstet Gynecol. 1997;1997:548–553. | Included women with repeated abnormal smears or abnormal smear other than ASC
Bollmann R, Bankfalvi A, Griefingholt H et al. Validity of combined cytology and human papillomavirus (HPV) genotyping with adjuvant DNA-cytometry in routine cervical screening: results from 31031 women from the Bonn-region in West Germany. Oncol Rep. 2005;13:915–922. | Colposcopy and/or histology only in positives
Boon ME, Rijkaart DC, Ouwerkerk-Noordam E, Korporaal H. Dutch solutions for liquid- based cytology: analysis of unsatisfactory slides and HPV testing of equivocal cytology. Diagn Cytopathol. 2006;34:644–648. | No relevant outcomes
Bory JP, Cucherousset J, Lorenzato M et al. Recurrent human papillomavirus infection detected with the hybrid capture II assay selects women with normal cervical smears at risk for developing high grade cervical lesions: a longitudinal study of 3,091 women. Int J Cancer. 2002;102:519–525. | No relevant outcomes
Bosch FX, de SS. Human papillomavirus in cervical cancer. Curr Oncol Rep. 2002;4:175–183. | Editorial, letter, non- systematic review, opinion, or case-control
Bozzetti M, Nonnenmacher B, Mielzinska I, I et al. Comparison between hybrid capture II and polymerase chain reaction results among women at low risk for cervical cancer. Ann Epidemiol. 2000;10:466. | Editorial, letter, non- systematic review, opinion, or case-control
Braganca JF, Derchain SF, Sarian LO, Messias da Silva SM, Labatte S, Zeferino LC. Aided visual inspection with acetic acid (VIA) and HPV detection as optional screening tools for cervical cancer and its precursor lesions. Clinical & Experimental Obstetrics & Gynecology. 2005;32:225–229. | Colposcopy and/or histology only in positives
Bratti MC, Rodriguez AC, Schiffman M et al. Description of a seven-year prospective study of human papillomavirus infection and cervical neoplasia among 10000 women in Guanacaste, Costa Rica. Rev Panam Salud Publica. 2004;15:75–89. | Reference standard not independent of screening test
Bulk S, Bulkmans NW, Berkhof J et al. Risk of high-grade cervical intra-epithelial neoplasia based on cytology and high-risk HPV testing at baseline and at 6-months. Int J Cancer. 2007;121:361–367. | Provides no data not otherwise covered in other articles for this study
Bulkmans NW, Bulk S, Ottevanger MS et al. Implementation of human papillomavirus testing in cervical screening without a concomitant decrease in participation rate. J Clin Pathol. 2006;59:1218–1220. | No relevant outcomes
Bulkmans NW, Rozendaal L, Voorhorst FJ, Snijders PJ, Meijer CJ. Long-term protective effect of high-risk human papillomavirus testing in population-based cervical screening. Br J Cancer. 2005;92:1800–1802. | Does not systematically apply reference standard of colposcopy and/or histology
Cagle AJ, Hu SY, Sellors JW et al. Use of an expanded gold standard to estimate the accuracy of colposcopy and visual inspection with acetic acid. Int J Cancer. 2010;126:156–161. | Colposcopy and/or histology only in positives
Carozzi F, Bisanzi S, Sani C et al. Agreement between the AMPLICOR Human Papillomavirus Test and the Hybrid Capture 2 assay in detection of high-risk human papillomavirus and diagnosis of biopsy-confirmed high-grade cervical disease. J Clin Microbiol. 2007;45:364–369. | Colposcopy and/or histology only in positives
Carozzi FM, Confortini M, Cecchini S et al. Triage with human papillomavirus testing of women with cytologic abnormalities prompting referral for colposcopy assessment. Cancer. 2005;105:2–7. | Poor reporting
Castle PE, Fetterman B, Poitras N, Lorey T, Shaber R, Kinney W. Five-year experience of human papillomavirus DNA and Papanicolaou test cotesting. Obstetrics & Gynecology. 2009;113:595–600. | No relevant outcomes
Castle PE, Gravitt PE, Solomon D, Wheeler CM, Schiffman M. Comparison of linear array and line blot assay for detection of human papillomavirus and diagnosis of cervical precancer and cancer in the atypical squamous cell of undetermined significance and low-grade squamous intraepithelial lesion triage study. J Clin Microbiol. 2008;46:109–117. | No comparison to cytology
Castle PE, Schiffman M, Wheeler CM, Wentzensen N, Gravitt PE. Impact of improved classification on the association of human papillomavirus with cervical precancer. Am J Epidemiol. 2010;171:155–163. | No comparison to cytology
Castle PE, Stoler MH, Solomon D, Schiffman M. The relationship of community biopsy-diagnosed cervical intraepithelial neoplasia grade 2 to the quality control pathology-reviewed diagnoses: an ALTS report. Am J Clin Pathol. 2007;127:805–815. | No relevant outcomes
Cattani P, Zannoni GF, Ricci C et al. Clinical performance of human papillomavirus E6 and E7 mRNA testing for high-grade lesions of the cervix. J Clin Microbiol. 2009;47:3895–3901. | No comparison to cytology
Cibas ES, Hong X, Crum CP, Feldman S. Age-specific detection of high risk HPV DNA in cytologically normal, computer-imaged ThinPrep Pap samples. Gynecol Oncol. 2007;104:702–706. | Does not systematically apply reference standard of colposcopy and/or histology
Ciotti M, Sesti F, Paba P et al. Human papillomavirus (HPV) testing in the management of women with abnormal Pap smears. Experience of a colposcopy referral clinic. Eur J Gynaecol Oncol. 2004;25:577–584. | Poor reporting
Clavel C, Masure M, Bory JP et al. Human papillomavirus testing in primary screening for the detection of high-grade cervical lesions: a study of 7932 women. Br J Cancer. 2001;84:1616–1623. | Poor reporting
Clavel C, Masure M, Levert M et al. Human papillomavirus detection by the hybrid capture II assay: a reliable test to select women with normal cervical smears at risk for developing cervical lesions. Diagn Mol Pathol. 2000;9:145–150. | No relevant outcomes
Cochand-Priollet B, Cartier I, de Cremoux P et al. Cost-effectiveness of liquid-based cytology with or without hybrid-capture II HPV test compared with conventional Pap smears: a study by the French Society of Clinical Cytology. Diagn Cytopathol. 2005;33:338–343. | Provides no data not otherwise covered in other articles for this study
Cogliano V, Grosse Y, Baan R, Straif K, Secretan B, El GF. Carcinogenicity of combined oestrogen-progestagen contraceptives and menopausal treatment. Lancet Oncol. 2005;6:552–553. | Editorial, letter, non- systematic review, opinion, or case-control
Confortini M, Giorgi RP, Barbarino P, Passarelli AM, Orzella L, Tufi MC. Screening for cervical cancer with the human papillomavirus test in an area of central Italy with no previous active cytological screening programme. J Med Screen. 2010;17:79–86. | Colposcopy and/or histology only in positives
Contribution of human papillomavirus testing by hybrid capture in the triage of women with repeated abnormal pap smears before colposcopy referral. Journal of Lower Genital Tract Disease. 2001;5:195–196. | Editorial, letter, non- systematic review, opinion, or case-control
Costa S, Sideri M, Syrjanen K et al. Combined Pap smear, cervicography and HPV DNA testing in the detection of cervical intraepithelial neoplasia and cancer. Acta Cytol. 2000;44:310–318. | Focus on excluded screening methods
Cotton S, Sharp L, Little J et al. The role of human papillomavirus testing in the management of women with low-grade abnormalities: multicentre randomised controlled trial. BJOG: An International Journal of Obstetrics & Gynaecology. 2010;117:645–659. | No comparison to cytology
Cotton SC, Sharp L, Little J et al. Trial of management of borderline and other low- grade abnormal smears (TOMBOLA): Trial design. Contemporary Clinical Trials. 2006;27:449–471. | No relevant outcomes
Coupe VM, Berkhof J, Bulkmans NW, Snijders PJ, Meijer CJ. Age-dependent prevalence of 14 high-risk HPV types in the Netherlands: implications for prophylactic vaccination and screening. Br J Cancer. 2008;98:646–651. | No relevant outcomes
Cox JT, Lorincz AT, Schiffman MH, Sherman ME, Cullen A, Kurman RJ. Human papillomavirus testing by hybrid capture appears to be useful in triaging women with a cytologic diagnosis of atypical squamous cells of undetermined significance. Am J Obstet Gynecol. 1995;1995:946–954. | Focus on excluded screening methods
Cox JT. The development of cervical cancer and its precursors: what is the role of human papillomavirus infection? Curr Opin Obstet Gynecol. 2006;18 Suppl 1:s5–s13. | Editorial, letter, non- systematic review, opinion, or case-control
Cuschieri KS, Cubie HA, Whitley MW et al. Persistent high risk HPV infection associated with development of cervical neoplasia in a prospective population study. J Clin Pathol. 2005;58:946–950. | No relevant outcomes
Cuschieri KS, Graham C, Moore C, Cubie HA. Human Papillomavirus testing for the management of low-grade cervical abnormalities in the UK--Influence of age and testing strategy. J Clin Virol. 2007;38:14–18. | Does not systematically apply reference standard of colposcopy and/or histology
Cuzick J, Arbyn M, Sankaranarayanan R et al. Overview of human papillomavirus- based and other novel options for cervical cancer screening in developed and developing countries. Vaccine. 2008;26:Suppl-41. | SER includes studies that do not meet design criteria
Cuzick J, Beverley E, Ho L et al. HPV testing in primary screening of older women. Br J Cancer. 1999;81:554–558. | Colposcopy and/or histology only in positives
Cuzick J, Clavel C, Petry KU et al. Overview of the European and North American studies on HPV testing in primary cervical cancer screening. Int J Cancer. 2006;119:1095–1101. | Editorial, letter, non- systematic review, opinion, or case-control
Cuzick J, Sasieni P, Davies P et al. A systematic review of the role of human papilloma virus (HPV) testing within a cervical screening programme: summary and conclusions. Br J Cancer. 2000;83:561–565. | Editorial, letter, non- systematic review, opinion, or case-control
Cuzick J, Sasieni P, Davies P et al. A systematic review of the role of human papillomavirus testing within a cervical screening programme. Health Technol Assess. 1999;3:i–196. | Precedes search period
Cuzick J, Szarewski A, Cubie H et al. Management of women who test positive for high-risk types of human papillomavirus: the HART study. Lancet. 2003;362:1871–1876. | Verification bias, lack of blinding, time to colpo/bx not reported^‡^
Cuzick J, Szarewski A, Terry G et al. Human papillomavirus testing in primary cervical screening. Lancet. 1995;1995:1533–1536. | Colposcopy and/or histology only in positives
Dalla Palma P, Pojer A, Girlando S. HPV triage of women with atypical squamous cells of undetermined significance: a 3-year experience in an Italian organized programme. Cytopathology. 2005;16:22–26. | Colposcopy and/or histology only in positives
Davies P, Arbyn M, Dillner J et al. A report on the current status of European research on the use of human papillomavirus testing for primary cervical cancer screening. Int J Cancer. 2006;118:791–796. | Editorial, letter, non- systematic review, opinion, or case-control
Dawar M, Deeks S, Dobson S. Human papillomavirus vaccines launch a new era in cervical cancer prevention. CMAJ. 2007;2007:456–461. | Editorial, letter, non- systematic review, opinion, or case-control
De Francesco MA, Gargiulo F, Schreiber C, Ciravolo G, Salinaro F, Manca N. Comparison of the AMPLICOR human papillomavirus test and the hybrid capture 2 assay for detection of high-risk human papillomavirus in women with abnormal PAP smear. J Virol Methods. 2008;147:10–17. | No comparison to cytology
de OM, varez-Arguelles ME, Torrents M et al. Prevalence, evolution, and features of infection with human papillomavirus: a 15-year longitudinal study of routine screening of a women population in the north of Spain. J Med Virol. 2010;82:597–604. | No relevant outcomes
de Vuyst H, Claeys P, Njiru S et al. Comparison of pap smear, visual inspection with acetic acid, human papillomavirus DNA-PCR testing and cervicography. International Journal of Gynaecology & Obstetrics. 2005;89:120–126. | Conducted solely in referred population or does not report routine and referred population outcomes separately
de Vuyst H, Steyaert S, Van Renterghem L et al. Distribution of human papillomavirus in a family planning population in nairobi, kenya. Sex Transm Dis. 2003;30:137–142. | No comparison to cytology
Denny L, Kuhn L, Pollack A, Wainwright H, Wright TC, Jr. Evaluation of alternative methods of cervical cancer screening for resource-poor settings. Cancer. 2000;89:826–833. | Focus on excluded screening methods
Derchain SF, Sarian LO, Naud P et al. Safety of screening with Human papillomavirus testing for cervical cancer at three-year intervals in a high-risk population: experience from the LAMS study. J Med Screen. 2008;15:97–104. | Colposcopy and/or histology only in positives
Dillner J, Rebolj M, Birembaut P et al. Long term predictive values of cytology and human papillomavirus testing in cervical cancer screening: joint European cohort study. BMJ. 2008;337:a1754. | Editorial, letter, non- systematic review, opinion, or case-control
Dockter J, Schroder A, Hill C, Guzenski L, Monsonego J, Giachetti C. Clinical performance of the APTIMA HPV Assay for the detection of high-risk HPV and high- grade cervical lesions. J Clin Virol. 2009;45:Suppl-61. | No comparison to cytology
Dowie R, Stoykova B, Crawford D et al. Liquid-based cytology can improve efficiency of cervical smear readers: evidence from timing surveys in two NHS cytology laboratories. Cytopathology. 2006;17:65–72. | No relevant outcomes
Ekalaksananan T, Pientong C, Kotimanusvanij D, Kongyingyoes B, Sriamporn S, Jintakanon D. The relationship of human papillomavirus (HPV) detection to pap smear classification of cervical-scraped cells in asymptomatic women in northeast Thailand. Journal of Obstetrics & Gynaecology Research. 2001;27:117–124. | Colposcopy and/or histology only in positives
Eltoum IA, Chhieng DC, Roberson J, McMillon D, Partridge EE. Reflex human papilloma virus infection testing detects the same proportion of cervical intraepithelial neoplasia grade 2–3 in young versus elderly women. Cancer. 2005;105:194–198. | Editorial, letter, non- systematic review, opinion, or case-control
Evans MF, Adamson CS, Papillo JL, St John TL, Leiman G, Cooper K. Distribution of human papillomavirus types in ThinPrep Papanicolaou tests classified according to the Bethesda 2001 terminology and correlations with patient age and biopsy outcomes. Cancer. 2006;106:1054–1064. | Does not systematically apply reference standard of colposcopy and/or histology
Fait G, Daniel Y, Kupferminc MJ, Lessing JB, Niv J, Bar-Am A. Does typing of human papillomavirus assist in the triage of women with repeated low-grade, cervical cytologic abnormalities? Gynecol Oncol. 1998;1998:319–322. | Focus on excluded screening methods
Fait G, Kupferminc MJ, Daniel Y et al. Contribution of human papillomavirus testing by hybrid capture in the triage of women with repeated abnormal pap smears before colposcopy referral. Gynecol Oncol. 2000;79:177–180. | Focus on excluded screening methods
Farag R, Redline R, bdul-Karim FW. Value of combining HPV-DNA testing with follow- up Papanicolaou smear in patients with prior atypical squamous cells of undetermined significance. Acta Cytol. 2008;52:294–296. | Does not systematically apply reference standard of colposcopy and/or histology
Ferenczy A, Franco E, Arseneau J, Wright TC, Richart RM. Diagnostic performance of Hybrid Capture human papillomavirus deoxyribonucleic acid assay combined with liquid-based cytologic study. Am J Obstet Gynecol. 1996;175:651–656. | Focus on excluded screening methods
Ferreccio C, Bratti MC, Sherman ME et al. A comparison of single and combined visual, cytologic, and virologic tests as screening strategies in a region at high risk of cervical cancer. Cancer Epidemiology, Biomarkers & Prevention. 2003;12:815–823. | Reference standard not independent of screening test
Ferris DG, Schiffman M, Litaker MS. Cervicography for triage of women with mildly abnormal cervical cytology results. Am J Obstet Gynecol. 2001;185:939–943. | Focus on excluded screening methods
Ferris DG, Wright TC, Jr., Litaker MS et al. Comparison of two tests for detecting carcinogenic HPV in women with Papanicolaou smear reports of ASCUS and LSIL. J Fam Pract. 1998;1998:136–141. | No comparison to cytology
Ferris DG, Wright TC, Jr., Litaker MS et al. Triage of women with ASCUS and LSIL on Pap smear reports: management by repeat Pap smear, HPV DNA testing, or colposcopy? J Fam Pract. 1998;1998:125–134. | No comparison to cytology
Flores Y, Bishai D, Lazcano E et al. Improving cervical cancer screening in Mexico: results from the Morelos HPV Study. Salud Publica Mex. 2003;45:Suppl-98. | Colposcopy and/or histology only in positives
Flores Y, Shah K, Lazcano E et al. Design and methods of the evaluation of an HPV- based cervical cancer screening strategy in Mexico: The Morelos HPV Study. Salud Publica Mex. 2002;44:335–344. | No relevant outcomes
Forslund O, Antonsson A, Edlund K et al. Population-based type-specific prevalence of high-risk human papillomavirus infection in middle-aged Swedish women. J Med Virol. 2002;66:535–541. | No relevant outcomes
Franco EL. A new generation of studies of human papillomavirus DNA testing in cervical cancer screening. J Natl Cancer Inst. 2009;101:1600–1601. | Editorial, letter, non- systematic review, opinion, or case-control
Franco EL. Randomized controlled trials of HPV testing and Pap cytology: toward evidence-based cervical cancer prevention. Int J Cancer. 2004;110:1–2. | Editorial, letter, non- systematic review, opinion, or case-control
Genova NJ. Evidence-based medicine--in real time. Comparing methods of cervical Ca screening. JAAPA. 2000;13:55–60, 63. | Editorial, letter, non- systematic review, opinion, or case-control
Gilbert G. HPV screening more accurate than pap (CCCaST). SO: Journal of the National Medical Association. 2008;100:265–266. | Editorial, letter, non- systematic review, opinion, or case-control
Giovannelli L, Capra G, Lama A et al. Atypical squamous cells of undetermined significance-favour reactive compared to atypical squamous cells of undetermined significance-favour dysplasia: association with cervical intraepithelial lesions and human papillomavirus infection. J Clin Virol. 2005;33:281–286. | No comparison to cytology
Girianelli VR, Thuler LC, Szklo M et al. Comparison of human papillomavirus DNA tests, liquid-based cytology and conventional cytology for the early detection of cervix uteri cancer. Eur J Cancer Prev. 2006;15:504–510. | Poor reporting
Goff BA, Muntz HG, Bell DA, Wertheim I, Rice LW. Human papillomavirus typing in patients with Papanicolaou smears showing squamous atypia. Gynecol Oncol. 1993;1993:384–388. | Focus on excluded screening methods
Gogola J, Van Dinh T, Lucci JA, III, Smith E, Hannigan EV. Human papillomavirus testing for triage in a referral population. Journal of Lower Genital Tract Disease. 2001;5:29–32. | Included women with repeated abnormal smears or abnormal smear other than ASC
Gonzalez-Bosquet E, Almagro MM, Mora I, Sunol M, Callejo J, Lailla JM. Prevalence of human papilloma virus infection of the uterine cervix in women with abnormal cervical cytology. Eur J Gynaecol Oncol. 2006;27:135–138. | Poor reporting
Gravitt PE, Schiffman M, Solomon D, Wheeler CM, Castle PE. A comparison of linear array and hybrid capture 2 for detection of carcinogenic human papillomavirus and cervical precancer in ASCUS-LSIL triage study. Cancer Epidemiology, Biomarkers & Prevention. 2008;17:1248–1254. | No comparison to cytology
Guido R, Schiffman M, Solomon D, Burke L. Postcolposcopy management strategies for women referred with low-grade squamous intraepithelial lesions or human papillomavirus DNA-positive atypical squamous cells of undetermined significance: a two-year prospective study. Am J Obstet Gynecol. 2003;188:1401–1405. | Focus on methods to improve followup of abnormal screening findings
Guido RS, Jeronimo J, Schiffman M, Solomon D. The distribution of neoplasia arising on the cervix: results from the ALTS trial. Am J Obstet Gynecol. 2005;193:1331–1337. | Does not focus on screening or harms of screening
Guillaud M, Benedet JL, Cantor SB, Staerkel G, Follen M, MacAulay C. DNA ploidy compared with human papilloma virus testing (Hybrid Capture II) and conventional cervical cytology as a primary screening test for cervical high-grade lesions and cancer in 1555 patients with biopsy confirmation. Cancer. 2006;107:309–318. | Conducted solely in referred population or does not report routine and referred population outcomes separately
Guyot A, Karim S, Kyi MS, Fox J. Evaluation of adjunctive HPV testing by Hybrid Capture II in women with minor cytological abnormalities for the diagnosis of CIN2/3 and cost comparison with colposcopy. BMC Infectious Diseases. 2003;3:23. | No comparison to cytology
Halfon P, Benmoura D, Khiri H et al. Comparison of the clinical performance of carcinogenic HPV typing of the Linear Array and Papillocheck HPV-screening assay. J Clin Virol. 2010;47:38–42. | No comparison to cytology
Halfon P, Trepo E, Antoniotti G et al. Prospective evaluation of the Hybrid Capture 2 and AMPLICOR human papillomavirus (HPV) tests for detection of 13 high-risk HPV genotypes in atypical squamous cells of uncertain significance. J Clin Microbiol. 2007;45:313–316. | Does not systematically apply reference standard of colposcopy and/or histology
Hall S, Lorincz A, Shah F et al. Human papillomavirus DNA detection in cervical specimens by hybrid capture: correlation with cytologic and histologic diagnoses of squamous intraepithelial lesions of the cervix. Gynecol Oncol. 1996;62:353–359. | Focus on excluded screening methods
Hartmann, KE, Hall, SA, Nanda, K, Boggess, JF, and Zolnoun, D. Screening for Cervical Cancer. ii–74. 2002. Agency for Healthcare Research and Quality. | Provides no data not otherwise covered in other articles for this study
HAYES and Inc. Hybrid capture HPV testing for cervical cancer. 2004. | Editorial, letter, non- systematic review, opinion, or case-control
HAYES. HPV Testing Versus Standard Cytology for Primary Screening of Cervical Cancer. 2007. | Editorial, letter, non- systematic review, opinion, or case-control
Herbert A, Best JM, Chana P et al. Human papillomavirus testing with conventional Pap smear screening in three inner London community clinics. Journal of Family Planning & Reproductive Health Care. 2007;33:171–176. | Colposcopy and/or histology only in positives
Herrero R, Hildesheim A, Bratti C et al. Population-based study of human papillomavirus infection and cervical neoplasia in rural Costa Rica. J Natl Cancer Inst. 2000;92:464–474. | No relevant outcomes
Herrero R, Schiffman MH, Bratti C et al. Design and methods of a population-based natural history study of cervical neoplasia in a rural province of Costa Rica: the Guanacaste Project. Rev Panam Salud Publica. 1997;1:362–375. | Reference standard not independent of screening test
Herrington CS, Evans MF, Hallam NF, Charnock FM, Gray W, McGee JD. Human papillomavirus status in the prediction of high-grade cervical intraepithelial neoplasia in patients with persistent low-grade cervical cytological abnormalities. Br J Cancer. 1995;1995:206–209. | Poor reporting
Hildesheim A, Herrero R, Castle PE et al. HPV co-factors related to the development of cervical cancer: results from a population-based study in Costa Rica. Br J Cancer. 2001;84:1219–1226. | No relevant outcomes
Hillemanns P, Kimmig R, Huttemann U, Dannecker C, Thaler CJ. Screening for cervical neoplasia by self-assessment for human papillomavirus DNA. Lancet. 1999;1999:1970. | Focus on excluded screening methods
Ho L, Terry G, Londesborough P, Cuzick J, Lorenzato F, Singer A. Human papillomavirus DNA detection in the management of women with twice mildly abnormal cytological smears. J Med Virol. 2003;69:118–121. | No relevant outcomes
Hovland S, Arbyn M, Lie AK et al. A comprehensive evaluation of the accuracy of cervical pre-cancer detection methods in a high-risk area in East Congo. Br J Cancer. 2010;102:957–965. | Conducted solely in referred population or does not report routine and referred population outcomes separately
Howard M, Sellors JW, Lytwyn A, Roth P, Mahony JB. Combining human papillomavirus testing or cervicography with cytology to detect cervical neoplasia. Archives of Pathology & Laboratory Medicine. 2004;128:1257–1262. | Poor reporting
HPV DNA Testing in Cervical Cancer Screening: Results From Women in a High-Risk Province of Costa Rica. Obstetrical & Gynecological Survey May 2000;55(5):284–286. 2000;284–286. | Editorial, letter, non- systematic review, opinion, or case-control
Huang S, Erickson B, Tang N et al. Clinical performance of Abbott RealTime High Risk HPV test for detection of high-grade cervical intraepithelial neoplasia in women with abnormal cytology. J Clin Virol. 2009;45:Suppl-23. | Included women with repeated abnormal smears or abnormal smear other than ASC
Infantolino C, Fabris P, Infantolino D et al. Usefulness of human papilloma virus testing in the screening of cervical cancer precursor lesions: a retrospective study in 314 cases. European Journal of Obstetrics, Gynecology, & Reproductive Biology. 2000;93:71–75. | Editorial, letter, non- systematic review, opinion, or case-control
Inoue M, Okamura M, Hashimoto S, Tango M, Ukita T. Adoption of HPV testing as an adjunct to conventional cytology in cervical cancer screening in Japan. Int J Gynaecol Obstet. 2010. | Colposcopy and/or histology only in positives
Inoue M, Sakaguchi J, Sasagawa T, Tango M. The evaluation of human papillomavirus DNA testing in primary screening for cervical lesions in a large Japanese population. International Journal of Gynecological Cancer. 2006;16:1007–1013. | Colposcopy and/or histology only in positives
Institute for Clinical Systems Improvement. HPV DNA Testing for the Screening and Monitoring of Cervical Cancer. 2007. | Editorial, letter, non- systematic review, opinion, or case-control
Jastania R, Geddie WR, Chapman W, Boerner S. Characteristics of apparently false- negative digene hybrid capture 2 high-risk HPV DNA testing. Am J Clin Pathol. 2006;125:223–228. | No relevant outcomes
Juric D, Mahovlic V, Rajhvajn S et al. Liquid-based cytology--new possibilities in the diagnosis of cervical lesions. Coll Antropol. 2010;34:19–24. | Does not systematically apply reference standard of colposcopy and/or histology
Kahn JA, Hillard PJ. Cervical cytology screening and management of abnormal cytology in adolescent girls. J Pediatr Adolesc Gynecol. 2003;16:167–171. | Editorial, letter, non- systematic review, opinion, or case-control
Kahn JA, Slap GB, Bernstein DI et al. Personal meaning of human papillomavirus and Pap test results in adolescent and young adult women. Health Psychology. 2007;26:192–200. | No relevant outcomes
Kaufman RH, Adam E, Icenogle J et al. Relevance of human papillomavirus screening in management of cervical intraepithelial neoplasia. Am J Obstet Gynecol. 1997;176:87–92. | Included women with repeated abnormal smears or abnormal smear other than ASC
Kaufman RH, Adam E, Icenogle J, Reeves WC. Human papillomavirus testing as triage for atypical squamous cells of undetermined significance and low-grade squamous intraepithelial lesions: sensitivity, specificity, and cost-effectiveness. Am J Obstet Gynecol. 1997;177:930–936. | Included women with repeated abnormal smears or abnormal smear other than ASC
Khanna N, Brooks SE, Chen TT, Simsir A, Gordon NJ, Taylor G. Human papillomavirus absence predicts normal cervical histopathologic findings with abnormal papanicolaou smears: a study of a university-based inner city population. J Hum Virol. 2001;4:283–287. | No comparison to cytology
Kiatpongsan S, Niruthisard S, Mutirangura A et al. Role of human papillomavirus DNA testing in management of women with atypical squamous cells of undetermined significance. International Journal of Gynecological Cancer. 2006;16:262–265. | No comparison to cytology
Kitchener HC, Almonte M, Wheeler P et al. HPV testing in routine cervical screening: cross sectional data from the ARTISTIC trial. Br J Cancer. 2006;95:56–61. | Provides no data not otherwise covered in other articles for this study
Koliopoulos G, Arbyn M, Martin-Hirsch P, Kyrgiou M, Prendiville W, Paraskevaidis E. Diagnostic accuracy of human papillomavirus testing in primary cervical screening: A systematic review and meta-analysis of non-randomized studies. Gynecol Oncol. 2007;104:232–246. | SER includes studies that do not meet design criteria
Koliopoulos G, Martin-Hirsch P, Paraskevaidis E, Arbyn M. HPV testing versus cervical cytology for screening for cancer of the uterine cervix. Cochrane Database of Systematic Reviews. 2006. | Editorial, letter, non- systematic review, opinion, or case-control
Kotaniemi TL, Malila N, Nieminen P et al. Test positivity cutoff level of a high risk human papillomavirus test could be increased in routine cervical cancer screening. SO: International journal of cancer Journal international du cancer. 2008;123:2902–2906. | Provides no data not otherwise covered in other articles for this study
Koutsky LA, Harper DM, Breen N et al. Human papillomavirus testing for triage of women with cytologic evidence of low-grade squamous intraepithelial lesions: Baseline data from a randomized trial. J Natl Cancer Inst. 2000;92:397–402. | No relevant outcomes
Kuhn L, Denny L, Pollack A, Lorincz A, Richart RM, Wright TC. Human papillomavirus DNA testing for cervical cancer screening in low-resource settings. J Natl Cancer Inst. 2000;92:818–825. | Colposcopy and/or histology only in positives
Kulasingam SL, Rajan R, St PY, Atwood CV, Myers ER, Franco EL. Human papillomavirus testing with Pap triage for cervical cancer prevention in Canada: a cost- effectiveness analysis. BMC Medicine. 2009;7:69. | Editorial, letter, non- systematic review, opinion, or case-control
Kumar K, Iyer VK, Bhatla N, Kriplani A, Verma K. Comparative evaluation of smear cytology & hybrid capture II for the diagnosis of cervical cancer. Indian J Med Res. 2007;126:39–44. | Population not comparable to primary care
Lazcano-Ponce E, Lorincz AT, Salmeron J et al. A pilot study of HPV DNA and cytology testing in 50,159 women in the routine Mexican Social Security Program. Cancer Causes Control. 2010. | Colposcopy and/or histology only in positives
Lee GY, Kim SM, Rim SY, Choi HS, Park CS, Nam JH. Human papillomavirus (HPV) genotyping by HPV DNA chip in cervical cancer and precancerous lesions. International Journal of Gynecological Cancer. 2005;15:81–87. | Included women with repeated abnormal smears or abnormal smear other than ASC
Lee JK, Kim MK, Song SH et al. Comparison of human papillomavirus detection and typing by hybrid capture 2, linear array, DNA chip, and cycle sequencing in cervical swab samples. International Journal of Gynecological Cancer. 2009;19:266–272. | Poor reporting
Lee KJ, Lee JK, Saw HS. Can human papillomavirus DNA testing substitute for cytology in the detection of high-grade cervical lesions? Archives of Pathology & Laboratory Medicine. 2004;128:298–302. | Included women with repeated abnormal smears or abnormal smear other than ASC
Lee NW, Kim D, Park JT, Kim A. Is the human papillomavirus test in combination with the Papanicolaou test useful for management of patients with diagnoses of atypical squamous cells of undetermined significance/low-grade squamous intraepithelial lesions? Archives of Pathology & Laboratory Medicine. 2001;125:1453–1457. | Colposcopy and/or histology only in positives
Lepej SZ, Grgic I, Poljak M et al. Detection of human papillomavirus genotypes 16/18/45 by hybrid capture hybridisation genotyping probe in clinical specimens: the first report. J Clin Virol. 2007;40:171–172. | Focus on excluded screening methods
Lerma E, Quintana MJ, Quilez M et al. Effectiveness of liquid-based cytology and papanicolaou tests in a low risk population. Acta Cytol. 2007;51:399–406. | Colposcopy and/or histology only in positives
Li C, Wu M, Wang J et al. A population-based study on the risks of cervical lesion and human papillomavirus infection among Women in Beijing, People’s Republic of China. Cancer Epidemiol Biomarkers Prev. 2010. | Does not systematically apply reference standard of colposcopy and/or histology
Li N, Shi JF, Franceschi S et al. Different cervical cancer screening approaches in a Chinese multicentre study. Br J Cancer. 2009;100:532–537. | Poor reporting, no indeterminate results provided
Li Y, Ye F, Lu WG, Zeng WJ, Wei LH, Xie X. Detection of human telomerase RNA gene in cervical cancer and precancerous lesions: comparison with cytological and human papillomavirus DNA test findings. International Journal of Gynecological Cancer. 2010;20:631–637. | Poor reporting
Lin CT, Tseng CJ, Lai CH, Hsueh S, Huang HJ, Law KS. High-risk HPV DNA detection by Hybrid Capture II. An adjunctive test for mildly abnormal cytologic smears in women > or = 50 years of age. J Reprod Med. 2000;45:345–350. | No comparison to cytology
Lin HP, Huang YY, Wu HY, Kao JT. Method for testing for human papillomavirus infection in patients with cervical intraepithelial disease. J Clin Microbiol. 2004;42:366–368. | Poor reporting
Lindh M, Gorander S, Andersson E, Horal P, Mattsby-Balzer I, Ryd W. Real-time Taqman PCR targeting 14 human papilloma virus types. J Clin Virol. 2007;40:321–324. | Focus on excluded screening methods
Little J. Human papillomavirus testing. Effectiveness of testing for high risk HPV for triage of low grade abnormal smears is being assessed in TOMBOLA trial. BMJ. 2001;323:109. | Editorial, letter, non- systematic review, opinion, or case-control
Longatto-Filho A, Erzen M, Branca M et al. Human papillomavirus testing as an optional screening tool in low-resource settings of Latin America: experience from the Latin American Screening study. International Journal of Gynecological Cancer. 2006;16:955–962. | No comparison to cytology
Lonky NM, Felix JC, Naidu YM, Wolde-Tsadik G. Triage of atypical squamous cells of undetermined significance with hybrid capture II: colposcopy and histologic human papillomavirus correlation. Obstetrics & Gynecology. 2003;101:481–489. | No comparison to cytology
Lonky NM, Mahdavi A, Wolde-Tsadik G, Bajamundi K, Felix JC. Evaluation of the clinical performance of high-risk human papillomavirus testing for primary screening: a retrospective review of the Southern California Permanente Medical Group experience. Journal of Lower Genital Tract Disease. 2010;14:200–205. | Colposcopy and/or histology only in positives
Lorenzato F, Ho L, Terry G et al. The use of human papillomavirus typing in detection of cervical neoplasia in Recife (Brazil). Int J Gynecol Cancer. 2000;10:143–150. | Focus on excluded screening methods
Lorincz AT, Richart RM. Human papillomavirus DNA testing as an adjunct to cytology in cervical screening programs. Archives of Pathology & Laboratory Medicine. 2003;127:959–968. | Editorial, letter, non- systematic review, opinion, or case-control
Luyten A, Scherbring S, Reinecke-Luthge A et al. Risk-adapted primary HPV cervical cancer screening project in Wolfsburg, Germany--experience over 3 years. J Clin Virol. 2009;46:Suppl-10. | Colposcopy and/or histology only in positives
Lytwyn A, Sellors JW, Mahony JB et al. Adjunctive human papillomavirus testing in the 2-year follow-up of women with low-grade cervical cytologic abnormalities: a randomized trial and economic evaluation. Archives of Pathology & Laboratory Medicine. 2003;127:1169–1175. | Focus on excluded screening methods
Lytwyn A, Sellors JW, Mahony JB et al. Comparison of human papillomavirus DNA testing and repeat Papanicolaou test in women with low-grade cervical cytologic abnormalities: a randomized trial. HPV Effectiveness in Lowgrade Paps (HELP) Study No. 1 Group. CMAJ. 2000;163:701–707. | Insufficient sample size, poor reporting, inappropriate exclusions
MacDonald N, Hebert PC. Human papillomavirus vaccine: waiting for a miracle. CMAJ. 2007;2007:433, 435. | Editorial, letter, non- systematic review, opinion, or case-control
Markowitz LE, Dunne EF, Saraiya M, Lawson HW, Chesson H, Unger ER. Quadrivalent Human Papillomavirus Vaccine: Recommendations of the Advisory Committee on Immunization Practices (ACIP). MMWR Recomm Rep. 2007;56:1–24. | Does not focus on screening or harms of screening
Masumoto N, Fujii T, Ishikawa M et al. Papanicolaou tests and molecular analyses using new fluid-based specimen collection technology in 3000 Japanese women. Br J Cancer. 2003;88:1883–1888. | Poor reporting
Medical Services Advisory Committee. Human papillomavirus testing in women with cytological prediction of low-grade abnormality. 2002. | Precedes search period
Medical Services Advisory Committee. Human papillomavirus testing for cervical screening. 2003. | Precedes search period
Monsonego J, Pintos J, Semaille C et al. Human papillomavirus testing improves the accuracy of colposcopy in detection of cervical intraepithelial neoplasia. International Journal of Gynecological Cancer. 2006;16:591–598. | Conducted solely in referred population or does not report routine and referred population outcomes separately
Morin C, Bairati I, Bouchard C et al. Managing atypical squamous cells of undetermined significance in Papanicolaou smears. J Reprod Med. 2001;46:799–805. | Poor reporting
Morin, C. Comparison of the hybrid capture test and polymerase chain reaction in identifying women who have an atypical squamous cell of undetermined significance Papanicolaou smear and need colposcopy. J Lower Genit Tract Disease 3, 231–238. 1999. | Focus on excluded screening methods
Moscicki AB, Cox JT. Practice improvement in cervical screening and management (PICSM): symposium on management of cervical abnormalities in adolescents and young women. Journal of Lower Genital Tract Disease. 2010;14:73–80. | Editorial, letter, non- systematic review, opinion, or case-control
Moscicki AB, Hills N, Shiboski S et al. Risks for incident human papillomavirus infection and low-grade squamous intraepithelial lesion development in young females. JAMA. 2001;285:2995–3002. | No relevant outcomes
Moscicki AB. Cervical cytology testing in teens. Curr Opin Obstet Gynecol. 2005;17:471–475. | Editorial, letter, non- systematic review, opinion, or case-control
Moss S, Gray A, Legood R et al. Effect of testing for human papillomavirus as a triage during screening for cervical cancer: observational before and after study. BMJ. 2006;332:83–85. | No relevant outcomes
Mould TA, Singer A, Gallivan S. Quantitative detection of oncogenic HPV DNA using hybrid capture to triage borderline and mildly dyskaryotic Papanicolaou smears. Eur J Gynaecol Oncol. 2000;21:245–248. | Focus on excluded screening methods
Munoz N, Bosch FX, Castellsague X et al. Against which human papillomavirus types shall we vaccinate and screen? The international perspective. Int J Cancer. 2004;111:278–285. | Does not focus on screening or harms of screening
Nene BM, Sankaranaryanan R, Dinshaw KD et al. Comparative efficacy of visual inspection with acetic acid, HPV testing and conventional cytology in cervical cancer screening: a randomised intervention trial in Maharashtra State, India. Int J Cancer. 2002;98. | Editorial, letter, non- systematic review, opinion, or case-control
Nieminen P, Vuorma S, Viikki M, Hakama M, Anttila A. Comparison of HPV test versus conventional and automation-assisted Pap screening as potential screening tools for preventing cervical cancer. BJOG: An International Journal of Obstetrics & Gynaecology. 2004;111:842–848. | Colposcopy and/or histology only in positives
Nobbenhuis MA, Walboomers JM, Helmerhorst TJ et al. Relation of human papillomavirus status to cervical lesions and consequences for cervical-cancer screening: a prospective study. Lancet. 1999;354:20–25. | No relevant outcomes
Nomelini RS, Barcelos AC, Michelin MA, Adad SJ, Murta EF. Utilization of human papillomavirus testing for cervical cancer prevention in a university hospital. Cad Saude Publica. 2007;23:1309–1318. | No comparison to cytology
Noorani, H. Z., Brown, A., Skidmore, B., and Stuart, G. C. E. Liquid-based cytology and human papillomavirus testing in cervical cancer screening. 2003. | SER includes studies that do not meet design criteria
Nuovo GJ, Bartholomew D, Jung WW et al. Correlation of Pap smear, cervical biopsy, and clinical follow-up with an HPV typing microarray system. Diagn Mol Pathol. 2008;17:107–111. | Does not systematically apply reference standard of colposcopy and/or histology
Nyirjesy I, Billingsley FS, Forman MR. Evaluation of atypical and low-grade cervical cytology in private practice. Obstet Gynecol. 1998;92:601–607. | Focus on excluded screening methods
Ogilvie G, Krajden M, Maginley J et al. Feasibility of self-collection of specimens for human papillomavirus testing in hard-to-reach women. CMAJ. 2007;2007:480–483. | Focus on excluded screening methods
Ogilvie GS, van Niekerk DJ, Krajden M et al. A randomized controlled trial of Human Papillomavirus (HPV) testing for cervical cancer screening: trial design and preliminary results (HPV FOCAL Trial). BMC Cancer. 2010;10:111. | No relevant outcomes
Oh YL, Shin KJ, Han J, Kim DS. Significance of high-risk human papillomavirus detection by polymerase chain reaction in primary cervical cancer screening. Cytopathology. 2001;12:75–83. | Does not systematically apply reference standard of colposcopy and/or histology
Ozsaran AA, Dikmen Y, Akercan F et al. The triage of squamous cell abnormalities of cervical cytology by human papilloma virus screening. Eur J Gynaecol Oncol. 2003;24:535–538. | Focus on excluded screening methods
Pajtler M, Milicic-Juhas V, Milojkovic M, Topolovec Z, Curzik D, Mihaljevic I. Assessment of HPV DNA test value in management women with cytological findings of ASC-US, CIN1 and CIN2. Coll Antropol. 2010;34:81–86. | Does not systematically apply reference standard of colposcopy and/or histology
Pannier-Stockman C, Segard C, Bennamar S et al. Prevalence of HPV genotypes determined by PCR and DNA sequencing in cervical specimens from French women with or without abnormalities. J Clin Virol. 2008;42:353–360. | Does not systematically apply reference standard of colposcopy and/or histology
Paraskevaidis E, Malamou-Mitsi V, Koliopoulos G et al. Expanded cytological referral criteria for colposcopy in cervical screening: comparison with human papillomavirus testing. Gynecol Oncol. 2001;82:355–359. | Colposcopy and/or histology only in positives
Partridge EE, bu-Rustum N, Campos S et al. Cervical cancer screening. Journal of the National Comprehensive Cancer Network. 2008;6:58–82. | Editorial, letter, non- systematic review, opinion, or case-control
Peto J, Gilham C, Deacon J et al. Cervical HPV infection and neoplasia in a large population-based prospective study: the Manchester cohort. Br J Cancer. 2004;91:942–953. | No relevant outcomes
Petry KU, Bohmer G, Iftner T, Flemming P, Stoll M, Schmidt RE. Human papillomavirus testing in primary screening for cervical cancer of human immunodeficiency virus-infected women, 1990–1998. Gynecol Oncol. 1999;1999:427–431. | Population not comparable to primary care
Petry, K. U., Menton, M., Bohmer, G., and Iftner, T. Human papillomavirus DNA- testing for primary cervical cancer screening in germany. Anticancer Research 22[1B], 482. 2002. | Editorial, letter, non- systematic review, opinion, or case-control
Plummer M, Schiffman M, Castle PE, Maucort-Boulch D, Wheeler CM, ALTS Group. A 2-year prospective study of human papillomavirus persistence among women with a cytological diagnosis of atypical squamous cells of undetermined significance or low- grade squamous intraepithelial lesion. J Infect Dis. 2007;195:1582–1589. | No relevant outcomes
Powell N. Single HPV test not useful for predicting CIN2 or worse or for guiding choice of further investigations for women aged 20–59 presenting to NHS Cervical Screening Programme with borderline abnormalities or mild dyskaryosis. Evid Based Med. 2010. | Editorial, letter, non- systematic review, opinion, or case-control
Pretorius RG, Kim RJ, Belinson JL, Elson P, Qiao YL. Inflation of sensitivity of cervical cancer screening tests secondary to correlated error in colposcopy. Journal of Lower Genital Tract Disease. 2006;10:5–9. | Provides no data not otherwise covered in other articles for this study
Pretorius RG, Peterson P, Novak S, Azizi F, Sadeghi M, Lorincz AT. Comparison of two signal-amplification DNA tests for high-risk HPV as an aid to colposcopy. J Reprod Med. 2002;47:290–296. | No comparison to cytology
Prinsen CF, Fles R, Wijnen-Dubbers CW et al. Baseline human papillomavirus status of women with abnormal smears in cervical screening: a 5-year follow-up study in The Netherlands. BJOG: An International Journal of Obstetrics & Gynaecology. 2007;114:951–957. | Conducted solely in referred population or does not report routine and referred population outcomes separately
Proca DM, Williams JD, Rofagha S, Tranovich VL, Keyhani-Rofagha S. Improved rate of high-grade cervical intraepithelial neoplasia detection in human papillomavirus DNA hybrid capture testing. Analytical & Quantitative Cytology & Histology. 2007;29:264–270. | Focus on excluded screening methods
Ratnam S, Franco EL, Ferenczy A. Human papillomavirus testing for primary screening of cervical cancer precursors. Cancer Epidemiol Biomarkers Prev. 2000;9:945–951. | Focus on excluded screening methods
Rebello G, Hallam N, Smart G, Farquharson D, McCafferty J. Human papillomavirus testing and the management of women with mildly abnormal cervical smears: an observational study. BMJ. 2001;322:893–894. | Poor reporting
Reuschenbach M, Clad A, von Knebel DC et al. Performance of p16(INK4a)-cytology, HPV mRNA, and HPV DNA testing to identify high grade cervical dysplasia in women with abnormal screening results. Gynecol Oncol. 2010. | No comparison to cytology
Rijkaart DC, Berkhof J, van Kemenade FJ et al. Comparison of HPV and cytology triage algorithms for women with borderline or mild dyskaryosis in population-based cervical screening (VUSA-screen study). Int J Cancer. 2010;126:2175–2181. | Colposcopy and/or histology only in positives
Rijkaart DC, Coupe VM, van Kemenade FJ et al. Comparison of Hybrid capture 2 testing at different thresholds with cytology as primary cervical screening test. Br J Cancer. 2010. | Colposcopy and/or histology only in positives
Rodriguez AC, Schiffman M, Herrero R et al. Longitudinal study of human papillomavirus persistence and cervical intraepithelial neoplasia grade 2/3: critical role of duration of infection. J Natl Cancer Inst. 2010;102:315–324. | No comparison to cytology
Ronnett BM, Manos MM, Ransley JE et al. Atypical glandular cells of undetermined significance (AGUS): cytopathologic features, histopathologic results, and human papillomavirus DNA detection. Hum Pathol. 1999;30:816–825. | Included women with repeated abnormal smears or abnormal smear other than ASC
Rousseau MC, Villa LL, Costa MC, Abrahamowicz M, Rohan TE, Franco E. Occurrence of cervical infection with multiple human papillomavirus types is associated with age and cytologic abnormalities. Sex Transm Dis. 2003;30:581–587. | No relevant outcomes
Safaeian M, Solomon D, Wacholder S, Schiffman M, Castle P. Risk of precancer and follow-up management strategies for women with human papillomavirus-negative atypical squamous cells of undetermined significance. Obstetrics & Gynecology. 2007;109:1325–1331. | No relevant outcomes
Salmeron J, Lazcano-Ponce E, Lorincz A et al. Comparison of HPV-based assays with Papanicolaou smears for cervical cancer screening in Morelos State, Mexico. Cancer Causes & Control. 2003;14:505–512. | Colposcopy and/or histology only in positives
Sandri MT, Lentati P, Benini E et al. Comparison of the Digene HC2 assay and the Roche AMPLICOR human papillomavirus (HPV) test for detection of high-risk HPV genotypes in cervical samples. J Clin Microbiol. 2006;44:2141–2146. | Does not systematically apply reference standard of colposcopy and/or histology
Sankaranarayanan R, Nene BM, Dinshaw KA et al. A cluster randomized controlled trial of visual, cytology and human papillomavirus screening for cancer of the cervix in rural India. Int J Cancer. 2005;116:617–623. | Provides no data not otherwise covered in other articles for this study
Sankaranarayanan R, Thara S, Sharma A et al. Accuracy of conventional cytology: results from a multicentre screening study in India. J Med Screen. 2004;2004;11:77–84. | Focus on excluded screening methods
Santos AL, Derchain SF, Martins MR, Sarian LO, Martinez EZ, Syrjanen KJ. Human papillomavirus viral load in predicting high-grade CIN in women with cervical smears showing only atypical squamous cells or low-grade squamous intraepithelial lesion. Sao Paulo Medical Journal = Revista Paulista de Medicina. 2003;121:238–243. | Poor reporting
Sarian LO, Derchain SF, Naud P et al. Evaluation of visual inspection with acetic acid (VIA), Lugol’s iodine (VILI), cervical cytology and HPV testing as cervical screening tools in Latin America. This report refers to partial results from the LAMS (Latin AMerican Screening) study. J Med Screen. 2005;12:142–149. | Poor reporting
Sarode VR, Werner C, Gander R et al. Reflex human papillomavirus DNA testing on residual liquid-based (TPPT) cervical samples: focus on age-stratified clinical performance. Cancer. 2003;99:149–155. | No comparison to cytology
Saslow D, Castle PE, Cox JT et al. American Cancer Society Guideline for human papillomavirus (HPV) vaccine use to prevent cervical cancer and its precursors. CA Cancer J Clin. 2007;57:7–28. | Does not focus on screening or harms of screening
Schiffman M, Herrero R, Hildesheim A et al. HPV DNA testing in cervical cancer screening: results from women in a high-risk province of Costa Rica. JAMA. 2000;283:87–93. | Reference standard not independent of screening test
Schiffman M, Khan MJ, Solomon D et al. A study of the impact of adding HPV types to cervical cancer screening and triage tests. J Natl Cancer Inst. 2005;97:147–150. | Does not focus on screening or harms of screening
Schiffman M, Solomon D. Findings to date from the ASCUS-LSIL Triage Study (ALTS). Arch Pathol Lab Med. 2003;127:946–949. | Editorial, letter, non- systematic review, opinion, or case-control
Schlecht NF, Platt RW, Duarte-Franco E et al. Human papillomavirus infection and time to progression and regression of cervical intraepithelial neoplasia. J Natl Cancer Inst. 2003;95:1336–1343. | No relevant outcomes
Schledermann D, Andersen BT, Bisgaard K et al. Are adjunctive markers useful in routine cervical cancer screening? Application of p16(INK4a) and HPV-PCR on ThinPrep samples with histological follow-up. Diagn Cytopathol. 2008;36:453–459. | Does not systematically apply reference standard of colposcopy and/or histology
Schneede P, Hillemanns P, Ziller F et al. Evaluation of HPV testing by Hybrid Capture II for routine gynecologic screening. Acta Obstet Gynecol Scand. 2001;80:750–752. | No relevant outcomes
Schneider A, Hoyer H, Lotz B et al. Screening for high-grade cervical intra-epithelial neoplasia and cancer by testing for high-risk HPV, routine cytology or colposcopy. Int J Cancer. 2000;89:529–534. | Colposcopy and/or histology only in positives
Selvaggi SM. ASC-US and high-risk HPV testing: performance in daily clinical practice. Diagn Cytopathol. 2006;34:731–733. | Does not systematically apply reference standard of colposcopy and/or histology
Sherman ME, Castle PE, Solomon D. Cervical cytology of atypical squamous cells- cannot exclude high-grade squamous intraepithelial lesion (ASC-H): characteristics and histologic outcomes. Cancer. 2006;108:298–305. | No relevant outcomes
Sherman ME, Lorincz AT, Scott DR et al. Baseline cytology, human papillomavirus testing, and risk for cervical neoplasia: a 10-year cohort analysis. J Natl Cancer Inst. 2003;95:46–52. | No relevant outcomes
Sherman ME, Schiffman MH, Lorincz AT et al. Cervical specimens collected in liquid buffer are suitable for both cytologic screening and ancillary human papillomavirus testing. Cancer. 1997;81:89–97. | Focus on excluded screening methods
Shi JF, Belinson JL, Zhao FH et al. Human papillomavirus testing for cervical cancer screening: results from a 6-year prospective study in rural China. Am J Epidemiol. 2009;170:708–716. | Provides no data not otherwise covered in other articles for this study
Shin EK, Lee SR, Kim MK et al. Immunocytochemical staining of p16(ink4a) protein as an adjunct test in equivocal liquid-based cytology. Diagn Cytopathol. 2008;36:311–316. | No comparison to cytology
Shlay JC, Dunn T, Byers T, Baron AE, Douglas JM, Jr. Prediction of cervical intraepithelial neoplasia grade 2–3 using risk assessment and human papillomavirus testing in women with atypia on papanicolaou smears. Obstetrics & Gynecology. 2000;96:410–416. | No comparison to cytology
Siddiqi A, Spataro M, McIntire H et al. Hybrid capture 2 human papillomavirus DNA testing for women with atypical squamous cells of undetermined significance Papanicolaou results in SurePath and ThinPrep specimens. Cancer Cytopathology. 2009;117:318–325. | Does not systematically apply reference standard of colposcopy and/or histology
Sideri M, Spinaci L, Schettino F et al. Risk factors for high-grade cervical intraepithelial neoplasia in patients with mild cytological dyskaryosis: human papillomavirus testing versus multivariate tree analysis of demographic data. Cancer Epidemiol Biomarkers Prev. 1998;7:237–241. | Focus on excluded screening methods
Sigurdsson K, Arnadottir T, Snorradottir M, Benediktsdottir K, Saemundsson H. Human papillomavirus (HPV) in an Icelandic population: the role of HPV DNA testing based on hybrid capture and PCR assays among women with screen-detected abnormal Pap smears. Int J Cancer. 1997;1997:446–452. | Editorial, letter, non- systematic review, opinion, or case-control
Silverloo I, Andrae B, Wilander E. Value of high-risk HPV-DNA testing in the triage of ASCUS. Acta Obstet Gynecol Scand. 2009;88:1006–1010. | Colposcopy and/or histology only in positives
Slawson DC, Bennett JH, Simon LJ, Herman JM. Should all women with cervical atypia be referred for colposcopy: a HARNET study. Harrisburgh Area Research Network. J Fam Pract. 1994;1994:387–392. | Focus on excluded screening methods
Snijders PJ, Hogewoning CJ, Hesselink AT et al. Determination of viral load thresholds in cervical scrapings to rule out CIN 3 in HPV 16, 18, 31 and 33-positive women with normal cytology. Int J Cancer. 2006;119:1102–1107. | No relevant outcomes
Sodhani P, Gupta S, Sharma JK et al. Test characteristics of various screening modalities for cervical cancer: a feasibility study to develop an alternative strategy for resource-limited settings. Cytopathology. 2006;17:348–352. | Poor reporting
Srodon M, Parry DH, Ronnett BM. Atypical squamous cells, cannot exclude high- grade squamous intraepithelial lesion: diagnostic performance, human papillomavirus testing, and follow-up results. Cancer. 2006;108:32–38. | Does not systematically apply reference standard of colposcopy and/or histology
Stoler MH, Castle PE, Solomon D, Schiffman M, American Society for Colposcopy and Cervical Pathology. The expanded use of HPV testing in gynecologic practice per ASCCP-guided management requires the use of well-validated assays. Am J Clin Pathol. 2007;127:335–337. | Editorial, letter, non- systematic review, opinion, or case-control
Stuart G, Taylor G, Bancej CM et al. Report of the 2003 pan-Canadian forum on cervical cancer prevention and control. J Obstet Gynaecol Can. 2004;26:1004–1028. | Editorial, letter, non- systematic review, opinion, or case-control
Sun XW, Ferenczy A, Johnson D et al. Evaluation of the Hybrid Capture human papillomavirus deoxyribonucleic acid detection test. Am J Obstet Gynecol. 1995;1995:1432–1437. | Focus on excluded screening methods
Suwannarurk K, Tapanadechopol P, Pattaraarchachai J, Bhamarapravati S. Hospital- based prevalence and sensitivity of high-risk human papillomavirus in Thai urban population. Cancer Epidemiology. 2009;33:56–60. | Colposcopy and/or histology only in positives
Syrjanen K, Derchain S, Roteli-Martins C et al. Value of conventional pap smear, liquid-based cytology, visual inspection and human papillomavirus testing as optional screening tools among Latin American women <35 and > or =35 years of age: experience from the Latin American Screening Study. Acta Cytol. 2008;52:641–653. | Poor reporting
Syrjanen K, Naud P, Derchain S et al. Comparing PAP smear cytology, aided visual inspection, screening colposcopy, cervicography and HPV testing as optional screening tools in Latin America. Study design and baseline data of the LAMS study. Anticancer Res. 2005;25:3469–3480. | Poor reporting
Syrjanen S, Shabalova IP, Petrovichev N et al. Human Papillomavirus Testing and Conventional Pap Smear Cytology as Optional Screening Tools of Women at Different Risks for Cervical Cancer in the Countries of the Former Soviet Union. J Low Genit Tract Dis. 2002;6:97–110. | Colposcopy and/or histology only in positives
Tarkkanen J, Auvinen E, Nieminen P et al. HPV DNA testing as an adjunct in the management of patients with low grade cytological lesions in Finland. Acta Obstet Gynecol Scand. 2007;86:367–372. | Included women with repeated abnormal smears or abnormal smear other than ASC
Terry G, Ho L, Londesborough P, Cuzick J, Mielzynska-Lohnas I, Lorincz A. Detection of high-risk HPV types by the hybrid capture 2 test. J Med Virol. 2001;65:155–162. | No relevant outcomes
Tiews S, Steinberg W, Schneider W, Hanrath C. Determination of the diagnostic accuracy of testing for high-risk (HR) human papillomavirus (HPV) types 16, 18 and 45 in precancerous cervical lesions: preliminary data. J Clin Virol. 2009;46:Suppl-5. | Does not systematically apply reference standard of colposcopy and/or histology
UK NHS National Coordinating Centre for Health Technology Assessment. A randomised trial of human papillomavirus testing in primary cervical screening - primary research project (ongoing). UK NHS National Coordinating Centre for Health Technology Assessment. 2002. | Editorial, letter, non- systematic review, opinion, or case-control
University of Zimbabwe/JHPIEGO Cervical Cancer Project. Visual inspection with acetic acid for cervical-cancer screening: test qualities in a primary-care setting. University of Zimbabwe/JHPIEGO Cervical Cancer Project. Lancet. 1999;1999:869–873. | Focus on excluded screening methods
Utagawa ML, Pereira SM, Makabe S et al. Pap test in a high-risk population comparison of conventional and liquid-base cytology. Diagn Cytopathol. 2004;31:169–172. | Focus on excluded screening methods
van den Akker-van Marie ME, van Ballegooijen M, Rozendaal L, Meijer CJ, Habbema JD. Extended duration of the detectable stage by adding HPV test in cervical cancer screening. Br J Cancer. 2003;89:1830–1833. | No relevant outcomes
Vassilakos P. Biopsy-based comparison of liquid-based, thin-layer preparations to conventional Pap smears. The Journal of reproductive medicine. 2000;11–16. | Colposcopy and/or histology only in positives
Voss JS, Kipp BR, Campion MB et al. Assessment of fluorescence in situ hybridization and hybrid capture 2 analyses of cervical cytology specimens diagnosed as low grade squamous intraepithelial lesion for the detection of high grade cervical intraepithelial neoplasia. Analytical & Quantitative Cytology & Histology. 2010;32:121–130. | No comparison to cytology
Vrtacnik-Bokal E, Rakar S, Jancar N, Mozina A, Poljak M. Role of human papillomavirus testing in reducing the number of surgical treatments for precancerous cervical lesions. Eur J Gynaecol Oncol. 2005;26:427–430. | No comparison to cytology
Wahlstrom C, Iftner T, Dillner J, Dillner L, Swedescreen Study Group. Population- based study of screening test performance indices of three human papillomavirus DNA tests. J Med Virol. 2007;79:1169–1175. | Conducted solely in referred population or does not report routine and referred population outcomes separately
Walker JL, Wang SS, Schiffman M, Solomon D. Predicting absolute risk of CIN3 during post-colposcopic follow-up: results from the ASCUS-LSIL Triage Study (ALTS). Am J Obstet Gynecol. 2006;195:341–348. | Focus on methods to improve followup of abnormal screening findings
Wensveen C, Kagie M, Veldhuizen R et al. Detection of cervical intraepithelial neoplasia in women with atypical squamous or glandular cells of undetermined significance cytology: a prospective study. Acta Obstet Gynecol Scand. 2003;82:883–889. | Included women with repeated abnormal smears or abnormal smear other than ASC
Wentzensen N, Gravitt PE, Solomon D, Wheeler CM, Castle PE. A study of Amplicor human papillomavirus DNA detection in the atypical squamous cells of undetermined significance-low-grade squamous intraepithelial lesion triage study. Cancer Epidemiology, Biomarkers & Prevention. 2009;18:1341–1349. | No comparison to cytology
Witt A, Hudelist G, Gregor H, Kucera E, Walchetseder C, Czerwenka K. The detection of HPV DNA improves the recognition of cervical intraepithelial lesions. Archives of Gynecology & Obstetrics. 2003;268:29–34. | Focus on excluded screening methods
Womack SD, Chirenje ZM, Blumenthal PD et al. Evaluation of a human papillomavirus assay in cervical screening in Zimbabwe. BJOG: An International Journal of Obstetrics & Gynaecology. 2000;107:33–38. | Population not comparable to primary care
Womack SD, Chirenje ZM, Gaffikin L et al. HPV-based cervical cancer screening in a population at high risk for HIV infection. Int J Cancer. 2000;85:206–210. | Population not comparable to primary care
Wright JD, Rader JS, Davila R et al. Human papillomavirus triage for young women with atypical squamous cells of undetermined significance. Obstetrics & Gynecology. 2006;107:822–829. | Editorial, letter, non- systematic review, opinion, or case-control
Wright TC, Jr. Cervical cancer screening in the 21st century: is it time to retire the PAP smear? Clin Obstet Gynecol. 2007;50:313–323. | Editorial, letter, non- systematic review, opinion, or case-control
Wright TC, Jr., Denny L, Kuhn L, Pollack A, Lorincz A. HPV DNA testing of self- collected vaginal samples compared with cytologic screening to detect cervical cancer. JAMA. 2000;283:81–86. | Colposcopy and/or histology only in positives
Wright TC, Jr., Lorincz A, Ferris DG et al. Reflex human papillomavirus deoxyribonucleic acid testing in women with abnormal Papanicolaou smears. Am J Obstet Gynecol. 1998;178:962–966. | No comparison to cytology
Wright TC, Sun XW, Koulos J. Comparison of management algorithms for the evaluation of women with low-grade cytologic abnormalities. Obstet Gynecol. 1995;1995:202–210. | Focus on excluded screening methods
Wu HH, Allen SL, Kirkpatrick JL, Elsheikh TM. Reflex high-risk human papilloma virus DNA test is useful in the triage of women with atypical squamous cells cannot exclude high-grade squamous intraepithelial lesion. Diagn Cytopathol. 2006;34:707–710. | Does not systematically apply reference standard of colposcopy and/or histology
Wu S, Meng L, Wang S, Ma D. A comparison of four screening methods for cervical neoplasia. International Journal of Gynaecology & Obstetrics. 2005;91:189–193. | No relevant outcomes
Xiao GQ, Emanuel PO. Cervical parakeratosis/hyperkeratosis as an important cause for false negative results of Pap smear and human papillomavirus test. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2009;49:302–306. | Does not systematically apply reference standard of colposcopy and/or histology
Yarandi F, Shojaei H, Eftekhar Z, Izadi-Mood N. Comparison of three management strategies for patients with atypical squamous cells of undetermined significance, after six months delay: a three-year experience in an Iranian university hospital. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2009;49:207–210. | Poor reporting
Yeoh GP, Tse MP, Chan KW, Lord L. Human papillomavirus DNA and liquid-based cervical cytology cotesting in screening and follow-up patient groups. Acta Cytol. 2006;50:627–631. | Does not systematically apply reference standard of colposcopy and/or histology
Yoon JH, Yoo SC, Kim WY, Chang SJ, Chang KH, Ryu HS. Role of HPV DNA testing for detection of high-grade cervical lesions in women with atypical squamous cells of undetermined significance: a prospective study in a Korean population. Eur J Gynaecol Oncol. 2009;30:271–274. | No comparison to cytology
You K, Liang X, Qin F, Guo Y, Geng L. High-risk human papillomavirus DNA testing and high-grade cervical intraepithelial lesions. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2007;47:141–144. | Focus on excluded screening methods
Zappacosta R, Caraceni D, Ciccocioppo L et al. Is HPV-DNA testing a useful tool in predicting low-grade squamous intraepithelial lesion outcome? A retrospective longitudinal study. Int J Immunopathol Pharmacol. 2010;23:317–326. | No relevant outcomes
Zdenek, H., Lukac, J., Jabor, A., Chvalova, M., Voracek, J., and Brozkova, M. H. Human papillomavirus deoxyribonucleic acid testing in screening of high grade cervical intraepithelial neoplasia. Saudi Medical Journal 20[11], 861–864. 1999. | Poor reporting
Zhao C, Zhao S, Heider A, Austin RM. Significance of high-risk human papillomavirus DNA detection in women 50 years and older with squamous cell papanicolaou test abnormalities. Archives of Pathology & Laboratory Medicine. 2010;134:1130–1135. | Does not systematically apply reference standard of colposcopy and/or histology
Zielinski GD, Snijders PJ, Rozendaal L et al. High-risk HPV testing in women with borderline and mild dyskaryosis: long-term follow-up data and clinical relevance. J Pathol. 2001;195:300–306. | No comparison to cytology
Zielinski SL. Trial quickly changed management of cervical abnormalities. J Natl Cancer Inst. 2005;97:479–480. | Editorial, letter, non- systematic review, opinion, or case-control
Zuna RE, Wang SS, Rosenthal DL et al. Determinants of human papillomavirus- negative, low-grade squamous intraepithelial lesions in the atypical squamous cells of undetermined significance/low-grade squamous intraepithelial lesions triage study (ALTS). Cancer. 2005;105:253–262. | No relevant outcomes

* See Appendix B Table 2 for more detailed exclusion criteria

‡ A large trial that did not meet criteria for inclusion in Key Question 3 was the HPV in Addition to Routine Testing (HART) study conducted in the UK. In this study, 10,358 women who presented for screening at one of 161 family practice clinics in the UK received both an HPV test (HC2) and cytology. Women with LSIL or worse went directly to colposcopy. A 5 percent sample of women negative on both HPV tests and cytology were recalled for colposcopy, and approximately two-thirds attended. The remaining subset of women who had either ASC-US cytology, HPV positive test results, or both were randomized to cytology and HPV testing at 6 and 12 months or to immediate colposcopy. Although the authors report that the specific aims of the study were to compare HPV assays with conventional cytology in the detection rate and positive predictive value of CIN2+, the results of both tests were used to determine management of positive screening results after co-testing. Thus, the randomized portion of the HART study was not designed to determine whether there are benefits of using HPV testing alone or in combination with cytology compared to not testing for HPV but to evaluate relative merits of management strategies after co-testing or HPV with cytology triage. Results from HART might be useful to inform future modeling exercises of HPV testing (with or without cytology co-testing or triage) in women aged 30 to 35 years and older.

The HART study could potentially provide theoretical absolute test results of the sensitivity and specificity of HPV versus cytology, as they offered colposcopy to a random 5 percent subset of those who were HPV negative and cytology negative. However, there was 38 percent nonreceipt of colposcopy from that sample, yielding a nonrandom group of approximately 3 percent of women who were both HPV and cytology negative. Although none of these had CIN2+, it is a small nonrandom sample (n=283) whose results are assumed to apply to all women who tested negative on both tests (n=9173) for the purposes of test performance calculations. Relative test performance (between randomized arms) of HPV versus cytology was not available, as the randomization scheme was performed in order to determine effective management strategies (immediate colposcopy versus surveillance over 6 to 12 months) for women who were HPV positive but cytology negative or borderline at most. Given other limitations to the study, we could not be sure that this study could provide unbiased theoretical absolute test performance estimates for HPV versus cytology. The main limitation is risk of verification bias given that there was differential loss to followup for colposcopy referral among the study arms (13 to 28%). Although the authors tried to calculate test performance within strata to “adjust” for differential noncompliance, this assumes that those not lost to followup are representative of the whole sample, which was shown to not be true using data provided in Table 4 of the Cuzick article. Other issues include uncertainty as to the timeframe within which colposcopy and biopsy was provided, lack of blinding of colposcopists to cytology results (with perhaps the ability to guess HPV results), and exclusion of those with unsatisfactory cytology or incomplete cytology or HPV results (even those with colposcopy).

Appendix D Table 4 Studies Excluded From the Review for KQ4

Key Question 4: What are the harms of liquid-based cytology?
Reference | Reason for exclusion^*^
Atkins KA, Jeronimo J, Stoler MH, ALTS Group. Description of patients with squamous cell carcinoma in the atypical squamous cells of undetermined significance/low-grade squamous intraepithelial lesion triage study. Cancer. 2006;108:212–221. | Reported outcomes do not address a key question
Bacon J, Francoeur D, Goldfarb AF, Breech LL. Abnormal pap smears in adolescents. J Pediatr Adolesc Gynecol. 2003;16:157–166. | Editorials, letters, non- systematic review, opinion or case-control
Genova NJ. Evidence-based medicine--in real time. Comparing methods of cervical Ca screening. JAAPA. 2000;13:55–60, 63. | Editorials, letters, non- systematic review, opinion or case-control
Hartmann, KE, Hall, SA, Nanda, K, Boggess, JF, and Zolnoun, D. Screening for Cervical Cancer. ii–74. 2002. Agency for Healthcare Research and Quality. | Provides data covered in other articles
Kahn JA, Hillard PJ. Cervical cytology screening and management of abnormal cytology in adolescent girls. J Pediatr Adolesc Gynecol. 2003;16:167–171. | Editorials, letters, non- systematic review, opinion or case-control
Moseley RP, Paget S. Liquid-based cytology: is this the way forward for cervical screening? Cytopathology. 2002;13:71–82. | Precedes search period
Noorani, H. Z., Brown, A., Skidmore, B., and Stuart, G. C. E. Liquid-based cytology and human papillomavirus testing in cervical cancer screening. 2003. | SER includes studies that do not meet design criteria
Petticrew MP, Sowden AJ, Lister-Sharp D, Wright K. False-negative results in screening programmes: systematic review of impact and implications. Health Technol Assess. 2000;4:1–120. | Precedes search period
Stuart G, Taylor G, Bancej CM et al. Report of the 2003 pan-Canadian forum on cervical cancer prevention and control. J Obstet Gynaecol Can. 2004;26:1004–1028. | Editorials, letters, non- systematic review, opinion or case-control
Weintraub, J. The coming revolution in cervical cytology: a pathologist’s guide for the clinician. References en Gynecologie Obstetrique 5, 1–6. 1997. | Editorials, letters, non- systematic review, opinion or case-control
Zielinski SL. Trial quickly changed management of cervical abnormalities. J Natl Cancer Inst. 2005;97:479–480. | Editorials, letters, non- systematic review, opinion or case-control

* See Appendix B Table 2 for more detailed exclusion criteria

Appendix D Table 5 Studies Excluded From the Review for KQ5

Key Question 5: What are the harms of using HPV testing as a screening test, either alone or in combination with cytology?
Reference | Reason for exclusion^*^
Atkins KA, Jeronimo J, Stoler MH, ALTS Group. Description of patients with squamous cell carcinoma in the atypical squamous cells of undetermined significance/low-grade squamous intraepithelial lesion triage study. Cancer. 2006;108:212–221. | Reported outcomes do not address a key question
Bacon J, Francoeur D, Goldfarb AF, Breech LL. Abnormal pap smears in adolescents. J Pediatr Adolesc Gynecol. 2003;16:157–166. | Editorials, letters, non- systematic review, opinion or case-control
Bell S, Porter M, Kitchener H, Fraser C, Fisher P, Mann E. Psychological response to cervical screening. Prev Med. 1995;24:610–616. | Does not focus on screening or harms of screening
Campion MJ, Brown JR, McCance DJ et al. Psychosexual trauma of an abnormal cervical smear. Br J Obstet Gynaecol. 1988;95:175–181. | Editorials, letters, non- systematic review, opinion or case-control
Castle PE, Katki HA. Benefits and risks of HPV testing in cervical cancer screening. Lancet Oncology. 2010;11:214–215. | Editorials, letters, non- systematic review, opinion or case-control
Clarke P, Ebel C, Catotti DN, Stewart S. The psychosocial impact of human papillomavirus infection: implications for health care providers. Int J STD AIDS. 1996;7:197–200. | Editorials, letters, non- systematic review, opinion or case-control
Conaglen HM, Hughes R, Conaglen JV, Morgan J. A prospective study of the psychological impact on patients of first diagnosis of human papillomavirus. International Journal of STD & AIDS. 2001;12:651–658. | Population not comparable to primary care
Daley EM, Perrin KM, McDermott RJ et al. The psychosocial burden of HPV: a mixed- method study of knowledge, attitudes and behaviors among HPV+ women. Journal of Health Psychology. 2010;15:279–290. | Editorials, letters, non- systematic review, opinion or case-control
Filiberti A, Tamburini M, Stefanon B et al. Psychological aspects of genital human papillomavirus infection: a preliminary report. J Psychosom Obstet Gynaecol. 1993;14:145–152. | Editorials, letters, non- systematic review, opinion or case-control
Genova NJ. Evidence-based medicine--in real time. Comparing methods of cervical Ca screening. JAAPA. 2000;13:55–60, 63. | Editorials, letters, non- systematic review, opinion or case-control
Graziottin A, Serafini A. HPV infection in women: psychosexual impact of genital warts and intraepithelial lesions. Journal of Sexual Medicine. 2009;6:633–645. | Editorials, letters, non- systematic review, opinion or case-control
Hartmann, KE, Hall, SA, Nanda, K, Boggess, JF, and Zolnoun, D. Screening for Cervical Cancer. Rockville (MD): Agency for Healthcare Research and Quality; 2002. Systematic Evidence Review Number 25. | Data covered in other articles
Howlett RI. Acceptability of HPV-DNA testing HPV vaccines and levels of HPV knowledge. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2008;Vol.68:4420. | Does not focus on screening or harms of screening
Kahn JA, Hillard PJ. Cervical cytology screening and management of abnormal cytology in adolescent girls. J Pediatr Adolesc Gynecol. 2003;16:167–171. | Editorials, letters, non- systematic review, opinion or case-control
Kahn JA, Slap GB, Bernstein DI et al. Psychological, behavioral, and interpersonal impact of human papillomavirus and Pap test results. Journal of Psychiatric Research. 2005;14:650–659. | Editorials, letters, non- systematic review, opinion or case-control
Keller ML, von S, V, Pankratz B, Hermsen J. Self-disclosure of HPV infection to sexual partners. West J Nurs Res. 2000;22:285–296. | Reported outcomes do not address a key question
Kitchener HC, Almonte M, Gilham C et al. ARTISTIC: a randomised trial of human papillomavirus (HPV) testing in primary cervical screening. Health technology assessment (Winchester, England). 2009;13:1–150. | Data covered in other articles
Lehr, S. and Lee, M. The psychosocial and sexual trauma of a genital HPV infection. Nurse Practitioner Forum 1990; 1, 25–30. | Editorials, letters, non- systematic review, opinion or case-control
Linnehan MJ, Groce NE. Psychosocial and educational services for female college students with genital human papillomavirus infection. Fam Plann Perspect. 1999;31:137–141. | Editorials, letters, non- systematic review, opinion or case-control
Maggino T, Casadei D, Panontin E et al. Impact of an HPV diagnosis on the quality of life in young women. Gynecol Oncol. 2007;107:Suppl-9. | Quality issues: small sample size, poor reporting, >6 mos between HPV diagnosis and questionnaire in 50% of sample
Mast TC, Zhu X, muro-Mercon C, Cummings HW, Sings HL, Ferris DG. Development and psychometric properties of the HPV Impact Profile (HIP) to assess the psychosocial burden of HPV. Current Medical Research & Opinion. 2009;25:2609–2619. | Does not focus on screening or harms of screening
McCaffery K, Forrest S, Waller J, Desai M, Szarewski A, Wardle J. Attitudes towards HPV testing: a qualitative study of beliefs among Indian, Pakistani, African-Caribbean and white British women in the UK. Br J Cancer. 2003;88:42–46. | Editorials, letters, non- systematic review, opinion or case-control
McCaffery K, Waller J, Nazroo J, Wardle J. Social and psychological impact of HPV testing in cervical screening: a qualitative study. Sex Transm Infect. 2006;82:169–174. | Editorials, letters, non- systematic review, opinion or case-control
Monk BJ, Wiley DJ. Human papillomavirus infections: truth or consequences. Cancer. 2004;100:225–227. | Editorials, letters, non- systematic review, opinion or case-control
Newton DC, McCabe MP. Sexually transmitted infections: impact on individuals and their relationships. Journal of Health Psychology. 2008;13:864–869. | Does not focus on screening or harms of screening
Noorani, H. Z., Brown, A., Skidmore, B., and Stuart, G. C. E. Liquid-based cytology and human papillomavirus testing in cervical cancer screening. Ottawa: Canadian Coordinating Office for Health Technology Assessment; 2003. Technology report no 40. | SER includes studies that do not meet design criteria
Perrin KK, Daley EM, Naoom SF et al. Women’s reactions to HPV diagnosis: insights from in-depth interviews. Women & Health. 2006;43:93–110. | Editorials, letters, non- systematic review, opinion or case-control
Petticrew MP, Sowden AJ, Lister-Sharp D, Wright K. False-negative results in screening programmes: systematic review of impact and implications. Health Technol Assess. 2000;4:1–120. | Precedes search period
Philips Z, Johnson S, Avis M, Whynes DK. Human papillomavirus and the value of screening: young women’s knowledge of cervical cancer. Health Educ Res. 2003;18:318–328. | Does not focus on screening or harms of screening
Pirotta M, Ung L, Stein A et al. The psychosocial burden of human papillomavirus related disease and screening interventions. Sex Transm Infect. 2009;85:508–513. | Does not focus on screening or harms of screening
Ramirez JE, Ramos DM, Clayton L, Kanowitz S, Moscicki AB. Genital human papillomavirus infections: knowledge, perception of risk, and actual risk in a nonclinic population of young women. J Womens Health. 1997;6:113–121. | Editorials, letters, non- systematic review, opinion or case-control
Reed BD, Ruffin MT, Gorenflo DW, Zazove P. The psychosexual impact of human papillomavirus cervical infections. J Fam Pract. 1999;48:110–116. | Editorials, letters, non- systematic review, opinion or case-control
Rosen NO, Knauper B, Di DP et al. The impact of intolerance of uncertainty on anxiety after receiving an informational intervention about HPV: A randomised controlled study. Psychol Health. 2009;1–17. | Does not focus on screening or harms of screening
Rosen NO, Knauper B, Page G et al. Brief research report: uncertainty-inducing and reassuring facts about HPV: a descriptive study of French Canadian women. Health Care Women Int. 2009;30:892–902. | Does not focus on screening or harms of screening
Rubin MM, Tripsas CK. Perceived uncertainty, coping strategies, and adaptation in women with human papillomavirus on pap smear. Journal of Lower Genital Tract Disease. 2010;14:81–89. | Does not focus on screening or harms of screening
Stuart G, Taylor G, Bancej CM et al. Report of the 2003 pan-Canadian forum on cervical cancer prevention and control. J Obstet Gynaecol Can. 2004;26:1004–1028. | Editorials, letters, non- systematic review, opinion or case-control
Waller J, Marlow LA, Wardle J. The association between knowledge of HPV and feelings of stigma, shame and anxiety. Sex Transm Infect. 2007;83:155–159. | Editorials, letters, non- systematic review, opinion or case-control
Waller J, McCaffery K, Forrest S, Szarewski A, Cadman L, Wardle J. Awareness of human papillomavirus among women attending a well woman clinic. Sex Transm Infect. 2003;79:320–322. | Does not focus on screening or harms of screening
Waller J, McCaffery K, Kitchener H, Nazroo J, Wardle J. Women’s experiences of repeated HPV testing in the context of cervical cancer screening: a qualitative study. Psycho-Oncology. 2007;16:196–204. | Editorials, letters, non- systematic review, opinion or case-control
Waller J, McCaffery K, Nazroo J, Wardle J. Making sense of information about HPV in cervical screening: a qualitative study. Br J Cancer. 2005;92:265–270. | Reported outcomes do not address a key question
Waller J, McCaffery KJ, Forrest S, Wardle J. Human papillomavirus and cervical cancer: issues for biobehavioral and psychosocial research. Ann Behav Med. 2004;27:68–79. | Editorials, letters, non- systematic review, opinion or case-control
Wang KL, Jeng CJ, Yang YC et al. The psychological impact of illness among women experiencing human papillomavirus-related illness or screening interventions. Journal of Psychosomatic Obstetrics & Gynecology. 2010;31:16–23. | Does not focus on screening or harms of screening
Wilkinson C, Jones JM, McBride J. Anxiety caused by abnormal result of cervical smear test: a controlled trial. BMJ. 1990;300:440. | Does not focus on screening or harms of screening
Zielinski SL. Trial quickly changed management of cervical abnormalities. J Natl Cancer Inst. 2005;97:479–480. | Editorials, letters, non- systematic review, opinion or case-control

* See Appendix B Table 2 for more detailed exclusion criteria