# Evidence Tables

Appendix C Table 1 Evidence Table for Age at Which to Begin Screening (KQ1)

Appendix C Table 2 Evidence Table for Liquid-Based Cytology (KQ2)

Appendix C Table 3 Evidence Table for Benefits of HPV Testing (KQ3)

Appendix C Table 4 Evidence Table for Harms of HPV Testing (KQ5)