# Detailed Methods

## Literature Search Strategy

For all key questions (KQs), we used existing systematic evidence reviews and meta-analyses to the extent possible and supplemented with primary systematic literature searches bridging the time period covered by the prior review. Results are presented in a cumulative fashion, incorporating the relevant studies from the prior review. We evaluated the studies included in the previous review by Hartmann and colleagues against the inclusion and exclusion criteria for the current review, and found only one study was eligible for inclusion. 100 For all key questions, we initially searched for systematic reviews, meta-analyses, and evidence-based guidelines on cervical cancer screening in the Database of Abstracts of Reviews of Effects (DARE), the Cochrane Database of Systematic Reviews (CDSR), PubMed, and the Health Technology Assessment database (HTA) from 2000 through 2007. Subsequent searches specific to each key question supplemented evidence found in the search of reviews and meta-analyses. Two reviewers independently examined abstracts from all searches for relevance to all key questions.

For KQs 1, 3, 4, and 5 (addressing age to begin screening, benefits of HPV testing, and harms of liquid-based cytology and HPV testing), we found no systematic reviews or meta-analyses that met our inclusion criteria. Therefore, we conducted primary literature searches to cover the time period since the previous USPSTF review (2000 through September 2010) in MEDLINE and the Cochrane Collaboration Registry of Clinical Trials (CCRCT) without restrictions on study designs. For KQ5, we also searched PsycINFO to capture adverse psychological effects of HPV testing. Search terms are listed in Appendix B, Table 1.

Appendix B Table 1 Search Strategies

Systematic Reviews
Databases: CDSR, DARE, HTA, Pubmed
2000 to January 2007
1. "Uterine Cervical Neoplasms"[MeSH] OR "Uterine Cervical Dysplasia"[MeSH] OR "Cervical Intraepithelial Neoplasia"[MeSH] OR "Papillomavirus Infections"[MeSH] OR "Papillomaviridae"[MeSH]; 2. "Mass Screening"[MeSH:NoExp] OR "Vaginal Smears"[MeSH]; 3. screen*[tiab] OR "vaginal smear"[tiab] OR "vaginal smears"[tiab] OR Papanicolaou[tiab] OR Papanicolau[tiab] OR pap[tiab]; 4. "cervical smear"[tiab] OR "cervical smears"[tiab]; 5. 2 OR 3 OR 4; 6. 1 AND 5; 7. "cervical cancer screening"[tiab]; 8. "hpv testing"[tiab]; 9. "cervical screening"[tiab]; 10. "Vaginal Smears"[MeSH]; 11. "liquid based cytology"[tiab]; 12. "human papillomavirus testing"[tiab]; 13. 6 OR 7 OR 8 OR 9 OR 10 OR 11 OR 12; 14. 13 AND systematic[sb] Limits: English, Publication Date from 2000 to 2007
When to Begin Screening (KQ1)
Databases: Medline, CCRCT
2000 to September 2010
1. uterine cervical diseases/or uterine cervical dysplasia/or uterine cervical neoplasms/; 2. Cervical Intraepithelial Neoplasia/; 3. Vaginal Smears/; 4. 1 or 2 or 3; 5. mass screening/; 6. screen$.ti,ab.; 7. 5 or 6; 8. 4 and 7; 9. cervical cancer screening.ti,ab.; 10. cervical neoplas$ screening.ti,ab.; 11. cervical screening.ti,ab.; 12. 8 or 9 or 10 or 11; 13. Coitus/; 14. (first adj4 intercourse).ti,ab.; 15. (first adj4 coitus).ti,ab.; 16. (initi$ adj4 intercourse).ti,ab.; 17. (sexual$ adj4 activ$).ti,ab.; 18. chronologic$ age.ti,ab.; 19. different age$.ti,ab.; 20. (young$ adj2 wom#n).ti,ab.; 21. (age adj2 specific).ti,ab.; 22. (beg#n$ adj4 screen$).ti,ab.; 23. (start$ adj4 screen$).ti,ab.; 24. (age adj4 beg#n$).ti,ab.; 25. (age adj4 start$).ti,ab.; 26. (age adj4 first).ti,ab.; 27. age factors/; 28. age distribution/; 29. (old$ adj2 wom#n).ti,ab.; 30. (stop$ adj4 screen$).ti,ab.; 31. (age adj4 stop$).ti,ab.; 32. age restrict$.ti,ab.; 33. (withdraw$ adj4 screen$).ti,ab.; 34. 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33; 35. 12 and 34; 36. limit 35 to english language; 37. limit 36 to yr="2000 - 2010"
Liquid-based Cytology Benefits (KQ2) & Harms (KQ4)
Databases: Medline, CCRCT
2003 to September 2010 (KQ2), 2000 to September 2010 (KQ4)
1. Cervix Uteri/cy [Cytology]; 2. Uterine Cervical Diseases/pa, di [Pathology, Diagnosis]; 3. Uterine Cervical Neoplasms/pa, di [Pathology, Diagnosis]; 4. Cervical Intraepithelial Neoplasia/pa, di [Pathology, Diagnosis]; 5. Uterine Cervical Dysplasia/pa, di [Pathology, Diagnosis]; 6. Vaginal Diseases/pa, di [Pathology, Diagnosis]; 7. Vaginal Smears/; 8. 1 or 2 or 3 or 4 or 5 or 6 or 7; 9. Cytological Techniques/; 10. Histocytological Preparation Techniques/; 11. Cytodiagnosis/; 12. 9 or 10 or 11; 13. cervix.ti,ab,hw.; 14. cervical.ti,ab,hw.; 15. vaginal.ti,ab,hw.; 16. 13 or 14 or 15; 17. 12 and 16; 18. ((cervical or cervix or vaginal) adj3 cytolog$).ti,ab.; 19. 8 or 17 or 18; 20. liquid$.ti,ab.; 21. fluid based.ti,ab.; 22. thinprep.ti,ab.; 23. thin prep.ti,ab.; 24. surepath.ti,ab.; 25. autocyte.ti,ab.; 26. cytorich.ti,ab.; 27. monolayer.ti,ab.; 28. mono layer.ti,ab.; 29. thin layer.ti,ab.; 30. 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29; 31. 19 and 30; 32. "Sensitivity and Specificity"/; 33. "Predictive Value of Tests"/; 34. ROC Curve/; 35. False Negative Reactions/; 36. False Positive Reactions/; 37. Diagnostic Errors/; 38. "Reproducibility of Results"/; 39. Reference Values/; 40. Reference Standards/; 41. Observer Variation/; 42. Quality Control/; 43. Quality Assurance, Health Care/; 44. standards.fs.; 45. specificit$.ti,ab.; 46. sensitiv$.ti,ab.; 47. predictive value.ti,ab.; 48. accurac$.ti,ab.; 49. false positive$.ti,ab.; 50. false negative$.ti,ab.; 51. miss rate$.ti,ab.; 52. error rate$.ti,ab.; 53. comparison$.ti.; 54. compare$.ti.; 55. comparing.ti.; 56. comparative study.pt.; 57. detection rate$.ti,ab.; 58. diagnostic yield$.ti,ab.; 59. 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58; 60. 31 and 59; 61. limit 60 to english language; 62. limit 61 to humans; 63. limit 61 to animals; 64. 63 not 62; 65. 61 not 64; 66. limit 65 to yr="2003 – 2010"; 67. harm$.ti,ab.; 68. adverse$.ti,ab.; 69. adverse effects.fs.; 70. inadequate$.ti,ab.; 71. 67 or 68 or 69 or 70; 72. 31 and 71; 73. limit 72 to english language; 74. limit 73 to humans; 75. limit 73 to animals; 76. 75 not 74; 77. 73 not 76; 78. limit 77 to yr="2000 – 2010"; 79. 66 or 78
HPV DNA Testing Benefits (KQ3) & Harms (KQ5)
Databases: Medline, CCRCT, PsycINFO
2000 to September 2010
1. Papillomavirus Infections/di [Diagnosis]; 2. Papillomaviridae/ip [Isolation & Purification]; 3. Alphapapillomavirus/ip [Isolation & Purification]; 4. Human papillomavirus 16/ip [Isolation & Purification]; 5. Human papillomavirus 18/ip [Isolation & Purification]; 6. (hpv$ adj3 test$).ti,ab.; 7. (hpv$ adj3 detect$).ti,ab.; 8. (papillomavirus$ adj3 test$).ti,ab.; 9. (papillomavirus$ adj3 detect$).ti,ab.; 10. (papilloma virus$ adj3 test$).ti,ab.; 11. (papilloma virus$ adj3 detect$).ti,ab.; 12. DNA Probes, HPV/; 13. hybrid capture.ti,ab.; 14. hc2.ti,ab.; 15. hc 2.ti,ab.; 16. hcII.ti,ab.; 17. hc II.ti,ab.; 18. digene.ti,ab.; 19. pcr.ti.; 20. polymerase chain reaction$.ti.; 21. polymerase chain reaction/; 22. Reverse Transcriptase Polymerase Chain Reaction/; 23. linear array.ti,ab.; 24. amplicor.ti,ab.; 25. 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24; 26. papillomavirus$.ti,ab,hw.; 27. papillomaviridae$.ti,ab,hw.; 28. papilloma virus$.ti,ab,hw.; 29. hpv$.ti,ab,hw.; 30. 26 or 27 or 28 or 29; 31. 25 and 30; 32. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 31; 33. cervix.ti,ab,hw.; 34. cervical.ti,ab,hw.; 35. vaginal.ti,ab,hw.; 36. (pap or Papanicolaou).ti,ab.; 37. "Diagnostic Techniques, Obstetrical and Gynecological"/; 38. female.sh.; 39. 33 or 34 or 35 or 36 or 37 or 38; 40. 32 and 39; 41. "Sensitivity and Specificity"/; 42. "Predictive Value of Tests"/; 43. ROC Curve/; 44. False Negative Reactions/; 45. False Positive Reactions/; 46. Diagnostic Errors/; 47. "Reproducibility of Results"/; 48. Reference Values/; 49. Reference Standards/; 50. Quality Control/; 51. Quality Assurance, Health Care/; 52. specificit$.ti,ab.; 53. sensitiv$.ti,ab.; 54. predictive value.ti,ab.; 55. accurac$.ti,ab.; 56. false positive$.ti,ab.; 57. false negative$.ti,ab.; 58. miss rate$.ti,ab.; 59. error rate$.ti,ab.; 60. comparison$.ti.; 61. compare$.ti.; 62. comparing.ti.; 63. comparative study.pt.; 64. detection rate$.ti,ab.; 65. diagnostic yield$.ti,ab.; 66. performance.ti,ab.; 67. triage/; 68. 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67; 69. 40 and 68; 70. limit 69 to english language; 71. limit 70 to yr="2000 – 2010"; 72. limit 71 to humans; 73. limit 71 to animals; 74. 73 not 72; 75. 71 not 74

For KQ2, we found two systematic reviews of liquid-based cytology providing coverage through July 2003.97,98 We used these reviews as source documents and bridged their searches for liquid-based cytology. Therefore, for KQ2, we searched MEDLINE and CCRCT, without restrictions on study designs, from the beginning of 2003 through September 2010.

We also obtained articles from outside experts and through reviewing bibliographies of other relevant articles and systematic reviews. In addition to these searches for published trials, we searched the following sources for unpublished trials: Computer Retrieval of Information on Scientific Projects (CRISP), ClinicalStudyResults.org, Current Controlled Trials, ClinicalTrials.gov.

## Inclusion and Exclusion Criteria

We developed the following set of inclusion/exclusion criteria that were applied to the key questions. Differences in inclusion, exclusion, and quality criteria precluded us from incorporating any of the existing systematic reviews or meta-analyses that were identified; however, the high-quality reviews and meta-analyses were used to check the completeness of our searches for primary studies.

Populations: This review addresses all females at risk for cervical cancer. Studies focusing only on high-risk populations (e.g., HIV-infected women) or women who have had a hysterectomy were excluded.

Settings: This review includes studies conducted in primary care or other settings generalizable to primary care (e.g., family planning clinics, STI clinics, school-based health clinics). No studies were excluded based on geographic location.

[underlined: Screening interventions:] This report addresses the following screening interventions:

1. Liquid-based cytology (obtained as a screening test or adjunct to screening rather than followup of documented disease)
2. Conventional cytology
3. Primary screening with HPV test alone
4. HPV testing with cytology triage of positive HPV (reflex cytology)
5. Combination HPV and cytology testing (co-testing)
6. Cytology testing with HPV triage of positive cytology (reflex HPV)

For KQ3, we focused on the high-risk HPV types as identified by Hybrid Capture 2 (16, 18, 31, 33, 35, 39, 45, 51, 52, 56, 58, 59, and 68). We included studies that used HC2 or PCR (including Linear Array and Amplicor) to identify these 13 HPV types. We excluded studies that focused exclusively on HPV types not listed above. We also excluded studies of in-situ hybridization, p16 immunostaining, and viral load.

[underlined: Outcomes:] For KQ1, we included studies reporting age-specific incidence and prevalence of CIN2, CIN3, invasive carcinoma, or death. For KQs 2 and 3, we included studies reporting detection of histologically-confirmed CIN2, CIN3, and invasive cervical cancer. For KQ4, we included studies of psychological distress and the consequences of false positive results (e.g., colposcopy/biopsy, unnecessary treatment). For KQ5, we included studies reporting the following harms of HPV testing: stigma and under-screening due to association with sexually-transmitted disease, partner discord, unnecessarily labeling some women as high risk, anxiety from and consequences of high-risk labeling, and undermined importance of cytologic screening. We did not systematically review the harms of treatment procedures such as LEEP, cryotherapy, and laser cone biopsy. Instead, we report the results of two systematic reviews on the harms of cervical cancer treatment procedures.

[underlined: Study designs:] For KQ1, addressing when to begin screening, we included RCTs, CCTs, population-based prospective and retrospective cohort studies, case-control studies, ecological-level reports correlating population-based rates of CIN and cancer detection with screening, systematic reviews, and meta-analyses. We only included studies in routine screening populations that present age-specific outcomes, report screening-related denominators, and use age intervals that allow for evaluation of young women separately.

For KQs 2 and 3, evaluating liquid-based cytology and HPV testing, we included studies that provided evidence regarding absolute and relative test performance. Our specific criteria are as follows:

1. To determine absolute test performance, we required that the reference standard of colposcopy and/or biopsy was systematically applied to all those screening positive and at least a random sample of screen negatives, with valid adjustment for verification bias when necessary. The reference standard must have been independent of the screening test (i.e., the screening test results were not used to establish the final diagnosis).
2. If a study did not test negatives appropriately with the gold standard, we could not use their absolute test performance estimates. However, if the study was a randomized controlled trial, compared test performance within the randomization scheme, and was of appropriate quality, then we included relative test performance measures.
3. Many studies reported theoretical test performance by estimating results for different screening and management programs than what was actually done in the trials. We determined these calculations could not be included if the assumptions required to estimate performance introduced potential threats to validity. We usually could not determine how to fairly assess whether these assumptions affected the validity of the calculated test performance, and if they did, what direction or degree of bias was introduced.

For HPV testing in primary screening, we included studies conducted in routine screening populations that compared HC2 or PCR to cytology (conventional or liquid based). For HPV triage of women with ASC-US or LSIL cytology, we included studies in women referred with a single ASC-US or LSIL cytology result that compared HPV triage to repeat cytology.

For KQs 4 and 5, addressing the harms of liquid-based cytology and HPV testing, we included RCTs, CCTs, case-control studies, systematic reviews, and high-quality observational studies.

[underlined: Quality:] We excluded studies that met criteria for “Poor” quality using the USPSTF design-specific criteria (Appendix B, Table 3).

Appendix B Table 3 Quality Rating Criteria

Design | United States Preventive Services Task Force quality rating criteria95 | National Institute for Health and Clinical Excellence methodology checklists101 | The QUADAS Tool102
Systematic reviews and meta-analyses | - Comprehensiveness of sources considered/search strategy used; - Standard appraisal of included studies; - Validity of conclusions; - Recency and relevance are especially important for systematic reviews | - The study addresses an appropriate and clearly focused question; - A description of the methodology used is included; - The literature search is sufficiently rigorous to identify all the relevant studies; - Study quality is assessed and taken into account; - There are enough similarities between the studies selected to make combining them reasonable | Not applicable
Case-control studies | - Accurate ascertainment of cases; - Nonbiased selection of cases/controls with exclusion criteria applied equally to both; - Response rate; - Diagnostic testing procedures applied equally to each group; - Measurement of exposure accurate and applied equally to each group; - Appropriate attention to potential confounding variables | - The study addresses an appropriate and clearly focused question; - The cases and controls are taken from comparable populations; - The same exclusion criteria are used for both cases and controls; - What percentage of each group (cases and controls) participated in the study?; - Comparison is made between participants and non-participants to establish their similarities or differences; - Cases are clearly defined and differentiated from controls; - Is it clearly established that controls are non- cases?; - Measures have been taken to prevent knowledge of primary exposure influencing case ascertainment; - Exposure status is measured in a standard, valid and reliable way; - The main potential confounders are identified and taken into account in the design and analysis; - Have confidence intervals been provided? | Not applicable
Randomized controlled trials (RCTs) | - Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to follow-up or overall high loss to follow-up; - Measurements: equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - The study addresses an appropriate and clearly focused question; - The assignment of subjects to treatment groups is randomized; - An adequate concealment method is used; - Subjects and investigators are kept ‘blind’ about treatment allocation; - The treatment and control groups are similar at the start of the trial; - The only difference between groups is the treatment under investigation; - All relevant outcomes are measured in a standard, valid and reliable way; - What percentage of the individuals or clusters recruited into each treatment arm of the study dropped out before the study was completed?; - All the subjects are analyzed in the groups to which they were randomly allocated (often referred to as intention-to-treat analysis); - Where the study is carried out at more than one site, results are comparable for all sites | Not applicable
Cohort studies | - Initial assembly of comparable groups employs consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to follow-up or overall high loss to follow-up; - Measurements: equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - The study addresses an appropriate and clearly focused question; - The two groups being studied are selected from source populations that are comparable in all respects other than the factor under investigation; - The study indicates how many of the people asked to take part did so, in each of the groups being studied; - The likelihood that some eligible subjects might have the outcome at the time of enrollment is assessed and taken into account in the analysis; - What percentage of individuals or clusters recruited into each arm of the study dropped out before the study was completed?; - Comparison is made between full participants and those lost to follow-up, by exposure status; - The outcomes are clearly defined; - The assessment of outcome is made blind to exposure status; - Where blinding was not possible, there is some recognition that knowledge of exposure status could have influenced the assessment of outcome; - The measure of assessment of exposure is reliable; - Evidence from other sources is used to demonstrate that the method of outcome assessment is valid and reliable; - Exposure level or prognostic factor is assessed more than once; - The main potential confounders are identified and taken into account in the design and analysis; - Have confidence intervals been provided? | Not applicable
Diagnostic accuracy studies | - Screening test relevant, available for primary care, adequately described; - Study uses a credible reference standard, performed regardless of test results; - Reference standard interpreted independently of screening test; - Handles indeterminate result in a reasonable manner; - Spectrum of patients included in study; - Sample size; - Administration of reliable screening test | - The nature of the test being studied is clearly specified; - The test is compared with an appropriate gold standard; - Where no gold standard exists, a validated reference standard is used as a comparator; - Patients for testing are selected either as a consecutive series or randomly, from a clearly defined study population; - The test and gold standard are measured independently (blind) of each other; - The test and gold standard are applied as close together in time as possible; - Results are reported for all patients that are entered into the study; - A pre-diagnosis is made and reported | - The spectrum of patients are representative of the patients who will receive the test in practice; - Selection criteria are clearly described; - The reference standard is likely to correctly classify the target condition; - The time period between the reference standard and the index test is short enough to be reasonably sure that the target condition did not change between the two tests; - The whole sample or a random selection of the sample receives verification using a reference standard of diagnosis; - Patients receive the same reference standard regardless of the index test result; - The reference standard is independent of the index test; - The execution of the index test is described in sufficient detail to permit replication of the test; - The execution of the reference standard is described in sufficient detail to permit its replication; - The index test results are interpreted without knowledge of the results of the reference standard; - The reference standard results are interpreted without knowledge of the results of the index test; - The same clinical data is available when test results are interpreted as would be available when the test is used in practice; - Uninterpretable/intermediate test results are reported; - Withdrawals from the study are explained

[underlined: Language:] We excluded non-English language abstracts and articles.

## Article Review and Data Abstraction

We reviewed a total of 4,262 abstracts and 641 complete articles for all KQs (Appendix B, Figure 1). While we conducted three searches to cover age to begin screening, liquid-based cytology, HPV testing, and harms of liquid-based cytology and HPV testing, we reviewed all abstracts for potential inclusion for any of the KQs. Two investigators independently reviewed all abstracts.

Appendix B Figure 1 Search Results and Article Flow

Appendix B Figure 1 is a flow chart that summarizes the search and selection of articles. There were 4,262 citations identified by searching literature databases (e.g., MEDLINE). An additional 211 citations were identified from outside sources such as reference lists. Of these, 641 full-text articles were examined for inclusion (95 for KQ1, 142 for KQ2, 337 for KQ3, 11 for KQ4, and 49 for KQ5). 575 studies were excluded (see Appendix D for list of excluded studies and reasons for exclusion). 66 articles were included in the final report (6 for KQ1, 7 for KQ2, 48 for KQ3, 0 for KQ4, and 5 for KQ5). These articles accounted for 35 studies.

Two investigators independently reviewed articles against inclusion/exclusion criteria specific for each key question and marked articles for exclusion as soon as an exclusion criterion was met. Included studies that met all criteria were then independently rated for quality by two investigators, using the USPSTF’s study design-specific criteria95 supplemented by National Institute for Health and Clinical Excellence (NICE) criteria for quality assessment101 and the QUADAS tool for quality assessment of diagnostic accuracy studies102 (Appendix B, Table 3). The Methods Work Group of the USPSTF has defined a three-category rating of “good,” “fair,” and “poor” based on these criteria. In general, a good study meets all criteria well. A fair study does not meet, or it is not clear that it meets, at least one criterion, but has no known important limitation that could invalidate its results. A poor study has important limitations. Articles were rated as good, fair, or poor by each rater, and disagreements were settled by consensus. Studies receiving a poor final quality rating were excluded from the review. Listings of excluded articles for each key question, along with the reason for exclusion, are in Appendix D Tables 1–5. A list of all exclusion criteria is in Appendix B Table 2.

Appendix B Table 2 Exclusion Criteria for Key Questions

Exclusion Criteria Applied to All Key Questions
Population:; ▪ Studies focusing only on high-risk populations (e.g., HIV-infected women) or women who have had a hysterectomy
Setting:; ▪ Screening not conducted in primary care or other setting with primary care-comparable population
Design:; ▪ Editorials; Letters; Non-systematic reviews; Opinions
Quality:; ▪ Does not meet quality criteria
No relevant outcomes
Precedes search period
Article covered by an included systematic review
Systematic review used as source document only
Non-English
Additional Exclusion Criteria Specific to Each Key Question
Key Question 1 - When should cervical cancer screening begin, and does this vary by screening technology or by age, sexual history, or other patient characteristics?
Population:; ▪ Conducted solely in referred population
Design:; ▪ Data not stratified by age; ▪ Denominators for outcomes unknown; ▪ Age intervals presented don’t allow evaluation of young women separately; ▪ Modeling study; ▪ Ecological study reporting incidence/mortality in total population without link to screening; ▪ Provides prevalence data only
Key Question 2 - To what extent does liquid-based cytology improve sensitivity, specificity, and diagnostic yield and reduce indeterminate results and inadequate samples compared to conventional cervical cytology?
Relevance:; ▪ Does not focus on cervical cancer screening; ▪ Focused on treatment of CIN, carcinoma in situ, or invasive cervical cancer; ▪ Focused on methods to promote uptake and continuance of appropriate screening; ▪ Focused on methods to improve follow up of abnormal screening findings; ▪ Focused on comparison of tools for collection of cytologic samples (e.g., type of spatula, brush, or swab); ▪ Focused on patient education, satisfaction, or test acceptability
Population:; ▪ Conducted solely in referred population or doesn’t report outcomes in routine screening population separately
Design:; ▪ Case-control study; ▪ Does not systematically apply reference standard of colposcopy and/or biopsy; ▪ Reference standard applied to screening test positives only (for studies of absolute test performance); ▪ Physician choice of cytology; ▪ No comparison to conventional cytology
Screening intervention:; ▪ Obtained as follow up of documented disease; ▪ Home self-test; ▪ See and treat; ▪ Automated screening technologies
Key Question 3 - What are the benefits of using HPV testing as a screening test, either alone or in combination with cytology, compared with not testing for HPV?
Relevance:; ▪ Does not focus on cervical cancer screening; ▪ Focused on treatment of CIN, carcinoma in situ, or invasive cervical cancer; ▪ Focused on methods to promote uptake and continuance of appropriate screening; ▪ Focused on methods to improve follow up of abnormal screening findings; ▪ Focused on patient education, satisfaction, or test acceptability
Population:; ▪ For primary screening, conducted solely in referred population or doesn’t report outcomes in routine screening population separately; ▪ For triage studies, includes women with repeated abnormal smears or abnormal smear other than ASC- US or LSIL
Design:; ▪ Case-control study; ▪ Does not systematically apply reference standard of colposcopy and/or biopsy; ▪ Reference standard applied to screening test positives only (for studies of absolute test performance); ▪ Physician choice of cytology; ▪ No comparison to cytology
Screening intervention:; ▪ Home self-test; ▪ See and treat; ▪ HPV testing conducted to follow up on treatment; ▪ In-situ hybridization; ▪ p16 immunostaining; ▪ Tests of viral load; ▪ Focus on HPV types other than: 16, 18, 31, 33, 35, 39, 45, 51, 52, 56, 58, 59, and 68; ▪ Hybrid Capture I
Key Question 4 - What are the harms of liquid-based cytology?
Relevance:; ▪ Focus on harms of treatment procedures (e.g., LEEP, cryotherapy, laser cone biopsy)
Screening intervention:; ▪ Obtained as follow up of documented disease; ▪ Home self-test; ▪ See and treat; ▪ Automated screening technologies
Key Question 5 - What are the harms of using HPV testing as a screening test, either alone or in combination with cytology?
Relevance:; ▪ Focus on harms of treatment procedures (e.g., LEEP, cryotherapy, laser cone biopsy)
Screening intervention:; ▪ Home self-test; ▪ See and treat; ▪ HPV testing conducted to follow up on treatment; ▪ In-situ hybridization; ▪ p16 immunostaining; ▪ Tests of viral load; ▪ Focus on HPV types other than: 16, 18, 31, 33, 35, 39, 45, 51, 52, 56, 58, 59, and 68; ▪ Hybrid Capture I

There are 35 studies (reported in 66 articles) included in this review. For KQ1, we found 5 studies reported in 6 articles, none of which were included in the previous USPSTF report. For KQ2, we found 4 studies reported in 7 articles, none of which were included in the previous USPSTF report. For KQ3, we found 22 studies reported in 48 articles, 1 of which was included in the previous USPSTF report. For KQ4, we found no studies. For KQ5, we found 4 studies reported in 5 articles, none of which were included in the previous USPSTF report. One primary reviewer abstracted relevant information such as study setting, population, screening method, and outcomes into standardized evidence tables for each included article (Appendix C Tables 1–4). A second reviewer checked the abstracted data for accuracy and completeness.

## Data Synthesis

We found no data for KQ4. Except for cytology testing with HPV triage of positive cytology (KQ3), data synthesis for all questions was qualitative because heterogeneity in the samples, settings, study designs, and instruments did not allow for quantitative synthesis. In the results text, studies are summarized qualitatively within the key questions. For KQ3 addressing HPV testing, studies are categorized by the four different uses of HPV testing in cervical cancer screening. In addition, randomized controlled trials providing primarily relative test performance measures within screening programs are described first, followed by studies reporting absolute test performance data. Studies from countries with less developed cervical cancer screening programs are discussed separately due to their lower applicability to the US population. Where possible, the data is provided stratified by age for two primary reasons: 1) the FDA has approved the use of HC2 in women 30 years and older as an adjunct to cytology to assess the absence or presence of high-risk HPV types,70,71 and 2) the prevalence of high-risk HPV is much lower in women aged 30 and older than in women under age 30, dropping sharply with age from a prevalence of 35 percent for women aged 15–19 to <15 percent for women aged 30–39 (Figure 3). For evidence on the benefits of using HPV testing to triage women with ASC-US cytology, we estimated the combined difference in sensitivity and specificity between HPV and repeat conventional cytology. A random effects model was used to incorporate variation among studies. For the difference in sensitivity and specificity between HC2 and cytology, we used risk difference as the effect measure. Statistical heterogeneity was assessed by Cochran’s Q test and the I^2^ statistic.103 All analyses were performed using Stata 10.0 (StataCorp, College Station, TX, 2007).

Many of the results reported in the evidence and summary tables are calculated from data provided in the articles. Such calculations are indicated in the evidence tables by ‘(calc)’ following the results. In the randomized controlled trials, results were generally reported using women screened (instead of women randomized as in an “intention-to-screen” analysis) within each arm and each round. To be consistent, we abstracted from the articles or calculated results using the number of women screened within each randomized arm as the denominator unless noted as otherwise in the evidence tables. Consideration of program results only among women screened may be less appropriate to determine overall population impact, but acceptable when primarily evaluating the relative merits (including false positives and other adverse effects) of efficacious screening alternatives.

The trials reviewed generally applied the histology reference standard to screen-positive but not systematically to screen-negative participants. The numbers of true positive versus false positive screening test results are thus known (if not always fully reported), represented in the tables below as “a” and “b” respectively. However, the numbers of true versus false negative results (“d” and “c”) and the total numbers of participants with (a+c) and without (b+d) disease are unknown (collectively, all the shaded cells below).

Intervention arm | | Disease
Intervention arm | | + | −
Test 1 | + | a_1_ | b_1_ | a_1_+b_1_
Test 1 | − | c_1_ | d_1_ | c_1_+d_1_
| | a_1_+c_1_ | b_1_+d_1_ | n_1_ =a_1_+b_1_+c_1_+d_1_

Absolute test performance in the intervention group:

- Sensitivity_1_ = a_1_/a_1_+c_1_
- Specificity_1_ = d_1_/b_1_+d_1_

Control arm | | Disease
Control arm | | + | −
Test 2 | + | a_2_ | b_2_ | a_2_+b_2_
Test 2 | − | c_2_ | d_2_ | c_2_+d_2_
| | a_2_+c_2_ | b_2_+d_2_ | n_2_ =a_2_+b_2_+c_2_+d_2_

Absolute test performance in the control group:

- Sensitivity_2_ = a_2_/a_2_+c_2_
- Specificity_2_ = d_2_/b_2_+d_2_

As a result, absolute sensitivity and specificity as defined above cannot be derived. However, clinically relevant relative test performance measures can be calculated. In a randomized trial where disease prevalence is expected to be the same between study arms, if the number of participants in each arm of the trial are the same then the number of participants with disease (a+c) should be the same in the intervention and control groups, i.e., (a_1_+c_1_) = (a_2_+c_2_). The relative detection rate (RDR, which could also be called relative sensitivity) can then be calculated:

Relative detection rate ( RDR ) = [ a_1_ / ( a_1_ + c_1_ ) ] / a_2_ / ( a_2_ + c_2_ ) ] = a_1_ / a_2_

Where the number of participants in each arm of the trial differs, the RDR can be calculated instead as:

Relative detection rate ( RDR ) = [ ( a_1_ / n_1_ ) / ( a_2_ / n_2_ ) ]

Where

a_1_ = cases of disease detected (or true positives) in the intervention arm

n_1_ = number of participants in the intervention arm

a_2_ = cases of disease detected (or true positives) in the control arm

n_2_ = number of participants in the control arm

We used the latter formula, correcting for differences in number of participants between arms, in all our RDR calculations. Inclusion of CIN outcomes from opportunistic screening varied between trials, and was not always clearly reported. For example, detection rates (a/n) and relative detection rates reported for the POBASCAM trial used the numerator of all CIN or cancer cases detected in each study arm, regardless of screening test result, including cases detected by opportunistic screening in screen-negative women. ARTISTIC publications included only screen-detected CIN in reported detection rates, and we did the same in calculating age-specific RDRs. For the Finnish trial, initial publications appeared to include only screen-detected CIN in detection rates, though CIN outcomes were not reported by screening test result. Extended followup published in 2010 reported RDRs in both screen-positive women and all attendees, and we reported the results in all attendees as better representing the real-world effectiveness of the screening program. Swedescreen appeared to report screen-detected CIN in Round 1 RDRs, while including opportunistic screening from both rounds with Round 2.

Less often reported, but analogous to the RDR, is another relative test performance measure, which we have called the relative false positive proportion (RFPP). The RFPP is an estimate of the relative harms of screening tests, specifically the relative proportion of women referred unnecessarily to colposcopy.

Relative False Positive Proportion ( RFPP ) = [ ( b_1_ / n_1_ ) / ( b_2_ / n_2_ ) ]

Where

b_1_ = false positives in the intervention arm (i.e., those with a positive screening test not found by histology to have true disease)

n_1_ = number of participants in the intervention arm

b_2_ = false positives in the control arm

n_2_ = number of participants in the control arm

A similar calculation of “relative specificity” is not possible, as it would require information on true versus false negatives which these trials do not obtain (specifically, d_1_ and d_2_ or the true negatives in the tables above). We therefore neither abstracted nor calculated any specificity measure from the trials. Both absolute and relative positive predictive value (PPV) should be calculable for all trials since this measure describes screen-positive women only, for whom full histology data were obtained. Wherever reported data allowed, we abstracted or calculated both PPV measures as well.

Absolute PPV in the intervention group = PPV_1_ = a_1_ / ( a_1_ + b_1_ )

Where

a_1_ = cases of disease detected (in screen-positive participants, i.e., true positives) in the intervention arm

a_1_+b_1_ = all participants in the intervention arm with a positive screening test

Absolute PPV in the control group = PPV_2_ = a_2_ / ( a_2_ + b_2_ )

Where

a_2_ = cases of disease detected (in screen-positive participants, i.e., true positives) in the control arm

a_2_+b_2_= all participants in the control arm with a positive screening test

Relative PPV ( intervention vs . control arm ) = PPV_1_ / PPV_2_

The randomized controlled trials of HPV testing include complicated, different protocols for followup retesting and referral to colposcopy among those with positive results not meeting the threshold for immediate colposcopy referral. In some cases, studies used different colposcopy referral thresholds; therefore, we performed PPV and RFPP calculations using the lowest referral criterion for cytology, HPV+ and/or ASC-US+, to define a positive screening test. This is a conservative strategy that may overestimate false positives for trials with higher initial referral criteria such as POBASCAM, ARTISTIC (both HSIL+), and the Finnish trial (LSIL+), though the relative test performance measures available from these trials may be less affected than would absolute test performance measures. A conservative definition of a positive screening test is consistent with the cumulative CIN outcomes reported in the trials and used in test performance calculations, including results from intensified followup as well as from immediate colposcopy. It is also consistent with clinical practice, in which an ASC-US+ cytology result or positive HPV test triggers additional followup, even if not immediate referral to colposcopy.

## External Review Process

The USPSTF appointed eight liaisons to guide the scope and reporting of this review. The work plan for the review was sent to four experts on cervical cancer screening, whom we asked to comment on the general proposed approach, scope of the review, and adequacy of the identified questions. In addition, ten outside experts provided feedback on a draft version of this evidence synthesis.