# Terminology and Abbreviations

Adenocarcinoma223: Cancer that begins in cells that line certain internal organs and that have gland-like (secretory) properties.
Baseline screening: Initial cross-sectional results from a screening episode, with associated histologic results from immediate colposcopy referrals. Does not include complete retesting results (repeat screens after an initial equivocal result) or associated histology. For example, in Phase 1 of the NTCC trial, baseline results included histologic lesions detected up to one year after initial colposcopy referral, but not lesions detected over the full three-year interval between screening rounds.
Cervical cancer223: Cancer that forms in tissues of the cervix (the organ connecting the uterus and vagina). It is usually a slow-growing cancer that may not have symptoms but can be found with regular Pap tests.
Cervix223: The lower, narrow end of the uterus that forms a canal between the uterus and vagina.
Colposcopy223: Examination of the vagina and cervix using a lighted magnifying instrument called a colposcope.
Cone biopsy223: Surgery to remove a cone-shaped piece of tissue from the cervix and cervical canal. Cone biopsy may be used to diagnose or treat a cervical condition. Also called conization.
Cryotherapy223: Any method that uses cold temperature to treat disease.
Cytology223: The study of cells using a microscope.
False positive: A patient with an abnormal screening test but a normal gold standard test for disease. Depending on the outcome of interest, the definition of a normal disease outcome will vary. For example, in analyzing the performance of a cytology screening test result of LSIL+ to predict CIN3+ detected by colposcopically-directed biopsy, false positives would be women with LSIL+ cytology and either normal colposcopy (no biopsy), normal biopsy, or biopsy showing CIN1 or CIN2.
Histology223: The study of tissues and cells under a microscope.
HPV testing224: Detects presence of HPV genetic material (DNA) high-risk for cervical cancer.
HPV vaccine223: A vaccine being studied in the prevention of human papillomavirus infection and cervical cancer. Infection with certain types of HPV increases the risk of developing cervical cancer. Also called human papillomavirus vaccine.
Liquid-based cytology223: A method for screening for cancerous or precancerous changes of the cervix performed by scraping cells from the cervix and rinsing the sampling device into a vial containing a liquid preservative.
Loop electrosurgical excision procedure223: A technique that uses electric current passed through a thin wire loop to remove abnormal tissue. Also called loop excision and LEEP.
Pap smear223: A method developed by Dr. George Papanicolaou for screening for cancerous or precancerous changes of the cervix performed by scraping cells from the cervix and fixing them on a glass slide. Also known as conventional cytology.
Primary cervical cancer screening test(s)163: A first test (historically cervical cytology) that, if abnormal and meets a pre-established threshold (such as LSIL+), leads to referral for a diagnostic procedure (usually colposcopy and biopsy).
Rescreening: The next routine screening episode after a negative screening test result.
Retesting163: After a primary cervical cancer screening test, those with abnormal results who do not reach the threshold for diagnostic referral go through a repeated protocol of follow-up screening with later colposcopy referral based on persistent or advancing abnormalities.
Round 1 screening: Screening test results (both initial Round 1 results and retesting results) and associated histology for the full duration of Round 1.
Round 2 screening: Screening test results (both initial Round 2 results and restesting results) and associated histology for the full duration of Round 2.
Screening: Testing asymptomatic individuals in order to detect disease at an earlier, more treatable stage and minimize adverse outcomes.
Screening interval (or rescreening interval): Time between routine screening episodes (e.g. three years).
Screening program: A comprehensive screening plan including routine screening intervals and protocols for retesting after equivocal tests and for referral to colposcopy, represented by the designs of national screening programs or of randomized controlled trials.
Squamous cell carcinoma223: Cancer that begins in squamous cells, which are thin, flat cells that look like fish scales. Squamous cells are found in the tissue that forms the surface of the skin, the lining of the hollow organs of the body, and the passages of the respiratory and digestive tracts. Also called epidermoid carcinoma.
Triage test163: A test applied to those with a positive primary test to further select women before referral for a diagnostic procedure (colposcopy and biopsy).

## List of acronyms and abbreviations

Abbreviation/Acronym: Phrase, term, name of instrument
AGC: Atypical glandular cells (specify endocervical or not otherwise specified [NOS])
AGUS: Atypical glandular cells of undetermined significance
ACIS: Endocervical adenocarcinoma in situ
ASC-H: Atypical squamous cells – cannot exclude HSIL
ASC-US: Atypical squamous cells of undetermined significance
CC: Conventional cytology
CI: Confidence interval
CIN: Cervical intraepithelial neoplasia
CIS: Carcinoma in situ
CKC: Cold knife conization
CSQ: Cervical Screening Questionnaire
DR: Detection rate
ECC: Endocervical curettage
GHQW-12: General Health Questionnaire
HC2: Digene Hybrid Capture 2 high-risk HPV DNA test
HIV: Human immunodeficiency virus
HPV: Human papillomavirus
HR: Hazard ratio
hrHPV: High-risk human papillomavirus
HSIL: High-grade squamous intraepithelial lesion encompassing: moderate and severe dysplasia, CIN2, CIN3, and carcinoma in situ
ICC: Invasive cervical cancer
IQR: Interquartile range
LBC: Liquid-based cytology
LEEP: Loop electrosurgical excision procedure
LSIL: Low-grade squamous intraepithelial lesion encompassing: human papillomavirus/ mild dysplasia/CIN1
OR: Odds ratio
PCR: Polymerase chain reaction
PEAPS-Q: Psychosocial Effects of Abnormal Pap Smear Questionnaire
PPV: Positive predictive value
RCT: Randomized controlled trial
RFPP: Relative false positive proportion
RLU: Relative light unit
RR: Relative risk
SCC: Squamous cell carcinoma
SD: Standard deviation
SE: Standard error
SONE: Strips of neoplastic endocervix
S-STAI-6: Short form of Spielberger State-Trait Anxiety Inventory
STI: Sexually transmitted infection
VIA: Visual inspection with acetic acid