# Appendixes

Appendix A Terminology and Abbreviations

Appendix B Detailed Methods

Appendix C Evidence Tables

Appendix D Excluded Studies

Appendix E Screening Benefit Considerations Illustrated by NTCC Phase II Trial

Appendix F Ongoing and Pending Trials

Appendix G Recommendations of Other Groups

Appendix H Cervical Cancer and HPV: Prevalence, Incidence and Mortality Rates