# References

1 Rosamond W, Flegal K, Furie K, et al. Heart disease and stroke statistics—2008 update: a report from the American Heart Association Statistics Committee and Stroke Statistics Subcommittee. Circulation. 2008;117(4):e25-146. [pmid: 18086926].
2 National Heart Lung and Blood Institute Fact Book, Fiscal Year 2006. Bethesda, Md. National Heart Lung and Blood Institute, National Institutes of Health. 2006. Last accessed at http://www.nhlbi.nih.gov/about/factbook-06/toc.htm on. 12 April 2011.
3 Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults. Executive Summary of the Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III). JAMA. 2001;285(19):2486-97. [pmid: 11368702].
4 Hayden M, Pignone M, Phillips C, et al. Aspirin for the primary prevention of cardiovascular events: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;136(2):161-72. [pmid: 11790072].
5 The Sixth Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure. Arch Intern Med. 1997;157(21):2413-46. [pmid: 9385294].
6 Grundy SM, Bazzarre T, Cleeman J, et al. Writing Group I. Prevention Conference V. Beyond secondary prevention: identifying the high-risk patient for primary prevention. Medical Office Assessment. Circulation. 2000;101(1):e3-11. [pmid: 10618316].
7 Pearson TA, Blair SN, Daniels SR, et al. AHA Guidelines for Primary Prevention of Cardiovascular Disease and Stroke: 2002 Update. Circulation. 2002;106(3):388-91. [pmid: 12119259].
8 Montgomery AA, Fahey T, MacKintosh C, et al. Estimation of cardiovascular risk in hypertensive patients in primary care. Br J Gen Pract. 2000;50(451):127-8. [pmid: 10750210].
9 Chatellier G, Blinowska A, Menard J, et al. Do physicians estimate reliably the cardiovascular risk of hypertensive patients?. Medinfo. 1995;8(Pt 2):876-9. [pmid: 8591574].
10 Grover SA, Lowensteyn I, Esrey KL, et al. Do doctors accurately assess coronary risk in their patients? Preliminary results of the Coronary Health Assessment Study. BMJ. 1995;310(6985):975-8. [pmid: 7728035].
11 Friedmann PD, Brett AS, Mayo-Smith MF. Differences in generalists' and cardiologists' perceptions of cardiovascular risk and the outcomes of preventive therapy in cardiovascular disease. Ann Intern Med. 1996;124(4):414-21. [pmid: 8554250].
12 Meland E, Laerum E, Lehmann EH. Assessment of coronary heart disease risk, II: a clinical multicentre study of general practitioners' risk assessment. Fam Pract. 1994;11(2):122-6. [pmid: 7958573].
13 Meland E, Laerum E, Stensvold I. Assessment of coronary heart disease risk, I: a postal inquiry among primary care physicians. Fam Pract. 1994;11(2):117-21. [pmid: 7958572].
14 Assmann G, Cullen P, Schulte H. Simple scoring scheme for calculating the risk of acute coronary events based on the 10-year follow-up of the Prospective Cardiovascular Münster (PROCAM) study. Circulation. 2002;105(3):310-5. [pmid: 11804985].
15 Pocock SJ, McCormack V, Gueyffier F, et al. A score for predicting risk of death from cardiovascular disease in adults with raised blood pressure, based on individual patient data from randomised controlled trials. BMJ. 2001;323(7304):75-81. [pmid: 11451781].
16 Tunstall-Pedoe H. The Dundee coronary risk-disk for management of change in risk factors. BMJ. 1991;303(6805):744-7. [pmid: 1932933].
17 Menotti A, Lanti M, Puddu PE, et al. Coronary heart disease incidence in northern and southern European populations: a reanalysis of the Seven Countries Study for a European coronary risk chart. Heart. 2000;84(3):238-44. [pmid: 10956281].
18 Anderson KM, Odell PM, Wilson PW, et al. Cardiovascular disease risk profiles. Am Heart J. 1991;121(1 Pt 2):293-8. [pmid: 1985385].
19 Wilson PW, D'Agostino RB, Levy D, et al. Prediction of coronary heart disease using risk factor categories. Circulation. 1998;97(18):1837-47. [pmid: 9603539].
20 Menotti A, Puddu PE, Lanti M. Comparison of the Framingham risk function-based coronary chart with risk function from an Italian population study. Eur Heart J. 2000;21(5):365-70. [pmid: 10666350].
21 Game FL, Bartlett WA, Bayly GR, et al. Comparative accuracy of cardiovascular risk prediction methods in patients with diabetes mellitus. Diabetes Obes Metab. 2001;3(4):279-86. [pmid: 11520308].
22 Sheridan S, Pignone M, Mulrow C. Framingham-based tools to calculate the global risk of coronary heart disease: a systematic review of tools for clinicians. J Gen Intern Med. 2003;18(12):1039-52. [pmid: 14687264].
23 D'Agostino RB Sr, Grundy S, Sullivan LM, et al. Validation of the Framingham coronary heart disease prediction scores: results of a multiple ethnic groups investigation. JAMA. 2001;286(2):180-7. [pmid: 11448281].
24 Liao Y, McGee DL, Cooper RS. Prediction of coronary heart disease mortality in blacks and whites: pooled data from two national cohorts. Am J Cardiol. 1999;84(1):31-6. [pmid: 10404847].
25 Liao Y, McGee DL, Cooper RS, et al. How generalizable are coronary risk prediction models? Comparison of Framingham and two national cohorts. Am Heart J. 1999;137(5):837-45. [pmid: 10220632].
26 Grundy SM, D'Agostino RB Sr, Mosca L, et al. Cardiovascular risk assessment based on US cohort studies: findings from a National Heart Lung and Blood Institute workshop. Circulation. 2001;104(4):491-6. [pmid: 11468215].
27 U.K. Prospective Diabetes Study Group. Tight blood pressure control and risk of macrovascular and microvascular complications in type 2 diabetes: UKPDS 38. BMJ. 1998;317(7160):703-13. [pmid: 9732337].
28 Haffner SM, Lehto S, Ronnemaa T, et al. Mortality from coronary heart disease in subjects with type 2 diabetes and in nondiabetic subjects with and without prior myocardial infarction. N Engl J Med. 1998;339(4):229-34. [pmid: 9673301].
29 Buyken AE, von Eckardstein A, Schulte H, et al. Type 2 diabetes mellitus and risk of coronary heart disease: results of the 10-year follow-up of the PROCAM study. Eur J Cardiovasc Prev Rehabil. 2007;14(2):230-6. [pmid: 17446801].
30 Diverse Populations Collaborative Group. Prediction of mortality from coronary heart disease among diverse populations: is there a common predictive function?. Heart. 2002;88(3):222-8. [pmid: 12181209].
31 Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults. Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III): final report. Circulation. 2002;106(25):3143-421. [pmid: 12485966].
32 Brindle P, Beswick A, Fahey T, et al. Accuracy and impact of risk assessment in the primary prevention of cardiovascular disease: a systematic review. Heart. 2006;92(12):1752-9. [pmid: 16621883].
33 Eichler K, Puhan MA, Steurer J, et al. Prediction of first coronary events with the Framingham score: a systematic review. Am Heart J. 2007;153(5):722-31. [pmid: 17452145].
34 Wilson PW, Bozeman SR, Burton TM, et al. Prediction of first events of coronary heart disease and stroke with consideration of adiposity. Circulation. 2008;118(2):124-30. [pmid: 18591432].
35 Hippisley-Cox J, Coupland C, Vinogradova Y, et al. Predicting cardiovascular risk in England and Wales: prospective derivation and validation of QRISK2. BMJ. 2008;336(7659):1475-82. [pmid: 18573856].
36 Simmons RK, Sharp S, Boekholdt SM, et al. Evaluation of the Framingham risk score in the European Prospective Investigation of Cancer-Norfolk cohort: does adding glycated hemoglobin improve the prediction of coronary heart disease events?. Arch Intern Med. 2008;168(11):1209-16. [pmid: 18541829].
37 Gaziano TA, Young CR, Fitzmaurice G, et al. Laboratory-based versus non-laboratory-based method for assessment of cardiovascular disease risk: the NHANES I Follow-Up Study cohort. Lancet. 2008;371(9616):923-31. [pmid: 18342687].
38 Yang X, So WY, Kong AP, et al. Development and validation of a total coronary heart disease risk score in type 2 diabetes mellitus. Am J Cardiol. 2008;101(5):596-601. [pmid: 18308005].
39 D'Agostino RB Sr, Vasan RS, Pencina MJ, et al. General cardiovascular risk profile for use in primary care: the Framingham Heart Study. Circulation. 2008;117(6):743-53. [pmid: 18212285].
40 Becker A, Leber A, Becker C, et al. Predictive value of coronary calcifications for future cardiac events in asymptomatic individuals. Am Heart J. 2008;155(1):154-60. [pmid: 18082507].
41 Assmann G, Schulte H, Cullen P, et al. Assessing risk of myocardial infarction and stroke: new data from the Prospective Cardiovascular Münster (PROCAM) study. Eur J Clin Invest. 2007;37(12):925-32. [pmid: 18036028].
42 Vaidya D, Yanek LR, Moy TF, et al. Incidence of coronary artery disease in siblings of patients with premature coronary artery disease: 10 years of follow-up. Am J Cardiol. 2007;100(9):1410-5. [pmid: 17950799].
43 Hippisley-Cox J, Coupland C, Vinogradova Y, et al. Performance of the QRISK cardiovascular risk prediction algorithm in an independent UK sample of patients from general practice: a validation study. Heart. 2008;94(1):34-9. [pmid: 17916661].
44 Lindman AS, Veierod MB, Pedersen JI, et al. The ability of the SCORE high-risk model to predict 10-year cardiovascular disease mortality in Norway. Eur J Cardiovasc Prev Rehabil. 2007;14(4):501-7. [pmid: 17667638].
45 Weiner DE, Tighiouart H, Elsayed EF, et al. The Framingham predictive instrument in chronic kidney disease. J Am Coll Cardiol. 2007;50(3):217-24. [pmid: 17631213].
46 Hippisley-Cox J, Coupland C, Vinogradova Y, et al. Derivation and validation of QRISK, a new cardiovascular disease risk score for the United Kingdom: prospective open cohort study. BMJ. 2007;335(7611):136. [pmid: 17615182].
47 Jee SH, Park JW, Lee SY, et al. Stroke risk prediction model: a risk profile from the Korean study. Atherosclerosis. 2008;197(1):318-25. [pmid: 17586511].
48 Koller MT, Steyerberg EW, Wolbers M, et al. Validity of the Framingham point scores in the elderly: results from the Rotterdam study. Am Heart J. 2007;154(1):87-93. [pmid: 17584559].
49 Berry JD, Lloyd-Jones DM, Garside DB, et al. Framingham risk score and prediction of coronary heart disease death in young men. Am Heart J. 2007;154(1):80-6. [pmid: 17584558].
50 Strom Moller C, Zethelius B, Sundstrom J, et al. Persistent ischaemic ECG abnormalities on repeated ECG examination have important prognostic value for cardiovascular disease beyond established risk factors: a population-based study in middle-aged men with up to 32 years of follow-up. Heart. 2007;93(9):1104-10. [pmid: 17483125].
51 Mainous AG 3rd, Koopman RJ, Diaz VA, et al. A coronary heart disease risk score based on patient-reported information. Am J Cardiol. 2007;99(9):1236-41. [pmid: 17478150].
52 Miyasaka Y, Barnes ME, Gersh BJ, et al. Coronary ischemic events after first atrial fibrillation: risk and survival. Am J Med. 2007;120(4):357-63. [pmid: 17398231].
53 Denes P, Larson JC, Lloyd-Jones DM, et al. Major and minor ECG abnormalities in asymptomatic women and risk of cardiovascular events and mortality. JAMA. 2007;297(9):978-85. [pmid: 17341712].
54 Ridker PM, Buring JE, Rifai N, et al. Development and validation of improved algorithms for the assessment of global cardiovascular risk in women: the Reynolds Risk Score. JAMA. 2007;297(6):611-9. [pmid: 17299196].
55 Barzi F, Patel A, Gu D, et al. Cardiovascular risk prediction tools for populations in Asia. J Epidemiol Community Health. 2007;61(2):115-21. [pmid: 17234869].
56 Reissigova J, Zvarova J. The Framingham risk function underestimated absolute coronary heart disease risk in Czech men. Methods Inf Med. 2007;46(1):43-9. [pmid: 17224979].
57 Yang X, So WY, Kong AP, et al. Development and validation of stroke risk equation for Hong Kong Chinese patients with type 2 diabetes: the Hong Kong Diabetes Registry. Diabetes Care. 2007;30(1):65-70. [pmid: 17192335].
58 Marrugat J, Subirana I, Comin E, et al. Validity of an adaptation of the Framingham cardiovascular risk function: the VERIFICA Study. J Epidemiol Community Health. 2007;61(1):40-7. [pmid: 17183014].
59 Woodward M, Brindle P, Tunstall-Pedoe H. Adding social deprivation and family history to cardiovascular risk assessment: the ASSIGN score from the Scottish Heart Health Extended Cohort (SHHEC). Heart. 2007;93(2):172-6. [pmid: 17090561].
60 Macfarlane PW, Norrie J. The value of the electrocardiogram in risk assessment in primary prevention: experience from the West of Scotland Coronary Prevention Study. J Electrocardiol. 2007;40(1):101-9. [pmid: 17069838].
61 Cook NR, Buring JE, Ridker PM. The effect of including C-reactive protein in cardiovascular risk prediction models for women. Ann Intern Med. 2006;145(1):21-9. [pmid: 16818925].
62 Lee ET, Howard BV, Wang W, et al. Prediction of coronary heart disease in a population with high prevalence of diabetes and albuminuria: the Strong Heart Study. Circulation. 2006;113(25):2897-905. [pmid: 16769914].
63 Donnan PT, Donnelly L, New JP, et al. Derivation and validation of a prediction score for major coronary heart disease events in a U.K. type 2 diabetic population. Diabetes Care. 2006;29(6):1231-6. [pmid: 16732001].
64 May M, Lawlor DA, Brindle P, et al. Cardiovascular disease risk assessment in older women: can we improve on Framingham? British Women's Heart and Health prospective cohort study. Heart. 2006;92(10):1396-401. [pmid: 16547204].
65 Wannamethee SG, Shaper AG, Lennon L, et al. Metabolic syndrome vs Framingham risk score for prediction of coronary heart disease, stroke, and type 2 diabetes mellitus. Arch Intern Med. 2005;165(22):2644-50. [pmid: 16344423].
66 Brindle PM, McConnachie A, Upton MN, et al. The accuracy of the Framingham risk-score in different socioeconomic groups: a prospective study. Br J Gen Pract. 2005;55(520):838-45. [pmid: 16281999].
67 Silventoinen K, Pankow J, Lindstrom J, et al. The validity of the Finnish Diabetes Risk Score for the prediction of the incidence of coronary heart disease and stroke, and total mortality. Eur J Cardiovasc Prev Rehabil. 2005;12(5):451-8. [pmid: 16210931].
68 Ulmer H, Kollerits B, Kelleher C, et al. Predictive accuracy of the SCORE risk function for cardiovascular disease in clinical practice: a prospective evaluation of 44,649 Austrian men and women. Eur J Cardiovasc Prev Rehabil. 2005;12(5):433-41. [pmid: 16210929].
69 Vliegenthart R, Oudkerk M, Hofman A, et al. Coronary calcification improves cardiovascular risk prediction in the elderly. Circulation. 2005;112(4):572-7. [pmid: 16009800].
70 Arad Y, Goodman KJ, Roth M, et al. Coronary calcification, coronary disease risk factors, C-reactive protein, and atherosclerotic cardiovascular disease events: the St. Francis Heart Study. J Am Coll Cardiol. 2005;46(1):158-65. [pmid: 15992651].
71 Cooper JA, Miller GJ, Humphries SE. A comparison of the PROCAM and Framingham point-scoring systems for estimation of individual risk of coronary heart disease in the Second Northwick Park Heart Study. Atherosclerosis. 2005;181(1):93-100. [pmid: 15939059].
72 Bernard S, Serusclat A, Targe F, et al. Incremental predictive value of carotid ultrasonography in the assessment of coronary risk in a cohort of asymptomatic type 2 diabetic subjects. Diabetes Care. 2005;28(5):1158-62. [pmid: 15855582].
73 Guzder RN, Gatling W, Mullee MA, et al. Prognostic value of the Framingham cardiovascular risk equation and the UKPDS risk engine for coronary heart disease in newly diagnosed type 2 diabetes: results from a United Kingdom study. Diabet Med. 2005;22(5):554-62. [pmid: 15842509].
74 Bhopal R, Fischbacher C, Vartiainen E, et al. Predicted and observed cardiovascular disease in South Asians: application of FINRISK, Framingham and SCORE models to Newcastle Heart Project data. J Public Health (Oxf). 2005;27(1):93-100. [pmid: 15749725].
75 McNeill AM, Rosamond WD, Girman CJ, et al. The metabolic syndrome and 11-year risk of incident cardiovascular disease in the Atherosclerosis Risk in Communities Study. Diabetes Care. 2005;28(2):385-90. [pmid: 15677797].
76 Ferrario M, Chiodini P, Chambless LE, et al. Prediction of coronary events in a low incidence population: assessing accuracy of the CUORE cohort study prediction equation. Int J Epidemiol. 2005;34(2):413-21. [pmid: 15659467].
77 Wang Z, Hoy WE. Is the Framingham coronary heart disease absolute risk function applicable to Aboriginal people?. Med J Aust. 2005;182(2):66-9. [pmid: 15651963].
78 Stephens JW, Ambler G, Vallance P, et al. Cardiovascular risk and diabetes: are the methods of risk prediction satisfactory?. Eur J Cardiovasc Prev Rehabil. 2004;11(6):521-8. [pmid: 15580065].
79 Stern MP, Williams K, Gonzalez-Villalpando C, et al. Does the metabolic syndrome improve identification of individuals at risk of type 2 diabetes and/or cardiovascular disease?. Diabetes Care. 2004;27(11):2676-81. [pmid: 15505004].
80 Dunder K, Lind L, Zethelius B, et al. Evaluation of a scoring scheme, including proinsulin and the apolipoprotein B/apolipoprotein A1 ratio, for the risk of acute coronary events in middle-aged men: Uppsala Longitudinal Study of Adult Men (ULSAM). Am Heart J. 2004;148(4):596-601. [pmid: 15459588].
81 Chambless LE, Heiss G, Shahar E, et al. Prediction of ischemic stroke risk in the Atherosclerosis Risk in Communities Study. Am J Epidemiol. 2004;160(3):259-69. [pmid: 15257999].
82 Ducloux D, Kazory A, Chalopin JM. Predicting coronary heart disease in renal transplant recipients: a prospective study. Kidney Int. 2004;66(1):441-7. [pmid: 15200454].
83 Liu J, Hong Y, D'Agostino RB Sr, et al. Predictive value for the Chinese population of the Framingham CHD risk assessment tool compared with the Chinese Multi-Provincial Cohort Study. JAMA. 2004;291(21):2591-9. [pmid: 15173150].
84 Erikssen G, Bodegard J, Bjornholt JV, et al. Exercise testing of healthy men in a new perspective: from diagnosis to prognosis. Eur Heart J. 2004;25(11):978-86. [pmid: 15172470].
85 McEwan P, Williams JE, Griffiths JD, et al. Evaluating the performance of the Framingham risk equations in a population with diabetes. Diabet Med. 2004;21(4):318-23. [pmid: 15049932].
86 Koenig W, Lowel H, Baumert J, et al. C-reactive protein modulates risk prediction based on the Framingham score, implications for future risk assessment: results from a large cohort study in southern Germany. Circulation. 2004;109(11):1349-53. [pmid: 15023871].
87 Greenland P, LaBree L, Azen SP, et al. Coronary artery calcium score combined with Framingham score for risk prediction in asymptomatic individuals. JAMA. 2004;291(2):210-5. [pmid: 14722147].
88 Brindle P, Emberson J, Lampe F, et al. Predictive accuracy of the Framingham coronary risk score in British men: prospective cohort study. BMJ. 2003;327(7426):1267. [pmid: 14644971].
89 Milne R, Gamble G, Whitlock G, et al. Discriminative ability of a risk-prediction tool derived from the Framingham Heart Study compared with single risk factors. N Z Med J. 2003;116(1185):U663. [pmid: 14615805].
90 Empana JP, Ducimetiere P, Arveiler D, et al. Are the Framingham and PROCAM coronary heart disease risk functions applicable to different European populations? The PRIME Study. Eur Heart J. 2003;24(21):1903-11. [pmid: 14585248].
91 Folsom AR, Chambless LE, Duncan BB, et al. Prediction of coronary heart disease in middle-aged adults with diabetes. Diabetes Care. 2003;26(10):2777-84. [pmid: 14514579].
92 Hense HW, Schulte H, Lowel H, et al. Framingham risk function overestimates risk of coronary heart disease in men and women from Germany—results from the MONICA Augsburg and the PROCAM cohorts. Eur Heart J. 2003;24(10):937-45. [pmid: 12714025].
93 Simons LA, Simons J, Friedlander Y, et al. Risk functions for prediction of cardiovascular disease in elderly Australians: the Dubbo Study. Med J Aust. 2003;178(3):113-6. [pmid: 12558481].
94 Bastuji-Garin S, Deverly A, Moyse D, et al. The Framingham prediction rule is not valid in a European population of treated hypertensive patients. J Hypertens. 2002;20(10):1973-80. [pmid: 12359975].
95 Suka M, Sugimori H, Yoshida K. Validity of the Framingham risk model applied to Japanese men. Methods Inf Med. 2002;41(3):213-5. [pmid: 12162145].
96 Kothari V, Stevens RJ, Adler AI, et al. UKPDS 60: risk of stroke in type 2 diabetes estimated by the UK Prospective Diabetes Study risk engine. Stroke. 2002;33(7):1776-81. [pmid: 12105351].
97 Orford JL, Sesso HD, Stedman M, et al. A comparison of the Framingham and European Society of Cardiology coronary heart disease risk prediction models in the normative aging study. Am Heart J. 2002;144(1):95-100. [pmid: 12094194].
98 Suka M, Sugimori H, Yoshida K. Application of the updated Framingham risk score to Japanese men. Hypertens Res. 2001;24(6):685-9. [pmid: 11768728].
99 Grover SA, Dorais M, Paradis G, et al. Lipid screening to prevent coronary artery disease: a quantitative evaluation of evolving guidelines. CMAJ. 2000;163(10):1263-9. [pmid: 11107461].
100 Detrano RC, Wong ND, Doherty TM, et al. Coronary calcium does not accurately predict near-term future coronary events in high-risk adults. Circulation. 1999;99(20):2633-8. [pmid: 10338455].
101 Paynter NP, Chasman DI, Buring JE, et al. Cardiovascular disease risk prediction with and without knowledge of genetic variation at chromosome 9p21.3. Ann Intern Med. 2009;150(2):65-72. [pmid: 19153409].
102 de Ruijter W, Westendorp RG, Assendelft WJ, et al. Use of Framingham risk score and new biomarkers to predict cardiovascular mortality in older people: population based observational cohort study. BMJ. 2009;338:a3083. [pmid: 19131384].
103 C-reactive protein and parental history improve global cardiovascular risk prediction: the Reynolds Risk Score for men. Circulation. 2008;118(22):2243-51. [pmid: 18997194].
104 Becker A, Leber AW, Becker C, et al. Predictive value of coronary calcifications for future cardiac events in asymptomatic patients with diabetes mellitus: a prospective study in 716 patients over 8 years. BMC Cardiovasc Disord. 2008;8:27. [pmid: 18847481].
105 Mainous AG 3rd, Everett CJ, Player MS, et al. Importance of a patient's personal health history on assessments of future risk of coronary heart disease. J Am Board Fam Med. 2008;21(5):408-13. [pmid: 18772295].
106 Scheltens T, Verschuren WM, Boshuizen HC, et al. Estimation of cardiovascular risk: a comparison between the Framingham and the SCORE model in people under 60 years of age. Eur J Cardiovasc Prev Rehabil. 2008;15(5):562-6. [pmid: 18756178].
107 Cederholm J, Eeg-Olofsson K, Eliasson B, et al. Risk prediction of cardiovascular disease in type 2 diabetes: a risk equation from the Swedish National Diabetes Register. Diabetes Care. 2008;31(10):2038-43. [pmid: 18591403].
108 Elkeles RS, Godsland IF, Feher MD, et al. Coronary calcium measurement improves prediction of cardiovascular events in asymptomatic patients with type 2 diabetes: the PREDICT Study. Eur Heart J. 2008;29(18):2244-51. [pmid: 18573867].
109 Assmann G, Schulte H, Seedorf U. Cardiovascular risk assessment in the metabolic syndrome: results from the Prospective Cardiovascular Münster (PROCAM) Study. Int J Obes (Lond). 2008;32(Suppl 2):S11-6.
110 Vergnaud AC, Bertrais S, Galan P, et al. Ten-year risk prediction in French men using the Framingham coronary score: results from the national SU.VI.MAX cohort. Prev Med. 2008;47(1):61-5. [pmid: 18456313].
111 Wu Y, Liu X, Li X, et al. Estimation of 10-year risk of fatal and nonfatal ischemic cardiovascular diseases in Chinese adults. Circulation. 2006;114(21):2217-25. [pmid: 17088464].
112 Conroy RM, Pyorala K, Fitzgerald AP, et al. Estimation of ten-year risk of fatal cardiovascular disease in Europe: the SCORE Project. Eur Heart J. 2003;24(11):987-1003. [pmid: 12788299].
113 Hingorani AD, Vallance P. A simple computer program for guiding management of cardiovascular risk factors and prescribing. BMJ. 1999;318(7176):101-5. [pmid: 9880285].
114 Pyorala K, De Backer G, Graham I, et al. Prevention of coronary heart disease in clinical practice: recommendations of the Task Force of the European Society of Cardiology, European Atherosclerosis Society and European Society of Hypertension. Eur Heart J. 1994;15(10):1300-31. [pmid: 7821306].
115 Dyslipidaemia Advisory Group; on behalf of the Scientific Committee of the National Heart Foundation of New Zealand. 1996 National Heart Foundation Clinical Guidelines for the assessment and management of dyslipidaemia. N Z Med J. 1996;109(1024):224-31. [pmid: 8769031].
116 Daniels LB, Laughlin GA, Clopton P, et al. Minimally elevated cardiac troponin T and elevated N-terminal pro-B-type natriuretic peptide predict mortality in older adults: results from the Rancho Bernardo Study. J Am Coll Cardiol. 2008;52(6):450-9. [pmid: 18672166].
117 Using nontraditional risk factors in coronary heart disease risk assessment: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2009;151(7):474-82. [pmid: 19805770].
118 Helfand M, Buckley DI, Freeman M, et al. Emerging risk factors for coronary heart disease: a summary of systematic reviews conducted for the U.S. Preventive Services Task Force. Ann Intern Med. 2009;151(7):496-507. [pmid: 19805772].
119 Stevens RJ, Kothari V, Adler AI, et al. The UKPDS risk engine: a model for the risk of coronary heart disease in type II diabetes (UKPDS 56). Clin Sci (Lond). 2001;101(6):671-9. [pmid: 11724655].
120 Fowkes FG, Murray GD, Butcher I, et al. Ankle brachial index combined with Framingham risk score to predict cardiovascular events and mortality: a meta-analysis. JAMA. 2008;300(2):197-208. [pmid: 18612117].
121 Ecological analysis of the association between mortality and major risk factors of cardiovascular disease: the World Health Organization MONICA Project. Int J Epidemiol. 1994;23(3):505-16. [pmid: 7960374].
122 The Lipid Research Clinics Coronary Primary Prevention Trial results, I: reduction in incidence of coronary heart disease. JAMA. 1984;251(3):351-64. [pmid: 6361299].
123 Flack JM, Neaton J, Grimm R Jr, et al. Blood pressure and mortality among men with prior myocardial infarction. Circulation. 1995;92(9):2437-45. [pmid: 7586343].
124 Frick MH, Elo O, Haapa K, et al. Helsinki Heart Study: primary-prevention trial with gemfibrozil in middle-aged men with dyslipidemia. N Engl J Med. 1987;317(20):1237-45. [pmid: 3313041].
125 Shepherd J, Cobbe SM, Ford I, et al. Prevention of coronary heart disease with pravastatin in men with hypercholesterolemia. N Engl J Med. 1995;333(20):1301-7. [pmid: 7566020].
126 Stamler J, Stamler R, Neaton JD. Blood pressure, systolic and diastolic, and cardiovascular risks: US population data. Arch Intern Med. 1993;153(5):598-615. [pmid: 8439223].
127 Stamler J, Wentworth D, Neaton JD. Is relationship between serum cholesterol and risk of premature death from coronary heart disease continuous and graded? Findings in 356,222 primary screenees of the Multiple Risk Factor Intervention Trial (MRFIT). JAMA. 1986;256(20):2823-8. [pmid: 3773199].
128 Vasan RS, Larson MG, Leip EP, et al. Impact of high-normal blood pressure on the risk of cardiovascular disease. N Engl J Med. 2001;345(18):1291-7. [pmid: 11794147].
129 Grundy SM, Pasternak R, Greenland P, et al. Assessment of cardiovascular risk by use of multiple-risk-factor assessment equations: a statement for healthcare professionals from the American Heart Association and the American College of Cardiology. Circulation. 1999;100(13):1481-92. [pmid: 10500053].
130 Smith SC Jr, Blair SN, Bonow RO, et al. AHA/ACC Guidelines for preventing heart attack and death in patients with atherosclerotic cardiovascular disease: 2001 update. J Am Coll Cardiol. 2001;38(5):1581-3. [pmid: 11691544].
131 Yeo WW, Yeo KR. Predicting CHD risk in patients with diabetes mellitus. Diabet Med. 2001;18(5):341-4. [pmid: 11472442].
132 Adlerberth AM, Rosengren A, Wilhelmsen L. Diabetes and long-term risk of mortality from coronary and other causes in middle-aged Swedish men: a general population study. Diabetes Care. 1998;21(4):539-45. [pmid: 9571339].
133 Stamler J, Vaccaro O, Neaton JD, et al. Diabetes, other risk factors, and 12-yr cardiovascular mortality for men screened in the Multiple Risk Factor Intervention Trial. Diabetes Care. 1993;16(2):434-44. [pmid: 8432214].
134 Hanley JA, McNeil BJ. The meaning and use of the area under a receiver operating characteristic (ROC) curve. Radiology. 1982;143(1):29-36. [pmid: 7063747].
135 Lemeshow S, Hosmer DW Jr. A review of goodness of fit statistics for use in the development of logistic regression models. Am J Epidemiol. 1982;115(1):92-106. [pmid: 7055134].
136 Anderson KM, Wilson PW, Odell PM, et al. An updated coronary risk profile: a statement for health professionals. Circulation. 1991;83(1):356-62. [pmid: 1984895].
137 Updated Strategies and Therapies for Reducing Ischemic and Vascular Events (STRIVE) ST-segment elevation myocardial infarction critical pathway toolkit. Crit Pathw Cardiol. 2008;7(4):223-31. [pmid: 19050418].
138 The Multiple Risk Factor Intervention Trial (MRFIT): a national study of primary prevention of coronary heart disease. JAMA. 1976;235(8):825-7. [pmid: 946311].
139 Napier JA. Field methods and response rates in the Tecumseh Community Health Study. Am J Public Health Nations Health. 1962;52:208-16. [pmid: 14478347].
140 Thomsen TF, McGee D, Davidsen M, et al. A cross-validation of risk-scores for coronary heart disease mortality based on data from the Glostrup Population Studies and Framingham Heart Study. Int J Epidemiol. 2002;31(4):817-22. [pmid: 12177028].
141 Andresdottir MB, Sigurdsson G, Sigvaldason H, et al. Fifteen percent of myocardial infarctions and coronary revascularizations explained by family history unrelated to conventional risk factors. Eur Heart J. 2002;23(21):1655-63. [pmid: 12398822].
142 Lumley T, Kronmal RA, Cushman M, et al. A stroke prediction score in the elderly: validation and Web-based application. J Clin Epidemiol. 2002;55(2):129-36. [pmid: 11809350].