# Results

## Yield of Literature Searches

Figure 1 presents the yield and results from the searches. In addition to the articles identified through the primary literature search, a number of articles were identified via hand-searching the reference lists of included articles. Therefore, we began with a yield of 3,499 articles, but retained only 84 articles29, 34-82, 14, 19, 23-25, 83-110,111 that we determined were relevant to the key questions and met the inclusion/exclusion criteria.

Figure 1 Yield of Literature

* The number of articles excluded exceeds the total number of articles in each category because most of the articles fit into multiple exclusion categories.

Figure 1 presents the yield and results from our searches. We retrieved 3,499 non-duplicate citations. We reviewed the full text of 636 articles and included 84 articles. Of the 552 articles excluded at the full-text review phase, 164 were excluded because they were not relevant to the topic. Among these 164, one was excluded because the study was a post-percutaneous coronary intervention, four because the study was about post-coronary artery bypass graft, 18 because they covered diagnostic tools, 58 because they covered prognostic tools, 56 because the studies were etiologic, and 304 because they did not cover a risk tool. Also, of the 552 articles excluded at the full-text review phase, 451 were excluded because the studies did not attempt to internally or externally validate the tools; 61 were excluded because they were not reporting original research; 153 were excluded because the studies were an ineligible study type; 179 were excluded because they did not report relevant outcomes for the review; 63 were excluded because the study size was less than 200; 243 were excluded because the study population was symptomatic for cardiovascular disease; and 66 were excluded because the mean study population was younger than age 18 years. The total number of articles in each category exceeds the number of articles excluded because most of the articles fit into multiple exclusion categories.

Results are divided into three primary sections: a description of all studies (primary model development and validation studies), results specific to Key Question 1, and results specific to Key Question 2.

### Definition of Relevant Outcomes

Before describing the results of the literature search, it should be noted that although the search focused entirely on CVD risk prediction, there was considerable heterogeneity in outcome definitions. The following definitions are derived from the literature and were not a priori definitions.

Hard CHD. Among the more restrictive outcomes, there were two definitions of hard CHD, including sudden CHD death and MI with or without cardiac procedures, such as coronary artery bypass graft or percutaneous coronary intervention.

Total CHD. There were three definitions of total CHD, including hard CHD outcome with unstable angina or angina pectoris.

CVA. There were six definitions of CVA, including various subsets of ischemic CVA, hemorrhagic CVA, and transient ischemic attack (Table 4a).

Table 4a Outcome Definitions for Total Coronary Heart Disease, Hard Coronary Heart Disease, and Cardiovascular Accident

| Total CHD | | | Hard CHD | | CVA
Name | 1 | 2 | 3 | 1 | 2 | 1 | 2 | 3 | 4 | 5 | 6
Ischemic stroke | | | | | | X | X | X | X | | X
Hemorrhagic stroke, all | | | | | | X | | | X | X
Hemorrhagic stroke, embolic & intracerebral | | | | | | | | | | | X
Transient ischemic attack | | | | | | | X | | X
Angina pectoris | X | | X
Unstable angina | X | X | X
Myocardial infarction | X | X | X | X | X
Intermittent claudication
Sudden CHD death | X | X | X | X | X
Cardiac procedure | | X | X | | X
Congestive heart failure

The aggregate outcome of CVD could include some or all of the candidate components from total CHD and CVA, but was required to have at least one component from each, which resulted in 19 different varieties of the CVD outcome (Table 4b). Full definitions for each variety of these outcomes are shown in Table 4b. From this point forward, any outcome mentioned will have a numerical subscript that will reference the outcome definition in Table 4b.

Table 4b Outcome Definitions for Cardiovascular Disease

| CVD
Name | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12 | 13 | 14 | 15 | 16 | 17 | 18 | 19
Ischemic stroke | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X
Hemorrhagic stroke, all | | X | | X | | | X | X | | X | X | | X | X | X | | | X | X
Hemorrhagic stroke, embolic & intracerebral | | | | | X
Transient ischemic attack | X | X | | X | | | | | X | X | X | X | X | X
Angina pectoris | X | X | | | X | X | | | X | X | X | X | X | X | | | | X
Unstable angina | X | X | | | X | X | | | X | X | X | X | X | X | | | | X | X
Myocardial infarction | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X
Intermittent claudication | | X | | | | | | | X | | | X | X | | | X | | X
Sudden CHD death | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X
Cardiac procedure | | | X | | X | | X | | X | | X | | X | | X | X | | X | X
Congestive heart failure | | X | | | | | X | | | | | X | X | X

## Description of All Studies

We examined studies in which primary models were developed as well as those in which the models were validated in other populations. Appendixes A-N provide a summary of the populations in which the models were developed, as well as the model components and performance. The summary tables are stratified by geographic location and, where appropriate, by sex. The intent is to describe the transition in the model populations as well as the models themselves in order to best consider their applicability to current patient populations. All tables are organized in order of cohort enrollment date, so that the earliest formed cohorts are first and the newest formed cohorts are last. Changes in issues such as population prevalence of disease over time suggest that it is important to consider the original cohort enrollment and end dates that serve as the basis for any model used by clinicians today.

A total of 84 papers29, 34-82,14, 19, 23-25, 83-110,111 were included in this review, representing a total of 102 risk prediction models. To develop the models, the authors used a total of 100 variations of 73 identifiable patient cohorts. These cohorts provided data on CHD outcomes (52 cohorts), CVD outcomes (31 cohorts), and CVA outcomes (12 cohorts). The results describe the cohorts that were used in the modeling literature, followed by the models themselves, in each case focusing on those with external validation first.

### Primary Model Development

Overview of cohorts. The original description of each of the data sources used in the development of these primary risk prediction models is available in Appendix E/Summary Table 2 (note that each of the cohorts could have been used to develop or assess multiple models).

In some cases, different subsets of a larger cohort were used in the models that we identified (e.g., multiple subsets of the Atherosclerosis Risk in Communities [ARIC] cohort were used to develop risk models in the United States), and we list each of these subcohorts separately. In total, there were 57 cohorts or subcohorts used to develop primary models.14, 19, 23-25, 34-42, 46, 47, 49-52, 54-64, 71, 72, 75, 76, 78, 80, 81, 83, 84, 87, 91, 94, 100, 102, 105, 107, 109, 110 Cohort inception ranged from 1954 to 1999. Of these, 27 were in the Americas (United States and Puerto Rico), 24 were in Europe, and five were in Asia.

A few large studies provide the majority of the available cohorts and subcohorts. For example, six distinct variants or subcohorts of the ARIC study were used to develop primary models with a cardiovascular outcome. Similarly, two subcohorts from the Women's Health Study (WHS) were used in model development. The subcohorts vary in start and end dates, and other population descriptors, such as cardiovascular risk factors or sex.

In Europe, three variants of the QRESEARCH database, two variants of the Uppsala Longitudinal Study of Adult Men (ULSAM), and two variants of the Prospective Cardiovascular Münster (PROCAM) cohort were used in the development of primary models. Cohort size ranged from 229 to 2,285,815, and follow-up ranged from 3.36 to 28.7 years. In Asia, two cohorts had their genesis in the Hong Kong Diabetes (HKD) Registry. Cohort size ranged from 7,067 to 1,223,740, and follow-up ranged from 5.37 to 13 years.

Substantial variation is evident across the populations or subcohorts used to develop models. Appendix F/Summary Table 3 provides an overview of the characteristics of individuals in each of the populations or subcohorts used for model development. We abstracted data on the population variables that we would expect to be presented, but as is clear from the table, there were significant missing data in the articles. We further stratified these data by geographic area and sex.

Description of cohorts. In the 27 American cohorts,19, 23-25, 34, 37, 39, 42, 49, 51, 52, 54, 61, 62, 75, 81, 87, 91, 100, 105 the average age ranged from 29.8 to 69.4 years (Appendix F/Summary Table 3). Twenty-six cohorts were comprised of all men19, 23-25, 37, 39, 42, 49, 51, 52, 62, 75, 81, 105 and 20 were comprised of all women.19, 23, 24, 37, 39, 42, 51, 52, 62, 75, 105 In those cohorts with both sexes, the proportion of women ranged from 10.2 to 62.6 percent.

The 26 cohorts19, 23-25, 37, 39, 42, 49, 51, 52, 62, 75, 81, 105 of American men were developed from seven distinct studies. The populations ranged in average age from 25 to 69.7 years. Prevalence of smokers ranged from 12 to 59.7 percent. Men with diabetes were represented in six studies; the proportion with diabetes ranged from 3.56 to 42 percent. The proportion of male participants with hypertension ranged from 13 to 61 percent when hypertension was measured by increased blood pressure and from 6.8 to 35.2 percent when it was measured by medication use.

There were 11 studies used to develop the 24 cohorts of American women.19, 23, 24, 37, 39, 42, 51, 52, 62, 75, 105 The populations studied ranged in average age from 46.1 to 69.3 years. The prevalence of smokers ranged from 15 to 48.5 percent. Women with diabetes were represented in six of the studies; the proportion with diabetes ranged from 4 to 51 percent. The proportion of female participants with hypertension in these studies ranged from 11 to 62.5 percent when hypertension was measured by increased blood pressure and from 10.7 to 51.7 percent when it was measured by medication use.

In 23 European cohorts,35, 36, 41, 46, 50, 56, 58-60, 63, 64, 71, 72, 76, 78, 80, 84, 94, 102, 104, 107, 109, 110 the average age ranged from 46.7 to 71 years. Nine cohorts were comprised of all men35, 36, 46, 58, 59, 78, 107 and 10 were comprised of all women.35, 36, 46, 58, 59, 78, 107 In those cohorts with both sexes, the proportion of women ranged from 29.4 to 75.4 percent.

The 10 cohorts35, 36, 46, 58, 59, 78, 107 of European men used in primary model development were derived from seven studies. The populations studied ranged in average age from 47 to 58.3 years. The prevalence of smokers ranged from 18.5 to 43.8 percent. Men with diabetes were represented in four cohorts;59, 78, 107 the proportion with diabetes ranged from 1.5 to 18.8 percent in those studies not exclusively of patients with diabetes.58, 59 Two cohorts78, 107 consisted only of men with diabetes. The proportion of male participants with hypertension was reported in one study58 (41.6 percent) when hypertension was measured by increased blood pressure, and ranged from 0.1 to 29.7 percent when it was measured by medication use.35, 58

The 10 cohorts of European women35, 36, 46, 58, 59, 78, 107 used for primary model development were derived from eight studies. The populations studied ranged in average age from 48.8 to 57.6 years. The proportion of smokers among participants was reported for three cohorts35, 58, 107 and ranged from 10.6 to 23.1 percent. Women with diabetes were represented in five cohorts, two of which consisted entirely of patients with diabetes;78, 107 the proportion with diabetes among the other studies ranged from 1.3 to 14.6 percent. The proportion of participants with hypertension was reported in one study58 (47.2 percent) when hypertension was measured by increased blood pressure, and ranged from 6.9 to 33.7 percent when it was measured by medication use.35, 46

In the eight Asian cohorts,38, 47, 55, 57, 83 the average age ranged from 46.6 to 68 years. Three cohorts were comprised of all men47, 55, 83 and three were comprised of all women.47, 55, 83 In those cohorts with both sexes, the proportion of women ranged from 36.5 to 54.6 percent.

Three cohorts of Asian men were represented in the literature.47, 55, 83 The populations studied ranged in average age from 45 to 47 years. The prevalence of smokers ranged from 59 to 68.4 percent. Men with diabetes were represented in two studies; the proportion with diabetes ranged from 4.8 to 6.9 percent. The proportion of participants with hypertension reported in two Asian male cohorts was 29 percent83 and 35.7 percent47 when hypertension was measured by increased blood pressure, and was not reported as a measure based on medication use.

There also were three cohorts of Asian women.47, 55, 83 The populations studied ranged in average age from 46 to 49 years. The prevalence of smokers ranged from 4 to 6.5 percent. Women with diabetes were represented in two studies; the proportion with diabetes ranged from 4.1 to 5 percent. The reported proportion of participants with hypertension in the cohorts was 22 percent83 and 29.2 percent47 when hypertension was measured by increased blood pressure, and was not reported as a measure based on medication use.

Models with external validations. Of the 102 models identified through the literature search, only 17^14, 18, 19, 23, 25, 46, 59, 63, 96, 112, 136^ were externally validated in a population other than the one in which the model was developed (Table 5). These models were all developed from the following nine primary patient cohorts:

- Scottish Heart Health Extended Cohort (SHHEC)
- Diabetes Audit and Research in Tayside, Scotland (DARTS)
- FINRISK
- Framingham Study (FRS)
- Framingham Offspring Study (FRS-O)
- Prospective Cardiovascular Münster Study (PROCAM)
- QRESEARCH Database
- Systematic Coronary Risk Evaluation (SCORE)
- United Kingdom Prospective Diabetes Study (UKPDS)

Table 5 Externally Validated Models

Model Name | Model Outcome | Year Published | Study Count | Cohort Abbreviation | Enroll Start Date | Enroll End Date | Enrollment | Followup^*^
ASSIGN59 | CVD_11_ | 2007 | 2 | SHHEC | 01/01/1984 | 12/31/1995 | 13,297
FINRISK74 | CVD | 2005 | 4 | FINRISK | | | 14,694
FRS (Anderson)18, 136 | CVD_2_ | 1991 | 21 | FRS, FRS-O | 01/01/1948 | 12/31/1975 | 5,573 | 12
FRS (Anderson)18, 136 | Total CHD_1_ | 1991 | 8 | FRS, FRS-O | 01/01/1948 | 12/31/1975 | 5,573 | 12
FRS (Anderson)18, 136 | Myocardial infarction | 1991 | 1^*^ | FRS, FRS-O | 01/01/1948 | 12/31/1975 | 5,573 | 12
FRS (Anderson)18, 136 | Sudden CHD death | 1991 | 1^*^ | FRS, FRS-O | 01/01/1948 | 12/31/1975 | 5,573 | 12
QRISK46 | CVD_4_ | 2007 | 4 | QRESEARCH | 01/01/1995 | 04/01/2007 | 614,553 | 6.5
SCORE112 High Risk TC Low Risk TC | CVD mortality | 2003 | 11 | SCORE | | | 205,178
FRS (Wilson)19 LDL TC | Total CHD_1_ | 1998 | 23 | FRS, FRS-O | 01/01/1948 | 12/31/1974 | 5,345 | 12
FRS (TC)19 | Hard CHD_1_ | 2001 | 8 | FRS, FRS-O | 01/01/1948 | 12/31/1974 | 5,345 | 12
FRS (ATP-III)23 | Hard CHD_1_ | 2001 | 16 | FRS, FRS-O
PROCAM14 | Hard CHD_1_ | 2002 | 11 | PROCAM | 01/01/1979 | 12/31/1985 | 5,159 | 10
UKPDS 56^96^ | Hard CHD_1_ | 2001 | 5 | UKPDS | | | 4,540
DARTS63 | Hard CHD_1_ | 2006 | 2 | DARTS | 01/01/1995 | 06/30/2004 | 4,569 | 4.1
FRS (4 variants)25 | CHD mortality | 1999 | 3 | FRS | 01/01/1954 | 12/31/1958 | 4,169 | 24
FRS18, 136 | Stroke_4_ | 1991 | 3 | FRS, FRS-O | 01/01/1948 | 12/31/1975 | 5,573 | 12
UKPDS 60^96^ | Stroke_1_ | 2002 | 2 | UKPDS | 01/01/1977 | 12/31/1991 | 4,549 | 10.5

* Followup measured in months.

A description of these nine cohorts is available in Appendix G/Summary Table 4. Models with external validation data were more likely to be used for individual prediction.

The five most common externally validated risk models (among the 11 total) were:

- 1991 FRS model for CVD_2_ (with 21 evaluations)
- 1998 FRS model for total CHD_1_ (with 23 evaluations)
- FRS ATP-III model for hard CHD_1_ (with 16 evaluations)
- PROCAM model for hard CHD_1_ (with 11 evaluations)
- SCORE model for CVD mortality (with 11 evaluations)

The externally validated models are typically considered general population, first-outcome incidence calculators, meaning that they were developed using mixed cohorts of patients meant to be representative of a given geographic area. However, it is important to note that the FRS ATP-III model excludes patients with diabetes, the PROCAM model excludes women, the DARTS and UKPDS models exclude patients without diabetes, and the ASSIGN model (derived from SHHEC) includes a non-traditional social deprivation index as a risk factor. Therefore, they are not entirely applicable in all general populations.

All of the FRS models were developed from the original and/or offspring cohorts of the Framingham Study in the United States. The DARTS, ASSIGN, QRESEACH, and UKPDS models were developed from U.K. patients. The PROCAM model was developed from German patients. The SCORE model was developed from patients in 12 European countries, and the FINRISK model was developed from Finnish patients (and is included as one of the 12 countries in the SCORE model).

Models without external validation. The majority of models (87 out of 102) identified through our search have never been validated in an external data set.14, 18, 19, 25, 34-39, 41, 47, 49, 51, 52, 54-57, 60-62, 71, 75, 76, 78, 80, 81, 83, 84, 87, 91, 93, 100, 101, 103, 107, 109, 111, 112, 114, 115, 136 In many cases, these represent a subset of studies in which variables were simply added or deleted to assess any change. These are unlikely to ever be used in risk prediction, but because they met inclusion criteria, they are included here. Among the 87 models without any external cohort validation, eight used variants in risk factors or outcomes or were temporal updates from well-known cohorts with externally validated risk models (Table 6).23, 35, 41, 81, 112

Table 6 Risk Models Without External Validation That Are Risk Factor Variants, Outcome Variants, or Temporal Updates From Well-Known Cohorts With Externally Validated Risk Models

Model Name | Model Outcome | Year Published | Cohort Abbreviation | Enroll Start Date | Enroll End Date | Enrollment | Followup^*^
FRS (D'Agostino)23 | CVD_2_ | 2008 | FRS, FRS-O | 01/01/1968 | 12/31/1987 | 8,491
QRISK2^35^ | CVD_1_ | 2008 | QRESEARCH | 01/01/1993 | 03/31/2008 | 2,285,815 | 15
SCORE112 High Risk TC-HDL Ratio Low Risk TC-HDL Ratio | CVD Mortality | 2003 | SCORE | | | 205,178
PROCAM41 | Stroke_2_ | 2007 | PROCAM | 01/01/1978 | 12/31/1995 | 7,295 | 12
ARIC81 Basic Basic + Age + Race Basic + NTRF + Age + Race | Stroke_3_ | 2004 | ARIC | 01/01/1987 | 12/31/1989 | 13,161 | 12.3

* Followup measured in months.

Two models were developed as point score simplifications or evaluations of risk modeling methods other than the Cox proportional hazards model (Table 7).14, 41

Table 7 Risk Models Without External Validation That Are Point Score Simplifications or Evaluations of Modeling Methods Other Than Cox Proportional Hazards

Model Name | Model Outcome | Year Published | Cohort Abbreviation | Enroll Start Date | Enroll End Date | Enrollment | Followup^*^
PROCAM (Point score)14 | Hard CHD_1_ | 2002 | PROCAM | 01/01/1979 | 12/31/1985 | 5,159 | 10
PROCAM (Weibull model)41 | Hard CHD_1_ | 2007 | PROCAM | 01/01/1978 | 12/31/1995 | 7,295 | 12

* Followup measured in months.

Ten were developed to compare or improve model performance between a new local model and external validations of more established models,51, 54, 56, 76, 78, 80, 103, 114, 115 and 57 were developed in order to evaluate candidate variables for risk model inclusion (Table 8).34, 36, 37, 50, 54, 60, 61, 71, 75, 80, 81, 84, 87, 91, 100, 101, 103, 109

Table 8 Risk Models Without External Validation That Compare or Improve Model Performance Between a New Local Model and External Validation of More Established Models

Model Name | Model Outcome | Year Published | Cohort Abbreviation | Enroll Start Date | Enroll End Date | Enrollment | Followup^*^
CRM78 | CVD | 1999 | NHS Trust | 01/01/1990 | 12/31/1991 | 798
New Zealand Risk Charts115 | CVD_2_ | 1996
Reynolds Risk Score (Men)103 Model A RRS + CRP + FamHx | CVD_15_ | 2008 | PHS-II | 12/01/1995 | | 10,724 | 10.8
Reynolds Risk Score (Women)54,56 Model A Model B, Clinically Simplified | CVD_3_ | 2007 | WHS (Val) | 09/01/1992 | | 8,158 | 10.2
JBSRC78 | CVD | 1998 | NHS Trust | 01/01/1990 | 12/31/1991 | 798
European Society of Cardiology114 | Total CHD_1_ | 1994 | FRS, FRS-O | 01/01/1948 | 12/31/1975 | 5,573 | 12
CUORE76 | Hard CHD_2_ | 2005 | CUORE | 01/01/1983 | 12/31/1996 | 6,865 | 9.1
Personal HEART51 | Hard CHD_2_ | 2007 | ARIC | 01/01/1987 | 12/31/1989 | 14,343
ULSAM80 | MI | 2004 | ULSAM | 01/01/1970 | 12/31/1973 | 1,108 | 28.7

* Followup measured in months.

Five models were developed to evaluate the heterogeneity of risk factors between cohorts (Table 9).18, 25, 55, 136

Table 9 Risk Models Without External Validation That Evaluate the Heterogeneity of Risk Factors Between Cohorts

Model Name | Model Outcome | Year Published | Cohort Abbreviation | Enroll Start Date | Enroll End Date | Enrollment | Followup^*^
NHANES I (4 variable)25 | CHD mortality | 1999 | NHANES I | 01/01/1971 | 12/31/1975 | 6,611 | 20
NHANES I & II, pooled25 | CHD mortality | 1999 | NHANES I & II | | | 18,542
NHANES II (4 variable)25 | CHD mortality | 1999 | NHANES II | 01/01/1976 | 12/31/1980 | 5,705 | 15
FRS CHD Mortality (4 variable)18, 136 | CHD mortality | 1991 | FRS, FRS-O | 01/01/1948 | 12/31/1975 | 5,573 | 12
FRS (Barzi)55 | CVD_8_ | 2007 | FRS, FRS-O | 01/01/1948 | 12/31/1974 | 5,345 | 12

* Followup measured in months.

Twelve models were developed to address specific patient populations, such as elderly patients,93 young patients,49 patients with diabetes,38, 57, 78, 107 Asian populations,38, 47, 57, 83, 111 patients with atrial fibrillation,52 and Native American populations62 (Table 10).

Table 10 Risk Models Without External Validation That Address Specific Patient Populations Known to Perform Poorly in the Most Widely Used Models

Model Name | Model Outcome | Year Published | Cohort Abbreviation | Enroll Start Date | Enroll End Date | Enrollment | Followup^*^
Dubbo93 | CVD_4_ | 2003 | Dubbo-All | 01/01/1988 | | 2,102
USA-PRC111 Point Scoring Simplified | CVD_17_ | 2006 | USA-PRC | 09/01/1983 | 10/31/1984 | 9,903 | 15.1
CRM78 | CVD | 1999 | NHS Trust | 01/01/1990 | 12/31/1991 | 798
Swedish NDR107 | CVD_5_ | 2008 | Swedish NDR | 01/01/1998 | 12/31/2003 | 11,646 | 5.64
Hong Kong Diabetes Score38 | Total CHD_1_ | 2008 | HKD Registry | 01/01/1995 | | 7,067 | 5.4
Miyasaka Post-AF52 | Total CHD_1_ | 2007 | Mayo | 01/01/1980 | 12/31/2000 | 2,768 | 6
CMCS83 | Hard CHD_1_ | 2004 | MUCA | 01/01/1992 | 12/31/1999 | 30,121
SHS Model62 | Hard CHD_1_ | 2006 | SHS | 01/01/1989 | 12/01/2001 | 4,372
Chicago Young Adults49 | CHD mortality | 2007 | CHA | 01/01/1967 | 01/31/1973 | 10,375 | 32
Hong Kong Diabetes Score57 | Stroke_1_ | 2007 | HKD Registry | 01/01/1995 | 07/30/2005 | 3,541 | 5.37
Korean Stroke Risk Prediction47 | Stroke_6_ | 2008 | NHIC | 01/01/1992 | 12/31/1995 | 1,205,268 | 13

* Followup measured in months.

### Model Validation Studies

Cohort descriptions. Appendix I/Summary Table 6 provides an overview of the data sources used to validate the various models described in this report.29, 35, 43-45, 48, 53, 54, 63, 65-70, 73, 74, 77, 79, 82, 85, 86, 88-90, 92, 93, 95-99, 101, 104, 106, 108 Cohort inception ranged from 1972 to 2000. Of the validation cohorts identified, nine were in the Americas (United States and Canada),45, 53, 54, 70, 79, 96, 97, 99, 101 26 were in Europe (including Australia and New Zealand),29, 35, 44, 48, 63, 65-69, 73, 77, 82, 85, 86, 88-90, 92, 104, 106, 108 and four were in Asia.74, 95, 98 Cohort size ranged from 230 to 1,072,800, and follow-up ranged from 3.3 to 21.3 years.

Details on the populations used for validation studies are presented in Appendix J/Summary Table 7. These details are intended to provide an overview of the characteristics of individuals in cohorts that form the basis for the validation studies. Similarly to the data on primary model development, we abstracted data on the population variables that we would expect to be presented, but as is clear from the validation data tables, there were significant missing data in the articles. We further stratified these data by geographic area and sex.

In the American cohorts,45, 53, 54, 70, 79, 96, 97, 99, 101 the average age ranged from 52 to 64.7 years. Three cohorts were comprised of all men45, 99, 103 and two were comprised of all women.45, 99 In the cohorts with both sexes, the proportion of women ranged from 33 to 61.8 percent. The proportion of individuals with diabetes ranged from 2.9 to 14 percent in the cohorts that were not exclusively patients with diabetes; one cohort consisted of patients with diabetes only.96

Three cohorts of American men were identified in validation studies.45, 99, 103 These cohorts ranged in average age from 50.8 to 65.8 years. The prevalence of smokers ranged from 3.2 to 35.4 percent. Patients with diabetes were represented in two cohorts, with 4.7 percent in one and 14.6 percent in the other. The proportion of participants with hypertension was only reported in one male cohort (35.5 percent)45 when hypertension was measured by increased blood pressure, and was not reported as a measure based on medication use.

There were three cohorts of American women used to validate risk models.45, 99 The populations studied ranged in average age from 52.6 to 64 years. The prevalence of smokers ranged from 18.2 to 27.2 percent. Patients with diabetes were represented in two of the cohorts, with 4.2 percent in one and 13.7 percent in the other. The proportion of participants with hypertension was only reported in one female cohort (28.4 percent)45 when hypertension was measured by increased blood pressure, and was not reported as a measure based on medication use.

In the European cohorts, the average age ranged from 34.4 to 71.1 years. Twenty-two cohorts were comprised of all men35, 43, 44, 66-68, 74, 77, 85, 86, 92, 104, 106 and 15 were comprised of all women.35, 43, 44, 48, 66-68, 74, 77, 85, 92, 104, 106 Overall, among those cohorts with both sexes, the proportion of women ranged from 27 to 58 percent.

In the 22 cohorts of European men used in the validation studies, the average age ranged from 32.8 to 68.5 years. The prevalence of smokers ranged from 24 to 83.7 percent. Patients with diabetes were represented in 16 cohorts; the proportion with diabetes ranged from 1.4 to 12 percent. The proportion of male participants with hypertension was reported by two studies (8 percent106 and 75 percent67) when measured by increased blood pressure and was also reported by two studies (6.6 and 8 percent) when it was measured by medication use.43

Validation studies were conducted in 15 cohorts of European women. The populations studied ranged in average age from 36.1 to 71.1 years. The proportion of smokers among participants ranged from 16.7 to 71 percent. Patients with diabetes were represented in eight cohorts; the proportion with diabetes ranged from 1 to 16 percent. The proportion of female participants with hypertension ranged from 6 to 55 percent when hypertension was measured by increased blood pressure and from 10.5 to 12.1 percent when it was measured by medication use.

The average age in the Asian cohorts was 44.7 years. Three cohorts were comprised of all men74 and three were comprised of all women. 74 The three distinct cohorts of Asian men were all derived from the Newcastle Heart Project (NHP), with foci on different subgroups (Pakistan, India, and South Asia). Age and proportion of smokers were not reported. The proportion of men with diabetes ranged from 16 to 26 percent. No hypertension data was reported for the three male cohorts. All three cohorts of Asian women were also similarly derived from the NHP study. 74 Age and percentage of smokers were not reported. The proportion of women with diabetes ranged from 16 to 28 percent.

Model performance characteristics. Appendix K/Summary Table 8 presents performance data (discrimination and calibration) on all of the models assessed (both primary and validation). There were a total of 260 instances of CHD and CVD model testing in a cohort, including both model development cohorts and external validation cohorts. The studies resulted in an AUC ranging from 0.52 to 0.88. There were 71 studies that reported Hosmer-Lemeshow goodness-of-fit statistics, and among these, 55 percent were adequately calibrated. We describe these data here by region and by whether the data reflect internal or external validation.

Americas – internal validation. Model performance characteristics were variably reported for each of the models (Table 11). In most cases, the older, well-validated models did not report AUC-type statistics for internal validation. Among those models developed in the Americas, the internally validated AUC measurement or C statistic ranged from 0.63 to 0.84. It should be noted that many of these were studies in which the main focus was to explore the potential impact of a set of variables. Among those models intended to be “finished” products for external consumption, internally validated AUC-type statistics ranged from 0.65 to 0.83. The total cholesterol and low-density lipoprotein variants of the Wilson FRS model for total CHD_1_ both reported a C statistic of 0.74 for men and 0.77 for women.19 An outcome update for 5-year hard CHD_1_ for the total cholesterol version of the Wilson FRS model reported an AUC of 0.79 for men and 0.83 for women.23 An updated FRS model adapted to point scores by D'Agostino and colleagues for 12-year CVD_2_ reported a C statistic of 0.76 for men and 0.79 for women.120 The Reynolds Risk Score for women developed from the WHS cohort for 10-year CVD_3_ was measured to have a C statistic of 0.81.^54^ The Reynolds Risk Score for men developed from the Physicians' Health Study II cohort for 10-year CVD_15_ was measured to have a C statistic of 0.71.^103^ The Personal Heart Early Assessment Risk Tool (HEART) score for hard CHD_2_ developed from the ARIC cohort was measured to have an AUC of 0.65 for men and 0.79 for women.51 The Strong Heart Study (SHS) model developed from the SHS cohort for hard CHD_1_ was measured to have a C statistic of 0.70 for men and 0.73 for women.62

Table 11 Model Development Performance Characteristics (Americas): Internal Validation

Cohort Abbreviation | Outcome (Cohort/Model) | Model Name | Group Name | AUC | AUC Variance | Hosmer-Lemeshow Goodness-of-Fit | | O/E Ratio
Cohort Abbreviation | Outcome (Cohort/Model) | Model Name | Group Name | AUC | AUC Variance | | | O/E Ratio
Cohort Abbreviation | Outcome (Cohort/Model) | Model Name | Group Name | AUC | AUC Variance | χ^2^ | P | O/E Ratio
FRS-O | CVD_12_ | Wilson AFT CVD34 | All
| | Model A | | 0.78
| | Model A No BMI | | 0.78
| | Model B | | 0.80
| | Model B No BMI | | 0.80
FRS-O | Total CHD_1_ | Wilson AFT CHD34 | All
| | Model A | | 0.79
| | Model A No BMI | | 0.78
| | Model B | | 0.81
| | Model C | | 0.80
| | Model D | | 0.81
| | Model E | | 0.81
| | Model E No BMI | | 0.81
FRS-O | Stroke_2_ | Wilson AFT CeVD34 | All
| | Model A | | 0.79
| | Model A No BMI | | 0.77
| | Model B | | 0.80
| | Model C | | 0.80
| | Model D | | 0.80
| | Model D No BMI | | 0.80
FRS, FRS-O | CVD_2_ | D'Agostino CVD39 | Men | 0.76 | 0.75-0.78 | 13.5
| | | Women | 0.79 | 0.77-0.81 | 7.8
| Total CHD_1_/CVD_2_ | | Men | 0.73 | 0.71-0.75 | 18.2
| | | Women | 0.79 | 0.76-0.81 | 14.8
| Stroke_4_/CVD_2_ | | Men | 0.83 | 0.79-0.86 | 26.1
| | | Women | 0.77 | 0.72-0.82 | 5.3
| CHF/CVD_2_ | | Men | 0.84 | 0.80-0.88 | 27.2
| | | Women | 0.85 | 0.80-0.89 | 9.3
| PVD/CVD_2_ | | Men | 0.81 | 0.78-0.85 | 19.1
| | | Women | 0.83 | 0.79-0.87 | 11.3
| Hard CHD_1_ (5 yr) | FRS [TC] (Wilson)19 | Men | 0.79
| | | Women | 0.83
| Hard CHD_1_ (5 yr) | FRS Best Cox Models19 | Men | 0.79 | | 3.3
| | | Women | 0.83 | | 3.7
WHS | CVD_3_ | Reynolds Risk Score (Women)
| | Model A54 | All | 0.81
| | Model B, Clinically Simplified56 | All | 0.81
| | Model With hsCRP61 | All | 0.82
| | Model Without hsCRP61 | All | 0.81
WGHS | CVD_3_ | ATP-III Vars + Genotype101 | All | 0.81 | 0.019 | 5.96
| | RRS Vars + Genotype101 | All | 0.81 | 0.019 | 7.43
PHS-II | CVD_15_ | Reynolds Risk Score (Men)103
| | Model A | All | 0.70 | | 11.3
| | RRS + CRP + FamHx | All | 0.71 | | 12.9
| Hard CHD_2_/CVD_15_ | Reynolds Risk Score (Men)103
| | Model A | All | 0.69
| | RRS + CRP + FamHx | All | 0.70
NHANES-I | CVD_7_ | NHANES-EFS (Gaziano)37
EFS | | Lab-Based Model | Men | 0.78 | 0.77-0.80 | 6.7 | 0.57
| | Non Lab-Based Model | Men | 0.78 | 0.77-0.80 | 3.5 | 0.90
| | Lab-Based Model | Women | 0.83 | 0.81-0.85 | 6.6 | 0.58
| | Non Lab-Based Model | Women | 0.83 | 0.82-0.85 | 3.5 | 0.90
SHS | Hard CHD_1_ | SHS (Lee)62 | Men | 0.71 | | 7.18 | 0.51
| | | Women | 0.73 | | 7.25 | 0.45
SBHW | Hard CHD_1_ | Detrano-Data Derived100 | All | 0.68 | 0.05
| | Detrano-Data Derived + Ca100 | All | 0.71 | 0.04
| Hard CHD_2_ | Detrano-Data Derived100 | All | 0.69 | 0.04
| | Detrano-Data Derived + Ca100 | All | 0.72 | 0.04
| Hard CHD_1_ | FRS (ATP-III) Variables + CACS87 | All | 0.68
NHANES I | CHD mortality | NHANES I (4 Variables)25 | Men | 0.71
| | | Women | 0.81
NHANES II | CHD mortality | NHANES II (4 Variables)25 | Men | 0.75
| | | Women | 0.77
NHANES I/II | CHD death | NHANES I and II, Pooled24 | White Men | 0.77
| | | Black Men | 0.76
| | | White Women | 0.84
| | | Black Women | 0.82
ARIC | Hard CHD_2_ | Metabolic Syndrome Model75 | Men | 0.63
| | | Women | 0.73
| | Personal HEART51 | Men | 0.65 | 0.63-0.67
| | | Women | 0.79 | 0.77-0.80
| | ARIC, Basic + Liberal DM-Specific91 | DM Men | 0.67
| | | DM Women | 0.72
| | | Non-DM Men | 0.79
| | | Non-DM Women | 0.69
| | ARIC, Basic + Restrictive DM-Specific91 | DM Men | 0.75
| | | DM Women | 0.70
| | | Non-DM Men | 0.79
| | | Non-DM Women | 0.69
| | ARIC, Basic Combined91 | DM Men | 0.65
| | | DM Women | 0.71
| | ARIC, Multiple Factors + Liberal DM-Specific91 | DM Men | 0.74
| | | DM Women | 0.77
| | | Non-DM Men | 0.71
| | | Non-DM Women | 0.80
| | ARIC, DM-Specific Basic91 | DM Men | 0.68
| | | DM Women | 0.71
| | | Non-DM Men | 0.68
| | | Non-DM Women | 0.78
| | ARIC, DM-Specific Basic + Multiple Factors91 | DM Men | 0.70
| | | DM Women | 0.72
| | | Non-DM Men | 0.70
| | | Non-DM Women | 0.78
| | ARIC, DM-Specific Basic + Restrictive DM91 | DM Men | 0.72
| | | DM Women | 0.70
| Stroke_3_ | Chambless Models81
| | Basic | Men | 0.76
| | Basic | Women | 0.79
| | Basic + Age + Race | Men | 0.79
| | Basic + Age + Race | Women | 0.81
| | NTRF + Age + Race | Men | 0.80
| | NTRF + Age + Race | Women | 0.84
CHA | CHD mortality | CHA49 | Men | | | | | 0.95
Mayo | Total CHD_1_ | Miyasaka CHD Post-AF52 | Men | | | | | 0.78
| | | Women | | | | | 0.86

Note: If the cohort and model outcomes match, only one outcome is listed; otherwise both are listed. For internal model development, any cohort/model outcome mismatches are intentional to evaluate the effect of outcome mismatching on the performance of the model. O/E ratios are not relevant for internally developed models (they are all close to 1.0).

Calibration measurements were also not reported for internal validation of the older, well-validated models, and were variably reported in the newer studies as an O/E ratio, Hosmer-Lemeshow goodness-of-fit statistic, or a calibration plot, and occasionally as less common measurements, such as the Bayesian or Akaike information criterion. Internal validation of the SHS, D'Agostino CVD, 5-year hard CHD_1_ FRS, and Reynolds Risk Score for men and women all reported adequate calibration. The Personal HEART model did not report internal validation calibration measurements.

Americas – external validation. For external validation, outcomes may not exactly match between the cohort and the model. If they are matched, they are designated as such, and if they are not matched, the cohort outcomes will always be listed first (Table 12).

Table 12 Model Development Performance Characteristics (Americas): External Validation

Cohort Abbreviation | Outcome (Cohort/Model) | Model Name | Group Name | AUC | AUC Variance | Hosmer-Lemeshow Goodness-of-Fit | | O/E Ratio
Cohort Abbreviation | Outcome (Cohort/Model) | Model Name | Group Name | AUC | AUC Variance | | | O/E Ratio
Cohort Abbreviation | Outcome (Cohort/Model) | Model Name | Group Name | AUC | AUC Variance | χ^2^ | P | O/E Ratio
LRCPS | CHD mortality/Total CHD_1_ | FRS (Anderson)99 | All | 0.83 | 0.81-0.85
| | | Men | 0.83
| | | Women | 0.82
SBHW | Hard CHD_1_^*^ | FRS (Anderson)100 | All | 0.69 | 0.05
| Hard CHD_2_/Hard CHD_1_^*^ | | All | 0.67 | 0.04 | | | 1.17
ARIC | Hard CHD_1_ (5 yr) | FRS [TC] (Wilson)23 | White Men | 0.75 | | 13.8
| | | Black Men | 0.67 | | 5.3
| | | White Women | 0.83 | | 6.2
| | | Black Women | 0.79 | | 5.0
HHP | Hard CHD_1_ (5 yr) | FRS [TC] (Wilson)23 | Men | 0.72 | | 66
PRHHP | Hard CHD_1_ (5 yr) | FRS [TC] (Wilson)23 | Men | 0.69 | | 142
SHS | Hard CHD_1_ (5 yr) | FRS [TC] (Wilson)23 | Men | 0.69 | | 10.6
| | | Women | 0.75 | | 22.7
CHS | Hard CHD1 (5 yr) | FRS [TC] (Wilson)23 | Men | 0.63 | | 13.2
| | | Women | 0.66 | | 10.4
ARIC/CHS | Hard CHD_1_ (10yr) | FRS [TC] (Wilson)45 | Men | 0.60 | | 72.3 | <0.01 | 1.49
| | | Women | 0.73 | | 75.1 | <0.01 | 2.02
| Hard CHD_1_ (5yr) | | Men | 0.62 | | 33.4 | <0.01 | 1.64
| | | Women | 0.77 | | 61.2 | <0.01 | 2.73
JHSS | Total CHD_1_ | FRS [TC] (1998)42 | Men | | | 75.0 | <0.01 | 1.67
| | | Women | | | 8.0 | 0.43 | 1.13
CHA | Hard CHD_1_/Total CHD_1_ (10 yr) | FRS [TC] (1998)49 | Men | | | | | 0.05
WHI | Hard CHD_1_/Total CHD_1_ | FRS [?] (Wilson)53 | Women | 0.69
| CVD_15_/Total CHD_1_ | | Women | 0.68
SAHS | CVD_15_/Total CHD_1_ | FRS [?] (Wilson)79 | All | 0.82
NAS | Total CHD_1_ | FRS [TC] (1998)97 | All | 0.63 | | | | 0.93
ARIC | Hard CHD_2_/Hard CHD_1_ | FRS [TC] (Wilson)23 | Men | 0.69 | 0.67-0.71
| | | Women | 0.81 | 0.79-0.82
WHS | CVD_3_/Total CHD_1_ | FRS [TC] (1998)61 | Women | 0.75 | | | <0.01
| | FRS [LDL] (1998)61 | Women | 0.75 | | | <0.01
SFHS | Hard CHD_2_/Hard CHD_1_ | FRS (ATP-III)70 | All | 0.68 | 0.62-0.74
ARIC | Hard CHD_2_/Hard CHD_1_ | FRS (ATP-III)75 | Men | 0.63
| | | Women | 0.73
SBHW | Hard CHD_1_ | FRS (ATP-III)87 | All | 0.63
WHS | CVD_3_/Hard CHD_1_ | FRS (ATP-III)101 | Women | 0.79 | | | <0.01
ARIC | Hard CHD_2_/Hard CHD_1_ (6 yr) | FRS (ATP-III)75 | All | 0.72
| | | Men | 0.65
| | | Women | 0.67
CHA | Hard CHD_1_ (10 yr) | FRS (ATP-III)49 | Men | | | | | 0.07
NAS | Total CHD_1_ | European Society of Cardiology (ESC)97 | All | 0.58

* The model outcome was calculated using the sum of MI and sudden CHD death models from FRS (Anderson).

Note: If the cohort and model outcomes match, only one outcome is listed; otherwise both are listed. AUC refers to AUC or C statistic. The LRCPS study did not clearly state which FRS (Anderson) outcome it used in the study.

FRS (Anderson) model validations. This model was evaluated in the South Bay Heart Watch cohort for matched 3-year hard CHD_1_ (MI and sudden death models added together), and had an AUC of 0.69, with calibration not reported.100 The authors also evaluated the effect of outcome mismatching by evaluating 3-year hard CHD_2_/hard CHD_1_ and found a non-significant change in AUC to 0.67. The model was evaluated in the Lipid Research Clinics Prevalence Study cohort for CHD mortality/total CHD_1_, and the AUC was 0.83 in men and 0.82 in women, but the authors did not report on calibration. The outcome mismatch occurred because that cohort did not have non-fatal CHD outcomes.

FRS (Wilson) model validations. D'Agostino and colleagues evaluated five U.S. cohorts for 5-year hard CHD_1_, using the outcome-matched variant FRS Wilson model.23 This FRS model was developed in this study using the same cohort and risk variables as the Wilson models; thus, we considered it part of the Wilson family of models. Calibration was evaluated by the Hosmer-Lemeshow goodness-of-fit test, and chi-square values less than 5.5 indicate adequate calibration.

Applying the model to the ARIC cohort produced an AUC of 0.75 in white men, 0.67 in black men, 0.83 in white women, and 0.79 in black women. Calibration was adequate for each of the subcohorts as measured by the Hosmer-Lemeshow test. The ARIC cohort was also evaluated for unmatched 10-year hard CHD_2_/hard CHD_1_, and the AUC was 0.69 for men and 0.81 for women.51

Applying the model to the SHS cohort resulted in an AUC of 0.69 in Native American men and 0.75 in Native American women. Calibration was adequate for men, but inadequate (χ^2^ = 22.7) for women. On the other hand, calibration was adequate for both sexes when the model was applied to the Cardiovascular Health Study (CHS), with an AUC of 0.63 in white men and 0.66 in white women.

Use of the model in the Puerto Rico Heart Health Program (PRHHP) cohort resulted in an AUC of 0.69 in Hispanic men, and calibration was inadequate (χ^2^ = 142.0), similar to results using the Honolulu Heart Program (HHP), in which the AUC was 0.72 in Japanese American men, with inadequate calibration again (χ^2^ = 66.0).

Another study combined patients with chronic kidney disease from the ARIC and CHS cohorts and evaluated matched 5- and 10-year hard CHD_1_.45 For 5-year outcomes, the C statistic was 0.62 in men and 0.77 in women, and for 10-year outcomes, the C statistic was 0.60 in men and 0.73 in women. Calibration was inadequate for both sexes and outcomes, with chi-square values ranging from 33.4 to 75.1.

The Johns Hopkins Sibling Study was evaluated with the model for matched total CHD_1_ among healthy siblings of patients with known premature coronary artery disease (CAD).42 The study did not report discrimination, and calibration was adequate for women but inadequate for men (χ^2^ = 75). The number of observed outcomes significantly exceeded those predicted in men (O/E ratio, 1.67 [95% confidence interval (CI), 1.34–2.06]), and non-significantly exceeded those predicted in women (O/E ratio, 1.13 [95% CI, 0.74–1.64]).

The Chicago Heart Association Detection Project in Industry study evaluated young men aged 18 to 39 years without diabetes for unmatched 10-year hard CHD_1_/total CHD_1_.49 Discrimination was not measured, and the number of observed outcomes was significantly lower than expected (O/E ratio, 0.05 [95% CI, 0.03–0.07]). The Women's Health Initiative evaluated women for unmatched hard CHD_1_/total CHD_1_, and the AUC was 0.69.^53^ The WHS cohort evaluated women for unmatched CVD_3_/total CHD_1_ using both the total cholesterol and low-density lipoprotein versions of the model.54 The AUC was 0.75 in both cases, and they were both inadequately calibrated. The San Antonio Heart Study cohort evaluated men and women, 68 percent of whom were Hispanic, for unmatched CVD_15_/total CHD_1_, and the AUC was 0.82.^79^ Finally, the Normative Aging Study evaluated male U.S. military veterans for matched total CHD_1_. The AUC was 0.63, and observed outcomes were non-significantly lower than expected (O/E ratio, 0.93 [95% CI, 0.81–1.06]).

FRS (ATP-III) model validations. The St. Francis Heart Study cohort evaluated men and women for unmatched hard CHD_2_/hard CHD_1_, and the AUC was 0.68.^70^ The ARIC cohort was evaluated in two studies for unmatched 6-year and mean 11-year hard CHD_2_/hard CHD_1_.75, 105 The 6-year study reported an AUC of 0.65 for men and 0.67 for women, and the mean 11-year study reported an AUC of 0.63 for men and 0.73 for women. The South Bay Heart Watch cohort evaluated men and women without diabetes for matched hard CHD_1_, and the AUC was 0.63.^87^ The WHS evaluated women for unmatched CVD_3_/hard CHD_1_, and the AUC was 0.79, with inadequate calibration.54 The Chicago Heart Association study evaluated young men aged 18 to 39 years without diabetes for 10-year matched hard CHD_1_.49 Discrimination was not reported, and calibration was inadequate (p = 0.07, based on the Hosmer-Lemeshow goodness-of-fit test).

Europe – internal validation. Reporting of model performance characteristics in internal cohorts during model development was highly variable (Table 13). Discrimination measurements, either AUC or C statistic, ranged from 0.52 to 0.83 for those models developed in European patients. The QRESEARCH cohort in the United Kingdom was used to develop a series of models under the QRISK name, namely version 1, version 1.1, and version 2.^35, 43, 46^ Version 1 was developed for CVD_4_, version 1.1 was developed for CVD_10_, and version 2 was developed for CVD_1_. The AUC for these models ranged from 0.77 to 0.79 among men and from 0.79 to 0.82 among women. Calibration measurements in version 1 were reported using the Brier score and O/E ratio, and were not significantly different from 1.0. Calibration measurements were reported to be adequate and were represented in graphical form for version 2.

Table 13 Model Development Performance Characteristics (Europe): Internal Validation

Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | Hosmer-Lemeshow Goodness-of-Fit | | O/E Ratio
Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | | | O/E Ratio
Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | χ^2^ | P | O/E Ratio
QRESEARCH | CVD_4_ (10 yr) | QRISK43 | Men | 0.77 | | | | 1.00
| | | Women | 0.79 | | | | 0.98
| CVD_10_ (10 yr) | QRISK 1.1^43^ | Men | 0.77 | 0.77-0.77
| | | Women | 0.79 | 0.78-0.79
| CVD_1_ | QRISK 2^43^ | Men | 0.79 | 0.79-0.79
| | | Women | 0.82 | 0.81-0.82
Swedish NDR | CVD_5_ | Swedish NDR107 | Risk Grouped | 0.70 | | 4.3 | 0.83
| | | Subgroup B | 0.69
SU.VI.MAX | Total CHD_1_ | SU.VI.MAX110 | All | 0.75
EPIC-Norfolk | Total CHD_1_ | FRS (1998) + EPIC + HbA1c36 | Men | 0.73 | 0.70-0.75
| | FRS (1998) + EPIC + HbA1c | Women | 0.80 | 0.78-0.83
| | FRS (1998) + EPIC + w/o DM + HbA1c | Men | 0.73 | 0.70-0.74
| | FRS (1998) + EPIC + w/o DM + HbA1c | Women | 0.80 | 0.77-0.82
WOSCOPS | Hard CHD_1_ | QT Dispersion60 | All | 0.52
CUORE | Hard CHD_2_ | CUORE76 | Men | 0.74 | 0.68-0.80 | 15.5 | 0.05
DARTS | Hard CHD_1_ | DARTS63 | All | 0.71 | 0.63-0.79
PROCAM | Hard CHD_1_ | PROCAM CHD (Cox Model)14 | All | 0.83 | | 6.5 | 0.3
| | PROCAM CHD (Point Score)14 | All | 0.82
NPHS-II | Hard CHD_2_ | Score 1 (Basic)71 | Men | 0.64 | 0.58-0.70
| | Score 2 (Basic + DM + FamHx) | Men | 0.66 | 0.60-0.71
| | Score 3 (Basic + DM) | Men | 0.63 | 0.58-0.69
| | Score 4 (Basic + FamHx) | Men | 0.64 | 0.59-0.69
| | Score 5 (Basic + Fibrinogen) | Men | 0.66 | 0.60-0.71
| | Score 6 (Basic + LpA) | Men | 0.67 | 0.61-0.72
| | Score 7 (Basic + ApoA1 + ApoB) | Men | 0.64 | 0.60-0.72
PROCAM | Hard CHD_1_ | PROCAM (BMI-modified)109 | All | 0.82 | | | | 0.88
| | PROCAM CHD (Cox Model)137 | All | 0.82
NZWork | CVD_2_ (5 yrs) | New Zealand Risk Charts89 | Men | 0.73 | 0.72-0.74
| | | Women | 0.78 | 0.75-0.81
INSIGHT | CVD_14_ | INSIGHT CVD94 | All | 0.661 | | | | 1.25
PROCAM | Hard CHD_1_ (10 yr) | PROCAM CHD (Cox Model)41 | All | 0.824
| | PROCAM CHD (Weibull Model)41 | All | 0.824
NorGov | CHD Mortality | Erikssen CRF-X Model84 | All | | | | | 1.00
| | Erikssen CRF Model | All
| | Erikssen X Model | All
INSIGHT | Stroke^4^ | INSIGHT Stroke94 | All | | | | | 1.00
Dubbo | CVD_4_ (5 yr) | Dubbo Model93 | All | | | 107 | <0.01
| CVD_4_ (10yr) | | All | | | 167 | <0.01
ULSAM (70) | CVD Mortality | FRS (1998) + ECG50 | All | | 0.67

Note: If the cohort and model outcomes match, only one outcome is listed; otherwise both are listed.

The Swedish National Diabetes Register was used to develop a diabetes-specific risk model that added hemoglobin A_1c_, age at onset of diabetes, and duration of diabetes to the traditional risk factors for the outcome of CVD_5_. The C statistic for the model was 0.70, and it was adequately calibrated by the Hosmer-Lemeshow goodness-of-fit test.107 The Supplementation en Vitamines et Mineraux Antioxydants (SU.VI.MAX) model was developed in a French cohort of men for the outcome of total CHD_1_, and the AUC was 0.75. No calibration measurements were reported. Models were developed from the Second Northwick Park Heart Study (NPHS-II), West of Scotland Coronary Prevention Study, European Prospective Investigation of Cancer-Norfolk (EPIC-Norfolk), and the Norwegian Government Study to evaluate diabetes variables, echocardiography characteristics, family history of CAD, fibrinogen, lipoprotein A, apolipoproteins A1 and B, and exercise testing.36, 60, 71, 84 The CUORE cohort, consisting of men from Italy, was used to develop a model for the outcome of hard CHD_2_.76 Internal validation was reported as an AUC of 0.74, with questionable calibration (χ^2^ = 15.5). The DARTS cohort consisted of patients with type 2 diabetes in Scotland who were utilized to develop a model for hard CHD_1_.63 The AUC in the internal validation was 0.71, and calibration measurements were not reported. The PROCAM cohort of German men was used to develop a risk prediction model for hard CHD_1_. The AUC of the model was 0.83, and the calibration was adequate. A cohort from New Zealand was used to develop a risk prediction model for 5-year CVD_2_, and the AUC was 0.73 for men and 0.78 for women.89 The Intervention as a Goal in Hypertension Treatment (INSIGHT) cohort utilized a multinational cohort including patients with hypertension to develop a model for CVD_14_ and stroke_4_.94 The CVD version reported an AUC of 0.66. Calibration was reported by an O/E ratio of 1.0 for the stroke version and 1.25 for the CVD version. A cohort of elderly (aged 60–79 years) Australians in Dubbo, New South Wales was used to generate a risk prediction model for 5- and 10-year CVD_4_.93 No discrimination measures were reported, and the calibration was reported as inadequate for both 5- and 10-year outcomes.

Europe – external validation. The FRS (Anderson) family of models has been extensively externally validated among European cohorts. The Poole Diabetes Study evaluated men and women with diabetes for unmatched total CHD_3_/total CHD_1_ and CVD_13_/CVD_2_ outcomes with two version of the model.73 The entire cohort as well as a variety of subcohorts (men, women, and patients with treated and untreated hypertension) were evaluated. The same trends were present for all analyses. The CVD outcome analysis found an AUC of 0.67 and 0.68 for men and women, respectively. The CHD outcome analysis found an AUC of 0.73 and 0.70 for men and women, respectively. In the overall cohort, there was inadequate calibration for both outcomes, and the O/E ratio was 1.46 for the CHD outcome and 1.48 for the CVD outcome.

The SHHEC, which consisted of Scottish men and women, was evaluated for the unmatched outcome of 10-year CVD_11_/CVD_2_. The AUC was 0.72 for men and 0.74 for women. The O/E ratio was 0.71 (95% CI, 0.66–0.76) for men and 0.65 (95% CI, 0.59–0.71) for women, indicating that the model predicted an excess of outcomes. The British Regional Heart Study (BRHS), consisting of men aged 40 to 59 years without diabetes, was evaluated for a series of unmatched outcomes using the total CHD_1_ version of the model and 10- and 20-year hard CHD_1_, stroke_1_, and diabetes mellitus outcomes.65 The AUC measurement ranged from 0.63 to 0.69, and the outcomes were purposely mismatched to evaluate the performance of the tool for these outcomes. Calibration was not calculable, except for 20-year hard CHD_1_/total CHD_1_, which reported an O/E ratio of 2.5 (95% CI, 2.33–2.68), revealing that the observed outcomes were largely in excess of predicted outcomes.

The Leiden-85 cohort, a group of elderly (age 85 years) men and women from the Netherlands, was evaluated for unmatched CVD mortality/CVD_2_.102 The AUC was 0.53. The Cardiff Diabetes Database cohort, a group of men and women with diabetes, was evaluated for the matched outcome of CVD_2_.85 The AUC was 0.64 for men and 0.66 for women. The O/E ratio for men was 0.81 (95% CI, 0.67–0.98) and for women it was 0.86 (95% CI, 0.67–1.08).

A cohort from New Zealand was evaluated for 5-year CVD_2_; the AUC was 0.74 for men and 0.77 for women, and the O/E ratio was 1.17 (95% CI, 1.05–1.31) and 1.09 (95% CI, 0.88–1.34) for men and women, respectively.89 The QRESEARCH cohort was evaluated for unmatched 10-year CVD_4_/CVD_2_, and the AUC was 0.76 for men and 0.77 for women.43 The O/E ratio was 0.68 for men and 0.83 for women. The same cohort was evaluated for unmatched 10-year CVD_10_/CVD_2_, and the AUC was 0.76 for men and 0.78 for women.46

The British Women's Heart and Health cohort was evaluated for unmatched total CHD_3_/total CHD_1_ and CVD_11_/CVD_2_.64 The AUC was 0.63 for the CHD outcome and 0.64 for the CVD outcome. The O/E ratio for the CHD outcome was 0.97 (95% CI, 0.84–1.11) and for the CVD outcome it was 0.65 (95% CI, 0.57–0.74). The Health Improvement Network cohort was evaluated for 10-year CVD_10_/CVD_2_, and the AUC for men was 0.74 and for women it was 0.76.^43^ The O/E ratio for men was 0.76 (95% CI, 0.75–0.76) and for women it was 0.91 (95% CI, 0.90–0.92). The Monitoring Project on Cardiovascular Disease Risk Factors (MP-CVDRF) cohort was evaluated for 10-year CVD mortality/CVD_2_.106 The AUC was 0.86 for all patients, and was 0.69 among smokers, 0.81 in patients with elevated total cholesterol, 0.79 in patients with hypertension, and 0.80 in high-risk patients. The PROCAM cohort was evaluated for the hard CHD_1_ outcome.92 The O/E ratio for men was 0.56 (95% CI, 0.50–0.63) and for women it was 0.35 (95% CI, 0.24–0.59), and the AUC for men was 0.73 and for women it was 0.88. The Renfrew-Paisley cohort compared manual and non-manual labor employment as a socioeconomic status indicator for the unmatched CVD mortality/CVD_2_ outcome.66 The O/E ratio for the entire cohort was 1.71 (95% CI, 1.59–1.85) and the AUC was 0.73. The AUC for manual laborers was 0.72 and for non-manual laborers it was 0.74. The Prospective Evaluation of Diabetic Ischaemic Disease by Computed Tomography (PREDICT) cohort of patients with diabetes was evaluated for the unmatched CVD_19_/CVD_2_ outcome, and the AUC was 0.63.^108^ An Australian Aboriginal cohort was evaluated for the matched total CHD_1_ outcome, and the O/E ratio for men was 2.00 (95% CI, 1.37–2.82) and for women it was 3.92 (95% CI, 2.81–5.32).77 The BRHS cohort of men was evaluated for the matched outcomes of CHD mortality and total CHD_1_.88 The models revealed poor calibration using both model outcome versions, with the CHD mortality version resulting in a chi-square value of 30.2 (p<0.01) and an O/E ratio of 0.68 (95% CI, 0.59–0.79). The total CHD_1_ version resulted in a chi-square value of 155 (p<0.01) and an O/E ratio of 0.64 (95% CI, 0.59–0.69). The INSIGHT cohort of middle-aged patients with hypertension was evaluated for the unmatched outcome of CVD_14_/CVD_2_, the matched outcome of total CHD_1_, and the matched outcome of stroke_4_.94 The O/E ratio for the unmatched CVD outcome was 0.39 (95% CI, 0.38–0.44), for the total CHD_1_ outcome it was 0.44 (95% CI, 0.36–0.52), and for the stroke_4_ outcome it was 1.00 (95% CI, 0.81–0.22). The MONICA Augsburg cohort was evaluated for unmatched hard CHD_1_/CVD_2_, and the AUC for men was 0.78 and for women it was 0.88. The O/E ratio for men was 0.50 (95% CI, 0.42–0.59), and for women it was 0.39 (95% CI, 0.27–0.54).92 The Wisconsin Epidemiologic Study of Diabetic Retinopathy (WESDR) cohort of patients with diabetes was evaluated for unmatched stroke mortality/CVD_2_, and the O/E ratio was 1.79 (95% CI, 1.37–2.29).96 The NHP-Europe cohort was evaluated for unmatched stroke mortality/stroke_4_, and the O/E ratio was 3.91 (95% CI, 1.91–7.18).

The FRS (Wilson) family of models has also been extensively externally validated among European cohorts. The EPIC-Norfolk cohort was evaluated for matched total CHD_1_, and the AUC for both men and women was 0.71.^36^ The Study of Atherosclerotic Risk Factors cohort of Czech men without diabetes was evaluated for the matched outcome of total CHD_1_, and the AUC was 0.64, with an O/E ratio of 1.28 (95% CI, 1.05–1.54). The Validez de la Ecuación de Riesgo Individual de Framingham de Incidentes Coronarios Adaptada (VERIFICA) cohort of Spanish patients was evaluated for matched total CHD_1_.58 The AUC for men was 0.68 and for women it was 0.73. Calibration, as evaluated by the Hosmer-Lemeshow goodness-of-fit test, was inadequate for both men (χ^2^ = 110) and women (χ^2^ = 64). The O/E ratio for men and women, respectively, was 0.45 (95% CI, 0.37–0.54) and 0.44 (95% CI, 0.34–0.55). A cohort of patients with diabetes in Lyon, France was evaluated for unmatched CVD_6_/total CHD_1_.72 The AUC was 0.72, and the O/E ratio was 1.36 (95% CI, 0.96–1.88). The ULSAM cohort of Swedish men was evaluated for unmatched CVD mortality/total CHD_1_, and the AUC was 0.58.^80^ The CUORE cohort of Italian men was evaluated for unmatched hard CHD_2_/total CHD_1_.76 The AUC was 0.72, and the O/E ratio was 0.33 (95% CI, 0.29–0.37). The Rotterdam Coronary Calcification Study was evaluated for unmatched CVD_3_/total CHD_1_.69 The AUC was 0.73 and 0.68 for men and women, respectively. The MONICA Augsberg cohort of white male patients in Germany was evaluated for unmatched hard CHD_1_/total CHD_1_, and the AUC was 0.74.^86^ The SU. VI.MAX cohort of French male patients was evaluated for matched total CHD_1_.110 The AUC was 0.74 and the O/E ratio was 0.50. A cohort of patients with diabetes in a German university clinic was evaluated for unmatched MI/hard CHD_1_, and the AUC was 0.63.^104^ A cohort of renal transplant patients in France were evaluated for matched total CHD_1_, and the O/E ratio was 1.69 (95% CI, 1.13–2.42).82

The FRS ATP-III model has been externally validated a number of times in European cohorts. A cohort of German clinic patients was evaluated for matched hard CHD_1_, and the AUC was 0.63.^104^ A cohort of patients aged 55 years and older living in a suburb of Rotterdam, Netherlands was evaluated for matched hard CHD_1_. The AUC was 0.63 and 0.73 for men and women, respectively. The O/E ratio was 0.72 (95% CI, 0.65–0.80) for men and 1.02 (95% CI, 0.93–1.12) for women.48 The NPHS-II cohort of British men was evaluated for unmatched hard CHD_2_/hard CHD_1_.71 The AUC was 0.62, and the O/E ratio was 0.47 (95% CI, 0.41–0.54). The Prospective Epidemiological Study of Myocardial Infarction (PRIME) cohort of Northern Irish men evaluated unmatched 5-year total CHD_1_/hard CHD_1_.90 The AUC was 0.66, and the O/E ratio was 0.75 (95% CI, 0.62–0.89). The PRIME cohort of French men was evaluated for unmatched 5-year total CHD_1_/hard CHD_1_.90 The AUC was 0.68, and the O/E ratio was 0.67 (95% CI, 0.58–0.77). The ULSAM cohort of Swedish men aged 70 years and older was evaluated for unmatched MI/hard CHD_1_, and the AUC was 0.61.^50^ The same cohort was evaluated for matched 10-year hard CHD_1_, and the O/E ratio was 0.21 (95% CI, 0.15–0.30). The PROCAM cohort was evaluated for matched hard CHD_1_.14 The AUC was 0.78, and the calibration, as measured by the Hosmer-Lemeshow goodness-of-fit test (χ^2^ = 44; p < 0.01), was inadequate. The Dubbo study of Australian patients aged 60 to 79 years without diabetes was evaluated for matched 10-year CVD_4_.93 The O/E ratio for men and women, respectively, was 0.91 (95% CI, 0.75–1.10) and 0.93 (95% CI, 0.74–1.13).

The UKPDS hard CHD_1_ risk model for patients with diabetes has been externally validated in other European cohorts. British patients with diabetes were evaluated for unmatched total CHD_3_/hard CHD_1_. The overall population was found to have an AUC of 0.67, calibration by the Hosmer-Lemeshow test (χ^2^ = 17.1; p = 0.03) was inadequate, and the O/E ratio was 1.15 (95% CI, 0.89–1.48). Among men, the AUC was 0.67 and the O/E ratio was 1.11 (95% CI, 0.81–1.49). Among women, the AUC was 0.62 and the O/E ratio was 1.19 (95% CI, 0.74–1.82).73 The National Health Service (NHS) Trust cohort of patients with diabetes at an UK university diabetes clinic was evaluated on the unmatched outcomes of CVD_18_/hard CHD_1_ and total CHD_2_/hard CHD_1_.78 The CVD outcome had an AUC of 0.74 and an O/E ratio of 1.20 (95% CI, 1.08–1.33). The CHD outcome had an AUC of 0.76 and an O/E ratio of 1.60 (95% CI, 1.42–1.80). The PREDICT cohort of British patients with diabetes was evaluated for unmatched CVD_19_/hard CHD_1_ and total CHD_2_/hard CHD_2_. The CVD outcome had an AUC of 0.67, and the total CHD outcome had an AUC of 0.63.^108^ A cohort of patients with diabetes in Munich was evaluated for unmatched MI/hard CHD_1_, and the AUC was 0.66.^104^

The SCORE model for CVD mortality was externally validated in a number of European cohorts. A cohort of German patients from Ludwig University was evaluated for unmatched hard CHD_1_/CVD mortality, and the AUC was 0.66.^104^ The Vorarlberg Health Monitoring and Promotion Program of Austrian patients was evaluated for both matched CVD mortality and unmatched CHD mortality/CVD mortality.68 The CVD outcome had an AUC of 0.80 for the entire population, 0.76 for men, and 0.78 for women. The O/E ratio for this outcome was 0.73 (95% CI, 0.67–0.80) for everyone, 0.84 (95% CI, 0.75–0.92) for men, and 0.52 (95% CI, 0.42–0.62) for women. The unmatched CHD outcome had an AUC of 0.75 for men and 0.84 for women, and the O/E ratio was 0.79 (95% CI, 0.70–0.89) for men and 0.46 (95% CI, 0.35–0.60) for women. A cohort of Norwegian patients aged 60 to 69 years without diabetes was evaluated for matched CVD mortality.44 The high-risk equation reported an AUC for men and women of 0.65 and 0.68, respectively, and an O/E ratio of 0.45 (95% CI, 0.40–0.50) and 0.37 (95% CI, 0.31–0.44). The low-risk equation reported an O/E ratio for men and women of 0.79 (95% CI, 0.70–0.88) and 0.56 (95% CI, 0.47–0.66), respectively. The Norwegian Counties Study of patients aged 40 to 59 years without diabetes was evaluated for matched CVD mortality.44 The high-risk equation reported an AUC for men aged 40 to 49 years of 0.67 and for men aged 50 to 59 years it was 0.68. The AUC for women aged 40 to 49 years was 0.66 and for women aged 50 to 59 years it was 0.72. The O/E ratio for men was 0.53 (95% CI, 0.48–0.58) and for women it was 0.42 (95% CI, 0.34–0.51). The MP-CVDRF cohort of patients aged 20 to 59 years from the Netherlands was evaluated for matched 10-year CVD mortality.106 The NHP-Europe cohort of patients was evaluated for unmatched CHD mortality/CVD mortality, and the O/E ratio was 3.24 (95% CI, 2.08–4.82).74

The PROCAM Cox proportional hazards model for hard CHD_1_ was evaluated in a number of European cohorts. The NHS Trust cohort of British patients with diabetes was evaluated for unmatched CVD_18_/hard CHD_1_ and total CHD_2_/hard CHD_1_.78 The CVD outcome had an AUC of 0.67 and an O/E ratio of 2.79 (95% CI, 2.51–3.09). The total CHD outcome had an AUC of 0.65 and an O/E ratio of 2.05 (95% CI, 1.82–2.31). The Ludwig University cohort was evaluated for matched hard CHD_1_, and the AUC was 0.65.^104^ The Northern Irish PRIME cohort of men was evaluated for 5-year hard CHD_1_; the AUC was 0.61 and the O/E ratio was 0.56 (95% CI, 0.43–0.72).90 The French PRIME cohort of men was evaluated for matched 5-year hard CHD_1_; the AUC was 0.64 and the O/E ratio was 0.23 (95% CI, 0.19–0.28).90 The ULSAM cohort of men was evaluated for matched 10-year hard CHD_1_ and unmatched MI/hard CHD_1_.80 The MI outcome had an AUC of 0.63, and the hard CHD outcome had an O/E ratio of 0.27 (95% CI, 0.19–0.38). The NPHS-II cohort of white men was evaluated for unmatched hard CHD_2_/hard CHD_1_.71 The AUC was 0.63, and the O/E ratio was 0.46 (95% CI, 0.40–0.52). A cohort of German working men in the region of Münster (a subset of the PROCAM cohort) was evaluated for matched hard CHD_1_, and the O/E ratio was 0.78 (95% CI, 0.70–0.87).29

The ASSIGN model for CVD_11_ was evaluated in the SHHEC and QRESEARCH cohorts. In the SHHEC cohort, the matched 10-year CVD_11_ outcome was evaluated.59 For men, the AUC was 0.73 and the O/E ratio was 0.79 (95% CI, 0.73–0.85). For women, the AUC was 0.77 and the O/E ratio was 0.67 (95% CI, 0.61–0.74). In the QRESEARCH cohort, the unmatched 10-year CVD_4_/CVD_1_ outcome was evaluated.46 For men, the AUC was 0.76 and the O/E ratio was 0.73 (95% CI, 0.72–0.74). For women, the AUC was 0.78 and the O/E ratio was 0.73 (95% CI, 0.72–0.74).

Both the CardioRisk Manager (CRM) and Joint British Societies Risk Prediction Chart (JBSRC) models were evaluated in a single cohort, the NHS Trust. The outcomes in the cohort were total CHD_2_ and CVD_18_; in both cases, the total CHD_2_ outcome was matched to the models and the CVD outcomes were unmatched. The total CHD outcome was evaluated with the JBSRC model and had an AUC of 0.77. The same outcome was evaluated with the CRM model and the AUC was 0.73. The CVD outcome was evaluated in the JBSRC model and the AUC was 0.80, and for the CRM model, it was 0.37.

The DARTS model was evaluated for matched hard CHD_1_ in the Salford, England cohort of patients with diabetes.63 The AUC for this model was 0.69.

The QRISK model was quasi-externally evaluated in the QRESEARCH cohort for the unmatched outcome of CVD_1_/CVD_4_. The AUC for men was 0.79, and for women it was 0.81.^35^

The UKPDS-60 model for stroke was evaluated in the WESDR cohort for unmatched stroke mortality/stroke_1_. The O/E ratio was 1.13 (95% CI, 0.87–1.45) (Table 14).

Table 14 Model Development Performance Characteristics (Europe): External Validation

Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | Hosmer-Lemeshow Goodness-of-Fit | | O/E Ratio
Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | | | O/E Ratio
Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | χ^2^ | P | O/E Ratio
SHHEC | CVD_11_/CVD_2_ (10 yr) | FRS (1991)59 | Men | 0.72 | | | | 0.71
| | | Women | 0.74 | | | | 0.65
PDS | Total CHD_3_/Total CHD_1_ | FRS (1991)73 | All | 0.66 | 0.58-0.73 | | | 1.46
| | | All (Exclude LVH) | 0.67 | 0.59-0.74 | | | 1.50
| | | Men | 0.73 | 0.64-0.81 | | | 1.71
| | | Women | 0.70 | 0.64-0.76 | | | 1.36
| | | Treated BP | 0.67 | 0.54-0.80 | 19.8 | 0.01 | 1.71
| | | Untreated BP | 0.66 | 0.57-0.76 | 22.6 | <0.01 | 1.44
PDS | CVD_13_/CVD_2_ | FRS (1991)73 | All | 0.67 | 0.61-0.73 | | | 1.48
| | | All (Exclude LVH) | 0.68 | 0.62-0.74 | | | 1.51
| | | Men | 0.67 | 0.59-0.75 | | | 1.54
| | | Women | 0.68 | 0.58-0.78 | | | 1.40
| | | Treated BP | 0.63 | 0.53-0.74 | 32.8 | <0.01 | 1.67
| | | Untreated BP | 0.69 | 0.61-0.77 | 39.5 | <0.01 | 1.38
BRHS | Hard CHD_1_ + Stroke_1_ + DM_2_/Total CHD_1_ (20 yrs) | FRS (1991)65 | Men | 0.67 | 0.65-0.69 | | | 2.5
| Hard CHD_1_/Total CHD_1_ (10 yrs) | FRS (1991)65 | Men | 0.73 | 0.71-0.75
| Hard CHD_1_/Total CHD_1_ (20 yrs) | FRS (1991)65 | Men | 0.68 | 0.66-0.70
| Stroke_1_/Total CHD_1_ (10 yrs) | FRS (1991)65 | Men | 0.71 | 0.65-0.77
| Stroke_1_/Total CHD_1_ (20 yrs) | FRS (1991)65 | Men | 0.66 | 0.62-0.70
| DM_2_/Total CHD_1_ (10 yrs) | FRS (1991)65 | Men | 0.61 | 0.55-0.67
| DM_2_//Total CHD_1_ (20 yrs) | FRS (1991)65 | Men | 0.6 | 0.56-0.64
L85 | CVD Mortality/CVD_2_ | FRS (1991)102 | All | 0.53 | 0.42-0.63
Cardiff DM | CVD_2_ | FRS (1991)85 | Men | 0.64 | | | | 0.82
| | | Women | 0.66 | | | | 0.86
NZWork | CVD_2_ (5 yrs) | FRS (1991)89 | Men | 0.74 | 0.73-0.75 | | | 1.17
| | | Women | 0.77 | 0.74-0.80 | | | 1.09
QRESEARCH | CVD_4_/CVD_2_ (10 yr) | FRS (1991)43 | Men | 0.76 | | | | 0.68
| | | Women | 0.77 | | | | 0.83
BWHH | Total CHD_3_/Total CHD_1_ | FRS (1991)64 | All | 0.63 | 0.59-0.67 | | | 0.97
| CVD_11_/CVD_2_ | FRS (1991)64 | All | 0.64 | 0.61-0.68 | | | 0.65
QRESEARCH | CVD_10_/CVD_2_ (10 yr) | FRS (1991)43 | Men | 0.76 | 0.76-0.77
| | | Women | 0.78 | 0.77-0.78
THIN | CVD_10_/CVD_2_ (10 yr) | FRS (1991)43 | Men | 0.74 | 0.73-0.74 | | | 0.76
| | | Women | 0.76 | 0.76-0.76 | | | 0.91
MP-CVDRF | CVD Mortality/CVD_2_ (10 yr) | FRS (1991)106 | All | 0.86 | 0.84-0.88
| | | High-risk Patients | 0.80 | 0.77-0.82
| | | SBP >140 mmHg | 0.79 | 0.75-0.83
| | | TC >6.5 mmol/L | 0.81 | 0.77-0.85
| | | Smokers | 0.69 | 0.65-0.74
PROCAM | Hard CHD_1_^*^ | FRS (1991)92 | Men | 0.73 | 0.70-0.75 | | | 0.56
| | | Women | 0.88 | 0.80-0.96 | | | 0.35
Renfrew-Paisley | CVD Mortality/CVD_2_ | FRS (1991)66 | All | 0.73 | 0.72-0.75
| | | Manual Labor | 0.72 | 0.70-0.74
| | | Non-manual Labor | 0.74 | 0.71-0.78 | | | 1.71
PREDICT | CVD_19_/CVD_2_ | FRS (1991)108 | All | 0.63 | 0.55-0.71
Aboriginal | Total CHD_1_ | FRS (1991)77 | Men | | | | | 2.00
| | | Women | | | | | 3.92
BRHS | CHD Mortality | FRS (1991) CHD Mortality88 | Men | | | 30.2 | <0.01 | 0.68
BRHS | Total CHD_1_ | FRS (1991)88 | Men | | | 155 | <0.01 | 0.64
INSIGHT | CVD_14_/CVD_2_ | FRS (1991)94 | All | | | | | 0.39
INSIGHT | Total CHD_1_ | FRS (1991)94 | All | | | | | 0.44
LudwigU | Hard CHD_1_/CVD Mortality | SCORE (?)40 | All | 0.66 | 0.62-0.68
SHHEC | CVD_11_ (10 yr) | ASSIGN59 | Men | 0.73 | | | | 0.79
| | | Women | 0.77 | | | | 0.67
PDS | Total CHD_3_/Hard CHD_1_ | UKPDS 56^73^ | All | 0.67 | 0.60-0.74 | | | 1.15
| | | Men | 0.67 | 0.59-0.76 | | | 1.11
| | | Women | 0.62 | 0.49-0.75 | | | 1.19
| | | Treated BP | 0.70 | 0.58-0.82 | | | 1.26
| | | Untreated BP | 0.65 | 0.56-0.74 | 17.1 | 0.03 | 1.09
VHM&PP | CVD Mortality | SCORE (Low Risk TC)68 | All | 0.80 | 0.79-0.82 | | | 0.73
| | | Men | 0.76 | 0.74-0.79 | | | 0.84
| | | Women | 0.78 | 0.74-0.82 | | | 0.52
VHM&PP | CHD Mortality/CVD Mortality | SCORE (Low Risk TC)68 | Men | 0.75 | 0.72-0.78 | | | 0.79
| | | Women | 0.84 | 0.80-0.88 | | | 0.46
QRESEARCH | CVD_4_/CVD_11_ (10 yr) | ASSIGN46 | Men | 0.76 | | | | 0.73
| | | Women | 0.78 | | | | 0.73
CP-Norway | CVD Mortality | SCORE (High Risk TC)44 | Men | 0.65 | | | | 0.45
| | | Women | 0.68 | | | | 0.37
NCS | CVD Mortality | SCORE (High Risk TC)44 | Men (40-49 yrs) | 0.67 | | | | 0.53
| | | Men (50-59 yrs) | 0.68 | | | | 0.53
| | | Women (40-49 yrs) | 0.66 | | | | 0.60
| | | Women (50-59 yrs) | 0.72 | | | | 0.45
MP-CVDRF | CVD Mortality (10 yr) | SCORE (?)106 | All | 0.85 | 0.83-0.87
| | | High-risk Patients | 0.75 | 0.72-0.78
| | | SBP >140 mmHg | 0.76 | 0.72-0.81
| | | TC >6.5 mmol/L | 0.78 | 0.73-0.82
| | | Smokers | 0.62 | 0.55-0.68
QRESEARCH | CVD_1_/CVD_4_ | QRISK43 | Men | 0.79 | 0.79-0.79
| | | Women | 0.81 | 0.81-0.81
NHS Trust | CVD_18_/Hard CHD_1_ | PROCAM (Cox)78 | All | 0.67 | 0.62-0.73 | | | 2.79
| CVD_18_/Hard CHD_1_ | UKPDS 56^78^ | All | 0.74 | 0.70-0.78 | | | 1.20
| Total CHD_2_/Hard CHD_1_ | PROCAM (Cox)78 | All | 0.65 | 0.59-0.71 | | | 2.05
| Total CHD_2_/Hard CHD_1_ | UKPDS 56^78^ | All | 0.76 | 0.72-0.80 | | | 1.60
EPIC-Norfolk | Total CHD_1_ | FRS [TC] (1998)36 | Men | 0.71 | 0.69-0.73
| | | Women | 0.71 | 0.68-0.74
LudwigU | Hard CHD_1_ | PROCAM (Cox)40 | All | 0.65 | 0.62-0.68
| | FRS (ATP-III)40 | All | 0.63 | 0.59-0.65
Rotterdam | Hard CHD_1_ | FRS (ATP-III)48 | Men | 0.63 | 0.52-0.74 | | | 0.72
| | | Women | 0.73 | 0.65-0.83 | | | 1.02
STULONG | Total CHD_1_ | FRS [TC] (1998)56 | All | 0.638 | 58.4-69.1 | | | 1.282
VERIFICA | Total CHD_1_ | FRS [TC] (1998)58 | Men | | | 110 | <0.01
| | | Women | 0.68 | | 64 | <0.01 | 0.45
| | | Patients w/Diabetes | 0.73 | | 54 | <0.01 | 0.44
NHS Trust | CVD_18_/CVD | JBSRC78 | All | 0.80 | 0.75-0.85
| CVD_18_/CVD | CRM78 | All | 0.76 | 0.72-0.79 | | | 2.30
| Total CHD_2_ | JBSRC78 | All | 0.77 | 0.74-0.80
| Total CHD_2_ | CRM78 | All | 0.73 | 0.70-0.77 | | | 1.74
NPHS-II | Hard CHD_2_/Hard CHD_1_ | FRS (ATP-III)71 | All | 0.62 | 0.58-0.66 | | | 0.47
PRIME-Belfast | Total CHD_1_/Hard CHD_1_ (5 yr) | FRS (ATP-III)90 | All | 0.66 | | | | 0.75
| Hard CHD_1_ (5 yr) | PROCAM (Cox)90 | All | 0.61 | | | | 0.56
PRIME-France | Total CHD_1_/Hard CHD_1_ (5 yr) | FRS (ATP-III)90 | All | 0.68 | | | | 0.67
| Hard CHD_1_ (5 yr) | PROCAM (Cox)90 | All | 0.64 | | | | 0.23
PREDICT | CVD_19_/Hard CHD_1_ Total CHD_2_/Hard CHD_1_ | UKPDS 56^108^ | All | 0.67 | 0.60-0.75
PREDICT | CVD_19_/Hard CHD_1_ Total CHD_2_/Hard CHD_1_
PREDICT | CVD_19_/Hard CHD_1_ Total CHD_2_/Hard CHD_1_ | UKPDS 56^108^ | All | 0.63 | 0.56-0.71
Lyon | CVD_6_/Total CHD_1_ | FRS [Unknown Version] (1998)72 | All | 0.72 | | | | 1.36
ULSAM (70) | CVD Mortality/Total CHD_1_ | FRS [Unknown Version] (1998)50 | All | 0.58
ULSAM | MI/Hard CHD_1_ | PROCAM (Cox)80 | Men | 0.63
| | FRS (ATP-III)80 | Men | 0.61
CUORE | Hard CHD_2_/Total CHD_1_ | FRS [TC] (1998)76 | Men | 0.723 | 0.67-0.78 | | | 0.33
RCC | CVD_3_/Total CHD_1_ | FRS [?] (1998)69 | All | 0.73
| | | Age >70 yrs | 0.68
MONICA-Augsburg | Hard CHD_1_/Total CHD_1_ | FRS [?] (1998)86 | All | 0.74
PROCAM | Hard CHD_1_ | FRS (ATP-III)14 | All | 0.78 | | 44 | <0.01
NPHS-II | Hard CHD_2_/Hard CHD_1_ | PROCAM (Cox)71 | All | 0.63 | 0.59-0.67 | | | 0.46
SU.VI.MAX | Total CHD_1_ | FRS [?] (1998)110 | All | 0.74 | | | | 0.50
MunichDM | MI/Hard CHD_1_ | UKPDS 56^104^ | All | 0.66 | 0.62-0.68
| | FRS [?] (1998)104 | All | 0.63 | 0.59-0.66
Salford | Hard CHD_1_ | DARTS63 | All | 0.69 | 0.58-0.78
THIN | CVD_10_/CVD_4_ (10 yr) | QRISK43 | Men | 0.76 | 0.76-0.77 | | | 1.15
| | | Women | 0.79 | 0.79-0.79 | | | 1.11
MONICA-Augsburg | Hard CHD_1_/CVD_2_ | FRS (1991)92 | Men | 0.78 | 0.73-0.84
| | | Women (55-64 yrs) | 0.88 | 0.80-0.96 | | | 0.50
NHP–Europe | Stroke Mortality/Stroke_4_ | FRS (1991) Stroke74 | All | | | | | 3.91
INSIGHT | Stroke_4_ | FRS (1991) Stroke94 | All | | | | | 1.00
WESDR | Stroke Mortality/CVD_2_ | FRS (1991)96 | All | | | | | 1.79
Dubbo | CVD_4_ (10 yr) | FRS (ATP-III)93 | Non-DM Men | | | | | 0.91
| | | Non-DM Women | | | | | 0.93
WESDR | Stroke Mortality/Stroke | UKPSD 60^96^ | All | | | | | 1.14
ULSAM | Hard CHD_1_ (10 yr) | FRS (ATP-III)80 | All | | | | | 0.21
| | PROCAM (Cox)80 | All | | | | | 0.27
NHP–Europe | CHD Mortality | SCORE (Unknown Version)74 | All | | | | | 3.24
FrRenal | Total CHD_1_ | FRS [?] (1998)82 | All | | | | | 1.69
MünsterWork | Hard CHD_1_ | Procam (Cox)29 | Men | | | | | 0.78
QRESEARCH | CVD_1_ | FRS (1991) NICE Recal35 | Men | 0.78 | 0.78-0.78
| | | Women | 0.80 | 0.80-0.80
EPIC-Norfolk | Total CHD_1_ | FRS (1998) EPIC36 | Men | 0.72 | 0.70-0.75
| | | Women | 0.80 | 0.78-0.83
VERIFICA | Total CHD_1_ | FRS (1998) REGICOR | Men | 0.69 | | 5.1 | 0.08 | 1.26
| | VERIFICA58 | Women | 0.81 | | 2.7 | 0.26 | 1.03
CUORE | Hard CHD_2_ | FRS (1998 TC) D'Ag CUORE76 | Men | 0.72 | 0.67-0.78 | 27.1 | <0.01 | 0.78
| | PROCAM (Cox) D'Ag CUORE76 | Men | 0.74 | 0.68-0.79 | 220 | <0.01 | 0.34
| | FRS (1998 TC) Chb CUORE76 | Men | 0.72 | 0.67-0.78 | 19.9 | 0.01 | 1.01
| | PROCAM (Cox) Chb CUORE76 | Men | 0.74 | 0.68-0.79 | 53.0 | <0.01 | 1.01
Cardiff DM | CVD_2_ | FRS (1991) Cardiff DM85 | Men | 0.65
| | | Women | 0.68
BRHS | CHD Mortality | FRS (1991) BRHS88 | Men | | | 3.4 | 0.91
| Total CHD_1_ | | | | | 24.6 | <0.01
VERIFICA | Total CHD_1_ | FRS (1998) REGICOR | Patients w/Diabetes
| | VERIFICA58 | | | | 1.4 | 0.99

* The model outcome was calculated using the sum of MI and sudden CHD death models from FRS (Anderson).

Note: If the cohort and model outcomes match, only one outcome is listed; otherwise both are listed.

Asia – internal validation. Reporting of model performance characteristics in internal cohorts during model development was variable. The discrimination measurements, either AUC or C statistic, ranged from 0.74 to 0.82 for those models developed in European patients. The Cox proportional hazards model developed from the Chinese Multi-Provincial Study (MUCA) cohort evaluated the outcome of hard CHD_1_.83 The AUC for men and women was 0.74 and 0.76, respectively. Models for both sexes were also calibrated, with a chi-square value of 12.6 (p=0.13) in men and 14.2 (p=0.08) in women. The MUCA-II cohort was utilized to develop a model for predicting CVD_17_, and the AUC for the simple version was 0.79 for both sexes. For the point score adaptation, the AUC for men was 0.79 and for women it was 0.78. The National Health Insurance Corporation cohort was used to produce the Korean Stroke Risk Prediction model for 10-year stroke_6_. The AUC for men was 0.82 and for women it was 0.81. Models for both sexes were adequately calibrated, with the male model reporting a chi-square value of 7.7 (p=0.56) and the female model reporting a chi-square value of 14.3 (p=0.16). The HKD Registry was used to develop both a total CHD_1_ and a stroke1 risk model. The stroke risk model reported an AUC of 0.79, and the total CHD_1_ model reported an AUC of 0.74. The study also evaluated how much mismatched stroke outcomes (stroke_5_ and stroke_3_) would affect discrimination, and the AUC reported for stroke_5_ and stroke_3_ was 0.77 and 0.79, respectively (Table 15).

Table 15 Model Development Performance Characteristics (Asia): Internal Validation

Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | Hosmer-Lemeshow Goodness-of-Fit | | O/E Ratio
Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | | | O/E Ratio
Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | χ^2^ | P | O/E Ratio
MUCA-II | CVD_17_ | USA-PRC (Simple)111 | Men | 0.79 | 0.76-0.83
| | USA-PRC (Simple) | Women | 0.79 | 0.75-0.82
| | USA-PRC (Points) | Men | 0.79 | 0.76-0.83
| | USA-PRC (Points) | Women | 0.78 | 0.77-0.82
MUCA | Hard CHD_1_ | CMCS Cox Model83 | Men | 0.74 | 0.70-0.78 | 12.6 | 0.13
| | | Women | 0.76 | 0.70-0.82 | 14.2 | 0.08
NHIC | Stroke_6_ (10 yr) | Korean Stroke Risk Prediction47 | Men | 0.82 | 0.80-0.83 | 7.7 | 0.56
| | | Women | 0.81 | 0.79-0.83 | 14.3 | 0.16
HKD Registry | Stroke_1_ | HKD Stroke Risk Score57 | All | 0.79 | 0.72-0.78
| Stroke_5_/Stroke_1_ | HKD Stroke Risk Score57 | All | 0.77
| Stroke_3_/Stroke_1_ | HKD Stroke Risk Score57 | All | 0.79
| Total CHD_1_ | HKD CHD Risk Score57 | All | 0.74

Note: If the cohort and model outcomes match, only one outcome is listed; otherwise both are listed.

Asia – external validation. The FRS (Wilson) family of models was evaluated in two cohorts in Asia. First, the MUCA cohort was used to evaluate the matched outcome of hard CHD_1_. The AUC for men was 0.71, and for women it was 0.74. Neither sex-specific model was calibrated; for men the chi-square value was 646 (p<0.01) and for women it was 148 (p<0.01). The JapanWork cohort of men was used to evaluate matched 5-year and 10-year total CHD_1_. The AUC for the 5-year total CHD_1_ outcome was 0.71, and for the 10-year total CHD_1_ outcome it was 0.62. The O/E ratio was 0.38 for the 5-year outcome and 0.58 for the 10-year outcome.

The UKPDS-56 model for patients with diabetes was evaluated in one Asian cohort, the HKD Registry, for matched hard CHD_1_. The AUC was 0.61. The UKPDS-60, the stroke risk model, was applied to the same cohort for matched stroke_1_, and the AUC was 0.61.

A custom FRS model55 was applied to the Asia Pacific Cohort Studies Collaboration (APCSC) total Asian cohort for the matched outcome of CVD_8_. The AUC for men was 0.75, and for women it was 0.79. Neither sex-specific model was calibrated, with the male model reporting a chi-square value of 558 (p<0.01) and the female model reporting a chi-square value of 608 (p<0.01). The O/E ratio of the male model was 0.27, and for the female model it was 0.50.

The SCORE risk model was evaluated in the NHP South Asia cohort for unmatched CHD mortality/CVD mortality. The O/E ratio was 4.42.

Finally, the FRS (Anderson) stroke model was applied to the NHP South Asia cohort, and the O/E ratio was 1.88 (Table 16).

Table 16 Model Development Performance Characteristics (Asia): External Validation

Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | Hosmer-Lemeshow Goodness-of-Fit | | O/E Ratio
Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | | | O/E Ratio
Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | χ^2^ | P | O/E Ratio
MUCA | Hard CHD_1_ | FRS Hard CHD [TC] (1998)83 | Men | 0.71 | 0.67-0.75 | 646 | <0.01
| | | Women | 0.74 | 0.69-0.80 | 148 | <0.01
JapanWork | Total CHD_1_ (5 yr) | FRS [?] (Wilson)95 | Men | 0.71 | | | | 0.38
| Total CHD_1_ (10 yr) | | Men | 0.62 | | | | 0.58
HKD Registry | Stroke_1_ | UKPDS 60^57^ | All | 0.59 | 0.55-0.63 | | | 0.51
| Hard CHD_1_ | UKPDS 56^38^ | All | 0.61 | 0.58-0.64
APCSC China | CVD_8_ | FRS (2007 Barzi)55 | Men | 0.75 | 0.72-0.78 | 558 | <0.01 | 0.27
| | | Women | 0.79 | 0.74-0.83 | 608 | <0.01 | 0.50
NHP–South Asia | CHD Mortality/CVD Mortality | SCORE (?)74 | All | | | | | 4.42
| Stroke Mortality/Stroke_4_ | FRS (1991) Stroke74 | All | | | | | 1.88

Note: If the cohort and model outcomes match, only one outcome is listed; otherwise both are listed.

### Remodeling and Recalibration

Americas. Model recalibration is a method in which the source model's intercepts are adjusted by the outcome incidence in the local population, but the risk variable coefficients remain intact. Remodeling is a method in which the risk variables from a prior equation are used to develop a new model in a local population. For this reason, any models that were generated in new cohorts that used the same variables as a previously published risk prediction model were considered remodeling efforts, not new model development. In addition, remodeling adjusts the new model by definition to matching outcomes between the cohort and model, while recalibration does not, since the risk variable coefficients are unchanged from the source model.

The FRS (Wilson) model was recalibrated or remodeled in a number of other cohorts. WHS data were used to remodel both the total cholesterol and low-density lipoprotein versions of the FRS (Wilson) model for total CHD_1_ to the outcome of CVD_3_.54 In both cases, the source models had shown inadequate calibration, while both of the remodeled models showed adequate calibration, with an AUC of 0.79 for both. D'Agostino and colleagues evaluated five U.S. cohorts for 5-year hard CHD_1_ using the outcome-matched variant FRS Wilson model.23 Of the five cohorts, the source model failed calibration tests in Native American women in the SHS cohort, Hispanic men in the PRHHP cohort, and Japanese American men in the HHP cohort. The source model was recalibrated in each of those cohorts, and in each case, the recalibrated model had adequate calibration. The Johns Hopkins Sibling Study was evaluated with the model for matched total CHD_1_ among healthy siblings of patients with known premature CAD.42 The source model was found to be inadequately calibrated for men. The model was recalibrated using the local cohort, and calibration was found to be adequate in the adjusted model. One study combined patients with chronic kidney disease from the ARIC and CHS cohorts and evaluated matched 5- and 10-year hard CHD_1_.45 Calibration was determined to be inadequate for both outcomes for both sexes. After recalibration was performed by replacing the baseline incidence using the local cohort, calibration was adequate for both sexes for the 5-year outcome and for women at 10 years, but calibration remained inadequate in men for the 10-year outcome. This study also remodeled the source model in both sexes for the 10-year outcome. This resulted in adequate calibration for both sexes, and significantly improved discrimination in men from 0.60 to 0.68, and in women it improved from 0.73 to 0.81.

The FRS ATP-III model was recalibrated or remodeled in a number of other cohorts. WHS data were used to perform remodeling of the FRS ATP-III model for hard CHD_1_ to the outcome of CVD_3_.54 The source model had shown inadequate calibration, and the remodeled model was reported to be adequately calibrated, with an AUC of 0.81.

A custom four-variable model from the fourth examination of the FRS was developed to be applied to both the National Health and Nutrition Examination Survey (NHANES) I and II cohorts in order to evaluate model performance in external U.S. cohorts and whether remodeling would result in significant risk variable coefficient changes.25 This study evaluated four of the six variables (excluding diabetes and low-density lipoprotein cholesterol) from the FRS (Wilson) family. All four variables (age, systolic blood pressure, total cholesterol, and smoking) showed significant coefficient variation among models developed from each of the three cohorts in men, but only smoking varied significantly for women. In addition, AUC estimates when each of the cohorts was internally validated or when the custom FRS model was externally validated were nearly identical. Finally, while the O/E ratio was not significantly different than 1.0 for women, the custom FRS model overestimated the mortality rate for men in both NHANES cohorts (Table 17).

Table 17 Model Recalibration/Remodeling Performance Characteristics (Americas)

Cohort Abbreviation | Outcome (Cohort/Model) | Model Name | Group Name | AUC | AUC Variance | Hosmer-Lemeshow Goodness-of-Fit | | O/E Ratio
Cohort Abbreviation | Outcome (Cohort/Model) | Model Name | Group Name | AUC | AUC Variance | | | O/E Ratio
Cohort Abbreviation | Outcome (Cohort/Model) | Model Name | Group Name | AUC | AUC Variance | χ^2^ | P | O/E Ratio
WHS (Val) | CVD_3_ | FRS (Wilson TC) WHS54,# | Women | 0.79 | | | 0.18
| | FRS (Wilson LDL) WHS54,# | Women | 0.79 | | | 0.16
WGHS | CVD_3_ | FRS (ATP-III) WGHS101,# | Women | 0.80 | 0.78-0.82 | 6.2 | 0.62
| | Reynolds Risk Score WGHS101,# | Women | 0.81 | 0.79-0.83 | 7.8 | 0.46
NHANES I | CHD Mortality | FRS (Custom 4 Variable)25 | Men | 0.71
| | | Women | 0.80 | | | | 0.90
NHANES II | CHD Mortality | FRS (Custom 4 Variable)25 | Men | 0.74
| | | Women | 0.76 | | | | 0.65
WHS | CVD_3_ | FRS (ATP-III) WHS101,# | Women | 0.81 | | | 0.25
SHS | Hard CHD_1_ (5 yr) | SHS Best Cox23 | Men | 0.77 | | 2.7
| | | Women | 0.86 | | 3.5
ARIC | Hard CHD1 (5 yr) | ARIC Best Cox23 | White Men | 0.76 | | 5.4
| | | Black Men | 0.70 | | 7.2
| | | White Women | 0.84 | | 5.2
| | | Black Women | 0.85 | | 3.4
HHP | Hard CHD_1_ (5 yr) | HHP Best Cox23 | Men | 0.74 | | 2.6
PRHHP | Hard CHD_1_ (5 yr) | PR Best Cox23 | Men | 0.72 | | 7.2
CHS | Hard CHD_1_ (5 yr) | CHS Best Cox23 | Men | 0.69 | | 6.8
| | | Women | 0.68 | | 6.8
JHSS | Total CHD_1_ | FRS (Wilson) D'Agostino JHSS42$ | Men | | | | 9.0
| | | Women | | | | 8.0
ARIS/CHS | Hard CHD_1_ (5 yr) | FRS CKD ARIS/CHS45$ | Men | | | 13.7
| | | Women | | | 8.7
| Hard CHD_1_ (10 yr) | FRS CKD ARIS/CHS45$ | Men | | | 32.3
| | | Women | | | 8.9
| | FRS (1998) CKD Best Cox Remodel45 | Men | 0.68 | | 4.0
| | | Women | 0.81 | | 2.5

Note: If the cohort and model outcomes match, only one outcome is listed; otherwise both are listed. Please note that remodeling changes the outcome to match the cohort, regardless of the source data for the variables. Also note that a model is considered a remodeling effort if it uses the same variables as a previous model.

# indicates remodeling based upon the preceding cohort;

$ Indicates recalibrated based upon the preceding cohort.

Europe. The FRS (Anderson) family of models was recalibrated or remodeled in three separate cohorts. The QRESEARCH cohort was used to recalibrate the model using the Nationwide Instruction for Cardiovascular Education method for the matched outcome of CVD_1_.46 The AUC for men was 0.78, and for women it was 0.80. The Cardiff cohort was used to perform remodeling for CVD_2_, and the AUC for men and women was 0.65 and 0.68, respectively.85 Finally, the BRHS cohort of men was used to remodel both CHD mortality and total CHD_1_ outcomes.88 The new CHD mortality model was adequately calibrated (χ^2^ = 3.4; p=0.91), but the total CHD model was inadequately calibrated (χ^2^ = 24.6; p<0.01).

The FRS (Wilson) family of models was recalibrated or remodeled in three separate cohorts. The EPIC-Norfolk cohort was used to perform remodeling, and the AUC for men was 0.72, and for women it was 0.80.^36^ The VERIFICA cohort was used to perform remodeling for the outcome of total CHD_1_. The AUC for men was 0.69, and for women it was 0.81. Both sex-specific models reported adequate calibration. The CUORE cohort of men was used to perform remodeling for the hard CHD_2_ outcome using both the D'Agostino and Chambless methods.76 The D'Agostino method resulted in an AUC of 0.72, but the calibration was inadequate (χ^2^ = 27.1; p<0.01). The Chambless method resulted in an AUC of 0.72, and the calibration was also inadequate (χ^2^ = 19.9; p=0.01).

The CUORE cohort was also used to remodel the PROCAM model for the outcome of hard CHD_2_, using both the D'Agostino and Chambless methods. In both cases, the AUC was 0.74, and there was inadequate calibration.76 For the D'Agostino method, the chi-square value was 220 (p<0.01), and for the Chambless method, it was 53 (p<0.01) (Table 18).

Table 18 Model Recalibration/Remodeling Performance Characteristics (Europe)

Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | Hosmer-Lemeshow Goodness-of-Fit | | O/E Ratio
Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | | | O/E Ratio
Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | χ^2^ | P | O/E Ratio
QRESEARCH | CVD_1_ | FRS (1991) NICE Recal35$ | Men | 0.78 | 0.78-0.78
| | | Women | 0.80 | 0.80-0.80
Cardiff DM | CVD_2_ | FRS (1991) Cardiff DM85,# | Men | 0.65
| | | Women | 0.68
BRHS | CHD Mortality | FRS (1991) BRHS88$ | Men | | | 3.4 | 0.91
BRHS | Total CHD1 | FRS (1991) BRHS88$ | Men | | | 24.6 | <0.01
EPIC-Norfolk | Total CHD_1_ | FRS (1998) EPIC36,# | Men | 0.72 | 0.70-0.75
| | | Women | 0.80 | 0.78-0.83
VERIFICA | Total CHD_1_ | FRS (1998) REGICOR VERIFICA58,# | Men | 0.69 | | 5.1 | 0.08 | 1.26
| | | Women | 0.81 | | 2.7 | 0.26 | 1.03
VERIFICA | Total CHD_1_ | FRS (1998) REGICOR VERIFICA58,# | Patients w/Diabetes | | | 1.4 | 0.99
CUORE | Hard CHD_2_ | FRS (1998 TC) D'Ag CUORE76,# | Men | 0.72 | 0.67-0.78 | 27.1 | <0.01 | 0.78
CUORE | Hard CHD_2_ | FRS (1998 TC) Chb CUORE76,# | Men | 0.72 | 0.67-0.78 | 19.9 | 0.01 | 1.01
CUORE | Hard CHD_2_ | PROCAM (Cox) D'Ag CUORE76,# | Men | 0.74 | 0.68-0.79 | 220.0 | <0.01 | 0.34
CUORE | Hard CHD_2_ | PROCAM (Cox) Chb CUORE76,# | Men | 0.74 | 0.68-0.79 | 53.0 | <0.01 | 1.01

Note: If the cohort and model outcomes match, only one outcome is listed; otherwise both are listed.

# indicates remodeling based upon the preceding cohort;

$ Indicates recalibrated based upon the preceding cohort.

Asia. The FRS (Anderson) family of models was the source for recalibration among both the MUCA and MUCA-II cohorts. The outcome in MUCA was matched hard CHD_1_, and in MUCA-II it was matched CVD_17_. The MUCA cohort reported an AUC in men of 0.74 and in women it was 0.76. The MUCA-II cohort reported an AUC of 0.80 among men and 0.79 among women. The custom FRS model55 was remodeled using the APCSC China cohort, and the AUC for men was 0.76, and for women it was 0.80. The model was not adequately calibrated for men (χ^2^ = 16.7; p=0.03) but was calibrated for women (χ^2^ = 12.2; p=0.15) (Table 19).

Table 19 Model Recalibration/Remodeling Performance Characteristics (Asia)

Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | Hosmer-Lemeshow Goodness-of-Fit | | O/E Ratio
Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | | | O/E Ratio
Cohort Abbreviation | Cohort Outcome | Model Name | Group Name | AUC | AUC Variance | χ^2^ | P | O/E Ratio
MUCA-II | CVD_17_ | FRS (1998) MUCA-II111,# | Men | 0.80 | 0.76-0.83
| | | Women | 0.79 | 0.76-0.83
MUCA | Hard CHD_1_ | FRS (1998) MUCA83,# | Men | 0.74 | 0.70-0.78 | 31.5 | <0.01
| | | Women | 0.76 | 0.70-0.82 | 16.9 | 0.03
APCSC China | CVD_8_ | FRS (Barzi 2007) APCSC55,# | Men | 0.76 | 0.73-0.79 | 16.7 | 0.03
| | | Women | 0.80 | 0.75-0.84 | 12.2 | 0.15

Note: If the cohort and model outcomes match, only one outcome is listed; otherwise both are listed.

# indicates remodeling based upon the preceding cohort.

## Synthesis of Data Specific to Key Question 1

KQ1: Do any of the currently available tools for the prediction of cardiovascular risk in a North American population offer clear advantages over the others in predicting incident CHD, cerebrovascular stroke (stratified by thrombotic or hemorrhagic type), or a combination of these two?

The external validations with the strongest evidence are those with matched outcomes among North American and European cohorts. Asian cohorts are less applicable, as it has been well-established that those populations have significantly different outcome event rates of CHD and cerebrovascular disease than the general U.S. population, and are therefore not discussed in this section.

A 5-year version of the 1998 FRS model was evaluated in five different U.S. cohorts for matched outcomes. This study found that prediction performance was superior in women across all cohorts. In addition, while relative risk performance was maintained across all cohorts, absolute risk prediction was poor in Asian American or Hispanic cohorts.23 The 1991 FRS model was evaluated in high-risk patients (patients with <10 percent FRS risk were excluded at baseline) for matched outcomes and had an acceptable O/E ratio.100 The 1998 FRS model was evaluated in siblings of patients with early onset CVD for matched outcomes, and the tool significantly underpredicted outcomes.42 The 1998 FRS model was evaluated in male veterans for matched outcomes and had an acceptable O/E ratio.97 The FRS ATP-III model was evaluated in young adults aged 18 to 39 years for matched outcomes and it significantly overpredicted outcomes.49

British patients with diabetes and predominantly white workers from New Zealand were both evaluated using the 1991 FRS equation with matched outcomes.85, 89 Female patients with diabetes had an acceptable O/E ratio, but outcomes for men were underpredicted. The male worker outcomes were underpredicted, and the female worker outcomes were acceptably predicted. The 1991 FRS equation was also used to evaluate the PROCAM cohort with matched outcomes, and outcomes were significantly overpredicted.92 Australian Aborigines were evaluated with the 1991 FRS model for matched outcomes, and the model significantly underpredicted the outcome rate.77 Two outcome versions of the 1991 FRS model were evaluated for matched outcomes in a cohort of British men, and both outcomes were overpredicted.88 A multinational cohort of patients from Western Europe and Israel was evaluated with the 1991 FRS model for matched outcomes, and the tool significantly overpredicted outcomes.94 The 1998 FRS model was used to evaluate Czech men without diabetes for matched outcomes, and it significantly underpredicted outcomes.56 A cohort of Spanish patients was evaluated with the 1998 FRS model for matched outcomes, and it significantly overpredicted outcomes.56 A cohort of French men was evaluated with the 1998 FRS model for matched outcomes, and it significantly overpredicted outcomes.110 A cohort of French renal transplant patients was evaluated with the 1998 FRS model, and it significantly underpredicted outcomes.82 A cohort of German patients (including those with diabetes) was evaluated with the ATP-III FRS model for matched outcomes, and the O/E ratio was acceptable.104 A cohort of elderly patients from the Netherlands was evaluated with the ATP-III FRS model for matched outcomes, and the outcomes were significantly overpredicted for men and acceptably predicted for women.48 The German PROCAM cohort of men (including those with diabetes) was evaluated with the ATP-III FRS model for matched outcomes, and the tool significantly overpredicted risk.14 A cohort of Swedish men was evaluated with the ATP-III FRS model for matched outcomes, and it drastically overpredicted risk.80

An Austrian cohort of patients was evaluated with the SCORE model for matched outcomes, and the outcomes were significantly overpredicted.68 An elderly cohort of Norwegian patients without diabetes was evaluated with the SCORE model for matched outcomes, and the tool overpredicted risk.44 A middle-aged cohort of Norwegian patients without diabetes was evaluated with the SCORE model for matched outcomes, and the high-risk version overpredicted outcomes and the low-risk version underpredicted outcomes.44 Another Norwegian cohort of patients aged 20 to59 years was evaluated with the SCORE model for matched outcomes, and the tool overpredicted outcomes.106 French and Irish cohorts in the PRIME study were evaluated with the PROCAM model, and the tool overpredicted risk.90 A Swedish cohort of men was evaluated with the PROCAM model for matched outcomes, and it also overpredicted risk.50 A cohort of German men was evaluated with the PROCAM model for matched outcomes, and it overpredicted risk.29 A cohort of Scottish patients was evaluated with the ASSIGN model, and it overpredicted risk.29 The Salford cohort of patients with diabetes was evaluated using the DARTS model for matched outcomes, and the risk estimation was acceptable.63

## Synthesis of Data Specific to Key Question 2

KQ2a: Do tools that treat diabetes as a CVD or CHD outcome equivalent have different performance characteristics than those that use diabetes as an independent risk factor for those outcomes?

KQ2b: Is the appropriateness of using diabetes as a coronary risk equivalent modified by the number of other cardiac risk factors that the individual has?

Six diabetic cohorts were used to develop risk prediction models, and 11 diabetic cohorts were used in external validation of diabetes-specific risk models for CVD, CHD, or stroke outcomes.38, 57, 63, 72, 73, 78, 85, 96, 104, 107, 108, 119 Thirteen non-diabetic cohorts were used in either primary model development or external validation of risk models excluding diabetes or general purpose models.

### Diabetes Cardiovascular Risk Models

The most widely cited and externally validated risk model for patients with type 2 diabetes is the UKPDS risk model, which was developed in 4,540 white and Afro-Caribbean British patients for hard CHD_1_.119 The tool was developed among patients aged 25 to 65 years to predict greater than 4-year event rates. Events up to 4 years were excluded because the standardized mortality ratio observed in the general population (0.94 for men, 0.96 for women) was less than that, probably because patients with life threatening illnesses and those older than age 65 years at baseline were excluded from the study cohort. Risk variables used in the model are summarized in Table 24.

Table 24 Model and Online Tool Comparison

Model | Model Type | Outcome | Test Patient
Model | Model Type | Outcome | 1 | 2 | 3 | 4 | 5
FRS (Anderson)
DBP | Model Generated | CVD_2_ | 0.05 | 0.09 | 0.43 | 0.66 | N/A
SBP | Model Generated | CVD_2_ | 0.05 | 0.09 | 0.49 | 0.70 | N/A
Points | Model Generated | CVD_2_ | 0.05 | 0.10 | 0.42 | N/A | N/A
| Online | CVD_2_ | 0.05 | 0.19 | 0.44 | N/A | N/A
FRS (Wilson)
TC | Model Generated | Total CHD_1_ | 0.06 | 0.12 | 0.20 | 0.51 | 0.16
LDL | Model Generated | Total CHD_1_ | 0.05 | 0.13 | 0.18 | 0.33 | 0.19
| Online | Total CHD_1_ | 0.03 | 0.03 | 0.06 | 0.39 | 0.16
FRS (ATP-III)
Points | Model Generated | Hard CHD_1_ | 0.02 | 0.03 | Outcome | Outcome | 0.22
| Online | Hard CHD_1_ | 0.03 | 0.03 | Outcome | Outcome | N/A
UKPDS
| Model Generated | Hard CHD_1_ | N/A | N/A | 0.16 | 0.29 | N/A
| Online | Hard CHD_1_ | N/A | N/A | 0.15 | 0.33 | N/A
Other
PROCAM (Point Score) | Model Generated | Hard CHD_1_ | 0.01 | 0.11 | 0.18 | >0.30 | N/A
SCORE (High Risk) | Model Generated | CHD Mortality | N/A | 0.01 | 0.02 | 0.16 | N/A

Another externally validated type 2 diabetes cardiovascular risk model is the DARTS model, which was developed in 4,569 patients in Tayside, Scotland for hard CHD_1_.63 Only 1 percent of the cohort was non-white. Type 1 diabetes was excluded, but there was no severity of illness or age exclusions in this cohort. Risk variables used in the model are summarized in Table 24.

An internally validated type 2 diabetes risk model was developed in 7,067 Chinese patients from the HKD Registry for total CHD_1_.38 It should be noted that 6.2 percent of the cohort had peripheral artery disease and 3.9 percent of the cohort had a prior stroke (Table 20).

Table 20 Variables Used By Cardiovascular Risk Models for Patients With Diabetes

Variable | UKPDS96 | DARTS63 | HKD38
Age | At diagnosis | At diagnosis | *
Sex | * | * | *
Race | Afro-Caribbean
Smoking status | Current | Current & Former | Current
DM diagnosis duration | | * | *
eGFR | | | *
Spot urine A/C ratio | | | *
Lipid profile | Total/HDL Ratio | Total | Non-HDL
Hemoglobin A_1_c | * | *
Systolic BP | * | *
Treated hypertension | | *
Height | | *

* Indicates that the variable was used by that model, and any text describes the particular subset of the variable in question that was used in the model.

Diabetes as a modeling risk factor. There is significant evidence to support the conclusion that the relative risk of the known risk factors for CVD outcomes can vary among different cohorts within the United States, as well as between the United States and Europe or Asia.

In a study by D'Agostino and colleagues for the National Heart Lung and Blood Institute CHD Prediction Workshop, a total of seven U.S. cohorts were evaluated for 5-year hard CHD_1_.23 For men and women in each cohort, an original and remodeled FRS (Wilson 1998) equation was applied to each sex in each cohort. Among men, there were significant differences between the FRS cohort and the Physicians' Health Study cohort, Japanese Americans in the HHP cohort, Hispanics in the PRHHP cohort, Native Americans in the SHS cohort, and the CHS cohort. Among women, there were significant differences between the FRS cohort and African Americans in the ARIC cohort and Native Americans in the SHS cohort. Absolute risk performance for the Framingham risk score in the other cohorts was acceptable for all except for men in the HHP and PRHHP cohorts and women in the SHS cohort. A summary of relative risk for hard CHD_1_ among patients with diabetes is shown in Table 21.

Table 21 Comparison of Relative Risk for Hard CHD_1_ Among Patients With Diabetes Across Seven U.S. Cohorts23

Cohort | Diabetes Relative Risk (95% CI)^*^
Men
Framingham Heart Study | 1.69 (1.11-2.57)
ARIC (White) | 2.42 (1.69-2.57)
ARIC (Black) | 1.40 (0.75-2.62)
Physician's Heart Study | 1.54 (1.05-2.26)
Honolulu Heart Program | 2.55 (1.82-3.57)
Puerto Rico Heart Program | 2.07 (1.50-2.85)
Strong Heart Study | 4.29 (2.27-8.10)^#^
Cardiovascular Health Study | 1.47 (0.89-2.44)
Women
Framingham Heart Study | 2.38 (1.40-4.06)
ARIC (White) | 3.62 (2.21-5.94)
ARIC (Black) | 2.01 (1.16-3.48)
Strong Heart Study | 8.63 (2.55-29.16)^#^
Cardiovascular Health Study | 2.29 (1.23-4.23)

* These relative risks were adjusted for age, systolic and diastolic blood pressure, total cholesterol, high-density lipoprotein cholesterol, and current smoking status.

# indicates significant difference between the cohort and the FRS.

A study by the Diverse Populations Collaborative Group Investigators that compared 16 cohorts from the Americas and Europe found that the proportion of patients with diabetes ranged from 0.2 (rural patients in the Yugoslavia Cardiovascular Disease Study) to 9.1 percent (Japanese Americans in the HHP).30 The overall CHD mortality rate per 1,000 person-years ranged from 1.0 (rural patients in the PRHHP) to 6.5 percent (Tecumseh Community Health Study). When comparing multivariate models of age, systolic blood pressure, total cholesterol, current smoking, and diabetes across these cohorts, diabetes relative risk among men varied widely from 1.24 (range, 0.61–2.51) in the control arm of the Multiple Risk Factor Intervention Trial to 8.05 (range, 3.80–17.03) in the random sample of the Lipid Research Clinics Follow-Up Study. Among women, the relative risk varied from 1.32 (range, 0.62–2.82) in the Tecumseh Community Health Study to 8.67 (range, 3.81–19.77) in the Norwegian Counties Study (Table 22).

Table 22 Comparison of Diabetes Relative Risk Across 16 North American, European, and Asian Cohorts

Cohort | Diabetes Relative Risk^*^ (95% CI)
Men
Framingham Heart Study23$ | 1.99 (1.23-3.21)
NHANES I25$ | 2.17 (1.60-2.94)
NHANES II25$ | 1.73 (1.15-2.60)
Honolulu Heart Program23$ | 2.85 (2.17-3.75)
Puerto Rico Heart Health Program23$
Urban | 2.88 (2.07-4.03)
Rural | 2.86 (1.23-6.60)
HDFP (Regular Care)38$ | 1.79 (1.06-3.05)
MRFIT (Usual Care)138$ | 1.24 (0.61-2.51)
Tecumseh Community Health Study139 | 1.85 (0.94-3.66)
Renfrew and Paisley Study66 | 2.73 (1.93-3.87)
Glostrup Cohort140 | 2.52 (1.26-5.02)
Iceland Reykjavik Study141 | 1.78 (1.17-2.71)
Israeli Ischemic Heart Disease Study142 | 2.31 (1.86-2.87)
Norwegian Counties Study44 | 3.98 (2.62-6.03)^#^
Yugoslavia Cardiovascular Disease Study17 | 4.63 (2.15-9.96)^#^
Lipid Research Clinics Follow-Up Study99
Random Sample | 8.05 (3.80-17.03)^#^
Hyperlipidemia | 3.79 (1.60-3.05)^#^
Women
Framingham Heart Study23 | 4.67 (2.70-8.07)
NHANES I25 | 2.50 (1.89-3.30)
NHANES II25 | 2.76 (1.92-3.97)
HDFP (Regular Care)38 | 2.57 (1.37-4.81)
Tecumseh Community Health Study139 | 1.32 (0.62-2.82)
Renfrew and Paisley Study66 | 3.65 (2.36-5.65)
Norwegian Counties Study44 | 8.67 (3.81-19.77)
Iceland Reykjavik Study141 | 3.81 (2.25-6.44)

* These relative risks were adjusted for age, systolic blood pressure, total cholesterol, and current smoking status.

# indicates significant difference between the cohort and the FRS.

$ indicates a U.S. cohort.

Remodeling efforts of established risk models for other cohorts also serves to illuminate systematic relative risk differences between risk factors. The UKPDS risk model was remodeled using the HKD Registry, and a comparison of hazard ratios in the UKPDS and remodeled HKD models is shown in Table 23. Comparing the variable estimates between the original and remodeled equation for the Chinese cohort revealed that sex and hemoglobin A_1c_ were significantly different predictors of CHD between the two cohorts.

Table 23 Comparison of Variable Coefficients Between UKPDS and HKD Registry for Coronary Heart Disease Outcome in Patients With Diabetes

Variable | UKPDS119 (95% CI) | HKD Registry38 (95% CI)
Age (1 year of age at Dx DM) | 1.059 (1.05-1.07) | 1.04 (1.03-1.06)
Female | 0.525 (0.42-0.63) | 0.81 (0.59-1.10)
Afro-Caribbean ethnicity | 0.390 (0.19-0.59) | ---
Current smoker | 1.350 (1.11-1.59) | 1.40 (0.99-1.98)
HgbA_1c_ (per 1% increase) | 1.183 (1.11-1.25) | 1.03 (0.95-1.16)
SBP (per 10 mmHg increase) | 1.088 (1.04-1.14) | 1.09 (1.01-10.17)
Total/HDL lipid ratio | 3.845 (2.59-5.10) | 2.74 (1.67-4.50)

Diabetes risk model external validations. The model development study by Donnan and colleagues used 4,569 patients from Salford, England to externally validate the model developed in the DARTS cohort.

Diabetic cohorts evaluated by non-specific risk models. A small cohort of French patients with diabetes was evaluated by the 1998 FRS model, and the O/E ratio was acceptable, but the outcomes were fairly mismatched.72 The Poole Diabetes Study was evaluated using the 1991 FRS model for both total CHD and CVD, although the definitions varied between cohort and model in each case in very small ways.73 Both outcomes were significantly underpredicted in the cohort by the risk model. The NHS Trust cohort was evaluated by the PROCAM model for a mismatched outcome between total and hard CHD, and the model significantly underpredicted the number of outcomes.78 The Cardiff Diabetes Database was evaluated with the 1991 FRS model for a completely matched CVD outcome, and the model underpredicted the number of outcomes among both sexes, but was marginally better for women.85 A study on 716 patients in Munich, Germany was evaluated by the 1998 FRS equation for total CHD, and the predicted and observed outcomes were not significantly different.104 However, there was an outcome mismatch due to measurement of hard CHD in the cohort, which would underestimate the number of outcomes compared to what the model would expect. The PREDICT cohort in London was evaluated with the 1991 FRS equation, but the study did not report calibration or the predicted number of outcomes.108

## Assessment of Tools Available Online

We identified 44 online tools for calculating CVD risk using the approach described in the Methods section. The models on which these tools are based, along with their online location, are listed in Appendix D/Summary Table 1.

We used a set of test patients to predict risk using SAS versions of the original models and the online tools that purported to use those models. We compared our SAS-generated risk to those generated with the online tools (Table 24). All of the online versions had some variation from the referenced source model, but in most cases these differences were modest. FRS (Anderson) Online did show a large difference for Patient 2 (0.19 vs. 0.09). FRS (Wilson) Online also showed a large difference for Patient 2 (0.03 vs. 0.13). In addition, there were large variations among the risk tools for each patient. Some of the variation can be explained by the different outcomes the models were attempting to model. In particular, the FRS (Anderson) model predicts a CVD outcome with a large number of components, which is known to be 2 to 3 times as high as the hard CVD outcome. For patients without diabetes, risk measurements were very consistent across models. For patients with diabetes, risk estimates varied greatly.

Figures 2 and 3 show the variation in predicted outcomes obtained for two of the test patients when only age was varied (from 35 to 65 years). As age increases, the model predictions demonstrate increasing variation.

Figure 2 Variation in Predicted Outcomes, Patient 2

Figure 2 is a line graph that demonstrates the differences in predicted outcomes by each tool when we hold all variables constant except age. In the figure, the model estimates are closer at age 35 years, but diverge significantly by age 65 years. In Patient 2, by age 65 years the model predictions range from about 0.05 to 0.2.

Figure 3 Variation in Predicted Outcomes, Patient 3

Figure 3 is a line graph that demonstrates the differences in predicted outcomes by each tool when we hold all variables constant except age. In the figure, the model estimates are closer at age 35 years, but diverge significantly by age 65 years. In Patient 3, by age 65 years the lines have diverged such that the risk estimates range from 0.05 to 0.5.

## Quality of the Literature

We assessed the quality of each study included in our review. Individual results for quality scoring are presented in Appendix M/Summary Table 10, and a summary of quality scores is presented in Figure 4, with the proportion of studies achieving each level of each quality measure represented by a horizontal bar.

Figure 4 Summary of Quality Scores

Figure 4 is a bar graph showing the distribution of quality scores. The first column is the particular quality question. The second through fourth columns are bar graphs. Each column represents a geographical region. The first is “all,” the second “Americas,” the third “Asia,” and the fourth “Europe.” Of the total 83 studies, 28 are in the Americas, eight in Asia, and 47 in Europe. The bars represent the number of studies that received each possible score for each quality scoring question.

No quality measure was fully achieved by 100 percent of the included studies. Fewer than half of the studies in any geographic region provided an adequate description of the study population or the inclusion/exclusion criteria on which the initial cohort was built. Very few studies had adequate follow-up (<20 percent), and among those with substantial loss to follow-up, none accounted for the potential effects of the loss. Internal validation should be a basic requirement for the reporting of model development studies, but fewer than 30 percent overall reported measures of internal validation. Among U.S. studies in which existing models were validated, both discrimination and calibration were almost always (88 percent) reported, although this was not the case among studies in the other geographic areas, which reported these measures less than 40 percent of the time.