# Methods

Here we document the procedures that the Vanderbilt Evidence-based Practice Center used to develop this report on tools for predicting cardiovascular risk. We first describe the strategy for identifying articles relevant to the key questions, the inclusion/exclusion criteria, and the process used to abstract relevant information from the eligible articles and generate summary tables.

## Literature Review Methods

### Inclusion and Exclusion Criteria

The inclusion/exclusion criteria were developed in consultation with the Technical Expert Panel to capture the literature most closely related to the key questions. Inclusion criteria are summarized in Table 2.

Table 2 Inclusion Criteria

Category | Criteria
Study population | Asymptomatic adults
Study settings and geography | Any clinical/research settings in any country
Publication languages | English only
Admissible evidence (study design and other criteria) | [underlined: Admissible designs]; - Randomized controlled trials, controlled clinical trials, cohorts; - Study size ≥200
| [underlined: Other criteria]; - Original research studies that provide sufficient detail regarding methods and results to enable use and adjustment of the data and results; - Studies must attempt either internal or external validation; - Studies must report on one or both of the following outcomes:; ◦ Coronary artery disease (nonfatal and fatal MI and sudden coronary heart disease death); ◦ Cerebrovascular stroke (thrombotic/hemorrhagic); - Relevant outcomes must be able to be abstracted from data presented in the papers

We excluded studies that 1) were not published in English; 2) did not report information pertinent to the key questions; 3) had fewer than 200 participants at enrollment; 4) were not original studies; and 5) did not perform any internal or external validation of the model. For this review, the relevant population was men and women who were currently asymptomatic for CVD.

### Literature Search and Retrieval Process

Search literature. We began with a focused search on known and unknown CVD risk assessment tools (Appendix A) to get an idea of the size of the literature, and then searched for review articles to provide overview and context.

As we developed each of the search components with input from previous systematic reviews, we employed an approach of iterative refinement, using a pool of approximately 50 relevant articles previously identified as a quasi-validation set to assess recall of our search iterations (i.e., whether our searches retrieved or missed known items of interest).31-33

Article selection process. Once we identified articles through the electronic database searches (published January 1, 1999 to February 24, 2009), review articles, and bibliographies, we examined abstracts of articles to determine whether studies met the criteria. Two reviewers separately evaluated the abstracts for inclusion or exclusion (Appendix B). If either reviewer concluded that the article could be eligible for the review based on the abstract, we retained it.

Of the entire group of 3,499 articles, 636 required full-text review. For the full article review, two reviewers read each article and decided whether it met the inclusion criteria (Appendix B).

## Literature Synthesis

### Development of Summary Tables and Data Abstraction Process

The data for this project were abstracted into a database (Appendix C) designed to capture study information such as cohort characteristics, risk model characteristics, model performance statistics, and quality review elements. We captured information about the study populations to allow for stratification of results by variables, including sex and geographic area.

Summary tables were developed using database queries and then formatted in Microsoft Word for presentation. The tables are designed to provide overviews of the available literature, the diversity of populations used to develop the risk assessment models, and the degree to which the variables in the models and model performance vary.

The team was trained to abstract by pulling relevant data from several articles into the database and then reconvening as a group to discuss the utility of the table design. We repeated this process through several iterations. The content lead (Dr. Matheny) reviewed each abstraction to ensure accuracy and completeness. The full research team met regularly during the article abstraction period and discussed global issues related to the data abstraction process.

### Assessment of Available Tools

In addition to assessing the studies and models presented in the literature, we searched for all available online tools and documented their location and the model on which they purported to be based. We then used the online tools to calculate risk for five test cases, in order to identify any variation in estimated risk. The test cases are presented in Table 4.

We used a two-pronged Internet search strategy to find potential sites where online risk assessment tools are available. First, we searched specifically for each model identified through the literature search using the following approaches:

1. (model name) + online tool
2. (model name) + online tool + CVD
3. (model name) + risk score
4. (model name) + risk score + CVD
5. (model name) + online calculator + CVD
6. (model name) + available CVD online calculator

We then searched for additional tools using the following set of terms, and cross-referenced the results with those already identified to find any additional tools:

1. CVD available online calculators
2. CVD online assessment tools
3. Calculating CVD risk online
4. Calculating CVD and stroke risk
5. CVD online risk assessment tools

Characteristics of five test patients (Table 3) were developed and applied in each of the online tools (Appendix D/Summary Table 1). In addition, statistical analysis software (SAS) models were developed for each of the models that the online tools purported to use, and the test patient characteristics were applied to those as well.

Table 3 Test Patient Characteristics

| Patient 1 | Patient 2 | Patient 3 | Patient 4 | Patient 5
Age (years) | 43 | 54 | 58 | 63 | 77
Female | No | Yes | Yes | No | Yes
Race | White | Black | White | Black | White
Cholesterol Data^*^
Total cholesterol (mg/dL) | 220 | 245 | 237 | 197 | 260
High-density lipoprotein cholesterol (mg/dL) | 43 | 46 | 35 | 22 | 33
Low-density lipoprotein cholesterol (mg/dL) | 134 | 167 | 133 | 89 | 173
Triglycerides (mg/dL) | 83 | 144 | 236 | 244 | 145
Taking lipid medication | No | No | Yes | Yes | No
Hypertension Data
Systolic blood pressure (mmHg) | 118 | 143 | 139 | 151 | 148
Diastolic blood pressure (mmHg) | 76 | 85 | 85 | 93 | 91
Taking hypertension medication | No | No | Yes | Yes | No
Diabetes Data
Patient self-report | No | No | Yes | Yes | No
Physician reported diagnosis | No | No | Yes | Yes | No
Fasting baseline glucose | 89 | 104 | 145 | 169 | 135
Diabetes medication use | No | No | Yes | Yes | No
HgbA_1c_ (%) | 5.7 | 5.8 | 7.4 | 8.5 | 6.5
Smoking
Current | No | No | No | Yes | No
Former | No | No | Yes | No | Yes
Never | Yes | Yes | No | No | No
Other Variables
Left ventricular hypertrophy by EKG | No | No | Yes | Yes | Yes
Body mass index | 24.3 | 31.4 | 32.6 | 28.6 | 27.6
Family history of premature coronary heart disease | No | Yes | No | Yes | Yes
Family history of myocardial infarction | No | Yes | No | Yes | No
Chronic kidney disease | No | No | No | Yes | No
Atrial fibrillation | No | No | No | No | Yes
Rheumatoid arthritis | No | No | No | No | No
Microalbuminuria | No | No | Yes | No | No
Macroalbuminuria | No | No | No | Yes | No

* To convert to mmol/L, divide entry by 38.67 (except for triglycerides).

### Assessment of Study Quality

We assessed the quality of individual studies across multiple dimensions using the following questions. We did not assign quality scores to the individual studies or the literature as a whole, but chose instead to present patterns of quality. Quality assessment questions were developed to reflect the importance of fully characterizing a population in which a model is developed, and the prevalence of missing data and loss to follow-up. In addition, evaluation methods and measures were pursued.

Does the article state both the inclusion and exclusion criteria, and any additional exclusions that were made after cohort inception? The inclusion and exclusion criteria provide relevant information about how the cohort was formed and characterized. However, some articles use separate criteria to create an analysis subcohort, in which case, the initially established criteria would not adequately describe the cohort.

Was the study population well described? Participant characteristics that might affect outcomes should be fully characterized in order to interpret conclusions or ascertain the relevance of a given model to a new population.

Was the loss to follow-up over the course of the study less than 20 percent? Lack of complete information on the cohort may distort the assessed implications of various predictor variables.

If loss to follow-up was more than 20 percent, did the authors acknowledge the potential effects on the model? The potential for differential loss to follow-up to result in a model that “works” in a non-representative population is high, particularly in studies with long-term follow-up. It is helpful if authors of studies in which a large proportion of the population is lost to follow-up support the reader's interpretation.

Did missing data cause more than 20 percent of the population to be excluded from the model? Even if individuals were not lost to follow-up in a given study, the failure to collect complete data could result in a model being developed in a substantially smaller subcohort that is not entirely reflective of the intended population. Authors should make every attempt to gather data from the greatest number of study participants possible.

If missing data caused more than 20 percent of the population to be excluded, was a missing data technique applied? Approaches to evaluating the potential impact of missing data include sensitivity analyses. These methods can vary from evaluating the change in study results between only the patients with full data to various imputation methods that fill in the missing patient data. Imputation methods can range from simple sample mean imputation to more sophisticated multiple imputation methods.

For validation studies, did the authors report both discrimination and calibration? The degree to which each study evaluated the model performance, regardless of whether it was an internal or external model evaluation, is characterized in this quality assessment. Measures of discrimination include the area under the receiver operating characteristic curve (AUC) and the C statistic. Measures of calibration include the observed-to-expected (O/E) ratio, calibration plots or curves, and the Hosmer-Lemeshow goodness-of-fit test. Less common performance measurements, such as the Brier score, were also occasionally reported.

For model development, did the authors assess internal validation? This item assesses whether the model performance was reported for the cohort in which the model was developed. Any of the discrimination or calibration measures would count for this assessment.

### Presentation of Results In This Report

For Key Question 1, we separated all of the modeling studies into three categories, depending on the outcome: CHD, CVD, and cardiovascular accident (CVA). Special emphasis was placed on those models that had been externally validated at least once, because the critical importance of this question relates to the impact model use has on patients in cohorts other than the development cohort.

For Key Question 2, we separated the modeling studies into three categories, depending on whether the cohort included no, some, or only patients with diabetes. Special emphasis was placed on those models that had been externally validated at least once. Again, this was because the critical importance of this question relates to the impact model use has on patients in cohorts other than the development cohort.

All of the models developed in diabetic populations were summarized in order to discuss which variables were chosen in these models and any recalibration or remodeling that was performed. This was best explored in those studies that collected multiple cohorts and evaluated a common set of risk factors for a matched outcome using an identical method. These multivariate modeling methods can be used equally for risk factor exploration and risk prediction modeling. In the primary inclusion/exclusion criteria, any study that did not report any risk prediction performance characteristic was excluded, but some exclusive risk factor exploration studies are referenced here for completeness.

### Key Definitions

In order to interpret these results, it is important to have common definitions of discrimination and calibration. Discrimination is a measurement of how well a model can separate those patients that will experience the outcome from those who will not, but it does not address individual risk predication accuracy. Discrimination also gives a general sense of how much of the underlying information leading to the outcome has been captured by the risk. The most common measurements of discrimination are AUC and the C statistic.134 Graphically, this is represented by plotting sensitivity versus 1 minus specificity over all the possible probability cut-off points in the prediction model. The area under that plot is the AUC measurement, with 1.00 reflecting perfect separation between cases and non-cases, and 0.50 reflecting a modeling performance that is no better than chance in detecting the outcome of interest. In some domains in which outcomes are estimated a few days or weeks into the future, the AUC measurement approaches 0.90, while in other domains with very long outcomes and/or difficult-to-capture risk factors, an AUC measurement of 0.60 to 0.70 is considered acceptable. The C statistic, which is also commonly reported in this literature, is also a measure of concordance and discrimination. For binary outcomes, the C statistic is identical to AUC.

Absolute risk estimation is also called calibration in the risk modeling literature, and it is a measure of risk prediction accuracy in individuals or small groups. This is most commonly measured by the Hosmer-Lemeshow goodness-of-fit test, which sorts and separates the cohort into 10 groups and compares the observed and expected number of outcomes in each subgroup (or bin).135 Each bin is evaluated with a chi-square test, and the chi-square value from each bin is added together and a P value is calculated. Although 10 bins are standard, a different number may be used. The chi-square value for P=0.05 for 10 bins (8 degrees of freedom) is 15.51. Chi-square values less than (and P values greater than) this are considered adequately calibrated and can be interpreted as a non-significant overall difference between observed and expected outcome event rates (after comparing each bin). A more coarse measurement of calibration is the O/E ratio, which compares the observed to expected number of outcomes for the entire cohort. An O/E ratio is only interpretable with confidence intervals. If 1.00 is within the confidence interval, then the O/E ratio is acceptable. However, it should be noted that underprediction in one portion of the risk spectrum and overprediction in another would show up as poor calibration if the cohort is split into 10 groups, but the model could appear to perform well judging by the O/E ratio.

### Model Performance Evaluation Methods Summary

Risk calculators provide a percent risk of an outcome over a set number of years, and both relative risk (discrimination) and absolute risk prediction (calibration) performance measurements can be calculated. O/E ratios are the crudest measurement of absolute risk performance, but can result in an acceptable performance, even when specific ranges of risk are overpredicted while others are underpredicted. The Hosmer-Lemeshow test is a more granular evaluation method which sorts all patients by predicted risk, divides them into 10 categories, evaluates the O/E ratio separately for each category, and sums up the chi-square error in each category to report an aggregate measurement. Absolute risk prediction performance is dependent on both the baseline outcome incidence and the contributions of risk from each risk factor in the source cohort.