# Introduction

## Importance of Predicting Risk of Cardiovascular Events

There have been a number of studies that show that medical treatment of cardiovascular risk factors reduces the occurrence of adverse cardiovascular outcomes.122-128 Because of the high incidence and cost of this disease, clinical practice guidelines target primary prevention, and recommend that providers evaluate patients for cardiac risk factors that may warrant medical treatment.3-7 However, previous research has shown that providers do not accurately estimate the risk of cardiovascular disease (CVD) events on their own.8-13 A number of multivariate risk prediction equations, derived from large prospective cohort studies or randomized trials, have been developed to estimate CVD risk in intervals ranging from 5 to 10 years.14-21 In order to make them more usable to busy clinicians, many of these risk models only require information from a patient's medical history and easily available laboratory tests, and have been adapted for interpretation through simplified charts or tables in paper or computer-based formats.3, 22

The most commonly used CVD risk prediction models in the United States are those based upon the Framingham cohort. These models were developed in a large prospective cohort of U.S. men and women aged 30 to 74 years, have been subsequently validated in multiple diverse populations, and discriminate well among those patients who will have a CVD event and those who will not.17, 20, 23-26 However, these models do not accurately predict the risk for some patients, such as those younger than age 30 years or older than age 65 years, Japanese American men, Hispanic men, or Native American women.23, 26, 129 In addition, they demonstrate reduced ability to predict accurately in patients with diabetes mellitus, severe hypertension, or left ventricular hypertrophy.129-131

Concern over diabetes as a risk factor for CVD escalated in the late 1990s as several studies were published showing highly elevated risk of CVD among patients with diabetes.27, 28 One of these was a landmark study by Haffner and colleagues that evaluated 1,373 patients without diabetes and 1,059 patients with diabetes among a Finnish cohort.28 This study found that the 7-year risk of myocardial infarction (MI) among asymptomatic patients was 3.5 percent in patients without diabetes and 20.2 percent in patients with diabetes. MI recurrence rates among those patients who had already experienced an MI were 18.8 percent in patients without diabetes and 45 percent in patients with diabetes. These studies informed the Adult Treatment Panel III (ATP-III) recommendation for diabetes to be considered as a coronary heart disease (CHD) risk equivalent, because the MI recurrence rates in patients without diabetes were similar to first MI rates in patients with diabetes.

However, there is a growing literature in this domain showing that model performance is highly dependent on how similar the source model cohort is to the cohort in which it is applied.17, 23 In addition, diabetes is a high-risk condition for CVD with a number of well-defined process measurements, such as hemoglobin A_1c_ and urine albumin, that have been shown to be predictive of organ damage and adverse outcomes.132, 133 Since these risk factors are not present in general CVD risk prediction models, absolute risk prediction performance among patients with diabetes could be poor. We performed a systematic review of CVD risk prediction tools in order to determine whether tools that include diabetes as a risk factor in a general CVD risk model were able to perform adequately compared to those that were developed for only patients with or without diabetes.

The aim of this systematic review is to summarize the current state of CVD risk models, with a focus on models for use in the U.S. patient population. In addition, performance of each of the available models in populations other than the source cohort is assessed, as well as a summarization of which models use which risk factors and the impact that recalibration and reclassification has had in the last few decades on these models. Finally, we address the specific question of whether it is appropriate to treat diabetes as a CVD equivalent or as an independent risk factor.

### Key Questions

The key questions for this report were:

- KQ1: Do any of the currently available tools for the prediction of cardiovascular risk in a North American population offer clear advantages in discriminatory power over the others in predicting incident CHD, cerebrovascular stroke (stratified by thrombotic or hemorrhagic type), or a combination of these two?
- KQ2a: Do tools that treat diabetes as a CVD or CHD outcome equivalent have different performance characteristics than those that use diabetes as an independent risk factor for those outcomes?
- KQ2b: Is the appropriateness of using diabetes as a coronary risk equivalent modified by the number of other cardiac risk factors that the individual has?

### Technical Expert Panel

Table 1 lists the individuals who served as technical experts, providing feedback on the search, inclusion/exclusion criteria, and scope of the project. In addition, Dr. Diana Petitti provided expert consultation, particularly on the goals, methods, and scope of the project.

Table 1 Technical Expert Panel

| Physician | Other clinician | Researcher | Consumer/Patient | End User
USPSTF
Michael L. LeFevre, MD, MSPH | X | | X | | X
Timothy Wilt, MD, MPH | X | | X | | X
Russell P. Harris, MD, MPH | X | | X | | X
Non-USPSTF
Lucila Ohno-Machado, MD, PhD | X | | X | | X
Michael Kattan, PhD | | | X | | X

## Uses of This Report

The report is intended to describe the breadth and state of the literature on cardiovascular risk prediction, with a particular focus on models and tools relevant to the U.S. population. In requesting this review, the U.S. Preventive Services Task Force (USPSTF) sought to determine whether a specific model or tool had better performance characteristics than others, and therefore might be most useful in primary care. Although the report was specifically designed to provide data to the USPSTF for their use in making recommendations, it is hoped that the report may also be useful to researchers working in the field of cardiovascular risk prediction, particularly in areas in which research is currently inadequate for making recommendations.